# Discussion

## General Conclusions

In this review, we found that obesity and overweight are common, are easy to screen for, can potentially pose a substantial health burden in this country, and can be addressed with a substantial array of therapies. These factors make this a significant clinical condition for clinicians in primary care settings like those addressed by the U.S. Preventive Services Task Force.

Data specific to the overweight population are very limited, but they suggest that counseling interventions may promote modest weight loss in overweight people (those with body mass index [BMI] of 25–29.9). Obese patients can achieve modest but clinically significant weight loss with counseling, for either diet or exercise, or both, with or without additional behavioral interventions to modify motivations, skills, and supports related to dietary or physical activity patterns.

In prior systematic reviews, counseling-based interventions of at least 1 year duration led to weight changes in the range of +1.9 kg to -10.6 kg. ^3,^ ^46,^ ^47^ In our updated searches of counseling efficacy, mean weight loss in counseled groups beyond that in control groups was as follows, depending on the intensity of the intervention: high intensity, 0 kg to 5.4 kg; moderate intensity, 0.25 kg to 3.5 kg; and low intensity, 0 kg to 2.7 kg. We defined intensity in terms of numbers of face-to-face encounters in the first 3 months of an intervention; moderate intensity was 3 such encounters and high (or low) was more (or fewer) than that. Importantly, these may be conservative estimates of counseling-based weight loss, as “control” groups frequently did receive some form of intervention.

Patients can achieve similar levels of weight loss with pharmacotherapy interventions. Prior review has noted that patients treated with either sibutramine or orlistat lose 3 kg to 4 kg beyond those treated with placebo. ^51^ Limited data suggest that appetite suppressants may be effective in the short term, but they have not been tested or approved for long-term use. In our updated searches for pharmacotherapy efficacy, the mean loss beyond placebo was between 3.2 kg and 5.5 kg. From 5% to 27% more of those treated with drugs (sibutramine or orlistat) achieved 10% weight loss than those treated with placebo, and 19% to 37% more of those with sibutramine achieved at least a 5% weight loss. Again, these figures may be conservative estimates of weight loss achieved with drugs because they do not reflect the effect of diet and exercise. Behavioral interventions should accompany pharmacotherapy use.

Finally, in a select group of patients, surgical options promoted large amounts of average weight loss (9.7–57.9 kg over 1–2 years). Generally, these are patients with extreme body mass index (BMI >40) or marked obesity (BMI >35) with associated health complications and failure to respond to other modalities in the past.

We arrived at all these findings through a variety of sources of evidence. Systematic reviews of primary literature comprising randomized controlled trials (RCTs) found counseling, behavioral, and pharmacotherapy efficacy similar to levels in more recent RCTs of fair to good quality. Our conclusions about surgical therapy are based upon RCTs comparing different types of banding techniques (open vs laparoscopic approaches, and different placements of laparoscopic techniques), a well-conducted nonrandomized comparison study, and dramatic results from cohort studies.

### Cross-cutting Findings and Future Research Issues

The literature on which this systematic review is based yielded some insights into more, or less, effective approaches, although some questions remain unanswered. Studies also had a variety of limitations. We note here some important additional conclusions, together with our assessment of significant future research that should be pursued.

#### Clarifying Benefits Over the Longer Term

Counseling-based interventions involving diet and exercise were consistently more effective in the setting of a behavioral component. Treating patients on an individual basis, as contrasted with using group interventions, appeared to be less important. Of note, many of the interventions evaluated here were not carried out in the health providers' office, and high-intensity programs may be difficult to incorporate into routine clinical practice. One option may be referral to intensive counseling and behavioral therapy programs. Another is to evaluate further the long-term efficacy of combining less intensive office-based counseling approaches with different delivery approaches for behavioral therapy such as video or internet-delivered adjuncts. Although evidence examining the role of behavioral interventions in coordination with pharmacotherapeutical approaches is limited, 1 sibutramine trial suggested that such an approach may provide substantial added benefit.

Thus, we would advocate for continued development and testing of counseling and behavioral interventions with better, and longer, follow-up, whether independently or as part of a multi-faceted approach that involved medications. Such multi-component studies might also add social components to standard counseling or behavioral therapies. In addition, we emphasize the need for investigators to invoke more conservative intention-to-treat analyses, rather than falling back on methods involving last-observation-carried-forward approaches. Finally, the efficacy of interventions to alter body fat distribution and clarification of health effects of purposeful reduction of central adiposity deserve more attention.

For non-surgical options, weight loss was evaluated with relatively short-term follow-up (at least 1 year for counseling trials and at least 6 months for drug trials). Longer follow-up seems to be associated with lesser weight loss. Both prolonged counseling- and pharmacotherapy-based interventions do appear to help maintain weight loss. Nonetheless, studies of longer-term interventions (over several years) have not been done. A key area of future research is to institute longer-term follow-up for benefits and harms, particularly for pharmaceutical interventions. In addition, we note that work on weight maintenance interventions (independent of investigations of weight loss) deserve attention (including long-term follow-up as well).

Although evidence does not conclusively show that reducing weight extends life, we can estimate the potential reduction in coronary heart disease (CHD) events from the effect of weight reduction on risk factors. For example, studies of weight loss from counseling and behavioral interventions find a reduction in systolic blood pressure of about 3 mm Hg and a reduction in total cholesterol of about 5% from a 7% reduction in weight. ^3^ Using the Framingham risk equation, and assuming that these reductions in blood pressure and cholesterol would be maintained for 10 years, we calculated that 1 CHD event would be avoided per 180 to 200 obese people age 50 with mildly elevated blood pressure (140 mm Hg) and total cholesterol (220 mg/dl) who were treated according to the protocol of the Diabetes Prevention Program intervention. ^79^

For patients with higher levels of BMI, combinations of interventions may be more effective than a single modality. Studies of long-term outcomes with ongoing counseling, behavioral, and pharmacologic therapies are needed, as already suggested, but some research emphasis needs to be directed at studies of multi-component interventions, especially those that draw on recent conceptualizations of the behavioral elements of such approaches.

In addition, we found very limited data regarding efficacy of treatment options for patients who are overweight but not obese (ie, BMI 25–29.9). In the interest of obesity prevention, this patient population deserves further attention. Among the obese, studies of surgery among patients with BMI levels lower than among patients who have been subjects of recent trials may be warranted.

#### Clarifying Harms and Risks

All modes of treatment appear to be reasonably safe. We uncovered no evidence documenting harms of the diet and/or exercise counseling or behavioral interventions. With respect to medications, sibutramine is sometimes associated with increased blood pressure (mean increase of up to 3.9 mm Hg), and orlistat causes gastrointestinal distress in 15% to 37% of people taking the drug. However, safety has been assessed in trials lasting, at most, 1 to 2 years; as noted, long-term adverse effects of pharmacotherapy are less well defined and ought to be clarified through studies with longer follow-up periods. Useful future research would entail developing and testing newer drugs that would pose even fewer side effects, especially medications that do not increase blood pressure.

Surgical options clearly involve the highest risk, but current surgical approaches have much lower complication rates than those of the past. Surgical procedures lead to mortality in less than 1% of patients in pooled samples; in up to 25% of patients, however, re-operation is necessary over 5 years.

#### Clarifying Benefits and Harms for Specific Populations

We were not able to assess the relative effectiveness of treatment options by sex or ethnicity. Investigations have tended to focus on women; including more men in these studies is desirable. In addition, most studies of health outcomes related to weight and of treatment efficacy have been carried out in people of European origin. Because certain ethnic groups have a disproportionate prevalence of obesity, including black populations, Mexican Americans, American Indians, and Alaska Natives, this area needs further attention. Limited evidence suggests that mortality risk is not as closely linked with body mass in African Americans as in European Americans. However, the prevalence of diabetes, hypertension, and heart disease is clearly disproportionate in black populations, suggesting that the elevated risk for these conditions in the presence of obesity that has been established in white samples is not specific to race. Further evaluation is needed to clarify these links.

#### Clarifying Costs and Cost-Effectiveness

At the outset of this work, we had intended to examine issues of costs and cost-effectiveness of screening and treatment options, as a means of understanding the financial ramifications of addressing this clinical problem in the face of its demonstrable financial impact on patients, health budgets, and the economy. In the end, constraints of time and resources and the paucity of new relevant literature meant that we did not pursue this question further. Moreover, we doubt the utility of pursuing cost or cost-effectiveness with respect to use of BMI as the screening tool; it is for all intents and purposes costless and is clearly the screening measure of choice for both clinical and research applications.

We note, however, that significant questions ought to be subjected to economic investigation, which could take several directions. First are questions of documenting better both direct and indirect costs of treatment for specific interventions within the 3 broad types of treatments we have dealt with in this review. Such data would enable researchers and policymakers to determine better, for example, the cost-effectiveness of different approaches for providing diet and exercise counseling, whether or not they are coupled with additional behavioral interventions. Obviously, the same is true for pharmaceutical interventions and surgical options. Second, and far more challenging, are questions of costs and relative cost-effectiveness of options across these 3 categories. Finally, understanding better the costs and cost-effectiveness of various options directed at special patient populations (eg, only overweight, obese, or extremely obese; populations defined by ethnic and cultural background) will be of important long-term benefit for policymaking at both the clinical and health plan levels.