# Methods

## Analytic Framework and Key Questions

### Analytic Framework

Using methods of the U.S. Preventive Services Task Force (USPSTF), ^50^ we developed an analytic framework (Figure 5) and 6 key questions (KQs) (Table 2) to guide the literature searches and analyses for this systematic evidence review (SER). The analytic framework begins with a population at risk (in this case, adults) and moves through screening to identification of individuals as either obese or overweight. Those so defined may receive one or more treatments that affect weight loss or maintenance of weight loss (the top intermediate outcomes) or glucose tolerance, blood pressure, or lipids (the bottom set of intermediate outcomes). The treatments include various counseling and behavioral interventions, medications, and surgery. The intermediate outcomes in turn may be related not only to each other but also to a set of health outcomes, here mortality and morbidity, mental health, physical functioning, or various other outcomes. One overarching relationship concerns a direct relationship between screening and health outcomes. In addition, the figure notes (the two ovals) our concerns with harms of both screening and treatment. Numbers in parentheses refer to our main key clinical questions.

Table 2. Screening for Obesity: Key Questions

(Overarching): Is there direct evidence that screening for obesity improves health outcomes?
What is the prevalence of overweight and obesity?
Is there a reliable and valid screening test?
Do any of the interventions below lead to sustained weight reduction or improved glucose tolerance, lipid status, or blood pressure:
Counseling and behavioral treatments?
Medications?
Surgery?
Do any of these interventions lead to improved health outcomes?
What are the harms of screening and treatment?

Figure 5. Analytic Framework: Screening and Interventions for Overweight and Obesity in Adults

### Key Questions

As noted in Table 2, the first KQ examined direct evidence connecting screening and reduced morbidity or mortality or other outcomes (marked 1 as in Figure 1). KQs 2 through 5 dealt with indirect evidence of the various relationships depicted in the figure.

KQ 2 concerned the prevalence of overweight and obesity in the population and KQ 3 concerned the accuracy of screening tests. KQ 4 examined the efficacy of 3 treatments for overweight and obesity (counseling and behavioral interventions, medications, and surgery) for sustained weight reduction and for improved measures of glucose tolerance, blood pressure, and lipid status; KQ 5 examined the impact of these interventions (perhaps mediated through weight reduction or improvement in glucose intolerance, blood pressure, and lipid levels) on the 4 sets of health outcomes. Finally, KQ 6 concerned the harms of screening and treatment.

## Literature Search Strategy and Synthesis

### Search Terms

We examined the critical literature reviewed in the 1996 Guide to Clinical Preventive Services from the USPSTF. ^2^ We also searched the MEDLINE database and Cochrane Library for reviews and relevant studies published in the English language between January 1, 1994, and February 2002, using search terms consistent with the inclusion criteria. All searches were constrained to human populations and English language.

### Inclusion and Exclusion Criteria

We developed inclusion and exclusion criteria for selecting the evidence relevant to answer the key questions. Table 3 documents the number of articles meeting these criteria for each key question, except KQ 3; because all relevant studies measured weight directly or by BMI, we did not conduct searches for KQ3. Articles were excluded that did not meet USPSTF criteria for at least “fair” quality. ^50^

Table 3. Screening for Obesity: Inclusion Criteria and Results of Searches

| Key Question | Inclusion Criteria* | Number of Articles Meeting Inclusion Criteria and Not in Prior Systematic Review^†^
1 | Efficacy of screening | RCT | 0
| | Mass screening
2 | Prevalence of overweight and obesity | Large U.S. population-based surveys | 1
4. – 5. | Efficacy of treatment for wt reduction or intermediate outcomes
| a. Counseling and behavioral treatment | Counseling and behavioral interventions:
| | - RCT (of fair or good quality) | 21
| | - Outcome: wt loss or BMI reduction; glucose tolerance, blood pressure, lipid disorders
| | - Duration: ≥ 1 yr
| | - BMI ≥ 25
| | - 12 mo follow-up
| b. Medications | Medications:
| | - RCT (of fair or good quality) | 10
| | - Outcome: wt loss or BMI reduction; glucose tolerance, blood pressure, lipid disorders
| | - Duration: ≥ 6 mos
| | - Population: generalizable to typical U.S. primary care population
| c. Surgery | Surgery:
| | - RCT ( of fair or good quality) | 2
| | - Outcome: wt loss or BMI reduction; glucose tolerance, blood pressure, lipid disorders
| | - Duration: ≥ 1 yr
| | - Cohort
| | - Initial BMI ≥ 25
| | - Surgical procedure
6 | Harms of screening and treatment | Same studies as efficacy of counseling/behavioral and medication interventions | 21 counseling
| | For surgery, same studies as efficacy plus multiple cohorts and one nonrandomized controlled trial | 10 medication
| | | 2 surgery

* BMI, body mass index; RCT, randomized controlled trial.

† Prior systematic reviews ^3,^ ^46,^ ^47,^ ^51^

## Article Review and Data Abstraction

We found 3 well-conducted, recent systematic reviews relevant to the issue of screening for obesity. ^3,^ ^46,^ ^47^ A fourth systematic review of good quality examined pharmacotherapy for obesity. ^51^ These studies are presented in Table 4, along with a comparison to our review. Inclusion criteria for prior reviews were based on USPSTF criteria for systematic review methods. ^50^ After checking studies from our searches against the studies in these reviews, we reviewed in detail only those studies that had not been included in at least 1 of the systematic reviews.

Table 4. Summary of Findings from Prior Systematic Reviews and Our Updated Searches of Obesity Treatment Efficacy*

Intervention Type | Evidence Source | Months of Follow-up | | RCTs | Treatments Compared to Control | Wt Change: Intervention Group (kg) | | Wt Change: Intervention Control (kg)
| | Range | Median | Number | Number | Range | Mean | Range | Mean
Counseling and behavioral therapy | NIH ^3^ | 12–60 | 12 | 29 | 54 | 8 to -21.6 | -5.7 | 1.9 to -8.8 | -3.3
| NHS ^47^ | 12–60 | 12 | 24 | 51 | 5.4 to -12.9 | -4.5 | 1.4 to -10.6 | -3.0
| CTFPHC ^46^ | 24–60 | 24 | 6 | 12 | 2.7 to -9.2 | -3.3 | -0.2 to -4.5 | -2.1
| Updated searches - 1 | 12–54 | 12 | 12 | 22 | 9.2 to -17 | -3.7 | 0.88 to -5.8 | -2.0
| Updated searches - 2 | 12–54 | 12 | 13 | 24 | 9.2 to -17.9 | -4.6 | 0.88 to -12.3 | -2.6
Pharmacotherapy (orlistat or sibutramine) | BMJ Clinical Evidence ^51^ | 0.5–24 | NA | 17^†^ | NR | NR | NR | -2.5 to -4.4 | NR
| Updated searches | 6–12 | 6 | 10 | 11 | -3.3 to -13.1 | -6.5 | -2.8 to -5.8 | -4.0
Surgery | NIH ^3^ | 12–48 | 24 | 5 | 7 | -9.7 to -159 | -76.0 | NA
| NHS ^47^ | 12–48 | 30 | 6 | 8 | -9.7 to -57.9 | -45.1 | NA
| CTFPHC ^46^ | 24–60 | 36 | 4 | 9 | -17 to -45.5 | -29.9 | NA
| Updated searches | 18-18 | 18 | 2 | 4 | -34 to <-46 | NA | NA

Note: CTFPHC, Canadian Task Force on Preventive Health Care; NA, data not available to do appropriate calculation; NHS, UK National Health Service; NIH, National Institute of Health; NR, not reported; RCT, randomized controlled trials.

* Data extracted from prior reviews' evidence tables reflect those RCTs that have at least 1 year of follow-up; the longest follow-up reported is shown. Only those counseling and pharmacotherapy trials that provided data on treatment effect with and without adjustment for control are included. Surgery data reflect only current procedures. Updates searches for counseling and behavioral therapy are shown without (number 1) and with (number 2) a trial combining alternative counseling strategies with pharmacotherapy. ^52^

† Data presented are for sibutramine (n = 7) and orlistat (n = 10) studies only.

At least 2 authors reviewed abstracts and articles to find those that met inclusion criteria. For these included studies, a primary reviewer then abstracted relevant information using standardized abstraction forms. Key data appear in the evidence tables in Appendix B. We graded the quality of all included articles according to USPSTF criteria. ^50^

## Preparation of this Systematic Evidence Review

The authors worked with 3 members of the USPSTF throughout the review (see Acknowledgments in Appendix A) and, during 2001 and early 2002, presented a work plan and interim reports to the full USPSTF. After Task Force feedback and any necessary revisions, we distributed a draft of this systematic review for broad-based external peer review, including experts in the field and relevant professional organizations and federal agencies. Following peer review, we revised the evidence report and presented it to the Task Force for it to use in making final recommendations on this topic.