# Appendix C. Descriptions of Intensive Counseling and Behavioral Intervention Studies

Appendix C: Descriptions of Intensive Counseling and Behavioral Intervention Studies

Study | Intervention | Intervention Setting | Intervention Delivery | Counseling and Behavioral Description
Stevens et al, 2001 ^69^ | Control | Not noted | Not noted | Usual care (details not noted)
| Wt loss only | Not noted | Dieticians or health educators | One individual counseling session, then 14 weekly group meetings, then 6 biweekly group meetings, then monthly group meetings. After 18 mos, alternative options were offered, including individual counseling and special group sessions focused on selected wt loss topics. Focus included self-directed behavior change, nutrition and physical activity education, and social support for making and maintaining behavior changes. Behavior change techniques included self-monitoring, setting explicit short-term goals, developing action plans to achieve those objectives, and alternative strategies for situations triggering problem eating. Dietary intervention focused on reduced calorie intake by less consumption of fat, sugar, and alcohol, with a minimum daily calorie intake of 1500 kcal for men and 1200 kcal for women, and moderate wt loss goals of no more than 0.9 kg per wk. Physical activity goal was for gradually increased activity to moderate-intensity activity (40%–55% of heart rate reserve) 30–45 mins per day, 4–5 days per wk. The primary exercise was brisk walking.
Diabetes Prevention Program, 2002 ^79^ | Standard lifestyle + placebo: | Not noted | Not noted | Written information and an annual 20–30 min individual session emphasizing importance of healthy lifestyles. Advice included encouragement to follow the Food Guide pyramid and the equivalent of a National Cholesterol Education Program Step I diet, reduce wt, and increase physical activity.
| Intensive lifestyle: | Not noted | Case managers | 16 session curriculum covering diet, exercise and behavior modification taught by case managers on a 1:1 basis in the first 24 wks. Flexible, culturally sensitive, and individualized. Subsequent individual (typically monthly) and group sessions with case managers to reinforce behavioral change.
Kuller et al, 2001 ^65^ | Assessment only | Large research clinic | Psychologists (PhD level) | Clinical assessment, with baseline health education pamphlet on reducing cardiovascular risk factors, and advice to quit smoking.
| Lifestyle intervention | Large research clinic | Psychologists (PhD level), nutritionists, exercise physiologists | Cognitive-behavioral program aimed at preventing rises in LDL cholesterol and wt gain, and increasing leisure-time activity. Intensive group program in the first 6 mos, then follow-up individual and group sessions from mos 6–54. Wt loss goal was 5–15 lbs, depending on baseline wt. Participants were asked to lower dietary fat intake and daily caloric intake. Lifestyle approach to increasing physical activity to 1000–1500 kcal expenditure weekly.
Tuomilehto et al, 2001 ^66^ | Control | Not noted | Not noted | General oral and written information about diet and exercise at baseline and at subsequent annual visits. 3-day food diary at baseline and at each annual visit.
| Intervention | Not noted | Nutritionist | Detailed advice about how to achieve their wt loss, diet, and exercise goals. Participants met with the nutritionist 7 times over the 1st yr, then every 3 mos. Dietary advice was tailored to each subject based on quarterly food diaries, and included behavioral modification tips. Also, participants received individual guidance on increasing their physical activity level. Endurance exercise (walking, jogging, swimming, aerobic ball games, or skiing) was recommended as a way of increasing aerobic capacity. Supervised, progressive, individualized circuit-type resistance training also offered for improving functional capacity and strength.
Fogelholm et al, 2000 ^74^ | Control (40 wk follow-up after 12-wk wt reduction program) | Not noted | Nutritionist (wt loss phase) | 12-wk wt reduction program (wk 1: low energy diet based on meal-exchange; wks 2–9 VLCD; wks 10–12: low energy diets), with weekly small groups (5–12 participants) instructing on diet, wt maintenance, relapse prevention. No increase in habitual exercise in the 40-wk follow-up.
| Walking program (4.2 MJ/wk target expenditure) following 12-wk wt reduction program | Not noted | Nutritionist (wt loss phase) exercise instructor (maintenance phase) | 12-wk wt reduction program as above. In maintenance program, each participant had a weekly walking time prescribed, and walked with a heart rate monitor. One weekly walking session was supervised. All subjects participated in weekly meetings in small groups throughout the maintenance program, conducted by an exercise instructor. Educational material was distributed monthly. Weekly homework included monitoring of high-risk situations for overeating. Problems in diet and prevention of relapse were discussed in the meetings.
| Walking program (8.4 MJ/wk target expenditure) following 12-wk wt reduction program. | Not noted | Nutritionist (wt loss phase) exercise instructor (maintenance phase) | 12 wk wt reduction program, then 40 wk walking wt maintenance program as described in the 4.2 MJ program above; only difference was increased targeted energy expenditure.
Jakicic et al, 1999 ^71^ | Short-bout exercise | Not noted | Nutritionists, exercise physiologists, behavioral therapists | Behavioral wt loss program: group treatment meetings of diminishing frequency (weekly in mos 1–6, biweekly in mos 7–12, monthly in wks 13–18). Meetings focused on behavioral strategies for modifying eating and exercise behaviors. Participants were instructed to reduce daily energy and fat intake. Caloric goal based on baseline wt, with goal of 0.45–0.9 kg loss per wk). Fat intake goal was 20% of total intake. Food diaries reviewed weekly, with feedback from interventionists.
| | | | Exercise: (same volume of exercise, all home based, in all 3 groups). Participants instructed to exercise 5 days/wk: initially 20 mins/day (wks 1–4), increasing to 40 mins/day by wk 9). Exercise was divided into multiple 10-min bouts performed at convenient times in the day.
| Long-bout exercise | Not noted | Nutritionists, exercise physiologists, behavioral therapists | Behavioral wt loss program as in the short-bout exercise arm.
| | | | Exercise: daily total exercise amounts as described in the short-bout Exercise arm. Exercise was to be performed in one long-bout.
| Short-bout exercise with equipment | Not noted | Nutritionists, exercise physiologists, behavioral therapists | Behavioral wt loss program as in the short-bout exercise arm.
| | | | Exercise: daily total exercise amounts as described in the short-bout exercise arm. Participants were provided with motorized home treadmills.
Jones et al, 1999 ^68^ | Control | Not noted | Study nurse | Participants were told that they should lose wt, but received no formal diet counseling or group support.
| Wt loss | Not noted | Registered dietician | Patients individually counseled within 10 days of randomization, and 2–4 wks later. Content focused on food selection and preparation, and wt reduction goals were established. No exercise advice. They also met in groups twice monthly for 3 mos, then every 3–6 mos.
Sbrocco et al, 1999 ^73^ | Behavioral choice treatment | Not noted | Clinical psychologist or clinical social worker (also a psychology graduate student) with extensive experience in the behavior treatment of obesity. Two inexperienced graduate students (psychology) were co-leaders. | 13 weekly 1.5 hr group sessions with 5–7 members per group. Participants received 2-wk meal plans and recipe booklets for a low fat (25%) diet: 1800 kcal/day. Diaries reviewed, with immediate feedback each session - including graphs of daily fat and calorie intake and a list of highest-fat foods and some alternatives. Participants encouraged to eat at a constant calorie level. Self-monitoring phased out before acute treatment ended. Participants were encouraged to complete a walking program 30 mins/day, 3 days/wk in a single bout. No formal exercise groups, but daily exercise logs.
| | | | State purpose: to stop dieting and to view eating as a choice; to expect slower wt loss than they had experienced in the past, but more permanent change. Health behavior including food choice, avoiding exercise, eating behaviors discussed as choices designed to achieve certain outcomes. Individuals taught to identify their choices and the outcomes controlling these choices - and to focus on learning to eat in a manner consistent with a reasonable eventual end-goal wt, rather than focusing on how quickly wt can be lost.
| Traditional behavioral treatment | Not noted | Clinical psychologist or clinical social worker (also a psychology graduate student) with extensive experience in the behavior treatment of obesity. Two inexperienced graduate students (psych) were co-leaders | Weekly group sessions, meal plans, recipes, food diaries, and exercise as above, but with 1200 kcal/day diet. Stated purpose: to promote a substantial wt loss and to help develop habits and strategies to maintain this loss. Standard behavioral wt management techniques (eg self-monitoring, stimulus control, and behavioral substitution) were taught. Participants were encouraged to avoid eating and purchasing high-calorie foods, to lose wt so they could then maintain these changes; they were taught to understand their reasons for eating and to engage in problem solving to determine other methods to respond to stress.
Ashley et al, 2001 ^80^ | Dietician-led lifestyle intervention | Not noted | Registered dietician | 26 1-hr sessions over 1 yr. Participants received instruction manuals that included lessons based on an established wt control program (LEARN). Diet included a low-calorie diet (1200 kcal/day, with ≤ 30% of calories from fat), using standard recommendations for food groups and portion sizes. Activity instruction included walking up to 10,000 steps per day, measured by a supplied pedometer. Self-monitoring of food intake and energy expenditure in diaries. Specific to this group, participants attended small (8–10) people classes led by a registered dietician. Classes were weekly for 3 mos, then biweekly for 3 mos then monthly for 4 mos. Diet was made up of conventional food items.
| Dietician-led lifestyle intervention with meal replacements | Not noted | Registered dietician | As in the traditional group above, instruction manuals for dieting, 1200 kcal/day diet, and exercise instructions with pedometer use and self-monitoring. Sessions with registered dietician as above. However, 2 of the 3 main meals were replaced with meal-replacement shakes or bars (reduced to 1 main meal if goal reached and maintained).
| Primary care office intervention with meal replacements | Physician office | Primary care physician (2/3 of visits) or Registered Nurse (1/3 of visits) | 26 biweekly 10–15 min individual sessions over 1 yr, with a focus of helping patients lose wt (although other related medical problems were also discussed). Diet prescription with meal replacements as in the “Dietician-led with meal replacement” plan above. During each visit, diet, behavior modification, and physical activity habits were reviewed, and questions answered about the diet instructions.
Wadden et al, 2001 ^52^ | Sibutramine alone | Not noted | Physician | Baseline meeting with a physician who described medication use and the importance of lifestyle modification. A balanced diet (1200–1500 kcal/day) was prescribed. Gradual increased exercise (typically walking) to 4–5 sessions per wk, each of 30–40 mins duration. Literature supporting these instructions was disseminated. Over the trial, patients had 10 brief (5–10 min) follow-up visits with the physician (wks 2, 4, 8, 12, 16, 20, 24, 32, 40, 52). No lifestyle counseling or instruction for self-monitoring of lifestyle change.
| Sibutramine plus lifestyle | Not noted | Physician (outcomes monitoring) doctoral-level psychologists (counseling) | Physician visits on same schedule as sibutramine alone group. Additionally, in the first 20 wks, they attended weekly psychologist-led group lifestyle modification sessions. They were prescribed the same diet and exercise goals as the drug-only group but were given behavioral strategies for achieving them, and asked to self-monitor food intake and physical activity for at least 16 wks. Behavioral topics discussed at weekly sessions included stimulus control, slowed rate of eating, social support and cognitive restructuring. During wks 24–52, sessions focused on skills for maintenance of wt loss.
| Sibutramine plus lifestyle plus diet | Not noted | Physician (outcomes monitoring) doctoral-level psychologists (counseling) | Identical intervention to the sibutramine plus lifestyle group, with the addition of the first 16 wks prescription of a 1000 kcal/day portion-controlled diet (4 servings/day of a liquid nutritional supplement with an evening balanced meal). After wk 16, gradual decreased consumption of liquid supplement, with 1200–1500 kcal/day diet of conventional food diet by wk 20 (similar to the patients in the other 2 arms).
Wing and Anglin, 1996 ^76^ | Behavior therapy with a LCD | Not noted | Multidisciplinary team (all white) | 1 yr of weekly sessions - including review of self-monitoring records, weighing, and a lecture/discussion on nutrition, behavioral techniques, or exercise. Topics included stimulus control, goal setting, and self-monitoring of diet and exercise. Participants encouraged to gradually increase activity until walking 2 miles/day, 5 days/wk. LCD (1000–1200 kcal/day), with <30% calories as fat.
| Behavior therapy with intermittent VLCD | Not noted | Multidisciplinary team (all white) | Counseling and behavioral therapy as above for diet and exercise. Intermittent VLCD in wks 1–12 and 24–36. During VLCD intervals, goal consumption of approximately 500 kcal/day, either as liquid formula or lean meat, fish, or fowl. After each VLCD, other foods gradually reintroduced until consumption of 1000–1200 kcal/day was reached.

* Information source: primarily published articles. In selected cases (Tuomilehto et al, Kuller et al) ^65^ additional information was obtained from study staff.

† Kcal/day, kilocalories/day; LCD, Low calorie diet; LDL, low-density lipoprotein; MJ/wk, megajoules per weekVLCD, Very low calorie diet.