# Appendix B. Counseling Intervention Descriptions

Appendix B: Counseling Intervention Descriptions

Author | Population Description | Intervention Description
Stevens et al, 2001 ^69^ | N: 1191 | 3 yr program for control vs intervention.
| 79% white, 18% black | Intervention: group meetings and individual counseling focused on dietary change, physical activity, and social support.
| 66% male
Jakicic et al, 1999 ^71^ | N: 148 | 3 treatment arms with varying exercise regimens. All participants were prescribed the same amount of exercise, and instructed to reduce daily energy and fat intake. All groups with weekly group meetings in mos 1–6, biweekly in mos 7–12, and monthly in mos 13–18 focusing on behavioral strategies for modifying diet and exercise.
| Race NR | LB: Long-bout exercise 5 d/wk: initially 20 min, up to 40 min/session by wk 9.
| 100% female | SB: Short-Bout exercise 5 d/wk: same daily duration but divided into 10 min bouts.
| | SBEQ: SB as above, but participants were provided with motorized treadmills.
Kuller et al, 2001 ^65^ | N: 535 | 5 yr cognitive-behavioral program: intervention vs control. Intensive group program × 6 mos then individual and group sessions from 6–54 mos.
| 92% white | Intervention participants were asked to lower dietary fat intake, saturated fat intake, and dietary cholesterol, for a modest wt loss goal of 5–15 lb, and to increase physical activity to 1000–1500 kcal/wk.
| 100% female
Bemelmans et al, 2000 ^81^ | N: 42 | Intensive group education on the Mediterranean diet vs distribution of leaflet with Dutch nutritional guidelines.
| Race NR | Intervention:0. 3 2 hr group meetings within the 1st 2-mos of the study, with a focus on education, establishment of a positive attitude, and improved skills in the preparation of Mediterranean diet food. Follow-up with an individualized letter about their adherence to Mediterranean nutritional guidelines.
| Intervention group, 37% male; Control group 49% male
Fogelholm et al, 2000 ^74^ | N: 82 | Diet alone vs diet plus 1 of 2 40-wk moderate-intensity walking training programs. Dietary component was a low-energy diet with weekly small-group meetings focusing on wt loss and maintenance strategies. All participants had weekly small group meetings throughout the maintenance programs.
| Race NR | 1^st^ PA Regimen: targeted to expend 4.2 MJ/wk.
| 100% female | 2^nd^ PA Regimen: targeted to expend 8.4 MJ/wk.
Jones et al, 1999 ^68^ | N: 102 | Intervention vs control.
| Intervention group: 63% white, 37% black; Control group: 57% white, 43% black | Intervention: dietary counseling regarding food selection, preparation, and goals. No exercise advice. Counseling repeated once in 2–4 wks. Also twice monthly group support sessions × 3 mos then every 3–6 mos. Control: advised to lose wt -- no formal dietary counseling or group support.
| Intervention group: 45% male; Control group 51% male
Sbrocco et al, 1999 ^73^ | N: 24 | Behavioral Choice Treatment (BCT) vs Traditional Behavioral Therapy (TBT). All participants attended 13 weekly 1.5 hour group sessions, then group sessions at 3 and 6 mos. All participants were given 2-wk meal plans (BCT = 1800 kcal/day, TBT = 1200 kcal/day) and recipe booklets, and encouraged to walk 30 mins, 3 days a wk.
| Race NR
| 100% female
Swinburn et al, 1999 ^70^ | N: 176 | Monthly small-group meetings aimed at identifying and reducing dietary fat, with counseling included goal setting, self-monitoring, and evaluation. Control group received standard dietary information for healthy eating (comorbidity-specific).
| Intervention group: 69% European, 12% Maori, 14% Pacific Islander, 4% other; Control group: 75% European, 7% Maori, 14% Pacific Islander, 3% other
| Intervention group: 65% male; Control group 79% female
Jeffery and French, 1997 ^75^ | N: 822 (228 men, 594 women) | Education alone, education plus a lottery incentive or control. Education included monthly newsletters and semi-annual classes on nutrition and exercise. Focus included weekly self-weighing, adequate fruit and vegetable intake, reduced intake of high-fat foods, moderate walking.
| Men were 94% white
| 27.7% male
Lindholm et al, 1995 ^77^ | N: 681 | Usual health advice vs usual advice plus 6 group sessions with a health care professional that included 5 videos of MI risk factors and discussion, practical advice for buying and cooking recommended foods, and information regarding local exercise facilities. The first 3 sessions were 90 mins and monthly. The 4th session lasted all day. 5th session at mo 12. 6th session 3–6 mos later. Usual health advice included instruction to reduce dietary fat, lose wt if necessary, exercise daily, stop smoking if appropriate. It was reinforced with a small pamphlet.
| Race NR
| 85% male
Imperial Cancer Research Fund OXCHECK Study Group, 1995^78^ | N: 4121 | General-practice-based nurse-run health check vs no check. Check included medical history, lifestyle questionnaire, dietary assessment, height, wt, blood pressure, cholesterol measurement, with scheduled follow-up for patients with multiple risk factors.
| Race NR
| 53% male
Tuomilehto et al, 2001 ^66^ | N: 522 | Diet plus physical activity counseling with behavioral therapy vs control. Intervention: 7 visits in 1st yr, then 4 times per yr (4 yr total). Control included basic counseling once a yr.
| Race NR
| 33% male
Wadden et al, 2001 ^52^ | N: 53 | Participants randomized to counseling adjuncts with sibutramine therapy, vs sibutramine therapy alone.
| Race NR | Sibutramine plus lifestyle intervention: weekly groups for 20 wks with daily record-keeping.
| 100% female | Sibutramine plus lifestyle intervention plus portion-controlled low-calorie diet.
Rothacker et al, 2001 ^67^ | N: 75 | Participants randomized to 1 of 2 1200 kcal/day diets: Low-calorie liquid supplement to replace at least 1 meal/day vs low energy-low-fat food diet. Both plans with similar carbohydrate, fat, and protein composition.
| Race NR
| 100% female
Wing and Anglin, 1996 ^76^ | N: 93 | Two different diets delivered with behavioral therapy. Behavioral therapy included weekly sessions led by a multidisciplinary team, with discussions of nutrition, behavioral techniques, and exercise.
| 80% white, 17% black, 2% other | 1^st^ diet: low-calorie (1000–1200 kcal/day)
| white: 25% male; black 34% male | 2^nd^ diet: alternating low-calorie diet and very-low-calorie diet VLCD (VLCD: 500 kcal/day in wks 1–12 and 24–36).
Leermakers et al, 1999 ^72^ | N: 66 | Participants randomized to 1 of 2 maintenance programs following 6 mos of wt loss. Maintenance program was either exercise-focused or wt-focused. Exercise-focused maintenance program: 6 mos of biweekly group sessions: supervised exercise, payment for meeting exercise goals, competitions and prizes, training in relapse prevention. Wt-focused maintenance program: 6 mos of biweekly group sessions with therapist-led discussion on the maintenance of wt loss, including factors that represented an obstacle to maintaining wt loss. All participants kept track of diet and physical activity.
| 94% white
| 20% male
Knowler et al, 2002 ^79^ (DPP) | N: 3234 | Participants randomized to 1 of 3 groups, receiving metformin therapy (850 mg bid), lifestyle modification, or placebo. Lifestyle modification group received high intensity counseling for diet and exercise, as well as behavioral therapy.
| 55% white
| 32% male
Ashley et al, 2001 ^80^ | N: 113 | Participants randomized to 1of 3 groups, Group A participated in 26 1-hr dietician-led group interventions over the course of 1 yr; Group B participated in 26 1-hr dietician-led group interventions over 1 yr and were given meal replacement; Group C received a 1 yr, 26 session (lasting 10–15 mins) program based in a primary care office, including a 1200 calorie diet incorporating meal replacements and walking.
| Race NR
| 100% female

* BCT, Behavioral Choice Treatment; Kcal/wk, kilocalories/week; MI, myocardial infarction; MJ, megajoule; N, number; NR, not reported; PA, physical activity; TBT, Traditional Behavioral Therapy; VLCD, very-low-calorie diet.