# Appendix A. Evidence Tables

## Glossaries

Codes for Evidence Table 1

Code or Abbreviation | Definition
Intervention Mode: Group | Group-based
Intervention Mode: Individual | Individual-based
Intervention Intensity: Low | <1 encounter/month (first 3 mos)
Intervention Intensity: Moderate | 1 encounter/month (first 3 mos)
Intervention Intensity: High | >1 encounter/month (first 3 mos)
Trial Type Loss | Weight loss
Trial Type Main | Maintenance of weight loss
Intervention Type: D | Diet
Intervention Type: E | Exercise
Intervention Type: B | Behavioral

Abbreviations for All Evidence Tables and Appendices

Code or Abbreviation | Definition
ASGB | Adjustable silicone gastric banding
approx | approximately
B | Behavior, behavioral therapy
bid | Twice a day
BMI | Body mass index
BP | Blood pressure
BPM | Beats per minute
BT | Behavioral therapy
CA | Cancer
CVD | Cardiovascular disease
D | Diet, dietary intervention
diff | Difference
dL | Deciliter
DM | Diabetes mellitus
dx | Diagnosis
E | Exercise, exercise intervention
Ed | Education
EGP | Esophagogastric placement
ETOH | Excess alcohol use
F | Female
FPG | Fasting plasma glucose
f/u | Follow-up
G | Group
GI | Gastrointestinal
HbA1c | Hemoglobin A1c
I | Individual
Int | Intervention
Kcal/d | Kilocalories/day
kg | Kilogram
L | Loss
LASGB | Laproscopic adjustable silicone gastric banding
lb | Pound
LCD | Low-calorie diet
LDL | Low-density lipoprotein
LOCF | Last observation carried forward analysis
M | Male, maintenance
m^2^ (or kg/m^2^) | Meters squared
MI | Myocardial infarction
MJ | Megajoule
mm | Millimeters
mmol/l | Millimoles per liter
mo | Month
n | Number
NR | Not reported
NS | Not significant
OASGB | Open adjustable silicone gastric banding
P | P-value
PA | Physical activity
PCP | Primary Care Provider
PE (or PE Ed) | Physical exercise (education)
qd | Once a day
RGP | Retrogastric placement
SES | Socio-economic status
s.e. | Standard error
Signif | Significant
tid | Three times a day
tit | Titrate
tx | Treatment
VLCD | Very-low-calorie diet
vs | Versus
wk | Week
w/o | Without
Wt | Weight
Yr | Year

Evidence Table 1. Randomized Controlled Trials of Counseling and Behavioral Interventions

Citation | Intervention Mode/Intensity | Trial Type | Intervention Type | Baseline Weight | Time Interval | Delta (Vs Control Unless Noted) | P Value | Loss to Follow-up | Quality Comments
Stevens et al, 2001 ^69^ | Group and individual/high | Loss and main | D/E/B | Mean BMI: | 18 mos | -2.7 kg | P ≤ 0.001 | 8% at 36 mos | Good
| | | | Men: 31 | 36 mos | -2.0 kg
| | | | Women: 31
Kuller et al, 2001 ^65^ | Group and individual/high | Loss and main | D/E/B | Mean BMI: 25 | 54 mos | -5.4 lb | P ≤ 0.001 | Overall, 5% loss at 54 mos | Good
Tuomilehto et al, 2001 ^66^ | Group/high | Loss | D/E/B | Mean BMI: 31 | 1 yr | -3.4 kg | P ≤ 0.001 | 8% loss | Good
| | | | | 2 yrs | -2.7 kg | P ≤ 0.001
| | | | | 1 yr | -30% with at least 5% wt reduction | P = 0.001
Fogelholm et al, 2000 ^74^ | Group/high | Loss and main | D/E/B | Mean BMI: 34 | 1 yr (12 wks L, 40 wks M) | 1st PA program: -2.7 kg | P = 0.06 (group diff) | Overall 10% loss | Fair
| | | | | 2 yrs | 2nd PA program: -2.6 kg | P = 0.07 (group diff)
| | | | | | 1st PA program: -3.8 kg
| | | | | | 2nd PA program: -0.5 kg
Diabetes Prevention Program, 2000 ^79^ | Group/individual high | Loss and main | D/E/B | Mean BMI: 34 | 2.8 yrs | -2.1 kg (metformin) | P ≤ 0.001 | Overall 7.5% dropout | Good
| | | | | | -5.6 kg (lifestyle) | | | minorities over-represented
| | | | | | -0.1 kg (placebo)
Jakicic et al, 1999 ^71^ | Group/high (diet individualized) | Loss | D/E/B | Wt: 20%–75% higher than ideal body wt | 18 mos | -3.7 kg (BT and short bouts of PA with (vs w/o) home equipment lost more wt) | P ≤ 0.05 | 22% dropout overall (13%–29% each group) | Fair
| | | | | | | NS difference other PA groups | | High dropout
Jones et al, 1999 ^68^ | Group and individual/High | Loss | D/B | Mean BMI: 34 | 6 mos | -1.4 kg | P = 0.05 | Overall 9% dropout | Fair
| | | | | 12, 18, 24, 30 mos | not reported | NS
Sbrocco et al, 1999 ^73^ | Group/high | Loss | D/E/B | Mean BMI: 33 | 12 mos | -5.76 kg (behavioral choice tx led to more wt loss than traditional BT) | P ≤ 0.01 | 17% loss (n = 2) | Fair
Wadden et al, 2001 ^52^ | Group/high | Loss | D/E/B | BMI: 36–39 | 1 yr | -7.3 kg: addition of lifestyle intervention to sibutramine | P ≤ 0.05 | 32% dropout (6/19) | Fair
| | | | | 1 yr | -12.8 kg: addition of lifestyle intervention + diet to sibutramine | P ≤ 0.05
Ashley et al, 2001 ^80^ | Group and individual/high | Loss | D/E/B | BMI: 25–35 | 1 yr | -3.7 kg: Addition of meal replacements | P ≤ 0.05 | 38% dropout (14/37) | Fair
| | | | | | -0.1 kg: Addition of meal replacements and intervention not taking place at primary care physicians office | Not reported | 32% dropout (12/38) | Less than 100 per group
| | | | | | | | 34% dropout (13/38)
Wing and Anglin, 1996 ^76^ | Group/high | Loss | D/E/B | Mean BMI: | 1 yr | Black (approx): -2 kg | Not reported | 19% dropout (19/93) | Fair
| | | | Black: 37 | | (BT + VLCD instead of LCD) | Not reported | | Results reported by race, not by intervention (graph only no variance data)
| | | | White: 38 | | White (approx): -4 kg
| | | | | | (BT + VLCD instead of LCD)
Lindholm et al, 1995 ^77^ | Group/moderate | Loss | D/E | Mean BMI: | 18 mos | -0.09 kg/m^2^ | NS | 6% dropout | Good
| | | | Int M: 27 | 18 mos | -0.25 kg | NS
| | | | Int F: 30
| | | | Control M: 27
| | | | Control F: 29
Swinburn et al, 1999 ^70^ | Group/moderate | Loss | B/E | Intervention: 84 kg | 12 mos | -3.5 kg | P ≤ 0.001 | 38% without full data | Fair, high dropout
| | | | Control: 85 kg
Jeffery and French, 1997 ^75^ | Group/low | Loss | D/E | Mean BMI: | 12 mos | [underlined: Men:] | [underlined: Men:] | 14% dropout | Good
| | | | Men: 28 | | Diet & PA Education: -1.22 lb | Both tx NS vs control
| | | | Women: 26–28 | | Diet & PA Ed + lottery: -1.73 lb | [underlined: Women:]
| | | | | | [underlined: Women:] | High-SES:
| | | | | | High-SES: | Both tx NS vs control
| | | | | | Diet & PA Education: -0.35 lb | Low-SES:
| | | | | | Diet & PE Ed. + lottery: -0.87 lb | Both tx NS vs control
| | | | | | Low-SES:
| | | | | | Diet & PA Education: 0.81 lb
| | | | | | Diet & PE Ed + lottery: 1.93 lb
Bemelmans et al, 2000 ^81^ | Group/low | Loss | D | Mean BMI: 30 | 52 wks | Men: 0.1kg/m^2^ | NS | Overall 8% dropout | Fair (but, non-randomized)
| | | | | | Women: 0 kg/m^2^ | NS | | Netherlands population
Leermakers et al, 1999 ^72^ | Group/high | Main | D/E/B | Mean BMI: 31 | 18 mos | -2.1 kg (less wt regain with wt-focused vs PA-focused program) | P ≤ 0.05 | 15% loss 1st 6 mos | Fair
| | | | | 18 mos | -36% (extra portion of wt loss maintained with wt-focused vs PA-focused program) | P ≤ 0.01 | 28% did not complete 18 mos | ITT used conservance assumptions that all dropouts returned to their baseline wt
Rothacker et al, 2001 ^67^ | Individual/low | Main | D | Mean BMI: 25 | 1 yr | -5 kg | P ≤ 0.001 | 17% loss | Fair
| | | | Meal replacement: 75 kg
| | | | Traditional food: 78 kg
OXCHECK Study Group, 1995 ^78^ | Individual/low | Loss | D | Not reported | 3 yrs | At f/u: those with health checks were 0.38 kg/m^2^ less than control patients | P ≤ 0.05 | 25% dropout | Fair

* B, behavior; BMI, body mass index; BT, behavioral therapy; D, diet; E, exercise; F, female; f/u, follow-up; Int, Intervention; L, loss; LCD, low-calorie diet; M, maintenance, male; m2, meters squared; NS, not significant; PA, physical activity; PE (or PE Ed), physical exercise (education); SES, socio-economic status; tx, treatment; VLCD, very-low-calorie diet; w/o, without; HbA1C, Hemoglobin A1c.

Evidence Table 2. Randomized Controlled Trials of Pharmacotherapy for Weight Loss: Sibutramine

Citation | Participants | | Intervention Drug, Frequency, Time | Results/Outcomes | | Quality Comments
| Number, Demographics | How Recruited | | Weight Loss | Adverse Effects
Fujioka, et al, 2000 ^84^ | N: 175 | Multi-center (16 centers in U.S.) | Sibutramine: tit up to 20 qd | Mean kg Change: | Sibutramine: | Fair
| Sibutramine: 89 | Recruitment method: unspecified | placebo | Sibutramine: -3.7 kg Placebo: -0.4 kg | Dropout rate: 29/89 | Very select population, high loss to f/u, adherence not reported
| Placebo: 86 | [underlined: Included:] | 24 wks | P < 0.5 | Dropout rate due to adverse event: 9/89
| [underlined: Female:] | Age: ≥ 18 | [underlined: Co-interventions:] | Freq 5% wt loss: | Placebo:
| Sibutramine: 38 | BMI: ≥ 27–40 | 250–500 kcal/d caloric deficit diet | Sibutramine: 26% | Dropout rate: 25/86
| Placebo: 44 | At least 1 unsuccessful attempt to lose wt by dieting | Individual dietary counseling | P < 0.001 | Dropout rate due to adverse event: 10/86
| [underlined: Male:] | Diabetes, with stable treatment by diet or a single oral agent | Interval clinical assessments and measurements of FPG performed | Freq 10% wt loss:
| Sibutramine: 51 | [underlined: Excluded:] | | Sibutramine: 4.8%
| Placebo: 42 | Patients with: serious cardiovascular disease, metabolic disease, history of drug or alcohol abuse, in need of anti-depressant agents | | P < 0.12
| [underlined: Age:] | Patients receiving medications to influence body wt
| Sibutramine: 53.5 yrs
| Placebo: 55 yrs
| [underlined: BMI:]
| Sibutramine: 34.1 (mean)
| Placebo: 33.8 (mean)
Gokcel et al, 2001 ^85^ | N: 60 | Baskent University Endocrinology and Metabolism Clinic | Sibutramine: 10 bid | Mean kg change: | Sibutramine: | Fair
| [underlined: Gender:] Female | Recruitment method: referred due to poor glucose control | placebo | Sibutramine: -3.9 kg Placebo: 0.36 kg | Dropout rate: 1/30 | Group change only
| [underlined: Age:] | [underlined: Included:] | 24 wks | P < 0.0001 | Dropout rate due to adverse event: 1/30 | Incomplete side-effect or adherence information
| Sibutramine: 46.93±1.62 | Patients with Type II Diabetes and HbA1c > 8, with maximum doses of metformin and sulfonylureas | [underlined: Co-interventions] | | Placebo: | Small study set in Turkey
| Placebo: 49.28±1.34 | [underlined: Excluded:] | Monthly clinic visits | | Dropout rate: 5/30
| [underlined: BMI:] | Pregnancy, uncontrolled hypertension, glaucoma | Physical exam at each visit | | Dropout due to adverse event: not reported
| Sibutramine: 39.3 (mean) | Patients receiving medications that may influence body wt | Initial dietary counseling
| Placebo: 37.4 (mean) | | maintenance diet
James et al, 2000 ^83^ | N: 467 | 8 European centers | Sibutramine: 10–20 qd | Mean kg change: | Sibutramine: | Fair
| Sibutramine: 352 | Recruitment method: not given | placebo | Sibutramine: -4 kg | Dropout rate: 148/352 | No dose titration, high dropout, many exclusion criteria
| Placebo: 115 | [underlined: Included:] | 80 wks | P < 0.001 | Dropout rate due to adverse event: 48/352
| [underlined: Female:] | BMI of 30–45 | [underlined: Co-interventions:] | | Adverse event rate: not reported per person
| Sibutramine: 294 | [underlined: Excluded:] | 600 kcal deficit diet (individualized) | | Placebo:
| Placebo: 96 | Recent wt change | | | Dropout rate: 58/115
| [underlined: Male:] | Many specified diseases including diabetes and hypertension | | | Dropout rate due to adverse event: 6/115
| Sibutramine: 58 | Drugs: anorectic; B-blockers; B-agonists | | | Adverse event rate: not reported per person
| Placebo: 19
| [underlined: Age:] 17–65 yr
| Sibutramine: 40.7 (mean)
| Placebo: 40.4 (mean)
| [underlined: BMI:]
| Sibutramine: 36.5 (mean)
| Placebo: 36.6 (mean)
Smith and Goulder, 2001 ^86^ | N: 485 | Primary care setting | Sibutramine: 10 qd | Mean kg change: | Sibutramine 10 mg: | Fair
| [underlined: Female:] | Recruitment Method: via PCPs | Sibutramine: 15 qd | Sibutramine: 10 qd: -4.4 kg | Dropout rate: 67/161 | Very high attrition, generally healthy group, LOCF
| Sibutramine 10 mg: 128 | [underlined: Included:] | lacebo | Placebo: -1.6 kg | Dropout rate due to adverse event: 2/161
| Sibutramine 15 mg: 131 | Healthy people | 52 wks | Sibutramine: 15 qd: -6.4 kg | Adverse event rate: 20/161
| Placebo: 131 | Age 18–65 | [underlined: Co-interventions:] | Placebo: -1.6 kg | Sibutramine 15 mg:
| [underlined: Male:] | BMI of 25–44 | Dietary advice | P < 0.01 | Dropout rate: 79/161
| Sibutramine 10 mg: 33 | [underlined: Excluded:] | | Freq 5% wt loss: | Dropout rate due to adverse event: 2/161
| Sibutramine 15 mg: 30 | Wt loss ≥ 3 kg last 3 mos | | Sibutramine 10 qd: 19% | Adverse event rate: 18/161
| Placebo: 32 | Obesity of endocrine origin | | Sibutramine 15 qd: 37% | Placebo:
| [underlined: Age:] 18–65 yr | Diabetes mellitus | | P < 0.01 | Dropout rate: 83/163
| Sibutramine 10 mg: 41.0 (mean) | Vital sign | | Freq 10% wt loss: | Dropout rate due to adverse event: 4/163
| Sibutramine 15 mg: 42.7 (mean) | Abnormalities | | Sibutramine 10 qd: 12% | Adverse event rate: 24/163
| Placebo: 41.9 (mean) | Patients receiving drugs altering body wt | | Sibutramine 15 qd: 27%
| [underlined: BMI:] | Inability to follow dietary advice | | P < 0.01
| Sibutramine 10 mg: 32.9 (mean)
| Sibutramine 15 mg: 32.7 (mean)
| Placebo: 32.4 (mean)
Wirth and Krause, 2001 ^87^ | N: 1,001 | 108 private practices and 3 hospital outpatient departments in Germany | Sibutramine: 15 qd (continuous) | Mean kg change: | Sibutramine (continuous): | Good
| Sibutramine (continuous): 405 | Recruitment method: unspecified | Sibutramine: 15 qd (intermittent) | Sibutramine (continuous): -3.8 kg | Dropout rate: 79/405
| Sibutramine (intermittent): 395 | [underlined: Included:] | placebo | Placebo: -0.2 kg. | Dropout rate due to adverse event: 25/405
| Placebo: 201 | Age: 18–65 yrs. | 44 wks | Sibutramine (intermittent): -3.3 kg | Adverse event rate: 303/405
| [underlined: Female:] | BMI: 30–40 | [underlined: Co-interventions:] | Placebo: -0.2 kg. | Sibutramine (intermittent):
| Sibutramine (continuous): 302 | At least 1 unsuccessful attempt to lose wt by dieting | Physician counseling for wt loss | P < 0.001 | Dropout rate: 80/395
| Sibutramine (intermittent): 311 | [underlined: Excluded:] | Written dietary information | Freq 5% wt loss: | Dropout rate due to adverse event: 13/395
| Placebo: 155 | Patients with: serious cardiovascular disease, metabolic disease, history of drug or alcohol abuse, in need of anti-depressant agents | Physical exams during interval visits | Sibutramine (continuous): 30% | Adverse event rate: 283/395
| [underlined: Male:] | Patients receiving medications to influence body wt | | Sibutramine (intermittent): 28% | Placebo:
| Sibutramine (continuous): 103 | | | P < 0.001 | Dropout rate: 55/201
| Sibutramine (intermittent): 84 | | | Freq 10% wt loss: | Dropout rate due to adverse event: 9/201
| Placebo: 46 | | | Sibutramine (continuous): 19% | Adverse event rate: 151/201
| [underlined: Age:] | | | Sibutramine (intermittent): 20%
| Sibutramine (continuous): 43.1 | | | P < 0.001
| Sibutramine (intermittent): 42.6
| Placebo: 44.0
| [underlined: BMI:]
| Sibutramine (continuous): 34.7 (mean)
| Sibutramine (intermittent): 34.9 (mean)
| Placebo: 35.0 (mean)
Dujovne et al, 2001 ^88^ | N: 222 | 13 study centers | Sibutramine: 20 mg qd | Mean kg change: | Sibutramine | Fair
| Sibutramine: 162 | [underlined: Included:] | placebo | Sibutramine: -4.9 | Dropout rate: 29.6%
| Placebo: 160 | BMI ≥ 27 | 24 wks | Placebo: -0.6 | Dropout rate due to adverse event: 9.9% | LOCF
| [underlined: Gender:] Female | TG ≥ 250 or ≤ 1000 mg/dL | [underlined: Co-interventions:] | P ≤ 0.05 | Dropout rate for hypertension: 0.6% | 30% dropout
| Sibutramine: 56% | HDL ≤ 45 women | Female:1500 kcal/d | BMI change: | Change in systolic blood pressure: +4 mm
| Placebo: 51% | ≤ 40 men | Male: 1800 kcal/d | Sibutramine: -1.7 | Change in diastolic blood pressure: 3.6 mm
| [underlined: Age:] | Only those with ≥ 75% compliance during run-in were enrolled | | Placebo: -0.2 | Change in pulse: +6.8 bpm
| Sibutramine: 45 | [underlined: Excluded:] | | P= not reported | Placebo:
| Placebo: 46 | Recent wt loss, ETOH, uncontrolled hypertension, h/o of medical condition affecting major organ system including DM, CVD, CA, signif psycho dysfunction, recent substance addiction | | Freq 5% wt loss: | Dropout rate: 33.8%
| [underlined: BMI:] | | | Sibutramine: 42% | Dropout rate due to adverse event: 6.9%
| Sibutramine: 35.1 | | | Placebo: 8% | Dropout rate for hypertension: 1.9%
| Placebo: 35.5 | | | P ≤ 0.05 | Change in systolic blood pressure: +2 mm (NS different vs drug arm)
| | | | Freq 10% wt loss: | Change in diastolic blood pressure: +1.0 mm (P < 0.05 vs drug arm)
| | | | Sibutramine: 12% | Change in pulse: +0.1 bpm (P < 0.05 vs drug arm)
| | | | Placebo: 3%
| | | | P ≤ 0.05

* BMI, body mass index; bid, twice a day; bpm, beats per minute; CA, cancer; CVD, cardiovascular disease; dL, deciliter; DM, diabetes mellitus; ETOH, excess alcohol use; FPG, fasting plasma glucose; f/u, follow-up; HbA1c, Hemoglobin A1c; h/o, history of; Kcal/d, kilocalories/day; LOCF, Last observation carried forward analysis; mm, millimeters; N, number; PCP, primary care provider; qd, once a day; signif, significant; tit, titrate.

Evidence Table 3. Randomized Controlled Trials of Pharmacotherapy for Weight Loss: Orlistat

| Participants | | | Results/Outcomes
Citation Design | Number, Demographics | How Recruited | Intervention Drug, Frequency, Time | Weight Loss | Adverse Effects | Quality Comments
Hill et al, 1999 ^90^ | N: 729 | 17 clinical research centers in the U.S. | Orlistat: 30 mg tid | Mean kg change: | Orlistat 30 mg: | Fair
| Orlistat 30 mg: 187 | Recruitment method: via PCPs | Orlistat: 60 mg tid | Orlistat 30 mg: +0.5 kg | Dropout rate: 47/187 | Gender differential not quantified
| Orlistat 60 mg: 173 | [underlined: Included:] | Orlistat: 120 mg tid | Orlistat 60 mg: -0.6 kg | Dropout rate due to adverse event: 17/187 | Very select patient population
| Orlistat 120 mg: 181 | Age: ≥ 18 yrs | placebo | Orlistat 120 mg: -1.8 kg | Orlistat 60 mg: | Race/ethnicity distributions differ among the 3 dosing regiments
| Placebo: 188 | BMI: 28–43 | 52 wks | P < 0.001 | Dropout rate: 40/173
| [underlined: Age:] | Obese subjects with ≥ 8% loss of body wt in 6-mo lead-in | [underlined: Co-interventions:] | | Dropout rate due to adverse event: 17/173
| Orlistat 30 mg: 46.8±0.8 | [underlined: Excluded:] | Clinic visits every 2 wks | | Orlistat 120 mg:
| Orlistat 60 mg: 46.1±0.7 | Significant medical disorders including hypertension and diabetes | Maintenance diet | | Dropout rate: 55/181
| Orlistat 120 mg: 45.9±0.7 | Patients receiving medications that may influence body wt | Dietary counseling | | Dropout rate due to adverse event: 27/181
| Placebo: 46.4±0.7 | | Encouraged to increase activity | | Placebo:
| [underlined: BMI:] | | Multi-vitamin | | Dropout rate: 50/188
| Orlistat 30 mg: 32.6 (mean) | | 4-session behavioral modification program in lead-in | | Dropout rate due to adverse event: 5/188
| Orlistat 60 mg: 32.9 (mean)
| Orlistat 120 mg: 32.8 (mean)
| Placebo: 32.8±0.2 (mean)
Muls et al, 2001 ^91^ | N: 294 | 19 centers in Belgium | Orlistat: 120 mg tid placebo | Mean kg change: | Orlistat: | Good
| Orlistat: 147 | | 24 wks | Orlistat: -4.66 | Dropout rate: 19/147
| Placebo: 147 (but 3 withdrew early) | | [underlined: Co-intervention:] | Placebo: -1.88 | Adverse event rate: 80% (P = 0.016 vs placebo)
| [underlined: Gender:] Female | | Hypocalorie diet | P ≤ 0.001 | Placebo:
| Orlistat: 82% | | | Mean % wt change: | Dropout rate: 20/147
| Placebo: 78% | | | (Not including run-in) | Adverse event rate: 67%
| [underlined: Mean age:] (range 18–70) | | | Orlistat: -5.3
| Orlistat: 50 | | | Placebo: -2.3
| Placebo: 48 | | | P ≤ 0.001
| [underlined: Mean BMI:] (range 27–40) | | | Freq 5% wt loss:
| Orlistat: 33 | | | Orlistat: 64%
| Placebo: 33 | | | Placebo: 39%
| | | | P = not reported
| | | | Freq 10% wt Loss:
| | | | Orlistat: 23%
| | | | Placebo: 13%
| | | | P = not reported
Rissanen et al, 2001 ^96^ | N: 55 | Healthy Finnish women | Orlistat: 120 mg tid | Mean kg change: | Dropout rate: 4/55 | Fair
| Orlistat: 25 | | placebo | Orlistat: -13 | Dropout and adverse event rates not reported by intervention status
| Placebo: 26 | | 12 mos | Placebo: -7.2
| Only 51 completed trial | | [underlined: Co-intervention:] | P = NS
| [underlined: Gender:] Female | | 600 Kcal deficit diet adjusted for actual body wt and daily activities
| [underlined: Mean age:] 44 (s.e. = 0.7)
| [underlined: Mean BMI:] 36.2 (s.e. = 0.5)
Karhunen et al, 2000 ^91^ | N: 72 (59 women, 13 men) | 2 centers (Kuopio and Helsinki) in Finland | Orlistat: 120 mg tid | Mean kg change: | No data | Fair
| [underlined: Age:] | [underlined: Recruitment method:] Occupational health care systems | placebo | Orlistat: -13.1 kg | | Group change only
| 43.4±6.0 y | [underlined: Included:] | (rerandomized after 1 yr) | Placebo: -8.6 kg | | No data on adverse effects
| [underlined: BMI:] | BMI of 30–43 | [underlined: Interventions:] | P = 0.007 | | No gender-breakdown by group
| 35.9±3.9 kg/m^2^ | Age ≥ 18 | Dietary advice
| | [underlined: Excluded:] | 0–52 wks (loss phase of 104 wk trial)
| | Many specified diseases including diabetes and uncontrolled hypertension
| | Eating disorders
Micic et al, 1999 ^92^ | N: 119 | Referent Yugoslav endocrinology centers | Orlistat: 120 tid | Mean kg change: | Orlistat: | Fair
| Orlistat 120 mg: 60 | Recruitment method: not mentioned | placebo | Orlistat: -10.75 kg | Dropout rate: 10/60 | Individual-based wt results only in terms of “gain” or “loss”
| Placebo: 59 | [underlined: Included:] | 24 wks | Placebo: -7.34 kg | Dropout rate due to adverse event: 1/60 | Yugoslavian population
| [underlined: Age:] 18–75 (range) | BMI ≥ 30 kg/m^2^ | [underlined: Co-interventions:] | P = 0.001 | Adverse event rate: 18/60 | Small study
| [underlined: BMI:] | Serum LDL cholesterol ≥ 4.2 mmol/l | Hypocaloric diet with dietary advice | | Placebo:
| Orlistat: 34.8 (mean) | If female, use of adequate contraception | Monthly MD visits | | Dropout rate: 10/59
| Placebo: 35.2 (mean) | [underlined: Excluded:] | | | Dropout rate due to adverse event: not reported
| | Total serum triglyccrides > 4.5 mmol/l | | | Adverse event rate: 7/59
| | Many specified diseases including diabetes
| | Patients receiving drugs altering body wt
Van Gaal et al, 1998 ^89^ | N: 613 | 14 centers in Austria, Belgium, Brazil, Finland, Germany, Italy, Sweden, Switzerland, United Kingdom | Orlistat: 30 tid | Mean kg change: | Orlistat 30 mg: | Fair
| Orlistat 30 mg: 122 | Recruitment method: not specified | Orlistat: 60 tid | Orlistat 30: -2% | Dropout rate: 29/122 | Multiple countries, adequate outcomes, but very select population, no race data
| Orlistat 60 mg: 123 | [underlined: Included:] | Orlistat: 120 tid | Orlistat 60: -2.3% | Dropout rate due to adverse event: 7/122
| Orlistat 120 mg: 120 | BMI of 28–43 | Orlistat: 240 tid | Orlistat 120: -3.3% | Adverse event rate: 79%
| Orlistat 240 mg: 117 | Good compliance in run-in | placebo | Orlistat 240: -2.8% | Orlistat 60 mg:
| Placebo: 123 | [underlined: Excluded:] | 52 wks | P ≤ 0.001 | Dropout rate: 29/124
| [underlined: Mean age:] | Wt loss > 4 kg last 3 mos | [underlined: Co-interventions:] | Frequency of 10% wt loss: | Dropout rate due to adverse event: 6/124
| 40–44 | Many specified diseases including diabetes and hypertension | Hypocaloric diet | Orlistat 30: 9% | Adverse event rate: 83%
| [underlined: Mean BMI:] | Patients receiving drugs altering body wt | Dietary advice from dietician | Orlistat 60: 9% | Orlistat 120 mg:
| 34–35 kg/m^-2^ | Pregnancy/lactation | | Orlistat 120: 18% | Dropout rate: 23/122
| | | | Orlistat 240: 19% | Dropout rate due to adverse event: 2/122
| | | | P = not reported | Adverse event rate: 84%
| | | | | Orlistat 240 mg:
| | | | | Dropout rate: 20/120
| | | | | Dropout rate due to adverse event: 3/120
| | | | | Adverse event rate: 87%
| | | | | Placebo:
| | | | | Dropout rate: 27/125
| | | | | Dropout rate due to adverse event 3/125
| | | | | Adverse event rate: 69%

* BMI, body mass index; BP, blood pressure; Kcal, kilocalories; kg/m2, meters squared; mmol/l, millimoles per liter; N, number; P, P-value; PCP, primary care provider; s.e., standard error; tid, three times daily.

Evidence Table 4. Randomized Controlled Trials of Pharmacotherapy for Weight Loss: Metformin

Citation Design | Participants | | Intervention Drug, Frequency, Time | Results/Outcomes | | Quality Comments
| Number, Demographics | How Recruited | | Weight Loss | Adverse Effects
Giugliano et al, 1993 ^95^ | N: 50 | 17 Clinical research centers in the U.S. | Metformin: 850 bid | Data in graph form | Not reported | Fair/good
| Metformin: 27 | Recruitment method: not reported | placebo | P = NS | | No information on the population involved
| Placebo: 23 | [underlined: Included] | 6 mos | | | BMI results graphed, without actual numbers
| [underlined: Female:] | DM on insulin, dx after age 40 | [underlined: Co-interventions:] | | | Small sample size
| Metformin: 17 | DM > 3 yrs | Patients seen on outpatient basis
| Placebo: 14 | Inadequate glucose control despite therapy oral > 1 yr | 1 mo interval visits
| [underlined: Male:] | [underlined: Excluded:] | Body wt and BP
| Metformin: 10 | Age > 70
| Placebo: 9 | Creatinine > 1.2
| [underlined: Age:] | Ischemic or wasting disease
| Metformin: 60 (mean) | Acute severe disease
| Placebo: 60.8 (mean)
| [underlined: BMI:]
| Metformin: 33 (mean)
| Placebo: 32.7 (mean)

* bid, twice a day; BP, blood pressure; DM, diabetes mellitus; dx, diagnosis, N, number; NS, not significant; P, P-value.

Evidence Table 5. Randomized Controlled Trials of Surgical Therapies for Obesity

Citation Design | Participants | | Intervention Time, Surgical Procedure | Results/Outcomes | | Quality Comments
| Number, Demographics | How Recruited | | Weight Loss | Adverse Effects
de Wit et al, 1999 ^97^ | N: 50 | Recruitment method: Gastroenterology Outpatient Clinic | 18 mos | Mean wt loss: | Readmissions: | Fair
Open vs Laparoscopic Adjustable Silicone Gastric Banding (ASGB) | Laparoscopic ASGB: 25 | [underlined: Included:] | Laparoscopic ASGB | Laparoscopic ASGB: 35 kg | LASGB: 6 | Group-data only
| Open ASGB: 25 | Obesity > 5 yrs with documented prior wt loss attempts | Open ASGB | Open ASGB: 34 kg | OASGB: 15 | No co-morbidity information
| [underlined: Sex ratio:](M/F) | BMI > 40 kg/m^2^ | | NS difference between groups, significant change | (NS) | No co-intervention information
| Laparoscopic ASGB: 8/17 | [underlined: Excluded:] | | (P < 0.05) both groups over time | Surgical complications:
| Open ASGB: 8/17 | Previous gastric surgeries | | | LASBG: 1
| [underlined: Age:] 18–55 yrs. | Large hiatal hernias | | | OASGB: 8
| [underlined: Mean BMI:] | Alcohol abuse | | | (NS)
| Laparoscopic ASGB: 51 | Pregnancy
| Open ASGB: 50 | Psychiatric disease/treatment
| | Hormonal or genetic obesity-related diseases
Weiner et al, 2001 ^98^ | N: 101 | Nordwest Hospital, Frankfurt, Germany | 18 mos | Mean wt loss: | Intra-operative complications: | Fair
Open vs Laparoscopic Adjustable Silicone Gastric Banding (ASGB) | RGP: 51 | [underlined: Included:] | Retrogastric placement | RGP: > 43 kg | RGP: 0 | No individual-based outcome data
| EGP: 50 | Patients who underwent a laproscopic ASGB between May 1996 and August 1999 at the Nordwest hospital | Esophagogastric placement | EGP: > 46 kg | EGP: 0 | No co-morbidity data
| [underlined: Sex: (Female/Male)] | | | | Post-operative complications: | No co-interventions specified
| RGP: 42/8 | | | | RGP: 0
| EGP: 44/7 | | | | EGP: 3
| [underlined: Mean Age:] | | | | Deaths: 0
| RGP: 35 (18–54) | | | | Hunger at 18 mo:
| EGP: 35 (19–52) | | | | RGP: 3
| [underlined: Mean BMI: (kg/m_2_)] | | | | EGP: 1
| RGP: 50 | | | | GI esophagitis at 18 mo:
| EGP: 49 | | | | RGP: 1
| | | | | EGP: 1

* ASGP, Adjustable Silicone Gastric Banding; BMI, body mass index; EGP, Esophagogastric placement; F, female; kg/m2, meters squared; LASGB, laproscopic adjustable silicone gastric banding; M, male; N, number; OASGB , open adjustable silicone gastric banding; PCP, Primary care provider; RGP, retrogastric placement.