# References

1 Moyer VA, U. S. Preventive Services Task Force. Vitamin, mineral, and multivitamin supplements for the primary prevention of cardiovascular disease and cancer: U.S. Preventive services Task Force recommendation statement. Ann Intern Med. 2014;160(8):558–64. PMID: 24566474. 10.7326/M14-0198 24566474
2 Fairfield KM. Vitamin supplementation in disease prevention. Seres D, ed. Waltham, MA: UpToDate. http://www.uptodate.com. Accessed December 7, 2018: 2020.
3 National Center for Complementary and Integrative Health, National Institutes of Health. Vitamins and Minerals. https://nccih.nih.gov/health/vitamins. Accessed: July 31, 2020.
4 U.S. Department of Agriculture and U.S. Department of Health and Human Services. Dietary Guidelines for Americans, 2020-2025. 9th Edition. December 2020. https://www.dietaryguidelines.gov/. Accessed: 2020.
5 National Institutes of Health Office of Dietary Supplements. Multivitamin/mineral Supplements: Fact Sheet for Health Professionals. https://ods.od.nih.gov/factsheets/MVMS-HealthProfessional/#en4. Accessed: 07/23/2020.
6 Huang HY, Caballero B, Chang S, . Multivitamin/mineral supplements and prevention of chronic disease. Evid Rep Technol Assess (Full Rep). 2006(139):1–117. PMID: 17764205.17764205
7 Institute of Medicine. Dietary reference intakes: the essential guide to nutrient requirements. Washington, DC: The National Academies Press: 2006.
8 National Institutes of Health Office of Dietary Supplements. Nutrient Recommendations: Dietary Reference Intakes (DRI). https://ods.od.nih.gov/health_information/dietary_reference_intakes.aspx. Accessed: July 31, 2020.
9 Manson JE, Bassuk SS. Vitamin and Mineral Supplements: What Clinicians Need to Know. JAMA. 2018;319(9):859–60. PMID: 29404568. 10.1001/jama.2017.21012 29404568
10 U.S. Food & Drug Administration. Dietary Supplement Products & Ingredients. https://www.fda.gov/food/dietary-supplements/dietary-supplement-products-ingredients. Accessed: 07/23/2020.
11 National Institutes of Health. Using Dietary Supplements Wisely. https://www.nccih.nih.gov/health/using-dietary-supplements-wisely. Accessed: 07/23/2020.
12 LeBlanc ES, Perrin N, Johnson JD, . Over-the-Counter and Compounded Vitamin D: Is Potency What We Expect? JAMA Internal Medicine. 2013;173(7):585–6. 10.1001/jamainternmed.2013.3812 23400578
13 Cowan AE, Jun S, Gahche JJ, . Dietary Supplement Use Differs by Socioeconomic and Health-Related Characteristics among U.S. Adults, NHANES 2011(-)2014. Nutrients. 2018;10(8). PMID: 30126136. 10.3390/nu10081114 30126136
14 Dickinson A, Blatman J, El-Dash N, . Consumer usage and reasons for using dietary supplements: report of a series of surveys. J Am Coll Nutr. 2014;33(2):176–82. 10.1080/07315724.2013.875423 24724775
15 Heron MP. Deaths: leading causes for 2017. 2019.
16 Murphy SL, Xu J, Kochanek KD, . Deaths: Final Data for 2018. Natl Vital Stat Rep. 2021;69(13):1–83.
17 Tsao CW, Aday AW, Almarzooq ZI, . Heart Disease and Stroke Statistics-2022 Update: A Report From the American Heart Association. Circulation. 2022;145(8):e153.e639. 10.1161/cir.0000000000001052 35078371
18 Benjamin EJ, Muntner P, Alonso A, . Heart Disease and Stroke Statistics-2019 Update: A Report From the American Heart Association. Circulation. 2019:CIR0000000000000659. PMID: 30700139. 10.1161/CIR.0000000000000659 30700139
19 National Center for Health Statistics. National Health Interview Survey, 2018. Public-use data file and documentation. http://www.cdc.gov/nchs/nhis/SHS/tables.htm. Accessed: July 23, 2020.
20 National Cancer Institute. Cancer Statistics. https://www.cancer.gov/about-cancer/understanding/statistics. Accessed: July 31, 2020.
21 National Cancer Institute. Cancer Stat Facts: Cancer of Any Site. https://seer.cancer.gov/statfacts/html/all.html. Accessed: July 23, 2020.
22 Henley SJ, Ward EM, Scott S, . Annual Report to the Nation on the Status of Cancer, Part I: National Cancer Statistics. Cancer. 2020;126:2225–49.32162336
23 National Cancer Institute. Risk Factors for Cancer. https://www.cancer.gov/about-cancer/causes-prevention/risk. Accessed: July 30, 2020.
24 Koene RJ, Prizment AE, Blaes A, . Shared Risk Factors in Cardiovascular Disease and Cancer. Circulation. 2016;133(11):1104–14. 10.1161/circulationaha.115.020406 26976915
25 Homocysteine and risk of ischemic heart disease and stroke: a meta-analysis. Jama. 2002;288(16):2015–22. 10.1001/jama.288.16.2015 12387654
26 Zhang D, Wen X, Wu W, . Elevated homocysteine level and folate deficiency associated with increased overall risk of carcinogenesis: meta-analysis of 83 case-control studies involving 35,758 individuals. PLoS ONE [Electronic Resource]. 2015;10(5):e0123423. PMID: 25985325. 10.1371/journal.pone.0123423 25985325
27 He Y, Li Y, Chen Y, . Homocysteine level and risk of different stroke types: a meta-analysis of prospective observational studies. Nutr Metab Cardiovasc Dis. 2014;24(11):1158–65. 10.1016/j.numecd.2014.05.011 24984821
28 Giovannucci E, Rimm EB, Ascherio A, . Alcohol, low-methionine--low-folate diets, and risk of colon cancer in men. J Natl Cancer Inst. 1995;87(4):265–73. 10.1093/jnci/87.4.265 7707417
29 Feinberg AP, Tycko B. The history of cancer epigenetics. Nat Rev Cancer. 2004;4(2):143–53. 10.1038/nrc1279 14732866
30 Betteridge DJ. What is oxidative stress? Metabolism. 2000;49(2 Suppl 1):3–8. PMID: 10693912. 10.1016/S0026-0495(00)80077-3 10693912
31 Allen RH, Stabler SP, Savage DG, . Metabolic abnormalities in cobalamin (vitamin B12) and folate deficiency. Faseb j. 1993;7(14):1344–53. 10.1096/fasebj.7.14.7901104 7901104
32 Scott JM. Folate and vitamin B12. Proc Nutr Soc. 1999;58(2):441–8. 10.1017/s0029665199000580 10466189
33 Traber MG. Vitamin E and K interactions--a 50-year-old problem. Nutrition reviews. 2008;66(11):624–9. 10.1111/j.1753-4887.2008.00123.x 19019024
34 Humphrey LL, Fu R, Rogers K, . Homocysteine level and coronary heart disease incidence: a systematic review and meta-analysis. Mayo Clin Proc. 2008;83(11):1203–12. 10.4065/83.11.1203 18990318
35 Goncalves A, Roi S, Nowicki M, . Fat-soluble vitamin intestinal absorption: absorption sites in the intestine and interactions for absorption. Food Chem. 2015;172:155–60. 10.1016/j.foodchem.2014.09.021 25442537
36 García-Casal MN, Layrisse M, Solano L, . Vitamin A and beta-carotene can improve nonheme iron absorption from rice, wheat and corn by humans. J Nutr. 1998;128(3):646–50. 10.1093/jn/128.3.646 9482776
37 Khazai N, Judd SE, Tangpricha V. Calcium and vitamin D: skeletal and extraskeletal health. Curr Rheumatol Rep. 2008;10(2):110–7. 10.1007/s11926-008-0020-y 18460265
38 Burton GW, Traber MG, Acuff RV, . Human plasma and tissue alpha-tocopherol concentrations in response to supplementation with deuterated natural and synthetic vitamin E. Am J Clin Nutr. 1998;67(4):669–84. 10.1093/ajcn/67.4.669 9537614
39 Colombo ML. An update on vitamin E, tocopherol and tocotrienol-perspectives. Molecules (Basel). 2010;15(4):2103–13. 10.3390/molecules15042103
40 Marra MV, Bailey RL. Position of the Academy of Nutrition and Dietetics: Micronutrient Supplementation. J Acad Nutr Diet. 2018;118(11):2162–73. PMID: 30366569. 10.1016/j.jand.2018.07.022 30366569
41 World Cancer Research Fund/American Institute for Cancer Research. Continuous Update Project Expert Report 2018. Recommendations and public health and policy implications. https://www.wcrf.org/sites/default/files/Recommendations.pdf. Accessed: July 31, 2020.
42 Kopecky SL, Bauer DC, Gulati M, . Lack of Evidence Linking Calcium With or Without Vitamin D Supplementation to Cardiovascular Disease in Generally Healthy Adults: A Clinical Guideline From the National Osteoporosis Foundation and the American Society for Preventive Cardiology. Ann Intern Med. 2016;[Epub ahead of print]. PMID: 27776362. 10.7326/m16-1743 27776362
43 American Heart Association. Vitamin Supplements: Hype or Help for Healthy Eating. https://www.heart.org/en/healthy-living/healthy-eating/eat-smart/nutrition-basics/vitamin-supplements-hype-or-help-for-healthy-eating. Accessed: July 31, 2020.
44 Canada Cancer Society. Nutrition and Fitness (Healthy Eating, Vitamin D). http://www.cancer.ca/en/prevention-and-screening/reduce-cancer-risk/make-healthy-choices/eat-well/should-i-take-a-vitamin-d-supplement/?region=on. Accessed: July 31, 2020.
45 Dickinson A, Bonci L, Boyon N, . Dietitians use and recommend dietary supplements: report of a survey. Nutr J. 2012;11:14. PMID: 22416673. 10.1186/1475-2891-11-14 22416673
46 Dickinson A, Boyon N, Shao A. Physicians and nurses use and recommend dietary supplements: report of a survey. Nutr J. 2009;8:29. PMID: 19570197. 10.1186/1475-2891-8-29 19570197
47 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force: 2015.
48 U.S. Preventive Services Task Force, Grossman DC, Curry SJ, . Vitamin D, Calcium, or Combined Supplementation for the Primary Prevention of Fractures in Community-Dwelling Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2018;319(15):1592–9. PMID: 29677309. 10.1001/jama.2018.3185 29677309
49 U.S. Preventive Services Task Force, Grossman DC, Curry SJ, . Interventions to Prevent Falls in Community-Dwelling Older Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2018;319(16):1696–704. PMID: 25419853. 10.1001/jama.2018.3097 29710141
50 US Preventive Services Task Force. Screening for Vitamin D Deficiency in Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2021;325(14):1436–42. 10.1001/jama.2021.3069 33847711
51 Patnode CD, Perdue LA, Rossom RC, . Screening for Cognitive Impairment in Older Adults: An Evidence Update for the U.S. Preventive Services Task Force. Rockville, MD: Agency for Healthcare Research and Quality; 2020. PMID.
52 U.S. Preventive Services Task Force. Folic Acid Supplementation for the Prevention of Neural Tube Defects: US Preventive Services Task Force Recommendation Statement. JAMA. 2017;317(2):183–9. 10.1001/jama.2016.19438 28097362
53 Fortmann SP, Burda BU, Senger CA, . Vitamin, Mineral, and Multivitamin Supplements for the Primary Prevention of Cardiovascular Disease and Cancer: A Systematic Evidence Review for the U.S. Preventive Services Task Force. 2013. PMID: 24308073.24308073
54 Moazzen S, Dolatkhah R, Tabrizi JS, . Folic acid intake and folate status and colorectal cancer risk: A systematic review and meta-analysis. Clinical Nutrition. 2018;37(6 Pt A):1926–34. PMID: 29132834. 10.1016/j.clnu.2017.10.010 29132834
55 Malihi Z, Wu Z, Mm Lawes C, . Noncalcemic adverse effects and withdrawals in randomized controlled trials of long-term vitamin D2 or D3 supplementation: a systematic review and meta-analysis. Nutrition reviews. 2017;75(12):1007–34. PMID: 29202186. 10.1093/nutrit/nux059 29202186
56 Khan SU, Khan MU, Riaz H, . Effects of Nutritional Supplements and Dietary Interventions on Cardiovascular Outcomes: An Umbrella Review and Evidence Map. Annals of Internal Medicine,. 2019. 10.7326/M19-0341
57 Jiang K, Tang K, Liu H, . Ascorbic Acid Supplements and Kidney Stones Incidence Among Men and Women: A systematic review and meta-analysis. Urology journal. 2019;16(2):115–20. PMID: 30178451. 10.22037/uj.v0i0.4275 30178451
58 Hamishehkar H, Ranjdoost F, Asgharian P, . Vitamins, Are They Safe? Adv. 2016;6(4):467–77. PMID: 28101454. 10.15171/apb.2016.061 28101454
59 Goulao B, Stewart F, Ford JA, . Cancer and vitamin D supplementation: a systematic review and meta-analysis. Am J Clin Nutr. 2018;107(4):652–63. PMID: 29635490. 10.1093/ajcn/nqx047 29635490
60 Chowdhury R, Kunutsor S, Vitezova A, . Vitamin D and risk of cause specific death: systematic review and meta-analysis of observational cohort and randomised intervention studies. BMJ. 2014;348:g1903. PMID: 24690623.24690623
61 Vinceti M, Filippini T, Del Giovane C, . Selenium for preventing cancer. Cochrane Database of Systematic Reviews. 2018;1:CD005195. PMID: 29376219. 10.1002/14651858.CD005195.pub4 29376219
62 United Nations Development Programme. Human Development Report 2016: Human Development Everyone. New York, NY: United Nations Development Programme; 2016.
63 Omenn GS, Goodman GE, Thornquist MD, . Effects of a combination of beta carotene and vitamin A on lung cancer and cardiovascular disease. N Engl J Med. 1996;334(18):1150–5. PMID: 8602180.8602180
64 Moon TE, Levine N, Cartmel B, . Effect of retinol in preventing squamous cell skin cancer in moderate-risk subjects: a randomized, double-blind, controlled trial. Southwest Skin Cancer Prevention Study Group. Cancer Epidemiol Biomarkers Prev. 1997;6(11):949–56. PMID: 9367069.9367069
65 Dean AJ, Bellgrove MA, Hall T, . Effects of vitamin D supplementation on cognitive and emotional functioning in young adults--a randomised controlled trial. PLoS ONE. 2011;6(11):e25966. PMID: 22073146. 10.1371/journal.pone.0025966 22073146
66 Kahwati LC, Weber RP, Pan H, . Vitamin D, Calcium, or Combined Supplementation for the Primary Prevention of Fractures in Community-Dwelling Adults: Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2018;319(15):1600–12. PMID: 29677308. 10.1001/jama.2017.21640 29677308
67 Morton SC, Murad MH, O’Connor E, . Quantitative synthesis—An update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews [Internet]: Agency for Healthcare Research and Quality (US); 2018.
68 Hartung J, Knapp G. A refined method for the meta-analysis of controlled clinical trials with binary outcome. Stat Med. 2001;20(24):3875–89.11782040
69 DerSimonian R, Kacker R. Random-effects model for meta-analysis of clinical trials: an update. Contemp Clin Trials. 2007;28(2):105–14. PMID: 16807131. 10.1016/j.cct.2006.04.004 16807131
70 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID.
71 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
72 Hercberg S, Galan P, Preziosi P, . The SU.VI.MAX Study: a randomized, placebo-controlled trial of the health effects of antioxidant vitamins and minerals. Arch Intern Med. 2004;164(21):2335–42. PMID: 15557412. 10.1001/archinte.164.21.2335 15557412
73 Green A, Williams G, Neale R, . Daily sunscreen application and betacarotene supplementation in prevention of basal-cell and squamous-cell carcinomas of the skin: a randomised controlled trial. Lancet. 1999;354(9180):723–9. PMID: 10475183.10475183
74 Lee IM, Cook NR, Gaziano JM, . Vitamin E in the primary prevention of cardiovascular disease and cancer: the Women’s Health Study: a randomized controlled trial. JAMA. 2005;294(1):56–65. PMID: 15998891.15998891
75 Hennekens CH, Buring JE, Manson JE, . Lack of effect of long-term supplementation with beta carotene on the incidence of malignant neoplasms and cardiovascular disease. N Engl J Med. 1996;334(18):1145–9. PMID: 8602179.8602179
76 The Alpha-Tocopherol Beta Carotene Cancer Prevention Study Group. The effect of vitamin E and beta carotene on the incidence of lung cancer and other cancers in male smokers. The Alpha-Tocopherol, Beta Carotene Cancer Prevention Study Group. N Engl J Med. 1994;330(15):1029–35. PMID: 8127329.8127329
77 Salonen JT, Nyyssonen K, Salonen R, . Antioxidant Supplementation in Atherosclerosis Prevention (ASAP) study: a randomized trial of the effect of vitamins E and C on 3-year progression of carotid atherosclerosis. J Intern Med. 2000;248(5):377–86. PMID: 11123502.11123502
78 Clark LC, Combs GF, Jr., Turnbull BW, . Effects of selenium supplementation for cancer prevention in patients with carcinoma of the skin. A randomized controlled trial. Nutritional Prevention of Cancer Study Group. JAMA. 1996;276(24):1957–63. PMID: 8971064. 10.1001/jama.1996.03540240035027 8971064
79 Wactawski-Wende J, Kotchen JM, Anderson GL, . Calcium plus vitamin D supplementation and the risk of colorectal cancer. N Engl J Med. 2006;354(7):684–96. PMID: 16481636.16481636
80 Lippman SM, Klein EA, Goodman PJ, . Effect of selenium and vitamin E on risk of prostate cancer and other cancers: the Selenium and Vitamin E Cancer Prevention Trial (SELECT). JAMA. 2009;301(1):39–51. PMID: 19066370.19066370
81 Sesso HD, Buring JE, Christen WG, . Vitamins E and C in the prevention of cardiovascular disease in men: the Physicians’ Health Study II randomized controlled trial. JAMA. 2008;300(18):2123–33. PMID: 18997197.18997197
82 Bolland MJ, Barber PA, Doughty RN, . Vascular events in healthy older women receiving calcium supplementation: randomised controlled trial. BMJ. 2008;336(7638):262–6. PMID: 18198394. 10.1136/bmj.39440.525752.BE 18198394
83 Lappe JM, Travers-Gustafson D, Davies KM, . Vitamin D and calcium supplementation reduces cancer risk: results of a randomized trial. Am J Clin Nutr. 2007;85(6):1586–91. PMID: 17556697. 10.1093/ajcn/85.6.1586 17556697
84 Cole BF, Baron JA, Sandler RS, . Folic acid for the prevention of colorectal adenomas: a randomized clinical trial. JAMA. 2007;297(21):2351–9. PMID: 17551129. 10.1001/jama.297.21.2351 17551129
85 Baron JA, Beach M, Wallace K, . Risk of prostate cancer in a randomized clinical trial of calcium supplementation. Cancer Epidemiol Biomarkers Prev. 2005;14(3):586–9. PMID: 15767334. 10.1158/1055-9965.EPI-04-0319 15767334
86 Chylack LT, Jr., Brown NP, Bron A, . The Roche European American Cataract Trial (REACT): a randomized clinical trial to investigate the efficacy of an oral antioxidant micronutrient mixture to slow progression of age-related cataract. Ophthalmic Epidemiol. 2002;9(1):49–80. PMID: 11815895. 10.1076/opep.9.1.49.1717 11815895
87 Greenberg ER, Baron JA, Stukel TA, . A clinical trial of beta carotene to prevent basal-cell and squamous-cell cancers of the skin. The Skin Cancer Prevention Study Group. N Engl J Med. 1990;323(12):789–95. PMID: 2202901.2202901
88 Trivedi DP, Doll R, Khaw KT. Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. BMJ. 2003;326(7387):469. PMID: 12609940.12609940
89 Avenell A, MacLennan GS, Jenkinson DJ, . Long-term follow-up for mortality and cancer in a randomized placebo-controlled trial of vitamin D(3) and/or calcium (RECORD trial). Journal of Clinical Endocrinology & Metabolism. 2012;97(2):614–22. PMID: 22112804. 10.1210/jc.2011-1309 22112804
90 Rayman MP, Blundell-Pound G, Pastor-Barriuso R, . A randomized trial of selenium supplementation and risk of type-2 diabetes, as assessed by plasma adiponectin. PLoS ONE. 2012;7(9):e45269. PMID: 23028897.23028897
91 Baron JA, Barry EL, Mott LA, . A Trial of Calcium and Vitamin D for the prevention of colorectal adenomas N Engl J Med. 2015;373(16):1519–30. PMID: 26465985. 10.1056/NEJMoa1500409 26465985
92 Scragg R, Stewart AW, Waayer D, . Effect of Monthly High-Dose Vitamin D Supplementation on Cardiovascular Disease in the Vitamin D Assessment Study: A Randomized Clinical Trial. JAMA Cardiol. 2017;2(6):608–16. PMID: 28384800. 10.1001/jamacardio.2017.0175 28384800
93 Lappe J, Watson P, Travers-Gustafson D, . Effect of Vitamin D and Calcium Supplementation on Cancer Incidence in Older Women: A Randomized Clinical Trial. JAMA. 2017;317(12):1234–43. PMID: 28350929. 10.1001/jama.2017.2115 28350929
94 Manson JE, Cook NR, Lee IM, . Vitamin D Supplements and Prevention of Cancer and Cardiovascular Disease. N Engl J Med. 2019;380(1):33–44. PMID: 30415629. 10.1056/NEJMoa1809944 30415629
95 Brisson J, Berube S, Diorio C, . A Randomized Double-Blind Placebo-Controlled Trial of the Effect of Vitamin D3 Supplementation on Breast Density in Premenopausal Women. Cancer Epidemiology, Biomarkers & Prevention. 2017;26(8):1233–41. PMID: 28515107. 10.1158/1055-9965.EPI-17-0249 28515107
96 Bonelli L, Puntoni M, Gatteschi B, . Antioxidant supplement and long-term reduction of recurrent adenomas of the large bowel. A double-blind randomized trial. J Gastroenterol. 2013;48(6):698–705. PMID: 23065023. 10.1007/s00535-012-0691-z 23065023
97 van Wijngaarden JP, Swart KM, Enneman AW, . Effect of daily vitamin B-12 and folic acid supplementation on fracture incidence in elderly individuals with an elevated plasma homocysteine concentration: B-PROOF, a randomized controlled trial. Am J Clin Nutr. 2014;100(6):1578–86. PMID: 25411293. 10.3945/ajcn.114.090043 25411293
98 Rayman MP, Winther KH, Pastor-Barriuso R, . Effect of long-term selenium supplementation on mortality: Results from a multiple-dose, randomised controlled trial. Free Radic Biol Med. 2018;127:46–54. PMID: 29454039. 10.1016/j.freeradbiomed.2018.02.015 29454039
99 Thompson PA, Ashbeck EL, Roe DJ, . Selenium Supplementation for Prevention of Colorectal Adenomas and Risk of Associated Type 2 Diabetes. Journal of the National Cancer Institute. 2016;108(12):12. PMID: 27530657. 10.1093/jnci/djw152 27530657
100 Witham MD, Ireland S, Houston JG, . Vitamin D therapy to reduce blood pressure and left ventricular hypertrophy in resistant hypertension: randomized, controlled trial. Hypertension. 2014;63(4):706–12. PMID: 24420547. 10.1161/HYPERTENSIONAHA.113.02177 24420547
101 Rucklidge JJ, Frampton CM, Gorman B, . Vitamin-mineral treatment of attention-deficit hyperactivity disorder in adults: double-blind randomised placebo-controlled trial. Br J Psychiatry. 2014;204:306–15. PMID: 24482441. 10.1192/bjp.bp.113.132126 24482441
102 Chen AC, Martin AJ, Choy B, . A phase 3 randomized trial of nicotinamide for skin-cancer chemoprevention. New England Journal of Medicine. 2015;373(17):1618–26. PMID: 26488693. 10.1056/NEJMoa1506197 26488693
103 Aloia J, Fazzari M, Islam S, . Vitamin D Supplementation in Elderly Black Women Does Not Prevent Bone Loss: a Randomized Controlled Trial. J Bone Miner Res. 2018;33(11):1916–22. PMID: 29905969. 10.1002/jbmr.3521 29905969
104 de Gaetano G, Collaborative Group of the Primary Prevention Project. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. 2001;357(9250):89–95. PMID: 11197445. 10.1016/s0140-6736(00)03539-x 11197445
105 Lewis JR, Calver J, Zhu K, . Calcium supplementation and the risks of atherosclerotic vascular disease in older women: results of a 5-year RCT and a 4.5-year follow-up. J Bone Miner Res. 2011;26(1):35–41. PMID: 20614474. 10.1002/jbmr.176 20614474
106 Reid IR, Ames R, Mason B, . Randomized controlled trial of calcium supplementation in healthy, nonosteoporotic, older men. Arch Intern Med. 2008;168(20):2276–82. PMID: 19001206. 10.1001/archinte.168.20.2276 19001206
107 Avenell A, Campbell MK, Cook JA, . Effect of multivitamin and multimineral supplements on morbidity from infections in older people (MAVIS trial): pragmatic, randomised, double blind, placebo controlled trial. BMJ. 2005;331(7512):324–9. PMID: 16081445. 10.1136/bmj.331.7512.324 16081445
108 Toss G, Magnusson P. Is a daily supplementation with 40 microgram vitamin D3 sufficient? A randomised controlled trial. European journal of nutrition. 2012;51(8):939–45. PMID: 22086300. 10.1007/s00394-011-0271-7 22086300
109 Logan RF, Grainge MJ, Shepherd VC, . Aspirin and folic acid for the prevention of recurrent colorectal adenomas. Gastroenterology. 2008;134(1):29–38. PMID: 18022173. 10.1053/j.gastro.2007.10.014 18022173
110 Wu K, Platz EA, Willett WC, . A randomized trial on folic acid supplementation and risk of recurrent colorectal adenoma. Am J Clin Nutr. 2009;90(6):1623–31. PMID: 19864409. 10.3945/ajcn.2009.28319 19864409
111 Dawson-Hughes B, Dallal GE, Krall EA, . Effect of vitamin D supplementation on wintertime and overall bone loss in healthy postmenopausal women. Ann Intern Med. 1991;115(7):505–12. PMID: 1883119. 10.7326/0003-4819-115-7-505 1883119
112 Lips P, Graafmans WC, Ooms ME, . Vitamin D supplementation and fracture incidence in elderly persons. A randomized, placebo-controlled clinical trial. Ann Intern Med. 1996;124(4):400–6. PMID: 8554248. 10.7326/0003-4819-124-4-199602150-00003 8554248
113 Komulainen M, Kroger H, Tuppurainen MT, . Prevention of femoral and lumbar bone loss with hormone replacement therapy and vitamin D3 in early postmenopausal women: a population-based 5-year randomized trial. J Clin Endocrinol Metab. 1999;84(2):546–52. PMID: 10022414. 10.1210/jcem.84.2.5496 10022414
114 Fedirko V, Bostick RM, Flanders WD, . Effects of vitamin D and calcium supplementation on markers of apoptosis in normal colon mucosa: a randomized, double-blind, placebo-controlled clinical trial. Cancer Prev Res (Phila). 2009;2(3):213–23. PMID: 19258546. 10.1158/1940-6207.CAPR-08-0157 19258546
115 Zittermann A, Frisch S, Berthold HK, . Vitamin D supplementation enhances the beneficial effects of weight loss on cardiovascular disease risk markers. Am J Clin Nutr. 2009;89(5):1321–7. PMID: 19321573. 10.3945/ajcn.2008.27004 19321573
116 Sanders KM, Stuart AL, Williamson EJ, . Annual high-dose oral vitamin D and falls and fractures in older women: a randomized controlled trial. JAMA. 2010;303(18):1815–22. PMID: 20460620. 10.1001/jama.2010.594 20460620
117 Glendenning P, Zhu K, Inderjeeth C, . Effects of three-monthly oral 150,000 IU cholecalciferol supplementation on falls, mobility, and muscle strength in older postmenopausal women: a randomized controlled trial. J Bone Miner Res. 2012;27(1):170–6. PMID: 21956713. 10.1002/jbmr.524 21956713
118 Kenny AM, Biskup B, Robbins B, . Effects of vitamin D supplementation on strength, physical function, and health perception in older, community-dwelling men. Journal of the American Geriatrics Society. 2003;51(12):1762–7. PMID: 14687355. 10.1046/j.1532-5415.2003.51561.x 14687355
119 Murdoch DR, Slow S, Chambers ST, . Effect of vitamin D3 supplementation on upper respiratory tract infections in healthy adults: the VIDARIS randomized controlled trial. JAMA. 2012;308(13):1333–9. PMID: 23032549. 10.1001/jama.2012.12505 23032549
120 Wood AD, Secombes KR, Thies F, . Vitamin D3 supplementation has no effect on conventional cardiovascular risk factors: a parallel-group, double-blind, placebo-controlled RCT. J Clin Endocrinol Metab. 2012;97(10):3557–68. PMID: 22865902. 10.1210/jc.2012-2126 22865902
121 Uusi-Rasi K, Patil R, Karinkanta S, . Exercise and vitamin D in fall prevention among older women: a randomized clinical trial. JAMA Intern Med. 2015;175(5):703–11. PMID: 25799402. 10.1001/jamainternmed.2015.0225 25799402
122 Grady D, Halloran B, Cummings S, . 1,25-Dihydroxyvitamin D3 and muscle strength in the elderly: a randomized controlled trial. J Clin Endocrinol Metab. 1991;73(5):1111–7. PMID: 1939527. 10.1210/jcem-73-5-1111 1939527
123 Pike J, Chandra RK. Effect of vitamin and trace element supplementation on immune indices in healthy elderly. International journal for vitamin and nutrition research Internationale Zeitschrift fur Vitamin- und Ernahrungsforschung Journal international de vitaminologie et de nutrition. 1995;65(2):117–21. PMID: 7591530.7591530
124 Dawson-Hughes B, Harris SS, Krall EA, . Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med. 1997;337(10):670–6. PMID: 9278463. 10.1056/NEJM199709043371003 9278463
125 Baeksgaard L, Andersen KP, Hyldstrup L. Calcium and vitamin D supplementation increases spinal BMD in healthy, postmenopausal women. Osteoporos Int. 1998;8(3):255–60. PMID: 9797910. 10.1007/s001980050062 9797910
126 Gallagher JC, Fowler SE, Detter JR, . Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab. 2001;86(8):3618–28. PMID: 11502787. 10.1210/jcem.86.8.7703 11502787
127 Hodis HN, Mack WJ, LaBree L, . Alpha-tocopherol supplementation in healthy individuals reduces low-density lipoprotein oxidation but not atherosclerosis: the Vitamin E Atherosclerosis Prevention Study (VEAPS). Circulation. 2002;106(12):1453–9. PMID: 12234947. 10.1161/01.cir.0000029092.99946.08 12234947
128 Cooper L, Clifton-Bligh PB, Nery ML, . Vitamin D supplementation and bone mineral density in early postmenopausal women. Am J Clin Nutr. 2003;77(5):1324–9. PMID: 12716689. 10.1093/ajcn/77.5.1324 12716689
129 Dukas L, Bischoff HA, Lindpaintner LS, . Alfacalcidol reduces the number of fallers in a community-dwelling elderly population with a minimum calcium intake of more than 500 mg daily. Journal of the American Geriatrics Society. 2004;52(2):230–6. PMID: 14728632. 10.1111/j.1532-5415.2004.52060.x 14728632
130 McNeil JJ, Robman L, Tikellis G, . Vitamin E supplementation and cataract: randomized controlled trial. Ophthalmology. 2004;111(1):75–84. PMID: 14711717. 10.1016/j.ophtha.2003.04.009 14711717
131 Aloia JF, Talwar SA, Pollack S, . A randomized controlled trial of vitamin D3 supplementation in African American women. Arch Intern Med. 2005;165(14):1618–23. PMID: 16043680. 10.1001/archinte.165.14.1618 16043680
132 Magliano D, McNeil J, Branley P, . The Melbourne Atherosclerosis Vitamin E Trial (MAVET): a study of high dose vitamin E in smokers. Eur J Cardiovasc Prev Rehabil. 2006;13(3):341–7. PMID: 16926662. 10.1097/01.hjr.0000219108.10167.46 16926662
133 Durga J, van Boxtel MP, Schouten EG, . Effect of 3-year folic acid supplementation on cognitive function in older adults in the FACIT trial: a randomised, double blind, controlled trial. Lancet. 2007;369(9557):208–16. PMID: 17240287. 10.1016/S0140-6736(07)60109-3 17240287
134 Clinical Trial of Nutritional Supplements, Age-Related Cataract Study G, Maraini G, . A randomized, double-masked, placebo-controlled clinical trial of multivitamin supplementation for age-related lens opacities. Clinical trial of nutritional supplements and age-related cataract report no. 3. Ophthalmology. 2008;115(4):599.607 e1. PMID: 18387406. 10.1016/j.ophtha.2008.01.005 18387406
135 Salovaara K, Tuppurainen M, Karkkainen M, . Effect of vitamin D(3) and calcium on fracture risk in 65- to 71-year-old women: a population-based 3-year randomized, controlled trial--the OSTPRE-FPS. J Bone Miner Res. 2010;25(7):1487–95. PMID: 20200964. 10.1002/jbmr.48 20200964
136 Pittas AG, Dawson-Hughes B, Sheehan P, . Vitamin D Supplementation and Prevention of Type 2 Diabetes. N Engl J Med. 2019. PMID: 31173679. 10.1056/NEJMoa1900906 31173679
137 Alonso A, Chen LY, Rudser KD, . Effect of Magnesium Supplementation on Circulating Biomarkers of Cardiovascular Disease. Nutrients. 2020;12(6):06. 10.3390/nu12061697
138 Hemilä H, Haukka J, Alho M, . Zinc acetate lozenges for the treatment of the common cold: A randomised controlled trial. BMJ Open. 2020;10(1). 10.1136/bmjopen-2019-031662
139 Rake C, Gilham C, Bukasa L, . High-dose oral vitamin d supplementation and mortality in people aged 65–84 years: The vidal cluster feasibility rct of open versus double-blind individual randomisation. Health Technology Assessment. 2020;24(10):1–53. 10.3310/hta24100
140 Bischoff-Ferrari HA, Vellas B, Rizzoli R, . Effect of Vitamin D Supplementation, Omega-3 Fatty Acid Supplementation, or a Strength-Training Exercise Program on Clinical Outcomes in Older Adults: The DO-HEALTH Randomized Clinical Trial. JAMA. 2020;324(18):1855–68. 10.1001/jama.2020.16909 33170239
141 Wood ME, Liu H, Storrick E, . The Influence of Vitamin D on Mammographic Density: Results from CALGB 70806 (Alliance) a Randomized Clinical Trial. Cancer Prev Res (Phila Pa). 2021;14(7):753–62. PMID: 33849913. 10.1158/1940-6207.CAPR-20-0581 33849913
142 Virtanen JK, Nurmi T, Aro A, . Vitamin D supplementation and prevention of cardiovascular disease and cancer in the Finnish Vitamin D Trial-a randomized controlled trial. Am J Clin Nutr. 2022;04:04. PMID: 34982819. 10.1093/ajcn/nqab419 34982819
143 Neale RE, Baxter C, Romero BD, . The D-Health Trial: a randomised controlled trial of the effect of vitamin D on mortality. The Lancet Diabetes & Endocrinology. 2022;10(2):120–8. PMID: 35026158. 10.1016/S2213-8587(21)00345-4 35026158
144 Schutten JC, Joris PJ, Minovic I, . Long-term magnesium supplementation improves glucocorticoid metabolism: A post-hoc analysis of an intervention trial. Clin Endocrinol (Oxf). 2021;94(2):150–7. PMID: 33030273. 10.1111/cen.14350 33030273
145 Coelho C, Witt SA, Ji H, . Zinc to treat tinnitus in the elderly: a randomized placebo controlled crossover trial. Otol Neurotol. 2013;34(6):1146–54. PMID: 23598691. 10.1097/MAO.0b013e31827e609e 23598691
146 Feskanich D, Singh V, Willett WC, . Vitamin A intake and hip fractures among postmenopausal women. JAMA. 2002;287(1):47–54. PMID: 11754708.11754708
147 Lim LS, Harnack LJ, Lazovich D, . Vitamin A intake and the risk of hip fracture in postmenopausal women: the Iowa Women’s Health Study. Osteoporos Int. 2004;15(7):552–9. PMID: 14760518.14760518
148 Zheng Selin J, Rautiainen S, Lindblad BE, . High-Dose Supplements of Vitamins C and E, Low-Dose Multivitamins, and the Risk of Age-related Cataract: A Population-based Prospective Cohort Study of Men. Am J Epidemiol. 2013;177(6):548–55. PMID: 23420353.23420353
149 Ferraro PM, Taylor EN, Gambaro G, . Vitamin D Intake and the Risk of Incident Kidney Stones. Journal of Urology. 2017;197(2):405–10. PMID: 27545576. 10.1016/j.juro.2016.08.084 27545576
150 Taylor EN, Stampfer MJ, Curhan GC. Dietary factors and the risk of incident kidney stones in men: new insights after 14 years of follow-up. J Am Soc Nephrol. 2004;15(12):3225–32. PMID: 15579526. 10.1097/01.ASN.0000146012.44570.20 15579526
151 Rautiainen S, Lindblad BE, Morgenstern R, . Vitamin C supplements and the risk of age-related cataract: a population-based prospective cohort study in women. Am J Clin Nutr. 2010;91(2):487–93. PMID: 19923367. 10.3945/ajcn.2009.28528 19923367
152 Sesso HD, Manson JE, Aragaki AK, . Effect of cocoa flavanol supplementation for prevention of cardiovascular disease events: The COSMOS randomized clinical trial. The American Journal of Clinical Nutrition. 2022. 10.1093/ajcn/nqac055
153 National Institutes of Health Office of Dietary Supplements. Vitamin A: Fact Sheet for Health Professionals. https://ods.od.nih.gov/factsheets/VitaminA-HealthProfessional/. Accessed: 2020.
154 Chasan-Taber L, Willett WC, Seddon JM, . A prospective study of vitamin supplement intake and cataract extraction among U.S. women. Epidemiology. 1999;10(6):679–84. PMID: 10535780.10535780
155 Manson JE, Bassuk SS, Buring JE, . Principal results of the VITamin D and OmegA-3 TriaL (VITAL) and updated meta-analyses of relevant vitamin D trials. Journal of Steroid Biochemistry & Molecular Biology. 2020;198:105522. 10.1016/j.jsbmb.2019.105522 31733345
156 Fischbach FT, Fischbach MA. Fischbach’s manual of laboratory and diagnostic tests: Wolters Kluwer; 2017.
157 van Dijk SC, Enneman AW, Swart KM, . Effects of 2-year vitamin B12 and folic acid supplementation in hyperhomocysteinemic elderly on arterial stiffness and cardiovascular outcomes within the B-PROOF trial. J Hypertens. 2015;33(9):1897.906; discussion 906. PMID: 26147383. 10.1097/HJH.0000000000000647 26147383
158 Figueiredo JC, Grau MV, Haile RW, . Folic acid and risk of prostate cancer: results from a randomized clinical trial. Journal of the National Cancer Institute. 2009;101(6):432–5. PMID: 19276452.19276452
159 Meyer HE, Willett WC, Fung TT, . Association of High Intakes of Vitamins B6 and B12 From Food and Supplements With Risk of Hip Fracture Among Postmenopausal Women in the Nurses’ Health Study. JAMA netw. 2019;2(5):e193591. PMID: 31074816. 10.1001/jamanetworkopen.2019.3591 31074816
160 Pfeiffer CM, Schleicher RL, Osterloh JD, . National Report on Biochemical Indicators of Diet and Nutrition in the US Population 1999-2002. The FASEB Journal. 2009;23:551.26–.26.
161 Jenkins DJA, Spence JD, Giovannucci EL, . Supplemental Vitamins and Minerals for CVD Prevention and Treatment. J Am Coll Cardiol. 2018;71(22):2570–84. PMID: 29852980. 10.1016/j.jacc.2018.04.020 29852980
162 Alexander DD, Weed DL, Chang ET, . A systematic review of multivitamin-multimineral use and cardiovascular disease and cancer incidence and total mortality. Journal of the American College of Nutrition. 2013;32(5):339–54. PMID: 24219377. 10.1080/07315724.2013.839909 24219377
163 Kim J, Choi J, Kwon SY, . Association of Multivitamin and Mineral Supplementation and Risk of Cardiovascular Disease: A Systematic Review and Meta-Analysis. Circ Cardiovasc Qual Outcomes. 2018;11(7):e004224. PMID: 29991644. 10.1161/CIRCOUTCOMES.117.004224 29991644
164 Allan GM, Cranston L, Lindblad A, . Vitamin D: A Narrative Review Examining the Evidence for Ten Beliefs. Journal of general internal medicine. 2016;31(7):780–91. PMID: 26951286. 10.1007/s11606-016-3645-y 26951286
165 Bjelakovic G, Gluud LL, Nikolova D, . Vitamin D supplementation for prevention of mortality in adults. Cochrane Database Syst Rev. 2014(1):CD007470. PMID: 24414552. 10.1002/14651858.CD007470.pub3 24414552
166 LeBlanc E, Chou R, Zakher B, . Agency for Healthcare Research and Quality (US). 2014:11. PMID: 25521000.25521000
167 Zhang Y, Fang F, Tang J, . Association between vitamin D supplementation and mortality: systematic review and meta-analysis. BMJ. 2019;366:l4673. PMID: 31405892. 10.1136/bmj.l4673 31405892
168 Moser MA, Chun OK. Vitamin C and Heart Health: A Review Based on Findings from Epidemiologic Studies. Int. 2016;17(8):12. PMID: 27529239. 10.3390/ijms17081328 27529239
169 Lee B, Oh SW, Myung SK. Efficacy of Vitamin C Supplements in Prevention of Cancer: A Meta-Analysis of Randomized Controlled Trials. Korean J Fam Med. 2015;36(6):278–85. PMID: 26634093. 10.4082/kjfm.2015.36.6.278 26634093
170 Chung M, Tang AM, Fu Z, . Calcium Intake and Cardiovascular Disease Risk: An Updated Systematic Review and Meta-analysis. Ann Intern Med. 2016. PMID: 27776363. 10.7326/m16-1165 27776363
171 Chen F, Du M, Blumberg JB, . Association Among Dietary Supplement Use, Nutrient Intake, and Mortality Among U.S. Adults: A Cohort Study. Annals of internal medicine. 2019;170(9):604–13. 10.7326/M18-2478 30959527
172 Asemi Z, Saneei P, Sabihi SS, . Total, dietary, and supplemental calcium intake and mortality from all-causes, cardiovascular disease, and cancer: A meta-analysis of observational studies. Nutr Metab Cardiovasc Dis. 2015;25(7):623–34. PMID: 25912278. 10.1016/j.numecd.2015.03.008 25912278
173 Zittermann A, Prokop S. The role of vitamin D for cardiovascular disease and overall mortality. Adv Exp Med Biol. 2014;810:106–19. PMID: 25207362.25207362
174 Cashman KD. A review of vitamin D status and CVD. Proceedings of the Nutrition Society. 2014;73(1):65–72. PMID: 24103845. 10.1017/S0029665113003595 24103845
175 Wei H, Jing H, Wei Q, . Associations of the risk of lung cancer with serum 25-hydroxyvitamin D level and dietary vitamin D intake: A dose-response PRISMA meta-analysis. Medicine (Baltimore). 2018;97(37):e12282. PMID: 30212966. 10.1097/MD.0000000000012282 30212966
176 Garland CF, Gorham ED. Dose-response of serum 25-hydroxyvitamin D in association with risk of colorectal cancer: A meta-analysis. Journal of Steroid Biochemistry & Molecular Biology. 2017;168:1–8. PMID: 27993551. 10.1016/j.jsbmb.2016.12.003 27993551
177 McCullough ML, Zoltick ES, Weinstein SJ, . Circulating Vitamin D and Colorectal Cancer Risk: An International Pooling Project of 17 Cohorts. Journal of the National Cancer Institute. 2019;111(2):158–69. PMID: 29912394. 10.1093/jnci/djy087 29912394
178 Lin G, Ning L, Gu D, . Examining the association of circulating 25-hydroxyvitamin D with kidney cancer risk: a meta-analysis. Int J Clin Exp Med. 2015;8(11):20499–507. PMID: 26884966.26884966
179 Liu J, Dong Y, Lu C, . Meta-analysis of the correlation between vitamin D and lung cancer risk and outcomes. Oncotarget. 2017;8(46):81040–51. PMID: 29113365. 10.18632/oncotarget.18766 29113365
180 Tanvetyanon T, Bepler G. Beta-carotene in multivitamins and the possible risk of lung cancer among smokers versus former smokers: a meta-analysis and evaluation of national brands. Cancer. 2008;113(1):150–7. 10.1002/cncr.23527 18429004
181 Malila N, Virtamo J, Virtanen M, . The effect of alpha-tocopherol and beta-carotene supplementation on colorectal adenomas in middle-aged male smokers. Cancer Epidemiol Biomarkers Prev. 1999;8(6):489–93.10385137
182 Schwingshackl L, Boeing H, Stelmach-Mardas M, . Dietary Supplements and Risk of Cause-Specific Death, Cardiovascular Disease, and Cancer: A Systematic Review and Meta-Analysis of Primary Prevention Trials. Adv Nutr. 2017;8(1):27–39. PMID: 28096125. 10.3945/an.116.013516 28096125
183 Dong H, Pi F, Ding Z, . Efficacy of Supplementation with B Vitamins for Stroke Prevention: A Network Meta-Analysis of Randomized Controlled Trials. PLoS ONE [Electronic Resource]. 2015;10(9):e0137533. PMID: 26355679. 10.1371/journal.pone.0137533 26355679
184 Vollset SE, Clarke R, Lewington S, . Effects of folic acid supplementation on overall and site-specific cancer incidence during the randomised trials: meta-analyses of data on 50,000 individuals. Lancet. 2013;381(9871):1029–36. PMID: 23352552.23352552
185 Jenkins DJA, Spence JD, Giovannucci EL, . Supplemental Vitamins and Minerals for Cardiovascular Disease Prevention and Treatment: JACC Focus Seminar. Journal of the American College of Cardiology. 2021;77(4):423–36. PMID: 33509399. 10.1016/j.jacc.2020.09.619 33509399
186 Price AJ, Travis RC, Appleby PN, . Circulating Folate and Vitamin B(12) and Risk of Prostate Cancer: A Collaborative Analysis of Individual Participant Data from Six Cohorts Including 6875 Cases and 8104 Controls. Eur Urol. 2016;70(6):941–51. 10.1016/j.eururo.2016.03.029 27061263
187 Wang R, Zheng Y, Huang JY, . Folate intake, serum folate levels, and prostate cancer risk: a meta-analysis of prospective studies. BMC Public Health. 2014;14:1326. PMID: 25543518. 10.1186/1471-2458-14-1326 25543518
188 Garg A, Sharma A, Krishnamoorthy P, . Role of Niacin in Current Clinical Practice: A Systematic Review. American Journal of Medicine. 2017;130(2):173–87. PMID: 27793642. 10.1016/j.amjmed.2016.07.038 27793642
189 Schandelmaier S, Briel M, Saccilotto R, . Niacin for primary and secondary prevention of cardiovascular events. Cochrane Database of Systematic Reviews. 2017;6:CD009744. PMID: 28616955. 10.1002/14651858.CD009744.pub2 28616955
190 Keene D, Price C, Shun-Shin MJ, . Effect on cardiovascular risk of high density lipoprotein targeted drug treatments niacin, fibrates, and CETP inhibitors: meta-analysis of randomised controlled trials including 117,411 patients. BMJ. 2014;349:g4379. PMID: 25038074. 10.1136/bmj.g4379 25038074
191 Rees K, Hartley L, Day C, . Selenium supplementation for the primary prevention of cardiovascular disease. Cochrane Database of Systematic Reviews. 2013. PMID: 23440843.23440843
192 Vinceti M, Filippini T, Rothman KJ. Selenium exposure and the risk of type 2 diabetes: a systematic review and meta-analysis. Eur J Epidemiol. 2018;33(9):789–810. PMID: 29974401. 10.1007/s10654-018-0422-8 29974401
193 Viswanathan M, Treiman KA, Doto JK, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Folic Acid Supplementation: An Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2017.
194 Parva NR, Tadepalli S, Singh P, . Prevalence of Vitamin D Deficiency and Associated Risk Factors in the US Population (2011-2012). Cureus. 2018;10(6):e2741. 10.7759/cureus.2741 30087817
195 Weishaar T, Rajan S, Keller B. Probability of Vitamin D Deficiency by Body Weight and Race/Ethnicity. J Am Board Fam Med. 2016;29(2):226–32. 10.3122/jabfm.2016.02.150251 26957379
196 Shoenfeld N, Amital H, Shoenfeld Y. The effect of melanism and vitamin D synthesis on the incidence of autoimmune disease. Nature Clinical Practice Rheumatology. 2009;5(2):99–105. 10.1038/ncprheum0989
197 Food and Nutrition Board IoM. Dietary reference intakes for vitamin A, vitamin K, arsenic, boron, chromium, copper, iodine, iron, manganese, molybdenum, nickel, silicon, vanadium, and zinc. National Academy of Medicine. 2001.
198 Ashor AW, Brown R, Keenan PD, . Limited evidence for a beneficial effect of vitamin C supplementation on biomarkers of cardiovascular diseases: an umbrella review of systematic reviews and meta-analyses. Nutr Res. 2019;61:1–12. PMID: 30683434. 10.1016/j.nutres.2018.08.005 30683434
199 Juraschek SP, Guallar E, Appel LJ, . Effects of vitamin C supplementation on blood pressure: a meta-analysis of randomized controlled trials. Am J Clin Nutr. 2012;95(5):1079–88. 10.3945/ajcn.111.027995 22492364
200 Zhang X, Li Y, Del Gobbo LC, . Effects of Magnesium Supplementation on Blood Pressure: A Meta-Analysis of Randomized Double-Blind Placebo-Controlled Trials. Hypertension. 2016;68(2):324–33. PMID: 27402922. 10.1161/HYPERTENSIONAHA.116.07664 27402922
201 Verma H, Garg R. Effect of magnesium supplementation on type 2 diabetes associated cardiovascular risk factors: a systematic review and meta-analysis. Journal of Human Nutrition & Dietetics. 2017;30(5):621–33. PMID: 28150351. 10.1111/jhn.12454 28150351
202 Cormick G, Ciapponi A, Cafferata ML, . Calcium supplementation for prevention of primary hypertension. Cochrane Database of Systematic Reviews. 2015(6):CD010037. PMID: 26126003. 10.1002/14651858.CD010037.pub2 26126003
203 Li K, Liu C, Kuang X, . Effects of Multivitamin and Multimineral Supplementation on Blood Pressure: A Meta-Analysis of 12 Randomized Controlled Trials. Nutrients. 2018;10(8):03. PMID: 30081527. 10.3390/nu10081018 30081527
204 Beveridge LA, Struthers AD, Khan F, . Effect of Vitamin D Supplementation on Blood Pressure: A Systematic Review and Meta-analysis Incorporating Individual Patient Data. JAMA InternMed. 2015;175(5):745–54. PMID: 25775274.25775274
205 Swart KM, Lips P, Brouwer IA, . Effects of vitamin D supplementation on markers for cardiovascular disease and type 2 diabetes: an individual participant data meta-analysis of randomized controlled trials. Am J Clin Nutr. 2018;107(6):1043–53. PMID: 29868916. 10.1093/ajcn/nqy078 29868916
206 Zhang D, Cheng C, Wang Y, . Effect of Vitamin D on Blood Pressure and Hypertension in the General Population: An Update Meta-Analysis of Cohort Studies and Randomized Controlled Trials. Prev Chronic Dis. 2020;17:E03. 10.5888/pcd17.190307 31922371
207 Golzarand M, Shab-Bidar S, Koochakpoor G, . Effect of vitamin D3 supplementation on blood pressure in adults: An updated meta-analysis. Nutr Metab Cardiovasc Dis. 2016;26(8):663–73. PMID: 27287826. 10.1016/j.numecd.2016.04.011 27287826
208 Wu L, Sun D. Effects of calcium plus vitamin D supplementation on blood pressure: a systematic review and meta-analysis of randomized controlled trials. J Hum Hypertens. 2017;31(9):547–54. PMID: 28230063. 10.1038/jhh.2017.12 28230063
209 Zhang D, Cheng C, Wang Y, . Effect of Vitamin D on Blood Pressure and Hypertension in the General Population: An Update Meta-Analysis of Cohort Studies and Randomized Controlled Trials. Preventing Chronic Disease. 2020;17:E03. 10.5888/pcd17.190307 31922371
210 Mirhosseini N, Rainsbury J, Kimball SM. Vitamin D Supplementation, Serum 25(OH)D Concentrations and Cardiovascular Disease Risk Factors: A Systematic Review and Meta-Analysis. Front. 2018;5:87. PMID: 30050908. 10.3389/fcvm.2018.00087 30050908
211 Margolis KL, Ray RM, Van Horn L, . Effect of calcium and vitamin D supplementation on blood pressure: the Women’s Health Initiative Randomized Trial. Hypertension. 2008;52(5):847–55. 10.1161/HYPERTENSIONAHA.108.114991 18824662
212 Verma H, Garg R. Effect of Vitamin K Supplementation on Cardiometabolic Risk Factors: A Systematic Review and Meta-Analysis. Endocr Metab Immune Disord Drug Targets. 2019;19(1):13–25. PMID: 29968548. 10.2174/1871530318666180703125007 29968548
213 Kuruppu D, Hendrie HC, Yang L, . Selenium levels and hypertension: a systematic review of the literature. Public health nutrition. 2014;17(6):1342–52. PMID: 23590757. 10.1017/S1368980013000992 23590757
214 Ranasinghe P, Wathurapatha WS, Ishara MH, . Effects of Zinc supplementation on serum lipids: a systematic review and meta-analysis. Nutr Metab (Lond). 2015;12:26. PMID: 26244049. 10.1186/s12986-015-0023-4 26244049
215 Khazdouz M, Djalalinia S, Sarrafi Zadeh S, . Effects of Zinc Supplementation on Cardiometabolic Risk Factors: a Systematic Review and Meta-analysis of Randomized Controlled Trials. Biological trace element research. 2020;195(2):373–98. 10.1007/s12011-019-01870-9 31494808
216 Dibaba DT. Effect of vitamin D supplementation on serum lipid profiles: a systematic review and meta-analysis. Nutrition reviews. 2019. PMID: 31407792. 10.1093/nutrit/nuz037 31407792
217 Challoumas D, Stavrou A, Pericleous A, . Effects of combined vitamin D--calcium supplements on the cardiovascular system: should we be cautious? Atherosclerosis. 2015;238(2):388–98. PMID: 25558033. 10.1016/j.atherosclerosis.2014.12.050 25558033
218 Rajpathak SN, Xue X, Wassertheil-Smoller S, . Effect of 5 y of calcium plus vitamin D supplementation on change in circulating lipids: results from the Women’s Health Initiative. Am J Clin Nutr. 2010;91(4):894–9. 10.3945/ajcn.2009.28579 20181812
219 Ashor AW, Siervo M, van der Velde F, . Systematic review and meta-analysis of randomised controlled trials testing the effects of vitamin C supplementation on blood lipids. Clinical Nutrition. 2016;35(3):626–37. PMID: 26164552. 10.1016/j.clnu.2015.05.021 26164552
220 Jorde R, Sollid ST, Svartberg J, . Vitamin D 20,000 IU per Week for Five Years Does Not Prevent Progression From Prediabetes to Diabetes. Journal of Clinical Endocrinology & Metabolism. 2016;101(4):1647–55. PMID: 26829443. 10.1210/jc.2015-4013 26829443
221 Kawahara T. Eldecalcitol, a vitamin D analog, for diabetes prevention in impaired glucose tolerance (DPVD study). Diabetes. 2018;67:LB34.
222 Ranasinghe P, Wathurapatha WS, Galappatthy P, . Zinc supplementation in prediabetes: A randomized double-blind placebo-controlled clinical trial. J Diabetes. 2018;10(5):386–97. PMID: 29072815. 10.1111/1753-0407.12621 29072815
223 Huang WL, Yang J, Yang J, . Vitamin D and new-onset atrial fibrillation: A meta-analysis of randomized controlled trials. HJC Hell. 2018;59(2):72–7. PMID: 29154815. 10.1016/j.hjc.2017.11.006 29154815
224 Kotecha D. Magnesium for Atrial Fibrillation, Myth or Magic? Circ Arrhythm Electrophysiol. 2016;9(9). 10.1161/CIRCEP.116.004521
225 Boursiquot BC, Larson JC, Shalash OA, . Vitamin D with calcium supplementation and risk of atrial fibrillation in postmenopausal women. Am Heart J. 2019;209:68–78. PMID: 30685677. 10.1016/j.ahj.2018.12.006 30685677
226 Albert CM, Cook NR, Pester J, . The Vital Rhythm Trial: Omega-3 Fatty Acid and Vitamin D Supplementation in the Primary Prevention of Atrial Fibrillation. American Heart Association Scientific Sessions; November 13. Writing2020.
227 Xu L, Wan X, Huang Z, . Impact of vitamin D on chronic kidney diseases in non-dialysis patients: a meta-analysis of randomized controlled trials. PLoS ONE [Electronic Resource]. 2013;8(4):e61387. PMID: 23626678. 10.1371/journal.pone.0061387 23626678
228 de Zeeuw D, Agarwal R, Amdahl M, . Selective vitamin D receptor activation with paricalcitol for reduction of albuminuria in patients with type 2 diabetes (VITAL study): a randomised controlled trial. Lancet. 2010;376(9752):1543–51. 10.1016/S0140-6736(10)61032-X 21055801
229 Barry EL, Mott LA, Melamed ML, . Calcium supplementation increases blood creatinine concentration in a randomized controlled trial. PLoS ONE [Electronic Resource]. 2014;9(10):e108094. PMID: 25329821. 10.1371/journal.pone.0108094 25329821
230 Elders PJ, Netelenbos JC, Lips P, . Calcium supplementation reduces vertebral bone loss in perimenopausal women: a controlled trial in 248 women between 46 and 55 years of age. J Clin Endocrinol Metab. 1991;73(3):533–40. 10.1210/jcem-73-3-533 1874931
231 Peacock M, Liu G, Carey M, . Effect of calcium or 25OH vitamin D3 dietary supplementation on bone loss at the hip in men and women over the age of 60. J Clin Endocrinol Metab. 2000;85(9):3011–9. 10.1210/jcem.85.9.6836 10999778
232 de Boer IH, Zelnick LR, Ruzinski J, . Effect of Vitamin D and Omega-3 Fatty Acid Supplementation on Kidney Function in Patients With Type 2 Diabetes: A Randomized Clinical Trial. Jama. 2019;322(19):1899–909. PMID: 31703120. 10.1001/jama.2019.17380 31703120
233 Baron JA, Barry EL, Ivanova A. Calcium and Vitamin D for the prevention of colorectal adenomas [Authors’ reply]. New England Journal of Medicine. 2016;374(8):791–2. PMID: 26933859. doi:10.1056/NEJMc1514501 26933859
234 Veettil SK, Ching SM, Lim KG, . Effects of calcium on the incidence of recurrent colorectal adenomas: A systematic review with meta-analysis and trial sequential analysis of randomized controlled trials. Medicine (Baltimore). 2017;96(32):e7661. PMID: 28796047. 10.1097/MD.0000000000007661 28796047
235 Baron JA, Beach M, Mandel JS, . Calcium supplements for the prevention of colorectal adenomas. Calcium Polyp Prevention Study Group. N Engl J Med. 1999;340(2):101–7. PMID: 9887161.9887161
236 Barry EL, Lund JL, Westreich D, . Body mass index, calcium supplementation and risk of colorectal adenomas. International Journal of Cancer. 2019;144(3):448–58. PMID: 30117164. 10.1002/ijc.31803 30117164
237 Bjelakovic G, Nagorni A, Nikolova D, . Meta-analysis: antioxidant supplements for primary and secondary prevention of colorectal adenoma. Aliment Pharmacol Ther. 2006;24(2):281–91. 10.1111/j.1365-2036.2006.02970.x 16842454
238 Gao QY, Chen HM, Chen YX, . Folic acid prevents the initial occurrence of sporadic colorectal adenoma in Chinese older than 50 years of age: a randomized clinical trial. Cancer Prev Res (Phila Pa). 2013;6(7):744–52. PMID: 23682073. 10.1158/1940-6207.CAPR-13-0013 23682073
239 Jaszewski R, Misra S, Tobi M, . Folic acid supplementation inhibits recurrence of colorectal adenomas: a randomized chemoprevention trial. World J Gastroenterol. 2008;14(28):4492–8. PMID: 18680228. 10.3748/wjg.14.4492 18680228
240 Food and Drug Administration. Food Labeling: Health Claims and Label Statements; Folate and Neural Tube Defects. In: Services HaH, editor.: Federal Register Online; 1996. PMID.
241 Lance P, Alberts DS, Thompson PA, . Colorectal Adenomas in Participants of the SELECT Randomized Trial of Selenium and Vitamin E for Prostate Cancer Prevention. Cancer Prev Res (Phila Pa). 2017;10(1):45–54. PMID: 27777235. 10.1158/1940-6207.CAPR-16-0104 27777235
242 Song M, Lee IM, Manson JE, . No Association Between Vitamin D Supplementation and Risk of Colorectal Adenomas or Serrated Polyps in a Randomized Trial. Clinical gastroenterology and hepatology : the official clinical practice journal of the American Gastroenterological Association. 2020. PMID: 32062040. 10.1016/j.cgh.2020.02.013 32062040
243 Bertone-Johnson ER, McTiernan A, Thomson CA, . Vitamin D and calcium supplementation and one-year change in mammographic density in the women’s health initiative calcium and vitamin D trial. Cancer Epidemiol Biomarkers Prev. 2012;21(3):462–73. 10.1158/1055-9965.EPI-11-1009 22253296
244 Vahedpoor Z, Jamilian M, Bahmani F, . Effects of Long-Term Vitamin D Supplementation on Regression and Metabolic Status of Cervical Intraepithelial Neoplasia: a Randomized, Double-Blind, Placebo-Controlled Trial. Horm Cancer. 2017;8(1):58–67. PMID: 28050798. 10.1007/s12672-016-0278-x 28050798
245 Vahedpoor Z, Mahmoodi S, Samimi M, . Long-Term Vitamin D Supplementation and the Effects on Recurrence and Metabolic Status of Cervical Intraepithelial Neoplasia Grade 2 or 3: A Randomized, Double-Blind, Placebo-Controlled Trial. Ann Nutr Metab. 2018;72(2):151–60. PMID: 29466786. 10.1159/000487270 29466786
246 Asemi Z, Vahedpoor Z, Jamilian M, . Effects of long-term folate supplementation on metabolic status and regression of cervical intraepithelial neoplasia: A randomized, double-blind, placebo-controlled trial. Nutrition. 2016;32(6):681–6. PMID: 26853484. 10.1016/j.nut.2015.12.028 26853484
247 Thomas LD, Elinder CG, Tiselius HG, . Ascorbic Acid Supplements and Kidney Stone Incidence Among Men: A Prospective Study. JAMA Intern Med. 2013;173(5):386–8. PMID: 23381591.23381591