# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tina Fan, MD, MPH, and Howard Tracer, MD, at the Agency for Healthcare Research and Quality; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; the National Cancer Institute, and the National Heart, Lung, and Blood Institute for providing federal partner review of the draft report; Erin LeBlanc, MD, MPH, Edward Giovannucci, MD, ScD, Stephanie Weinstein, PhD, Catharine Ross, PhD, and JoAnn Manson, MD, DrPH, MPH, who provided expert review of the draft report; and Nadia Redmond, MSPH, Jill Pope, BA, and Melinda Davies, MAIS, for technical and editorial assistance at the Center for Health Research.