# Chapter 4 Discussion

## Summary of Evidence

We conclude that most vitamin and mineral supplements provide no clinically important protective effects for CVD, cancer, or all-cause mortality in healthy adults without known nutritional deficiencies (Table 20, Figure 11), with vitamin E having the strongest body of evidence demonstrating no benefit for most outcomes relevant to this review. These conclusions are generally consistent with those of the previous review for the USPSTF on this topic.^53^ However, in contrast to the previous review, we found a small reduction in cancer incidence associated with multivitamin use (OR, 0.93 [95 % CI, 0.87 to 0.99]; 4 RCTs; n=48,859; I^2^=0.01%). The absolute risk difference among adequately powered trials ranged from −0.2 percent to −1.2 percent. There was no indication of serious harm associated with multivitamin use. However, the evidence for multivitamins had important limitations, including only three adequately powered trials, one with a median of only 3.6 years of multivitamin use and another that was limited to antioxidants. New evidence in this update was predominately for Vitamin D supplementation. Despite the new inclusion of 32 RCTs and 2 cohort studies, pooled estimates for all-cause mortality were similar to that in the prior review with confidence intervals just crossing 1 and point estimates suggesting at most a very small benefit.

Table 20 Summary of Evidence

Supplement; No. of Studies by study design (No. of observations) | Key question; No. of Studies by study design (No. of observations) | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
Multivitamin; 10 RCTs, 3 prospective cohort studies (n=240,132) | KQ1 (benefits); 9 RCTs (n=51,945) | Evidence suggested a possible small benefit for cancer, but small to no benefit for all-cause mortality or CVD. Pooled results reflected the findings of three large good-quality trials with CVD and cancer aims that provided most of the evidence. Pooled results included:; - All-cause mortality: OR 0.94 (95% CI, 0.87 to 1.01; 9 RCTs [n=51,550]).; - CVD mortality: OR 0.94 (95% CI, 0.83 to 1.06; 4 RCTs [n=37,400]); - Any cancer incidence: OR 0.93 (0.87 to 0.99; 4 RCTs [n=48,859])Lung cancer incidence: OR OR, 0.75 (0.58 to 0.95; 2 RCTs [n=36,052]) | All-cause, CVD-, and cancer-specific mortality; cancer incidence: Reasonably consistent, reasonably precise; Other CVD outcomes: reasonably consistent or NA, reasonably precise.; Site-specific cancers: Reasonably consistent, inconsistent, or NA, imprecise | Specific formulations differed widely and included both broad spectrum and antioxidant-focused supplements.; Two of the main trials had a background interventions in 2x2 or 2x2x2x2 study designs. | All-cause mortality: Low for small to no benefit; CVD: Low for no benefit; Cancer incidence: Low for small benefit | Most studies were conducted outside the US, including one of the two main trials. The other main trial was limited to male physicians.
Multivitamin; 10 RCTs, 3 prospective cohort studies (n=240,132) | KQ2 (harms); 9 RCTs (n=51,614); 3 prospective cohort studies (n=188,027) | No evidence of increased risk of serious adverse events, but few events. Small increases in cataracts reported by cohort studies were not statistically significant and were not examined in any of the trials. A large trial found small increased risk of skin rash and epistaxis. | Cataracts: Consistent, imprecise; Other serious: Consistency NA, imprecise; Skin rash and epistaxis: Consistency NA, reasonably precise. | Cataracts, hip fractures: evidence limited to observational studies, supplement use was self-reported. | Low for increased risk of skin rash, epistaxis, insufficient for other harms. | Most studies were conducted outside the US, including one of the two main trials. The other main trial was limited to male physicians.
Beta-carotene; 6 RCTs, 1 prospective cohort (n=278,653); Vitamin A; 2 RCTs, 2 prospective cohorts (n=177,014) | KQ3 (benefits); Beta-carotene; 6 RCTs (n=112,820); Vitamin A; 2 RCTs (n=20,611) | Pooled estimates for several outcomes showed statistically significant paradoxical harm associated with beta-carotene use, for example:; - All-cause mortality: OR 1.06 (95% CI, 1.00 to 1.12; 6 RCTs [n=112,820]); - All-cause mortality including vitamin A study (SKICAP): OR 1.06 (95% CI, 1.01 to 1.12); 7 RCTs [n=115,117]); - CVD mortality: OR 1.10 (1.02 to 1.19); 5 RCTs [n=95,506]); - Lung cancer: 1.20 (95% CI, 1.01 to 1.42); 4 RCTs [n=94,830]); Pooled estimates for all cancer mortality, any cancer incidence, colorectal, breast, and prostate cancer showed no statistically significant differences in risk associated with beta-carotene use. There were no differences in composite CVD events in 2 reporting trials.; Vitamin A had no impact on all-cause mortality. | All-cause mortality: reasonably consistent, precise for increased risk for beta-carotene with or without vitamin A; CVD mortality: reasonably consistent, precise for increased risk for beta-carotene; Cancer: Lung cancer: Reasonably consistent, precise for increased risk; Any cancers and other site-specific cancers: Consistent and imprecise for no difference | Variation in study dose and duration. Combined supplement use in CARET and varied background interventions in almost all other trials. Multiple comparisons and outcomes examined in a body of literature with different primary aims. | All-cause mortality: Moderate for small increased risk for beta-carotene with or without vitamin A; Low for no increased risk with vitamin A alone; CVD mortality: Moderate for a small increased risk for beta-carotene; CVD events: Low for no association for beta-carotene; Cancer: Lung cancer: moderate for an increased risk for beta-carotene; Any cancer and other site-specific cancers: Low for no difference for beta-carotene | Most studies of beta-carotene and vitamin A conducted in the US, but participants were primarily white. Included general risk samples as well as those limited to persons at increased risk for lung cancer due to smoking status or asbestos exposure.; Vitamin A doses above the current upper limit in all trials evaluating vitamin A.
Beta-carotene; 6 RCTs, 1 prospective cohort (n=278,653); Vitamin A; 2 RCTs, 2 prospective cohorts (n=177,014) | KQ4 (harms); Beta-carotene; 6 RCTs (n=112,820), 1 prospective cohort (n=121,700); Vitamin A; 2 RCTs (n=20,611), 2 prospective cohorts (n=156,403) | The most substantial serious harms are the paradoxical harms of increased all-cause mortality, CVD mortality, and lung cancer (see KQ3). Trials generally showed no statistically significant findings for other adverse events other than hypercarotenodermia (4 trials, ORs ranging from 1.10 to 24.75), and GI symptoms in the one trial reporting this outcome.; Two cohort studies in women found an elevated but not statistically significantly increased risk of hip fracture associated with vitamin A supplementation. | (excluding paradoxical harms above); Consistent, precise for beta-carotene and increased risk of hyper-carotenodermia; Consistent and imprecise for vitamin A and increased risk of hip fracture; Consistent and imprecise for other nonserious harms for beta-carotene and vitamin A | Variation in study dose and duration. Combined supplement use in CARET and varied background interventions in almost all other trials. Supplement use in cohort study was self-reported | (excluding paradoxical harms above); Hyper-carotenodermia: Moderate for increased risk with beta-carotene; Hip fractures: Low for increased risk for vitamin A; Cataracts: Low for no increased risk for vitamin A | Most studies of beta-carotene and vitamin A conducted in the US, but participants were primarily white. Evidence included general risk samples as well as those limited to persons at increased risk for lung cancer due to smoking status or asbestos exposure.; Vitamin A doses were above the current upper limit in all trials evaluating vitamin A.; Data suggesting a possible increased hip fracture risk with vitamin A are from cohort studies of primarily white women.
Vitamin D (with or without calcium); 38 RCTs, 3 prospective cohort studies (n=414,675) | KQ3 (benefits); 32 RCTs (n=123,140) | Evidence suggested no benefit for all primary outcomes of this review. For example, pooled ORs included:; - All-cause mortality: 0.96 (0.91 to 1.02); 27 RCTs (n=117,082); - CVD events: 1.00 (95% CI, 0.95 to 1.05; 7 RCTs (n=74,925); - Any cancer: 0.98 (95% CI, 0.92 to 1.03); 19 RCTs (n=86,899); Findings were consistent across different pooling methods, robustness of outcome ascertainment, and whether vitamin D was taken alone or with calcium. | All-cause mortality, CVD mortality, any cancer incidence: Reasonably consistent, precise; CVD events: Consistent, precise; Cancer mortality: Inconsistent, reasonably precise; Site-specific cancers: Reasonably consistent, imprecise | Most studies had primary aims related to bone density, fractures, or falls (however there were two very large good-quality trials plus additional smaller trials with cancer and CVD as primary aims). Few large studies reported most site-specific cancers. | ACM: Moderate for no benefit; CVD: High for no benefit; Cancer: Low for no benefit | Primarily white older adults.
Vitamin D (with or without calcium); 38 RCTs, 3 prospective cohort studies (n=414,675) | KQ4 (harms); 31RCTs (n=117,100),; 3 prospective cohort studies (n=289,659) | Both trial and cohort evidence suggested an increased risk of kidney stone with 1000 IU/day or more of vitamin D over 7 or more years. Most evidence supported no increased risk of GI-related symptoms. Other non-serious symptoms also generally found no group differences, and other serious harms had too few events to draw conclusions. | Kidney stones: inconsistent, imprecise; GI symptoms: consistent, precise; Other AE: inconsistent, imprecise | Most studies had primary aims related to bone density, fractures, or falls. Supplement use in cohort studies was self-reported | Kidney stones: Low for small increased risk; GI: Moderate for no increased risk; Other AE: Low for no increased risk | Primarily white older adults.
Vitamin E; 9 RCTs, 2 prospective cohort studies (N= 265,511) | KQ3 (benefits); 9 RCTs (n=116,468) | Most evidence indicated that vitamin E had no benefit for mortality, CVD, or cancer. For example, pooled ORs included:; - All-cause mortality: 1.02 (5% CI, 0.97 to 1.07; 9 RCTs [n=107,772]); - CVD events: 0.96 (95% CI, 0.90 to 1.04; 4 RCTs [n=62,136]); - Any cancer: 1.02 (95% CI, 0.98 to 1.08; 5 RCTs [n=76,777]) | All-cause mortality: Reasonably consistent, precise; CVD: Consistent, imprecise; Cancer: Inconsistent, imprecise for prostate cancer; Consistent, imprecise for other cancer outcomes | Few studies for most outcomes other than all-cause mortality, several studies underpowered for the main outcomes of this review (but all main outcomes for the review also include some studies powered for CVD and/or cancer outcomes). | All-cause mortality: High for no benefit; CVD, other than hemorrhagic stroke: Moderate for small to no benefit; Hemorrhagic stroke: Low for increased risk; Cancer: Low for prostate for small to no benefit; Moderate for small to no benefit for other cancer outcomes | Most included participants were white American or European adults age 45 and older. Included general risk samples as well as those limited to persons at increased risk for cancer or CVD due to smoking or CVD risk factors.
Vitamin E; 9 RCTs, 2 prospective cohort studies (N= 265,511) | KQ4 (harms); 7 RCTs (n=115,576); 2 prospective cohort studies (N= 149,043) | Although data on specific outcomes were sparse, no clear increased risk of serious harm was identified, but effects were wide-ranging and included findings in the direction of benefit and harm across all review outcomes, including 2 trials we increased risk of hemorrhagic stroke; one cohort study with a single assessment of vitamin E use found an increased risk of cataracts, but a higher quality cohort study with biennial reporting of vitamin E use showed no increased risk of cataracts. | Inconsistent, imprecise | Supplement use in cohort studies was self-reported | (other than paradoxical harm for hemorrhagic stroke above); Cataracts, hospitalization from pneumonia, other non-serious: Low for no increased risk | Most included participants were white American or European adults age 45 and older. Included general risk samples as well as those limited to persons at increased risk for cancer or CVD due to smoking or CVD risk factors.
Folic acid; 5 RCTs (N=6,370) | KQ3 (benefits); 5 RCTs (N=6,370) | Most evidence indicated that folic acid increased the risk of cancer and had no benefit for mortality. The pooled ORs included:; - All-cause mortality: 0.71 (95% CI 0.49 to 1.03; 5 RCTs [n=6,370]); - Any cancer: 1.42 (95% CI 1.10 to 1.84; 3 RCTs [n=4,612]); There were too few events to draw conclusions for CVD, or single-site cancers. One study found an increased risk of prostate cancer, however there were only 34 events total and another trial found no increased risk. | All-cause mortality: Reasonably consistent, imprecise; CVD: Reasonably consistent, imprecise; Cancer: Inconsistent and reasonably precise for any cancer incidence. Inconsistent and imprecise for site-specific cancers. | Trials were often underpowered for the main outcomes. None of the trials had CVD prevention as a primary aim. | All-cause mortality: Low for no benefit; CVD: Insufficient; Cancer: Any cancer: Low for increased risk. Site-specific: Insufficient | Three trials recruited participants with a history of colorectal adenomas. Other two trials recruited participants with an elevated homocysteine. Participants were from the US, the Netherlands, Great Britain, and Denmark with the mean age ranging from 57 to 74 years.
Folic acid; 5 RCTs (N=6,370) | KQ4 (harms); 4 RCTs (N=5,854) | Trial evidence suggests no serious or non-serious harms with folic acid use. | Withdrawals due to AE: reasonably consistent, imprecise; Other: Consistency NA, imprecise | Trials were often underpowered for the main outcomes. None of the trials had CVD prevention as a primary aim. | Low for no serious harms other than increased cancer risk. | Three trials recruited participants with a history of colorectal adenomas. Other two trials recruited participants with an elevated homocysteine. Participants were from the US, the Netherlands, Great Britain, and Denmark with the mean age ranging from 57 to 74 years.
Vitamin B3 (evaluated as nicotinamide); 1 RCT (n=386) | KQ3 (benefits); 1 RCT (n=386) | Insufficient evidence to determine the effect on mortality, CVD, or cancer. Only a very small number of events was reported. | All-cause mortality: Consistency NA, imprecise; CVD: Consistency NA, imprecise; Cancer: Consistency NA, imprecise | Only one RCT, which was underpowered for the outcomes of interest. | All-cause mortality: Insufficient; CVD: Insufficient; Cancer: Insufficient | Included participants were Australian men and women aged 30–91 years with a history of two or more nonmelanoma skin cancers.
Vitamin B3 (evaluated as nicotinamide); 1 RCT (n=386) | KQ4 (harms); 1 RCT (n=386) | Only a very small number of adverse events reported with no difference between the groups. | Consistency NA, imprecise | Only one RCT, which was underpowered for serious harms. | Insufficient | Included participants were Australian men and women aged 30–91 years with a history of two or more nonmelanoma skin cancers.
Vitamin B6; 1 Prospective cohort study (n=75,864) | KQ3 (benefits) | No evidence found. | NA | NA | NA | NA
Vitamin B6; 1 Prospective cohort study (N=75,864) | KQ4 (harms); 1 Prospective cohort study (N=75,864) | The increased risk for hip fracture was associated with a high cumulative intake (food and supplements) of vitamin B6 and vitamin B6 from supplements only. | Consistency NA, reasonably precise | Only one cohort study. All data on vitamin B6 intake, potential confounders, hip fractures were self-reported by questioners. Supplement use in was self-reported | All-cause mortality: NA; CVD: NA; Cancer: NA; Harms: Low for increased risk | All participants were preliminarily white postmenopausal female registered nurses in the United States.
Vitamin C; 2 RCTs, 4 prospective cohorts (N=254,587) | KQ3 (benefits); 2 RCTs (n=15,031) | One large (n=14,641) good quality trial found that vitamin C had no benefit for mortality, CVD, or cancer. HRs include:; - All-cause mortality: 1.07 (95% CI, 0.97 to 1.18); - CVD events: 0.99 (95% CI, 0.89 to 1.11); - Any cancer: 1.01 (95% CI, 0.92 to 1.10); The other RCT was small and not powered to evaluate mortality. One death occurred in each group; all deaths were CVD-related. | All-cause mortality: Consistent, reasonably precise; CVD: Consistent, reasonably precise; Cancer: Consistency NA, reasonably precise | Evidence is primarily from one very large trial in men only; the other trial was not powered to evaluate health outcomes.; Multiple and varied background interventions in context of 2x2x2x2 trial. | All-cause mortality: Low for no benefit; CVD: Low for no benefit; Cancer: Low for no benefit | Most trial data were in men with high socioeconomic status who were predominately white.
Vitamin C; 2 RCTs, 4 prospective cohorts (N=254,587) | KQ4 (harms); 2 RCTs (n=15,031), 4 prospective cohorts (N=239,556) | Trial evidence suggested no serious or nonserious harms and no statistically significant paradoxical findings. Cohort studies had conflicting results for cataracts with possible increased risk of cataracts which was not confirmed in a large trial. 2 large cohorts show evidence for increased risk of kidney stones in men. | Cataracts: Inconsistent and reasonably precise; Other serious and non-serious: Consistent and reasonably precise | Supplement use in cohort studies was self-reported and collected at one time only in two cohorts. | Kidney stones: Low for increased risk Cataract: Low for no increased risk; Other harms: Low for no increased risk | Most trial data were in men with high socioeconomic status who were predominately white. All cohort evidence for kidney stones was in men only.
Calcium; 8 RCTs, 1 prospective cohort (n=134,707) | KQ3 (benefits); 7 RCTs (n=11,884) | Most evidence indicated no benefit for mortality, CVD, or cancer after up to 6 years of calcium use. However, one smaller study suggested a possible reduction in prostate cancer, among persons with a recent adenoma. Pooled ORs for other outcomes include:; - All-cause mortality: 1.05 (95% CI, 0.92 to 1.21; 6 RCTs [n=8,394]); - CVD events: 1.11 (95% CI, 0.90 to 1.36; 4 RCTs [n=4,076]); - Any cancer: 0.94 (95% CI, 0.41 to 2.14; 3 RCTs [n=5,051]) | All-cause mortality: Reasonably consistent, Reasonably precise; CVD: Inconsistent, imprecise; Cancer: Inconsistent or NA (for site-specific cancers), imprecise | Primary outcomes were often underpowered, since half of studies had primary aims irrelevant to this review. | ACM: Moderate for no benefit; CVD: Low for no benefit; Cancer: Low for no benefit | Best evidence limited to white adults age 70 years and older with fragility fractures. Other studies also primarily in adults age 40 and older, white, and mostly female.
Calcium; 8 RCTs, 1 prospective cohort (n=134,707) | KQ4 (harms); 8 RCTs (n=11,930), 1 prospective cohort (n=121,700) | Findings suggested an increased risk of constipation and gastrointestinal complaints, and possibly kidney stones. | Gastrointestinal complaints: Consistent, reasonably precise; Kidney stones: Reasonably consistent and imprecise | Reporting of any, any serious, and withdrawal due to adverse effects sparely reported; kidney stone evidence primarily limited to observational data in women only, where supplement use was measured by self-report | GI-related complaints: Moderate for increased risk; Kidney stones: Low for increased risk | Best evidence limited to white adults age 70 years and older with fragility fractures. Other studies also primarily in adults age 40 and older, white, and mostly female.
Selenium; 5 RCTs (n=29,909) | KQ3 (benefits); 4 RCTs (n=29,408) | Most evidence suggested that approximately 6 months to 5.5 years of selenium use had no benefit for mortality, CVD, or cancer at followup ranging from 6 months to 15.9 years. The pooled OR for all-cause mortality was 0.94 (0.83 to 1.07; 4 RCTs [n=20,832]). Effect sizes for any CVD event ranged from HRs of 0.97 (95% CI, 0.86 to 1.09) to 1.04 (95% CI, 0.73 to 1.49). Cancer incidence effects were highly variable and rarely differed between groups, although one smaller study of persons with a history of basal or squamous cell cancer (75% male) found a reduction in cancer incidence (HR, 0.75 (95% CI 0.58 to 0.97), despite no impact on the recurrence of skin cancer. | All-cause mortality: Inconsistent, imprecise; CVD: Reasonably consistent, imprecise; Cancer: Inconsistent, imprecise | Few studies, females not well-represented, most studies did not have CVD prevention as a primary aim. | All-cause mortality: Low for no benefit; CVD: Low for no benefit; Cancer: Low for no benefit | The largest, best-quality trial was conducted in the US and Canada but limited to males. Across the body of evidence, participants were predominantly white race and age 50 years and older (mean age in the 60s for all studies).
Selenium; 5 RCTs (N=29,909) | KQ4 (harms); 5 RCTs (N=29,909) | No clear increased risk of serious harm. The smallest study (n=491) found increased risk of all-cause mortality, but all others found no association, and no other increased risk of serious harm was identified in any study. | Reasonably consistent, imprecise | Few studies, females not well-represented, most studies did not have CVD prevention as a primary aim. | Low for no serious harm | The largest, best-quality trial was conducted in the US and Canada but limited to males. Across the body of evidence, participants were predominantly white race and age 50 years and older (mean age in the 60s for all studies).
Zinc; 2 RCT (N=203) | KQ3 (benefits) | No evidence found. | NA | NA | NA | NA
Zinc; 2 RCT (N=203) | KQ4 (harms) | One trial showing increased risk of having any adverse events, including stomachache, taste problems, teeth and mouth roughness or dryness, and aching in the mouth; one trial showing few withdrawals due to adverse events that were similar in zinc and placebo groups. | Inconsistent, imprecise | Two small studies of varied aims, one testing 5-day use only | Insufficient | General US adult population
Magnesium; 2 RCT (N=110) | KQ3 (benefits) | No evidence found. | NA | NA | NA | NA
Magnesium; 2 RCT (N=110) | KQ4 (harms) | Increased risk of gastrointestinal symptoms | Consistent, imprecise | Two small studies of varied aims | Insufficient | General US adult population

Figure 11 Overview of Evidence Base and Strength of Evidence for Multivitamin Supplements and Single or Paired Nutrient Supplements^*^ * Not shown in the figure are one to two studies of harms for each of vitamin B6, zinc, and magnesium; insufficient strength of evidence in all three cases.

Abbreviations: ACM = All-cause mortality; CRC = Colorectal cancer; CVD = Cardiovascular disease; RCT = Randomized controlled trial.

This figure is an overview the evidence base and strength of evidence for multivitamin supplements and single or paired nutrient supplements

Our findings confirm the previous review’s finding that beta-carotene supplementation, especially with concomitant vitamin A use, likely increases the risk of lung cancer incidence in those at high risk for lung cancer. We extended these findings to note that cardiovascular mortality may also be increased with beta-carotene use. We found some information on additional harms that was not identified in the previous review, including weak evidence that the risk of kidney stones may be increased with vitamin D use, among women with calcium supplementation, and among men with vitamin C supplementation. These and all findings in our review are relevant only to micronutrients taken in the form of supplements, and not to dietary intake.

The current review included substantially more evidence on folic acid, however this was still a small body of evidence with most studies reporting only a small number of events, showing weak evidence that folic acid (with or without concomitant vitamin B12), may be associated with an increased risk of cancer incidence. For the first time, we included evidence related to the benefits and harms of vitamin B3 and harms of vitamin B6, zinc, and magnesium. We found weak evidence that vitamin B6 may increase the risk of hip fracture, however the findings were otherwise inconclusive for these supplements so add little of substance to the findings of the previous review. For all supplements, the findings of our review are consistent with other systematic reviews of supplementation use,^59,^ ^161–170^ including some reviews of observational studies.^171,^ ^172^

### Other Evidence Supporting Our Findings

#### Vitamin D

Our findings for vitamin D are generally consistent with other reviews which have reported pooled estimates in the range of 0.93 to 0.97,^164–166^ and slightly larger relative reductions in cancer-specific mortality.^59,^ ^165,^ ^167^ The review for the USPSTF on vitamin D and calcium supplementation for the prevention of fractures did not find a benefit for all-cause mortality, and found an effect size that was similar to ours and also very close to being statistically significant for vitamin D alone (RR, 0.91 [95% CI, 0.82 to 1.01]).^66^ In general, the statistical significance of an all-cause mortality benefit in pooled analyses is unstable, being sensitive to the number of included studies and which study aims are considered. Although observational studies of serum vitamin D levels tend to show increased risk of CVD^173,^ ^174^ and some cancers^175–179^ with deficient serum levels, other reviews of trial evidence have concluded that vitamin D supplementation does not appear to reduce the risk of cancer^59,^ ^164^ or CVD events.^66^

#### Beta-Carotene and Vitamin A

Our results on the potential harms of supplemental beta-carotene are also supported by the broader evidence base in addition to the previous USPSTF review. We found that beta-carotene supplementation (with or without other supplements) was associated with statistically significant paradoxical harm for CVD mortality, lung cancer, and when combined with the vitamin A results, all-cause mortality. The highest magnitude of increased risk was for lung cancer. The most robust evidence for increased lung cancer risk was from the two studies included in our review of populations at high-risk for lung cancer (ATBC^76^ and CARET^63^), which showed that increased lung cancer risk was statistically significant only for current smokers. This finding was supported by another meta-analysis, which did a more detailed examination of subgroup analyses by smoking status provided by the four largest studies in our review.^180^ However, study-level subgroup analyses are confounded by heterogeneity of dose and duration and are limited by reduced power due to a small number of events in subgroups by smoking status, particularly in WHS. There was no signal of benefit for any health outcome associated with supplemental beta-carotene use, and limited data from the intermediate outcomes of diabetes incidence and colorectal adenoma further suggest no benefit.^76,^ ^181^

The addition of one vitamin A trial reporting all-cause mortality to the beta-carotene studies rendered the point estimate statistically significant for an increased risk (OR 1.06 [95% CI, 1.01 to 1.12]; 7 RCTs [n=115,117]). Further, two large cohort studies in women suggest a possible increased risk for hip fracture associated with vitamin A supplementation.^146,^ ^147^ Guidance from the Institute of Medicine (IOM) states that high beta-carotene intake is not known to cause hypervitaminosis A, however, an upper limit of 3,000 RAE is established for preformed vitamin A which is based on liver abnormalities as the critical endpoint.^7^ This guidance also notes that chronic vitamin A toxicity may also be associated with reduced bone mineral density. This is consistent with our finding of a signal for possible increased risk of hip fracture in two cohort studies. Of note, the two trials evaluating supplementation with preformed vitamin A, CARET and SKICAP, both used a dose of 7,500 RAE, which is twice the upper limit.

### Other Evidence That Contrasts With Our Findings

#### Vitamin E

There are a few minor points of departure between our findings and other systematic reviews that underscore the uncertainty of some of our findings. While we found clear evidence that vitamin E had no impact on all-cause mortality and CVD events, another review of primary prevention in adults concluded that vitamin E may reduce the risk of CVD mortality.^182^ Our pooled analysis for CVD mortality was not statistically significant, although the point estimate was in the direction of benefit (OR, 0.88 [95% CI, 0.74 to 1.04]). The point estimate in the other review was identical to ours but was statistically significant (RR, 0.88 [95% CI, 0.80 to 0.96]).^182^ Their analysis included studies of multivitamins that contained vitamin E in addition to vitamin E alone, in contrast to our meta-analysis that was limited intervention arms examining vitamin E alone. While this might indicate a relatively small effect that is only detectable in very large pooled analyses, the clear lack of association with all-cause mortality CVD events, and cancer incidence led us to conclude that vitamin E most likely has little to no effect on CVD mortality as well.

#### B Vitamins

Regarding folic acid, in contrast to our review, one network meta-analysis^183^ reported a reduction in stroke with folic acid when combined with B6 and with the combination of B6 and B12. However, most of the studies in this analysis were limited to individuals with CVD or a history of stroke or transient ischemic attack. We found two meta-analyses examining the impact of folic acid on CVD outcomes, although both primarily included persons with pre-existing CVD, so provided little information on prevention in a general population. One of these found no association between folic acid and CVD events (RR, 1.04 [95% CI, 0.98 to 1.11]) in persons with CVD, stroke, or diabetes mellitus.^184^ The other meta-analysis found a benefit of folic acid for stroke (RR, 0.79 [95% CI, 0.69 to 0.92]) and a composite CVD outcome (RR, 0.83 [95% CI, 0.73 to 0.93]), although this analysis was limited to trials with persons with known chronic conditions only (e.g., CVD, end-stage renal disease) and trials not eligible for our review (e.g., conducted in China).^185^ Thus, we believe evidence for folic acid supplementation for CVD prevention in general populations, with or without vitamin B6 and B12, suggests no effect on MI and stroke and is inconclusive for other CVD outcomes due to the very small number of events in our included studies.

Two of the three folic acid studies reporting cancer incidence in our review found an increased risk with folic acid supplementation. While another meta-analysis showed no such association (RR, 1.06 [95% CI, 0.99 to 1.1]), this meta-analysis was published prior to B-PROOF,^97^ the trial with the most cancer outcome events in our review, and which showed an increased risk. One (AFPPS^84^) of two studies reporting prostate cancer included in our review detected an increased risk for prostate cancer with folic acid use. Two other reviews of prospective cohort studies found that higher serum folate levels were associated with higher prostate cancer risk.^186,^ ^187^ For example, one reported a 13 percent increase in the odds of prostate cancer for the highest vs. lowest 20% of serum folate levels (OR 1.13, 95% CI, 1.20 to 1.26), and a similar findings for serum B_12_ levels (OR, 1.12 (95% CI, 1.01 to 1.25).^186^ However, one of these reviews found no association between high dietary folate (with or without vitamin B12 intake) and increased risk for prostate cancer.^187^

While we find very limited evidence related to vitamin B3, four systematic reviews^185,^ ^188–190^ evaluated the evidence for the use of vitamin B3 with or without statins for prevention of CVD events and all-cause mortality. The authors of the Cochrane report^189^ found high to moderate quality of evidence of no statistically significant effect of vitamin B3 for all-cause mortality, CVD mortality, and MI, and low quality of evidence of no effect for non-fatal stroke. This review included a mix of primary prevention and secondary prevention studies. Three other reviews were limited to studies in persons with or at increased risk for CVD (e.g., with CVD risk factors).^185,^ ^188,^ ^190^ These studies found that the use of vitamin B3 was associated with an increased risk of worsening of diabetes,^188,^ ^190^ skin,^188,^ ^190^ gastrointestinal,^188^ and musculoskeletal adverse events,^188^ and increased risk for all-cause mortality.^185^ Also, the Cochrane review^189^ found that persons who used vitamin B3 were more likely to discontinue treatment, compared with persons randomized to control.

#### Selenium

While we found no evidence that serious harms are increased with selenium use in the included studies, two systematic reviews^191,^ ^192^ showed a small association between selenium supplementation and increased risk for incident diabetes with 200 mcg/day selenium use. This finding was statistically significant in only one of the reviews, however (pooled RR, 1.11 [95% CI, 1.01 to 1.22]; I^2^=0%, 5 RCTs).^21^ The upper level for safe consumption is currently 400 mcg/day for adults. The IOM report describing the evidence used to establish safe upper limits identified the most common effects associated with excess selenium intake to be hair and nail brittleness and loss (most frequently reported symptoms), gastrointestinal disturbances, skin rash, garlic breath odor, fatigue, irritability, and nervous system abnormalities.^7^ They concluded that doses of up to 388 mcg/day for “short periods of time” did not appear to be associated with adverse effects.

## Limitations of Our Approach

Our review had several limitations. Due to our focus on CVD and cancer, our review does not address other potential benefits of supplemental vitamins and minerals on other outcomes. There may be some benefits of some supplements that are not covered in our review. For example, folic acid in women who are pregnant or soon to be pregnant is known to be valuable for prevention of neural tube defects in their offspring.^193^ In addition, our non-systematic examination of precursor cardiovascular and cancer outcomes suggested possible small effects on blood pressure and lipids for some vitamins or minerals (Appendix D). In addition, because we focused on studies in predominantly healthy populations without known nutritional deficiencies, our review also does not cover therapeutic use of supplements in persons with physical symptoms, medical conditions, or nutritional deficits.

We did not do an extensive analysis of the exact formulations of the supplements studied, such as whether they were synthetically produced or naturally derived, or the type of vitamin D provided (cholecalciferol vs. other forms of D3). Given the many dimensions along which studies displayed heterogeneity, we felt it unlikely that this factor would elucidate variability in effect sizes, especially since these types of details were not always provided.

We did not address the effects of vitamin D and calcium on bone health since our focus was on the prevention of CVD and cancer. Although some included studies of vitamin D reported on outcomes such as fractures and bone mineral density, and some found an increased risk of harm, we believe a better source of information on this association are systematic reviews designed to examine this association, such as the review commissioned by the USPSTF to support their recommendation on use of vitamin D and calcium to prevent fractures.^66^ This review concluded that Vitamin D supplementation alone or with calcium was not associated with reduced fracture incidence among community-dwelling adults without known vitamin D deficiency, and also found no clear indication of an increased risk.

In addition, due to our focus on serious harms, our review of non-serious harms is not comprehensive. We limited extraction of non-serious harms to those that were experienced by at least 5 percent of participants taking the supplement or those that appeared to have been specified a priori due to known risk. Because some studies reported dozens of specific harms that were reported by participants, most experienced by only a small number of individuals, a substantial number of outcomes were not included for some studies. We believe these data provided little additional value; these outcomes were non-serious and presumably reversible, and there was limited power to detect group differences in these outcomes that were not commonly reported. We also did not address risks of high doses, which are most comprehensively explicated in the reviews conducted by the IOM for setting tolerable upper limits.^7^ One exception is that we included studies with vitamin A and vitamin D doses above the recommended upper limit, for consistency with the previous review. We recommend that these studies be excluded in future USPSTF reviews.

Finally, due to the large number of analyses we conducted, there is a risk of false positive findings due to chance.

## Limitations of the Literature

In general, the impacts of individual micronutrients on human health are very difficult to detect in generally healthy populations with adequate nutrition. Supplement exposure is complicated by exposure to nutrients through dietary intake, and some studies reported fairly high levels of independent use of supplements among their study populations. There is variability in how individuals absorb and metabolize nutrients, and interactions among nutrients and between nutrients and myriad enzymes and hormones in the human body complicate our ability to detect their effects. Relatedly, many of the included studies used factorial designs with other background chemoprevention agents in some participants, such as other vitamins and minerals, aspirin, omega-3 fatty acids, and cocoa extract. Another limitation is that we had minimal evidence available to explore the impact of dose for most supplements. Supplement doses were wide ranging and the only supplement with sufficient data to explore dose-response associations was vitamin D. More generally, there may be other doses, formulations, or supplement combinations that could be beneficial or less harmful that we did not have the data to explore.

In addition, there are some limitations related to the reporting of outcomes. First, many studies did not report full ascertainment of the primary outcomes for our review. This was primarily the case in studies where CVD and cancer prevention were not primary aims, in which CVD and cancer outcomes were collected through adverse event reporting, sometimes in an open-ended manner. Despite this, many supplements had evidence in more directly relevant studies that were adequately powered for the outcomes relevant to our review, so while these studies add some “noise” to the review, we were still able to draw conclusions with moderate or high strength of evidence for several supplements, including vitamin D, vitamin E, and calcium. Second, many studies reported dozens of outcomes, so some statistically significant findings may be occurring due to chance. Third, effects on such long-term outcomes as cancer, CVD, and all-cause mortality are likely subtle in otherwise healthy adults with reasonably healthy eating patterns, and are presumed to take many years to manifest. Most trials followed patients for less than 10 years, many less than three years, so effects may not yet be realized. One the other hand, there were some large studies with long-term follow-up, particularly among trials of beta-carotene and vitamin E.

Evidence on the impact of supplementation in some important populations was lacking. There was minimal representation of people who are Black, Indigenous, or people of color across all supplements. Some vitamin D trials were limited to older Black women, however these were focused on bone density and provided minimal evidence for CVD and cancer prevention. In addition, although women were generally well-represented for most supplements, there was only one large trial of a broad-spectrum multivitamin that included women, and it was limited by having a median of only 3.6 years of supplement use and followup.

## Future Research Needs

Continued long-term surveillance of participants in the large, included trials of vitamin D would be valuable, since effects on cancer, CVD and mortality may take a decade or more to manifest. Similarly, continued surveillance of the COSMOS trial of a broad-spectrum multivitamin for cancer and CVD prevention would be important as its median followup of 3.6 years is likely too short to detect effects for these outcomes. We urge the investigators conducting these studies to report on the impact of supplement use in racial and ethnic groups, particularly for vitamin D, given an intriguing (albeit post-hoc) signal that vitamin D supplementation may reduce the risk of cancer in Black adults.^94^ In the United States, Black adults experience disproportionately high incidence of some cancers and a higher risk for vitamin D deficiency, likely due to the impact of melanin on the synthesis of vitamin D.^194–196^ We acknowledge, however, that racial and ethnic inequities in health outcomes are multifactorial and also involve nonbiologic factors.

The evidence base demonstrating no benefit of vitamin E on cancer and CVD is robust and does not warrant resource investment in major new de novo studies. However, examination of CVD mortality with robust ascertainment in the included vitamin E studies that did not report this outcome would be valuable, as well as continued followup of CVD mortality in the existing trials. Such additional followup could be valuable to elucidate the long-term impact on this important outcome with a signal for possible benefit. In addition, the contradictory findings for prostate cancer among between ATBC (which showed an increased risk) and SELECT (which showed a decreased risk) warrants continued followup in these studies and examination in other large vitamin E studies that did not report this outcome.

Most research to date on folic acid for CVD and cancer prevention has been focused on secondary prevention in persons with known CVD, which were not included in our review. Because these reviews suggest a possible reduction in CVD events, particularly stroke, it remains plausible that folic acid could help prevent CVD in general populations as well. Therefore, studies sufficiently powered for CVD outcomes with long-term followup could be valuable. Also, the effect of folic acid administered with other B vitamins on CVD and cancer outcomes remains understudied. There is some evidence that folic acid coupled with vitamins B6 and B12 may reduce homocysteine levels, and therefore large, long-term controlled trials to examine the impact of these B vitamins on CVD may warrant further investigation. However, these possible benefits must be weighed against the weak evidence we found that folic acid may increase the risk of cancer incidence. Examination of overall cancer incidence, colorectal cancer, and prostate cancer as outcomes in studies that have not yet reported them would be valuable first steps before planning larger CVD prevention studies, as would longer-term followup on cancer outcomes in studies that did report them.

Studies of the effects of vitamin C in preventing cancer and CVD for women and people of color may be valuable, given the paucity of this evidence. However, careful monitoring of participants for early indications of kidney stone formation may be important, since we found weak evidence of an increased risk of kidney stones in men.

Given the risks identified for beta-carotene, we see no need for further research on the role of beta-carotene in CVD and cancer prevention, nor, by extension, for vitamin A.

## Conclusions

Vitamin and mineral supplementation provides little to no benefit in preventing cancer, CVD, and death, with the exception of a benefit for cancer-related mortality and a possible small benefit for cancer incidence with multivitamin use, where lung cancer showed the largest benefit. Beta-carotene is associated with increased risk of lung cancer and other harmful outcomes in persons at high risk of lung cancer. Data were absent or insufficient to draw conclusions for any of the B vitamins, iron, zinc, or magnesium.