# Chapter 3 Results

## Description of Included Studies

A total of 84 studies (n=739,803) were included, comprising 78 RCTs (n= 324,837)^63–65,^ ^72–145^ and six cohort studies (n=390,689),^124,^ ^146–151^ which are listed in Appendix B. Throughout this report, we will be citing the primary publication from these included studies; ancillary publications that were also considered are listed in Appendix B. These studies addressed multivitamins, vitamins A, B3, B6, B12, C, D, E, beta-carotene, folic acid, calcium, selenium, zinc, and magnesium. Seventeen of the studies were included only for harms (KQs 2 and 4), including all of the cohort studies. Overall, 60 studies were newly identified and not included in the previous review. Many of the newly-included studies became eligible due to our more inclusive approach to studies reporting harms or all-cause mortality without CVD or cancer outcomes, but 25 were newly published since the previous review. Most of the new studies since the previous recommendation evaluated vitamin D with or without calcium (38 studies) or multivitamins (9 studies). We found no eligible studies addressing benefits or harms of iron, niacin, or vitamins B1 or B2.

The weighted average age across all included studies was 61.0 years. An estimated 65.1 percent of all participants were women. Among the 36 studies conducted in the United States, 22 provided any information on participants’ race or ethnicity. Most participants were non-Hispanic White in studies conducted in the US; in the 16 studies reporting the percent of Black participants, an estimated 19.6 percent were Black. Representation of other racial and ethnic groups was substantially lower. Studies conducted outside of the US were in Canada, European countries, Australia, and New Zealand. Additional detailed participant characteristics are reported within sections addressing specific supplements.

Across the entire body of evidence, 26 studies (31.0%) had a stated aim of cancer or CVD prevention. The primary aims of the remaining studies were wide ranging. Primary aims in some of the other studies were related to cancer or CVD, such as prevention of colorectal adenomas or CVD risk factors, and other studies’ aims were not, such as prevention of bone density loss and fractures, infections, cataracts, or improving mental health and cognitive function.

## KQ1 and KQ2 What Is the Efficacy of Multivitamin Supplementation for Reducing CVD, Cancer, and Mortality in the General Adult Population? What Are the Harms of Multivitamin Supplementation in the General Adult Population?

### Summary of Results

Thirteen studies of multivitamin use were included (n=240,132, Table 5), comprising ten RCTs (n=52,105)^72,^ ^81,^ ^86,^ ^96,^ ^101,^ ^107,^ ^123,^ ^125,^ ^134,^ ^152^ and three cohort studies (n=188,027).^146,^ ^148,^ ^151^ Most studies had study aims other than the prevention of CVD and cancer, but three large good-quality trials had dual prevention aims of CVD and cancer. These were SUpplementation en VItamines et Minéraux AntioXydants (SU.VI.MAX, n=13,017),^72^ which examined an antioxidant-focused supplement among adults age 35 to 60 years; the Physicians’ Health Study II (PHS-II, n=14,641), which examined a broad-spectrum supplement among male physicians age 50 and older;^81^ and COcoa Supplement and Multivitamin Outcomes Study (COSMOS), which examined a broad-spectrum supplement among adults age 60 (men) or 65 (women) and older.^152^ Four of the thirteen studies were included in the previous review,^72,^ ^81,^ ^86,^ ^146^ including SU.VI.MAX and PHS-II, as well as the largest cohort study.^146^ Four studies were conducted in the US.^81,^ ^86,^ ^146,^ ^152^ The age ranges in the studies varied considerably, and the average age across all studies was 59.8 years. Among the RCTs, the specific formulations of micronutrients varied (Table 6). Followup times ranged from 8 weeks to 13 years.

Table 5 Table of Study, Intervention, and Population Characteristics for Studies of Multivitamin Use, Sorted by Study Design, Then Author (KQ1 and KQ2)

Author, Year (Study); Quality | In previous | Study N^*^ (% FUP) | Type | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ1 | KQ2 | Ascertainment
RCT
Avenell, 2005 (MAVIS)^107^; Fair | | 910 (91.6%) | Broad | 1 (1) | GBR | Other: Infection-related morbidity | Adults age ≥65 years | Mean age: 72; % Female: 47; % White: NR; % Black: NR; Mean BMI: 28.0; % Curr. smoker: 13 | | X | X | ACM: NR; Ca: NA; CVD: NA
Baeksgaard, 1998^125^; Fair | | 240 (82.9%) | Broad | 2 (2) | DNK | Other: Bone mineral density | Women aged 58-67 years | Mean age: 62; % Female: 100; % White: 100; % Black: 0; Mean BMI: NR; % Curr. smoker: NR | Ca: 2.3 mmol/L | X | X | ACM: NR; Ca: NA; CVD: NA
Bonelli, 2013^96^ (NA); Fair | | 411 (80.3%) | Antiox. | 5 (5) | ITA | Other: Recurrent colorectal adenoma | Adults aged 25-75 years with at least one adenoma recently removed from colon | Mean age: 58; % Female: 38; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | | X | | ACM: NR; Ca: NR; CVD: NA
Chylack, 2002 (REACT)^86^; Fair | X | 297 (100%) | Antiox. | 2.8 (2.8) | USA, GBR | Other: Age-related cataracts | Adults age ≥40 years with early cataract | Mean age: 66; % Female: 59; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 19 | | X | X | ACM: NR; Ca: NR; CVD: NR
CTNS Study Group, 2008 (CTNS)^134^; Good | | 1020 (99.3%) | Broad | 13 (13) | ITA | Other: Age-related cataract | Adults aged 55 to 75 years with early cataract or no cataract | Mean age: 68; % Female: 45; % White: NR; % Black: NR; Mean BMI: 27.9; % Curr. smoker: 18 | | X | X | ACM: Full; Ca: Self-report; CVD: Self-report
Hercberg, 2004 (SU.VI.MAX)^72^; Good | X | 13017 (93.5%) | Antiox. | 8 (7.5, 8.9, 12.5) | FRA | CVD, Cancer | Adults age 35-60 years | Mean age: 48; % Female: 60; % White: NR; % Black: NR; Mean BMI: 23.8; % Curr. smoker: 16 | | X | X | ACM: Full; Ca: Full; CVD: Full
Pike, 1995^123^; Fair | | 47 (74.5%) | Broad | 1 (1) | CAN | Other: Immune function | Adults age 60 or older | Mean age: 69; % Female: 72; % White: 100; % Black: 0; Mean BMI: NR; % Curr. smoker: NR | | X | X | ACM: Full; Ca: NR; CVD: NA
Rucklidge, 2014^101^; Fair | | 80 (92.5%) | Broad | 0.15 (0.15) | NZL | Other: ADHD | Age ≥16 years with ADHD | Mean age: 35; % Female: 34; % White: 80; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | | | X | ACM: NA; Ca: NA; CVD: NA
Sesso, 2008 (PHS-II)^81^; Good | X | 14641 (98.0%) | Broad | 11.2 | USA | CVD, Cancer | US male physicians aged ≥ 50 years | Mean age: 64; % Female: 0; % White: NR; % Black: NR; Mean BMI: 26; % Curr. smoker: 4 | | X | X | ACM: Full; Ca: Full; CVD: Full
Sesso, 2022 (COSMOS)^152^; Good | | 21442 (97.7%) | Broad | 3.6 | USA | CVD, Cancer | Age ≥65 (women) or ≥60 (men) years without history of MI, stroke, or recent cancer | Mean age: 72; % Female: 59; % White: 90; % Black: 5.3; Mean BMI: 26.8; % Curr. smoker: 44.6 | | X | X | ACM: Full; Ca: Full; CVD: Full
Cohort
Feskanich, 2002 (NHS-I)^146^; Fair | X | 121700 (Varies) | Varied | <2; 2-4; <5; 5-9; ≥10; 10-14; ≥15; (12, 18, 20.9) | USA | Other: Hip fractures, kidney stones, cataracts | Postmenopausal registered nurses age 30-55 years | Mean age: 58; % Female: 100; % White: NR; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 26 | | | X | ACM: NA; Ca: NA; CVD: NA
Rautiainen, 2010 (SMC)^151^; Fair | | 38984 (63.1%) | Varied | 8.2 (8.2) | SWE | Other: Cataract | Women aged 49-83 years | Mean age: 61; % Female: 100; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 25 | | | X | ACM: NA; Ca: NA; CVD: NA
Zheng Selin, 2013 (COSM)^148^; Fair | | 27343 (100%) | Varied | 11 (8.4, 11) | SWE | Other: Cataracts | Men age 45-79 years | Mean age: 58; % Female: 0; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 25 | | | X | ACM: NA; Ca: NA; CVD: NA

* Includes participants randomized to all intervention groups, including for supplements other than multivitamins.

Abbreviations: ACM = All-cause mortality; ADHD = Attention hyper deficit disorder; Antiox. = Antioxidant; BC = Beta carotene; BL = Baseline; BMI = Body mass index; Ca = Calcium; COSM = Cohort of Swedish Men; CTNS = Clinical Trial of Nutritional Supplements and Age-Related Cataract; Curr. = Current; CVD = Cardiovascular disease; FUP = Follow up; MAVIS = Mineral and Vitamin Intervention Trial; NA = Not applicable; NHS-I = Nurse’ Health Study; NR = Not reported; PHS-II = Physicians’ Health Study; RCT = Randomized controlled trial; REACT = Roche European American Cataract Trial; SMC = Swedish Mammography Cohort; SUVIMAX = The Supplémentation en Vitamines et Minéraux Antioxydants; Vit E = Vitamin E; Vit C = Vitamin C.

Table 6 Vitamin and Mineral Components in the Multivitamin Trials

Vitamin/mineral | Units | Bonelli, 2013^96^ | REACT^86^ | SU.VI.MAX^72^ | Baeksgaard, 1998^125^ | CTNS^134^ | MAVIS^107^ | Pike, 1995^123^ | COSMOS, 2022^152^ | PHS-II^81^ | Rucklidge, 2014^101^
Number of components | | 4 | 3 | 5 | 13 | 26 | 16 | 16 | 29 | 31 | 27
Multivitamin Type | | Antioxidant | Antioxidant | Antioxidant | Broad | Broad | Broad | Broad | Broad | Broad | Broad
Beta-carotene | IU/day | | 30,006 | 1,000 | | | | | * | *
Boron | mg/day | | | | | | | | | 0.15 | 2.4
Calcium | mg/day | | | | | 162 | | 162 | 220 | 200 | 1,320
Chloride | mg/day | | | | | 36.3 | | | 72 | 72.6
Chromium | mcg/day | | | | | 25 | | | 50 | 130 | 624
Copper | mg/day | | | | | 2 | 0.75 | 1.5 | 0.5 | 2 | 7.2
Iodine | mcg/day | | | | | 150 | 150 | 225 | 150 | 150 | 204
Iron | mg/day | | | | | 18 | 14 | 27 | | 4 | 13.7
Magnesium | mg/day | | | | | 100 | 0 | 100 | 50 | 100 | 600
Manganese | mg/day | | | | | 2.5 | 1 | | 2.3 | 3.5 | 9.6
Molybdenum | mcg/day | | | | | 25 | | | 45 | 160 | 144
Nickel | mcg/day | | | | | | | | 5 | 5 | 29.4
Phosphorus | mg/day | | | | | 125 | | | 20 | 48 | 840
Potassium | mg/day | | | | | 40 | | | 80 | 80 | 240
Selenium | mcg/day | 200 | | 100 | | 25 | | | 19 | 20 | 204
Silicon | mg/day | | | | | | | | 2 | 2
Vanadium | mcg/day | | | | | | | | 10 | 10 | 1,194
Vitamin A | IU/day | 6,666 | | | 2,666 | 5,000 | 2,326 | 2,668 | 2,500 | 5,000 | 5,760
Vitamin B1 (Thiamin) | mg/day | | | | | 1.5 | 1.4 | 2.18 | 1.5 | 1.5 | 18
Vitamin B12 | mcg/day | | | | 1,400 | 6 | 1 | 9 | 25 | 25 | 900
Vitamin B2 (Riboflavin) | mg/day | | | | 1.6 | 1.7 | | 2.6 | 1.7 | 1.7 | 13.5
Vitamin B3 (Niacin or Nicotinamide) | mg/day | | | | 18 | 20 | 18 | 30 | 20 | 20 | 90
Vitamin B5 (Pantothenic acid) | mg/day | | | | 6 | 10 | 6 | | 10 | 10 | 12.6
Vitamin B6 | mg/day | | | | | 2 | | 3.65 | 3 | 3 | 36
Vitamin B7 (Biotin) | mcg/day | | | | 150 | 30 | | | 30 | 30 | 1,080
Vitamin B9 (Folic acid) | mcg/day | | | | 100 | 400 | 200 | 400 | 400 | 400 | 1,440
Vitamin C | mg/day | 180 | 750 | 120 | 60 | 60 | 60 | 90 | 60 | 60 | 600
Vitamin D | IU/day | | | | | 400 | 200 | 200 (D2) | 1000 | 400 | 1,440
Vitamin E | IU/day | 44.7 | 330 | 30 mg^†^ | 14.9 | 30 | 11 | 67.05 | 50 | 45 | 360
Vitamin K | mcg/day | | | | | 25 | | | 30 | 10
Zinc | mg/day | 30 | | 20 | 0 | 15 | 15 | 22.5 | 11 | 15 | 48
Other | | | | | Participants also received 1000 mg calcium carbonate and 560 IU cholecalciferol | | 2 mg pyridoxine | | | | Choline bitartrate (540 mg), dl-Phenylalanine (360 mg), Citrus bioflavonoids (240 mg), Inositol (180 mg), Glutamine (180 mg), Methionine (60 mg), Grape seed (45 mg), Ginkgo biloba (36 mg), Germanium sesquioxide (20.7 mg)

* 40 percent as beta-carotene supplemented as vitamin A.

† Unknown type of vitamin E.

Note: Empty cells mean that the vitamin/mineral was not a part of the pill or capsule.

Abbreviations: CTNS=Clinical Trial of Nutritional Supplements; IU = international unit(s); MAVIS = Mineral and Vitamin Intervention Trial; mcg = microgram(s); mg = milligram(s); PHS-II = Physicians’ Health Study II; REACT = Roche European American Cataract Trial; SU.VI.MAX = SUpplementation en VItamines et Minéraux AntioXydants.

Nine RCTs reported KQ1 outcomes (n=51,945)^72,^ ^81,^ ^86,^ ^96,^ ^107,^ ^123,^ ^125,^ ^134,^ ^152^ and KQ2 outcomes were reported in 9 RCTs (n=51,614)^72,^ ^81,^ ^86,^ ^101,^ ^107,^ ^123,^ ^125,^ ^134^ and 3 cohort studies (n=188,027).^146,^ ^148,^ ^151^ The evidence suggested small to no benefits of multivitamin use for all-cause mortality, CVD, and cancer outcomes. The pooled OR for all-cause mortality was a statistically non-significant 0.94 (95% CI, 0.87 to 1.01; 9 RCTs [n=51,550]; I^2^=0%, Figure 2, Appendix E Figure 1). The largest trial, COSMOS, reported that 3.4 percent of participants taking a multivitamin had died after a median of 3.6 years followup, compared with 3.6 percent who were taking a placebo (HR, 0.93 [95% CI, 0.81 to1.08], n=21,442).^152^ The pooled effect sizes were similar for cancer mortality (OR, 0.94 [95 % CI, 0.81 to 1.09]; 4 RCTs; n=37,400; I^2^=28.9%) and cancer incidence (OR, 0.93 [95 % CI, 0.87 to 0.99]; 4 RCTs; n=48,859; I^2^=0.01%). For cancer incidence, which showed a statistically significant pooled effect, 4.8 percent of participants in COSMOS taking a multivitamin had developed invasive cancer after 3.6 years, compared with 5.0 percent taking placebo (HR, 0.97 [95% CI, 0.86 to1.09], n=21,442).^152^ The pooled effect was also statistically significant for lung cancer, however this was reported in only two trials (OR, 0.75 [95% CI, 0.58 to 0.95]; 2 RCTs, n=36,052; I^2^=30) None of the individual or pooled results indicated a benefit for CVD-related outcomes. There was no indication that multivitamin use increased the risk of serious harm.

Figure 2 Meta-Analysis or Best Evidence Summary for Multivitamins^*^ * I-squared values shown for analyses using the MH model are taken from sensitivity analyses using random effects models; the MH model is based on a fixed effect model where calculation of I-squared is not applicable because it is assumed to be 0. If data were insufficient for meta-analysis, findings from the largest and most comprehensive study reporting the outcome are presented.

Note: Supplement type (column 2) refers to whether the included studies examined broad spectrum multivitamins (“Broad”), antioxidant focused multivitamins (“Antiox.”), or both (“Both”).

Abbreviations: CG = Control group; CI = Confidence interval; CVD = cardiovascular disease; IG = Intervention group; MH = Mantel-Hantzel; MI = Myocardial infarction; NA = Not applicable; OR = Odds ratio; PHS-II = Physicians’ Health Study II; REML-KH = Restricted Maximum Likelihood model with the Knapp-Hartung adjustment; SU.VI.MAX = SUpplementation en VItamines et Minéraux AntioXydants.

This figure is a forest plot showing meta-analysis or best evidence summary for multivitamins

### Detailed Study Characteristics

Thirteen studies of multivitamin use were included (n=240,132, Table 5), comprising ten RCTs (n=52,105)^72,^ ^81,^ ^86,^ ^96,^ ^101,^ ^107,^ ^123,^ ^125,^ ^134,^ ^152^ and three cohort studies (n=188,027).^146,^ ^148,^ ^151^ The best evidence comes from three large good-quality studies with primary aims of CVD and cancer prevention: SU.VI.MAX (n=13,017)^72^ of adults age 35 to 60 years; PHS-II (n=14,641) of male physicians age 50 and older;^81^ and COcoa Supplement and Multivitamin Outcomes Study (COSMOS), which examined a broad-spectrum supplement among adults age 60 (men) or 65 (women) and older.^152^ Four of thirteen studies were included in the previous review,^72,^ ^81,^ ^86,^ ^146^ including SU.VI.MAX and PHS-II, as well as the largest cohort study.^146^

The studies were conducted in the U.S., Canada, New Zealand, and European countries. Across all studies, the average age was 59.8 years, and 76.18 percent of participants were women. Race and ethnicity were typically not reported, and ranged from 80 to 100 percent White in the few trials that provided these data.^101,^ ^123,^ ^125,^ ^152^

The specific supplement combinations in the RCTs varied and included both broad-spectrum formulations and those that focused on antioxidants. Followup times among the RCTs ranged from 8 weeks to 13 years. The RCT with 8-week followup was only included for harms.^101^ COSMOS (n=21,442)^152^ and PHS-II (n=14,641),^81^ both conducted in the U.S., examined the effects of a broad-spectrum multivitamin (Centrum® Silver®) that included 29 to 31 different specific nutrients, taken daily for a median of 3.6^152^ and 11.2 years.^81^ PHS-II also evaluated vitamin E, vitamin C, and beta-carotene in addition to the multivitamin in a 2x2x2x2 factorial design while COSMOS also examined cocoa extract in a 2x2 factorial design. SU.VI.MAX (n=14,641),^72^ conducted in France, studied the effects of a multivitamin that focused more narrowly on supplements with antioxidant properties, including vitamins A and E, selenium, beta-carotene, and zinc, taken daily for 8 years. Some non-vitamin or mineral substances were included in some supplements, such as lycopene in the PHS-II supplement,^81^ and herbal substances such as ginkgo biloba in another trial.^101^

Three large cohorts provided additional evidence on harms with followup ranging from 8 to 18 years, and one study^146^ examined several different use durations. Specific dosing was unknown in the cohort studies and was captured by self-report.

### Detailed Results by Outcome

Nine RCTs reported KQ1 outcomes (n=51,945)^72,^ ^81,^ ^86,^ ^96,^ ^107,^ ^123,^ ^125,^ ^134,^ ^152^ and KQ2 outcomes were reported in 9 RCTs (n=51,614)^72,^ ^81,^ ^86,^ ^101,^ ^107,^ ^123,^ ^125,^ ^134,^ ^152^ and 3 cohort studies (n=188,027).^146,^ ^148,^ ^151^ See Appendix F Table 1 for a summary of findings for each trial and Appendix F Table 2 for a listing of results from all pooled analyses. Comprehensive and detailed study-level results are available in Appendix F Tables 3, 4, 5, and 6.

#### All-Cause Mortality (KQ1)

All-cause mortality was reported in nine trials.^72,^ ^81,^ ^86,^ ^96,^ ^107,^ ^123,^ ^125,^ ^134,^ ^152^ The largest trials showed small effect sizes in the direction of benefit that were not statistically significant.^72,^ ^81,^ ^152^ The largest effect was reported by SU.VI.MAX; after 7.5 years, 1.2 percent taking an antioxidant-focused multivitamin had died, compared with 1.5 percent taking a placebo.^72^ This finding was very close to being statistically significant (RR, 0.77 [95% CI, 0.57 to 1.00]). The effect was smaller and not statistically significant after 12 years (RR, 0.87 [95% CI, 0.70 to 1.04]). The largest trial, COSMOS, reported that 3.4 percent of participants taking a multivitamin died after a median of 3.6 years followup, compared with 3.6 percent who were taking a placebo (HR, 0.93 [95% CI, 0.81 to 1.08], n=21,442). PHS-II reported 18.4 percent all-cause mortality among men taking a broad-spectrum multivitamin after a median of 11.2 years, compared with 19.3 percent who were not taking the multivitamin (HR, 0.94 [95% CI, 0.88 to 1.02]).^81^ The overall mortality rate was lower in COSMOS and SU.VI.MAX than PHS-II, consistent with the mean age being 16 years younger in SU.VI.MAX than PHS-II and the substantially longer followup in PHS-II than COSMOS. The pooled effect was consistent with these studies and was not statistically significant (OR 0.94 [95% CI, 0.87 to 1.01]; 9 RCTs [n=30,108]; I^2^=0%, Figure 2). The effect size was very similar when limited to studies with full ascertainment and was not statistically significant (Appendix F Table 2).

SU.VI.MAX^72^ examined the effect of multivitamin use on all-cause mortality by gender, and although the interaction term with gender was not statistically significant, it found reduced mortality in men at 7.5 year follow (RR, 0.63 [95% CI, 0.42 to 0.93]) but not women (RR, 1.03 [95% CI, 0.64 to 1.63]). This effect was less pronounced at the 12-year followup when the effect size for men was no longer statistically significant (RR, 0.78 [95% CI, 0.59 to 1.04]), vs. RR, 0.99 [95% CI, 0.71 to 1.38]) in women. No other studies reported mortality outcomes in specific populations, such as by gender, age, race, or ethnicity.

#### Cardiovascular Outcomes (KQ1)

Cardiovascular events were reported in five trials^72,^ ^81,^ ^86,^ ^134,^ ^152^ but only COSMOS,^152^ PHS-II^81^ and SU.VI.MAX^72^ reported full ascertainment of CVD outcomes (and had primary aims of CVD prevention). All three of these trials found no association between multivitamin use and CVD events. The outcome reported by the most studies was CVD mortality, which demonstrated no association with multivitamin use in the pooled analysis (OR, 0.94 [95 % CI, 0.83 to 1.06]; 4 RCTs; n=37,400; I^2^=0%, Figure 2, Appendix E Figure 2). Effect sizes from COSMOS or from combining COSMOS and PHS-II ranged from 0.96 (95% CI, 0.84 to 1.11) for MI to 1.06 (95% CI, 0.93 to 1.22) for stroke for other CVD outcomes.

SU.VI.MAX reported examination of differential effects on CVD outcomes for our a priori specific populations; it found that effects did not differ for men and women. In addition, PHS-II^81^ found a differential effect across age groups in cardiovascular events (interaction p=0.041). The largest difference was between men aged 50 to 59 (HR, 1.27; 95% CI 0.99 to 1.63) and men aged 70 years and older (HR, 0.91; 95% CI 0.81 to 1.03). PHS-II found no suggestion of variability in effect across other clinical, lifestyle, familial, biochemical or dietary risk factors. PH-II was limited to men, so could not examine differences by gender. No other studies reported outcomes in specific populations, such as by gender, age, race, or ethnicity.

#### Cancer (KQ1)

Five trials reported cancer outcomes,^72,^ ^81,^ ^86,^ ^134,^ ^152^ but again, only COSMOS,^152^ PHS-II^81^ and SU.VI.MAX^72^ reported full cancer ascertainment. The pooled result for cancer incidence suggested a small benefit (OR, 0.93 [95% CI, 0.87 to 0.99]; 4 RCTs; N=48,859; I^2^=0.01%, Figure 2, Appendix E Figure 3), however multivitamin use conferred no benefit for colorectal, breast, or prostate cancer, specifically. In addition, no benefit was seen for cancer mortality (OR, 0.94 [95% CI, 0.81 to 1.09]; 4 RCTs; N=37,400; I^2^=28.9%, Figure 2, Appendix E Figure 3) COSMOS reported that 4.8 percent of multivitamin users developed invasive cancer after a median of 3.6 years, compared to 5.0 percent taking a placebo (HR, 0.97 [95% CI, 0.86 to 1.09). COSMOS found no differences in the incidence of colorectal, breast, or prostate cancer, however they did report a statistically significant reduction in lung cancer incidence (HR, 0.62 [95% CI, 0.42 to 0.92]; 0.4% taking a multivitamin vs. 0.6% taking placebo).^152^ The pooled effect for lung cancer combining COSMOS with PHS-II also indicated a possible benefit, with an absolute reduction of 0.2 percent in both trials (OR, 0.75 [95% CI, 0.58 to 0.95]; 2 RCTs, n=36,052; I^2^=30%) n PHS-II, overall cancer incidence demonstrated a small, statistically significant effect after 11.2 years (HR, 0.92 [95% CI, 0.85 to 1.00], p=.04), but findings were not statistically significant for colorectal, lung, or prostate cancer.^81^ SU.VI.MAX reported small, statistically non-significant effect sizes in the direct of benefit for any cancer incidence at 7.5 years (RR, 0.90 [95% CI, 0.76 to 1.06]) and 12.5 years (RR, 0.93 [95% CI, 0.82 to 1.05)]. At 7.5 years, 4.2 percent of participants taking the antioxidant supplement developed cancer, compared with 4.6 percent taking placebo. SU.VI.MAX also reported a number of site-specific cancers, and effect sizes were wide ranging, reflecting the small number of events; most were in the direction of a benefit, but none were statistically significant.^72^

SU.VI.MAX^72^ found an interaction between cancer incidence and gender, such that there was a protective effect of multivitamin use in men (RR, 0.69 [95% CI, 0.53 to 0.91] but not women (RR, 1.04 [95% CI, 0.85 to 1.29). In addition, PHS-II^81^ found that the effect on any cancer incidence was largest among men age 70 years or older (HR, 0.82 [95% CI, 0.72 to 0.93, vs. HRs 0.96 and 1.01 in among ages 50-59 and 60-69, respectively). However, this interaction was not statistically significant (p=0.06). No other studies reported outcomes in specific populations, such as by gender, age, race, or ethnicity.

#### Adverse Events (KQ2)

Four of the trials reported no group differences in any adverse effects,^107,^ ^134^ serious adverse effects,^86^ or withdrawals due to adverse effects,^101^ although very few events were reported for the serious adverse effects or withdrawals due to adverse effects (Appendix F Table 6). Small increases in cataracts^146,^ ^151^ and hip fractures^146^ reported by cohort studies were not statistically significant and were not examined in any of the trials. There was evidence of no effect modification by age or smoking status on cataracts in NHS-I.^146^ Several studies found no clear increased risk in gastrointestinal-related outcomes (nausea, constipation, GI symptoms, or GI-related hospitalizations), but most were hampered by small sample sizes and reported very few events.^101,^ ^123,^ ^125,^ ^134^ PHS-II found an increased risk of skin rash (29.0% among multivitamin users, 27.3% among non-multivitamin users; OR, 1.06 [95% CI, 1.01 to 1.12]) and epistaxis (21.6% among multivitamin users, 19.8% among non-multivitamin users; OR, 1.09 [95% CI, 1.02 to 1.16]). However, these findings were not replicated in COSMOS, which found no differences in these outcomes and very few differences in a long list of other potential side effects.^152^

## KQ3 and KQ4 What Is the Efficacy of Supplementation With Single Nutrients or Functionally Related Nutrient Pairs for Reducing CVD, Cancer, and Mortality in the General Adult Population? What Are the Harms of Supplementation With Single Nutrients in the General Adult Population?

Results for KQs 3 and 4 are organized by supplement, with results for KQ4 (harms) immediately following results for KQ3 (benefits) for each supplement or supplement group. The order of the supplements is: fat soluble (beta-carotene and vitamin A, vitamin D, vitamin E), water-soluble (B vitamins, vitamin C), and minerals (calcium, selenium, zinc, magnesium).

### Beta-Carotene and Vitamin A

We discuss beta-carotene and vitamin A together since they are functionally related supplements. Beta-carotene is a vitamin A precursor, which is converted by the body into vitamin A.

#### Summary of Results

##### Beta-Carotene

Seven studies of beta-carotene supplementation with or without the use of other supplements were included (n=234,520, Table 7): 6 RCTs (n=112,820)^63,^ ^73–76,^ ^87^ and one cohort study (n=121,700).^146^ There are no newly included studies in this update. The included trials had a variety of study aims and primary outcomes. Two studies—PHS-I^75^ and the Women’s Health Study (WHS)^74^ —had broad cancer and CVD prevention aims and the remaining focused more narrowly on the prevention of lung cancer^63,^ ^76^ and skin cancer,^73,^ ^87^ all but one study targeting populations at high risk for cancer.^73^ Doses of beta-carotene ranged from 20 to 50 mg/day and was co-administered with high-dose vitamin A in CARET^63^ (25,000 IU/day, exceeding the current recommended upper limit). Duration of use ranged from 4 years in a study terminated early due to harm,^63^ to 12 years.^75^ Five of seven included studies were conducted in the U.S.^63,^ ^74,^ ^75,^ ^87,^ ^146^

Table 7 Table of Study, Intervention, and Population Characteristics for Studies of Beta-Carotene Use (With or Without Vitamin A), Sorted by Study Design, Then Author (KQ3 and KQ4)

Author, Year (Study); Quality | In previous | Study N^*^ (% FUP) | Daily dose | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ3 | KQ4 | Ascertainment
RCT
ATBC Study Group, 1994 (ATBC)^76^; Good | X | 29133 (100%) | IG1: 40000 mcg RAE + 111 IU Vitamin E; IG2: 40000 mcg RAE | 6.1 (6.1, 8, 11, 14, 22.1, 24.1) | FIN | Cancer | Male smokers age 50-69 years | Mean age: 57; % Female: 0; % White: NR; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 100 | BC: 0.32 mcmol/L; Vit A: 2.01 mcmol/L; Vit E: 26.7 mcmol/L | X | X | ACM: Full; Ca: Full; CVD: Full
Green, 1999 (NSCPS)^73^; Good | X | 1621 (85.3%) | 60000 mcg RAE | 4.5 (4.5) | AUS | Cancer | Adults, age 20-69 years | Mean age: 49; % Female: 56; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | NR | X | X | ACM: NR; Ca: Full; CVD: NR
Greenberg, 1990 (SCPS)^87^ | X | 1805 (100%) | 100000 mcg RAE | 4.3 (2, 5, 8.2) | US | Cancer | Adults aged <85 years with prior biopsy-proven basal or squamous cell carcinoma | Mean age: 63; % Female: 31; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 19 | BC: 0.42 mcmol/L | X | X | ACM: Full; Ca: Full; CVD: Full
Hennekens, 1996 (PHS-I)^75^; Good | X | 22071 (99.9%) | 50000 mcg RAE | 12 (12, 12.9) | US | CVD, Cancer | Male physicians age 40-84 years | Mean age: 53; % Female: 0; % White: NR; % Black: NR; Mean BMI: 24.9; % Curr. smoker: 11 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Lee, 2005 (WHS)^74^; Good | X | 39876 (99.4%) | 50000 mcg RAE | 4.1 (10) | US | CVD, Cancer | Adult females, aged ≥45 years, postmenopausal or not planning to become pregnant | Mean age: 55; % Female: 100; % White: 95; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 13 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Omenn, 1996 (CARET)^63^; Good | X | 18314 (100%) | 60000 mcg RAE + 7500 mcg RAE Vitamin A | 4 (3.7, 10, 11) | US | Cancer | Men age 45-69 years with a history of asbestos exposure or adults age 50-69 years with a history of at least 20 years of smoking | Mean age: 58; % Female: 34; % White: 93; % Black: 3; Mean BMI: NR; % Curr. smoker: 60 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Cohort
Feskanich, 2002 (NHS-I)^146^; Fair | X | 121700 (Varies%) | Varied | NR (12, 18, 20.9) | US | Other: Hip fractures, kidney stones, cataracts | Postmenopausal registered nurses age 30-55 years | Mean age: 58; % Female: 100; % White: NR; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 26 | NR | | X | ACM: NA; Ca: NA; CVD: NA

* Includes participants randomized to all intervention groups, including for supplements other than beta carotene.

Abbreviations: ACM = All-cause mortality; ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention BC =; Beta carotene; BL = Baseline; BMI = Body mass index; Ca = Calcium; CARET = The Beta-Carotene and Retinol Efficacy Trial; CVD = Cardiovascular disease; Curr. = Current; FUP = Followup; NA = Not applicable; NHS-I = Nurses’ Health Study I; NR = Not reported; NSCPS = Nambour Skin Cancer Prevention Study; PHS-I = Physicians’ Health Study-I; RAE = Retinol activity equivalents; SCPS = Skin Cancer Prevention Study; SKICAP = SKIn CAncer Prevention; Vit A = Vitamin A; Vit E = Vitamin E; WHS = Women’s Health Study.

All 6 RCTs (n=112,820) reported both KQ3 and KQ4 outcomes, plus the 1 cohort study was included for KQ4 (n=121,700). Pooled estimates for several outcomes showed statistically significant paradoxical harm associated with beta-carotene use (Figure 3). The most pronounced risk increase was for lung cancer, with the pooled estimate showing a 20 percent increased risk over 3.7 to 12 years of followup (OR 1.20 [95% CI, 1.01 to 1.42]; 4 RCTs [n=94,830]; I^2^=38.8%), including trials in general and high-risk populations. The range in absolute risk differences in individual trials was −0.1 percent to 0.6 percent. CVD mortality similarly showed an increased risk (OR 1.10 [95% CI, 1.02 to 1.19]; 5 RCTs [n=94,506]; I^2^=0%). The range in absolute risk differences in individual trials was −0.8 percent to 0.8 percent. Pooled estimates also suggested an increased risk of all-cause mortality associated with beta-carotene use, although the lower confidence interval was 1.00 (OR 1.06 [95% CI, 1.00 to 1.12]; 6 RCTs [n=112,820]; I^2^=6.4%); estimates were statistically significant in a sensitivity analysis using an alternate pooling method and when a study of vitamin A supplementation was included (Appendix F Table 7). Trials generally showed no statistically significant findings for other adverse events other than hypercarotenodermia, a nonserious and reversible yellowing of the skin.

Figure 3 Meta-Analysis Summary for Beta-Carotene^*^ * I-squared values shown for analyses using the MH model are taken from sensitivity analyses using random effects models; the MH model is based on a fixed effect model where calculation of I-squared is not applicable because it is assumed to be 0.

Abbreviations: CG = Control group; CI = Confidence interval; CVD = Cardiovascular disease; IG = Intervention group; MH = Mantel-Haenszel common (fixed) effects model; MI = Myocardial infarction; OR = Odds ratio; Peto = Peto odds ratio.

This figure is a forest plot showing meta-analysis summary for beta-carotene

##### Vitamin A

Four studies of vitamin A supplementation with or without the use of other supplements were included (n=177,014): two RCTs (n=20,611)^63,^ ^64^ and two cohort studies (n=156,403)^146,^ ^147^ (Table 8). There are no newly included studies in this update. Two of these studies are also discussed for beta-carotene: CARET, which co-administered vitamin A and beta-carotene, and the NHS-I cohort study. The two studies that only address vitamin A were the SKICAP trial—reporting all-cause mortality and any adverse events—and an additional harms cohort. SKICAP was a fair-quality U.S-based skin cancer prevention trial (n=2,297) recruiting participants with a history of more than 10 actinic keratoses and at most 2 squamous cell carcinoma or basal cell carcinoma skin cancers.^64^ SKICAP evaluated supplementation with 7,500 retinol activity equivalents (RAE) alone (25,000 IU retinol) for 5 years. This is a large dose equating to more than double the upper intake levels for preformed vitamin A.^153^

Table 8 Table of Study, Intervention, and Population Characteristics for Studies of Vitamin A Use (With or Without Beta-Carotene), Sorted by Study Design, Then Author (KQ3 and KQ4)

Author, Year (Study); Quality | In previous | Study N^*^ (% FUP) | Daily dose | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ3 | KQ4 | Ascertainment
RCT
Moon, 1997 (SKICAP)^64^; Fair | X | 2297 (%) | Vit A: 7500 mcg RAE | 3 (5, 5.1) | US | Cancer | Adults, age 21-85 years, with a history of more than 10 actinic keratoses and at most 2 squamous cell carcinoma or basal cell carcinoma skin cancers. | Mean age: 63; % Female: 30; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 12 | NR | X | X | ACM: NR; Ca: Full; CVD: NA
Omenn, 1996 (CARET)^63^; Good | X | 18314 (100%) | Vit A: 7500 mcg RAE + 60000 mcg RAE beta-carotene | 4 (3.7, 10, 11) | US | Cancer | Men age 45-69 years with a history of asbestos exposure or adults age 50-69 years with a history of at least 20 years of smoking | Mean age: 58; % Female: 34; % White: 93; % Black: 3; Mean BMI: NR; % Curr. smoker: 60 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Cohort
Feskanich, 2002 (NHS-I)^146^; Fair | X | 121700 (Varies) | Varied | <2; <3; ≥3; 2-4; 5-9; ≥10; (12, 18, 20.9) | US | Other: Hip fractures, kidney stones, cataracts | Postmenopausal registered nurses age 30-55 years | Mean age: 58; % Female: 100; % White: NR; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 26 | NR | | X | ACM: NA; Ca: NA; CVD: NA
Lim, 2004 (IWHS)^147^; Fair | X | 34703 (82.95%) | Varied | 9.5 () | US | Other: Hip fracture | Women aged 55-69 | Mean age: 62; % Female: 100; % White: 99; % Black: NR; Mean BMI: 27.0; % Curr. smoker: NR | NR | | X | ACM: NA; Ca: NA; CVD: NA

* Includes participants randomized to all intervention groups, including for supplements other than Vitamin A.

Abbreviations: ACM = All-cause mortality; BL = Baseline; BMI = Body mass index; Ca = Calcium; CARET = The Beta-Carotene and Retinol Efficacy Trial; Curr. = Current; CVD = Cardiovascular disease; FUP = Followup; IWHS = Iowa Women’s Health Study; NA = Not applicable; NHS-I = Nurses’ Health Study I; NR = Not reported; RAE = Retinol activity equivalents; RCT = Randomized controlled trial; SKICAP = SKIn CAncer Prevention; Vit A = Vitamin A.

Both RCTs (n=20,611) reported both KQ3 and KQ4 outcomes, plus the 2 cohort studies were included for KQ4 (n=156,403). In the SKICAP trial, there were 62 deaths (5.4%) in the supplementation group compared to 53 deaths (4.6%) in the placebo group during 5-years of followup (OR 1.16 [95% CI, 0.80 to 1.69]) (Figure 4).^64^ The addition of the SKICAP trial to the beta-carotene pooled estimate for all-cause mortality resulted in the same point estimate, but did make the finding statistically significant for increased harm (OR 1.06 [95% CI, 1.01 to 1.12]; 7 RCTs [n=115,117]).

Figure 4 Evidence Summary for Vitamin A

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; OR = Odds ratio; SKICAP = SKIn CAncer Prevention.

This figure is a forest plot showing the evidence summary for vitamin A

The incidence of any adverse effect was higher in participants in SKICAP randomized to vitamin A vs. those randomized to placebo (OR 1.77 [95% CI, 1.49 to 2.09]).^64^ The cohort studies suggested a possible association between vitamin A use and hip fractures, but did not indicate an association with overall fracture risk or cataracts.

#### Detailed Study Characteristics

##### Beta-Carotene

Seven studies of beta-carotene supplementation with or without the use of other supplements were included (n=227,234).^63,^ ^73–76,^ ^87,^ ^146^ These studies include six RCTs^63,^ ^73–76,^ ^87^ and one cohort study^146^ evaluating harms only (Table 7). There are no newly included studies in this update. All of the RCTs were rated as good quality. While the included cohort study, the Nurses’ Health Study,^146^ is a large cohort study that generally used good methods, we rated it as fair quality because of self-reported supplement use and the inability of cohort studies to fully adjust for potential confounders.

The included trials had a variety of study aims and primary outcomes. Two studies—PHS-I^75^ and WHS^74^—had broad cancer and CVD prevention aims. Both were factorial design trials additionally evaluating aspirin, and also vitamin E in WHS. Two trials, ATBC^76^ and CARET,^63^ had primary aims of lung cancer prevention and evaluated beta-carotene supplementation in high-risk populations such as smokers and asbestos-exposed workers. ATBC was multifactorial, with additional randomization to 50 mg/day vitamin E. Two studies, NSCPS^73^ and SCPS,^87^ were focused on beta-carotene supplementation with the aim of skin cancer prevention. NSCPS was conducted in the general population and was a 2x2 trial also including a sunscreen intervention. SCPS was a secondary skin cancer prevention study and we only include outcomes other than skin cancer because of the primary prevention focus of this review. All trials except NSCPS reported full ascertainment for all main outcomes for our review. NSCPS described outcome ascertainment for only its primary outcome of incident skin cancer.^73^ The included cohort for harms, NHS,^146^ ascertained hip fractures from self-report.

Doses of beta-carotene ranged widely in included studies, from as low as 20 mg/day in ATBC^76^ to as high as 50 mg/day in SCPS.^87^ Duration ranged from as little as 4 years in CARET,^63^ which was terminated early due to harm, to 12 years in PHS.^75^ Five of seven included studies were conducted in the U.S.^63,^ ^74,^ ^75,^ ^87,^ ^146^ Additional studies were conducted in Finland,^76^ and Australia.^73^ Where race and ethnicity were reported, the vast majority of participants were White. Mean ages ranged from 49 to 63 years. In the RCTs, the percent of participants who were female ranged from 0% to 100%, and the cohort study was limited to women.

The trials with broader cancer and CVD prevention aims were very large, with 22,071 participants in PHS-I,^75^ which were exclusively male and 39,876 participants in WHS, which was exclusively female.^74^ Eleven to 13 percent were smokers in these trials and mean BMIs were 25 to 26 kg/m^2^. The lung cancer prevention trials were also large, including 29,133 participants in ATBC^76^ and 18,314 participants in CARET.^63^ These trials were conducted primarily in men with ATBC being exclusively male and CARET 66 percent male.^63^ ATBC recruited current smokers and CARET recruited individuals with workplace asbestos exposure or a 20 pack-year history of smoking who currently smoked or quit within the previous 6 years. The skin cancer prevention studies were smaller, with 1,621 participants in NSCPS^73^ and 1,805 participants in SCPS.^87^ These studies were 44 and 69 percent male, respectively. NSCPS was conducted in the general population whereas SCPS recruited individuals with prior biopsy-proven basal or squamous cell carcinoma. Nineteen percent of the SCPS population were smokers; smoking was not reported in NSCPS. Across all studies, baseline levels of beta-carotene were sparsely reported.

##### Vitamin A

Four studies of vitamin A supplementation with or without the use of other supplements were included (n=177,014).^63,^ ^64,^ ^146,^ ^147^ These studies include two RCTs^63,^ ^64^ and two cohort studies^146,^ ^147^ evaluating harms only (Table 8). There are no newly included studies in this update.

SKICAP is the only trial that was not included in the section above on beta-carotene. It reported all-cause mortality and any adverse events. SKICAP was a fair-quality U.S-based skin cancer prevention trial recruiting participants at moderate risk for new nonmelanoma skin cancer, defined as a history of more than ten actinic keratoses and at most two squamous cell carcinoma or basal cell carcinoma skin cancers.^64^ SKICAP evaluated supplementation with 7,500 RAE alone (25,000 IU retinol) for 5 years. This is a large dose equating to more than double the upper intake levels for preformed vitamin A.^153^ SKICAP included 2,297 participants, the mean age of which was 63 years; 30 percent were female, and 12 percent were current smokers. Ascertainment methods for all-cause mortality were not described. Two large U.S.-based cohort studies evaluating vitamin A supplementation were included for harms only—the Nurses’ Health Study (n= 121,700)^146^ and the Iowa Women’s Health Study (IWHS, n= 34,703).^147^ Both cohort studies used generally good methods, but were rated as fair quality because of self-reported supplement use and the inability to fully adjust for confounders. These cohorts consisted of women who were predominately White, with mean ages between 58 and 62 years. Mean BMIs were 26 to 27 kg/m^2^. Twenty-six percent of those in the Nurses’ Health Study were current smokers and 34 percent in IWHS had ever smoked. In the Nurses’ Health Study, vitamin A exposure was ascertained every 2 years over 18 years of followup.^146^ In IWHS, vitamin A exposure was ascertained at baseline only and reported after 9 years of followup.^147^ Both cohorts ascertained the reported outcomes of fractures and cataracts through self-report.

#### Detailed Results by Outcome

All 6 RCTs (n=112,820) reported both KQ3 and KQ4 outcomes for beta-carotene, plus the 1 cohort study was included for KQ2 (n=121,700). Similarly, both RCTs (n=20,611) reported both KQ1 and KQ2 outcomes for vitamin A, plus the 2 cohort studies were included for KQ2 (n=156,403). See Appendix F Tables 8 and 9 for a summary of findings for each trial for beta-carotene and vitamin A, respectively, and Appendix F Table 7 for a listing of results from all pooled analyses. Comprehensive and detailed study-level results are available in Appendix F Tables 10, 11, 12, 13, 14, and 15.

##### All-Cause Mortality (KQ3)

All-cause mortality was reported in all six RCTs of beta-carotene.^63,^ ^73–76,^ ^87^ The pooled effect showed a statistically non-significant increased risk for all-cause mortality associated with beta-carotene use over 4 to 12 years of followup (OR 1.06 [95% CI, 1.00 to 1.12]; 6 RCTs [n=112,820]; Figure 3, Appendix E Figure 4). The increased risk for all-cause mortality was statistically significant in ATBC,^76^ a lung cancer prevention trial (ATBC: OR 1.09 [95% CI, 1.02 to 1.17], for the beta-carotene vs. no beta-carotene contrast). The odds ratio was above 1.0, although not statistically significant, in all other studies except NSCPS,^73^ which did not have full ascertainment for this outcome. The pooled results became statistically significant when dropping this study in a sensitivity analysis (OR 1.06 [95% CI, 1.01 to 1.12], 5 RTCs [n=111,199]; Appendix F Table 7). We also conducted a sensitivity analysis that was limited to studies that did not include concomitant vitamin A supplementation (e.g., dropping the CARET study). The result was identical to the full analysis (OR 1.06 [95% CI, 1.00 to 1.12], 5 RCTs [n=94,506]; Appendix F Table 7). CARET followed participants for 6 years after early termination of the randomized treatment period and an increased risk for all-cause mortality persisted (OR 1.13 [95% CI, 1.04 to 1.23]).^63^ The slightly elevated but statically non-significant increase in risk for all-cause mortality was similar at the 5 year- and extended 8.2-year followup in SCPS.^87^

One additional study of vitamin A supplementation, SKICAP, reported all-cause mortality.^64^ There were 62 deaths in the supplementation group compared to 53 deaths in the placebo group during 5-years of followup (OR 1.16 [95% CI, 0.80 to 1.69] (Figure 4). The addition of the SKICAP trial to the pooled estimate for all-cause mortality resulted in the same point estimate, but made the finding statistically significant for increased harm (OR 1.06 [95% CI, 1.01 to 1.12]; 7 RCTs [n=115,117]).

CARET found that, among heavy smokers, effect sizes were similar for men and women, but the harmful effects were only clearly present for female heavy smokers after 10 years (RR, 1.37 [95% CI, 1.16 to 1.62] for women; RR, 1.00 [95% CI, 0.89 to 1.13] for men).^63^ None of the other beta-carotene or vitamin A studies reported examination of effect modification for all-cause mortality by age, gender, race, or ethnicity. PHS-I reported that the effect of beta-carotene on all-cause mortality did not differ by smoking status (never, former, or current smoker), but no women were included in this study.^75^ The ATBC study, also limited to men, did report some variability in effects by baseline daily cigarette use and age of smoking initiation, with the largest association between beta-carotene and mortality in men who were heavier smokers and initiated smoking at age 21 years or older.^76^

##### Cardiovascular Outcomes (KQ3)

CVD mortality was the most commonly reported CVD outcome in this body of literature and was reported by all six RCTs of beta-carotene.^63,^ ^73–76,^ ^87^ The pooled effect showed a statistically significant increased risk for CVD mortality associated with beta-carotene supplementation at 4 to 12 years of followup (Peto OR 1.10 [95% CI, 1.02 to 1.19]; 5 RCTs [n=94,506]; I^2^=0%; Figure 3, Appendix E Figure 5). Absolute risk differences in individual trials ranged from −0.8 percent to 0.8 percent. Results were identical using different pooling methods and were very similar when dropping one study without full outcome ascertainment^73^ (Appendix F Table 7). However, this pooled estimate is likely an underestimate of increased risk as reporting for CARET at 3.7 year study termination was insufficient to include in pooled analyses, but suggested a larger magnitude of increased risk (RR 1.26 [95% CI, 0.99 to 1.61]).^63^ Six-year post-intervention followup in CARET showed that the CVD mortality risk dissipated after supplementation stopped (RR 1.02 [95% CI, 0.88 to 1.19]).

In addition to CVD deaths, PHS-I^75^ and WHS^74^ also reported composite CVD events, MI, and stroke. For composite CVD events, defined in both trials as nonfatal MI, nonfatal stroke, and CVD deaths, results were not statistically significant in either trial (PHS: RR 1.00 [95% CI, 0.91 to 1.09]; WHS: RR 1.14 [95% CI, 0.87 to 1.49]). Neither MI nor stroke showed an association with beta-carotene in either trial; however, WHS did show a notably elevated point estimate for stroke (RR 1.42 [95% CI, 0.96 to 2.10]). The pooled effects were similarly not statistically significant for CVD event outcomes.

The SKICAP trial of vitamin A supplementation did not report CVD outcomes. None of the beta-carotene or vitamin A studies reported examination of effect modification for CVD outcomes by age, gender, race, or ethnicity. PHS-I reported that the effect of beta-carotene on CVD events and CVD mortality did not differ by smoking status (never, former, or current smoker).^75^

##### Cancer (KQ3)

Some type of cancer outcome was reported in all six trials of beta-carotene (alone or with vitamin E or vitamin A^63,^ ^73–76,^ ^87^ and the one trial of vitamin A supplementation alone.^64^ Pooled estimates showed a statistically significant increased risk of lung cancer associated with beta-carotene use, with or without other supplements at 3.7 to 12 years of followup (Peto OR 1.20 [95% CI, 1.01 to 1.42]; 4 RCTs [n=94,830]; I^2^=38.8%; Figure 3, Appendix E Figure 6). Absolute risk differences in individual trials ranged from −0.1 percent to 0.6 percent. Confidence intervals were tighter in a sensitivity analysis with the Mantel-Haenszel common effects model, but the point estimate was nearly identical (OR 1.21 [95% CI, 1.07 to 1.36], Appendix E Table 7).

Lung cancer risk was statistically significantly increased in both trials with a lung cancer prevention aim where populations were smokers or those with workplace asbestos exposure (ATBC: RR 1.18 [95% CI, 1.03 to 1.36]; CARET: adjusted RR 1.28 [95% CI, 1.04 to 1.57].^63,^ ^76^ In ATBC, 3.3 percent of participants taking beta-carotene developed lung cancer, compared with 2.8 percent who were not taking beta-carotene after a median of 6.1 years.^76^ In ATBC, results of statistically significant harm for increased lung cancer risk persisted at 8 and 11 years of followup; at 14 and 24.1 years of followup, point estimates remained above 1 but no longer retained statistical significance.^76^ When we dropped CARET to see the impact of beta-carotene without vitamin A, from the pooled analysis, the result was no longer statistically significant (OR 1.12 [95% CI, 0.96 to 1.31], 3 RCTs [n=76,516], Appendix F Table 7). This limited the meta-analysis to the 3 studies that investigated beta-carotene without vitamin A and included one high-risk study sample and two non-high-risk samples.

CARET also reported the incidence of lung cancer for the 6 years after the intervention period ended (when participants were no longer taking the study supplement), excluding cases that occurred during the main intervention phase of the study. In this post-intervention-only analysis, the increased lung cancer risk tempered somewhat after and was no longer statistically significant (RR 1.12 [95% CI, 0.97 to 1.31]). Results were not statistically significant in two trials conducted in healthier populations with lower lung cancer incidence, with point estimates both below and above 1.0 (PHS: OR 0.93 [95% CI, 0.69 to 1.26]; WHS: OR 1.48 [95% CI, 0.85 to 2.57)].^74,^ ^75^ An additional study focused on skin cancer, SCPS, reported lung cancer mortality and found no statically significant differences associated with beta-carotene use, but there were only 30 total lung cancer deaths over 8.2 years of followup (OR 0.74 [95% CI, 0.36 to 1.54]).

In trials reporting both lung cancer incidence and mortality, results were generally consistent between the two outcomes. Notably, six-year post-intervention followup in CARET showed that the increased lung cancer mortality risk persisted after supplementation stopped (RR 1.20 [95% CI, 1.01 to 1.43]), in contrast to lung cancer incidence.^63^ ATBC found that the effect of beta-carotene on lung cancer was not affected by baseline serum levels.^76^ That study also reported no differential impact of beta-carotene use by serum level on other site-specific cancers.

Pooled outcomes for all cancer mortality, any cancer incidence, colorectal, breast, and prostate cancer showed no statistically significant differences in risk associated with beta-carotene use with ORs ranging from 0.97 (95% CI, 0.80 to 1.16; 2 RCTs [n=46,165]; I^2^=0%;) for breast cancer to 1.03 (95% CI, 0.92 to 1.14; 3 RCTs [n=48,665]; I^2^=0%;) for prostate cancer. Prostate cancer neared statistical significance for increased risk in the beta-carotene vs. no beta-carotene comparisons in ATBC at 6.1 years of followup (OR 1.24 [95% CI, 0.96 to 1.59]; 0.9% with beta-carotene, 0.8% in the control group)].^76^

Two studies evaluating beta-carotene or vitamin A for primary skin cancer prevention showed mixed results. The NSCPS was a primary skin cancer prevention study in the general population evaluating beta-carotene supplementation and sunscreen in a 2x2 design.^73^ Results showed no statistically significant association between beta-carotene supplementation and basal cell carcinoma or squamous cell carcinoma when analyzed either by number of participants or number of tumors. In SKICAP, a skin cancer prevention trial of vitamin A alone,^64^ vitamin A supplementation was associated with a reduced risk of new squamous cell carcinoma (HR 0.74 [95% CI, 0.56 to 0.99]) but showed no statistically significant association with new basal cell carcinoma at 5 years of followup (HR 1.06 [95% CI, 0.86 to 1.32]).

ATBC found no impact of age on the association between beta-carotene use and cancer incidence.^76^ No other studies of beta-carotene or vitamin A reported on differential effects on cancer outcomes by age, gender, race, or ethnicity.

##### Adverse Events (KQ4)

Overall, six RCTs^63,^ ^73–76,^ ^87^ and one cohort study^146^ report on the harms of beta-carotene supplementation, with or without the use of other supplements (Appendix F Table 13). The most substantial harms are the paradoxical harms of increased all-cause mortality, CVD mortality, and lung cancer described above. Trials generally showed no statistically significant findings for other adverse events other than hypercarotenodermia, and GI symptoms in the one trial reporting these outcomes.

For beta-carotene, there was a consistent and statistically significantly increased risk of hypercarotenodermia in the four trials reporting this adverse event at 2 to 12 years of followup.^74–76,^ ^87^ Odds ratios ranged from 1.11 to 6.84 in three trials reporting the incidence of hypercarotenodermia;^74–76^ in the one trial reporting withdrawal due to this outcome, there were 12 withdrawals in those taking beta-carotene vs. 0 events in those not taking beta-carotene.^87^ The only other harm for which there was a statistically significant increased risk from beta-carotene supplementation was GI symptoms in PHS which occurred in 2.5 percent of the intervention group compared to 1.1 percent of the control group at 12 years of followup (OR 2.25 [95% CI, 1.82 to 2.78]).^75^ No other study reported this outcome.

The one cohort study of beta-carotene included for harms outcomes only was the Nurses’ Health Study, which evaluated the association between the self-reported use of beta-carotene and hip fractures at 14 years of followup.^146^ No association was seen between supplementation and this outcome (adjusted RR 0.91 [95% CI, 0.57 to 1.44]).

In the one trial of vitamin A supplementation without beta-carotene, the cumulative incidence of any composite clinical or laboratory adverse symptom was higher in participants randomized to vitamin A vs. those randomized to placebo (OR 1.77 [95% CI, 1.49 to 2.09], Appendix F Table 15).^64^ Laboratory abnormalities were more common than clinical symptoms and showed generally higher serum cholesterol levels, elevated liver enzymes, and lower hemoglobin levels in the vitamin A group; however, group differences were not statistically significant for of any one type of abnormal lab value.

Two large cohort studies of vitamin A supplementation, conducted in women who were primarily White, both suggest a possible increased risk for hip fracture, although results were not statistically significant in the individual studies.^146,^ ^147^ In the Nurses’ Health Study, current use of vitamin A supplements compared to no use was associated with an adjusted 40 percent increased risk for hip fracture at 18 years of followup (95% CI, 0.99 to 1.99);^146^ however, there were only 36 hip fractures in women taking supplements. In IWHS, the adjusted increased risk for hip fracture associated with vitamin A supplementation was 18 percent at 9.5 years of followup (95% CI, 0.99 to 1.41).^147^ No dose-response relationship was identified. There was no increased risk for all fractures associated with vitamin A supplementation at 9.5 years of followup (RR 1.00 [95% CI, 0.95 to 1.05]).

Evidence for the association between vitamin A supplementation and risk of cataract extraction is available from the Nurses’ Health Study.^146,^ ^154^ Results are reported for past use and various durations of use compared to no use. No single comparison was statistically significant; however, a possible increased risk was detected in those with less than 2 years supplementation compared to no supplementation (adjusted RR 1.39 [95% CI, 0.97 to 1.98]). Only 32 cataract extractions occurred in those with this short duration of exposure, so confidence intervals are wide.

No studies reported on differential effects on adverse outcomes by age, gender, race, or ethnicity.

### Vitamin D

#### Summary of Results

Forty-one studies of vitamin D supplementation with or without calcium were included (n=414,675, Table 9), comprising 38 RCTs (n=123,140)^65,^ ^79,^ ^83,^ ^88,^ ^89,^ ^91–95,^ ^100,^ ^103,^ ^108,^ ^111–122,^ ^124–126,^ ^128,^ ^129,^ ^131,^ ^135,^ ^136,^ ^139,^ ^141–143^ and three cohort studies (n=289,659).^146,^ ^149,^ ^150^ Only six of the RCTs^65,^ ^79,^ ^83,^ ^88,^ ^89^ and one of the cohort studies^146^ were included in the previous review.

Table 9 Table of Study, Intervention, and Population Characteristics for Studies of Vitamin D Use (With or Without Calcium), Sorted by Study Design, Then Author (KQ3 and KQ4)

Author, Year (Study); Quality | In previous | Study N^*^ (% FUP) | Daily dose | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ3 | KQ4 | Ascertainment
RCT
Aloia, 2005^131^; Fair | | 208 (71.2%) | 1200 IU | 3 (3) | USA | Other: Bone loss | Postmenopausal African American women | Mean age: 61; % Female: 100; % White: 0; % Black: 100; Mean BMI: 29.5; % Curr. smoker: 7 | Vit D: 45.43 nmol/L | X | X | ACM: NR; Ca: NA; CVD: NA
Aloia, 2018 (PODA)^103^; Fair | | 260 (71.1%) | 3490 IU (average dose; titrated to maintain serum 25(OD)D >75 nmol/L) | 3 (3) | USA | Other: Bone loss prevention | African American women age ≥60 years | Mean age: 68; % Female: 100; % White: 0; % Black: 100; Mean BMI: 30.0; % Curr. smoker: 73 | Vit D: 54.66 nmol/L; Calc: 2.38 mmol/L | X | X | ACM: NR; Ca: NA; CVD: NR
Avenell, 2012 (RECORD)^89^; Good | X | 5292 (100%) | IG1: 800 IU + 1000 mg Calcium; IG2: 800 IU | 3.75 (3.75, 6.2) | GBR | CVD, Cancer | Older adults age ≥70 years with a fragility fracture | Mean age: 77; % Female: 85; % White: 99; % Black: NR; Mean BMI: NR; % Curr. smoker: 12 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Baeksgaard, 1998^125^; Fair | | 240 (82.9%) | 560 IU + 1000 mg Calcium | 2 (2) | DNK | Other: Bone mineral density | Women aged 58-67 years | Mean age: 62; % Female: 100; % White: 100; % Black: 0; Mean BMI: NR; % Curr. smoker: NR | NR; Calc: 2.3 mmol/L | X | X | ACM: NR; Ca: NA; CVD: NA
Baron, 2015 (VCPPS)^91^; Good | | 2259 (93.4%) | IG1: 1000 IU + 1200 mg Calcium; IG2: 1000 IU | 3.8 (3, 3.8) | USA | Other: Colorectal adenoma prevention | Age 45-75 years with recently diagnosed adenomas | Mean age: 58; % Female: 37; % White: 88; % Black: 8; Mean BMI: 29.0; % Curr. smoker: 10 | Vit D: 61.4 nmol/L | X | X | ACM: NR; Ca: Full; CVD: Full
Bischoff-Ferrari, 2020 (DO-HEALTH)^140^; Good | | 2157 (88%) | 2000 IU | 3 (3) | AUT, FRA, DEU, PRT, CHE | Other : 6 primary outcomes (BP, Short Physical Performance Battery, Montreal Cognitive Assessment, nonvertebral fractures, infections) | Community dwelling adults 70 years or older | Mean age: 75; % Female: 62; Percent white: NR; Mean BMI: NR; % Curr. smoker: 6 | Vit D: 55.91 nmol/L | X | X | ACM: Full; Ca :NA; CVD: NA
Brisson, 2017^95^; Good | | 405 (96.5%) | IG1: 2000 IU; IG2: 1000 IU; IG3: 3000 IU | 1 (1) | CAN | Other: Mammo-graphic breast density | Premenopausal women | Mean age: 43; % Female: 100; % White: 98; % Black: NR; Mean BMI: 24.3; % Curr. smoker: NR | Vit D: 64.1 nmol/L | | X | ACM: NA; Ca: NA; CVD: NA
Cooper, 2003^128^; Fair | | 187 (81.8%) | 1428.6 IU (10,000 IU weekly) + 1000 mg/day Calcium | 2 (2) | AUS | Other: Bone mineral density | Postmenopausal white women | Mean age: 56; % Female: 100; % White: 100; % Black: 0; Mean BMI: NR; % Curr. smoker: 7 | Vit D: 82.1 nmol/L; Calc: 2.4 mmol/L | X | X | ACM: NR; Ca: NA; CVD: NA
Dawson-Hughes, 1991^111^; Fair | | 276 (90.2%) | 400 IU + 377 mg Calcium | 1 (1) | USA | Other: Bone mineral density | White postmenopausal women | Mean age: 62; % Female: 100; % White: 100; % Black: 0; Mean BMI: NR; % Curr. smoker: 8 | NR | X | X | ACM: NR; Ca: NA; CVD: NA
Dawson-Hughes, 1997^124^ | | 445 (87.4%) | 700 IU + 500 mg Calcium | 3 (3) | USA | Other: Bone mineral density | Adults aged 65 years or older | Mean age: 71; % Female: 55; % White: 97; % Black: 2; Mean BMI: NR; % Curr. smoker: 6 | NR | | X | ACM: NA; Ca: NA; CVD: NA
Dean, 2011^65^; Good | X | 128 (99.2%) | 5000 IU | 0.12 (0.12) | AUS | Other: Cognitive and emotional functioning | Adults, age ≥18 years | Mean age: 22; % Female: 57; % White: 38; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | Vit D: 76.7 nmol/L | | X | ACM: NA; Ca: NA; CVD: NA
Dukas, 2004^129^; Fair | | 380 (84.5%) | 40 IU | 0.7 (0.7) | CHE | Other: Falls | Adults aged 70 and older | Mean age: 75; % Female: 52; % White: NR; % Black: NR; Mean BMI: 26.3; % Curr. smoker: NR | NR | X | X | ACM: NR; Ca: NA; CVD: NR
Fedirko, 2009^114^; Fair | | 92 (92.4%) | IG1: 800 IU + 2000 mg Calcium; IG2: 800 IU | 0.5 (0.5) | USA | Other: Markers of apoptosis in colorectal mucosa | Adults aged 30-75 years with a history of colon or rectal adenoma | Mean age: 61; % Female: 30; % White: 71; % Black: NR; Mean BMI: 30.1; % Curr. smoker: 3 | Vit D: 54.91 nmol/L | | X | ACM: NA; Ca: NA; CVD: NA
Gallagher, 2001 (STOP IT)^126^; Fair | | 246 (86.6%) | 20 IU | 3 (3) | USA | Other: Bone mineral density | Women aged 65-77 years | Mean age: 71; % Female: 100; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | Vit D: 79.3 nmol/L | X | X | ACM: NR; Ca: NR; CVD: NR
Glendenning, 2012^117^; Fair | | 686 (93.0%) | 1666.7 IU (150,000 IU every 3 months) | 0.75 (0.75) | AUS | Other: Falls, mobility | Women aged over 70 years | Mean age: 77; % Female: 100; % White: 96; % Black: 0; Mean BMI: 27.5; % Curr. smoker: NR | NR | X | X | ACM: NR; Ca: Self-report; CVD: Self-report
Grady, 1991^122^; Fair | | 98 (98.0%) | 20 IU | 0.5 (0.5) | USA | Other: Muscle strength | Adults aged 70 years or older | Mean age: 79; % Female: 54; % White: 95; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | Vit D: 63 nmol/L; Calc: 2.3 mmol/L | X | X | ACM: Full; Ca: Self-report; CVD: Self-report
Kenny, 2003^118^; Fair | | 65 (92.3%) | 1000 IU + 500 mg Calcium | 0.5 (0.5) | USA | Other: Strength; physical function | Men, aged 65 years and older | Mean age: 76; % Female: 0; % White: NR; % Black: NR; Mean BMI: 27.8; % Curr. smoker: NR | Vit D: 62.4 nmol/L | X | X | ACM: Full; Ca: NA; CVD: NA
Komulainen, 1999 (KOS)^113^; Fair | | 464 (94%) | 300 IU + 93 mg Calcium | 5 (5) | FIN | Other: Bone mineral density | Recently postmenopausal women, aged 47-56 years | Mean age: 53; % Female: 100; % White: NR; % Black: NR; Mean BMI: 26.8; % Curr. smoker: NR | NR | X | | ACM: NR; Ca: NR; CVD: NR
Lappe, 2007^83^; Fair | X | 1180 (86.8%) | 1000 IU + 1500 mg Calcium | 4 (4) | USA | Cancer, Other: Skeletal status and calcium economy | Women age >55 years | Mean age: 67; % Female: 100; % White: 100; % Black: 0; Mean BMI: 29.0; % Curr. smoker: NR | Vit D: 71.8 nmol/L; Calc: 2.33 mmol/L | X | X | ACM: NA; Ca: Full; CVD: NA
Lappe, 2017^93^; Good | | 2303 (95.4%) | 2000 IU + 1500 mg Calcium | 4 (4) | USA | Cancer | Postmenopausal women age ≥55 years; | Mean age: 65; % Female: 100; % White: 100; % Black: NR; Mean BMI: 30.0; % Curr. smoker: 6 | Vit D: 81.87 nmol/L | X | X | ACM: Full; Ca: Full; CVD: NA
Lips, 1996^112^; Fair | | 2578 (99.5%) | 400 IU | 3.5 (3.5) | NLD | Other: Fracture prevention | Adults 70 years of age or older | Mean age: 80; % Female: 74; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | NR | X | | ACM: Full; Ca: NA; CVD: NA
Pittas, 2019 (D2d)^136^; Good | | 2423 (99.1%) | 4000 IU | 3.5 (3.5) | US | Other: Diabetes incidence | Adults aged 30 or over (25+ for AI/AN) with pre-diabetes | Mean age: 60; % Female: 45; % White: 67; Mean BMI: 32.1; % Curr. smoker: NR | Vit D: 69.89 mmol/L | X | X | ACM: NR; Ca: NA; CVD: NA
Manson, 2018 (VITAL)^94^; Good | | 25871 (92.4%) | 2000 IU | 5.3 (5.3) | USA | CVD, Cancer | Men age ≥50 years and women ≥55 years, with no history of cancer or CVD | Mean age: 67; % Female: 51; % White: 71; % Black: 20; Mean BMI: 28.1; % Curr. smoker: 7 | Vit D: 76.88 nmol/L | X | X | ACM: Full; Ca: Full; CVD: Full
Murdoch, 2012^119^; Good | | 322 (91%) | 3333.3 IU (100,000 to 200,000 IU monthly) | 1.5 (1.5) | NZL | Other: Upper respiratory tract infections | Healthy nonpregnant adults ≥ 18 years | Mean age: 47; % Female: 75; % White: 94; % Black: NR; Mean BMI: 27.5; % Curr. smoker: 5 | Vit D: 71.14 nmol/L; Calc: 2.3 mmol/L | X | X | ACM: NA; Ca: Self-report; CVD: NA
Neale, 2022 (D-Health)^143^; Good | | 21,315 (99.9%) | 2000 IU | 5 (5, 6) | AUS | Other: Mortality | Adults, aged 60-84 years | Mean age: 69; % Female: 46; Percent white: 91; Mean BMI:; % Curr. smoker: 4 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Pittas, 2019^136^; Good | | 2423 (99.1%) | 4000 IU | 3.5 (3.5) | US | Other: Diabetes incidence | Adults with pre-diabetes aged 30^*^ or over (*25+ for AI/AN) | Mean age: 60; % Female: 45; Percent white: 67; Mean BMI: 32.1; % Curr. smoker: NR | Vit D: 69.89 nmol/L | X | X | ACM: NR; Ca: Full; CVD: NA
Rake, 2020 (VIDAL)^139^; Good | | 1615 (90.3%) | 3333 IU (100,000 IU monthly) | 2 | GBR | Other: Feasibility for larger trial with ACM endpoint | Older adults aged 65–84 years | Mean age: 72; % Female: 47; Percent white: 99; Mean BMI: NR; % Curr. smoker: NR | Vit D: 51.5 nmol/L | X | X | ACM: Full; Ca: Full; CVD: Full
Salovaara, 2010^135^; (OSTPRE-FPS); Fair | | 3432 (91.5%) | 800 IU + 1000 mg Calcium | 3.0 (3) | FIN | Other: Fracture | Women aged 65-71 years living in northern Savonia (latitude 62 to 64 North) | Mean age: 67; % Female: 100; % White: NR; % Black: NR; Mean BMI: 27.7; % Curr. smoker: 5 | Vit D: 49.5 nmol/L | X | | ACM: NR; Ca: NA; CVD: NA
Sanders, 2010 (Vital D)^116^; Fair | | 2258 (90.0%) | 1370 IU (500,000 IU annually) | 5 (4) | AUS | Other: Falls and fractures | Women aged 70 years or older residing in southern Victoria, Australia (latitude 38 South) at higher risk of hip fracture | Mean age: 76; % Female: 100; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | NR | X | X | ACM: NR; Ca: NR; CVD: NR
Scragg, 2017 (ViDA)^92^; Good | | 5110 (86.8%) | 3333 IU (100,000 IU monthly after initial 200,000 IU dose) | 3.3 (3.3) | NZL | CVD | Adults, age 50-84 years | Mean age: 66; % Female: 42; % White: 83; % Black: 0; Mean BMI: 28.4; % Curr. smoker: 6 | Vit D: 63.4 nmol/L; Calc: 2.3 mmol/L | X | X | ACM: Full; Ca: Full; CVD: Full
Toss, 2012^108^; Fair | | 56 (80.4%) | 1600 IU + 1000 mg Calcium | 1 (1) | SWE | Other: Bone & mineral metabolism | Adults 55-85 years at 58 North latitude with circumstances suggesting a risk for vitamin D insufficiency (NOS) | Mean age: 70; % Female: 71; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | Vit D: 48.9 nmol/L; Calc: 1.25 mmol/L | | X | ACM: NA; Ca: NA; CVD: NA
Trivedi, 2003^88^; Fair | X | 2686 (100%) | 1095.9 IU (100,000 IU every 4 months) | 5 (5) | GBR | Other: Fractures and mortality | Age 65-85 years | Mean age: 75; % Female: 24; % White: NR; % Black: NR; Mean BMI: 24.4; % Curr. smoker: 4 | NR | X | X | ACM: Full; Ca: Self-report; CVD: Self-report
Uusi-Rasi, 2015^121^; Fair | | 409 (90.5%) | 800 IU | 2 (2) | FIN | Other: Falls prevention | Women aged 70-80 years with a previous fall | Mean age: 74; % Female: 100; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 3 | Vit D: 67.14 nmol/L; Calc: 2.35 mmol/L | X | | ACM: NR; Ca: NA; CVD: NA
Virtanen, 2022^142^; Good | | 2495 (100%) | 1600 IU | 5 (5) | FIN | CVD, Cancer | Men and women aged 60 (men) or 65 (women) years and over, without a history of cancer or CVD. | Mean age: 68; % Female: 43; Percent white: 100; Mean BMI: 27.1; % Curr. smoker: 36 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Wactawski-Wende, 2006 (WHI)^79^; Good | X | 36282 (93.1%) | 400 IU + 1000 mg Calcium | 7 (7, 9.8, 11.1, 11.9) | USA | CVD, Cancer, Other: Mortality, adverse events, risk of fractures, | Postmenopausal women aged 50-79 years | Mean age: 62; % Female: 100; % White: 83; % Black: 9; Mean BMI: 29.0; % Curr. smoker: 8 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Witham, 2014^100^; Fair | | 68 (89.7%) | 1667 IU (100,000 IU bimonthly) | 0.5 (0.50) | GBR | Other: Reduce blood pressure and left ventricular hypertrophy | Age ≥18 years with resistant hypertension | Mean age: 63; % Female: 35; % White: 100; % Black: NR; Mean BMI: 31.7; % Curr. smoker: 6 | Vit D: 41.5 nmol/L; Calc: 2.3 mmol/L | X | X | ACM: NR; Ca: NA; CVD: Self-report
Wood, 2012^120^; Fair | | 305 (96.1%) | IG1: 400 IU; IG2: 1000 IU | 1 (1) | GBR | Other: CVD risk factors | Caucasian postmenopausal women aged 60-70 years | Mean age: 64; % Female: 100; % White: 100; % Black: 0; Mean BMI: 26.7; % Curr. smoker: NR | Vit D: 33.8 nmol/L; Calc: 2.35 mmol/L | X | X | ACM: NA; Ca: NR; CVD: NA
Wood, 2021^141^; Fair | | 300 (91.3%) | 2000 IU | 1 (1) | US | Other: Mammographic density | Premenopausal women with a breast density of at least 25%. | Mean age: 43; % Female: 100; Percent White: 79; Percent Black: 12; Mean BMI: 27.0; % Curr. smoker: NR | Vit D: 66.39 nmol/L | X | X | ACM: NR; Ca: NA; CVD: NA
Zitterman, 2009^115^; Fair | | 200 (82.5%) | 3332 IU | 1 (1) | DEU | Other: Weight loss, CVD risk factors | Adults aged 18-70 years with a BMI above 27 | Mean age: 48; % Female: 67; % White: NR; % Black: NR; Mean BMI: 33.3; % Curr. smoker: NR | NR | X | | ACM: NA; Ca: NR; CVD: NA
Cohort
Ferraro, 2017 (NHS-II)^149^; Fair | | 116430 (NR%) | Varied (a range of doses were examined) | NR (20) | USA | Other: Kidney stones | Female nurses aged 25 to 42 years | Mean age: NR; % Female: 100; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | NR | | X | ACM: NA; Ca: NA; CVD: NA
Feskanich, 2002 (NHS-I)^146^; Fair | X | 121700 (Varies%) | Varied (a range of doses were examined) | NR (12, 18, 20.9) | USA | Other: Hip fractures, kidney stones, cataracts | Postmenopausal registered nurses age 30-55 years | Mean age: 58; % Female: 100; % White: NR; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 26 | NR | | X | ACM: NA; Ca: NA; CVD: NA
Taylor, 2004 (HPFS)^150^; Fair | | 51529 (NR%) | Varied (a range of doses were examined) | NR (14, 26) | USA | Other: Kidney stones | Male health professionals age 40 to 75 years | Mean age: NR; % Female: 0; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | NR | | X | ACM: NA; Ca: NA; CVD: NA

* Includes participants randomized to all intervention groups, including for supplements other than Vitamin D.

Abbreviations: ACM = All-cause mortality; BL = Baseline; BMI = Body mass index; Ca = Cancer; Calc = Calcium; Curr = Current; CVD = Cardiovascular disease; FUP = Followup; IU = International units; mg = Milligrams; mmol/L = Millimoles per Liter; nmol/L = Nanomoles per liter; NA = not applicable; NOS = Not otherwise specified; NR = Not reported; RCT = Randomized controlled trial; Vit D = Vitamin D.

Most of the studies had aims related to bone density, fractures, or falls and were primarily limited to adults aged 55 years or older. However, five explicitly aimed to prevent CVD^79,^ ^89,^ ^92,^ ^94,^ ^142^ and seven had a cancer prevention aim.^79,^ ^83,^ ^89,^ ^91,^ ^93,^ ^94,^ ^142^ The three largest studies were the Women’s Health Initiative (WHI, n=36,282),^79^ which examined the effects of 400 IU vitamin D and 1000 mg calcium use daily; the VITamin D and OmegA-3 TriaL (VITAL, n=25,871),^94^ which tested the effects of 2000 IU/day of vitamin D, with or without an Omega-3 fatty acid supplement in a 2x2 factorial design; and D-Health, which examined the use of 2000 IU daily.^143^ Both WHI and VITAL had specific aims of cancer and CVD prevention among adults age 50 years or older, while mortality was the main outcome for D-Health. VITAL and D-Health were newly published and not included in the previous review. In the RCTs, doses ranged from 20 to 5000 IU/day for 1 month to 7 years and followup time ranged from 1 month to 11.9 years. Studies administered D3 in all cases, as cholecalciferol, alfacalcidol, or calcitriol, among studies reporting the specific agent.

Thirty-two RCTs reported KQ3 outcomes (n=123,140) and KQ4 outcomes were reported in 31RCTs (n=117,100) and 3 cohort studies (n=289,659). Pooling studies of vitamin D with or without calcium co-supplementation indicated no reduction in all-cause mortality (OR, 0.96 [0.91 to 1.02]; 27 RCTs [n=117,082]; I^2^=0%), CVD (e.g., composite CVD events: OR, 1.00 [0.95 to 1.05]; 7 RCTs [n=74,925]; I^2^=0%), or cancer outcomes (e.g. any cancer incidence: OR, 0.98 [0.92 to 1.03]; 19 RCTs [n=86,899]; I^2^=0%) (Figure 5). Two of the three large trials found an increased risk of kidney stones, as did two of three cohort studies. Findings suggested an increased risk of kidney stones with 7 years or more of vitamin D use, particularly with doses of 1000 IU/day or more, with or without concomitant calcium use.

Figure 5 Meta-Analysis Summary for Vitamin D (With or Without Calcium)^*^ * I-squared values shown for analyses using the MH model are taken from sensitivity analyses using random effects models; the MH model is based on a fixed effect model where calculation of I-squared is not applicable because it is assumed to be 0. If data were insufficient for meta-analysis, findings from the largest and most comprehensive study reporting the outcome are presented.

Abbreviations: CG = Control group; CI = Confidence interval; CVD = Cardiovascular disease; IG = Intervention group; MH = Mantel-Haenszel common (fixed) effects model; MI = Myocardial infarction; NA = Not applicable; OR = Odds ratio; Peto = Peto odds ratio; VITAL = VITamin D and OmegA-3 TriaL.

This figure is a forest plot showing meta-analysis or best evidence summary for vitamin D (with or without calcium)

Point estimates were very similar when limited to studies with full ascertainment, those examining vitamin D without calcium, and those examining vitamin D and calcium combined (Appendix F Table 16). Findings were also robust to different pooling methods. In addition, for all-cause mortality, composite CVD events, and any cancer incidence there was no clear association between effect size and vitamin D dose or the use of bolus dosing (e.g., 100,000 IU monthly), nor was there a difference in effect size between the studies in the previous review and newly-included studies.

#### Detailed Study Characteristics

Thirty-eight RCTs (n=123,140)^65,^ ^114,^ ^124^ ^79,^ ^83,^ ^88,^ ^89,^ ^91–95,^ ^100,^ ^103,^ ^108,^ ^111–113,^ ^115–122,^ ^125,^ ^126,^ ^128,^ ^129,^ ^131,^ ^135,^ ^136,^ ^139,^ ^141–143^ and three cohort studies^146,^ ^149,^ ^150^ (n= 289,659) of vitamin D use were included, for a total of 414,675 participants (Table 9). Six of these studies were included in the previous review.^65,^ ^79,^ ^83,^ ^88,^ ^89,^ ^146^ Twenty of the 35 newly included studies became eligible due to our slightly broader inclusion criteria rather than recent publication, and these studies typically collected CVD and cancer outcomes as part of their adverse events reporting, if at all, rather than having robust ascertainment of these outcomes from medical records or other comprehensive sources. However, some newly included trials did have CVD or cancer aims, including the large VITAL study^94^ (n=25,871) and one conducted by Virtanen and colleagues (n=2495) for CVD and cancer prevention, ViDA^92^ (n=5,110) for CVD prevention, and a study by Lappe and colleagues^93^ (n=2,303) for cancer prevention.

Thirteen^65,^ ^79,^ ^91–95,^ ^119,^ ^136,^ ^139,^ ^140,^ ^142,^ ^143^ of the included studies (all RCTs) were rated as good quality and the remaining studies were fair quality. Many of the fair-quality RCTs were downgraded because they lacked robust ascertainment of the outcomes pertinent to our review (cancer, CVD), since most were designed to address other outcomes. Full ascertainment of the main outcomes for this review were reported by 12^79,^ ^88,^ ^89,^ ^92–94,^ ^112,^ ^118,^ ^122,^ ^139,^ ^142,^ ^143^ trials for all-cause mortality, 8^79,^ ^89,^ ^91,^ ^92,^ ^94,^ ^139,^ ^142,^ ^143^ for CVD events, and 10^79,^ ^83,^ ^89,^ ^91–94,^ ^136,^ ^142,^ ^143^ for cancer incidence. The cohort studies were large and generally used good methods, however we rated them as fair quality because of their reliance on self-reported supplement use and inability to fully control for confounders.

Five studies^79,^ ^89,^ ^92,^ ^94,^ ^142^ had an explicit aim of CVD prevention and three additional trials aimed to improve CVD risk factors.^100,^ ^115,^ ^120^ Seven had a cancer prevention aim,^79,^ ^83,^ ^89,^ ^91,^ ^93,^ ^94,^ ^142^ plus one additional trial examined markers of apoptosis in colorectal mucosa.^114^ All three of the cohort studies examined the association between varying levels of self-reported vitamin D supplement use and kidney stones.^146,^ ^149,^ ^150^ Among the RCTs, 26 (68.47%) examined the use of vitamin D without calcium, nine (23.7%) examined the use of vitamin D and calcium together, and three^89,^ ^91,^ ^114^ had factorial designs examining vitamin D and calcium use alone and in combination. The most common doses were 800 and 2000 IU daily, and doses ranged from 20 to 5000 IU/day taken for 1 month to 7 years, with followup ranging from 1 month to 11.9 years post-baseline. Seven studies^88,^ ^92,^ ^100,^ ^116,^ ^117,^ ^119,^ ^139^ used bolus dosing, administering 100,000 to 500,000 IU at once, with periodicity ranging from monthly to annually. Only one of these had a study aim pertinent to this review, the VIDA study,^92^ which administered 100,000 IU per month for CVD prevention. Almost all doses were within the recommended daily upper limit of 4000 IU, including the bolus dosing when divided by the number of days between doses. The only exception was one small study that only reported harms and was included in the previous review, which administered 5000 IU daily for one month to promote optimal cognitive and emotional functioning.^65^ Calcium doses ranged from 93 to 2000 mg/day. The cohort studies included participants taking a range of daily doses and duration of vitamin D use, with supplement use based on self-report.

Fifteen of the studies were conducted in the U.S., and the remaining were conducted in Canada, Europe, Australia, and New Zealand. The mean ages were in the 60s or older (weighted average age of 66 years), most studies were majority or entirely female (75% of participants across all trials were female), and mean BMIs were most commonly in the overweight range (weighted average BMI of 28.5 kg/m^2^). The samples were predominantly of White race, however some studies of bone loss were limited to Black women.^103,^ ^131^ In the very large VITAL study, 20 percent of participants were Black, but that study had very limited representation of other people of color or Hispanic persons.^94^ Across all studies reporting baseline 25(OH)D, the median (interquartile range [IQR]) for baseline serum level was 63 nmol/L (53 to 71 nmol/L), suggesting few participants had vitamin D deficiency.

#### Detailed Results by Outcome

Thirty-two RCTs reported KQ3 outcomes (n=123,140) and KQ4 outcomes were reported in 31 RCTs (n=117,100) and 3 cohort studies (n=289,659). See Appendix F Table 16 for a summary of findings for each trial and Appendix F Table 17 for a listing of results from all pooled analyses. Comprehensive and detailed study-level results are available in Appendix F Tables 18, 19, 20, and 21.

Across all outcomes, there was no apparent effect modification related to the comprehensiveness of outcome ascertainment, whether vitamin D was used alone or in combination with calcium, or whether the supplement was given in a large bolus (e.g., 100,000 IU monthly) or taken daily in smaller doses. In addition, differing statistical pooling methods had almost identical results. Evidence for a possible association between all-cause mortality and dose is discussed below, and no association was identified between dose and either CVD events or cancer incidence. Sensitivity analysis results are shown in Appendix F Table 17. Results from factorial studies indicated similar effects for vitamin D with or without calcium, but these comparisons are not discussed in detail. Subgroup analyses within trials also demonstrated no effect modification by baseline vitamin D serum levels.^92,^ ^94^

##### All-Cause Mortality (KQ3)

All-cause mortality was reported in 27 RCTs and indicated no benefit for vitamin D use (OR, 0.96 [95% CI, 0.91 to 1.02]; 27 RCTs [n=117,082; I^2^=0%; Figure 5, Appendix E Figure 7) after 6 months to 6.2 years of followup.^79,^ ^88,^ ^89,^ ^91–94,^ ^103,^ ^111–113,^ ^116,^ ^121,^ ^122,^ ^125,^ ^126,^ ^128,^ ^129,^ ^131,^ ^135,^ ^136,^ ^139–143^ The results were very similar for vitamin D alone and vitamin D with calcium, and neither of these effects were statistically significant when pooled separately (Appendix F Table 17). The overall pooled estimate was identical using different pooling methods for rare events, however the effect was statistically significant when using the restricted maximum likelihood method. The proportion of participants dying was highly variable across these studies, ranging from 0 to 33 percent in the control groups, leaving the best pooling method unclear. The results were almost identical when the analysis was limited to studies with full ascertainment of all-cause mortality. The two largest trials that included both men and women, VITAL and D-Health, both found no reduction in all-cause mortality. The effect in VITAL suggested no benefit after 5.3 years (HR, 0.99 [95% CI, 0.87 to 1.12]); 3.8 percent in each group had died. In D-Health, 5.3 percent of participants taking vitamin D and 5.1 percent taking placebo had died after 5 years (HR, 1.04 [95% CI, 0.93 to 1.18]). Exploratory analyses using meta-regression suggested a larger effect at lower daily doses (measured continuously, p=.005), however early studies tended to use lower doses, so this effect may be confounded by secular trends. There was no association between effect size and the use of bolus dosing (p=.12), versus vitamin D taken daily doses, and nor was there a difference in effect size between previous and newly-included studies, however this effect was nearly statistically significant (p=.051)

Subgroup analyses for all-cause mortality were sparsely reported. Three studies found no differences in effect sizes for all-cause mortality by age,^79,^ ^88,^ ^143^ and two of these also found no effect modification by gender.^79,^ ^143^

##### Cardiovascular Outcomes (KQ3)

A CVD outcome was reported in 17 of the 35 trials (Figure 5, Appendix E Figure 10).^79,^ ^88,^ ^89,^ ^91,^ ^92,^ ^94,^ ^100,^ ^103,^ ^113,^ ^116,^ ^117,^ ^122,^ ^126,^ ^129,^ ^139,^ ^142,^ ^143^ Pooled effects showed no group differences for CVD mortality, the composite CVD event outcome, MI, and stroke. Point estimates for these outcomes ranged from 0.96 to 1.02, including sensitivity and subgroup analyses, and no pooled result was statistically significant. Very few individual study results showed a statistically significant benefit. Point estimates were in a similar range as the pooled effects for VITAL, D-Health, and WHI across a number of CVD-related outcomes. Meta-analyses included a range of four to nine trials and 35,979 to 75,73173 participants, with little to no statistical heterogeneity among the individual study effects. Two of these trials tested vitamin D and calcium use combined compared with placebo, and neither found any reduction in CVD deaths or events.^79,^ ^89^

The included studies found no effect modification by age,^79,^ ^88,^ ^94^ gender,^88,^ ^94^ or race,^94^ as well a number of other health-related characteristics such as smoking status^79,^ ^94^ and BMI.^79,^ ^94^ In addition, pooled analyses demonstrated no association between effect size for the composite CVD events outcome and vitamin D dose (interaction p=.89) or the use of bolus dosing (p=.82), versus vitamin D taken daily in smaller doses, nor was there a difference in effect size between the previous and newly-included studies (p=.81)

##### Cancer (KQ3)

Cancer outcomes were reported by 21 of the RCTs.^79,^ ^83,^ ^88,^ ^89,^ ^91–94,^ ^103,^ ^113,^ ^115–117,^ ^119,^ ^120,^ ^122,^ ^126,^ ^136,^ ^139,^ ^142,^ ^143^ The meta-analysis showed no association between vitamin D use and cancer mortality, any cancer incidence, or site-specific cancers (Figure 5, Appendix E Figure 8 and 9). For cancer mortality, the large VITAL,^79,^ ^94^ D-Health,^143^ and WHI^79^ trials did not find statistically significant group differences. VITAL and WHI both had point estimates in the direction of benefit (WHI^79^: HR, 0.89; 95% CI, 0.77 to 1.03; VITAL^94^: HR, 0.83; 95% CI, 0.67 to 1.02). In VITAL, 1.2 percent of participants taking vitamin D had died of cancer, compared with 1.4 percent taking placebo. On the other hand, D-Health findings trended in the opposite direction (HR, 1.15 [ 95% CI, 0.96 to 1.39], n=21,310; 2.3% taking vitamin D, 2.0% taking placebo died of cancer).^143^

There were very few trials with statistically significant effects of vitamin D use on cancer incidence, overall or site-specific, with or without concomitant calcium use (Appendix E Figures 8 and 9). Among studies reporting both cancer incidence and cancer mortality, most found effects more strongly in the direction of benefit for cancer mortality than cancer incidence, although confidence intervals within each study were highly overlapping (Table 10). WHI reported extensively on site-specific cancers and generally found statistically non-significant ORs between 0.90 and 1.10 for cancers with more than ten events per study group. The only statistically significant site-specific cancer finding for WHI was a reduction in breast cancer in situ after 11.9 years (HR, 0.82 [95% CI, 0.68 to 0.99], 1.1% in supplement group vs. 1.3% in the placebo group). However, WHI found no reduction in breast cancer overall (HR, 0.96 [95% CI, 0.86 to 1.07]) or invasive breast cancer (HR, 1.04 [95% CI, 0.94 to 1.14], 4.7% in the supplement group vs. 4.5% in the placebo group).

Table 10 Cancer Mortality and Cancer Incidence Results for Vitamin D Trials Reporting Both Outcomes (KQ3)

Study | Supplement (IU/day) | N | Followup, Years | Cancer mortality, OR (95% CI) | Cancer incidence, OR (95% CI)
Avenell, 2012 (RECORD)^89^ | Vitamin D (800) | 5,292 | 6.2 | 0.86 (0.63 to 1.20) | 1.08 (0.92 to 1.27)
Trivedi, 2003^88^ | Vitamin D (1095.9) | 2,686 | 5 | 0.87 (0.61 to 1.23) | 1.09 (0.86 to 1.39)
Manson 2018 (VITAL)^94^ | Vitamin D (2000) | 25,871 | 5.3 | 0.82 (0.66 to 1.02) | 0.96 (0.87 to 1.06)
Rake, 2020 (VIDAL)^139^ | Vitamin D (3333) | 1,615 | 4 | 2.87 (1.03 to 8.01) | 0.85 (0.47 to 1.53)
Scragg, 2017 (ViDA)^92^ | Vitamin D (3333) | 5,110 | 3.3 | 1.00 (0.60 to 1.66) | 1.01 (0.81 to 1.26)
Wactawski-Wende, 2006 (WHI)^79^ | Vitamin D (400) + Calcium | 36,282 | 7 | 0.90 (0.77 to 1.04) | 0.98 (0.9 to 1.06)

Abbreviations: CI = Confidence interval; IU = International units; OR = Odds ratio.

The included studies found no effect modification for cancer by age,^79,^ ^88,^ ^94,^ ^136^ gender,^88,^ ^94,^ ^136^ or smoking status.^79,^ ^94,^ ^136^ The VITAL study did find an interaction with BMI, but followup exploratory analyses found that the pattern of effects suggested that pre-diagnostic weight loss of cancer patients may explain the interaction with BMI. Preventive effects of vitamin D supplementation on cancer progression was also considered plausible, however. In addition, while confidence intervals overlapped, subgroup analyses suggested a larger benefit for cancer incidence among Black participants (HR, 0.77 [95% CI, 0.59 to 1.01] than Non-Hispanic White participants (HR, 0.99 [95% CI, 0.89 to 1.11]), but the interaction term was not statistically significant in VITAL or another study that examined this interaction^136,^ ^155^ In addition, meta-regression analyses demonstrated no association between effect size for the any cancer incidence and vitamin D dose (interaction p=.92) or the use of bolus dosing (p=.37), versus vitamin D taken daily in smaller doses, nor was there a difference in effect size between the previous and newly-included studies (p=.47)

##### Adverse Events (KQ4)

Thirty-one of the RCTs reported some kind of adverse event outcome, as did all three of the cohort studies. Among RCTs that reported the percent of participants experiencing any adverse event^65,^ ^92,^ ^114,^ ^116,^ ^118,^ ^129,^ ^140,^ ^141,^ ^143^ any serious adverse events^83,^ ^93,^ ^103,^ ^136,^ ^139,^ ^141,^ ^143^ or withdrawal due to adverse events.^93,^ ^95,^ ^103,^ ^120,^ ^124,^ ^128,^ ^136,^ ^139,^ ^143^ only one found an increase in withdrawals due to adverse events in a trial that administered 10,000 IU/week of vitamin D plus 1000 mg/day of calcium to postmenopausal women.^128^

While most trials reporting kidney stones had very few events, two of the three largest trials indicated a small increased risk.^83,^ ^91–94,^ ^111,^ ^126^ In WHI, 2.5 percent of participants taking 400 IU vitamin D and 1000 mg calcium daily developed a kidney stone after 7 years, compared with 2.1 percent in the placebo group (HR, 1.17 [95% CI, 1.02 to 1.34). VITAL found a similar effect size, although it was not statistically significant (HR, 1.12 [95% CI, 0.99 to 1.28]); 3.7 percent in those taking 2000 IU/day vitamin D vs. 3.3 percent in the placebo group after 5.3 years developed a kidney stone. However, there was no association found in D-Health (IRR, 1.03 [95% CI, 0.82 to 1.28); 1.5% in the vitamin D vs.1.4% in the placebo group) Two of the cohort studies^149,^ ^150^ found an increased risk of kidney stones with use of 1000 IU/day or more of vitamin D after 20 to 26 years, compared with no vitamin D use, but only one of these findings was statistically significant. There was no suggestion of increased risk with lower doses in either of these studies. The third cohort study, NHS-I,^146^ found no association between any dose of vitamin D and kidney stones.

A wide range of non-serious harms were reported, and no group differences were found.^89,^ ^94,^ ^95,^ ^100,^ ^103,^ ^108,^ ^120,^ ^124–126^

We found no evidence related to effect modification on harms of vitamin D use by age, sex, race, ethnicity, or dose.

### Vitamin E

#### Summary of Results

Eleven studies of vitamin E supplementation were included (n=265,511, Table 11): nine RCTs (n=116,468)^74,^ ^76,^ ^77,^ ^80,^ ^81,^ ^104,^ ^127,^ ^130,^ ^132^ and two cohort studies (n=149,043).^146,^ ^148^ Seven of the RCTs had an explicit aim to prevent CVD^74,^ ^80,^ ^81,^ ^104^ or related outcomes,^77,^ ^127,^ ^132^ most among adults at increased risk for CVD, due to either smoking history^76,^ ^132^ or the presence of CVD risk factors.^77,^ ^104,^ ^127^ Three of the trials with CVD aims also had a cancer prevention aim.^74,^ ^80,^ ^81^ One large trial had an exclusive aim of cancer prevention.^76^ In the RCTs, dose ranged from 111 to 666 IU daily (50 to 300 mg/day) for 3 to 10 years, and followup time ranged from 3 to 24 years. Five of the studies were conducted in the US^74,^ ^81,^ ^127,^ ^146^ or the US and Canada,^80^ primarily among adults aged 45 years and older.

Table 11 Table of Study, Intervention, and Population Characteristics for Studies of Vitamin E Use, Sorted by Author (KQ3 and KQ4)

Author, Year (Study); Quality | In previous | Study N^*^ (% FUP) | Daily dose | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ3 | KQ4 | Ascertainment
RCT
ATBC Study Group, 1994 (ATBC)^76^; Good | X | 29133 (100%) | 111 IU | 6.1 (6.1, 8, 11, 14, 22.1, 24.1) | FIN | Cancer | Male smokers age 50-69 years | Mean age: 57; % Female: 0; % White: NR; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 100 | Vit E: 26.7 mcmol/L | X | X | ACM: Full; Ca: Full; CVD: Full
de Gaetano, 2001 (PPP)^104^; Good | | 4495 (99.3%) | 666 IU | 4 (4) | ITA | CVD | Age ≥50 years with at least one CVD risk factor | Mean age: 64; % Female: 58; % White: NR; % Black: NR; Mean BMI: 27.6; % Curr. smoker: 15 | NR | X | X | ACM: Full; Ca: NA; CVD: Full
Hodis, 2002 (VEAPS)^127^; Fair | | 353 (73.1%) | 400 IU | 3 (3) | USA | Other: Subclinical atherosclerosis progression | Adults aged 40 years or older with LDL cholesterol ≥130 mg/dL | Mean age: 56; % Female: 52; % White: 75; % Black: NR; Mean BMI: NR; % Curr. smoker: 3 | NR | X | | ACM: NR; Ca: Self-report; CVD: Self-report
Lee, 2005 (WHS)^74^; Good | X | 39876 (99.4%) | 300 IU | 10 (10) | USA | CVD, Cancer | Adult females, aged ≥45 years, postmenopausal or not planning to become pregnant | Mean age: 55; % Female: 100; % White: 95; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 13 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Lippman, 2009 (SELECT)^80^; Good | X | 34888 (92.1%) | IG1: 400 IU; IG2: 400 IU + 200 mcg Selenium | 5.5 (7.1) | USA, CAN | CVD, Cancer | African American men age ≥50 years and men of other races age ≥55 years | Mean age: 63; % Female: 0; % White: 79; % Black: 13; Mean BMI: NR; % Curr. smoker: 8 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Magliano, 2006 (MAVET)^132^; Fair | | 409 (81.4%) | 500 IU | 4 (4) | AUS | Other: Carotid atherosclerosis progression | Caucasian smokers, aged 55 years or older | Mean age: 64; % Female: 54; % White: 100; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 100 | NR | X | | ACM: NR; Ca: NR; CVD: NR
McNeil, 2004 (VECAT)^130^; Good | | 1193 (87.4%) | 500 IU | 4 (4) | AUS | Other: Age-related cataracts | Adults aged 55-80 years with early or no cataract | Mean age: 66; % Female: 56; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 2 | NR | X | X | ACM: Full; Ca: NA; CVD: NA
Salonen, 2000 (ASAP)^77^; Fair | X | 520 (88.1%) | IG1: 404 IU + 500 mg Vitamin C; IG2: 404 IU | 3 (3) | FIN | CVD, Other: Carotid atherosclerosis | Adults aged 46-70 years with hypercholesterol-aemia | Mean age: 60; % Female: 51; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 40 | Vit E: 32.6 mcmol/L | X | X | ACM: NR; Ca: NA; CVD: NR
Sesso, 2008 (PHS-II)^81^; Good | X | 14641 (98.0%) | 200 IU | 8 | USA | CVD, Cancer | US male physicians aged ≥ 50 years | Mean age: 64; % Female: 0; % White: NR; % Black: NR; Mean BMI: 26; % Curr. smoker: 4 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Cohort
Feskanich, 2002 (NHS-I)^146^; Fair | X | 121700 (Varies%) | Unknown | <2; 2-4; 5-9; ≥10; (12, 18, 20.9) | USA | Other: Hip fractures, kidney stones, cataracts | Postmenopausal registered nurses age 30-55 years | Mean age: 58; % Female: 100; % White: NR; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 26 | NR | | X | ACM: NA; Ca: NA; CVD: NA
Zheng Selin, 2013 (COSM)^148^; Fair | | 27343 (100%) | Unknown | 11 (8.4, 11) | SWE | Other: Harms (Cataracts) | Men age 45-79 years | Mean age: 58; % Female: 0; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 25 | NR | | X | ACM: NA; Ca: NA; CVD: NA

* Includes participants randomized to all intervention groups, including for supplements other than multivitamins.

Abbreviations: ACM = All-cause mortality; BMI = Body mass index; Ca = Cancer; Calc = Calcium; Curr = Current; CVD = Cardiovascular disease; IU = International units; LDL = Low-density lipoprotein; mcmol/L = Micromole per liter; mg/dL = Milligram per deciliter; NA = Not applicable; NR = Not reported; Vit E = Vitamin E.

Nine RCTs reported KQ3 outcomes (n=116,468) and KQ4 outcomes were reported in seven RCTs (n=115,576) and two cohort studies (n=149,043). Most evidence indicated that vitamin E, with or without vitamin C, had no benefit for mortality, CVD, or cancer (Figure 6, Appendix E Figures 11, 12, and 13), and also no clear increased risk of serious harm. For example, pooled evidence demonstrated no association between vitamin E use and all-cause mortality (OR, 1.02 [95% CI, 0.97 to 1.07]; 9 RCTs [n=107,772]; I^2^=0%) or the composite outcomes of any CVD events (OR, 0.96 [95% CI, 0.90 to 1.04]; 4 RCTs [n=62,136]; I^2^=0%) or incidence of any cancer (OR, 1.02 [95% CI, 0.98 to 1.08]; 5 RCTs [n=76,777]; I^2^=0%). A cohort study of 27,343 Swedish men found a higher incidence of cataracts among men reporting any vitamin E use on a one-time survey than those who reported no use.^148^ However, no differences in cataract incidence were identified in the other, better-quality cohort study of postmenopausal American women that had biennial reporting of supplement use.^146^

Figure 6 Meta-Analysis Summary for Vitamin E^*^ * I-squared values shown for analyses using the MH model are taken from sensitivity analyses using random effects models; the MH model is based on a fixed effect model where calculation of I-squared is not applicable because it is assumed to be 0.

Abbreviations: CG = Control group; CI = Confidence interval; CVD = Cardiovascular disease; IG = Intervention group; MH = Mantel-Haenszel common (fixed) effects model; MI = Myocardial infarction; OR = Odds ratio; Peto = Peto odds ratio.

This figure is a forest plot showing meta-analysis summary for vitamin E

#### Detailed Study Characteristics

Nine RCTs^74,^ ^76,^ ^77,^ ^80,^ ^81,^ ^104,^ ^127,^ ^130,^ ^132^ and two cohort studies^146,^ ^148^ were included (n= 265,511, excluding participants randomized to take other supplements in factorial RCTs; Table 11). Five of these studies were newly identified and not included in the previous review: four RCTs^104,^ ^127,^ ^130,^ ^132^ and one cohort study.^148^ Only one^104^ of the newly-included studies had a primary aim of CVD and none had a primary aim of cancer. Both of the cohort studies were only included for harms, covering hip fractures, kidney stones, and cataracts.^146,^ ^148^ Six of the studies (all RCTs) were rated as good quality^74,^ ^76,^ ^80,^ ^81,^ ^104,^ ^130^ and the remaining trials were fair quality. The Nurses’ Health Study is a large cohort study that generally used good methods, however we rated it as fair quality because of its reliance on self-reported supplement use and inability to fully adjust for confounders.

Seven studies had an explicit aim of prevention of CVD^74,^ ^80,^ ^81,^ ^104^ or atherosclerosis progression,^77,^ ^127,^ ^132^ and three of these had a cancer prevention aim as well.^74,^ ^80,^ ^81^ One large trial had an exclusive aim of cancer prevention.^76^ Three studies aimed to explore the association between vitamin E and age-related cataracts,^130,^ ^146,^ ^148^ and one of these also explored hip fractures and kidney stones as potential harms of vitamin E use.^146^ Three of the studies did not describe having full ascertainment of the main outcomes for our review of all-cause mortality, CVD outcomes, or cancer incidence.^77,^ ^127,^ ^132^

In the trials, dosing was fairly wide-ranging, from 111 to 666 IU daily (50 to 300 mg/day), and duration of use ranged from 3 to 10 years. In the large Nurse’s Health Study cohort study,^146^ a variety of use durations were examined, compared with no use, with no restriction on dose. Two trials examined vitamin E with or without 500 mg of vitamin C^77^ and 200 mcg of selenium^80^ daily. However, the trial with concomitant vitamin C use was too small to allow conclusions with regard to all-cause mortality and did not report CVD or cancer outcomes. Five of the studies were conducted in the U.S.^74,^ ^81,^ ^127,^ ^146^ or the U.S. and Canada,^80^ and the others were conducted in Europe. Across all studies, the mean ages were in the 50s or 60s, mean BMIs were in the overweight range, and the samples were predominantly of White race. One of the largest trials, SELECT, reported the highest proportion of Black participants, which was only 13 percent.^80^ Two studies were limited to women^74,^ ^146^ and four were limited to men.^76,^ ^80,^ ^81,^ ^148^ Two studies were limited to smokers^76,^ ^132^ and three others selected patients based on other CVD risk factors.^77,^ ^104,^ ^127^ Most studies did not report baseline serum levels.

#### Detailed Results by Outcome

Nine RCTs reported KQ3 outcomes (n=116,468) and KQ4 outcomes were reported in seven RCTs (n=115,576) and two cohort studies (n=149,043). See Appendix F Table 22 for a summary of findings for each trial and Appendix F Table 23 for a listing of results from all pooled analyses. Comprehensive and detailed study-level results are available in Appendix F Tables 24, 25, 26, and 27.

##### All-Cause Mortality (KQ3)

All-cause mortality was reported in all nine RCTs. The pooled effect demonstrated no benefit of vitamin E use (OR, 1.02 [95% CI, 0.97 to 1.07]; 9 RCTs [n=107,772]; Figure 6, Appendix E Figure 11) after 3 to 10 years of followup. The results were identical using different pooling methods, and very similar when dropping four studies without full ascertainment of this outcome (Appendix F Table 23). Studies that reported additional longer term followup consistently reported similar findings to those shown in the Appendix E Figure 11,^76,^ ^80^ and no study found statistically significant group differences in all-cause mortality at any timepoint. None of the studies reported on effect modification by age, gender, race, or ethnicity. Effect sizes were very similar when vitamin E was used with or without selenium in SELECT.^80^

##### Cardiovascular Outcomes (KQ3)

CVD outcomes were reported in eight of the nine trials (Figure 6, Appendix E Figure 12). Pooled effects showed no group differences for CVD mortality, the composite CVD event outcome, MI, and stroke, and very few individual study results showed a statistically significant benefit. Several results shown in the forest plot were in the direction of benefit for CVD mortality, and WHS, a large good-quality trial of postmenopausal women,^74^ reported a statistically significant 24 percent reduction in the likelihood of CVD mortality after 10 years of 300 IU/day of vitamin E daily (study-reported RR=0.76 [95% CI, 0.59 to 0.98]). However, the pooled effect for CVD mortality was not statistically significant (OR, 0.88 [95% CI, 0.74 to 1.04]; 6 RCTs [n=77,114]) and effect sizes across all studies were wide-ranging, particularly when considering the broader set of related outcomes. Additionally, both PHS-II^81^ and ATBC showed an increased risk of hemorrhagic stroke mortality. In PHS-II, 0.5 percent among those taking vitamin E and 0.3 percent among those taking placebo experienced a hemorrhagic stroke (HR, 1.74 [95% CI, 1.04, 2.9]). In the ATBC study of smokers, hemorrhagic stroke death was similarly elevated (calculated OR, 1.50 [95% CI, 1.03 to 2.20]; vitamin E: 0.5%, placebo: 0.3%).^76^ Effect sizes across all pooled outcomes were very similar when limited to studies reporting full ascertainment of CVD outcomes. In SELECT, effect sizes for CVD outcomes were generally similar when vitamin E was taken with or without selenium, with the exception of stroke. Effect sizes suggested a less harmful impact when vitamin E was paired with selenium.^80^

WHS reported beneficial effects on CVD events among women age 65 years and older (RR, 0.74 [95% CI, 0.59 to 0.93]), which differed from the effect in younger women (interaction p=0.008; age 45-54: RR, 1.13 [95% CI, 0.91 to 1.4]; age 55-64: RR, 0.95 [95% CI, 0.77 to 1.16].^74^ No other studies reported effect sizes by age, and none of the studies reported effect modification by gender, race, or ethnicity.

##### Cancer (KQ3)

Cancer outcomes were reported by seven of the RCTs.^74,^ ^76,^ ^80,^ ^81,^ ^104,^ ^127,^ ^132^ Pooled effects showed no benefit of vitamin E use for cancer mortality, incidence of any cancer, or the incidence of colorectal, lung, breast, or prostate cancer (Figure 6, Appendix E Figure 13). Pooled ORs ranged from 0.98 (95% CI, 0.82 to 1.16; 3 RCTs [n=71,950]; I^2^=0%;) for colorectal cancer to 1.02 (95% CI, 0.98 to 1.08; 5 RCTs [n=76,777]; I^2^=0%;) for any incident cancer. For all outcomes, results were very similar when limited to trials with full ascertainment of cancer outcomes. However, the results for prostate cancer were inconsistent across studies. The ATBC study^76^ found a reduced risk of prostate cancer with 111 IU (50 mg) daily use for a median of 6.1 years, with or without concomitant beta-carotene use. For example, the ORs for prostate cancer for vitamin E (alone) were 0.64 (95% CI, 0.44 to 0.94) at 6.1-year followup and 0.88 (95% CI, 0.78 to 0.98) at the 24-year followup. On the other hand, no group differences were found in other large, good-quality trials (study-reported HR of 0.97 [95% CI, 0.85 to 1.09] in the PHS-II^81^ and 1.13 [95% CI, 0.95 to 1.35] in the SELECT study).^80^ Effect sizes for cancer outcomes were generally similar when vitamin E was taken with or without selenium.^80^ PHS-II found no effect modification by age, nor by several other health behaviors such as BMI, smoking status, physical activity, alcohol consumption, and parental history of cancer.^81^

##### Adverse Events (KQ4)

Three trials reported no group differences in the total number of adverse events,^104,^ ^130^ serious adverse events,^130^ or withdrawals due to adverse events.^77,^ ^130^ Trial evidence also supported no group differences in hospitalization from pneumonia,^76^ gastrointestinal disease,^104^ several bleeding outcomes,^81,^ ^104^ fatigue,^80^ nail changes,^80^ halitosis,^80^ easy bruising^81^ and noncataract ophthalmic events.^130^ However, some of these results were based on a very small or unknown number of events. Isolated statistically significant paradoxical (harmful) findings were reported for hemorrhagic stroke in two trials, as described above under CVD events.^76,^ ^81^

PHS-II found no increase in the incidence of cataracts with vitamin E use (HR, 0.99 [95% CI 0.88 to 1.11) after 8 years. Among the two cohort studies examining cataract incidence,^146,^ ^148^ the NHS^146^ found no group differences among 121,700 post-menopausal women for less than 2 years’ use, 2−4 years’ use, 5−9 years’ use, or 10 or more years’ use, compared with no use. Surveys were completed every 2 years to determine vitamin E use. However, a cohort study of 27,343 Swedish men age 49 to 79 years found a higher incidence of cataracts among men reporting any vitamin E use on a one-time survey than those who reported no use 8.4 years after completing the survey (HR, 1.57, 95% CI, 1.10 to 2.22; 22.2% of vitamin E users vs. 8.8% of non-users).^148^ Both of these studies relied on self-report to determine supplement use, which is subject to inaccuracy and recall bias.

### Folic Acid

#### Summary of Results

We identified five RCTs^84,^ ^97,^ ^109,^ ^110,^ ^133^ (n=6,370) of folic acid supplementation (Table 12). Three RCTs^84,^ ^109,^ ^110^ had primary aims relevant to this review; all three had an explicit aim to prevent colorectal cancer in persons with a previous adenoma, which were included for all outcomes, including colorectal cancer. Participants were randomized to use 1,000 mcg, 800 mcg, or 500 mcg of folic acid daily or to 400 mcg daily along with 500 mcg per day of vitamin B12.^97^ Four trials^97,^ ^109,^ ^110,^ ^133^ were newly identified and not included in the previous review. Two trials^84,^ ^110^ were conducted in the US, and across all trials, mean ages ranged from 57 to 74 years.

Table 12 Table of Study, Intervention, and Population Characteristics for Studies of Folic Acid Use, Sorted by Author

Author, Year (Study); Quality | In previous | Study N (% FUP) | Daily dose | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ3 | KQ4 | Ascertainment
RCT
Cole, 2007 (AFPPS)^84^; Fair | X | 1021 (59.4%) | 1000 mcg | 6.2 (2.75, 6.2, 7) | USA | Cancer | Adults, age 21-80 years, with a history of adenomas | Mean age: 57; % Female: 36; Percent White: 86; Percent Black: 6; Mean BMI: 27.4; % Curr. smoker: 14 | Fol: 23.8 nmol/L | X | | ACM: NR; Ca: Full; CVD: Full
Durga, 2007 (FACIT)^133^; Fair | | 819 (99.3%) | 800 mcg | 3 (3) | NLD | Other: Cognitive function | Adults aged 50-70 years with high homocysteine | Mean age: 60; % Female: 28; Percent White: NR; Percent Black: NR; Mean BMI: 26.5; % Curr. smoker: 20 | Fol: 12 nmol/L | X | X | ACM: NR; Ca: NA; CVD: NA
Logan, 2008 (ukCAP)^109^; Fair | | 939 (90.8%) | 500 mcg | 3 (3) | GBR, DNK | Other: Prevention of recurrent colorectal adenoma | Adults aged 75 years or younger with a recent history of colorectal adenoma | Mean age: 58; % Female: 43; Percent White: NR; Percent Black: NR; Mean BMI: NR; % Curr. smoker: NR | NR | X | X | ACM: NR; Ca: Self-report; CVD: Self-report
van Wijngaarden, 2014 (B-PROOF)^97^; Fair | | 2919 (82.7%) | 400 mcg + 500 mcg Vitamin B12 | 2 (2, 6.5) | NLD | Other: Fractures | Age ≥65 years with elevated homocysteine concentrations | Mean age: 74; % Female: 50; Percent White: NR; Percent Black: NR; Mean BMI: 27.2; % Curr. smoker: 10 | Fol: 18.8 nmol/L; Vit B12: 286.6 pmol/L | X | X | ACM: Relative-report; Ca: Full; CVD: NA
Wu, 2009^110^; Good | | 672 (100%) | 1000 mcg | 6.5 (6.5) | USA | Other: Colorectal adenoma | Adults aged 50-78 from NHS and HPFS cohorts with a history of colorectal adenoma | Mean age: 65; % Female: 62; Percent White: NR; Percent Black: NR; Mean BMI: 25.7; % Curr. smoker: 7 | Fol: 21.5 nmol/L | X | X | ACM: Relative-report; Ca: Full; CVD: NA

Abbreviations: ACM = All-cause mortality; AFPPS = Aspirin/Folate Polyp Prevention Study; BL = Baseline; BMI = Body mass index; B-PROOF = B-Vitamins for the PRevention Of Osteoporotic Fractures; Ca = Cancer; CVD = Cardiovascular disease; Curr = Current; FACIT = Folic Acid and Carotid Intima-media Thickness; Fol = Folic acid; FUP = Followup; HPFS = Health Professionals Follow-Up Study; mcg = Microgram; NHS = Nurses’ Health Study; NA = Not applicable; NR = Not reported; nmol/L = Nanomole per liter; pmol/L = Picomole per liter; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; Vit B12 = Vitamin B12.

Five RCTs reported KQ3 outcomes (n=6,370) and four reported KQ4 outcomes (n=5,854). Evidence indicated that folic acid had no benefit for mortality (Appendix E Figure 14), but increased the risk of any cancer incidence in 2 of 3 studies, which were limited to people with a history of adenomas or with elevated homocysteine concentrations (Figure 7). There were too few events to draw conclusions about CVD mortality and CVD composite outcomes (Appendix E Figure 15) or site-specific cancers, although one trial did report an increased risk of prostate cancer^84^ (Appendix E Figure 16). The pooled effect for all-cause mortality was in the direction of benefit, but was not statistically significant and most studies had fewer than 20 deaths in either group (Peto OR 0.71 [95% CI, 0.49 to 1.03]; 5 RCTs [n=6,370]; I^2^=21.1%, Appendix E Figure 14). On the other hand, the pooled effect for any cancer incidence demonstrated an increased risk at or beyond 2 years of followup (Peto OR, 1.42 [95% CI, 1.10 to 1.84]; 3 RCTs [n=4,612]; I^2^= 0%, Appendix E Figure 16). Evidence suggested no benefit for MI and stroke (Appendix E Figure 15). For example, the pooled effects for the composite outcomes for MI and stroke were OR 1.26 (95% CI, 0.86 to 1.85); 4 RCTs [n=3,201]; I^2^=43.8%) and OR 0.79 ([95% CI, 0.54 to 1.14]; 4 RCTs [n=3,201]; I^2^=13.1%), respectively, although both estimates were imprecise.

Figure 7 Meta-Analysis Summary for Folic Acid

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; OR = Odds ratio; Peto = Peto odds ratio.

This figure is a forest plot showing meta-analysis summary for folic acid

There was no clear increased risk of other serious harm aside from the cancer incidence findings.

#### Detailed Study Characteristics

We identified five RCTs^84,^ ^97,^ ^109,^ ^110,^ ^133^ (n=6,370) of folic acid supplementation among adults with mean ages ranging from 57 to 74 years. One trial^84^ was included for benefits only, the other four trials^97,^ ^109,^ ^110,^ ^133^ were included for benefits and harms. Four trials^97,^ ^109,^ ^110,^ ^133^ were newly identified and not included in the previous review.

Three RCTs^84,^ ^109,^ ^110^ had an explicit aim to prevent colorectal cancer and all three were limited to adults with a history of colorectal adenomas. The other two RCTs aimed to explore the effects of folic acid on cognitive performance^133^ and osteoporotic fractures,^97^ both limited to adults with slightly^133^ to moderately^97^ elevated homocysteine concentration. Participants in three RCTs received folic acid only in doses of 500 mcg/day,^109^ 800 mcg/day,^133^ and 1,000 mcg/day^110^ or placebo for 3 to 6.5 years. Participants in the Aspirin/Folate Polyp Prevention Study (AFPPS)^84^ were randomized to 1,000 mg/daily of folic acid or placebo, then separately randomized to receive aspirin (81 mg or 325 mg daily) or placebo (3x2 factorial design). This was the only study included in the previous review. The Wu 2009^110^ trial was conducted among participants of two large prospective cohorts—the Health Professionals Follow-Up Study and the Nurses’ Health Study, and was the only study rated as good quality. The remaining four trials^84,^ ^97,^ ^109,^ ^133^ were rated as fair quality, all were downgraded because ascertainment for outcomes relevant to our review were not reported; some had additional methodologic concerns.

The largest included trial, B Vitamins for the Prevention of Osteoporotic Fractures (B-PROOF),^97^ randomized 2,919 men and women aged ≥65 years and with moderately elevated homocysteine concentrations (12–50 micromol/L) to 400 mcg/day of folic acid and vitamins B12 and D3 (500 mcg/day and 15 mcg/day, respectively), or placebo supplementation with 15 mcg of vitamin D3 for 2 years. Trials were conducted in the US,^84,^ ^110^ The Netherlands^97,^ ^133^ and the UK and Denmark.^109,^ ^133^ Only one trial reported race or ethnicity, and only 8 percent of participants in this trial were Black.^84^ Among the four studies reporting baseline serum folic acid levels, the range was from 3.8^133^ to 10.5 ng/mL,^84^ values that are all considered normal (above 3.0 ng/mL).^156^

#### Detailed Results by Outcome

Five RCTs reported KQ3 outcomes (n=6,370) and four report KQ4 outcomes (n=5,854). See Appendix F Table 28 for a summary of findings for each trial and Appendix F Table 29 for a listing of results from all pooled analyses. Comprehensive and detailed study-level results are available in Appendix F Tables 30, 31, 32, and 33.

##### All-Cause Mortality (KQ3)

All-cause mortality was reported in all five trials—70 (2.2% of 3,191) deaths occurred in intervention groups and 95 deaths (3.0% of 3,179) occurred in control groups altogether. None of the trials demonstrated a statistically significant effect of 400 mcg to 1,000 mcg folic acid daily on all-cause mortality after 2 to 6.5 years of followup and 2 to 6.5 years of folic acid use. The pooled effect was not statistically significant (Peto OR, 0.71 [95% CI, 0.49 to 1.03]; five RCTs [n=6,370]; I^2^=21.1%, Figure 7, Appendix E Figure 14); however, our sensitivity analysis using an alternate pooling method demonstrated significant association between the use of folic acid and reduction in all-cause mortality when using the Mantel-Haenszel model (OR, 0.73 [95% CI, 0.73 to 0.99]; Appendix F Table 29). Most studies had fewer than 20 events per study group, so as few as two to three additional deaths in either group could substantially change a study’s effect size. All studies either did not report^84,^ ^109,^ ^133^ the ascertainment methods for all-cause mortality or deaths were reported by relatives.^97,^ ^110^ The study with the most deaths was B-PROOF, with 37 (2.5%) deaths in the intervention group taking folic acid combined with vitamin B12 and 42 (2.9%) deaths in the placebo group (OR, 0.88 [95% CI 0.56 to 1.37], n=2,919). No studies reported on effect modification by age, gender, race, or ethnicity.

##### Cardiovascular Outcomes (KQ3)

Four trials^84,^ ^97,^ ^109,^ ^110^ reported CVD outcomes (Appendix E Figure 15). The incident rates for CVD mortality,^110^ MI,^84,^ ^97,^ ^109,^ ^110^ stroke,^84,^ ^97,^ ^109,^ ^110^ and the composite CVD event outcome^110^ were wide-ranging and did not differ between the intervention and control groups in any the individual studies. Pooled effects showed no group differences for MI (OR 1.26 [95% CI, 0.86 to 1.85]; 4 RCTs [n=3,201]; I^2^=43.8%) and stroke (OR 0.79 [95% CI, 0.54 to 1.14]; 4 RCTs [n=3,201]; I^2^=31.1%). However, there were too few events in three^84,^ ^109,^ ^110^ out of four trials to draw conclusions about the effects of folic acid on CVD. For example, there were only a total of 32 MIs and 23 strokes across these three studies. Only a sub-analysis conducted on a random sample of 569 persons from the B-PROOF study reported a substantial number of events, finding no statistically significant difference for MI and stroke in older persons with an increased level of homocysteine.^157^

##### Cancer (KQ3)

Four trials reported a cancer outcome.^84,^ ^97,^ ^109,^ ^110^ In the pooled analysis, folic acid, either alone^84,^ ^110^ or with vitamin B12,^97^ was associated with higher rates of any cancer incidence (Peto OR 1.42 [95% CI, 1.10 to 1.84]; 3 RCTs [n=4,612]; I^2^=0.0%) at 2 to 6 years of followup, after 2 to 6 years of supplement use. Two^84,^ ^97^ of the three trials reported statistically significant increases in cancer incidence for at least one followup timepoint. The study with the most events for any cancer outcome was the B-PROOF^97^ trial, which was limited to people with elevated homocysteine levels. B-PROOF was the only study reporting on cancer that was not limited to people with a previous colorectal adenoma. B-PROOF found a higher rate of any cancer incidence at two years of followup (HR, 1.56 [95% CI, 1.04 to 2.31]), particularly for women (HR, 2.35 [95% CI, 1.23 to 4.50]. However, this effect was no longer statistically significant at 6.5 years followup (HR, 1.25 [95% CI, 1.00 to 1.57]) for both women and men combined, and results were not reported separately by gender. At the 2-year followup, there were 63 (4.3%) newly diagnosed cancer cases in the group taking folic acid and vitamin B12, compared with 42 (2.9%) in those taking placebo. After 6.5 years, the number cases were 171 (13.6%) with folic acid and vitamin B12, and 143 (11.3%) with the placebo. Excess cancer cases appeared to be primarily driven by colorectal cancer in B-PROOF and prostate cancer in AFPPS.

Although there were few site-specific cancer cases in any trials, B-PROOF was the largest study and had the most events with 19 cases of colorectal cancer.^97^ B-PROOF reported a statistically significant increase in the risk for colorectal cancer at 2 and 6.5 years of followup (HR, 1.77 [95% CI, 1.08 to 2.90] at 6.5 years). B-PROOF was the only study reporting colorectal cancer incidence that was not limited to people with a previous adenoma, however the other three studies were all underpowered for this outcome and only reported between 1 and 5 events per study arm. The pooled effect for colorectal cancer combining all four trials was not statistically significant (Peto OR, 1.16 [95% CI, 0.50 to 2.66]; 4 RCTs [n=5,538]; I^2^=37.3%; Figure 7, Appendix E Figure 16).

Two trials^84,^ ^110^ examined the effect of 1,000 mcg of folic acid daily on the incidence of prostate cancer at 6.5- and 7-years of followup. The number of prostate cancer diagnoses was small in the Wu 2009^110^ trial (11 cases total) and groups did not differ (OR, 0.79, 95% CI, 0.23 to 2.65). However, the AFPPS^84^ trial reported an increased risk for prostate cancer with folic acid use. Over a median of 7 years, the adjusted probability of prostate cancer diagnosis was 9.7 percent (95% CI, 6.5% to 14.5%) in the intervention group and 3.3 percent (95% CI, 1.7 to 6.5%) in the control group (multivariable-adjusted HR, 2.58 [95% CI, 1.14 to 5.86]), although this is based on a total of only 34 cases.^158^

None of the trials found evidence of benefit of folic acid, either alone or with vitamin B12 on the incidence of breast,^97,^ ^110^ lung,^97^ ^110^ hematological,^97^ musculoskeletal,^97^ melanoma,^97^ ear, nose, throat,^97,^ ^110^ reproductive system (both male and female) cancer,^97^ or urinary cancer either at 2 or 6 years of followup, with few events reported for site-specific cancers.

##### Adverse Events (KQ4)

All five trials reported on adverse events or potential harms with folic acid supplementation. None of the studies reported any increased risk of serious adverse events associated with folic acid, except the increased risk of prostate cancer in the AFPPS^84^(n=1,021) trial described above.

In B-PROOF,^97^ 1.0 percent of intervention group participants withdrew from the study due to perceived side effects attributed to the study tablets during the 2 years of followup, compared with 0.9 percent in the control group. In the good-quality study, one person (0.3%) in the intervention and seven people (2.1%) in the control group stopped taking study tablets due to patient-perceived symptoms attributed to the study tablets.^110^ There were no group differences in gastrointestinal-related outcomes,^109,^ ^133^ including gastrointestinal bleeding (0.8% taking folic acid vs. 1.3% taking the placebo) and peptic ulcer (0.2% taking folic acid vs. 0.6% taking the placebo), although there were too few events to draw firm conclusions.^109^

### Vitamin B3

#### Detailed Study Characteristics and Summary of Results

We included one RCT^102^ evaluating nicotinamide (a form of vitamin B3), which was included for KQ3 and KQ4. This study was a small, good-quality RCT that randomized 386 Australian men and women aged 30–91 years with at least two nonmelanoma skin cancers in the previous five years to nicotinamide (12 months of 1,000 mg/day) or placebo (Table 13). The purpose of this RCT was to test the protective effect of nicotinamide to reduce new nonmelanoma skin cancers and actinic keratoses in a high-risk population. This trial was newly identified and not included in the previous review. The full ascertainment was reported for the incidence of skin cancer only, which we did not retain since we did not address tertiary prevention in this review. Ascertainment of other cancers, mortality and CVD events was not reported; outcomes relevant to our review were captured as part of the adverse events reporting.

Table 13 Table of Study, Intervention, and Population Characteristics for Studies of Vitamin B3 and B6 Use, Sorted by Author (KQ3 and KQ4)

Author, Year (Study); Quality | In previous | Study N^*^ (% FUP) | Daily dose | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ3 | KQ4 | Ascertainment
RCT
Chen, 2015 (ONTRAC)^102^; Good | | 386 (91.2%) | Vit B3: 1000 mg | 1 (1) | AUS | Cancer | Age ≥18 years with history of ≥2 nonmelanoma skin cancers | Mean age: 66; % Female: 37; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | NR | X | X | ACM: NR; Ca: Self-report; CVD: Self-report
Cohort
Feskanich, 2002 (NHS-I)^146^; Fair | X | 121700 (Varies%) | Vit B6: Unknown; Vit B12: Unknown | NR (12, 18, 20.9) | USA | Other: Hip fractures, kidney stones, cataracts | Postmenopausal registered nurses age 30-55 years | Mean age: 58; % Female: 100; % White: NR; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 26 | NR | | X | ACM: NA; Ca: NA; CVD: NA

* Includes participants randomized to all intervention groups, including for supplements other than multivitamins.

Abbreviations: ACM = All-cause mortality; BL = Baseline; BMI = Body mass index’ Ca = Cancer; Curr = Current; CVD = Cardiovascular disease; NA = Not applicable; NHS-I = Nurses’ Health Study; NR = Not reported; ONTRAC = Oral Nicotinamide to Reduce Actinic Cancer; RCT = Randomized controlled trial; Vit B3 = Vitamin B3; Vit B12 = Vitamin B12.

In this trial, with only a few events reported, data were insufficient to draw conclusions for the impact on mortality, CVD, (non-skin) cancer outcomes, or serious harms (Table 14).

Table 14 Table of Results for Vitamin B3 for Main Review Outcomes by Intervention Group; One Randomized, Controlled Trial With Aim to Prevent Non-Melanoma Skin Cancer in Persons at High Risk (KQ 3)

Outcome | Vitamin B3; n/N (%) | Placebo; n/N (%)
All-cause mortality | 2/193 (1.0) | 1/193 (0.5)
MI | 3/193 (1.6) | 0/193 (0.0)
Stroke | 0/193 (0.0) | 1/193 (0.5)
Any cancer incidence | 5/193 (2.6) | 2/193 (1.0)
Colorectal cancer | 1/193 (0.5) | 0/193 (0.0)
Lung cancer | 1/193 (0.5) | 1/193 (0.5)
Prostate cancer | 1/193 (0.5) | 0/193 (0.0)

Abbreviation: MI = Myocardial infarction.

#### Detailed Results by Outcome

The included trial was included for both KQ3 and KQ4. See Appendix F Table 34 for a summary of findings for the included trial. A full listing of all relevant results is available in Appendix F Tables 35, 36, 37, and 38.

##### All-Cause Mortality (KQ3)

Data were insufficient to evaluate all-cause mortality, with only one death in the intervention group and two deaths in the control group over the 12-month study period.

##### Cardiovascular Outcomes (KQ3)

Data were insufficient to evaluate CVD outcomes (i.e., myocardial infarction, stroke, and heart failure); only a very small number of events was reported (no more than 3 participants experienced any of these outcomes in either group).

##### Cancer (KQ3)

Data were insufficient to evaluate cancer outcomes, including, colorectal, lung, prostate, duodenal cancer, non-Hodgkin’s lymphoma, or any neoplasm. The outcome with the most events was any neoplasm, experienced by eight individuals (4.1%) who took nicotinamide and four (2.1%) individuals taking a placebo (OR, 2.04 [95% CI, 0.60 to 6.90]).

##### Adverse Events (KQ4)

Only very few adverse events were reported. The most common adverse event reported was cardiac chest pain experienced by eight (4.1%) individuals in the placebo group and one (0.5%) person in the nicotinamide group.

### Vitamin B6

#### Study Characteristics and Results

We found no studies examining all-cause mortality, CVD, or cancer for vitamin B6. Only one fair-quality cohort study of vitamin B6 supplementation met the inclusion criteria for harms of supplementation—the Nurses’ Health Study (NHS-I, n=121,700)^146^ initiated in 1976^146,^ ^159^ (Table 13). The sub-analysis^146,^ ^159^ of this study included 75,864 women and examined the risk for hip fracture in postmenopausal female registered nurses in the US receiving vitamin B6 supplements in excess of dietary intake. The median cumulative intake of vitamin B6 was 3.6 mg/day (intake raged <2 to ≥35 mg/day). The doses of vitamin B6 received from a supplement ranged from <2 to ≥25 mg/day. The mean followup time was 20.9 years. This was a newly published result, although the Nurse’s Health Study was included in the previous review for vitamin A, multivitamins, and beta-carotene. See Appendix F Table 34 for a summary of findings for the included study.

##### All-Center Mortality, CVD, Cancer (KQ3)

No evidence was included.

##### Adverse Events (KQ4)

This study demonstrated that an intake of high cumulative doses of vitamin B6 (≥35 mg/day) was associated with an increased risk of hip fracture (RR, 1.29 [95% CI, 1.04 to 1.59], p-value for linear trend, 0.06), compared to the reference category of total vitamin B6 <2 mg/day. Women who consumed no vitamin B6 supplements had the lowest risk for hip fractures, compared to women receiving from less than 2 mg/day (RR, 1.37 [95% CI, 1.12 to 1.69]) to more than 25 mg/day (RR, 1.41 [95% CI, 1.10 to 1.80]). A listing of all relevant results reported in this study is available in Appendix F Table 38.

### Vitamin C

#### Summary of Results

Six studies of vitamin C use were included (n=254,587, Table 15): two RCTs (n=15,031)^77,^ ^81^ and four cohort studies (n=239,556).^146,^ ^148,^ ^150,^ ^151^ Three of the cohort studies are newly identified and not included in the previous review.^148,^ ^150,^ ^151^ Studies were conducted in the U.S. and Scandinavian countries and included adults primarily in their late 50s to mid-60s. Most evidence for CVD and cancer is from a single large and good-quality U.S-based study of male physicians (n=14,641), PHS-II, which had CVD and cancer prevention as primary aims.^81^ A smaller RCT of fair quality evaluated the effect of vitamin C on progression of carotid atherosclerosis and reported a very small number of deaths and adverse events.^77^ Vitamin C doses were 500 mg per day in both RCTs, with followup times of 3 and 8 years.

Table 15 Table of Study, Intervention, and Population Characteristics for Studies of Vitamin C Use, Sorted by Author (KQ3 and KQ4)

Author, Year (Study); Quality | In previous | Study N^*^ (% FUP) | Daily dose | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ3 | KQ4 | Ascertainment
RCT
Salonen, 2000 (ASAP)^77^; Fair | X | 520 (88.1%) | IG1: 500 mg + 404.04000854 IU Vitamin E; IG2: 500 mg | 3 (3) | FIN | CVD, Other: Carotid atherosclerosis | Adults aged 46-70 years with hypercholesterol-aemia | Mean age: 60; % Female: 51; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 40 | NR; Vit C: 32.6 mcmol/L | X | X | ACM: NR; Ca: NA; CVD: NR
Sesso, 2008 (PHS-II)^81^; Good | X | 14641 (98.0%) | 500 mg | 8 () | USA | CVD, Cancer | US male physicians aged ≥ 50 years | Mean age: 64; % Female: 0; % White: NR; % Black: NR; Mean BMI: 26; % Curr. smoker: 4 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Cohort
Feskanich, 2002 (NHS-I)^146^; Fair | X | 121700 (Varies) | Unknown | <2; 2-4; 5-9; ≥10; (12, 18, 20.9) | USA | Other: Hip fractures, kidney stones, cataracts | Postmenopausal registered nurses age 30-55 years | Mean age: 58; % Female: 100; % White: NR; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 26 | NR | | X | ACM: NA; Ca: NA; CVD: NA
Rautiainen, 2010 (SMC)^151^; Fair | | 38984 (63.1%) | 1000 mg | 8.2 (8.2) | SWE | Other: Cataract | Women aged 49-83 years | Mean age: 61; % Female: 100; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 25 | NR | | X | ACM: NA; Ca: NA; CVD: NA
Taylor, 2004 (HPFS)^150^; Fair | | 51529 (NR%) | Unknown | NR (14, 26) | USA | Other: Kidney stones | Male health professionals age 40 to 75 years | Mean age: NR; % Female: 0; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | NR | | X | ACM: NA; Ca: NA; CVD: NA
Zheng Selin, 2013 (COSM)^148^; Fair | | 27343 (100%) | Unknown | 11 (8.4, 11) | SWE | Other: Harms (Cataracts) | Men age 45-79 years | Mean age: 58; % Female: 0; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: 25 | NR | | X | ACM: NA; Ca: NA; CVD: NA

* Includes participants randomized to all intervention groups, including for supplements other than multivitamins.

Abbreviations: ACM = All-cause mortality; BL = Baseline; BMI = Body mass index; Ca = Cancer; CVD = Cardiovascular disease; Curr = Current; FUP = Followup; mcmol/L = Micromoles per liter; mg = Milligram; NA = Not applicable; NR = Not reported; Vit C = Vitamin C; Randomized controlled trial.

Both RCTs (n=15,031) reported KQ3 and KQ4 outcomes, and KQ4 outcomes were also reported in the 4 cohort studies (n=239,556). This small body of trial evidence suggests that vitamin C supplementation of 500 mg/day for 3 to 8 years has no benefit for mortality, CVD, or cancer outcomes and no serious harm (Figure 8). For example, PHS-II found no benefit for all-cause mortality (HR 1.07 [95% CI, 0.97 to 1.18]), cardiovascular events (HR 0.99 [95% CI, 0.89 to 1.11], or total cancer incidence (HR 1.01 [95% CI, 0.92 to 1.10]) at 8 years of followup. Evidence from cohort studies was inconsistent for a possible increased risk for cataracts and suggests increased risk of kidney stones in men.

Figure 8 Evidence Summary for Vitamin C

Abbreviations: CG = Control group; CI = Confidence interval; CVD = Cardiovascular disease; HR = Hazard ratio; IG = Intervention group; MI = Myocardial infarction; NA = Not applicable; PHS-II = Physicians’ Health Study II.

This figure is a forest plot showing the evidence summary for vitamin C

#### Detailed Study Characteristics

Six studies of vitamin C use were included (n=254,587).^77,^ ^81,^ ^146,^ ^148,^ ^150,^ ^151^ These studies include two RCTs^77,^ ^81^ and four cohort studies^146,^ ^148,^ ^150,^ ^151^ evaluating harms only (Table 15). Three studies are new in this update and all are cohort studies reporting harms.^148,^ ^150,^ ^151^

The largest RCT (n=14,641), PHS-II, was a good-quality trial conducted in the U.S. that recruited male physicians age 50 years or older that also evaluated vitamin E, multivitamin, and beta-carotene in addition to vitamin C in a 2x2x2x2 factorial design.^81^ The other much smaller RCT (n=390 for vitamin C-related supplements), ASAP, was a fair-quality trial conducted in Finland of men and women aged 45 to 69 years with mildly elevated cholesterol. This trial tested an intervention of vitamin C alone and an intervention of combined vitamin C and vitamin E.^77^ All four cohort studies were rated fair quality. Two were conducted in the U.S.^146,^ ^150^ and two were conducted in Sweden.^148,^ ^151^ Each cohort was large and was population-based or recruited from the health professions. Vitamin use was obtained by self-report in each cohort.

PHS-II had the primary aim of evaluating supplementation on total and prostate cancer, CVD, and the age-related eye diseases of cataract and macular degeneration. Outcome ascertainment was valid and robust for the main outcomes of our review. The smaller ASAP trial had the study aim of evaluating progression of carotid atherosclerosis. Outcome ascertainment is not described for the six deaths reported in this trial (3 deaths occurring in vitamin C or placebo groups). All cohort studies had broad aims about chronic disease. The two Swedish cohorts ascertained outcomes using registries and the two U.S. cohorts ascertained outcomes based on self-report with medical record confirmation.

Vitamin C doses were 500 mg per day in both RCTs, with followup times of 3 and 8 years for ASAP and PHS-II, respectively. In the cohort studies evaluating harms, followup ranged from 8 to 14 years, with sub-analyses reported by duration of use. Dose information in the harms studies, which was captured by self-report, was varied.

The trials were conducted in the U.S. and Finland and the cohort studies were conducted in the U.S. and Sweden. Across all studies, mean ages were in the late 50s to mid-60s. With the exception of the smaller trial,^77^ studies were conducted either exclusively in men or women. BMI was reported only in the largest trial and largest cohort, with a mean of 26 kg/m^2^ in both studies.^81,^ ^146^ Smoking rates were highly variable, ranging from 4 percent in the U.S.-based PHS-II trial,^81^ to 40 percent in the Finnish trial.^77^ Specific data on race/ethnicity was not reported for any study and was described only as predominately White in the large PHS-II trial. No study reported baseline vitamin C levels.

#### Detailed Results by Outcome

Both RCTs (n=15,031) reported KQ1 and KQ2 outcomes, and KQ2 outcomes were also reported in 4 cohort studies (n=239,556). See Appendix F Tables 39 for a summary of findings for each trial. Comprehensive and detailed study-level results are available in Appendix F Tables 40, 41, 42, and 43.

##### All-Cause Mortality (KQ3)

All-cause mortality was reported in two trials.^77,^ ^81^ The vast majority of evidence is from the PHS-II trial of exclusively men, which showed that 500 mg/day vitamin C was not associated with all-cause mortality (HR 1.07 [95% CI, 0.97 to 1.18], Figure 8) at 8 years of followup.^81^ At 8 years of followup, 11.7 percent of those in the vitamin C group died compared to 11.0 percent who were not taking vitamin C). The much smaller ASAP trial (n=390) was not powered to evaluate mortality. Three deaths occurred; one each in the vitamin C, vitamin C plus vitamin E, and placebo groups.^77^ None of the studies reported on effect modification by age, gender, race, or ethnicity.

##### Cardiovascular Outcomes (KQ3)

Cardiovascular events were reported in two trials.^77,^ ^81^ In PHS-II, vitamin C was not associated with cardiovascular events (HR 0.99 [95% CI, 0.89 to 1.11], Figure 8) at 8 years of followup.^81^ Similarly, results suggested no difference for CVD mortality (HR 1.02 [95% CI, 0.85 to 1.21], Figure 8), or any individual CVD event at 8 years of followup. For example, 3.5 percent of those in the vitamin C group experienced an MI compared with 3.4 percent in the no vitamin C group (HR 1.04 [95% CI, 0.87 to 1.24], Figure 8). For stroke, 3.0 percent in the vitamin C group experienced this event compared with 3.4 percent in the no vitamin C group (HR 0.89 [95% CI, 0.74 to 1.07], Figure 8). The three deaths that occurred in the smaller ASAP trial were CVD deaths; one each in the vitamin C, vitamin C + vitamin E, and placebo groups.^77^ PHS-II found no effect modification for CVD outcomes by age or CVD risk factors, including BMI, smoking status, physical activity, alcohol consumption, and parental history of CVD prior to age 60.

##### Cancer (KQ3)

Cancer was reported only in PHS-II, which had total and prostate cancer as co-primary outcomes (Figure 8).^81^ Vitamin C was not associated with total cancer incidence (HR 1.01 [95% CI, 0.92 to 1.10]) or total cancer death (HR 1.06 [95% CI, 0.89 to 1.25]) at 8 years of followup. Incident prostate cancer occurred in 6.9 percent in the vitamin C group and 6.8 percent in the group not receiving vitamin C with no statistically significant differences between groups (HR 1.02 [95% CI, 0.90 to 1.15]). Prostate cancer death occurred in 0.6 percent of the vitamin C group and 0.4 percent of the group not taking vitamin C with no statistically significant differences between groups (HR 1.46 [95% CI, 0.92 to 2.31]). There were no differences for any other reported individual cancer (colorectal and lung). PHS-II found no effect modification by age, nor by several other health behaviors such as BMI, smoking status, physical activity, alcohol consumption, and parental history of cancer.^81^

##### Adverse Events (KQ4)

All six studies reported on the harms of vitamin C use. The included trials found no increase in serious or nonserious harms from long-term vitamin C use.^77,^ ^81^ Furthermore, there were no statistically significant paradoxical findings for mortality, cancer, or CVD in either trial. PHS-II reported no statistically significant effects on minor bleeding (including hematuria, easy bruising, and epistaxis) or gastrointestinal symptoms (peptic ulcer, constipation, diarrhea, gastritis, and nausea), fatigue, drowsiness, skin discoloration, rashes, and migraine.^81^ The smaller ASAP trial reported only withdrawals due to adverse events and found similar numbers in all groups: six in those on vitamin C, seven in those on vitamin C plus vitamin E, and eight in the placebo group.^77^

Three cohort studies^146,^ ^148,^ ^151^ and one trial^81^ evaluated the association of vitamin C use with cataract extraction, with mixed results. The two Swedish cohorts, one in women and one in men, each found that vitamin C supplementation of an estimated dose of 1,000 mg/day was associated with a statistically significant increased risk of cataract extraction over 8 years of followup when compared to no supplementation.^148,^ ^151^ The magnitude of increased risk was similar in both cohorts: a hazard ratio of 1.25 (95% CI, 1.05 to 1.50) in the Swedish Mammography Cohort,^151^ and a hazard ratio of 1.21 (95% CI, 1.04 to 1.41) in the Cohort of Swedish Men.^148^ However, vitamin C use was assessed only by a one-time questionnaire. The NHS cohort study,^146^ which assessed vitamin C use every 2 years by questionnaire, found that vitamin C supplementation was not associated with cataract extraction for any duration of current use (<2 years: RR 1.08 [95% CI, 0.88 to 1.32], 2-4 years: RR 1.01 [95% CI, 0.76 to 1.33], 5−9 years: 1.05 [95% CI, 0.84 to 1.31], ≥10 years: RR 0.95 [95% CI, 0.76 to 1.20]). Vitamin C dose in NHS was not reported. Similarly, the very large PHS-II trial found no association of 500 mg/day vitamin C and cataracts (HR 1.02 [95% CI, 0.91 to 1.14]) at 8 years of followup.^81^ All three cohort studies reported no effect modification by age on likelihood of cataracts.

Two cohort studies,^148,^ ^150^ both conducted exclusively in men, evaluated the association of vitamin C use with kidney stones and suggest an association between supplementation and this harm. In the Cohort of Swedish Men, vitamin C use of an estimated dose of 1,000 mg/day was associated with the risk of a first kidney stone at 11 years of followup (RR 1.92 [95% CI, 1.33 to 2.77]).^148^ The Health Professionals Follow-up Study reported the risk of kidney stones for no vitamin C use compared to various doses at 14 years of followup.^150^ While no single dose category comparison was statistically significant, the overall trend across dose was statistically significant (p=0.01). The risk ratio for no use compared to 1,000 mg/day or more was 1.16 (95% CI, 0.97 to 1.39). Both cohorts performed one-time assessments of vitamin C use by questionnaire.

### Calcium

#### Summary of Results

Nine studies of calcium use were included (n=134,661, Table 16): 8 RCTs^82,^ ^83,^ ^85,^ ^89,^ ^91,^ ^105,^ ^106,^ ^114^ (n=12,961) and one large cohort study^146^ (n=121,700). Two studies had an explicit cancer prevention aim,^83,^ ^89^ and two additional trials aimed to prevent colorectal adenoma recurrence among patients with a recent adenoma.^85,^ ^91^ Two studies aimed to prevent CVD.^89,^ ^106^ Four^91,^ ^105,^ ^106,^ ^114^ trials were newly identified and not included in the previous review; none of these newly-included trials had a specific cancer or CVD prevention aim. The most common doses were 1000 and 1200 mg/day, and duration of use ranged from six months to five years. Followup time ranged from 6 months to 12 years post-baseline. Across all trials, participants were generally aged 40 years and older, and five of the studies were conducted in the US.^83,^ ^85,^ ^91,^ ^114,^ ^146^ The best evidence came from the RECORD trial (n=5,292), which examined the effects of 1000 mg/day of calcium, with or without 800 IU/day of vitamin D in a 2x2 factorial design, on CVD and cancer outcomes among older adults with fragility fractures.^89^

Table 16 Table of Study, Intervention, and Population Characteristics for Studies of Calcium Use (Without Vitamin D), Sorted by Author (KQ3 and KQ4)

Author, Year (Study); Quality | In previous | Study N^*^ (% FUP) | Daily dose | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ3 | KQ4 | Ascertainment
RCT
Avenell, 2012 (RECORD)^89^; Fair | X | 5292 (100%) | 1000 mg | 3.75 (3.75, 6.2) | GBR | CVD, Cancer | Older adults age ≥70 years with a fragility fracture | Mean age: 77; % Female: 85; % White: 99; % Black: NR; Mean BMI: NR; % Curr. smoker: 12 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Baron, 2005 (CPPS)^85^; Fair | X | 930 (89.5%) | 1200 mg | 4 (4, 6, 10.3) | USA | Other: Colorectal adenoma prevention | Adults age <80 years with ≥1 histologically confirmed large-bowel adenoma removed in past 3 months | Mean age: 61; % Female: 28; % White: NR; % Black: 5; Mean BMI: NR; % Curr. smoker: NR | NR | X | X | ACM: NR; Ca: Full; CVD: NA
Baron, 2015 (VCPPS)^91^; Good | | 2259 (93.4%) | 1200 mg | 3.8 (3, 3.8) | USA | Other: Colorectal adenoma prevention | Age 45-75 years with recently diagnosed adenomas | Mean age: 58; % Female: 37; % White: 88; % Black: 8; Mean BMI: 29.0; % Curr. smoker: 10 | NR | X | X | ACM: NR; Ca: Full; CVD: Full
Bolland, 2008 (ACS)^82^; Fair | X | 1471 (100%) | 1000 mg | 5 (5) | NZL | Other: Bone density and fracture incidence | Postmenopausal women age >55 years | Mean age: 75; % Female: 100; % White: NR; % Black: NR; Mean BMI: 26.4; % Curr. smoker: 3 | 2.31 mmol/L | X | X | ACM: Full; Ca: NA; CVD: Full
Fedirko, 2009^114^; Fair | | 92 (92.4%) | 2000 mg | 0.5 (0.5) | USA | Other: Markers of apoptosis in colorectal mucosa | Adults aged 30-75 years with a history of colon or rectal adenoma | Mean age: 61; % Female: 30; % White: 71; % Black: NR; Mean BMI: 30.1; % Curr. smoker: 3 | NR | | X | ACM: NA; Ca: NA; CVD: NA
Lappe, 2007^83^; Fair | X | 1180 (86.8%) | 1500 mg | 4 (4) | USA | Cancer, Other: Skeletal status and calcium economy | Women age >55 years | Mean age: 67; % Female: 100; % White: 100; % Black: 0; Mean BMI: 29.0; % Curr. smoker: NR | 2.33 mmol/L | X | X | ACM: NA; Ca: Full; CVD: NA
Lewis, 2011 (CAIFOS)^105^; Good | | 1460 (84.1%) | 1200 mg | 5 (5, 9.5) | AUS | Other: Fractures | Women age >70 years | Mean age: 75; % Female: 100; % White: NR; % Black: NR; Mean BMI: 27.2; % Curr. smoker: NR | NR | X | X | ACM: Full; Ca: NA; CVD: Full
Reid, 2008^106^; Fair | | 323 (96.6%) | IG1: 1200 mg; IG2: 600 mg | 2 (2) | NZL | Other: Bone density | Men age ≥40 years | Mean age: 56; % Female: 0; % White: NR; % Black: NR; Mean BMI: 26.6; % Curr. smoker: 27 | NR | X | X | ACM: NR; Ca: NA; CVD: Self-report
Cohort
Feskanich, 2002 (NHS-I)^146^; Fair | X | 121700 (Varies) | Varied | NR (12, 18, 20.9) | USA | Other: Hip fractures, kidney stones, cataracts | Postmenopausal registered nurses age 30-55 years | Mean age: 58; % Female: 100; % White: NR; % Black: NR; Mean BMI: 26.0; % Curr. smoker: 26 | NR | | X | ACM: NA; Ca: NA; CVD: NA

* Includes participants randomized to all intervention groups, including for supplements other than multivitamins.

Abbreviations: ACM = All-cause mortality; ACS = Auckland calcium study; BL = Baseline; BMI = Body mass index; Ca = Cancer; CAIFOS = Calcium Intake Fracture Outcome Study; CPPS = Calcium Polyp Prevention Study; CVD = Cardiovascular disease; Curr. = Current; FUP = Followup; mg = Milligrams; mmol/L = Millimoles per liter; NA = Not applicable; NHS – I = Nurses’ Health Study; NR = Not reported; RECORD = Randomized Evaluation of Calcium OR vitamin D; RCT = Randomized controlled trial; VCPPS = Vitamin D/Calcium Polyp Prevention Study; WHI = Women’s Health Initiative.

Seven RCTs reported KQ3 outcomes (n=11,884) and KQ4 outcomes were reported in eight RCTs (n=11,930) and one cohort study (n=121,700). Most of the included evidence indicated that calcium had no benefit for mortality, CVD, or cancer (Figure 9, Appendix E Figures 17, 18, and 19). Pooled effects uniformly indicated no group differences (Appendix F Table 44), and very few individual study findings demonstrated an effect of calcium supplementation on cancer, CVD, or mortality. For example, pooled estimates for all-cause mortality (OR, 1.05 [95% CI, 0.92 to 1.21]; 6 RCTs [n=8,394]; I^2^=0%), CVD events (OR, 1.11 [95% CI, 0.90 to 1.36]; 4 RCTs, n=4,076, I^2^= 0%), and any incidence of cancer (OR, 0.94 [95% CI, 0.41 to 2.14, 3 RCTs, n=5,051, I^2^=49.2%) all showed no association with calcium use. RCTs supported an increased risk of GI effects, but no clear increase in risk of fractures. The cohort study of women only suggested an increased risk of kidney stones, but most effects exploring various dose levels were not statistically significant. Evidence was too sparse to draw conclusions about other adverse events.

Figure 9 Meta-Analysis or Best Evidence Summary for Calcium (Without Vitamin D)^*^ * I-squared values shown for analyses using the MH model are taken from sensitivity analyses using random effects models; the MH model is based on a fixed effect model where calculation of I-squared is not applicable because it is assumed to be 0. If data were insufficient for meta-analysis, findings from the largest and most comprehensive study reporting the outcome are presented.

Abbreviations: CG = Control group; CI = Confidence interval; CPPS = Calcium Polyp Prevention Study; CVD = Cardiovascular disease; IG = Intervention group; MI = Myocardial infarction; NA = Not applicable; OR = Odds ratio; RECORD = Randomized Evaluation of Calcium OR vitamin D; REML-KH = Restricted Maximum Likelihood model with the Knapp-Hartung adjustment.

This figure is a forest plot showing meta-analysis or best evidence summary for calcium (without vitamin D)

#### Detailed Study Characteristics

Eight RCTs^82,^ ^83,^ ^85,^ ^89,^ ^91,^ ^105,^ ^106,^ ^114^ of calcium use were included (n=12,961 randomized, excluding participants randomized to take other supplements), examining nine active intervention groups (Table 16). In addition, we included one large cohort study (n= 121,700) that examined the risk of kidney stones,^146^ for a total of 134,707 participants across all studies. Two studies had broad cancer prevention aims,^83,^ ^89^ two aimed to prevent colorectal adenoma recurrence among patients with a recent adenoma,^85,^ ^91^ and two aimed to prevent CVD.^89,^ ^106^ Four^91,^ ^105,^ ^106,^ ^114^ of these trials were newly identified and not included in the previous review, and none of these newly included had a specific cancer or CVD prevention aim. One trial was only included for harms.^114^

Three trials were rated good quality^89,^ ^91,^ ^105^ and the remaining were rated fair quality. The best evidence came from a good-quality trial that including almost half of the included participants (n=5,292), the RECORD trial.^89^ RECORD had primary aims of cancer and CVD prevention, but was limited to older adults (age 70 years or older) with a fragility fracture. RECORD was included in the previous review. RECORD was a factorial trial that crossed 1000 mg/day calcium use with 800 IU/day of vitamin D. They reported both the calcium vs. no calcium contrast and provided data to calculate the effects of calcium alone compared with placebo. We included results comparing calcium (alone) with placebo in the meta-analyses.

Doses ranged from 600 to 2000 mg/day, and the most common doses were 1000 and 1200 mg/day. Duration of use ranged from six months to five years. Five of the studies were conducted in the US^83,^ ^85,^ ^91,^ ^114,^ ^146^ and the others were conducted in the UK, New Zealand, and Australia. Across all studies, the mean ages ranged from the late 50s to the late 70s, mean BMIs were generally in the overweight range, and the samples were predominantly of White race and women. Four studies were limited to women^82,^ ^83,^ ^105,^ ^146^ and one smaller trial was limited to men;^106^ 85 percent of the participants in RECORD^89^ were women. The smoking rate ranged from 3 to 27 percent of participants, and was highest in the study limited to men.^106^

#### Detailed Results by Outcome

Seven RCTs reported KQ3 outcomes (n=11,884) and KQ4 outcomes were reported in eight RCTs (n=11,930) and one cohort study (n=121,700). See Appendix F Table 45 for a summary of findings for each trial and Appendix F Table 44 for a listing of results from all pooled analyses. Comprehensive and detailed study-level results are available in Appendix F Tables 46, 47, 48, and 49.

##### All-Cause Mortality (KQ3)

All-cause mortality was reported in six trials.^82,^ ^85,^ ^89,^ ^91,^ ^105,^ ^106^ None of the trials found group differences in all-cause mortality and the pooled effect did not demonstrate a benefit (OR, 1.05 [95% CI, 0.92 to 1.21]; 6 RCTs [n=8,394]; I^2^=0%, Figure 9, Appendix E Figure 17). In RECORD, 34.1 percent of participants taking calcium (without vitamin D) and 32.6 percent of participants taking a placebo had died after a median of 6.2 years, after using calcium for a median of. 3.75 years.^89^ Pooled estimates were similar across pooling methods (Appendix F Table 44). None of the studies reported on effect modification for cancer by age, gender, race, or ethnicity.

##### Cardiovascular Outcomes (KQ3)

CVD outcomes were reported in five trials.^82,^ ^85,^ ^89,^ ^105,^ ^106^ Almost no CVD outcome showed a statistically significant difference at any timepoint, and none of the pooled effects indicated an association between calcium use and CVD events or CVD mortality (Figure 9, Appendix E Figure 18, Appendix F Table 44). For example, the pooled OR for CVD events was 1.11 (95% CI, 0.90 to 1.36, 4 RCTs, n=4,076, I^2^= 0%). In RECORD, 14.8 percent of participants taking calcium and 13.7 percent of those taking a placebo had died from CVD after 6.2 years (OR, 1.10 [95% CI, 0.88 to 1.37]). RECORD reported no group differences in CVD events (HR, 0.92 [95% CI, 0.80 to 1.08]), MI (HR, 0.97 [95% CI, 0.75 to 1.26]), or stroke (HR, 1.06 [95% CI, 0.85 to 1.32], Appendix F Table 47). RECORD did, however, find a reduction in congestive heart failure with calcium use (HR, 0.75 [95% CI, 0.58 to 0.97]; 102 events/2649 persons taking calcium vs. 136 events/2643 person taking placebo). The only other statistically significant finding was an increase in CVD events in postmenopausal women with 1000 mg/day of calcium for 5 years in one trial (IRR, 1.43 [95% CI, 1.01 to 2.04]; 23.3 events/1000 person-years with calcium use vs. 16.3 events/1000 person-years; n=1,471).^82^ None of the studies reported on effect modification for cancer by age, gender, race, or ethnicity for CVD.

##### Cancer (KQ3)

Cancer outcomes were reported by four trials (Appendix E Figure 19).^83,^ ^85,^ ^89,^ ^91^ The meta-analysis showed no association between calcium use and the composite outcome of any incidence of cancer (OR, 0.94 [95% CI, 0.41 to 2.14, 3 RCTs, n=5,051, I^2^=49.2%; Figure 9, Appendix F Table 44). Statistical heterogeneity was fairly high, limiting our confidence on the pooled result, given the small number of studies pooled. RECORD found no group differences in incidence of or mortality from lung, colorectal, breast, prostate, or any type of cancer combined. For example, RECORD reported 12.4 percent in the calcium group and 11.4 percent in the placebo group developed new cancer cases (OR, 1.10 [95% CI, 0.87 to 1.39]) over 6.2 years.^89^ The only cancer-related finding that was statistically significant was a reduction in prostate cancer at one of three followup timepoints in the smaller trial of adenoma recurrence prevention (RR, 0.52 [95% CI, 0.28 to 0.98]; 4.3% taking calcium vs. 8.3% taking placebo after 6 years, Figure 9, Appendix F Table 47).^85^ None of the studies reported on effect modification for cancer by age, gender, race, or ethnicity for cancer.

##### Adverse Events (KQ4)

The included studies that reported on the occurrence of any adverse events,^114^ any serious adverse events,^83^ and withdrawals due to adverse events^85,^ ^106^ identified very few events and found no group differences. Constipation and gastrointestinal symptoms were generally increased with calcium use, but findings were only statistically significant in three studies, both indicating higher risk with calcium use.^82,^ ^89,^ ^105^ Evidence from five trials suggested no increased risk of fractures.^82,^ ^89,^ ^91,^ ^105,^ ^106^ The cohort study, NHS-I, reported an increased incidence of kidney stones for any calcium use compared with no calcium use, but no dose-response trend was identified.^146^ Evidence on kidney stones from the trials was inconclusive due to the small numbers of events. See Appendix F Table 49 for detailed results. None of the studies reported on effect modification for cancer by age, gender, race, or ethnicity for adverse events.

### Selenium

#### Summary of Results

Five RCTs^78,^ ^80,^ ^90,^ ^98,^ ^99^ (n= 29,909) of selenium use by adults primarily aged 50 years and older were included (Table 17). All studies had an explicit cancer or colorectal adenoma prevention aim. The most common dose was 200 mcg/day. Duration of use ranged from 6 months to 5.5 years, and followup time ranged from 6 months to 15.9 years. Most evidence derived from a single large study of males only (Selenium and Vitamin E Cancer Prevention Trial [SELECT]^80^, n=25,984), which also had the longest duration of selenium use at a median of 5.5 years.^80^ Two of the trials were newly identified and not included in the previous review,^98,^ ^99^ but SELECT^80^ was included in the previous review.

Table 17 Table of Study, Intervention, and Population Characteristics for Studies of Selenium Use, Sorted by Author (KQ3 and KQ4)

Author, Year (Study); Quality | In previous | Study N^*^ (% FUP) | Daily dose | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ3 | KQ4 | Ascertainment
RCT
Clark, 1996 (NPC)^78^; Fair | X | 1312 (100%) | 200 mcg | 4.4 (6.3, 7.4, 7.6) | USA | Cancer | Adults with a history of 2 or more past-year basal cell or squamous cell carcinomas of the skin | Mean age: 63; % Female: 25; % White: NR; % Black: NR; Mean BMI: 25.6; % Curr. smoker: 28 | Se: 1.45 mcmol/L | X | X | ACM: Full; Ca: Full; CVD: NA
Lippman, 2009 (SELECT)^80^; Good | X | 34888 (92.1%) | IG1: 200 mcg; IG2: 200 mcg + 400 IU Vitamin E | 5.5 (7.1) | USA, CAN | CVD, Cancer | African American men age ≥50 years and men of other races age ≥55 years | Mean age: 63; % Female: 0; % White: 79; % Black: 13; Mean BMI: NR; % Curr. smoker: 8 | NR | X | X | ACM: Full; Ca: Full; CVD: Full
Rayman, 2012 (UK-PRECISE)^90^; Fair | X | 501 (93.2%) | IG1: 300 mcg; IG2: 100 mcg; IG3: 200 mcg | 0.5 (0.5) | GBR | Cancer | Adults, aged 60-74 years | Mean age: 68; % Female: 47; % White: NR; % Black: NR; Mean BMI: 27.5; % Curr. smoker: 10 | Se: 1.12 mcmol/L | | X | ACM: NA; Ca: NA; CVD: NA
Rayman, 2018 (DK-PRECISE)^98^; Fair | | 491 (78.0%) | IG1: 300 mcg; IG2: 100 mcg; IG3: 200 mcg | 5 (5, 15.9) | DNK | Cancer | Age 60 to 74 years | Mean age: 66; % Female: 48; % White: NR; % Black: NR; Mean BMI: 26.8; % Curr. smoker: 30 | Se: 1.1 mcmol/L | X | X | ACM: Full; Ca: Full; CVD: NA
Thompson, 2016 (Sel/Cel)^99^; Fair | | 1621 (84.8%) | 200 mcg | 2.8 (3) | USA | Other: Colorectal adenoma | Adults aged 40-80 years with a recent colorectal adenoma | Mean age: 63; % Female: 35; % White: 94; % Black: 3; Mean BMI: 29.2; % Curr. smoker: 10 | Se: 1.72 mcmol/L | X | X | ACM: NR; Ca: NR; CVD: NA

* Includes participants randomized to all intervention groups, including for supplements other than selenium.

Abbreviations: ACM = All-cause mortality; BL = Baseline; BMI = Body mass index; Ca = Cancer; CVD = Cardiovascular disease; Curr. = Current; DK-PRECISE = Denmark PREvention of Cancer by Intervention with Selenium; FUP = Followup; IU = International units; mcg = Microgram; mcmol/L = Micromoles per liter; NPC = Nutritional Prevention of Cancer; Se = Selenium; Sel/Cel = Selenium and Celecoxib; SELECT = Selenium and Vitamin E Cancer Prevention Trial; UK-PRECISE = United Kingdom PREvention of Cancer by Intervention with Selenium.

Four RCTs reported KQ3 outcomes (n=29,408) and KQ4 outcomes were reported in all five RCTs (n=29,909). Most of the included evidence indicated that selenium had no benefit for mortality, CVD, or cancer outcomes (Figure 10, Appendix E Figures 20, 21, and 22), and no clear increased risk of serious harm. For outcomes with sufficient evidence for pooling, no association was found between use of 200 mg daily of selenium and all-cause mortality (OR, 0.94 [95% CI, 0.83 to 1.07]; 4 RCTs [n=20,832]; I^2^=4.7%) or CVD mortality (OR, 0.93 [95% CI, 0.75 to 1.14]; 3 RCTs [n=19,008]; I^2^=0%). The SELECT trial demonstrated no benefit of 200 mcg/day of selenium for a median of 5.5 years on all-cause mortality, cancer incidence or mortality, and cardiovascular events or mortality at up to 7.1 year followup, with or without concomitant use of 400 IU/day of vitamin E.^80^ These results were generally supported by the other trials, with the exception of one smaller trial^78^ (n=1312) among persons with a history of basal or squamous cell carcinoma. This trial found benefits for a number of non-skin cancer outcomes at up to 7.4 years’ followup. The included studies found no increased risk of serious harm at doses at or below 200 mg/day, and withdrawals due to adverse events did not differ between subgroups defined by dose level.

Figure 10 Meta-Analysis or Best Evidence Summary for Selenium^*^ * I-squared values shown for analyses using the MH model are taken from sensitivity analyses using random effects models; the MH model is based on a fixed effect model where calculation of I-squared is not applicable because it is assumed to be 0. If data were insufficient for meta-analysis, findings from the largest and most comprehensive study reporting the outcome are presented.

Abbreviations: CG = Control group; CI = Confidence interval; CVD = Cardiovascular disease; IG = Intervention group; MH = Mantel-Haenszel common (fixed) effects model; MI = Myocardial infarction; NPC = Nutritional Prevention of Cancer; OR = Odds ratio; Peto = Peto odds ratio; SELECT = Selenium and Vitamin E Cancer Prevention Trial.

This figure is a forest plot showing meta-analysis or best evidence summary for selenium

#### Detailed Study Characteristics

Five RCTs^78,^ ^80,^ ^90,^ ^98,^ ^99^ of selenium use were included (n= 29,909 randomized, excluding participants randomized to take other supplements), examining ten active intervention groups (Table 17). Two of these trials were newly identified and not included in the previous review.^98,^ ^99^ One trial was only included for harms.^90^ The largest trial, SELECT, was conducted exclusively in men, was rated good quality, and included most of the observations in this body of literature (n=25,984, excluding the vitamin E-only group).^80^ The remaining trials were fair quality.

All studies had an explicit cancer^78,^ ^80,^ ^90,^ ^98^ or colorectal adenoma^99^ prevention aim, and two were limited to patients with an increased risk of cancer due to a personal history of basal or squamous cell carcinoma (Nutritional Prevention of Cancer Study [NPC])^78^ or a colorectal adenoma in the previous 6 months (Selenium and Celecoxib Trial [Sel/Cel]).^99^ The largest study^80^ also had CVD prevention as a study aim. All of these trials described full ascertainment of our main review outcomes except the Sel/Cel trial,^99^ which nevertheless had very similar effect sizes to the SELECT trial.

The most common dose was 200 mcg/day and ranged from 100 to 300 mcg daily. The SELECT trial examined selenium with and without 400 IU/day of vitamin E.^80^ Duration of use ranged from 6 months^90^ to a median of 5.5^80^ years. Three of the trials were conducted in the U.S.^78,^ ^99^ or the U.S. and Canada,^80^ and the others were conducted in Great Britain^90^ and Denmark.^98^ Across all studies, the mean ages were in the 60s, mean BMIs were in the overweight range, and the samples were predominantly of White race. The smoking rate was high in two of the smaller studies, at 28.2 percent^78^ and 29.7 percent.^98^ Among the four studies reporting baseline serum selenium levels, the range was from 86.5 to 135.3 ng/mL, values that are all considered normal (above 70 ng/mL).^160^

#### Detailed Results by Outcome

Four RCTs reported KQ3 outcomes (n=29,408) and KQ4 outcomes were reported in all five RCTs (n=29,909). See Appendix F Table 50 for a summary of findings for each trial and Appendix F Table 51 for a listing of results from all pooled analyses. Comprehensive and detailed study-level results are available in Appendix F Tables 52, 53, 54, and 55.

##### All-Cause Mortality (KQ3)

All-cause mortality was reported in four trials.^78,^ ^80,^ ^98,^ ^99^ The pooled effect did not demonstrate a benefit (OR, 0.94 [95% CI, 0.83 to 1.07]; 4 RCTs [n=20,832]; I^2^=4.7%, Figure 10, Appendix E Figure 20). The SELECT trial of men only had effects ranging from HR, 0.94 (95% CI, 0.77 to 1.13) to 0.99 (95% CI, 0.82 to 1.19) on a daily dose of 200 mcg, covering both intervention groups (with or without 400 IU of vitamin E) and followup assessments at 5.5 and 7.1 years.^80^ For example, at 7.1 years of followup, 6.3 percent had died in the selenium group (without vitamin E) compared to 6.5 percent among those taking the placebo (HR, 0.98 [95% CI, 0.84 to 1.14]). Effects were wide-ranging in the smaller trials, falling in the direction of both benefit and harm. The only statistically significant finding was an increased risk of all-cause mortality at 15 years of followup after 5 years of 300 mcg daily (HR, 1.59 [95% CI, 1.02 to 2.46]; 39.5% in the selenium group vs. 27.8% in the placebo group); the effect size was similar but not statistically significant at the 5-year followup.^98^ This study found that the harmful effect was limited to participants younger than 65 years when they began the study (HR, 3.12 [95% CI, 1.51 to 6.44]; HR, 0.93 [95% CI, 0.53 to 1.63] in those ≥ 65 years, interaction p=0.04). No other studies reported on effect modification for all-cause mortality by age, gender, race, or ethnicity.

##### Cardiovascular Outcomes (KQ3)

CVD outcomes were reported in three trials.^78,^ ^80,^ ^98^ Effect sizes for CVD mortality were wide ranging, reflecting the relatively few events in many cases, and no effects were statistically significant. The pooled estimate indicated no association between 200 mg/day selenium use and CVD mortality (OR, 0.93 [95% CI, 0.75 to 1.14]; 3 RCTs; n=19,008; I^2^=0%, Figure 10, Appendix E Figure 21). Two studies reported on CVD events;^78,^ ^80^ across all timepoints and intervention groups, effect sizes for the composite outcome of any CVD events ranged from HR, 0.97 (95% CI, 0.86 to 1.09) to 1.04 (95% CI, 0.73 to 1.49). Results were similar but more wide ranging for MI and stroke, and no effects for any CVD event outcome were statistically significant. No studies reported on effect modification by age, gender, race, or ethnicity for CVD. Two trials found that the effect of vitamin D on CVD events was similar across baseline serum selenium level.^78,^ ^90^

##### Cancer (KQ3)

Cancer outcomes were reported by four studies.^78,^ ^80,^ ^98,^ ^99^ Cancer mortality was reduced only in the trial limited to those with a history of basal or squamous cell carcinoma (n=1312).^78^ This trial reported reductions in overall cancer mortality (HR, 0.48 [95% CI, 0.31 to 0.76]; 4.4% in the selenium group vs. 8.6% in the placebo group) and lung cancer deaths (HR, 0.47 [95% CI, 0.23 to 0.93]; 1.8% in the selenium group vs. 3.8% in the placebo group) at a median 6.3 years’ followup after taking 200 mcg/day for a median of 4.4 years. This is despite having no impact on the incidence of recurrent basal or squamous cell carcinoma. Effects were wide-ranging and none were statistically significant in the other trials. In the largest trial, 1.5 percent taking selenium and 1.4 percent taking placebo died from cancer (HR, 1.02 [95% CI, 0.74 to 1.41]) after 5.5 years, with a similar effect size among those also taking vitamin E.^80^ The pooled OR for cancer mortality was 0.86 ([95% CI, 0.69 to 1.06]; 3 RCTs; n=19,008; I^2^=71.6%; Figure 10, Appendix E Figure 22), however the high degree of statistical heterogeneity and the small number of pooled trials limits our confidence in these results (Appendix F Table 51). The wide range of effect sizes could be related to variable underlying risk, and one study had very few events (a total of 4 cancer deaths after 5 years), which limited the reliability of their findings.^98^

Similar to cancer mortality, cancer incidence was reduced only in the trial of persons with a history of basal or squamous cell carcinoma (n=1312).^78^ In this study, reductions were seen at 7.4 years of followup in the incidence of: any cancer (HR, 0.75 [95% CI, 0.58 to 0.97]; 16.9% vs 21.8%), colorectal cancer, lung cancer, prostate cancer, and any carcinoma, but not breast, esophageal, head and neck, leukemia, melanoma, or urinary bladder cancer. Although an interaction test did not indicate a differential effect by gender, subgroup analyses suggested a benefit for men (HR, 0.67 [95% CI, 0.50 to 0.89]; n=932) but not women (HR, 1.20 [95% CI, 0.66 to 2.20]; n=318) for the composite outcome of any cancer incidence. The other studies did not find reductions in cancer, including no reduction in colorectal cancer among persons with a recent colorectal adenoma (n=1824), after 3 years followup and taking 200 mcg daily for an average of 2.8 years, with very few events (OR, 1.26 [95% CI, 0.34 to 4.70]; selenium: 0.5% vs placebo: 0.4%).^99^ In the largest trial, 9.6 percent taking selenium and 9.5 percent taking placebo had developed cancer of any kind (HR, 1.01 [95% CI, 0.89 to 1.15])^80^ Pooled effect size for colorectal cancer, reported in three studies,^78,^ ^80,^ ^99^ was limited due to the relatively high statistical heterogeneity and the small number of studies (OR, 0.82 [95% CI, 0.44 to 1.51]; 3 RCTs; n=20,584; I^2^=53.8%). Effect modification was not reported in any studies by age, race, or ethnicity.

##### Adverse Events (KQ4)

The included studies found no increased risk of serious harm at 200 mg/day of selenium use. Two small trials reported zero serious adverse effects at doses of 100 to 300 mg/day^90^ or no group differences in serious adverse events.^99^ Statistically significant paradoxical findings on mortality, cancer, and cardiovascular disease events were rare despite the large number of outcomes reported, often across multiple doses and followup timepoints. However, the smallest trial (n=491)^98^ found a higher likelihood of all-cause mortality with 300 mg selenium use daily, at 15.9 years of followup (39.5% among selenium users and 27.8% in the placebo group, HR, 1.59 [95% CI, 1.02 to 2.46]). The effect size was similar at the 5-year followup but with only 20 deaths altogether, group differences were not statistically significant (10.1% among selenium users and 6.3% in the placebo group, HR, 1.62 [95% CI, 0.66 to 3.96]). The only other adverse event that differed between groups in any trial was dermatitis in the SELECT trial, only when delivered without vitamin E (6.9% among those taking selenium vs. 5.9% with placebo, RR, 1.17 [95% CI, 1.0 to 1.35]; study-reported p<0.01).^80^ SELECT did not report on serious adverse events or withdrawals due to adverse events; the study reported no group differences in alopecia, halitosis, fatigue, and nausea.^80^ Two^78,^ ^98^ studies suggested higher numbers of withdrawals due to adverse effects with selenium, but group differences were not statistically significant and a third trial^90^ reported similar rates between groups with very few withdrawals related to adverse effects. One study reported interaction between selenium use and gender by serious adverse effects (p=0.39) or brittle or hard nails (p=0.78).^99^

### Zinc

#### Study Characteristics and Results

We found no studies examining all-cause mortality, CVD, or cancer for zinc supplementation. Two small fair-quality RCTs met the inclusion criteria for harms of supplementation (n=203)^138,^ ^145^ (Table 18). One study evaluated whether the use of a commercially available zinc acetate lozenge shortens the duration of the common cold.^138^ This study included adults aged 18 years and older (median, 49 years) who self-reported that they usually had 1 or more colds each winter. Ninety percent were women. Participants were randomized to 78 mg/day of elemental zinc or placebo upon the onset of cold symptoms, for at most 5 days The other study was a randomized crossover trial evaluating whether zinc could reduce tinnitus in adults 60 years or older with tinnitus for 6 or more months.^145^ About one third (38%) of participants were women and the mean age was 68 years. Participants were randomized to 220 mg zinc sulfate daily (50 mg of elemental zinc) or placebo for 4 months and were then crossed over to the other treatment after a 30-day washout. See Appendix F Table 56 for a summary of findings for the included studies.

Table 18 Table of Study, Intervention, and Population Characteristics for Studies of Zinc Use, Sorted by Author (KQ3 and KQ4)

Author, Year (Study); Quality | In previous | Study N (% FUP) | Daily dose | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ3 | KQ4 | Ascertainment
RCT
Coehlo, 2013^145^; Fair | | 116 (76.7) | 220 mg (50 mg elemental zinc) | 0.34 | US | Other: Tinnitus reduction | Adults, aged 60 years and older, with tinnitus | Mean age: 68; % Female: 38; Percent white: NR; Mean BMI:; % Curr. smoker: NR | NR | | X | ACM: NA; Ca: NA; CVD: NA
Hemila, 2020^138^; Fair | | 87 (100) | 78 mg | 0.03 (10 days) | FIN | Other: Treatment of common cold | Adults aged 18 and older with a self-report that they usually have had ≥1 colds per winter | Mean age: 47; % Female: 89.7; % White: NR; % Black: NR; Mean BMI: NR; % Curr. smoker: NR | NR | | X | ACM: NA; Ca: NA; CVD: NA

Abbreviations: ACM = All-cause mortality; BL = Baseline; BMI = Body mass index; Ca = Cancer; CVD = Cardiovascular disease; Curr. = Current; FUP = Followup; mg = Milligram; NA = Not applicable; NR = Not reported.

##### All-Center Mortality, CVD, Cancer (KQ3)

No evidence was included.

##### Adverse Events (KQ4)

In the study evaluating zinc for the common cold, zinc acetate (78 mg/day) was associated with an increased risk of having any adverse events, including stomachache, taste alteration, teeth and mouth roughness or dryness, and aching in the mouth, compared to placebo, OR, 3.81 (95% CI, 1.57 to 9.24).^138^ The study also reported that 1 participant in the zinc group (2.2%) and no participants in the placebo group withdrew due to adverse events, OR, 2.8 (95% CI, 0.11 to 70.68).^138^ In the study evaluating zinc for tinnitus (220 mg/d zinc sulfate corresponding to 50 mg of elemental zinc), there were no serious adverse events in any participant.^145^ One participant discontinued while on zinc due to indigestion and 2 participants discontinued while on placebo, 1 because of constipation and 1 due to a metallic taste. A listing of all adverse events is available in Appendix F Table 56.

### Magnesium

#### Study Characteristics and Results

We found no studies examining all-cause mortality, CVD, or cancer for magnesium. Only two small fair-quality RCT met the inclusion criteria for harms of supplementation (n=110)^137,^ ^144^ (Table 19). One study tested the effects of oral magnesium supplementation on supraventricular arrhythmias.^137^ The study included adults aged 55 years and older randomized to either an oral magnesium supplement (400 mg/day) or matching placebo for 12 weeks. The other study tested the effects of magnesium on glucocorticoid metabolism.^144^ The study included adults 45 to 70 years with BMI between 25 and 35 kg/m^2^ and randomized participants to magnesium (350 mg/day) or placebo for 24 weeks. See Appendix F Table 57 for a summary of findings for the included studies.

Table 19 Table of Study, Intervention, and Population Characteristics for Studies of Magnesium Use, Sorted by Author (KQ3 and KQ4)

Author, Year (Study); Quality | In previous | Study N (% FUP) | Daily dose | Years used (FUP) | Country | Study aim (CVD, Cancer, Other) | Brief population description | Demographics | Mean BL serum level | KQ3 | KQ4 | Ascertainment
RCT
Alonso, 2020^137^; Fair | | 59 (88.1) | 400 mg | 0.19 (0.19) | USA | Other: Atrial fibrillation | Adults, aged 55 years and older | Mean age: 62; % Female: 73.1; % White: 94.2; % Black: NR; Mean BMI: 28.1; % Curr. smoker: NR | NR | | X | ACM: NA; Ca: NA; CVD: NA
Schutten, 2021^144^; Fair | | 51 (96.1) | 350 mg | 0.46 | NLD | Other: Glucocorticoid metabolism | Adults, aged 45-70 years with BMI between 25 and 35 kg/m^2^ | Mean age: 62; % Female: 45; Percent white: NR; Mean BMI: 29; % Curr. smoker: NR | NR | | X | ACM: NA; Ca: NA; CVD: NA

Abbreviations: ACM = All-cause mortality; BL = Baseline; BMI = Body mass index; Ca = Cancer; CVD = Cardiovascular disease; Curr. = Current; FUP = Followup; mg = Milligram; NA = Not applicable; NR = Not reported.

##### All-Center Mortality, CVD, Cancer (KQ3)

No evidence was included.

##### Adverse Events (KQ4)

In the study testing the effects of magnesium on arrhythmias, magnesium (400 mg/day) was associated with an increased risk of gastrointestinal symptoms, OR, 15.00 (95% CI, 3.00 to 4.96) compared to placebo.^137^ The study also reported that 1 participant in the magnesium group (3.4%) and no participants in the placebo group withdrew due to adverse events, OR, 3.21 (95% CI, 0.13 to 82.07).^137^ In the study testing the effects of magnesium on glucocorticoid metabolism, there were no serious adverse events in any participant and 1 participant reported mild headache and gastrointestinal symptoms.^144^ A listing of all relevant results reported in this study is available in Appendix F Table 57.