# Chapter 2 Methods

## Scope and Purpose

This review is an update of the systematic review^53^ that supported the 2014 USPSTF recommendations on vitamin supplementation to prevent cancer and CVD.^1^ The approach for the current review was very similar to the previous review with 3 main differences: the current review addressed harms for all supplements (rather than selected supplements), included secondary prevention trials in persons with a history of adenomas or non-melanoma skin cancers, and included trials of supplements designed to prevent diseases other than CVD or cancer that reported all-cause mortality or adverse events.

## Analytic Framework and Key Questions

With input from the USPSTF, we developed an Analytic Framework (Figure 1) and four Key Questions (KQs) to guide the literature search and selection of studies, data abstraction, and evidence synthesis.

Figure 1 Analytic Framework

Figure 1 is an analytic framework that depicts four Key Questions to be addressed in the systematic review. The figure illustrates how multivitamin supplementation may reduce cardiovascular disease, cancer, and mortality in the general adult population (community-dwelling adults aged 18 years and older without known nutritional deficiencies) (Key Question 1), and whether multivitamin supplementation may result in any harms in the general adult population (Key Question 2). Additionally, the figure addresses the efficacy of multivitamin/mineral supplementation or single nutrients or functionally related pairs for reducing cardiovascular disease, cancer, and mortality in the general population (Key Question 3), and if multivitamin/mineral supplementation or single nutrients or functionally related pairs for reducing cardiovascular disease, cancer, and mortality in the general population may result in any harms (Key Question 4).

### KQs

1. What is the efficacy of multivitamin supplementation for reducing cardiovascular disease, cancer, and mortality in the general adult population?
2. What are the harms of multivitamin supplementation in the general adult population?
3. What is the efficacy of supplementation with single nutrients or functionally related nutrient pairs for reducing cardiovascular disease, cancer, and mortality in the general adult population?
4. What are the harms of supplementation with single nutrients in the general adult population?

## Data Sources and Searches

We conducted a search to identify literature published since the previous review for the USPSTF covering January 1, 2013 through February 1, 2022. We worked with a research librarian to develop our search strategy, which included the following databases: MEDLINE, PubMed (publisher-supplied records only), the Cochrane Central Register of Controlled Trials (CENTRAL), the Cochrane Database of Systematic Reviews, and Embase (Appendix A).

Additionally, we evaluated all previously included studies from the prior review for the USPSTF and reviewed reference lists of other systematic reviews for inclusion in the current review.^54–61^ We also reviewed table-of-contents alerts such as those produced by the USPSTF Scientific Resource Center LitWatch activity to identify additional studies not identified in our literature searches. We also searched ClinicalTrials.gov and WHO International Clinical Trials Registry Platform (ICTRP), for relevant ongoing trials. We managed all literature search results using EndNote^TM^ version 7.3.1 (Thomson Reuters, New York, NY).

## Study Selection

Detailed inclusion and exclusion criteria were developed to guide study selection (Appendix A Table 1). One investigator independently prescreened titles and abstracts of a subset of studies with electronically identified keywords pertaining to an excluded setting, population, or condition in the title, abstract, or keyword fields of EndNote (Appendix A Table 2). Abstracts deemed potentially relevant during single review were advanced for dual review. Of the 14,180 total citations screened, 5,929 were prescreened by a single reviewer based on keywords highly probable for exclusion in the title or abstract; of these, six were identified as potentially relevant and moved forward for dual review, along with the 8,251 assigned to dual review from the beginning. Two investigators independently reviewed 351 full-text articles. We used DistillerSR (Evidence Partners, Ottawa, Canada) to conduct abstract and full-text review.

### Population and Setting

For all KQs, we excluded studies limited to adults with known chronic disease, including but not limited to CVD, type 2 diabetes, cancer, or known nutritional or vitamin deficiencies. We excluded studies in which more than 50 percent of participants had vitamin deficiency, or a mean serum level in the deficient range across all participants. Consistent with the previous review, populations with risk factors for CVD or cancer, such as those with high blood pressure, smokers, or previous removal of colorectal adenoma were eligible for inclusion. Populations with a history of non-melanoma skin cancer were considered for non-skin cancer outcomes. We only included studies that were conducted in countries classified as “very high” on the 2017 Human Development Index to avoid the possibility of higher prevalence of nutritional deficiencies in other countries.^62^

### Intervention and Comparator

For KQs 1 and 2, we included studies evaluating supplementation with multivitamins/minerals, defined as three or more vitamins, minerals, or combinations of both without extensive added herbs, hormones, or drugs. For KQs 3 and 4, we included studies evaluating supplementation with single nutrients and functionally-related pairs (i.e., calcium; folic acid; vitamins B1, B2, B6, B12, D, E, C, and A; iron; zinc; magnesium; niacin; calcium/vitamin D; calcium/magnesium; folic acid/vitamin B12; selenium; beta-carotene; beta-carotene/vitamin A, and folic acid/vitamin B6). We only included studies that tested supplements at doses lower than their tolerable upper intake level, with the exception of three studies: two that included higher than recommended levels of vitamin A^63,^ ^64^ and one that included higher doses of vitamin D.^65^ These were included for consistency with the previous review. The decision to focus on supplementation at or below the upper limit reflects a focus on preventive vitamin and mineral supplementation, as opposed to therapeutic supplementation. Appendix A Table 3 lists the recommended dietary allowance (RDA) and upper intake levels for the micronutrients we included in the review. We excluded supplementation with other types of dietary supplements (e.g., herbal supplements, omega-3 fatty acids, amino acids, enzymes, proprietary products, fiber, garlic, or turmeric), vitamin-derived agents with dermatologic indication (i.e., tretinoin, isotretinoin) and interventions to increase dietary (rather than supplemental) intake of nutrients.

### Outcomes

For KQs 1 and 3, outcomes of interest were cancer (any cancer or site-specific), CVD incidence (including coronary heart, peripheral artery, and cerebrovascular disease), CVD events (myocardial infarction and ischemic and hemorrhagic stroke), heart failure, or mortality (all-cause, CVD–related, or cancer-related). A minimum of 1 year of followup was required for all-cause mortality, but other outcomes had no minimum followup requirement. For KQs 2 and 4, outcomes of interest were paradoxical effects on CVD, cancer, and mortality outcomes, serious adverse events (as defined by the study, or those likely requiring medical attention, such as kidney stones, sarcoidosis, and hip fracture), withdrawals due to adverse events, and nonserious adverse events (based on self-report or objective measurements and reported by at least 5% of the study sample taking the supplement). Studies that reported on a serious harm but no cancer, CVD, or mortality outcomes were included in this review.

Precancerous lesions (e.g., cervical intraepithelial neoplasia) and intermediate cardiovascular risk measure (blood pressure, lipid levels, glucose levels) were not systematically reviewed. These outcomes are addressed contextually in the Appendix D.

### Study Design

For KQs 1 and 3, only randomized controlled trials were included. Eligible comparator groups could be allocated to placebo, no intervention, or usual diet. For KQs 2 and 4, we additionally allowed large (n ≥1,000) comparative observational studies (cohort or case-control) or post-market surveillance data for outcomes of serious harm. However, we did not include cohort studies reporting on KQ1 and KQ3 outcomes; only randomized controlled trials were considered for studies showing paradoxical harmful effects on mortality, cancer, and CVD.

## Quality Assessment and Data Abstraction

Two reviewers independently rated the studies’ methodological quality using USPSTF design-specific criteria (Appendix A Table 4).^47^ Studies were rated as “good,” “fair,” or “poor,” and discrepancies between raters were resolved by discussion or consultation with the larger review team. Good-quality studies were those that met nearly all of the specified quality criteria (e.g., comparable groups were assembled initially and maintained throughout the study and followup was approximately 90% or higher), whereas fair-quality studies did not meet these criteria but did not have serious threats to their internal validity related to their design, execution, or reporting. Poor-quality studies had several important limitations, including at least one of the following risks of bias: very high attrition (generally >40%), differential attrition between intervention arms (generally >20%); substantial lack of baseline comparability between groups without adjustment; or issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting, inappropriate exclusion of participants from analyses, questionable validity of randomization and allocation concealment procedures, or data for relevant outcomes not collected systematically). Studies rated as “poor” quality were excluded from the review. For trials that had been included in the previous review on this topic, we did not repeat critical appraisal of the original studies. However, we did downgrade cohort studies that had been previously rated as “good” to “fair.” We felt that reliance on self-reported supplement use to determine the impact of supplement use along with the non-randomized nature of the studies qualified as “fair” quality data, even if methods were good otherwise. Cohort studies are only included for harms (KQs 2 and 4).

For all of the included studies, one reviewer extracted key data into standardized abstraction forms in DistillerSR (Evidence Partners, Ottawa, Canada). A second reviewer checked the data for accuracy. For each study, we abstracted general characteristics (e.g., author, year, study design), clinical and demographic characteristics of the sample and setting (e.g., age, race/ethnicity, CVD and cancer risk factors, vitamin use, serum vitamin levels, setting, country), intervention details (e.g., supplement, dose, duration of use), and results (see Outcomes section).

We did not abstract unexpected or paradoxical negative findings for studies with primary aims other than CVD or cancer. We did this because studies reporting paradoxical findings for their main outcome are a skewed subset of the evidence for that outcome. For example, there is a large, separate body of literature on vitamin and mineral supplementation to prevent fractures.^66^ In our review, fractures were not abstracted as a benefit or harm from studies with the primary aim of evaluating supplements for fractures. Selective inclusion of fracture outcomes only when findings demonstrated a harm would result in a small, unrepresentative subset of studies being included here. Inclusion of all studies of supplement use to prevent fractures is beyond the scope of this review, since most did not report mortality, CVD, or cancer. Other relevant outcomes that were reported (i.e., mortality, CVD, cancer, other harms) were abstracted from studies designed for fracture prevention. Fractures were abstracted from studies with other aims when reported as harms.

For multifactorial trials with additional randomization to other (non-vitamin or mineral) agents or placebo, we abstracted results for combined groups that compared all participants who received the relevant intervention with all those who did not, ignoring the assignments to the other intervention in the two groups.

During abstraction we noted whether cancer, CVD, or all-cause mortality outcomes had full outcome ascertainment, defined as comprehensive use of a study exam, medical records (with or without independent adjudication), or a health plan database for full capture of the outcome. Outcomes that were taken from participant flow reporting (e.g., CONSORT diagrams) or self-reported in response to open-ended querying of adverse events were not considered to have full outcome ascertainment. Outcome ascertainment status was subsequently used in sensitivity analyses, described further below.

## Data Synthesis and Analysis

We created summary tables for all KQs showing study, population, intervention characteristics, and outcomes for qualitative synthesis of the evidence. Analyses were stratified by supplement where multivitamins were addressed in KQs 1 and 2 and single nutrients or functionally related nutrient pairs were addressed in KQs 3 and 4. With regard to our use of terms to describe populations defined by sex or gender, none of the included studies explicitly distinguished between sex and gender, but most referred to “sex” when exploring subpopulations, presumably on the assumption that differences in effects may be related to biologically defined sex (e.g., due to differing impact of hormones or other biochemical differences). Despite this, we assume that sex/gender was collected through participant self-report and thus reflects the participants’ gender. Therefore, we use the nouns gender, man, and woman rather than sex, male, and female when referring to participant characteristics.

We conducted quantitative pooling where at least three studies of the same supplement reported the same outcome. We assessed the presence of statistical heterogeneity among the studies using the I^2^ statistic. We de-emphasized pooled results when there were few studies and concerning levels of statistical heterogeneity (e.g., I^2^ more than approximately 30% when combining very few studies, or more than approximately 70% when 10 or more studies were combined). We selected a single effect per study to include in each meta-analysis, preferentially selecting the timepoint corresponding with the end of supplement use and the intervention arm most consistent with the related studies in terms of dose and comparison group (preferring a straightforward comparison of the substance vs. a placebo, rather than a factorial approach comparing use vs. non-use of the supplement). Results for other followup times and groups are available in appendix tables, and in the results we note the rare cases where longer followup findings differed substantially from the end-of-intervention findings.

For pooling, most outcomes occurred in less than 10 percent of the study sample, so we used methods appropriate for rare events. Consistent with AHRQ’s EPC program guidance,^67^ when events typically occurred in less than 3 to 4 percent of the sample, study groups were balanced, and effects were in the range of OR=0.2 to 5.0, we used the Peto Odds ratios with a Restricted Maximum Likelihood (REML) model. When events typically occurred in 5 to 10 percent of the sample, we used a fixed effects Mantel-Haenszel model as the primary analysis. When events were typically more common, we pooled standard ORs using a REML model, adding the Knapp-Hartung correction for pooling a small number of studies.^68,^ ^69^ Because event rates were usually wide-ranging, we generally performed at least two analyses and report one or more as sensitivity analyses. In tables of pooled results, we list results using multiple approaches; the first effect listed for each outcome is the one judged most appropriate by the study team, and others are considered sensitivity analyses. However, if we judged the most appropriate analysis to be the fixed effects Mantel-Haenszel model, in the text and summary figures we provide I^2^ values from the parallel random effects model. We did this in order to provide a sense for statistical heterogeneity in the studies, since fixed effects models assume no statistical heterogeneity and do not calculate I^2^.

In some included studies, all cause-mortality, CVD events, and cancer outcomes were only identified through participant flow diagrams or adverse events reporting, or ascertainment was not described, rather than reporting attempts to fully capture these outcomes through means such as medical record review or death certificates. This was typically the cases when the aim of the study was not related to CVD or cancer. For outcomes with a substantial number of such studies that did not report full ascertainment methods, we conducted sensitivity analyses restricted to studies with full outcome ascertainment for these outcomes. We defined full ascertainment as an attempt to identify these outcomes for all participants with followup assessment, such as through medical records or similar databases or direct examination. Additionally, for vitamin D, which had the largest body of literature, we conducted stratified analyses to explore whether the effect size was associated with the presence of calcium in combination with vitamin D and whether they used large bolus dosing vs. daily or weekly doses. We also conducted meta-regressions to examine the association of dose and effect size, and whether the effect sizes were similar for the previously included and newly added studies. For other supplements, data were generally insufficient to statistically test the impact of dose, however study-level forest plots are sorted by dose, to allow visual inspection of the impact on dose. We detected no pattern of association between dose and effect size for any supplement and do not comment further on dose as an effect modifier.

We used Stata 16.1 (StataCorp LLC, College Station, TX). All significance testing was 2-sided, and results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each key question. We adapted the Evidence-based Practice Center approach,^70^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^71^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth domain—directness—as it is implied in the structure of the key questions (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

The domain of consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). The domain of precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Study quality reflects the quality ratings of the individual trials and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body-of-evidence limitations field highlights important restrictions in answering the overall key question (e.g., evidence of reporting bias, lack of replication of interventions, nonreporting of outcomes important to patients).

At least two independent reviewers rated the overall strength of evidence for each intervention type. We resolved discrepancies through consensus discussion with the full review team, consulting with outside reviewers as needed. We graded the overall strength of evidence as high, moderate, low, or insufficient. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit an estimate of an effect.

## Expert Review and Public Comment

The draft Research Plan was posted from May 23, 2019 to June 19, 2019. Comments addressed the inclusion of outcomes and suggestions to examine the influence of patient, supplement, and study characteristics on effect size. Additional specificity was added regarding cancer outcomes and clarifying text was added to note that populations with obesity are included. Metabolic syndrome, atrial fibrillation, and renal disease were added as outcomes that would be reviewed contextually. Comments regarding characteristics that might influence effect sizes were incorporated in our analysis plan. The draft version of this report was reviewed by five invited experts and 3 individuals at USPSTF Federal Partner agencies. Experts were selected based on their expertise with both methodologic and content aspects of the review and were selected to obtain diverse informed perspectives. All expert comments were considered, and the report was updated to improve clarity, ensure accuracy, and address scientifically relevant concerns. Additionally, a draft version of this report was posted for public comment on the USPSTF Web site from May 4, 2021 to June 1, 2021. All comments were reviewed and considered for inclusion. Text was updated or clarified in the introduction section, but no changes were made to the results or overall conclusions. All comments were shared with members of the USPSTF and the Agency for Healthcare Research and Quality (AHRQ).

## USPSTF and AHRQ Involvement

We consulted with USPSTF liaisons at key points in the review process to develop and refine the analytic framework and key questions and to resolve issues around scope for the final evidence synthesis. An AHRQ Medical Officer provided project oversight, reviewed the draft and final versions of the review, and assisted with public comment on the research plan and draft review. The USPSTF and AHRQ had no role in the study selection, quality assessment, or writing of the systematic review.