# Appendix G Ongoing Studies

Trial | Trial number | Location | N | Duration (years) | Intervention | Relevant endpoints | Estimated completion date
Finnish Vitamin D Trial (FIND) | NCT01463813 | Finland | 2,495 | 5 | Vitamin D (1600 or 3200 IU/day) | Cancer, CVD | Publication late 2020 or early 2021
D-Health | ACTRN12613000743763 | Australia | 21,315 | 5 | Vitamin D (60,000 IU/month) | Mortality, cancer | 2024

Abbreviations: CVD = Cardiovascular disease; IU = International units; US = United States.