# Appendix F Detailed Results Tables

Appendix F Table 1 Summary of Results for Studies of Multivitamin Use^*^

Author, Year (Study) | Quality Rating | Study Design | Study N^*^ | Multivitamin Type (No. of specific micronutrients) | ACM | CVD | Cancer | Harms
Avenell, 2005 (MAVIS)^107^ | Fair | RCT | 910 | Broad (16) | ? | NR | NR | ↔ Any AE
Baeksgaard, 1998^125^ | Fair | RCT | 240 | Broad (13) | ? | NR | NR | GI sx: ?
Bonelli, 2013 (NA)^96^ | Fair | RCT | 411 | Antioxidant (4) | ? | NR | ? | NR
Chylack, 2002 (REACT)^86^ | Fair | RCT | 297 | Antioxidant (3) | ? | ↔ | NR | Any, serious, non-serious: ?
CTNS Study Group, 2008 (CTNS)^134^ | Good | RCT | 1020 | Broad (26) | ↔ | ? | NR | Any, GI-related, urogenital hospitalization: ↔; Hospitalization: ↓?; Skin rash: ?
Hercberg, 2004 (SUVIMAX)^72^ | Good | RCT | 13,017 | Antioxidant (5) | ↓? | ↔ | ↔ | AE WD: ?
Pike, 1995^123^ | Fair | RCT | 47 | Broad (16) | ? | NR | ? | GI, skin rash: ?
Rucklidge, 2014^101^ | Fair | RCT | 80 | Broad (36) | NR | NR | NR | GI, AE WD, sarcoidosis, other non-serious: ?
Sesso, 2008 (PHS-II)^81^ | Good | RCT | 14,641 | Broad (31) | ↓? | ↔ | Any: ↓?; Prostate: ↔; Lung, CRC: ↔? | Skin rash, nose bleed: ↑; Easy bruising, hematuria: ↔
Sesso, 2022 (COSMOS)^152^ | Good | RCT | 21,442 | Broad (29) | ↓? | ↔ | Any, breast: ↔; Lung, prostate: ↓?; CRC: ↔? | skin rash, nose bleed, other skin, bruising, GI-related, many other non-serious: ↔
Feskanich, 2002 (NHS-I)^146^ | Good | Cohort | 12,1700 | Unknown/Variable | NA | NA | NA | Cataract: ↔; Hip fracture: ↑
Rautiainen, 2010 (SMC)^151^ | Fair | Cohort | 38,984 | Unknown/Variable | NA | NA | NA | Cataract: ↔?
Zheng Selin, 2013 (COSM)^148^ | Fair | Cohort | 27,343 | Unknown/Variable | NA | NA | NA | Cataract: ↔

* Includes only participants randomized to an intervention group assigned to take a multivitamin.

Abbreviations: ACM = All-cause mortality; AE = Adverse event; CI = Confidence interval; COSM = Cohort of Swedish Men; CRC = Colorectal cancer; CTNS = Clinical Trial of Nutritional Supplements and Age-Related Cataract; CVD = Cardiovascular disease; GI = Gastrointestinal; MAVIS = Mineral and Vitamin Intervention Trial; NA = Not applicable; NHS-I = Nurse’ Health Study; NR = Not reported; PHS-II = Physicians’ Health Study; RCT = Randomized controlled trial; REACT = Roche European American Cataract Trial; SMC = Swedish Mammography Cohort; SUVIMAX = The Supplémentation en Vitamines et Minéraux Antioxydants; WD = Withdrawal.

↑ Likely non-trivial increase in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

↑? Possible non-trivial increase in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↔ Evidence of no to minimal group differences (e.g., few to no statistically significant findings with reasonably precise estimates [e.g., >~20 events in all treatment arms])

↔? Limited evidence of no to minimal group differences (e.g., few to no statistically significant findings, but imprecise estimates/side CIs).

↓? Possible non-trivial decrease in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↓ Likely non-trivial decrease in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

? Insufficient evidence to evaluate (e.g., very few [e.g., <10] events).

Judgement for symbols based on totality of evidence for each study, considering statistical and clinical significance.

Appendix F Table 2 Multivitamin Meta-Analysis Results: Results of Meta-Analyses by Outcome, Primary Analysis Listed First for Each Outcome, Followed by Sensitivity Analyses

Outcome | Model | Pooled OR (95% CI) | No. studies | N analyzed | I^2^, % | Tau^2^
All-cause mortality | REML-KH | 0.94 (0.87 to 1.01) | 9 | 51,550 | 0.0 | 0.00
All-cause mortality | MH | 0.94 (0.87 to 1.00) | 9 | 51,550 | NA | NA
All-cause mortality | Full ascert. (REML-KH) | 0.93 (0.87 to 1.00) | 5 | 49,879 | 0 | 0
CVD mortality | MH | 0.94 (0.83 to 1.06) | 4 | 37,400 | NA | NA
CVD mortality | REML-KH | 0.94 (0.81 to 1.09) | 4 | 37,400 | 0 | 0
CVD mortality | Full ascert. (MH) | 0.95 (0.84 to 1.08) | 2 | 36,083 | NA | NA
MI | MH | 0.96 (0.84 to 1.11) | 2 | 36,083 | NA | NA
MI | REML-KH | 0.96 (0.60 to 1.55) | 2 | 36,083 | 0 | 0
Stroke | MH | 1.06 (0.93 to 1.22) | 2 | 36,083 | NA | NA
Stroke | REML-KH | 1.06 (0.92 to 1.24) | 2 | 36,083 | 0 | 0
Cancer mortality | MH | 0.93 (0.83 to 1.05) | 4 | 37,400 | NA | NA
Cancer mortality | REML-KH | 0.94 (0.81 to 1.09) | 4 | 37,400 | 28.9 | 0.01
Cancer incidence | REML-KH | 0.93 (0.87 to 0.99) | 4 | 48,859 | 0.01 | 0.0
Cancer incidence | MH | 0.93 (0.87 to 0.99) | 4 | 48,859 | NA | NA
Colorectal cancer | MH | 0.98 (0.77 to 1.24) | 2 | 35,961 | NA | NA
Colorectal cancer | REML-KH | 1.02 (0.10 to 10.81) | 2 | 35,961 | 46.1 | 0.03
Lung cancer | MH | 0.75 (0.58 to 0.95) | 2 | 36,052 | NA | NA
Lung cancer | REML-KH | 0.74 (0.11 to 4.99) | 2 | 36,052 | 30.0 | 0.01
Breast cancer | MH | 1.01 (0.82 to 1.24) | 2 | 29,155 | NA | NA
Breast cancer | REML-KH | 1.01 (0.49 to 2.07) | 2 | 29,155 | 0 | 0
Prostate cancer | MH | 0.96 (0.87 to 1.06) | 3 | 40,456 | NA | NA
Prostate cancer | REML-KH | 0.95 (0.77 to 1.18) | 3 | 40,456 | 9.8 | 0.0

Abbreviations: CI = Confidence interval; CVD = Cardiovascular disease; MH = Mantel-Haenszel common (fixed) effects model; MI = myocardial infarction; NA = Not applicable because fixed effects model assumes Tau^2^=0; OR = Odds ratio; Peto = Peto odds ratio; random effects REML model; REML-KH = random effects restricted maximum likelihood model with the Knapp-Hartung adjustment.

Appendix F Table 3 Multivitamin Mortality Results

Author, Year (Study) | Comparison | Antioxidant or Broad spectrum | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Avenell, 2005 (MAVIS)^107^ | Multivitamin vs. placebo | Broad | All-cause mortality | 1 | All | 2.01 (0.60 to 6.72) | 8/456 (1.8) | 4/454 (0.9) | 0.25
Baeksgaard, 1998^125^ | Vitamin D + calcium + multivitamin vs. placebo | Broad | All-cause mortality | 2 | All | 0.91 (0.06 to 14.91) | 1/70 (1.4) | 1/64 (1.6) | NR
Bonelli, 2013 (NA)^96^ | Multivitamin vs. placebo | Antiox. | All-cause mortality | 5 | All | 0.66 (0.23 to 1.91) | 6/164 (3.7) | 9/166 (5.4) | NR
Chylack, 2002 (REACT)^86^ | Multivitamin vs. placebo | Antiox. | All-cause mortality | 2.8 | All | 3.11 (0.82 to 11.71) | 9/149 (6.0) | 3/148 (2.0) | 0.07
CTNS Study Group, 2008 (CTNS)^134^ | Multivitamin vs. placebo | Broad | All-cause mortality | 13 | All | 0.94 (0.67 to 1.32) | 77/510 (15.1) | 81/510 (15.9) | NSD
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox. | All-cause mortality | 7.5 | All | RR=0.77 (0.57 to 1.00) | 76/6364 (1.2) | 98/6377 (1.5) | 0.09
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox. | All-cause mortality | 12.5 | All | RR=0.87 (0.70 to 1.04) | 156/6364 (2.5) | 178/6377 (2.8) | 0.19
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox. | All-cause mortality | 7.5 | Females | RR=1.03 (0.64 to 1.63) | 36/3844 (0.9) | 35/3869 (0.9) | 0.92
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox. | All-cause mortality | 12.5 | Females | RR=0.99 (0.71 to 1.38) | 70/3844 (1.8) | 70/3869 (1.8) | 0.95
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox. | All-cause mortality | 7.5 | Males | RR=0.63 (0.42 to 0.93) | 40/2520 (1.6) | 63/2508 (2.5) | 0.02
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox. | All-cause mortality | 12.5 | Males | RR=0.78 (0.59 to 1.04) | 86/2520 (3.4) | 108/2508 (4.3) | 0.09
Pike, 1995^123^ | Multivitamin vs. placebo | Broad | All-cause mortality | 1 | All | 3.36 (0.13 to 88.39) | 1/17 (5.9) | 0/18 (0.0) | NR
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | All-cause mortality | 11.2 | All | HR=0.94 (0.88 to 1.02) | 1345/7317 (18.4) | 1412/7324 (19.3) | 0.13
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | All-cause mortality | 3.6 | All | HR=0.93 (0.81 to 1.08) | 362/10720 (3.4) | 388/10722 (3.6) | NR
Chylack, 2002 (REACT)^86^ | Multivitamin vs. placebo | Antiox. | Any cancer deaths | 2.8 | All | 1.50 (0.25 to 9.11) | 3/149 (2.0) | 2/148 (1.4) | NR
CTNS Study Group, 2008 (CTNS)^134^ | Multivitamin vs. placebo | Broad | Any cancer deaths | 13 | All | 1.21 (0.77 to 1.90) | 44/510 (8.6) | 37/510 (7.3) | NSD
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | Any cancer deaths | 11.2 | All | HR=0.88 (0.77 to 1.01) | 403/7317 (5.5) | 456/7324 (6.2) | 0.07
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Any cancer deaths | 3.6 | All | HR=1.06 (0.82 to 1.38) | 116/10720 (1.1) | 109/10722 (1.0) | NR
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | Colorectal cancer deaths | 11.2 | All | HR=0.95 (0.60 to 1.48) | 37/7317 (0.5) | 39/7324 (0.5) | 0.81
Chylack, 2002 (REACT)^86^ | Multivitamin vs. placebo | Antiox. | CVD deaths | 2.8 | All | 2.00 (0.18 to 22.30) | 2/149 (1.3) | 1/148 (0.7) | NR
CTNS Study Group, 2008 (CTNS)^134^ | Multivitamin vs. placebo | Broad | CVD deaths | 13 | All | 0.73 (0.42 to 1.27) | 23/510 (4.5) | 31/510 (6.1) | NSD
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | CVD deaths | 11.2 | All | HR=0.95 (0.83 to 1.09) | 408/7317 (5.6) | 421/7324 (5.7) | 0.47
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | CVD deaths | 3.6 | All | HR=0.87 (0.65 to 1.17) | 84/10720 (0.8) | 96/10722 (0.9) | NR
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | Lung cancer deaths | 11.2 | All | HR=0.89 (0.64 to 1.25) | 65/7317 (0.9) | 73/7324 (1.0) | 0.50
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | Prostate cancer deaths | 11.2 | All | HR=0.91 (0.66 to 1.26) | 70/7317 (1.0) | 78/7324 (1.1) | 0.58

* Studies providing estimates other than ORs display effect type.

Abbreviations: CG = Control group; CTNS = Clinical Trial of Nutritional Supplements and Age-Related Cataract; CVD = Cardiovascular disease; HR = Hazard ratio; IG = Intervention group; MAVIS = Mineral and Vitamin Intervention Trial; mg = Milligram; NR = Not reported; NSD = No significant difference; OR = Odds ratio; PHS-II = Physicians’ Health Study; REACT = Roche European American Cataract Trial; RR = Risk ratio; SUVIMAX = The Supplémentation en Vitamines et Minéraux Antioxydants.

Appendix F Table 4 Multivitamin Cardiovascular Disease Results

Author, Year (Study) | Comparison | Antioxidant or Broad spectrum | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox. | CHD events | 7.5 | All | RR=0.97 (0.77 to 1.20) | 134/6481 (2.1) | 137/6356 (2.1) | 0.80
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox. | CHD events | 12.5 | All | RR=0.97 (0.80 to 1.17) | 222/5501 (4.0) | 224/5553 (4.0) | 0.73
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | CHD events | 7.5 | Females | RR=1.17 (0.67 to 2.05) | 27/3844 (0.7) | 23/3869 (0.6) | 0.57
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | CHD events | 12.5 | Females | RR=1.33 (0.87 to 2.04) | 50/3323 (1.5) | 37/3321 (1.1) | 0.19
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | CHD events | 7.5 | Males | RR=0.82 (0.71 to 1.20) | 107/2520 (4.2) | 114/2508 (4.6) | 0.54
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | CHD events | 12.5 | Males | RR=0.89 (0.72 to 1.09) | 172/2178 (7.9) | 187/2232 (8.4) | 0.25
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | CVD events | 11.2 | All | HR=1.01 (0.91 to 1.10) | 876 events/7317 | 856 events/7324 | 0.91
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | CVD events | 3.6 | All | HR=0.98 (0.86 to 1.12) | 429/10720 (4.0) | 437/10722 (4.1) | NR
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | MI | 11.2 | All | HR=0.93 (0.80 to 1.09) | 317/7317 (4.3) | 335/7324 (4.6) | 0.39
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | MI | 3.6 | All | HR=1.04 (0.78 to 1.38) | 96/10720 (0.9) | 93/10722 (0.9) | NR
CTNS Study Group, 2008 (CTNS)^134^ | Multivitamin vs. placebo | Broad | Other CVD | 13 | All | 0.89 (0.69 to 1.15) | 196/510 (38.4) | 210/510 (41.2) | NSD
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | Stroke | 11.2 | All | HR=1.06 (0.91 to 1.23) | 332/7317 (4.5) | 311/7324 (4.2) | 0.48
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Stroke | 3.6 | All | HR=1.04 (0.81 to 1.35) | 121/10720 (1.1) | 116/10722 (1.1) | NR
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Angina | 3.6 | All | HR=1.19 (0.79 to 1.79) | 50/10720 (0.5) | 42/10722 (0.4) | NR
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Carotid artery disease | 3.6 | All | HR=0.85 (0.49 to 1.47) | 24/10720 (0.2) | 28/10722 (0.3) | NR
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Coronary revascularization | 3.6 | All | HR=1.08 (0.88 to 1.34) | 177/10720 (1.7) | 164/10722 (1.5) | NR
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | CVD events + all cause death | 3.6 | All | HR=0.95 (0.86 to 1.06) | 680/10720 (6.3) | 716/10722 (6.7) | NR
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Major CVD event | 3.6 | All | HR=0.96 (0.82 to 1.14) | 274/10720 (2.6) | 285/10722 (2.7) | NR
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Major CVD event + CABG/PCI | 3.6 | All | HR=0.99 (0.86 to 1.14) | 381/10720 (3.6) | 384/10722 (3.6) | NR
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Peripheral artery disease | 3.6 | All | HR=0.79 (0.41 to 1.52) | 16/10720 (0.1) | 20/10722 (0.2) | NR

* Studies providing estimates other than ORs display effect type.

Abbreviations: CG = Control group; CHD =Coronary heart disease; CTNS = Clinical Trial of Nutritional Supplements and Age-Related Cataract; CVD = Cardiovascular disease; HR = Hazard ratio; IG = Intervention group; MI = Myocardial infarction; NR = Not reported; NSD = No significant difference; OR = Odds ratio; PHS-II = Physicians’ Health Study; RR = Risk ratio; SUVIMAX = The Supplémentation en Vitamines et Minéraux Antioxydants.

Appendix F Table 5 Multivitamin Cancer Results

Author, Year (Study) | Comparison | Antioxidant or Broad spectrum | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Any cancer incidence | 7.5 | All | RR=0.90 (0.76 to 1.06) | 267/6364 (4.2) | 295/6377 (4.6) | 0.19
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Any cancer incidence | 12.5 | All | RR=0.93 (0.82 to 1.05) | 490/5501 (8.9) | 511/5553 (9.2) | 0.27
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Any cancer incidence | 7.5 | Females | RR=1.04 (0.85 to 1.29) | 179/3844 (4.7) | 171/3869 (4.4) | 0.53
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Any cancer incidence | 12.5 | Females | RR=1.01 (0.86 to 1.19) | 283/3323 (8.5) | 276/3321 (8.3) | 0.91
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Any cancer incidence | 7.5 | Males | RR=0.69 (0.53 to 0.91) | 88/2520 (3.5) | 124/2508 (4.9) | 0.008
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Any cancer incidence | 12.5 | Males | RR=0.84 (0.69 to 1.01) | 207/2178 (9.5) | 235/2232 (10.5) | 0.06
Pike, 1995^123^ | Multivitamin vs. placebo | Broad | Any cancer incidence | 1 | All | 3.36 (0.13 to 88.39) | 1/17 (5.9) | 0/18 (0.0) | NR
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | Any cancer incidence | 11.2 | All | HR=0.92 (0.86 to 1.00) | 1290/7317 (17.6) | 1379/7324 (18.8) | 0.04
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Any cancer (invasive only) | 3.6 | All | HR=0.97 (0.86 to 1.09) | 518/10720 (4.8) | 535/10722 (5.0) | 0.57
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Breast cancer | 7.5 | Females | 0.96 (0.72 to 1.27) | 95/3844 (2.5) | 100/3869 (2.6)
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Breast cancer | 11.3 | Females | 0.88 (0.66 to 1.17) | 88/2317 (3.8) | 102/2367 (4.3) | NR
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Breast cancer | 3.6 | All | HR=1.06 (0.79 to 1.42) | 93/10720 (0.9) | 87/10722 (0.8) | NR
CTNS Study Group, 2008 (CTNS)^134^ | Multivitamin vs. placebo | Broad | Cancer-related hospitalization | 13 | All | 0.74 (0.46 to 1.17) | 34/510 (6.7) | 45/510 (8.8) | NSD
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | Colorectal cancer | 11.2 | All | HR=0.89 (0.68 to 1.17) | 99/7255 (1.4) | 111/7264 (1.5) | 0.39
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Colorectal cancer | 3.6 | All | HR=1.30 (0.80 to 2.12) | 38/10720 (0.4) | 29/10722 (0.3) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Digestive tract cancer | 7.5 | All | 0.83 (0.52 to 1.31) | 33/6364 (0.5) | 40/6377 (0.6) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Digestive tract cancer | 7.5 | Females | 1.01 (0.49 to 2.06) | 15/3844 (0.4) | 15/3869 (0.4) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Digestive tract cancer | 7.5 | Males | 0.71 (0.39 to 1.31) | 18/2520 (0.7) | 25/2508 (1.0) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Genital cancer | 7.5 | All | 0.89 (0.61 to 1.31) | 49/6364 (0.8) | 55/6377 (0.9) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Genital cancer | 7.5 | Females | 0.83 (0.45 to 1.53) | 19/3844 (0.5) | 23/3869 (0.6) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Genital cancer | 7.5 | Males | 0.93 (0.56 to 1.54) | 30/2520 (1.2) | 32/2508 (1.3) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Hematological cancer | 7.5 | All | 0.91 (0.49 to 1.69) | 19/6364 (0.3) | 21/6377 (0.3) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Hematological cancer | 7.5 | Females | 0.78 (0.29 to 2.10) | 7/3844 (0.2) | 9/3869 (0.2) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Hematological cancer | 7.5 | Males | 1.00 (0.45 to 2.22) | 12/2520 (0.5) | 12/2508 (0.5) | NR
Bonelli, 2013 (NA)^96^ | Multivitamin vs. placebo | Antiox | Laryngeal cancer | 5 | All | 3.06 (0.12 to 75.54) | 1/164 (0.6) | 0/166 (0.0) | NR
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | Lung cancer | 11.2 | All | HR=0.84 (0.61 to 1.14) | 74/7300 (1.0) | 88/7310 (1.2) | 0.26
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Lung cancer | 3.6 | All | HR=0.62 (0.42 to 0.92) | 41/10720 (0.4) | 66/10722 (0.6) | 0.015
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Melanoma skin cancer | 7.5 | All | 1.79 (0.79 to 4.06) | 16/6481 (0.2) | 9/6536 (0.1) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Melanoma skin cancer | 12.5 | All | 1.33 (0.73 to 2.41) | 25/6481 (0.4) | 19/6536 (0.3) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Melanoma skin cancer | 7.5 | Females | HR=4.31 (1.23 to 15.13) | 13/3912 (0.3) | 3/3964 (0.1) | 0.02
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Melanoma skin cancer | 12.5 | Females | 1.92 (0.85 to 4.31) | 17/3912 (0.4) | 9/3964 (0.2) | 0.11
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Melanoma skin cancer | 7.5 | Males | HR=0.49 (0.12 to 1.97) | 3/2569 (0.1) | 6/2572 (0.2) | 0.32
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Melanoma skin cancer | 12.5 | Males | 0.80 (0.32 to 2.03) | 8/2569 (0.3) | 10/2572 (0.4) | 0.64
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Melanoma skin cancer | 3.6 | All | HR=0.86 (0.54 to 1.35) | 34/10720 (0.3) | 40/10722 (0.4) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Oral cavity cancer | 7.5 | All | 0.50 (0.13 to 2.00) | 3/6364 (0.0) | 6/6377 (0.1) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Oral cavity cancer | 7.5 | Females | 5.04 (0.24 to 104.91) | 2/3844 (0.1) | 0/3869 (0.0) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Oral cavity cancer | 7.5 | Males | 0.17 (0.02 to 1.38) | 1/2520 (0.0) | 6/2508 (0.2) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Prostate cancer | 8.9 | Males | HR=0.88 (0.60 to 1.29) | 49/2522 (1.9) | 54/2512 (2.1) | 0.73
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Broad | Prostate cancer | 11.2 | All | HR=0.98 (0.88 to 1.09) | 683/6988 (9.8) | 690/6992 (9.9) | 0.76
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Broad | Prostate cancer | 3.6 | All | HR=0.82 (0.62 to 1.08) | 93/10720 (0.9) | 113/10722 (1.1) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Respiratory tract cancer | 7.5 | All | 0.47 (0.21 to 1.05) | 9/6364 (0.1) | 19/6377 (0.3) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Respiratory tract cancer | 7.5 | Females | 0.60 (0.14 to 2.53) | 3/3844 (0.1) | 5/3869 (0.1) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Respiratory tract cancer | 7.5 | Males | 0.43 (0.16 to 1.11) | 6/2520 (0.2) | 14/2508 (0.6) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Thyroid cancer | 7.5 | All | 1.37 (0.63 to 2.98) | 15/6364 (0.2) | 11/6377 (0.2) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Thyroid cancer | 7.5 | Females | 2.42 (0.85 to 6.88) | 12/3844 (0.3) | 5/3869 (0.1) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Thyroid cancer | 7.5 | Males | 0.50 (0.12 to 1.99) | 3/2520 (0.1) | 6/2508 (0.2) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Urinary tract cancer | 7.5 | All | 1.13 (0.43 to 2.92) | 9/6364 (0.1) | 8/6377 (0.1) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Urinary tract cancer | 7.5 | Females | 3.02 (0.31 to 29.06) | 3/3844 (0.1) | 1/3869 (0.0) | NR
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Antiox | Urinary tract cancer | 7.5 | Males | 0.85 (0.29 to 2.54) | 6/2520 (0.2) | 7/2508 (0.3) | NR
Bonelli, 2013 (NA)^96^ | Multivitamin vs. placebo | Antiox | Uterine cancer | 5 | All | 0.34 (0.01 to 8.29) | 0/164 (0.0) | 1/166 (0.6) | NR

* Studies providing estimates other than ORs display effect type.

Abbreviations: CG = Control group; CTNS = Clinical Trial of Nutritional Supplements and Age-Related Cataract; HR = Hazard ratio; IG = Intervention group; NR = Not reported; OR = Odds ratio; PHS-II = Physicians’ Health Study; RR = Risk ratio; SUVIMAX = The Supplémentation en Vitamines et Minéraux Antioxydants.

Appendix F Table 6 Multivitamin Adverse Events Results

Author, Year (Study) | Comparison | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%)
Rucklidge, 2014^101^ | Multivitamin vs. placebo | Abdominal pain | 0.15 | All | 0.51 (0.11 to 2.29) | 3/42 (7.1) | 5/38 (13.2)
Avenell, 2005 (MAVIS)^107^ | Multivitamin vs. placebo | Any AE | 1 | All | IRR=0.64 (0.22 to 1.93) | 28/456 (6.1) | 37/454 (8.1)
Chylack, 2002 (REACT)^86^ | Multivitamin vs. placebo | Any AE | 2.8 | All | | ./149 (.) | ./148 (.)
CTNS Study Group, 2008 (CTNS)^134^ | Multivitamin vs. placebo | Any AE | 13 | All | 0.80 (0.49 to 1.31) | 30/510 (5.9) | 37/510 (7.3)
Feskanich, 2002 (NHS-I)^146^ | Multivitamin 5-9 yrs use vs. no multivitamin | Cataract | 12 | All | RR=1.11 (0.92 to 1.35) | 206/100000 p-y | 181/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | Multivitamin <2 yrs use vs. no multivitamin | Cataract | 12 | All | RR=1.16 (0.94 to 1.43) | 214/100000 p-y | 181/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | Multivitamin 2-4 yrs use vs. no multivitamin | Cataract | 12 | All | RR=1.16 (0.92 to 1.46) | 218/100000 p-y | 181/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | Multivitamin ≥10 yrs use vs. no multivitamin | Cataract | 12 | All | RR=1.04 (0.86 to 1.25) | 197/100000 p-y | 181/100000 p-y
Rautiainen, 2010 (SMC)^151^ | Multivitamin vs. no supplement use | Cataract | 8.2 | All | HR=1.09 (0.94 to 1.25) | 252 events/2259 | 3/75524 p-y
Zheng Selin, 2013 (COSM)^148^ | Multivitamin vs. no multivitamin | Cataract | 8.4 | All | HR=0.96 (0.85 to 1.07) | 345/3532 (9.8) | 1937/22015 (8.8)
Rucklidge, 2014^101^ | Multivitamin vs. placebo | Constipation | 0.15 | All | 0.51 (0.15 to 1.71) | 5/42 (11.9) | 8/38 (21.1)
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Epistaxis | 11.2 | All | HR=1.10 (1.02 to 1.18) | 1579/7317 (21.6) | 1451/7324 (19.8)
CTNS Study Group, 2008 (CTNS)^134^ | Multivitamin vs. placebo | Gastrointestinal symptoms | 13 | All | 0.89 (0.46 to 1.73) | 17/510 (3.3) | 19/510 (3.7)
Pike, 1995^123^ | Multivitamin vs. placebo | Gastrointestinal symptoms | 1 | All | 3.36 (0.13 to 88.39) | 1/17 (5.9) | 0/18 (0.0)
Rucklidge, 2014^101^ | Multivitamin vs. placebo | Gastrointestinal symptoms | 0.15 | All | 1.44 (0.53 to 3.90) | 13/42 (31.0) | 9/38 (23.7)
CTNS Study Group, 2008 (CTNS)^134^ | Multivitamin vs. placebo | GI disease-related hospitalization | 13 | All | 0.97 (0.68 to 1.38) | 68/510 (13.3) | 70/510 (13.7)
Feskanich, 2002 (NHS-I)^146^ | Multivitamin current use vs. no multivitamin | Hip fracture | 18 | All | RR=1.32 (1.04 to 1.67) | 262/. (.) | 176/. (.)
Feskanich, 2002 (NHS-I)^146^ | Multivitamin <5 yrs use vs. no multivitamin | Hip fracture | 18 | All | RR=1.05 (0.74 to 1.49) | 39/. (.) | 176/. (.)
Feskanich, 2002 (NHS-I)^146^ | Multivitamin 5-9 yrs use vs. no multivitamin | Hip fracture | 18 | All | RR=1.25 (0.83 to 1.85) | 33/. (.) | 176/. (.)
Feskanich, 2002 (NHS-I)^146^ | Multivitamin 10-14 yrs use vs. no multivitamin | Hip fracture | 18 | All | RR=1.29 (0.81 to 2.05) | 24/. (.) | 176/. (.)
Feskanich, 2002 (NHS-I)^146^ | Multivitamin >=15 yrs use vs. no multivitamin | Hip fracture | 18 | All | RR=1.28 (0.86 to 1.91) | 42/. (.) | 176/. (.)
CTNS Study Group, 2008 (CTNS)^134^ | Multivitamin vs. placebo | Hospitalization (all-cause) | 13 | All | 0.78 (0.61 to 1.01) | 286/510 (56.1) | 316/510 (62.0)
Chylack, 2002 (REACT)^86^ | Multivitamin vs. placebo | Hypercarotenodermia | 2.8 | All | 13.45 (0.75 to 240.99) | 6/149 (4.0) | 0/148 (0.0)
Zheng Selin, 2013 (COSM)^148^ | Multivitamin vs. no multivitamin | Kidney stones | 11 | All | RR=0.86 (0.62 to 1.19) | ./. (.) | ./. (.)
Rucklidge, 2014^101^ | Multivitamin vs. placebo | Nausea | 0.15 | All | 1.50 (0.54 to 4.19) | 12/42 (28.6) | 8/38 (21.1)
Chylack, 2002 (REACT)^86^ | Multivitamin vs. placebo | Non-serious: Intercurrent illness (NS) | 2.8 | All | 1.94 (1.20 to 3.15) | 107/149 (71.8) | 84/148 (56.8)
Rucklidge, 2014^101^ | Multivitamin vs. placebo | Non-serious: Agitation (NS); anxiety (NS); dry mouth (NS); headache (NS); sedation (NS); sleep disruptions (NS) | 0.15 | All | | ./42 (.) | ./38 (.)
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Non-serious: Easy bruising (NS); hematuria (NS) | 11.2 | All | | ./7317 (.) | ./7324 (.)
Sesso, 2022 (COSMOS)^152^ | Multivitamin vs. placebo | Non-serious: Stomach upset or pain (IG<CG), nausea (NS), constipation (NS), diarrhea (IG<CG), skin rash (IG<CG; HR, 0.95 [0.90, 0.99]; annualized rates 10.8% in IG, 11.4 % in CG), skin discoloration (NS), fatigue or drowsiness (NS), dizziness (NS), flu-like symptoms (NS), frequent nosebleeds (NS; HR 0.97 [0.86, 1.10]; annualized rates 1.4% in IG vs 1.5% in CG), easy bruising (IG<CG), blood in urine (NS), GI bleeding (IG>CG), migraine (NS), other headaches (NS), lightheadedness (NS), unintentional fall (NS) | 3.6 | All | | ./10720 (.) | ./10722 (.)
Rucklidge, 2014^101^ | Multivitamin vs. placebo | Sarcoidosis | 0.15 | All | 2.78 (0.11 to 70.39) | 1/42 (2.4) | 0/38 (0.0)
Chylack, 2002 (REACT)^86^ | Multivitamin vs. placebo | Serious AEs | 2.8 | All | 0.99 (0.02 to 50.39) | 0/149 (0.0) | 0/148 (0.0)
CTNS Study Group, 2008 (CTNS)^134^ | Multivitamin vs. placebo | Skin rash | 13 | All | 1.25 (0.33 to 4.69) | 5/510 (1.0) | 4/510 (0.8)
Pike, 1995^123^ | Multivitamin vs. placebo | Skin rash | 1 | All | 3.36 (0.13 to 88.39) | 1/17 (5.9) | 0/18 (0.0)
Sesso, 2008 (PHS-II)^81^ | Multivitamin vs. no multivitamin | Skin rash | 11.2 | All | HR=1.07 (1.01 to 1.14) | 2125/7317 (29.0) | 2002/7324 (27.3)
CTNS Study Group, 2008 (CTNS)^134^ | Multivitamin vs. placebo | Urogenital hospitalizations | 13 | All | 1.07 (0.74 to 1.56) | 66/510 (12.9) | 62/510 (12.2)
Hercberg, 2004 (SUVIMAX)^72^ | Multivitamin vs. placebo | Withdrawals due to AEs | 8.9 | Males | 1.00 (0.02 to 50.22) | 0/2522 (0.0) | 0/2512 (0.0)
Rucklidge, 2014^101^ | Multivitamin vs. placebo | Withdrawals due to AEs | 0.15 | All | 2.78 (0.11 to 70.39) | 1/42 (2.4) | 0/38 (0.0)

* Studies providing estimates other than ORs display effect type.

Abbreviations: . = not reported; AE = Adverse event; CG = Control group; COSM = Cohort of Swedish Men; CTNS = Clinical Trial of Nutritional Supplements and Age-Related Cataract; GI = Gastrointestinal; HR = Hazard ratio; IG = Intervention group; MAVIS = Mineral and Vitamin Intervention Trial; NHS-I = Nurse’ Health Study; NR = Not reported; NS = Not significant; OR = Odds ratio; PHS-II = Physicians’ Health Study; REACT = Roche European American Cataract Trial; RR = Risk ratio; SMC = Swedish Mammography Cohort; SUVIMAX = The Supplémentation en Vitamines et Minéraux Antioxydants; yrs = Years.

Appendix F Table 7 Beta Carotene and Vitamin A Meta-Analysis Results: Results of Meta-Analyses by Outcome, Primary Analysis Listed First for Each Outcome, Followed by Sensitivity Analyses

Outcome | Model/Analysis | Pooled OR (95% CI) | No. studies | N analyzed | I^2^, % | Tau^2^
All-cause mortality (beta carotene with or without vitamin A) | MH | 1.06 (1.00 to 1.12) | 6 | 112,820 | NA | NA
All-cause mortality (beta carotene with or without vitamin A) | Peto | 1.06 (1.00 to 1.12) | 6 | 112,820 | 6.4 | 0.00
All-cause mortality (beta carotene with or without vitamin A) | Full ascert.(MH) | 1.06 (1.01 to 1.12) | 5 | 111,199 | NA | NA
All-cause mortality (beta carotene with or without vitamin A) | Beta-carotene without vitamin A (MH) | 1.06 (1.00 to 1.12) | 5 | 94,506 | NA | NA
All-cause mortality (beta carotene, vitamin A, or the combination) | MH | 1.06 (1.01 to 1.12) | 7 | 115,117 | NA | NA
CVD mortality | Peto | 1.10 (1.02 to 1.19) | 5 | 94,506 | 0.0 | 0.0
CVD mortality | MH | 1.10 (1.02 to 1.19) | 5 | 94,506 | NA | NA
CVD mortality | Full ascert. (Peto) | 1.11 (1.02 to 1.20) | 4 | 92,885 | NA | NA
Cancer mortality | Peto | 1.00 (0.87 to 1.14) | 4 | 65,373 | 0.0 | 0.0
Cancer mortality | MH | 1.00 (0.87 to 1.14) | 4 | 65,373 | NA | NA
Cancer mortality | Full ascert. (Peto) | 1.00 (0.87 to 1.14) | 4 | 65,373 | 0.0 | 0.0
Any cancer incidence | MH | 0.99 (0.92 to 1.07) | 2 | 61,947 | NA | NA
Any cancer incidence | Peto | 0.99 (0.92 to 1.07) | 2 | 61,947 | 0.02 | 0.0
Any cancer incidence | Full ascert. (MH) | 0.99 (0.92 to 1.07) | 2 | 61,947 | NA | NA
Colorectal cancer | Peto | 1.00 (0.85 to 1.16) | 4 | 109,394 | 0.0 | 0.0
Colorectal cancer | MH | 1.00 (0.85 to 1.16) | 4 | 109,394 | NA | NA
Colorectal cancer | Full ascert. (Peto) | 1.00 (0.85 to 1.16) | 4 | 109,394 | 0.0 | 0.0
Lung cancer | Peto | 1.20 (1.01 to 1.42) | 4 | 94,830 | 38.85 | 0.01
Lung cancer | MH | 1.21 (1.07 to 1.36) | 4 | 94,830 | NA | NA
Lung cancer | Full ascert. (Peto) | 1.20 (1.01 to 1.42) | 4 | 94,830 | 38.85 | 0.01
Lung cancer | Beta-carotene without vitamin A (MH) | 1.12 (0.96 to 1.31) | 3 | 76,516 | NA | NA
Breast cancer | Peto | 0.97 (0.80 to 1.16) | 2 | 46,165 | 0.0 | 0.0
Breast cancer | MH | 0.97 (0.81 to 1.16) | 2 | 46,165 | NA | NA
Breast cancer | Full ascert. (Peto) | 0.97 (0.80 to 1.16) | 2 | 46,165 | 0.0 | 0.0
Prostate cancer | Peto | 1.03 (0.92 to 1.14) | 3 | 48,665 | 0.0 | 0.0
Prostate cancer | MH | 1.03 (0.92 to 1.14) | 3 | 48,665 | NA | NA
Prostate cancer | Full ascert. (Peto) | 1.03 (0.92 to 1.14) | 3 | 48,665 | 0.0 | 0.0

Abbreviations: ascert. = ascertainment; CI = Confidence interval; CVD = Cardiovascular disease; NA = Not applicable; No. = Number; MH = Mantel-Haenszel common effects model; OR = Odds ratio; Peto = Peto odds ratio random effects REML model.

Appendix F Table 8 Summary of Results for Studies of Beta Carotene Use

Author, Year (Study) | Quality Rating | Study Design | Study N | Supplement (daily dose) | ACM | CVD | Cancer | Harms
ATBC Study Group, 1994 (ATBC)^76^ | Good | RCT | 29,133 | Beta-carotene (20 mg) | ? | | ↑ Lung; ↑? Prostate; ↔? Others
ATBC Study Group, 1994 (ATBC)^76^ | Good | RCT | 29,133 | Beta-carotene (20 mg) + Vitamin E (50 mg) | ↑ | ↑ | ↑ Lung; ↔ CRC; ↑? Prostate | ↑ Hypercarotenodermia; ↔ Hospitalizations for pneumonia
Feskanich, 2002 (NHS-I)^146^ | Fair | Cohort | 12,1700 | Beta-carotene (NR) | | | | ↔ Hip fracture
Green, 1999 (NSCPS)^73^ | Good | RCT | 1621 | Beta-carotene (30 mg) | ↓? | ↓? | ? Mortality; ↔ Skin | ↔ WD due to AE
Greenberg, 1990 (SCPS)^87^ | Good | RCT | 1805 | Beta-carotene (50 mg) | ↔ | ↑? | ↔ Lung; ↔ Mortality | ↑ WD due to AE; ↑ Hypercarotenodermia
Hennekens, 1996 (PHS-I)^75^ | Good | RCT | 22,071 | Beta-carotene (25 mg) | ↔ | ↔ | ↔ Lung; ↔ Mortality; ↔ Any incident; ↔CRC; ↔Prostate | ↑Hypercarotenodermia; ↑GI symptoms; ↔Serious AE
Lee, 2005 (WHS)^74^ | Good | RCT | 39,876 | Beta-carotene (25 mg) | ↔ | ↔ | ↑? Lung; ↔ Mortality; ↔ Any incident; ↔CRC; ↔Breast | ↑Hypercarotenodermia
Omenn, 1996 (CARET)^63^ | Good | RCT | 18,314 | Beta-carotene (30 mg) + Vitamin A (7500 RAE) | ↑? | ↑ | ↑ Lung; ↔CRC; ↔Breast; ↔Prostate | ↔ Any AE

Abbreviations: ACM = All-cause mortality; AE = Adverse event; ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CARET = The Beta-Carotene and Retinol Efficacy Trial; CRC = Colorectal cancer; CVD = Cardiovascular disease; GI = Gastrointestinal; NHS-I = Nurses’ Health Study I; NR = Not reported; NSCPS = Nambour Skin Cancer Prevention Study; PHS-I = Physicians’ Health Study-I; RCT = Randomized controlled trial; RAE = Retinol activity equivalents, SCPS = Skin Cancer Prevention Study; SKICAP = SKIn CAncer Prevention; WD = Withdrawal; WHS = Women’s Health Study.

↑ Likely non-trivial increase in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

↑? Possible non-trivial increase in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↔ Evidence of no to minimal group differences (e.g., few to no statistically significant findings with reasonably precise estimates [e.g., >~20 events in all treatment arms]).

↔? Limited evidence of no to minimal group differences (e.g., few to no statistically significant findings, but imprecise estimates/side CIs).

↓? Possible non-trivial decrease in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↓ Likely non-trivial decrease in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

? Insufficient evidence to evaluate (e.g., very few [e.g., <10] events).

Judgement for symbols based on totality of evidence for each study, considering statistical and clinical significance.

Appendix F Table 9 Summary of Results for Studies of Vitamin A Use

Study | Quality Rating | Study Design | Study N | Supplement (daily dose) | ACM | CVD | Cancer | Harms
Moon, 1997 (SKICAP)^64^ | Fair | RCT | 2297 | Vitamin A (7500 RAE) | ↔ | | ↓SCC; ↔BCC | ↑? Any AE
Omenn, 1996 (CARET)^63^ | Good | RCT | 18314 | Beta-carotene (30 mg) + Vitamin A (7500 RAE) | ↑? | ↑ | ↑ Lung; ↔CRC; ↔Breast; ↔Prostate | ↔ Any AE
Feskanich, 2002 (NHS-I)^146^ | Fair | Cohort | 121700 | Vitamin A (NR) | | | | ↔? Cataract; ↑? Hip fracture
Lim, 2004 (IWHS)^147^ | Fair | Cohort | 34703 | Vitamin A (NR) | | | | ↔ Fractures; ↑? Hip fracture

Abbreviations: ACM = All-cause mortality; AE = Adverse event; BCC = Basal cell carcinoma; CARET = The Beta-Carotene and Retinol Efficacy Trial; CVD = Cardiovascular disease; CRC = Colorectal cancer; IWHS = Iowa Women’s Health Study; NR = Not reported; NHS-I = Nurses’ Health Study I; RAE = retinol activity equivalents; SCC = squamous cell carcinoma; SKICAP = SKIn CAncer Prevention.

↑ Likely non-trivial increase in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

↑? Possible non-trivial increase in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↔ Evidence of no to minimal group differences (e.g., few to no statistically significant findings with reasonably precise estimates [e.g., >~20 events in all treatment arms])

↔? Limited evidence of no to minimal group differences (e.g., few to no statistically significant findings, but imprecise estimates/side CIs).

↓? Possible non-trivial decrease in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↓ Likely non-trivial decrease in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

? Insufficient evidence to evaluate (e.g., very few [e.g., <10] events).

Judgement for symbols based on totality of evidence for each study, considering statistical and clinical significance.

Appendix F Table 10 Beta Carotene Mortality Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | All-cause mortality | 24.1 | All | 1.02 (0.95 to 1.10) | 5052/7282 (69.4) | 5022/7287 (68.9) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | All-cause mortality | 6.1 | All | 1.09 (1.02 to 1.17) | 1851/14560 (12.7) | 1719/14573 (11.8) | 0.02
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | All-cause mortality | 11 | All | 1.11 (1.05 to 1.17) | 3129/14560 (21.5) | 2883/14573 (19.8) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | All-cause mortality | 14 | All | 1.10 (1.05 to 1.16) | 4584/14560 (31.5) | 4284/14573 (29.4) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | All-cause mortality | 16 | All | 1.09 (1.04 to 1.14) | 5555/14560 (38.2) | 5276/14573 (36.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | All-cause mortality | 24.1 | All | 1.07 (1.00 to 1.15) | 5117/7278 (70.3) | 5022/7287 (68.9) | NR
Green, 1999 (NSCPS)^73^ | Beta-carotene vs. placebo | 30 mg | All-cause mortality | 4.5 | All | RR=0.50 (0.24 to 1.03) | 11/820 (1.3) | 21/801 (2.6) | NR, NS
Greenberg, 1990 (SCPS)^87^ | Beta-carotene vs. placebo | 50 mg | All-cause mortality | 5 | All | IRR=1.08 (0.98 to 1.19) | 79/913 (8.7) | 72/892 (8.1) | NR, NS
Greenberg, 1990 (SCPS)^87^ | Beta-carotene vs. placebo | 50 mg | All-cause mortality | 8.2 | All | RR=1.03 (0.82 to 1.30) | 146/913 (16.0) | 139/892 (15.6) | 0.80
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | All-cause mortality | 12 | All | RR=1.02 (0.93 to 1.11) | 979/11036 (8.9) | 968/11035 (8.8) | 0.68
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | All-cause mortality | 4.1 | All | RR=1.07 (0.74 to 1.56) | 59/19937 (0.3) | 55/19939 (0.3) | 0.70
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | All-cause mortality | 3.7 | All | IRR=1.17 (1.03 to 1.33) | 56/9420 (0.6) | 41/8894 (0.5) | 0.02
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | All-cause mortality | 10 | All | 1.13 (1.04 to 1.23) | 1281/9420 (13.6) | 1088/8894 (12.2)
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | All-cause mortality | 3.7 | Asbestos-exposed (all male) | IRR=1.25 (1.01 to 1.56) | 17.76/1000 p-y | 14.3/1000 p-y | 0.04
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | All-cause mortality | 10 | Asbestos-exposed (all male) | RR=0.96 (0.81 to 1.13) | 283/1842 (15.4) | 293/1851 (15.8) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | All-cause mortality | 3.7 | Female heavy smokers | RR=1.16 (0.88 to 1.52) | ./3201 (.) | ./3081 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | All-cause mortality | 10 | Female heavy smokers | RR=1.37 (1.16 to 1.62) | 352/3044 (11.6) | 239/2965 (8.1) | <0.05
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | All-cause mortality | 3.7 | Heavy smokers | IRR=1.13 (0.96 to 1.32) | 13.26/1000 p-y | 10.91/1000 p-y | 0.14
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | All-cause mortality | 10 | Heavy smokers | RR=1.13 (1.02 to 1.24) | 942/6902 (13.6) | 754/6545 (11.5) | <0.05
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | All-cause mortality | 3.7 | Male heavy smokers | RR=1.10 (0.90 to 1.34) | ./4175 (.) | ./3797 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | All-cause mortality | 10 | Male heavy smokers | RR=1.00 (0.89 to 1.13) | 590/3858 (15.3) | 515/3580 (14.4) | NR, NS
Green, 1999 (NSCPS)^73^ | Beta-carotene vs. placebo | 30 mg | Any cancer deaths | 4.5 | All | 0.42 (0.11 to 1.62) | 3/820 (0.4) | 7/801 (0.9) | NR
Greenberg, 1990 (SCPS)^87^ | Beta-carotene vs. placebo | 50 mg | Any cancer deaths | 8.2 | All | RR=0.83 (0.54 to 1.29) | 38/913 (4.2) | 44/892 (4.9) | 0.41
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Any cancer deaths | 12 | All | RR=1.02 (0.89 to 1.18) | 386/11036 (3.5) | 380/11035 (3.4) | 0.76
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Any cancer deaths | 12.9 | All | RR=1.00 (0.90 to 1.20) | 414/11036 (3.8) | 406/11035 (3.7) | 0.71
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Any cancer deaths | 4.1 | All | RR=1.11 (0.67 to 1.85) | 31/19937 (0.2) | 28/19939 (0.1) | 0.69
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Chronic liver disease deaths | 22.1 | All | HR=1.06 (0.74 to 1.51) | 62/7274 (0.9) | 59/7282 (0.8) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Chronic liver disease deaths | 22.1 | All | HR=1.05 (0.82 to 1.36) | 121/14543 (0.8) | 116/14562 (0.8) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Chronic liver disease deaths | 22.1 | All | HR=1.01 (0.70 to 1.45) | 59/7269 (0.8) | 59/7282 (0.8) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Colorectal cancer deaths | 6.1 | All | RR=1.01 (0.56 to 1.79) | 23/14564 (0.2) | 24/14569 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | CVD deaths | 6.1 | All | 1.11 (1.01 to 1.23) | 905/14560 (6.2) | 818/14573 (5.6) | NR
Green, 1999 (NSCPS)^73^ | Beta-carotene vs. placebo | 30 mg | CVD deaths | 4.5 | All | 0.48 (0.18 to 1.30) | 6/820 (0.7) | 12/801 (1.5) | NR
Greenberg, 1990 (SCPS)^87^ | Beta-carotene vs. placebo | 50 mg | CVD deaths | 8.2 | All | RR=1.16 (0.82 to 1.64) | 68/913 (7.4) | 59/892 (6.6) | 0.41
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | CVD deaths | 12 | All | RR=1.09 (0.93 to 1.27) | 338/11036 (3.1) | 313/11035 (2.8) | 0.28
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | CVD deaths | 4.1 | All | RR=1.17 (0.54 to 2.53) | 14/19937 (0.1) | 12/19939 (0.1) | 0.69
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | CVD deaths | 3.7 | All | RR=1.26 (0.99 to 1.61) | ./9420 (.) | ./8894 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | CVD deaths | 10 | All | RR=1.02 (0.88 to 1.19) | 354/8744 (4.0) | 319/8396 (3.8) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | CVD deaths | 3.7 | Asbestos-exposed (all male) | RR=1.43 (0.97 to 2.12) | ./2044 (.) | ./2016 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | CVD deaths | 10 | Asbestos-exposed (all male) | RR=0.91 (0.69 to 1.21) | 95/1842 (5.2) | 103/1851 (5.6) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | CVD deaths | 3.7 | Female heavy smokers | RR=1.42 (0.80 to 2.54) | ./3201 (.) | ./3081 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | CVD deaths | 10 | Female heavy smokers | RR=1.44 (1.02 to 2.04) | 83/3044 (2.7) | 54/2965 (1.8) | <0.05
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | CVD deaths | 3.7 | Heavy smokers | RR=1.16 (0.85 to 1.58) | ./7376 (.) | ./6878 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | CVD deaths | 10 | Heavy smokers | RR=1.07 (0.89 to 1.29) | 259/6902 (3.8) | 216/6545 (3.3) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | CVD deaths | 3.7 | Male heavy smokers | RR=1.05 (0.73 to 1.52) | ./4175 (.) | ./3797 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | CVD deaths | 10 | Male heavy smokers | RR=0.93 (0.75 to 1.16) | 176/3858 (4.6) | 162/3580 (4.5) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Esophageal cancer deaths | 6.1 | All | RR=0.67 (0.19 to 2.37) | 4/7282 (0.1) | 6/7287 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Esophageal cancer deaths | 6.1 | All | RR=0.67 (0.24 to 1.88) | 6/14560 (0.0) | 9/14573 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Esophageal cancer deaths | 6.1 | All | RR=0.34 (0.07 to 1.66) | 2/7278 (0.0) | 6/7287 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Hemorrhagic stroke deaths | 6.1 | All | 1.16 (0.80 to 1.69) | 59/14560 (0.4) | 51/14573 (0.3) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Ischemic heart disease deaths | 6.1 | All | 1.12 (1.00 to 1.26) | 653/14560 (4.5) | 586/14573 (4.0) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Ischemic stroke deaths | 6.1 | All | 1.24 (0.87 to 1.77) | 68/14560 (8.0) | 55/14573 (6.5) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Laryngeal cancer deaths | 6.1 | All | RR=1.00 (0.20 to 4.96) | 3/7282 (0.0) | 3/7287 (0.0) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Laryngeal cancer deaths | 6.1 | All | RR=1.01 (0.29 to 3.46) | 5/14560 (0.0) | 5/14573 (0.0) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Laryngeal cancer deaths | 6.1 | All | RR=0.67 (0.11 to 4.00) | 2/7278 (0.0) | 3/7287 (0.0) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Lung cancer deaths | 6.1 | All | 1.16 (0.98 to 1.37) | 302/14560 (2.1) | 262/14573 (1.8) | NR
Greenberg, 1990 (SCPS)^87^ | Beta-carotene vs. placebo | 50 mg | Lung cancer deaths | 8.2 | All | 0.74 (0.36 to 1.54) | 13/913 (1.4) | 17/892 (1.9) | NR
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Lung cancer deaths | 12 | All | 1.02 (0.71 to 1.44) | 63/11036 (0.6) | 62/11035 (0.6) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer deaths | 3.7 | All | RR=1.46 (1.07 to 2.00) | ./9420 (.) | ./8894 (.) | 0.02
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer deaths | 10 | All | RR=1.20 (1.01 to 1.43) | 294/8744 (3.4) | 227/8396 (2.7) | <0.05
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer deaths | 3.7 | Asbestos-exposed (all male) | RR=1.29 (0.75 to 2.22) | ./2044 (.) | ./2016 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer deaths | 10 | Asbestos-exposed (all male) | RR=1.16 (0.77 to 1.75) | 50/1842 (2.7) | 43/1851 (2.3) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer deaths | 3.7 | Female heavy smokers | RR=1.46 (0.81 to 2.62) | ./3201 (.) | ./3081 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer deaths | 10 | Female heavy smokers | RR=1.33 (0.96 to 1.84) | 91/3044 (3.0) | 63/2965 (2.1) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer deaths | 3.7 | Heavy smokers | RR=1.55 (1.06 to 2.28) | ./7376 (.) | ./6878 (.) | <0.05
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer deaths | 10 | Heavy smokers | RR=1.21 (1.00 to 1.47) | 244/6902 (3.5) | 184/6545 (2.8) | <0.05
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer deaths | 3.7 | Male heavy smokers | RR=1.62 (0.98 to 2.68) | ./4175 (.) | ./3797 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer deaths | 10 | Male heavy smokers | RR=1.14 (0.89 to 1.45) | 153/3858 (4.0) | 121/3580 (3.4) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Oral cavity/pharynx cancer deaths | 6.1 | All | RR=2.01 (0.37 to 10.95) | 4/7282 (0.1) | 2/7287 (0.0) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Oral cavity/pharynx cancer deaths | 6.1 | All | RR=1.43 (0.55 to 3.76) | 10/14560 (0.1) | 7/14573 (0.0) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Oral cavity/pharynx cancer deaths | 6.1 | All | RR=3.01 (0.61 to 14.93) | 6/7278 (0.1) | 2/7287 (0.0) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Other CVD deaths | 6.1 | All | 0.99 (0.77 to 1.27) | 125/14560 (0.9) | 126/14573 (0.9) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Pancreatic cancer deaths | 6.1 | All | RR=0.81 (0.53 to 1.26) | 35/14560 (0.2) | 48/14573 (0.3) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Prostate cancer deaths | 6.1 | All | 1.17 (0.62 to 2.19) | 21/7282 (0.3) | 18/7287 (0.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Prostate cancer deaths | 6.1 | All | 1.14 (0.69 to 1.88) | 33/14560 (0.2) | 29/14573 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Prostate cancer deaths | 6.1 | All | 0.67 (0.32 to 1.39) | 12/7278 (0.2) | 18/7287 (0.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Renal cell carcinoma deaths | 6.1 | All | 0.43 (0.16 to 1.12) | 6/7282 (0.1) | 14/7287 (0.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Renal cell carcinoma deaths | 6.1 | All | 0.64 (0.34 to 1.20) | 16/14560 (0.1) | 25/14573 (0.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Renal cell carcinoma deaths | 6.1 | All | 0.71 (0.32 to 1.61) | 10/7278 (0.1) | 14/7287 (0.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Urothelial cancer deaths | 6.1 | All | 1.00 (0.29 to 3.46) | 5/7282 (0.1) | 5/7287 (0.1) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Urothelial cancer deaths | 6.1 | All | 1.18 (0.53 to 2.64) | 13/14560 (0.1) | 11/14573 (0.1) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Urothelial cancer deaths | 6.1 | All | 1.60 (0.52 to 4.90) | 8/7278 (0.1) | 5/7287 (0.1) | NR

* Studies providing estimates other than ORs display effect type.

Abbreviations: . = not reported; ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CARET = The Beta-Carotene and Retinol Efficacy Trial; CG = Control group; CVD = Cardiovascular disease; IG = Intervention group; NR = Not reported; NS = Not significant; NSCPS = Nambour Skin Cancer Prevention Study; mg = Milligrams; IRR = Incident rate ratio; IU = International units; OR = Odds ratio; PHS-I = Physicians’ Health Study-I; RR = Risk ratio; SCPS = Skin Cancer Prevention Study; WHS = Women’s Health Study.

Appendix F Table 11 Beta Carotene Cardiovascular Disease Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect | IG n/N (%) | CG n/N (%) | p-value
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | CVD events | 12 | All | RR=1.00 (0.91 to 1.09) | 967/11036 (8.8) | 972/11035 (8.8) | 0.90
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | CVD events | 4.1 | All | RR=1.14 (0.87 to 1.49) | 116/19937 (0.6) | 102/19939 (0.5) | 0.34
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | MI | 12 | All | RR=0.96 (0.84 to 1.09) | 468/11036 (4.2) | 489/11035 (4.4) | 0.50
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | MI | 4.1 | All | RR=0.84 (0.56 to 1.27) | 42/19937 (0.2) | 50/19939 (0.3) | 0.41
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Stroke | 12 | All | RR=0.96 (0.83 to 1.11) | 367/11036 (3.3) | 382/11035 (3.5) | 0.60
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Stroke | 4.1 | All | RR=1.42 (0.96 to 2.10) | 61/19937 (0.3) | 43/19939 (0.2) | 0.08

Abbreviations: CG = Control group; CVD = Cardiovascular disease; IG = Intervention group; MI = Myocardial infarction; PHS-I = Physicians’ Health Study-I; RR = Risk ratio; mg = Milligrams; WHS = Women’s Health Study.

Appendix F Table 12 Beta Carotene Cancer Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Any cancer incidence | 12 | All | RR=0.98 (0.91 to 1.06) | 1273/11036 (11.5) | 1293/11035 (11.7) | 0.65
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Any cancer incidence | 12.9 | All | RR=1.00 (0.90 to 1.00) | 1314/11036 (11.9) | 1353/11035 (12.3) | 0.41
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Any cancer incidence | 4.1 | All | RR=1.03 (0.89 to 1.18) | 378/19937 (1.9) | 369/19939 (1.9) | 0.73
Green, 1999 (NSCPS)^73^ | Beta-carotene vs. placebo | 30 mg | Basal cell carcinoma | 4.5 | All | IRR=1.04 (0.73 to 1.27) | 102/820 (12.4) | 93/801 (11.6) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Brain cancer | 12 | All | 0.81 (0.48 to 1.37) | 25/11036 (0.2) | 31/11035 (0.3) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Brain cancer | 12.9 | All | RR=0.80 (0.50 to 1.30) | 25/11036 (0.2) | 33/11035 (0.3) | 0.29
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Brain cancer | 4.1 | All | 0.67 (0.19 to 2.36) | 4/19937 (0.0) | 6/19939 (0.0) | NR, NS
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Breast cancer | 4.1 | All | 1.01 (0.81 to 1.25) | 169/19937 (0.8) | 168/19939 (0.8) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Breast cancer | 3.7 | Female heavy smokers | RR=0.78 (0.55 to 1.12) | 59/3208 (1.8) | 65/3081 (2.1) | 0.18
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Cervical cancer | 4.1 | All | 0.67 (0.11 to 3.99) | 2/19937 (0.0) | 3/19939 (0.0) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Colon cancer | 12.9 | All | RR=0.90 (0.70 to 1.20) | 128/11036 (1.2) | 139/11035 (1.3) | 0.48
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Colorectal cancer | 24.1 | All | 0.97 (0.80 to 1.18) | 203/7282 (2.8) | 209/7287 (2.9) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Colorectal cancer | 8 | All | RR=1.05 (0.75 to 1.47) | 69/14560 (0.5) | 66/14573 (0.5) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Colorectal cancer | 11 | All | 1.05 (0.81 to 1.36) | 116/14560 (0.8) | 111/14573 (0.8) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Colorectal cancer | 14 | All | 1.26 (1.01 to 1.56) | 189/14560 (1.3) | 151/14573 (1.0) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Colorectal cancer | 24.1 | All | 0.93 (0.76 to 1.14) | 195/7278 (2.7) | 209/7287 (2.9) | NR
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Colorectal cancer | 12 | All | 0.96 (0.77 to 1.19) | 167/11036 (1.5) | 174/11035 (1.6) | NR, NS
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Colorectal cancer | 4.1 | All | 1.00 (0.62 to 1.61) | 34/19937 (0.2) | 34/19939 (0.2) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Colorectal cancer | 3.7 | All | RR=1.02 (0.70 to 1.50) | 56/9420 (0.6) | 50/8894 (0.6) | 0.91
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Esophageal cancer | 6.1 | All | RR=0.86 (0.29 to 2.56) | 6/7282 (0.1) | 7/7287 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Esophageal cancer | 6.1 | All | RR=0.85 (0.38 to 1.90) | 11/14560 (0.1) | 13/14573 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Esophageal cancer | 6.1 | All | RR=0.72 (0.23 to 2.27) | 5/7278 (0.1) | 7/7287 (0.1) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Head and neck cancer | 3.7 | All | RR=1.26 (0.73 to 2.19) | 32/9420 (0.3) | 22/8894 (0.2) | 0.41
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Laryngeal cancer | 6.1 | All | RR=0.71 (0.34 to 1.48) | 12/7282 (0.2) | 17/7287 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Laryngeal cancer | 6.1 | All | RR=0.65 (0.38 to 1.11) | 22/14560 (0.2) | 34/14573 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Laryngeal cancer | 6.1 | All | RR=0.59 (0.27 to 1.29) | 10/7278 (0.1) | 17/7287 (0.2) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Leukemia | 12 | All | 0.83 (0.53 to 1.31) | 35/11036 (0.3) | 42/11035 (0.4) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Leukemia | 12.9 | All | RR=0.80 (0.50 to 1.20) | 36/11036 (0.3) | 45/11035 (0.4) | 0.31
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Leukemia | 3.7 | All | RR=2.18 (0.95 to 5.03) | 18/9420 (0.2) | 8/8894 (0.1) | 0.06
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Leukemia/lymphoma | 4.1 | All | 0.77 (0.41 to 1.46) | 17/19937 (0.1) | 22/19939 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Liver cancer | 22.1 | All | HR=1.26 (0.85 to 1.87) | 56/7274 (0.8) | 45/7282 (0.6) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Liver cancer | 22.1 | All | HR=1.13 (0.86 to 1.49) | 110/14543 (0.8) | 98/14562 (0.7) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Liver cancer | 22.1 | All | HR=1.21 (0.81 to 1.80) | 54/7269 (0.7) | 45/7282 (0.6) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Lung cancer | 6.1 | All | 1.17 (0.97 to 1.41) | 242/7282 (3.3) | 208/7287 (2.9) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Lung cancer | 24.1 | All | 1.02 (0.93 to 1.13) | 951/7282 (13.1) | 933/7287 (12.8) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Lung cancer | 6.1 | All | RR=1.18 (1.03 to 1.36) | 474/14560 (3.3) | 402/14573 (2.8) | 0.01
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Lung cancer | 8 | All | RR=1.16 (1.02 to 1.33) | 482/14560 (3.3) | 412/14573 (2.8) | <0.05
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Lung cancer | 11 | All | 1.17 (1.05 to 1.30) | 748/14560 (5.1) | 645/14573 (4.4) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Lung cancer | 14 | All | 1.10 (1.00 to 1.21) | 1009/14560 (6.9) | 923/14573 (6.3) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Lung cancer | 6.1 | All | 1.16 (0.96 to 1.40) | 240/7278 (3.3) | 208/7287 (2.9) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Lung cancer | 24.1 | All | 1.05 (0.96 to 1.16) | 976/7278 (13.4) | 933/7287 (12.8) | NR
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Lung cancer | 12 | All | 0.93 (0.69 to 1.26) | 82/11036 (0.7) | 88/11035 (0.8) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Lung cancer | 12.9 | All | RR=0.90 (0.70 to 1.20) | 85/11036 (0.8) | 93/11035 (0.8) | 0.54
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Lung cancer | 4.1 | All | 1.48 (0.85 to 2.57) | 31/19937 (0.2) | 21/19939 (0.1) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer | 3.7 | All | IRR=1.28 (1.04 to 1.57) | 229/9420 (2.4) | 159/8894 (1.8) | 0.02
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer | 6-yr post intervention period only | All | RR=1.12 (0.97 to 1.31) | 376/8744 (4.3) | 311/8396 (3.7) | NR
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer | 10 | All | 1.23 (1.09 to 1.39) | 605/9420 (6.4) | 470/8894 (5.3) | NR
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer | 3.7 | Asbestos-exposed (all male) | IRR=1.40 (0.95 to 2.07) | 62/2044 (3.0) | 44/2016 (2.2) | 0.08
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer | 10 | Asbestos-exposed (all male) | RR=0.92 (0.65 to 1.30) | 61/1842 (3.3) | 66/1851 (3.6) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer | 3.7 | Female heavy smokers | RR=1.19 (0.82 to 1.72) | ./3201 (.) | ./3081 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer | 10 | Female heavy smokers | RR=1.33 (1.01 to 1.75) | 127/3044 (4.2) | 88/2965 (3.0) | <0.05
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer | 3.7 | Heavy smokers | IRR=1.23 (0.96 to 1.56) | 167/7376 (2.3) | 115/6878 (1.7) | 0.09
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer | 10 | Heavy smokers | RR=1.18 (0.99 to 1.39) | 315/6902 (4.6) | 245/6545 (3.7) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer | 3.7 | Male heavy smokers | RR=1.25 (0.91 to 1.73) | ./4175 (.) | ./3797 (.) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lung cancer | 10 | Male heavy smokers | RR=1.08 (0.87 to 1.34) | 188/3858 (4.9) | 157/3580 (4.4) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Lymphoma | 12 | All | 1.08 (0.79 to 1.46) | 86/11036 (0.8) | 80/11035 (0.7) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Lymphoma | 12.9 | All | RR=1.00 (0.80 to 1.40) | 89/11036 (0.8) | 85/11035 (0.8) | 0.77
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Lymphoma | 3.7 | All | RR=0.91 (0.42 to 1.98) | 13/9420 (0.1) | 13/8894 (0.1) | 0.81
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Melanoma skin cancer | 12 | All | 0.88 (0.63 to 1.23) | 64/11036 (0.6) | 73/11035 (0.7) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Melanoma skin cancer | 12.9 | All | RR=0.90 (0.60 to 1.20) | 68/11036 (0.6) | 77/11035 (0.7) | 0.45
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Melanoma skin cancer | 4.1 | All | 0.90 (0.49 to 1.68) | 19/19937 (0.1) | 21/19939 (0.1) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Mesothelioma | 3.7 | All | RR=1.52 (0.66 to 3.52) | 14/9420 (0.1) | 9/8894 (0.1) | 0.32
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Oral cavity/pharyngeal cancer | 6.1 | All | RR=0.84 (0.42 to 1.66) | 15/7282 (0.2) | 18/7287 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Oral cavity/pharyngeal cancer | 6.1 | All | RR=0.97 (0.60 to 1.58) | 32/14560 (0.2) | 33/14573 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Oral cavity/pharyngeal cancer | 6.1 | All | RR=0.95 (0.49 to 1.84) | 17/7278 (0.2) | 18/7287 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Other cancer | 6.1 | All | 0.94 (0.81 to 1.09) | 356/14560 (2.4) | 379/14573 (2.6) | NR, NS
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Ovarian cancer | 4.1 | All | 1.33 (0.72 to 2.46) | 24/19937 (0.1) | 18/19939 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Pancreatic cancer | 6.1 | All | RR=0.46 (0.23 to 0.92) | 12/7282 (0.2) | 26/7287 (0.4) | <0.05
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Pancreatic cancer | 24.1 | All | 0.92 (0.70 to 1.20) | 101/7282 (1.4) | 110/7287 (1.5) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Pancreatic cancer | 6.1 | All | RR=0.75 (0.49 to 1.14) | 38/14560 (0.3) | 51/14573 (0.3) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Pancreatic cancer | 6.1 | All | RR=1.00 (0.52 to 1.73) | 26/7278 (0.4) | 26/7287 (0.4) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Pancreatic cancer | 24.1 | All | 1.00 (0.77 to 1.31) | 110/7278 (1.5) | 110/7287 (1.5) | NR
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Pancreatic cancer | 12 | All | 1.38 (0.79 to 2.42) | 29/11036 (0.3) | 21/11035 (0.2) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Pancreatic cancer | 12.9 | All | RR=1.40 (0.80 to 2.60) | 29/11036 (0.3) | 20/11035 (0.2) | 0.20
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Pancreatic cancer | 4.1 | All | 1.50 (0.42 to 5.32) | 6/19937 (0.0) | 4/19939 (0.0) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Prostate cancer | 6.1 | All | 1.20 (0.86 to 1.66) | 80/7282 (1.1) | 67/7287 (0.9) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Prostate cancer | 24.1 | All | 0.97 (0.87 to 1.09) | 656/7282 (9.0) | 672/7287 (9.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Prostate cancer | 6.1 | All | 1.24 (0.96 to 1.59) | 138/14560 (0.9) | 112/14573 (0.8) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Prostate cancer | 8 | All | RR=1.26 (0.98 to 1.62) | 138/14560 (0.9) | 110/14573 (0.8) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Prostate cancer | 11 | All | 1.21 (1.02 to 1.44) | 287/14560 (2.0) | 238/14573 (1.6) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Prostate cancer | 14 | All | 1.10 (0.96 to 1.25) | 480/14560 (3.3) | 440/14573 (3.0) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Prostate cancer | 24.1 | All | 0.95 (0.85 to 1.07) | 643/7278 (8.8) | 672/7287 (9.2) | NR
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Prostate cancer | 12 | All | 0.99 (0.87 to 1.12) | 520/11036 (4.7) | 527/11035 (4.8) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Prostate cancer | 12.9 | All | RR=1.00 (0.90 to 1.00) | 551/11036 (5.0) | 566/11035 (5.1) | 0.41
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Prostate cancer | 3.7 | Males | RR=1.01 (0.80 to 1.27) | 161/6212 (2.6) | 139/5813 (2.4) | 0.95
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Prostate cancer | 11 | Males | 1.01 (0.88 to 1.16) | 462/6197 (7.5) | 428/5803 (7.4) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Rectal cancer | 12.9 | All | RR=1.10 (0.70 to 1.80) | 42/11036 (0.4) | 37/11035 (0.3) | 0.58
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Renal cell carcinoma | 6.1 | All | 0.78 (0.44 to 1.38) | 21/7282 (0.3) | 27/7287 (0.4) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Renal cell carcinoma | 24.1 | All | 0.98 (0.73 to 1.31) | 88/7282 (1.2) | 90/7287 (1.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Renal cell carcinoma | 6.1 | All | RR=0.80 (0.60 to 1.30) | 48/14560 (0.3) | 54/14573 (0.4) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Renal cell carcinoma | 6.1 | All | 1.00 (0.59 to 1.71) | 27/7278 (0.4) | 27/7287 (0.4) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene and vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Renal cell carcinoma | 24.1 | All | 0.97 (0.72 to 1.30) | 87/7278 (1.2) | 90/7287 (1.2) | NR
Green, 1999 (NSCPS)^73^ | Beta-carotene vs. placebo | 30 mg | Squamous cell carcinoma | 4.5 | All | IRR=1.35 (0.84 to 2.19) | 40/820 (4.9) | 28/801 (3.5) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Stomach cancer | 6.1 | All | RR=1.38 (0.81 to 2.36) | 33/7282 (0.5) | 24/7287 (0.3) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Stomach cancer | 24.1 | All | 1.04 (0.79 to 1.36) | 108/7282 (1.5) | 104/7287 (1.4) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Stomach cancer | 6.1 | All | RR=1.26 (0.88 to 1.80) | 70/14560 (0.5) | 56/14573 (0.4) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Stomach cancer | 6.1 | All | RR=1.55 (0.92 to 2.62) | 37/7278 (0.5) | 24/7287 (0.3) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Stomach cancer | 24.1 | All | 1.09 (0.83 to 1.42) | 113/7278 (1.6) | 104/7287 (1.4) | NR
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Stomach cancer | 12 | All | 0.90 (0.49 to 1.68) | 19/11036 (0.2) | 21/11035 (0.2) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Stomach cancer | 12.9 | All | RR=0.90 (0.50 to 1.80) | 20/11036 (0.2) | 21/11035 (0.2) | 0.87
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Stomach cancer | 4.1 | All | 1.00 (0.06 to 15.99) | 1/19937 (0.0) | 1/19939 (0.0) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Thyroid cancer | 12 | All | 8.01 (1.84 to 34.84) | 16/11036 (0.1) | 2/11035 (0.0) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Thyroid cancer | 12.9 | All | RR=9.50 (2.20 to 40.70) | 19/11036 (0.2) | 2/11035 (0.0) | 0.003
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Thyroid cancer | 4.1 | All | 0.75 (0.32 to 1.78) | 9/19937 (0.0) | 12/19939 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Urinary bladder cancer | 6.1 | All | 1.04 (0.76 to 1.43) | 79/14560 (0.5) | 76/14573 (0.5) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Urinary bladder cancer | 12 | All | 1.51 (1.02 to 2.25) | 62/11036 (0.6) | 41/11035 (0.4) | NR, NS
Hennekens, 1996 (PHS-I)^75^ | Beta-carotene vs. no beta-carotene | 25 mg | Urinary bladder cancer | 12.9 | All | RR=1.50 (1.00 to 2.20) | 62/11036 (0.6) | 41/11035 (0.4) | 0.4
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Urinary bladder cancer | 4.1 | All | 0.83 (0.25 to 2.73) | 5/19937 (0.0) | 6/19939 (0.0) | NR, NS
Omenn, 1996 (CARET)^63^ | Beta-carotene + vitamin A vs. placebo | 30 mg + 25000 IU Vitamin A | Urinary bladder cancer | 3.7 | All | RR=1.08 (0.69 to 1.70) | 42/9420 (0.4) | 36/8894 (0.4) | 0.73
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Urothelial cancer | 6.1 | All | 1.16 (0.75 to 1.81) | 43/7282 (0.6) | 37/7287 (0.5) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. placebo | 20 mg | Urothelial cancer | 24.1 | All | 0.92 (0.75 to 1.12) | 190/7282 (2.6) | 206/7287 (2.8) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene vs. no beta-carotene | 20 mg + 50 mg Vitamin E | Urothelial cancer | 6.1 | All | RR=1.00 (0.70 to 1.30) | 85/14560 (0.6) | 84/14573 (0.6) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Urothelial cancer | 6.1 | All | 1.14 (0.73 to 1.77) | 42/7278 (0.6) | 37/7287 (0.5) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Beta-carotene + vitamin E vs. placebo | 20 mg + 50 mg Vitamin E | Urothelial cancer | 24.1 | All | 1.02 (0.84 to 1.24) | 209/7278 (2.9) | 206/7287 (2.8) | NR
Lee, 2005 (WHS)^74^ | Beta-carotene vs. no beta-carotene | 25 mg | Uterine cancer | 4.1 | All | 1.15 (0.69 to 1.92) | 31/19937 (0.2) | 27/19939 (0.1) | NR, NS

* Studies providing estimates other than ORs display effect type.

Abbreviations: . = not reported; ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CARET = The Beta-Carotene and Retinol Efficacy Trial; CG = Control group; IG = Intervention group; IRR = Incident rate ratio; IU = International units; mg = Milligram; NR = Not reported; NS = Not significant; NSCPS = Nambour Skin Cancer Prevention Study; OR = Odds ratio; RR = Risk ratio; PHS-I = Physicians’ Health Study-I; WHS = Women’s Health Study.

Appendix F Table 13 Beta Carotene Adverse Event Results

Author, Year (Study) | Dose | Comparison | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%)
Omenn, 1996 (CARET)^63^ | 30 mg + 25000 IU Vitamin A | Beta-carotene + vitamin A vs. placebo | Any AE | 3.7 | All | . (. to .) | ./9420 (.) | ./8894 (.)
Hennekens, 1996 (PHS-I)^75^ | 25 mg | Beta-carotene vs. no beta-carotene | Gastrointestinal symptoms | 12 | All | 2.25 (1.82 to 2.78) | 275/11036 (2.5) | 124/11035 (1.1)
Feskanich, 2002 (NHS-I)^146^ | NR | Beta-carotene vs. no beta-carotene | Hip fracture | 14 | All | RR=0.91 (0.57 to 1.44) | 21/. (.) | 419/. (.)
ATBC Study Group, 1994 (ATBC)^76^ | 20 mg + 50 mg Vitamin E | Beta-carotene vs. no beta-carotene | Hypercarotenodermia | 6.1 | All | 6.84 (6.37 to 7.36) | 4950/14560 (34.0) | 1020/14573 (7.0)
Greenberg, 1990 (SCPS)^87^ | 50 mg | Beta-carotene vs. placebo | Withdrawal due to Hypercarotenodermia | 2 | All | 24.75 (1.46 to 418.66) | 12/913 (1.3) | 0/892 (0.0)
Hennekens, 1996 (PHS-I)^75^ | 25 mg | Beta-carotene vs. no beta-carotene | Hypercarotenodermia | 12 | All | 1.16 (1.08 to 1.25) | 1745/11036 (15.8) | 1535/11035 (13.9)
Lee, 2005 (WHS)^74^ | 25 mg | Beta-carotene vs. no beta-carotene | Hypercarotenodermia | 4.1 | All | 1.11 (1.04 to 1.18) | 2131/19937 (10.7) | 1944/19939 (9.7)
ATBC Study Group, 1994 (ATBC)^76^ | 20 mg | Beta-carotene vs. placebo | Non-serious: Hospitalized for pneumonia (NS) | 6.1 | All | . (. to .) | ./7280 (.) | ./7284 (.)
ATBC Study Group, 1994 (ATBC)^76^ | 20 mg + 50 mg Vitamin E | Beta-carotene vs. no beta-carotene | Non-serious: Hospitalized for pneumonia (NS) | 6.1 | All | RR=0.98 (0.85 to 1.11) | 442/14560 (3.0) | 456/14573 (3.1)
Hennekens, 1996 (PHS-I)^75^ | 25 mg | Beta-carotene vs. no beta-carotene | Serious AEs | 12 | All | . (. to .) | ./11036 (.) | ./11035 (.)
Green, 1999 (NSCPS)^73^ | 30 mg | Beta-carotene vs. placebo | Withdrawals due to AEs | 4.5 | All | 0.99 (0.69 to 1.42) | 65/820 (7.9) | 64/801 (8.0)
Greenberg, 1990 (SCPS)^87^ | 50 mg | Beta-carotene vs. placebo | Withdrawals due to AEs | 2 | All | 1.58 (0.99 to 2.49) | 49/913 (5.4) | 31/892 (3.5)

* Studies providing estimates other than ORs display effect type.

Abbreviations: . = not reported; AE = Adverse event; ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CARET = The Beta-Carotene and Retinol Efficacy Trial; CG = Control group; IG = Intervention group; IU = International units; mg = Milligram; NHS-I = Nurses’ Health Study I; NS = Not significant; OR = Odds ratio; PHS-I = Physicians’ Health Study-I; RR = Risk ratio; SCPS = Skin Cancer Prevention Study; WHS = Women’s Health Study.

Appendix F Table 14 Vitamin A Mortality Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect | IG n/N (%) | CG n/N (%) | p-value
Moon, 1997 (SKICAP)^64^ | Vitamin A vs. placebo | 25000 IU | All-cause mortality | 5 | All | 1.16 (0.80 to 1.69) | 62/1157 (5.4) | 53/1140 (4.6) | NR

Abbreviations: CG = Control group; IG = Intervention group; IU = International units; NR = Not reported; SKICAP = SKIn CAncer Prevention.

Appendix F Table 15 Vitamin A Adverse Event Results

Author, Year (Study) | Dose | Comparison | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%)
Moon, 1997 (SKICAP)^64^ | 25000 IU | Vitamin A vs. placebo | Any AE | 5.1 | All | 1.77 (1.49 to 2.09) | 703/1124 (62.5) | 554/1140 (48.6)
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin A <2 yrs use vs. no vitamin A | Cataract | 12 | All | RR=1.39 (0.97 to 1.98) | 280/100000 p-y | 193/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin A 2-4 yrs use vs. no vitamin A | Cataract | 12 | All | RR=0.99 (0.51 to 1.92) | 201/100000 p-y | 193/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin A 5-9 yrs use vs. no vitamin A | Cataract | 12 | All | RR=0.70 (0.35 to 1.41) | 142/100000 p-y | 193/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin A ≥10 yrs use vs. no vitamin A | Cataract | 12 | All | RR=0.60 (0.27 to 1.34) | 133/100000 p-y | 193/100000 p-y
Lim, 2004 (IWHS)^147^ | NR | Vitamin A vs. Placebo | Fractures | 9.5 | All | RR=1.00 (0.95 to 1.05) | 2343/. (.) | 4159/. (.)
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin A current use vs. no vitamin A | Hip fracture | 18 | All | RR=1.40 (0.99 to 1.99) | 36/. (.) | 462/. (.)
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin A <3 yrs use vs. no vitamin A | Hip fracture | 18 | All | RR=1.23 (0.65 to 2.30) | 10/. (.) | 462/. (.)
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin A >=3 yrs use vs. no vitamin A | Hip fracture | 18 | All | RR=1.31 (0.72 to 2.39) | 12/. (.) | 462/. (.)
Lim, 2004 (IWHS)^147^ | NR | Vitamin A vs. Placebo | Hip fracture | 9.5 | All | RR=1.18 (0.99 to 1.41) | 211/. (.) | 324/. (.)

* Studies providing estimates other than ORs display effect type.

Abbreviations: . = not reported; AE = Adverse event; CG = Control group; IG = Intervention group; IU = International units; IWHS = Iowa Women’s Health Study; NHS-I = Nurses’ Health Study I; NR = Not reported; OR = Odds ratio; p-y = Person-years; RR = Risk ratio; SKICAP = SKIn CAncer Prevention.

Appendix F Table 16 Summary of Results for Studies of Vitamin D Use

Author, Year (Study) | Final Quality Rating | Study Design | N | Supplement (daily dose) | ACM | CVD | Cancer | Harms
Aloia, 2005^131^ | Fair | RCT | 208 | Vitamin D (30 mcg) + Calcium (NR NR) | ? | NR | NR | NR
Aloia, 2018 (PODA)^103^ | Fair | RCT | 260 | Vitamin D (3490 IU) | ? | ? | ? | ↔/? Extensive list of non-serious
Avenell, 2012 (RECORD)^89^ | Fair | RCT | 5292 | Vitamin D (800 IU) | ↔ | ↔ | ↔ | ↔ Fractures, GI sx
Avenell, 2012 (RECORD)^89^ | Fair | RCT | 5292 | Vitamin D (800 IU) + Calcium (1000 mg) | ↔ | ↔ | ↔ | ↔ Fractures
Baeksgaard, 1998^125^ | Fair | RCT | 240 | Vitamin D (560 IU) + Calcium (1000 mg) | ? | NR | NR | ? Constipation, nausea
Baron, 2015 (VCPPS)^91^ | Good | RCT | 2259 | Vitamin D (1000 IU) +/− Calcium (1200 mg) | ↔? | ? | ↔? | ↔ Hypercalcemia, hypercreatininemia, kidney stone, fracture
Bischoff-Ferrari, 2020 (DO-HEALTH)^140^ | Good | RCT | 2157 | Vitamin D (2000IU) | ? | NR | NR | ↓ Any AE; ? Kidney stones
Brisson, 2017^95^ | Good | RCT | 405 | Vitamin D (1000 IU) | NR | NR | NR | ↔? Nausea, vomiting, other non-serious; ? AE WD
Brisson, 2017^95^ | Good | RCT | 405 | Vitamin D (2000 IU) | NR | NR | NR | ↔? Nausea, vomiting, other non-serious; ? AE WD
Brisson, 2017^95^ | Good | RCT | 405 | Vitamin D (3000 IU) | NR | NR | NR | ↔? Nausea, vomiting, other non-serious; ? AE WD
Cooper, 2003^128^ | Fair | RCT | 187 | Vitamin D (1428.6 IU) + Calcium (1000 mg) | ? | NR | NR | ↑? AE WD
Dawson-Hughes, 1991^111^ | Fair | RCT | 276 | Vitamin D (400 IU) + Calcium (377 mg) | ? | NR | NR | ? Kidney stones, kidney failure/dialysis
Dawson-Hughes, 1997^124^ | Fair | RCT | 445 | Vitamin D (700 IU) + Calcium (500 mg) | NR | NR | NR | ? AE WD, GI sx
Dean, 2011^65^ | Good | RCT | 128 | Vitamin D (5000 IU) | NR | NR | NR | ? Any AE
Dukas, 2004^129^ | Fair | RCT | 380 | Vitamin D (1 microgram) | ? | ? | ? | ↔ Any AE, skin sx
Fedirko, 2009^114^ | Fair | RCT | 92 | Vitamin D (800 IU) | NR | NR | NR | ? Any AE
Fedirko, 2009^114^ | Fair | RCT | 92 | Vitamin D (800 IU) + Calcium (2.0 g) | NR | NR | NR | ? Any AE
Gallagher, 2001 (STOP IT)^126^ | Fair | RCT | 246 | Vitamin D (0.5 mcg) | ? | ? | ? | ↔? Major GI sx; ? Deep vein thrombosis, gallstones or cholecystitis, stroke, psychiatric sx
Glendenning, 2012^117^ | Fair | RCT | 686 | Vitamin D (1666.67 IU)^*^ | ? | ? | ↔? | ↔? Fractures
Grady, 1991^122^ | Fair | RCT | 98 | Vitamin D (0.5 mcg) | ? | ? | ? | NR
Kenny, 2003^118^ | Fair | RCT | 65 | Vitamin D (1000 IU) + Calcium (500 mg) | NR | NR | NR | ? Any AE
Komulainen, 1999 (KOS)^113^ | Fair | RCT | 464 | Vitamin D (300 IU) + Calcium (93 mg) | ? | ? | ? | NR
Lappe, 2007^83^ | Fair | RCT | 1180 | Calcium (1500 mg) + Vitamin D (1000 IU) | NR | NR | ↓? | ? Serious AE, kidney stones
Lappe, 2017^93^ | Good | RCT | 2303 | Calcium (1500 mg) + Vitamin D (2000 IU) | ? | NR | ? | ↔ AE WD, hypercalcemia; ↔? Kidney stones; ? Serious AEs
Lips, 1996^112^ | Fair | RCT | 2578 | Vitamin D (400 IU) | ↔ | NR | NR | NR
Neale, 2022^143^ | Good | RCT | 21,315 | Vitamin D (2000 IU) | ↔ | ↔ | ↔ | ↔ Any AE, serious AE, AD WD, kidney stones
Manson, 2018 (VITAL)^94^ | Good | RCT | 25,871 | Vitamin D (2000 IU) | ↔ | ↔ | ↔ | ↔ Kidney stones, kidney failure, GI bleed, extensive non-serious
Murdoch, 2012^119^ | Good | RCT | 322 | Vitamin D (3333.33 IU)^*^ | NR | NR | ? | ↔ Serious AE, AE WD
Pittas, 2019^136^ | Good | RCT | 2423 | Vitamin D (4000 IU) | ↔? | NR | ↔ | ↔ Serious AE
Rake, 2020^139^ | Good | RCT | 1615 | Vitamin D (3333.33 IU)^*^ | ↔ | ↔? | Any incidence: ↔; Morality:? | ↔ Any serious, AE WD
Salovaara, 2010 (OSTPRE-FPS)^135^ | Fair | RCT | 3432 | Vitamin D (800 IU) + Calcium (1000 mg) | ↔? | NR | NR | NR
Sanders, 2010 (Vital D)^116^ | Fair | RCT | 2258 | Vitamin D (1370 IU)^*^ | ↔? | ? | ? | ↔ Any AE; ↔? Serious AE
Scragg, 2017 (ViDA)^92^ | Good | RCT | 5110 | Vitamin D (3333 IU)^*^ | ↔ | ↔ | ↔ | ↔ Any AE, kidney stones, hypercalcemia, fractures
Toss, 2012^108^ | Fair | RCT | 56 | Vitamin D (1600 IU) + Calcium (1000 mg) | NR | NR | NR | ? Any AE, constipation
Trivedi, 2003^88^ | Fair | RCT | 2686 | Vitamin D (1095.9 IU)^*^ | ↔ | ↔ | ↔ | NR
Uusi-Rasi, 2015^121^ | Fair | RCT | 409 | Vitamin D (800 IU) | ? | NR | NR | NR
Virtanen, 2022^142^ | Good | RCT | 2495 | Vitamin D (1600 IU) | ? | ↔ | ↔ | ? Kidney stones
Wactawski-Wende, 2006 (WHI)^79^ | Good | RCT | 36,282 | Calcium (1000 mg) + Vitamin D (400 IU) | ↓? | ↔ | ↔ | ↔ Kidney stone, fractures
Witham, 2014^100^ | Fair | RCT | 68 | Vitamin D (1667 IU)^*^ | NR | ? | NR | ↔ Any AE, GI dx, dizziness, infection, musculoskeletal
Wood, 2012^120^ | Fair | RCT | 305 | Vitamin D (1000 IU) | NR | ? | NR | ↔ Any AE; ↔? Serious AE, AE WD, deep vein thrombosis, cellulitis, pneumonia, severe headache, GI sx
Wood, 2012^120^ | Fair | RCT | 305 | Vitamin D (400 IU) | NR | ? | NR | ↔ Any AE; ↔? Serious AE, AE WD, deep vein thrombosis, cellulitis, pneumonia, severe headache, GI sx
Wood, 2021^141^ | Fair | RCT | 300 | Vitamin D (2000 IU) | ? | NR | NR | ↔ Any AE, serious AE
Zitterman, 2009^115^ | Fair | RCT | 200 | Vitamin D (3332 IU) | NR | ? | NR | NR
Ferraro, 2017 (NHS-II)^149^ | Fair | Cohort | 11,6430 | Vitamin D (4 dose levels) | NA | NA | NA | ↔ Kidney stones (<1000 IU); ↑ Kidney stones (>=1000 IU)
Feskanich, 2002 (NHS-I)^146^ | Good | Cohort | 12,1700 | Vitamin D (4 dose levels) | NA | NA | NA | ↔ Kidney stones
Taylor, 2004 (HPFS)^150^ | Fair | Cohort | 51,529 | Vitamin D 4 dose levels) | NA | NA | NA | ↔ Kidney stones

* Bolus.

Abbreviations: ACM = All-cause mortality; AE = Adverse event; CVD = Cardiovascular disease; GI = Gastrointestinal; HPFS = Health Professionals Follow-up Study; IU = International units; KOS = Kuopio Osteoporosis Risk Factor and Prevention Study; mg = Milligram; NA = Not applicable; NHS = Nurses’ Health Study; NR = Not reported; OSTPRE-FPS = Osteoporosis Risk Factor and Prevention Fracture Prevention Study; PODA = The physical performance, osteoporosis prevention, and vitamin D in older African Americans; RCT = Randomized controlled trial; RECORD = Randomised evaluation of calcium or vitamin D; sx = Symptoms; VCPPS = Vitamin D/Calcium Polyp Prevention Study; VITAL = VITamin D and OmegA-3 TriaL; ViDa = Vitamin D Assessment Study; WHI = Women’s Health Initiative; WD = Withdrawal.

↑ Likely non-trivial increase in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

↑? Possible non-trivial increase in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↔ Evidence of no to minimal group differences (e.g., few to no statistically significant findings with reasonably precise estimates [e.g., >~20 events in all treatment arms]).

↔? Limited evidence of no to minimal group differences (e.g., few to no statistically significant findings, but imprecise estimates/side CIs).

↓? Possible non-trivial decrease in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↓ Likely non-trivial decrease in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

? Insufficient evidence to evaluate (e.g., very few [e.g., <10] events).

Judgement for symbols based on totality of evidence for each study, considering statistical and clinical significance.

Appendix F Table 17 Vitamin D Meta-Analysis Results, Showing Primary Analysis of Vitamin D With or Without Adjunctive Calcium First

Outcome | Model/Analysis | Pooled OR (95% CI) | No. studies | N analyzed | I^2^, % | Tau^2^
All-cause mortality | MH | 0.96 (0.91 to 1.02) | 27 | 117,082 | NA | NA
All-cause mortality | Peto | 0.96 (0.91 to 1.02) | 27 | 117,082 | 0 | 0.0
All-cause mortality | REML-KH | 0.96 (0.92 to 1.00) | 27 | 117,082 | 0 | 0.0
All-cause mortality | MH, RR rather than OR | RR=0.97 (0.92 to 1.01) | 27 | 117,082 | NA | NA
All-cause mortality | REML-KH, RR rather than OR | RR=0.96 (0.93 to 1.00) * | 27 | 117,082 | 0 | 0.0
All-cause mortality | Full ascert. (MH) | 0.96 (0.91 to 1.02) | 12 | 103,457 | NA | NA
All-cause mortality | Full ascert. (REML-KH) | 0.96 (0.91 to 1.02) | 12 | 103,457 | 0 | 0.0
All-cause mortality | Vit. D alone (MH) | 0.98 (0.92 to 1.05) | 20 | 74,398 | NA | NA
All-cause mortality | Vit. D + Ca (MH) | 0.93 (0.85 to 1.01) | 8 | 45,322 | NA | NA
All-cause mortality | Large bolus dosing (MH) | 1.02 (0.92 to 1.12) | 6 | 33,661 | NA | NA
CVD mortality | MH | 0.96 (0.87 to 1.06) | 9 | 98,422 | NA | NA
CVD mortality | Peto | 0.96 (0.87 to 1.06) | 9 | 98,422 | 0 | 0.0
CVD mortality | Full ascert. (MH) | 0.98 (0.88 to 1.09) | 7 | 95,356 | NA | NA
CVD mortality | Vit. D alone (MH) | 0.98 (0.87 to 1.11) | 8 | 62,140 | NA | NA
Composite CVD event | MH | 1.00 (0.95 to 1.05) | 7 | 74,925 | NA | NA
Composite CVD event | Peto | 1.00 (0.95 to 1.05) | 7 | 74,925 | 0 | 0.0
Composite CVD event | Full ascert. (MH) | 1.01 (0.95 to 1.07) | 4 | 69,756 | NA | NA
Composite CVD event | Vit. D alone (MH) | 0.98 (0.90 to 1.07) | 6 | 38,643 | NA | NA
MI | MH | 1.02 (0.91 to 1.14) | 6 | 72,261 | NA | NA
MI | Peto | 1.02 (0.91 to 1.14) | 6 | 72,261 | 0 | 0.0
MI | Full ascert. (MH) | 1.02 (0.91 to 1.14) | 5 | 72,015 | NA | NA
MI | Vit. D alone (MH) | 0.97 (0.81 to 1.16) | 5 | 35,979 | NA | NA
Stroke | MH | 0.98 (0.88 to 1.09) | 9 | 75,731 | NA | NA
Stroke | Peto | 0.98 (0.88 to 1.09) | 9 | 75,731 | 0 | 0.0
Stroke | Full ascert. (MH) | 0.96 (0.86 to 1.08) | 5 | 72,015 | NA | NA
Stroke | Vit. D alone (MH) | 1.00 (0.85 to 1.17) | 8 | 39,449 | NA | NA
Cancer mortality | MH | 0.94 (0.86 to 1.03) | 9 | 100,465 | NA | NA
Cancer mortality | REML-KH | 0.94 (0.79 to 1.12) | 9 | 100,465 | 31.0 | 0.01
Cancer mortality | Full ascert. (MH) | 0.95 (0.87 to 1.05) | 7 | 95,356 | NA | NA
Cancer mortality | Stated cancer aim (MH) | 0.87 (0.78 to 0.98) * | 4 | 67,323 | NA | NA
Cancer mortality | Vit. D alone (MH) | 0.97 (0.86 to 1.09) | 8 | 64,183 | NA | NA
Cancer mortality | Vit. D + Calcium (MH) | 0.90 (0.79 to 1.04) | 2 | 38,920 | NA | NA
Any cancer incidence | MH | 0.98 (0.92 to 1.03) | 19 | 86,899 | NA | NA
Any cancer incidence | REML-KH | 0.98 (0.92 to 1.03) | 18 | 86,899 | 0 | 0.0
Any cancer incidence | Full ascert. (MH) | 0.97 (0.91 to 1.02) | 9 | 77,624 | NA | NA
Any cancer incidence | Stated cancer aim (MH) | 0.97 (0.91 to 1.03) | 6 | 68,642 | NA | NA
Any cancer incidence | Vit. D alone (MH) | 1.00 (0.93 to 1.08) | 16 | 49,298 | NA | NA
Any cancer incidence | Vit. D + Calcium (MH) | 0.97 (0.90 to 1.04) | 4 | 40,239 | NA | NA
Any cancer incidence | Large bolus dosing (MH) | 1.04 (0.90 to 1.21) | 6 | 12,673 | NA | NA
Colorectal cancer | Peto | 1.06 (0.89 to 1.27) | 7 | 72,524 | 0 | 0.0
Colorectal cancer | MH | 1.06 (0.89 to 1.27) | 7 | 72,524 | NA | NA
Colorectal cancer | Full ascert. (MH) | 1.07 (0.88 to 1.28) | 6 | 69,838 | NA | NA
Colorectal cancer | Vit. D + Calcium (Peto) | 1.06 (0.86 to 1.31) | 3 | 39,213 | NA | NA
Lung cancer | MH | 0.93 (0.77 to 1.13) | 5 | 66,158 | NA | NA
Lung cancer | Peto | 0.93 (0.77 to 1.13) | 5 | 66,158 | 0 | 0.0
Lung cancer | Full ascert. (MH) | 0.92 (0.75 to 1.12) | 4 | 63,472 | NA | NA
Lung cancer | Vit. D + Calcium (Peto) | 0.87 (0.68 to 1.12) | 3 | 37,601 | NA | NA
Breast cancer | MH | 0.96 (0.87 to 1.06) | 6 | 67,901 | NA | NA
Breast cancer | Peto | 0.96 (0.87 to 1.06) | 6 | 67,901 | 0 | 0.0
Breast cancer | Full ascert. (MH) | 0.96 (0.87 to 1.05) | 5 | 67,579 | NA | NA
Breast cancer | Vit. D + Calcium (Peto) | 0.89 (0.69 to 1.15) | 3 | 39,213 | NA | NA
Prostate cancer | MH | 0.88 (0.73 to 1.07) | 2 | 28,366 | NA | NA
Prostate cancer | Peto | 0.88 (0.73 to 1.07) | 2 | 28,366 | 0 | 0
Prostate cancer | Full ascert. (MH) | 0.88 (0.73 to 1.07) | 2 | 28,366 | NA | NA

* Statistically significant at p<0.05.

Abbreviations: CI = Confidence interval; CVD = Cardiovascular disease; MH = Mantel-Haenszel common effects model; MI = Myocardial infarction; NA = Not applicable; No. = Number; OR = Odds ratio; Peto = Peto odds ratio random effects REML model; REML-KH = random effects restricted maximum likelihood model with the Knapp-Hartung adjustment; Vit D = Vitamin D.

Appendix F Table 18 Vitamin D Mortality Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Aloia, 2005^131^ | Vitamin D + calcium vs. calcium alone | 30 mcg + NR Calcium | All-cause mortality | 3 | All | 0.50 (0.04 to 5.55) | 1/104 (1.0) | 2/104 (1.9)
Aloia, 2018 (PODA)^103^ | Vitamin D vs. placebo | 3490 IU | All-cause mortality | 3 | All | 0.33 (0.01 to 8.19) | 0/130 (0.0) | 1/130 (0.8) | NR
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | All-cause mortality | 6.2 | All | 0.96 (0.82 to 1.13) | 415/1306 (31.8) | 434/1332 (32.6) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | All-cause mortality | 6.2 | All | HR=0.93 (0.85 to 1.02) | 836/2649 (31.6) | 881/2643 (33.3) | 0.132
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | All-cause mortality | 6.2 | All | 0.94 (0.80 to 1.11) | 421/1343 (31.3) | 434/1332 (32.6) | NR
Baeksgaard, 1998^125^ | Vitamin D + calcium vs. placebo | 560 IU + 1000 mg Calcium | All-cause mortality | 2 | All | 0.32 (0.01 to 8.08) | 0/65 (0.0) | 1/64 (1.6) | NR
Baron, 2015 (VCPPS)^91^ | Vitamin D vs. no vitamin D | 1000 IU + 1200 mg Calcium | All-cause mortality | 3.8 | All | 1.25 (0.58 to 2.69) | 15/1130 (1.3) | 12/1129 (1.1) | 0.56
Bischoff-Ferrari, 2020^140^ | Vitamin D alone vs. placebo | 2000 IU | All-cause mortality | 3 | All | 1.76 (0.51 to 6.07 | 7/272 (2.6) | 4/270 (1.5)
Cooper, 2003^128^ | Vitamin D + calcium vs. Placebo + calcium | 1428.6 IU + 1000 mg Calcium | All-cause mortality | 2 | All | 1.01 (0.02 to 51.47) | 0/93 (0.0) | 0/94 (0.0) | NR
Dawson-Hughes, 1991^111^ | Vitamin D + calcium vs. calcium alone | 400 IU + 377 mg Calcium | All-cause mortality | 1 | All | 1.01 (0.02 to 51.20) | 0/124 (0.0) | 0/125 (0.0)
Dukas, 2004^129^ | Vitamin D vs. placebo | 1 microgram | All-cause mortality | 0.7 | All | 0.97 (0.06 to 15.60) | 1/193 (0.5) | 1/187 (0.5) | 0.982
Gallagher, 2001 (STOP IT)^126^ | Vitamin D vs placebo | 0.5 mcg | All-cause mortality | 3 | All | 1.00 (0.06 to 16.17) | 1/123 (0.8) | 1/123 (0.8) | NR
Grady, 1991^122^ | Vitamin D vs. placebo | 0.5 mcg | All-cause mortality | 0.5 | All | 2.94 (0.12 to 73.94) | 1/50 (2.0) | 0/48 (0.0)
Komulainen, 1999 (KOS)^113^ | Vitamin D + calcium vs calcium alone | 300 IU + 93 mg Calcium | All-cause mortality | 5 | All | 0.34 (0.01 to 8.42) | 0/112 (0.0) | 1/115 (0.9)
Lappe, 2017^93^ | Calcium + vitamin D vs. placebo | 1500 mg + 2000 IU Vitamin D | All-cause mortality | 4 | All | 0.77 (0.29 to 2.08) | 7/1102 (0.6) | 9/1095 (0.8) | NR, NS
Lips, 1996^112^ | Vitamin D vs. placebo | 400 IU | All-cause mortality | 3.5 | All | 0.90 (0.75 to 1.08) | 282/1291 (21.8) | 306/1287 (23.8) | 0.20
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | All-cause mortality | 5.3 | All | HR=0.99 (0.87 to 1.12) | 485/12927 (3.8) | 493/12944 (3.8) | NR, NS
Neale, 2022 (D-Health)^143^ | Vitamin D vs. placebo | 2000 IU | All-cause mortality | 5 | All | HR=1.04 (0.93 to 1.18) | 562/10661 (5.3) | 538/10649 (5.1) | 0.47
Neale, 2022 (D-Health)^143^ | Vitamin D vs. placebo | 2000 IU | All-cause mortality | 5 | Females | HR=1.07 (0.86 to 1.32) | 170/4894 (3.5) | 159/4886 (3.3)
Neale, 2022 (D-Health)^143^ | Vitamin D vs. placebo | 2000 IU | All-cause mortality | 5 | Males | HR=1.03 (0.90 to 1.19) | 392/5767 (6.8) | 379/5763 (6.6)
Pittas, 2019 (D2d)^136^ | Vitamin D vs. placebo | 4000 IU | All-cause mortality | 3.5 | All | IRR=0.97 (0.28 to 3.35) | 5/1211 (0.4) | 5/1212 (0.4) | NR, NSD
Rake, 2020 (VIDAL)^139^ | Vitamin D vs. no vitamin D | 3333 IU | All-cause mortality | 4 | All | 1.52 (0.89 to 2.61) | 34/802 (4.2) | 23/813 (2.8) | 0.12
Salovaara, 2010 (OSTPRE-FPS)^135^ | Vitamin D + Calcium vs. no intervention | 800 IU + 1000 mg Calcium | All-cause mortality | 3 | All | 1.15 (0.55 to 2.43) | 15/1718 (0.9) | 13/1714 (0.8)
Sanders, 2010 (Vital D)^116^ | Vitamin D vs. placebo | 1370 IU | All-cause mortality | 4 | All | 0.84 (0.55 to 1.29) | 40/1131 (3.5) | 47/1125 (4.2)
Scragg, 2017 (ViDA)^116^ | Vitamin D vs. placebo | 3333 IU | All-cause mortality | 3.3 | All | 1.12 (0.78 to 1.60) | 65/2558 (2.5) | 58/2550 (2.3) | 0.53
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | All-cause mortality | 5 | All | RR=0.88 (0.74 to 1.06) | 224/1345 (16.7) | 247/1341 (18.4) | 0.18
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | All-cause mortality | 5 | Females | RR=0.91 (0.53 to 1.56) | 25/326 (7.7) | 27/323 (8.4) | 0.73
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | All-cause mortality | 5 | Males | RR=0.88 (0.73 to 1.07) | 199/1019 (19.5) | 220/1018 (21.2) | 0.19
Uusi-Rasi, 2015^121^ | Vitamin D vs. placebo | 800 IU | All-cause mortality | 2 | All | 1.00 (0.14 to 7.20) | 2/204 (1.0) | 2/205 (1.0) | NR
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | All-cause mortality | 5 | All | HR=0.81 (0.32 to 2.06) | 12/1665 (0.7) | 7/830 (0.8) | 0.66
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | All-cause mortality | 7 | All | HR=0.91 (0.83 to 1.01) | 744/18176 (4.1) | 807/18106 (4.5) | 0.07
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | All-cause mortality | 11.9 | All | HR=0.96 (0.90 to 1.03) | 1775/18176 (9.8) | 1823/18106 (10.1) | NR, NS
Wood, 2021^141^ | Vitamin D vs. Placebo | 2000 IU | All-cause mortality | 1 | All | 0.35 (0.01 to 8.56) | 0/134 (0.0) | 1/140 (0.7) | NR
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | Any cancer deaths | 6.2 | All | 0.96 (0.69 to 1.31) | 78/1306 (6.0) | 83/1332 (6.2) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Any cancer deaths | 6.2 | All | HR=0.85 (0.68 to 1.06) | 151/2649 (5.7) | 178/2643 (6.7) | 0.157
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | Any cancer deaths | 6.2 | All | 0.86 (0.63 to 1.20) | 73/1343 (5.4) | 83/1332 (6.2) | NR
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Any cancer deaths | 5.3 | All | HR=0.83 (0.67 to 1.02) | 154/12927 (1.2) | 187/12944 (1.4) | NR, NS
Neale, 2022 (D-Health)^143^ | Vitamin D vs. placebo | 2000 IU | Any cancer deaths | 5 | All | HR=1.15 (0.96 to 1.39) | 242/10661 (2.3) | 210/10649 (2.0) | 0.13
Pittas, 2019 (D2d)^136^ | Vitamin D vs. placebo | 4000 IU | Any cancer deaths | 3.5 | All | 0.20 (0.02 to 1.71) | 1/1211 (0.1) | 5/1212 (0.4)
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Any cancer deaths | 3.3 | All | HR=0.99 (0.60 to 1.64) | 30/2558 (1.2) | 30/2550 (1.2) | 0.97
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Any cancer deaths | 5 | All | RR=0.86 (0.61 to 1.20) | 63/1345 (4.7) | 72/1341 (5.4) | 0.37
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Any cancer deaths | 5 | Females | RR=0.53 (0.21 to 1.33) | 7/326 (2.1) | 13/323 (4.0) | 0.18
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Any cancer deaths | 5 | Males | RR=0.93 (0.64 to 1.34) | 56/1019 (5.5) | 59/1018 (5.8) | 0.69
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | Any cancer deaths | 5 | All | 0.50 (0.01 to 25.15) | 0/1665 (0.0) | 0/830 (0.0)
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Any cancer deaths | 7 | All | HR=0.89 (0.77 to 1.03) | 344/18176 (1.9) | 382/18106 (2.1) | 0.12
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | Breast cancer deaths | 6.2 | All | 1.79 (0.52 to 6.13) | 7/1306 (0.5) | 4/1332 (0.3) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Breast cancer deaths | 6.2 | All | 1.07 (0.50 to 2.29) | 14/2649 (0.5) | 13/2643 (0.5) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | Breast cancer deaths | 6.2 | All | 1.74 (0.51 to 5.96) | 7/1343 (0.5) | 4/1332 (0.3) | NR
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Breast cancer deaths | 7 | All | HR=0.99 (0.55 to 1.76) | 23/18176 (0.0) | 23/18106 (0.0) | NS, NR
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Cerebrovascular death | 7 | All | HR=0.89 (0.62 to 1.29) | 54 events/18176 | 60 events/18106 | NS, NR
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | CHD death | 7 | All | HR=1.01 (0.79 to 1.29) | 130/18176 (0.7) | 128/18106 (0.7) | NS, NR
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | CHD death | 11.9 | All | HR=0.99 (0.84 to 1.18) | 268/18176 (1.5) | 265/18106 (1.5) | NR, NS
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | Colorectal cancer deaths | 6.2 | All | 2.22 (0.84 to 5.86) | 13/1306 (1.0) | 6/1332 (0.5) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Colorectal cancer deaths | 6.2 | All | 1.54 (0.76 to 3.10) | 20/2649 (0.8) | 13/2643 (0.5) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | Colorectal cancer deaths | 6.2 | All | 1.16 (0.39 to 3.45) | 7/1343 (0.5) | 6/1332 (0.5) | NR
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Colorectal cancer deaths | 5 | All | RR=0.62 (0.24 to 1.60) | 7/1345 (0.5) | 11/1341 (0.8) | 0.33
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Colorectal cancer deaths | 5 | Females | 0.11 (0.01 to 2.03) | 0/326 (0.0) | 4/323 (1.2) | 0.04
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Colorectal cancer deaths | 5 | Males | RR=0.97 (0.34 to 2.78) | 7/1019 (0.7) | 7/1018 (0.7) | 0.96
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Colorectal cancer deaths | 7 | All | HR=0.82 (0.52 to 1.29) | 34/18176 (0.2) | 41/18106 (0.2) | 0.39
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Congestive heart failure deaths | 6.2 | All | HR=0.70 (0.53 to 0.91) | 89/2649 (3.4) | 127/2643 (4.8) | 0.009
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | CVD deaths | 6.2 | All | 0.99 (0.79 to 1.24) | 177/1306 (13.6) | 182/1332 (13.7) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | CVD deaths (Fatal cardiac failure, MI, or stroke only) | 6.2 | All | HR=0.87 (0.73 to 1.03) | 256/2649 (9.7) | 291/2643 (11.0) | 0.11
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | CVD deaths (Any CVD-related) | 6.2 | All | HR=0.91 (0.79 to 1.05) | 350/2649 (13.2) | 376/2643 (14.2) | 0.175
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | CVD deaths | 6.2 | All | 0.93 (0.75 to 1.17) | 173/1343 (12.9) | 182/1332 (13.7) | NR
Dukas, 2004^129^ | Vitamin D vs. placebo | 1 microgram | CVD deaths | 0.7 | All | 0.32 (0.01 to 7.94) | 0/193 (0.0) | 1/187 (0.5) | NR
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | CVD deaths | 5.3 | All | HR=1.11 (0.88 to 1.40) | 152/12927 (1.2) | 138/12944 (1.1) | NR, NS
Neale, 2022 (D-Health)^143^ | Vitamin D vs. placebo | 2000 IU | CVD deaths | 5 | All | HR=0.96 (0.72 to 1.28) | 92/10661 (0.9) | 96/10649 (0.9) | 0.77
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | CVD deaths | 3.3 | All | 1.20 (0.60 to 2.38) | 18/2558 (0.7) | 15/2550 (0.6) | NR
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | CVD deaths | 5 | All | RR=0.84 (0.65 to 1.10) | 101/1345 (7.5) | 117/1341 (8.7) | 0.20
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | CVD deaths | 5 | Females | RR=0.99 (0.43 to 2.30) | 11/326 (3.4) | 11/323 (3.4) | 0.99
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | CVD deaths | 5 | Males | RR=0.83 (0.62 to 1.10) | 90/1019 (8.8) | 106/1018 (10.4) | 0.19
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | CVD deaths | 5 | All | HR=0.85 (0.28 to 2.53) | 9/1665 (0.5) | 5/830 (0.6) | 0.77
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | CVD deaths | 7 | All | HR=0.92 (0.77 to 1.10) | 226/18176 (1.2) | 244/18106 (1.3) | NR, NS
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | CVD deaths | 11.9 | All | HR=1.03 (0.92 to 1.17) | 549/18176 (3.0) | 525/18106 (2.9) | NR, NS
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Ischemic heart disease deaths | 5 | All | RR=0.84 (0.56 to 1.27) | 42/1345 (3.1) | 49/1341 (3.7) | 0.41
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Ischemic heart disease deaths | 5 | Females | RR=0.99 (0.25 to 3.96) | 4/326 (1.2) | 4/323 (1.2) | 0.99
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Ischemic heart disease deaths | 5 | Males | RR=0.83 (0.54 to 1.28) | 38/1019 (3.7) | 45/1018 (4.4) | 0.40
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | Lung cancer deaths | 6.2 | All | 0.68 (0.34 to 1.34) | 14/1306 (1.1) | 21/1332 (1.6) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Lung cancer deaths | 6.2 | All | 0.70 (0.41 to 1.19) | 24/2649 (0.9) | 34/2643 (1.3) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | Lung cancer deaths | 6.2 | All | 0.47 (0.22 to 1.00) | 10/1343 (0.7) | 21/1332 (1.6) | NR
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Lung cancer deaths | 5 | All | RR=0.89 (0.38 to 2.09) | 10/1345 (0.7) | 11/1341 (0.8) | 0.78
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Lung cancer deaths | 5 | Females | 0.20 (0.01 to 4.12) | 0/326 (0.0) | 2/323 (0.6) | 0.16
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Lung cancer deaths | 5 | Males | RR=1.08 (0.44 to 2.65) | 10/1019 (1.0) | 9/1018 (0.9) | 0.87
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | MI, fatal | 6.2 | All | HR=0.99 (0.73 to 1.33) | 87/2649 (3.3) | 88/2643 (3.3) | 0.92
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | MI, fatal | 5.3 | All | HR=1.60 (0.84 to 3.06) | 24/12927 (0.2) | 15/12944 (0.1) | NR, NS
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Other/unknown death | 7 | All | HR=0.95 (0.77 to 1.17) | 174/18176 (1.0) | 181/18106 (1.0) | NR, NS
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | Prostate cancer deaths | 6.2 | All | 0.68 (0.11 to 4.07) | 2/1306 (0.2) | 3/1332 (0.2) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Prostate cancer deaths | 6.2 | All | 1.00 (0.32 to 3.10) | 6/2649 (0.2) | 6/2643 (0.2) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | Prostate cancer deaths | 6.2 | All | 1.32 (0.30 to 5.92) | 4/1343 (0.3) | 3/1332 (0.2) | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Stroke deaths | 6.2 | All | HR=0.99 (0.75 to 1.30) | 102/2649 (3.9) | 101/2643 (3.8) | 0.94
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Stroke deaths | 5.3 | All | HR=0.84 (0.46 to 1.54) | 19/12927 (0.1) | 23/12944 (0.2) | NR, NS
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Stroke deaths | 5 | All | RR=1.04 (0.61 to 1.77) | 28/1345 (2.1) | 26/1341 (1.9) | 0.89
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Stroke deaths | 5 | Females | RR=3.98 (0.44 to 35.64) | 4/326 (1.2) | 1/323 (0.3) | 0.22
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Stroke deaths | 5 | Males | RR=0.92 (0.52 to 1.61) | 24/1019 (2.4) | 25/1018 (2.5) | 0.77

* Studies providing estimates other than ORs display effect type.

Abbreviations: CG = Control group; CVD = Cardiovascular disease; HR = Hazard ratio; IG = Intervention group; IU = International units; KOS = Kuopio Osteoporosis Risk Factor and Prevention Study; mg = Milligrams; MI = Myocardial infarction; NR = Not reported; NS = Not significant; OSTPRE-FPS = Osteoporosis Risk Factor and Prevention Fracture Prevention Study; PODA = The physical performance, osteoporosis prevention, and vitamin D in older African Americans; RECORD = Randomised evaluation of calcium or vitamin D; RR = Risk ratio; VCPPS = Vitamin D/Calcium Polyp Prevention Study; ViDa = Vitamin D Assessment Study; VITAL = VITamin D and OmegA-3 TriaL; WHI = Women’s Health Initiative.

Appendix F Table 19 Vitamin D Cardiovascular Disease Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Angina | 3.3 | All | HR=1.43 (0.90 to 2.26) | 45/2558 (1.8) | 31/2550 (1.2) | 0.13
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Angina | 7 | All | HR=1.08 (0.94 to 1.24) | 404/18176 (2.2) | 377/18106 (2.1) | 0.30
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | CHD events | 11.9 | All | HR=1.03 (0.94 to 1.13) | 877/18176 (4.8) | 845/18106 (4.7) | NR, NS
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Congestive heart failure | 6.2 | All | HR=0.75 (0.58 to 0.97) | 102 events/2649 | 136 events/2643 | 0.027
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Coronary artery bypass graft | 5.3 | All | HR=0.75 (0.55 to 1.01) | 73/12927 (0.6) | 98/12944 (0.8) | NR, NS
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | CVD events | 6.2 | All | HR=0.92 (0.80 to 1.08) | 339 events/2649 | 363 events/2643 | 0.32
Komulainen, 1999 (KOS)^113^ | Vitamin D + calcium vs calcium alone | 300 IU + 93 mg Calcium | CVD events | 5 | All | 5.23 (0.25 to 110.08) | 2/112 (1.8) | 0/115 (0.0)
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | CVD events | 5.3 | All | HR=0.97 (0.85 to 1.12) | 396/12927 (3.1) | 409/12944 (3.2) | 0.69
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | CVD events | 5.3 | Females | HR=0.93 (0.76 to 1.14) | 173/6547 (2.6) | 186/6538 (2.8) | NR, NS
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | CVD events | 5.3 | Males | HR=1.01 (0.84 to 1.21) | 223/6380 (3.5) | 223/6406 (3.5) | NR, NS
Sanders, 2010 (Vital D)^116^ | Vitamin D vs. placebo | 1370 IU | CVD events | 4 | All | 1.31 (0.63 to 2.70) | 17/1131 (1.5) | 13/1125 (1.2)
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | CVD events | 3.3 | All | 1.07 (0.89 to 1.28) | 269/2558 (10.5) | 253/2550 (9.9) | NR
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | CVD events | 5 | All | RR=0.90 (0.77 to 1.06) | 477/1345 (35.5) | 503/1341 (37.5) | 0.22
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | CVD events | 5 | Females | RR=0.89 (0.63 to 1.27) | 85/326 (26.1) | 91/323 (28.2) | 0.52
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | CVD events | 5 | Males | RR=0.91 (0.76 to 1.09) | 392/1019 (38.5) | 412/1018 (40.5) | 0.30
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | CVD events | 5 | All | HR=0.90 (0.62 to 1.32) | 78/1665 (4.7) | 41/830 (4.9) | 0.60
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | CVD events | 7 | All | HR=1.00 (0.94 to 1.07) | 1832/18176 (10.1) | 1810/18106 (10.0) | NR
Gallagher, 2001 (STOP IT)^126^ | Vitamin D vs placebo | 0.5 mcg | Deep venous thrombosis | 3 | All | 0.33 (0.01 to 8.20) | 0/123 (0.0) | 1/123 (0.8) | NR
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Heart failure | 3.3 | All | HR=1.19 (0.84 to 1.68) | 69/2558 (2.7) | 57/2550 (2.2) | 0.34
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Heart failure | 7 | All | HR=0.95 (0.82 to 1.09) | 363/18023 (2.0) | 381/17960 (2.1) | 0.46
Manson, 2018 (VITAL)^94^ | 2000 IU | Vitamin D vs. placebo | Hospitalizations for heart failure | 5.3 | All | HR=0.93 (0.78 to 1.11) | 240/12904 (1.9) | 259/12931 (2.0) | Manson, 2018 (VITAL)^94^
Glendenning, 2012^117^ | Vitamin D vs placebo | 1666.67 IU | Ischemic heart disease | 0.75 | All | 0.47 (0.09 to 2.58) | 2/353 (0.6) | 4/333 (1.2) | 0.44
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Ischemic heart disease | 3.3 | All | HR=1.22 (0.64 to 2.33) | 21/2558 (0.8) | 17/2550 (0.7) | 0.54
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Ischemic heart disease | 5 | All | RR=0.94 (0.77 to 1.15) | 224/1345 (16.7) | 233/1341 (17.4) | 0.57
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Ischemic heart disease | 5 | Females | RR=0.79 (0.48 to 1.29) | 33/326 (10.1) | 40/323 (12.4) | 0.35
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Ischemic heart disease | 5 | Males | RR=0.98 (0.78 to 1.22) | 191/1019 (18.7) | 193/1018 (19.0) | 0.86
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | Major CVD event | 5 | Females | 1.70 (0.72 to 4.02) | 22/697 (3.2) | 7/372 (1.9) | 0.92
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | Major CVD event | 5 | Males | 0.77 (0.49 to 1.19) | 56/968 (5.8) | 34/458 (7.4) | 0.43
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | MI | 6.2 | All | HR=0.97 (0.75 to 1.26) | 114 events/2649 | 117 events/2643 | 0.84
Baron, 2015 (VCPPS)^91^ | Vitamin D vs. no vitamin D | 1000 IU + 1200 mg Calcium | MI | 3.8 | All | 1.14 (0.41 to 3.16) | 8/1130 (0.7) | 7/1129 (0.6) | 0.80
Gallagher, 2001 (STOP IT)^126^ | Vitamin D vs placebo | 0.5 mcg | MI | 3 | All | 1.34 (0.29 to 6.14) | 4/123 (3.3) | 3/123 (2.4) | NR
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | MI | 5.3 | All | HR=0.96 (0.78 to 1.19) | 169/12927 (1.3) | 176/12944 (1.4) | NR, NS
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | MI | 3.3 | All | HR=0.90 (0.54 to 1.50) | 28/2558 (1.1) | 31/2550 (1.2) | 0.68
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | MI | 5 | All | HR=0.98 (0.56 to 1.71) | 38/1665 (2.3) | 18/830 (2.2) | 0.94
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | MI | 7 | All | HR=1.05 (0.91 to 1.20) | 411/18176 (2.3) | 390/18106 (2.2) | 0.52
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | MI | 11.9 | All | HR=1.03 (0.92 to 1.15) | 659/18176 (3.6) | 637/18106 (3.5) | NR, NS
Witham, 2014^100^ | Vitamin D vs. placebo | 1667 IU | MI | 0.5 | All | . (. to .) | 0 events/34 | 1 events/34 | NR, NS
Aloia, 2018 (PODA)^103^ | Vitamin D vs. placebo | 3490 IU | Other CVD | 3 | All | 1.52 (0.42 to 5.53) | 6/130 (4.6) | 4/130 (3.1) | NR, NS
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Other CVD | 5.3 | All | HR=0.96 (0.86 to 1.08) | 536/12927 (4.1) | 558/12944 (4.3) | NR, NS
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Other CVD | 3.3 | All | HR=0.74 (0.34 to 1.61) | 11/2558 (0.4) | 15/2550 (0.6) | 0.45
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Other CVD | 3.3 | All | HR=0.93 (0.62 to 1.39) | 45/2558 (1.8) | 48/2550 (1.9) | 0.71
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Other CVD | 3.3 | All | HR=0.88 (0.51 to 1.52) | 24/2558 (0.9) | 27/2550 (1.1) | 0.65
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Percutaneous transluminal coronary angioplasty | 5.3 | All | HR=0.97 (0.79 to 1.19) | 182/12927 (1.4) | 188/12944 (1.5) | NR, NS
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Stroke | 6.2 | All | HR=1.06 (0.85 to 1.32) | 160 events/2649 | 149 events/2643 | 0.61
Baron, 2015 (VCPPS)^91^ | Vitamin D vs. no vitamin D | 1000 IU + 1200 mg Calcium | Stroke | 3.8 | All | 1.80 (0.60 to 5.40) | 9/1130 (0.8) | 5/1129 (0.4) | 0.28
Gallagher, 2001 (STOP IT)^126^ | Vitamin D vs placebo | 0.5 mcg | Stroke | 3 | All | 1.34 (0.29 to 6.14) | 4/123 (3.3) | 3/123 (2.4) | NR
Glendenning, 2012^117^ | Vitamin D vs placebo | 1666.67 IU | Stroke | 0.75 | All | 1.42 (0.24 to 8.54) | 3/353 (0.8) | 2/333 (0.6) | 1.00
Grady, 1991^122^ | Vitamin D vs. placebo | 0.5 mcg | Stroke | 0.5 | All | 0.31 (0.01 to 7.89) | 0/50 (0.0) | 1/48 (2.1)
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Stroke | 5.3 | All | HR=0.95 (0.76 to 1.20) | 141/12927 (1.1) | 149/12944 (1.2) | NR, NS
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Stroke | 3.3 | All | HR=0.95 (0.55 to 1.62) | 26/2558 (1.0) | 27/2550 (1.1) | 0.84
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Stroke | 5 | All | RR=1.02 (0.77 to 1.36) | 105/1345 (7.8) | 101/1341 (7.5) | 0.87
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Stroke | 5 | Females | RR=1.19 (0.60 to 2.37) | 19/326 (5.8) | 16/323 (5.0) | 0.62
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Stroke | 5 | Males | RR=0.99 (0.72 to 1.36) | 86/1019 (8.4) | 85/1018 (8.3) | 0.96
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | Stroke | 5 | All | HR=0.97 (0.55 to 1.72) | 36/1665 (2.2) | 18/830 (2.2) | 0.93
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Stroke | 7 | All | HR=0.95 (0.82 to 1.10) | 362/18176 (2.0) | 377/18106 (2.1) | 0.51
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Stroke | 11.9 | All | HR=1.04 (0.93 to 1.16) | 690/18176 (3.8) | 659/18106 (3.6) | NR, NS
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Stroke, Hemorrhagic | 7 | All | HR=0.84 (0.59 to 1.19) | 58/18176 (0.3) | 68/18106 (0.4) | 0.33
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Stroke, Ischemic | 7 | All | HR=0.98 (0.82 to 1.18) | 225/18176 (1.2) | 228/18106 (1.3) | 0.84
Baron, 2015 (VCPPS)^91^ | Vitamin D vs. no vitamin D | 1000 IU + 1200 mg Calcium | Transient ischemic attack | 3.8 | All | 3.00 (0.31 to 28.91) | 3/1130 (0.3) | 1/1129 (0.1) | 0.62
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Transient ischemic attack | 7 | All | HR=1.16 (0.95 to 1.42) | 213/18176 (1.2) | 182/18106 (1.0) | 0.13
Aloia, 2018 (PODA)^103^ | Vitamin D vs. placebo | 3490 IU | Vascular disorders (unspecified) | 3 | All | 2.30 (0.84 to 6.24) | 13/130 (10.0) | 6/130 (4.6) | NR, NS

* Studies providing estimates other than ORs display effect type.

Abbreviations: CG = Control group; CHD = Coronary heart disease; CVD = Cardiovascular disease; HR = Hazard ratio; IG = Intervention group; IU = International units; KOS = Kuopio Osteoporosis Risk Factor and Prevention Study; mcg = Microgram; mg = Milligram; MI = Myocardial infarction; NR = Not reported; NS = Not significant; PODA = The physical performance, osteoporosis prevention, and vitamin D in older African Americans; VCPPS = Vitamin D/Calcium Polyp Prevention Study; ViDa = Vitamin D Assessment Study; VITAL = VITamin D and OmegA-3 TriaL; WHI = Women’s Health Initiative.

Appendix F Table 20 Vitamin D Cancer Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Anal cancer | 7 | All | HR=0.20 (0.02 to 1.71) | 1/17343 (0.0) | 5/17327 (0.0) | 0.29
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Any cancer (excluding skin) | 3.3 | All | HR=0.99 (0.76 to 1.29) | 111/2558 (4.3) | 111/2550 (4.4) | 0.96
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Any cancer (excluding skin) | 5 | All | RR=1.11 (0.86 to 1.42) | 144/1345 (10.8) | 130/1341 (9.6) | 0.43
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Any cancer (excluding skin) | 5 | Females | RR=0.77 (0.39 to 1.55) | 15/326 (4.6) | 19/323 (5.9) | 0.47
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Any cancer (excluding skin) | 5 | Males | RR=1.17 (0.89 to 1.54) | 129/1019 (12.7) | 111/1018 (10.9) | 0.26
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Any cancer (invasive only) | 3.3 | All | HR=0.97 (0.76 to 1.24) | 128/2558 (5.0) | 131/2550 (5.1) | 0.80
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Any cancer incidence | 6.2 | All | HR=1.07 (0.92 to 1.25) | 338/2649 (12.8) | 315/2643 (11.9) | 0.376
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Any cancer incidence | 6.2 | All | | 369 events/2649 | 354 events/2643 | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | Any cancer incidence | 6.2 | All | 1.14 (0.90 to 1.44) | 172/1343 (12.8) | 152/1332 (11.4) | NR
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | Any cancer incidence | 6.2 | All | 1.13 (0.89 to 1.43) | 166/1306 (12.7) | 152/1332 (11.4) | NR
Baron, 2015 (VCPPS)^91^ | Vitamin D vs. no vitamin D | 1000 IU + 1200 mg Calcium | Any cancer incidence | 3.8 | All | 0.76 (0.51 to 1.12) | 47/1130 (4.2) | 61/1129 (5.4) | 0.17
Gallagher, 2001 (STOP IT)^126^ | Vitamin D vs placebo | 0.5 mcg | Any cancer incidence | 3 | All | 1.21 (0.36 to 4.08) | 6/123 (4.9) | 5/123 (4.1) | NR
Glendenning, 2012^117^ | Vitamin D vs placebo | 1666.67 IU | Any cancer incidence | 0.75 | All | 1.21 (0.60 to 2.41) | 19/353 (5.4) | 15/333 (4.5) | 0.73
Grady, 1991^122^ | Vitamin D vs. placebo | 0.5 mcg | Any cancer incidence | 0.5 | All | 2.94 (0.12 to 73.94) | 1/50 (2.0) | 0/48 (0.0)
Komulainen, 1999 (KOS)^113^ | Vitamin D + calcium vs calcium alone | 300 IU + 93 mg Calcium | Any cancer incidence | 5 | All | 0.68 (0.11 to 4.14) | 2/112 (1.8) | 3/115 (2.6)
Lappe, 2007^83^ | Calcium + vitamin D vs. placebo | 1500 mg + 1000 IU Vitamin D | Any cancer incidence | 4 | All | RR=0.40 (0.20 to 0.82) | 13/446 (2.9) | 20/288 (6.9) | 0.013
Lappe, 2017^93^ | Calcium + vitamin D vs. placebo | 1500 mg + 2000 IU Vitamin D | Any cancer incidence | 4 | All | HR=0.70 (0.47 to 1.02) | 45/1102 (4.1) | 64/1095 (5.8) | 0.06
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Any cancer incidence | 5.3 | All | HR=0.96 (0.88 to 1.06) | 793/12927 (6.1) | 824/12944 (6.4) | 0.47
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Any cancer incidence | 5.3 | Females | HR=1.02 (0.87 to 1.18) | 341/6547 (5.2) | 336/6538 (5.1) | NR, NS
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Any cancer incidence | 5.3 | Males | HR=0.93 (0.82 to 1.06) | 452/6380 (7.1) | 488/6406 (7.6) | NR, NS
Murdoch, 2012^119^ | Vitamin D vs. placebo | 3333.33 IU | Any cancer incidence | 1.5 | All | 4.08 (0.45 to 36.88) | 4/161 (2.5) | 1/161 (0.6)
Pittas, 2019^136^ | Vitamin D vs. placebo | 4000 IU | Any cancer incidence | 3.5 | All | HR=1.07 (0.70 to 1.62) | 47/1194 (3.9) | 43/1191 (3.6)
Pittas, 2019^136^ | Vitamin D vs. placebo | 4000 IU | Any cancer incidence | 3.5 | Female | HR=1.38 (0.67 to 2.85) | 18/531 (3.4) | 15/531 (2.8)
Pittas, 2019^136^ | Vitamin D vs. placebo | 4000 IU | Any cancer incidence | 3.5 | Male | HR=1.18 (0.68 to 2.03) | 28/663 (4.2) | 28/660 (4.2)
Rake, 2020 (VIDAL)^139^ | Vitamin D vs. no vitamin D | 3333 IU | Any cancer incidence | 2 | All | 0.85 (0.47 to 1.53) | 21/802 (2.6) | 25/813 (3.1) | 0.6
Sanders, 2010 (Vital D)^116^ | Vitamin D vs. placebo | 1370 IU | Any cancer incidence | 4 | All | 0.69 (0.26 to 1.83) | 7/1131 (0.6) | 10/1125 (0.9)
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Any cancer incidence | 3.3 | All | HR=1.01 (0.81 to 1.25) | 165/2558 (6.5) | 163/2550 (6.4) | 0.95
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Any cancer incidence | 3.3 | Females | HR=1.09 (0.75 to 1.59) | 57/1046 (5.4) | 53/1093 (4.8) | 0.66
Scragg, 2017 (ViDA)^92^ | Vitamin D vs. placebo | 3333 IU | Any cancer incidence | 3.3 | Males | HR=0.96 (0.74 to 1.25) | 108/1512 (7.1) | 110/1457 (7.5) | 0.76
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Any cancer incidence | 5 | All | RR=1.09 (0.86 to 1.36) | 188/1345 (14.0) | 173/1341 (12.9) | 0.47
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Any cancer incidence | 5 | Females | RR=0.95 (0.54 to 1.68) | 25/326 (7.2) | 26/323 (8.0) | 0.85
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Any cancer incidence | 5 | Males | RR=1.11 (0.87 to 1.42) | 163/1019 (16.0) | 147/1018 (14.4) | 0.39
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | Any cancer incidence | 5 | All | HR=1.04 (0.72 to 1.51) | 88/1665 (5.3) | 41/830 (4.9) | 0.83
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Any cancer incidence | 7 | All | HR=0.98 (0.90 to 1.05) | 1306/17343 (7.5) | 1333/17327 (7.7) | 0.78
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Any cancer incidence | 11.9 | All | HR=0.97 (0.92 to 1.02) | 2554/18176 (14.1) | 2617/18106 (14.5) | NR, NS
Wood, 2012^120^ | Vitamin D vs placebo | 400 IU | Any cancer incidence | 1 | All | 1.00 (0.02 to 50.88) | 0/102 (0.0) | 0/102 (0.0)
Wood, 2012^120^ | Vitamin D vs placebo | 1000 IU | Any cancer incidence | 1 | All | 3.06 (0.12 to 76.00) | 1/101 (1.0) | 0/102 (0.0)
Zitterman, 2009^115^ | Vitamin D vs. placebo | 3332 IU | Any cancer incidence | 1 | All | 0.33 (0.01 to 8.30) | 0/82 (0.0) | 1/83 (1.2)
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | Any cancer (invasive only) | 5 | Females | 1.36 (0.84 to 2.20) | 62/697 (8.9) | 25/372 (6.7) | 0.42
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | Any cancer (invasive only) | 5 | Males | 0.90 (0.60 to 1.36) | 71/968 (7.3) | 37/458 (8.1) | 0.42
Baron, 2015^91^ | Vitamin D vs. no vitamin D | 1000 IU Vitamin D + 1200 mg Calcium | Basal cell carcinoma | 3.8 | All | HR=0.96 (0.73 to 1.26) | 99/1130 (8.8) | 101/1129 (8.9) | 0.76
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Biliary tract cancer | 7 | All | HR=1.43 (0.61 to 3.35) | 13/17343 (0.1) | 9/17327 (0.1) | 0.88
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Bone, connective tissue, and skin cancer incidence (overall) | 7 | All | HR=0.96 (0.85 to 1.07) | 563/17343 (3.2) | 589/17327 (3.4) | 0.12
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Brain cancer | 7 | All | HR=1.58 (0.72 to 3.49) | 16/17343 (0.1) | 10/17327 (0.1) | 0.13
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Breast cancer | 6.2 | All | | 43 events/2649 | 37 events/2643 | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | Breast cancer | 6.2 | All | | 23 events/1343 | 16 events/1332 | NR
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | Breast cancer | 6.2 | All | | 20 events/1306 | 16 events/1332 | NR
Lappe, 2007^83^ | Calcium + vitamin D vs. placebo | 1500 mg + 1000 IU Vitamin D | Breast cancer | 4 | All | 0.40 (0.13 to 1.23) | 5/446 (1.1) | 8/288 (2.8) | NR
Lappe, 2017^93^ | Calcium + vitamin D vs. placebo | 1500 mg + 2000 IU Vitamin D | Breast cancer | 4 | All | HR=0.79 (0.43 to 1.43) | 19/1102 (1.7) | 24/1095 (2.2) | NR, NS
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Breast cancer | 5.3 | All | HR=1.02 (0.79 to 1.31) | 124/12927 (1.0) | 122/12944 (0.9) | NR, NS
Murdoch, 2012^119^ | Vitamin D vs. placebo | 3333.33 IU | Breast cancer | 1.5 | All | 3.04 (0.31 to 29.52) | 3/161 (1.9) | 1/161 (0.6)
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | Breast cancer | 5 | All | HR=0.88 (0.32 to 2.43) | 10/1665 (0.6) | 6/830 (0.7) | 0.81
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Breast cancer | 7 | All | HR=0.96 (0.86 to 1.07) | 668/18176 (0.5) | 693/18106 (0.5) | NR, NS
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Breast cancer-in situ | 11.9 | All | HR=0.82 (0.68 to 0.99) | 198/18176 (1.1) | 238/18106 (1.3) | <0.05
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Breast cancer-invasive | 11.9 | All | HR=1.04 (0.94 to 1.14) | 851/18176 (4.7) | 816/18106 (4.5) | NR, NS
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Cervical cancer | 7 | All | 12.99 (0.73 to 230.65) | 6/17343 (0.0) | 0/17327 (0.0)
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Colon cancer | 7 | All | HR=0.98 (0.76 to 1.27) | 117/17343 (0.7) | 118/17327 (0.7) | 0.72
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Colorectal cancer | 6.2 | All | | 41 events/2649 | 30 events/2643 | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | Colorectal cancer | 6.2 | All | | 17 events/1343 | 8 events/1332 | NR
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | Colorectal cancer | 6.2 | All | | 24 events/1306 | 8 events/1332 | NR
Baron, 2015 (VCPPS)^91^ | Vitamin D vs. no vitamin D | 1000 IU + 1200 mg Calcium | Colorectal cancer | 3.8 | All | 1.50 (0.25 to 8.99) | 3/1130 (0.3) | 2/1129 (0.2) | 1.00
Lappe, 2007^83^ | Calcium + vitamin D vs. placebo | 1500 mg + 1000 IU Vitamin D | Colorectal cancer | 4 | All | 0.32 (0.03 to 3.56) | 1/446 (0.2) | 2/288 (0.7) | NR
Lappe, 2017^93^ | Calcium + vitamin D vs. placebo | 1500 mg + 2000 IU Vitamin D | Colorectal cancer | 4 | All | 0.66 (0.19 to 2.35) | 4/1102 (0.4) | 6/1095 (0.5) | NR
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Colorectal cancer | 5.3 | All | HR=1.09 (0.73 to 1.62) | 51/12927 (0.4) | 47/12944 (0.4) | NR, NS
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Colorectal cancer | 5 | All | RR=1.02 (0.60 to 1.74) | 28/1345 (2.1) | 27/1341 (2.0) | 0.94
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Colorectal cancer | 5 | Females | RR=0.49 (0.12 to 1.98) | 3/326 (0.9) | 6/323 (1.9) | 0.32
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Colorectal cancer | 5 | Males | RR=1.18 (0.65 to 2.12) | 25/1019 (2.5) | 21/1018 (2.1) | 0.59
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | Colorectal cancer | 5 | All | HR=0.80 (0.19 to 3.37) | 5/1665 (0.3) | 3/830 (0.4) | 0.80
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Colorectal cancer | 7 | All | HR=1.08 (0.86 to 1.34) | 168/18176 (0.9) | 154/18106 (0.9) | 0.51
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Colorectal cancer | 11.9 | All | HR=0.95 (0.80 to 1.13) | 256/18176 (1.4) | 267/18106 (1.5) | NR, NS
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Digestive organs and peritoneum (overall), cancer | 7 | All | HR=0.94 (0.78 to 1.13) | 227/17343 (1.3) | 240/17327 (1.4) | 0.69
Lappe, 2017^93^ | Calcium + vitamin D vs. placebo | 1500 mg + 2000 IU Vitamin D | Endometrium | 4 | All | 0.66 (0.11 to 3.97) | 2/1102 (0.2) | 3/1095 (0.3) | NR
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Endometrium | 7 | All | HR=0.95 (0.71 to 1.28) | 85/17343 (0.5) | 88/17327 (0.5) | 0.56
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Esophageal cancer | 7 | All | HR=0.50 (0.19 to 1.32) | 6/17343 (0.0) | 12/17327 (0.1) | 0.09
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Eye cancer | 7 | All | HR=0.99 (0.25 to 3.94) | 4/17343 (0.0) | 4/17327 (0.0) | 0.93
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Gallbladder cancer | 7 | All | HR=1.04 (0.15 to 7.38) | 2/17343 (0.0) | 2/17327 (0.0) | 0.95
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Genital cancer | 7 | All | HR=1.07 (0.85 to 1.35) | 155/17343 (0.9) | 144/17327 (0.8) | 0.78
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Genital cancer | 7 | All | HR=2.56 (0.68 to 9.65) | 8/17343 (0.0) | 3/17327 (0.0) | 0.50
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Laryngeal cancer | 7 | All | HR=1.45 (0.24 to 8.69) | 3/17343 (0.0) | 2/17327 (0.0) | 0.77
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Leukemia | 7 | All | HR=0.97 (0.58 to 1.63) | 28/17343 (0.2) | 29/17327 (0.2) | 0.92
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Liver cancer | 7 | All | HR=0.45 (0.14 to 1.47) | 4/17343 (0.0) | 9/17327 (0.1) | 0.36
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Lung cancer | 6.2 | All | | 24 events/2649 | 32 events/2643 | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | Lung cancer | 6.2 | All | | 14 events/1343 | 18 events/1332 | NR
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | Lung cancer | 6.2 | All | | 10 events/1306 | 18 events/1332 | NR
Lappe, 2007^83^ | Calcium + vitamin D vs. placebo | 1500 mg + 1000 IU Vitamin D | Lung cancer | 4 | All | 0.21 (0.02 to 2.06) | 1/446 (0.2) | 3/288 (1.0) | NR
Lappe, 2017^93^ | Calcium + vitamin D vs. placebo | 1500 mg + 2000 IU Vitamin D | Lung cancer | 4 | All | 2.49 (0.48 to 12.87) | 5/1102 (0.5) | 2/1095 (0.2) | NR
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Lung cancer | 5 | All | RR=1.12 (0.56 to 2.25) | 17/1345 (1.3) | 15/1341 (1.1) | 0.75
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Lung cancer | 5 | Females | 0.20 (0.01 to 4.12) | 0/326 (0.0) | 2/323 (0.6) | 0.16
Trivedi, 2003^88^ | Vitamin D vs. placebo | 1095.9 IU | Lung cancer | 5 | Males | RR=1.29 (0.62 to 2.68) | 17/1019 (1.7) | 13/1018 (1.3) | 0.49
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Lung cancer | 7 | All | HR=0.86 (0.67 to 1.12) | 109/17343 (0.6) | 126/17327 (0.7) | 0.28
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Lung cancer | 11.1 | All | HR=0.91 (0.71 to 1.17) | 207/18176 (1.1) | 241/18106 (1.3) | NR, NS
Lappe, 2007^83^ | Calcium + vitamin D vs. placebo | 1500 mg + 1000 IU Vitamin D | Lymph, leukemia, myeloma | 4 | All | 0.32 (0.06 to 1.76) | 2/446 (0.4) | 4/288 (1.4) | NR
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Lymphatic and hematopoietic tissue malignant cancer | 7 | All | HR=7.00 (0.61 to 1.04) | 97/17343 (0.6) | 122/17327 (0.7) | 0.16
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Lymphoma, Hodgkin’s | 7 | All | HR=0.26 (0.06 to 1.23) | 2/17343 (0.0) | 8/17327 (0.0) | 0.14
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Lymphoma, non-Hodgkin’s | 7 | All | HR=0.72 (0.49 to 1.05) | 47/17343 (0.3) | 65/17327 (0.4) | 0.20
Lappe, 2017^93^ | Calcium + vitamin D vs. placebo | 1500 mg + 2000 IU Vitamin D | Melanoma skin cancer | 4 | All | 0.50 (0.09 to 2.71) | 2/1102 (0.2) | 4/1095 (0.4) | NR
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Melanoma skin cancer | 7 | All | HR=0.91 (0.63 to 1.32) | 54/17343 (0.3) | 60/17327 (0.3) | 0.27
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Multiple myeloma | 7 | All | HR=1.09 (0.59 to 2.01) | 21/17343 (0.1) | 20/17327 (0.1) | 0.59
Aloia, 2018 (PODA)^103^ | Vitamin D vs. placebo | 3490 IU | Neoplasms (benign, malignant, unknown) | 3 | All | 1.00 (0.38 to 2.61) | 9/130 (6.9) | 9/130 (6.9) | NR, NS
Lappe, 2017^93^ | Calcium + vitamin D vs. placebo | 1500 mg + 2000 IU Vitamin D | Neuroendocrine cancer | 4 | All | 0.50 (0.09 to 2.71) | 2/1102 (0.2) | 4/1095 (0.4) | NR
Baron, 2015 (VCPPS)^91^ | Vitamin D vs. no vitamin D | 1000 IU + 1200 mg Calcium | Non-CRC cancer incidence | 3.8 | All | 0.73 (0.49 to 1.10) | 44/1130 (3.9) | 59/1129 (5.2) | NR
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Oral cavity cancer | 7 | All | HR=1.43 (0.51 to 4.02) | 9/17343 (0.1) | 6/17327 (0.0) | 0.64
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Oral cavity, lip, pharynx cancer | 7 | All | HR=1.33 (0.61 to 2.89) | 15/17343 (0.1) | 11/17327 (0.1) | 0.34
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Other cancer | 7 | All | HR=1.86 (0.34 to 10.17) | 4/17343 (0.0) | 2/17327 (0.0) | 0.48
Lappe, 2017^93^ | Calcium + vitamin D vs. placebo | 1500 mg + 2000 IU Vitamin D | Ovarian cancer | 4 | All | 0.09 (0.00 to 1.63) | 0/1102 (0.0) | 5/1095 (0.5) | NR
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Ovarian cancer | 7 | All | HR=0.98 (0.66 to 1.44) | 50/17343 (0.3) | 51/17327 (0.3) | 0.98
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Pancreatic cancer | 7 | All | HR=0.88 (0.55 to 1.41) | 32/17343 (0.2) | 36/17327 (0.2) | 0.46
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. no vitamin D | 800 IU + 1000 mg Calcium | Prostate cancer | 6.2 | All | | 17 events/2649 | 12 events/2643 | NR
Avenell, 2012 (RECORD)^89^ | Vitamin D vs. placebo | 800 IU | Prostate cancer | 6.2 | All | | 9 events/1343 | 8 events/1332 | NR
Avenell, 2012 (RECORD)^89^ | Calcium + vitamin D vs. placebo | 1000 mg + 800 IU Vitamin D | Prostate cancer | 6.2 | All | | 8 events/1306 | 8 events/1332 | NR
Manson, 2018 (VITAL)^94^ | Vitamin D vs. placebo | 2000 IU | Prostate cancer | 5.3 | All | HR=0.88 (0.72 to 1.07) | 192/12927 (1.5) | 219/12944 (1.7) | NR, NS
Virtanen, 2022^142^ | Vitamin D vs. placebo | 1600 IU | Prostate cancer | 5 | All | HR=0.88 (0.47 to 1.79) | 26/1665 (1.6) | 13/830 (1.6) | 0.81
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Rectal cancer | 7 | All | HR=1.42 (0.88 to 2.28) | 41/17343 (0.2) | 29/17327 (0.2) | 0.16
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Renal cell carcinoma | 7 | All | HR=1.02 (0.60 to 1.74) | 28/17343 (0.2) | 27/17327 (0.2) | 0.26
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Renal cell carcinoma | 7 | All | HR=1.17 (1.02 to 1.34) | 449/18176 (2.5) | 381/18106 (2.1) | 0.02
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Respiratory tract cancer | 7 | All | HR=0.87 (0.68 to 1.12) | 114/17343 (0.7) | 130/17327 (0.8) | 0.29
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Respiratory tract cancer | 7 | All | HR=1.92 (0.17 to 21.24) | 2/17343 (0.0) | 1/17327 (0.0) | 0.71
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Retroperitoneum | 7 | All | HR=0.86 (0.26 to 2.77) | 5/17343 (0.0) | 6/17327 (0.0) | 0.89
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Small intestine | 7 | All | HR=1.88 (0.34 to 10.28) | 4/17343 (0.0) | 2/17327 (0.0) | 0.51
Baron, 2015^91^ | Vitamin D vs. no vitamin D | 1000 IU Vitamin D + 1200 mg calcium | Squamous cell carcinoma | 3.8 | All | HR=0.79 (0.49 to 1.27) | 31/1130 (2.7) | 37/1129 (3.3) | 0.33
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Thyroid cancer | 7 | All | HR=0.90 (0.49 to 1.65) | 20/17343 (0.1) | 22/17327 (0.1) | 0.97
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Tongue cancer | 7 | All | HR=0.25 (0.03 to 2.20) | 1/17343 (0.0) | 4/17327 (0.0) | 0.34
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Unknown primary site | 7 | All | HR=1.37 (0.71 to 2.66) | 21/17343 (0.1) | 15/17327 (0.1) | 0.07
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Ureteral cancer | 7 | All | 5.00 (0.24 to 104.07) | 2/17343 (0.0) | 0/17327 (0.0)
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Urinary bladder cancer | 7 | All | HR=1.49 (0.88 to 2.53) | 34/17343 (0.2) | 23/17327 (0.1) | 0.12
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Urinary organs, other | 7 | All | HR=0.48 (0.09 to 2.62) | 2/17343 (0.0) | 4/17327 (0.0) | 0.72
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Urinary tract cancer | 7 | All | HR=1.24 (0.86 to 1.78) | 66/17343 (0.4) | 53/17327 (0.3) | 0.04
Lappe, 2007^83^ | Calcium + vitamin D vs. placebo | 1500 mg + 1000 IU Vitamin D | Uterine cancer | 4 | All | 1.94 (0.08 to 47.85) | 1/446 (0.2) | 0/288 (0.0) | NR
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Uterine cancer | 7 | All | HR=1.25 (0.49 to 3.17) | 10/17343 (0.1) | 8/17327 (0.0) | 0.70
Wactawski-Wende, 2006 (WHI)^79^ | Calcium + vitamin D vs. placebo | 1000 mg + 400 IU Vitamin D | Vulvar cancer | 7 | All | HR=0.99 (0.20 to 4.91) | 3 events/17343 | 3 events/17327 | 0.97

* Studies providing estimates other than ORs display effect type.

Abbreviations: . = not reported; CG = Control group; HR = Hazard ratio; IG = Intervention group; IU = International units; KOS = Kuopio Osteoporosis Risk Factor and Prevention Study; mg = Milligram; NR = Not reported; Not significant; PODA = The physical performance, osteoporosis prevention, and vitamin D in older African Americans; RECORD = Randomised evaluation of calcium or vitamin D; RR = Risk ratio; VCPPS = Vitamin D/Calcium Polyp Prevention Study; ViDa = Vitamin D Assessment Study; VITAL = VITamin D and OmegA-3 TriaL; WHI = Women’s Health Initiative.

Appendix F Table 21 Vitamin D Adverse Event Results

Author, Year (Study) | Dose | Comparison | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%)
Bischoff-Ferrari, 2020 (DO-HEALTH)^140^ | 2000 IU | Vitamin D vs. No vitamin D | Any AE | 3 | All | 0.71 (0.38 to 1.31) | 17/1076 (1.6) | 26/1081 (2.4)
Dean, 2011^65^ | 5000 IU | Vitamin D vs. placebo | Any AE | 0.12 | All | 0.34 (0.01 to 8.47) | 0/63 (0.0) | 1/65 (1.5)
Dukas, 2004^129^ | 1 microgram | Vitamin D vs. placebo | Any AE | 0.7 | All | 0.81 (0.54 to 1.23) | 75/193 (38.9) | 82/187 (43.9)
Fedirko, 2009^114^ | 800 IU + 2 g Calcium | Vitamin D + calcium vs. placebo | Any AE | 0.5 | All | 1.00 (0.02 to 52.53) | 0/23 (0.0) | 0/23 (0.0)
Fedirko, 2009^114^ | 800 IU | Vitamin D vs. placebo | Any AE | 0.5 | All | 1.00 (0.02 to 52.53) | 0/23 (0.0) | 0/23 (0.0)
Kenny, 2003^118^ | 1000 IU + 500 mg Calcium | Vitamin D + calcium vs. calcium alone | Any AE | 0.5 | All | 1.07 (0.02 to 55.57) | 0/29 (0.0) | 0/31 (0.0)
Neale, 2022 (D-Health)^143^ | 2000 IU | Vitamin D vs. placebo | Any AE | 5 | All | IRR=0.99 (0.93 to 1.04) | 1640/10661 (15.4) | 1725/10649 (16.2)
Sanders, 2010 (Vital D)^116^ | 1370 IU | Vitamin D vs. placebo | Any AE | 4 | All | 1.14 (0.92 to 1.40) | 223/1131 (19.7) | 200/1125 (17.8)
Scragg, 2017 (ViDA)^92^ | 3333 IU | Vitamin D vs. placebo | Any AE | 3.3 | All | HR=1.03 (0.90 to 1.18) | 419/2539 (16.5) | 399/2517 (15.8)
Wood, 2021^141^ | 2000 IU | Vitamin D vs. Placebo | Any AE | 1 | All | 0.81 (0.47 to 1.40) | 32/134 (23.9) | 39/140 (27.9)
Toss, 2012^108^ | 1600 IU + 1000 mg Calcium | Vitamin D + Calcium vs. Calcium alone | Any AE: NSD between groups | 1 | All | | ./22 (.) | ./23 (.)
Witham, 2014^100^ | 1667 IU | Vitamin D vs. placebo | Any AE | 0.5 | All | | 35 events/34 | 38 events/34
Wood, 2012^120^ | 400 IU | Vitamin D vs placebo | Any AE | 1 | All | | 17 events/102 | 20 events/102
Wood, 2012^120^ | 1000 IU | Vitamin D vs placebo | Any AE | 1 | All | | 15 events/101 | 20 events/102
Baeksgaard, 1998^125^ | 560 IU + 1000 mg Calcium | Vitamin D + calcium vs. placebo | Constipation | 2 | All | 5.08 (0.24 to 107.89) | 2/65 (3.1) | 0/64 (0.0)
Baeksgaard, 1998^125^ | + 1000 mg Calcium | Vitamin D + calcium + multivitamin vs. placebo | Constipation | 2 | All | 4.71 (0.22 to 99.94) | 2/70 (2.9) | 0/64 (0.0)
Manson, 2018 (VITAL)^94^ | 2000 IU | Vitamin D vs. placebo | Constipation | 5.3 | All | HR=0.99 (0.95 to 1.03) | 5133/12927 (39.7) | 5162/12944 (39.9)
Toss, 2012^108^ | 1600 IU + 1000 mg Calcium | Vitamin D + Calcium vs. Calcium alone | Constipation | 1 | All | 1.06 (0.26 to 4.32) | 5/22 (22.7) | 5/23 (21.7)
Manson, 2018 (VITAL)^94^ | 2000 IU | Vitamin D vs. placebo | Diarrhea | 5.3 | All | HR=0.97 (0.94 to 1.01) | 5511/12927 (42.6) | 5668/12944 (43.8)
Bischoff-Ferrari, 2020 (DO-HEALTH)^140^ | 2000 IU | Vitamin D vs. No vitamin D | Disorders of mineral metabolism | 3 | All | | 1.4/ p-y | 1.2/ p-y
Gallagher, 2001 (STOP IT)^126^ | 0.5 mcg | Vitamin D vs placebo | Gallstones or cholecystitis | 3 | All | 7.17 (0.37 to 140.37) | 3/123 (2.4) | 0/123 (0.0)
Manson, 2018 (VITAL)^94^ | 2000 IU | Vitamin D vs. placebo | Gastrointestinal bleeding | 5.3 | All | HR=0.84 (0.73 to 0.98) | 341/12927 (2.6) | 403/12944 (3.1)
Avenell, 2012 (RECORD)^89^ | 800 IU + 1000 mg Calcium | Vitamin D vs. no vitamin D | Gastrointestinal symptoms | 3.75 | All | 0.93 (0.80 to 1.08) | 363/2649 (13.7) | 386/2643 (14.5)
Dawson-Hughes, 1997^124^ | 700 IU + 500 mg Calcium | Vitamin D + calcium vs. placebo | Gastrointestinal symptoms | 3 | All | 2.19 (0.40 to 12.08) | 4/187 (2.1) | 2/202 (1.0)
Witham, 2014^100^ | 1667 IU | Vitamin D vs. placebo | Gastrointestinal symptoms | 0.5 | All | | 4 events/34 | 5 events/34
Wood, 2012^120^ | 400 IU | Vitamin D vs placebo | Gastrointestinal symptoms | 1 | All | 7.21 (0.37 to 141.40) | 3/102 (2.9) | 0/102 (0.0)
Wood, 2012^120^ | 1000 IU | Vitamin D vs placebo | Gastrointestinal symptoms | 1 | All | 3.06 (0.12 to 76.00) | 1/101 (1.0) | 0/102 (0.0)
Aloia, 2018 (PODA)^103^ | 3490 IU | Vitamin D vs. placebo | GI disease | 3 | All | 0.94 (0.48 to 1.84) | 20/130 (15.4) | 21/130 (16.2)
Brisson, 2017^95^ | 1000 IU | Vitamin D vs. placebo | Kidney disease | 1 | All | 1.00 (0.02 to 50.91) | 0/96 (0.0) | 0/96 (0.0)
Brisson, 2017^95^ | 2000 IU | Vitamin D vs. placebo | Kidney disease | 1 | All | 0.97 (0.02 to 49.37) | 0/99 (0.0) | 0/96 (0.0)
Brisson, 2017^95^ | 3000 IU | Vitamin D vs. placebo | Kidney disease | 1 | All | 0.96 (0.02 to 48.87) | 0/100 (0.0) | 0/96 (0.0)
Dawson-Hughes, 1991^111^ | 400 IU + 377 mg Calcium | Vitamin D + calcium vs. calcium alone | Kidney failure or dialysis | 1 | All | 0.33 (0.01 to 8.26) | 0/124 (0.0) | 1/125 (0.8)
Manson, 2018 (VITAL)^94^ | 2000 IU | Vitamin D vs. placebo | Kidney failure or dialysis | 5.3 | All | HR=0.97 (0.72 to 1.30) | 85/12927 (0.7) | 88/12944 (0.7)
Baron, 2015 (VCPPS)^91^ | 1000 IU + 1200 mg Calcium | Vitamin D vs. no vitamin D | Kidney stones | 3.8 | All | 0.67 (0.37 to 1.21) | 19/1130 (1.7) | 28/1129 (2.5)
Bischoff-Ferrari, 2020 (DO-HEALTH)^140^ | 2000 IU | Vitamin D vs. No vitamin D | Kidney stones | 3 | All | | .7/ p-y | .7/ p-y
Dawson-Hughes, 1991^111^ | 400 IU + 377 mg Calcium | Vitamin D + calcium vs. calcium alone | Kidney stones | 1 | All | 1.01 (0.02 to 51.20) | 0/124 (0.0) | 0/125 (0.0)
Ferraro, 2017 (NHS-II)^149^ | IU | Vitamin D 1-399 vs no vitamin D | Kidney stones | 20 | All | HR=0.94 (0.84 to 1.04) | 770 events/. | 1357 events/.
Ferraro, 2017 (NHS-II)^149^ | IU | Vitamin D 400-599 vs no vitamin D | Kidney stones | 20 | All | HR=1.00 (0.89 to 1.13) | 635 events/. | 1357 events/.
Ferraro, 2017 (NHS-II)^149^ | IU | Vitamin D 600-999 vs no vitamin D | Kidney stones | 20 | All | HR=1.10 (0.92 to 1.32) | 196 events/. | 1357 events/.
Ferraro, 2017 (NHS-II)^149^ | IU | Vitamin D >=1000 vs no vitamin D | Kidney stones | 20 | All | HR=1.38 (1.03 to 1.85) | 56 events/. | 1357 events/.
Feskanich, 2002 (NHS-I)^146^ | IU | Vitamin D 1-399 IU/day vs. no vitamin D | Kidney stones | 26 | All | HR=0.89 (0.76 to 1.04) | 250 events/. | 671 events/.
Feskanich, 2002 (NHS-I)^146^ | IU | Vitamin D 400-599 IU/day vs. no vitamin D | Kidney stones | 26 | All | HR=1.09 (0.94 to 1.27) | 340 events/. | 671 events/.
Feskanich, 2002 (NHS-I)^146^ | IU | Vitamin D 600-999 IU/day vs. no vitamin D | Kidney stones | 26 | All | HR=1.05 (0.83 to 1.33) | 62 events/. | 671 events/.
Feskanich, 2002 (NHS-I)^146^ | IU | Vitamin D >=1000 IU/day vs. no vitamin D | Kidney stones | 26 | All | HR=1.03 (0.71 to 1.51) | 8 events/. | 671 events/.
Gallagher, 2001 (STOP IT)^126^ | 0.5 mcg | Vitamin D vs placebo | Kidney stones | 3 | All | 0.33 (0.01 to 8.20) | 0/123 (0.0) | 1/123 (0.8)
Lappe, 2007^83^ | 2000 IU + 1500 mg calcium | Vitamin D + calcium vs. placebo | Kidney stones | 4 | All | 0.64 (0.04 to 10.35) | 1/446 (0.2) | 1/288 (0.3)
Lappe, 2017^93^ | 2000 IU + 1500 mg calcium | Vitamin D + calcium vs. placebo | Kidney stones | 4 | All | 1.60 (0.72 to 3.54) | 16/1102 (1.4) | 10/1095 (0.9)
Manson, 2018 (VITAL)^94^ | 2000 IU | Vitamin D vs. placebo | Kidney stones | 5.3 | All | HR=1.12 (0.99 to 1.28) | 477/12927 (3.7) | 426/12944 (3.3)
Neale, 2022 (D-Health)^143^ | 2000 IU | Vitamin D vs. placebo | Kidney stones | 5 | All | IRR=1.03 (0.82 to 1.28) | 159/10661 (1.5) | 152/10649 (1.4)
Scragg, 2017 (ViDA)^92^ | 3333 IU | Vitamin D vs. placebo | Kidney stones | 3.3 | All | HR=0.62 (0.24 to 1.26) | 7/2558 (0.3) | 11/2550 (0.4)
Scragg, 2017 (ViDA)^92^ | 3333 IU | Vitamin D vs. placebo | Kidney stones | 3.3 | All | HR=0.90 (0.66 to 1.23) | 76/2539 (3.0) | 82/2517 (3.3)
Taylor, 2004 (HPFS)^150^ | IU | Vitamin D <400 IU/day vs no use | Kidney stones | 26 | All | HR=0.90 (0.78 to 1.04) | 343 events/. | 1068 events/.
Taylor, 2004 (HPFS)^150^ | IU | Vitamin D 400-599 IU/day vs no use | Kidney stones | 26 | All | HR=1.00 (0.86 to 1.15) | 426 events/. | 1068 events/.
Taylor, 2004 (HPFS)^150^ | IU | Vitamin D 600-999 IU/day vs no use | Kidney stones | 26 | All | HR=0.93 (0.74 to 1.18) | 98 events/. | 1068 events/.
Taylor, 2004 (HPFS)^150^ | IU | Vitamin D >=1000 IU/day vs no use | Kidney stones | 26 | All | HR=1.23 (0.81 to 1.86) | 28 events/. | 1068 events/.
Virtanen, 2022^142^ | 1600 IU | Vitamin D vs. placebo | Kidney stones | 5 | All | 0.64 (0.24 to 1.72) | 9/1665 (0.5) | 7/830 (0.8)
Wactawski-Wende, 2006 (WHI)^79^ | 400 IU | Vitamin D + calcium vs. placebo | Kidney stones | 7 | All | HR=1.17 (1.02 to 1.34) | 449/18176 (0.3) | 381/18106 (0.3)
Gallagher, 2001 (STOP IT)^126^ | 0.5 mcg | Vitamin D vs placebo | Major GI AEs | 3 | All | 0.89 (0.46 to 1.73) | 20/123 (16.3) | 22/123 (17.9)
Baeksgaard, 1998^125^ | 560 IU + 1000 mg Calcium | Vitamin D + calcium vs. placebo | Nausea | 2 | All | 0.19 (0.01 to 4.05) | 0/65 (0.0) | 2/64 (3.1)
Baeksgaard, 1998^125^ | + 1000 mg Calcium | Vitamin D + calcium + multivitamin vs. placebo | Nausea | 2 | All | 0.18 (0.01 to 3.76) | 0/70 (0.0) | 2/64 (3.1)
Brisson, 2017^95^ | 1000 IU | Vitamin D vs. placebo | Nausea | 1 | All | 1.29 (0.73 to 2.30) | 43/96 (44.8) | 37/96 (38.5)
Brisson, 2017^95^ | 2000 IU | Vitamin D vs. placebo | Nausea | 1 | All | 0.95 (0.53 to 1.70) | 37/99 (37.4) | 37/96 (38.5)
Brisson, 2017^95^ | 3000 IU | Vitamin D vs. placebo | Nausea | 1 | All | 0.72 (0.40 to 1.29) | 31/100 (31.0) | 37/96 (38.5)
Manson, 2018 (VITAL)^94^ | 2000 IU | Vitamin D vs. placebo | Nausea | 5.3 | All | HR=0.98 (0.94 to 1.03) | 3519/12927 (27.2) | 3589/12944 (27.7)
Aloia, 2018 (PODA)^103^ | 3490 IU | Vitamin D vs. placebo | Non-serious: General disorders and administration site conditions (NS); Hypercalcemia (NS); Hypercalciuria (NS); Infections (NS); Injury, poisoning, and procedural complications (NS); Metabolism and nutrition disorders (NS); Musculoskeletal and connective tissue disorders (NS); Nervous system disorders (NS); Responiratory, thoracic, and mediastinal disorders (NS); Surgical and medical procedures (NS) | 3 | All | | ./130 (.) | 9 events/130
Baron, 2015 (VCPPS)^91^ | 1000 IU + 1200 mg Calcium | Vitamin D vs. no vitamin D | Non-serious: Hypercalcemia (NS); Hypercreatininemia (NS) | 3 | All | | ./1115 (.) | ./1113 (.)
Brisson, 2017^95^ | 1000 IU | Vitamin D vs. placebo | Fatigue (NS), headache (NS), weakness (NS), decreasing appetite (NS), arrhythmia (NS) | 1 | All | | ./96 (.) | ./96 (.)
Brisson, 2017^95^ | 2000 IU | Vitamin D vs. placebo | Non-serious: Fatigue (NS), headache (NS), weakness (NS), decreasing appetite (NS), arrhythmia (NS) | 1 | All | | ./99 (.) | ./96 (.)
Brisson, 2017^95^ | 3000 IU | Vitamin D vs. placebo | Non-serious: Fatigue (NS), headache (NS), weakness (NS), decreasing appetite (NS), confusion (NS), arrhythmia (NS) | 1 | All | | ./100 (.) | ./96 (.)
Dukas, 2004^129^ | 1 microgram | Vitamin D vs. placebo | Non-serious: Itching (NS), skin eruption (NS) | 0.7 | All | | ./. (.) | ./. (.)
Manson, 2018 (VITAL)^94^ | 2000 IU | Vitamin D vs. placebo | Non-serious: Easy bruising (NS); hypercalcemia (NS); parathyroid condition (NS) | 5.3 | All | | ./12927 (.) | ./12944 (.)
Murdoch, 2012^119^ | 3333.33 IU | Vitamin D vs. placebo | Non-serious: NR | 1.5 | All | | 700 events/161 | 792 events/161
Scragg, 2017 (ViDA)^92^ | 3333 IU | Vitamin D vs. placebo | Non-serious: Hypercalcemia (NS) | 3.3 | All | | ./2558 (.) | ./2550 (.)
Witham, 2014^100^ | 1667 IU | Vitamin D vs. placebo | Non-serious: Dizziness (NS); Infection (NS); Musculoskeletal AE (NS) | 0.5 | All | | ./34 (.) | ./34 (.)
Manson, 2018 (VITAL)^94^ | 2000 IU | Vitamin D vs. placebo | Parathyroid condition | 5.3 | All | HR=0.81 (0.55 to 1.17) | 50/12927 (0.4) | 62/12944 (0.5)
Gallagher, 2001 (STOP IT)^126^ | 0.5 mcg | Vitamin D vs placebo | Psychiatric symptoms | 3 | All | 1.80 (0.51 to 6.30) | 7/123 (5.7) | 4/123 (3.3)
Aloia, 2018 (PODA)^103^ | 3490 IU | Vitamin D vs. placebo | Serious AEs | 3 | All | 1.00 (0.02 to 50.78) | 0/130 (0.0) | 0/130 (0.0)
Murdoch, 2012^119^ | 3333.33 IU | Vitamin D vs. placebo | Serious AEs | 1.5 | All | | 21 events/161 | 19 events/161
Neale, 2022 (D-Health)^143^ | 2000 IU | Vitamin D vs. placebo | Serious AEs | 5 | All | IRR=0.91 (0.83 to 1.00) | 747/10661 (7.0) | 798/10649 (7.5)
Pittas, 2019 (D2d)^136^ | 4000 IU | Vitamin D vs. placebo | Serious AEs | 3.5 | All | IRR=1.00 (0.83 to 1.20) | 7.53/100 p-y | 7.52/100 p-y
Rake, 2020 (VIDAL)^139^ | 3333 IU | Vitamin D vs no vitamin D | Serious AEs | 2 | All | 1.02 (0.66 to 1.57) | 46/395 (11.6) | 45/392 (11.5)
Sanders, 2010 (Vital D)^116^ | 1370 IU | Vitamin D vs. placebo | Serious AEs | 4 | All | 1.22 (0.99 to 1.50) | 244/1131 (21.6) | 207/1125 (18.4)
Wood, 2012^120^ | 400 IU | Vitamin D vs placebo | Serious AEs | 1 | All | | 7 events/102 | 4 events/102
Wood, 2012^120^ | 400 IU | Vitamin D vs placebo | Serious AEs (Pneumonia) | 1 | All | | 1 events/102 | 0 events/102
Wood, 2012^120^ | 400 IU | Vitamin D vs placebo | Serious AEs (Severe headache) | 1 | All | | 1 events/102 | 1 events/102
Wood, 2012^120^ | 400 IU | Vitamin D vs placebo | Serious AEs (Deep vein thrombosis) | 1 | All | | 0 events/102 | 1 events/102
Wood, 2012^120^ | 1000 IU | Vitamin D vs placebo | Serious AEs | 1 | All | | 8 events/101 | 4 events/102
Wood, 2012^120^ | 1000 IU | Vitamin D vs placebo | Serious AEs (Deep vein thrombosis) | 1 | All | | 0 events/102 | 1 events/102
Wood, 2012^120^ | 1000 IU | Vitamin D vs placebo | Serious AEs (Pneumonia) | 1 | All | | 0 events/102 | 0 events/102
Wood, 2021^141^ | 2000 IU | Vitamin D vs placebo | Serious AEs | 1 | All | 0.84 (0.34 to 2.11) | 9/134 (6.7) | 11/140 (7.9)
Rake, 2020 (VIDAL)^139^ | 3333 IU | Vitamin D vs no vitamin D | Serious AEs requiring hospitalization | 2 | All | 1.00 (0.74 to 1.36) | 95/802 (11.8) | 96/813 (11.8)
Manson, 2018 (VITAL)^94^ | 2000 IU | Vitamin D vs. placebo | Skin rash | 5.3 | All | HR=0.94 (0.90 to 0.99) | 3268/12927 (25.3) | 3430/12944 (26.5)
Manson, 2018 (VITAL)^94^ | 2000 IU | Vitamin D vs. placebo | Stomach upset or pain | 5.3 | All | HR=1.00 (0.96 to 1.04) | 4860/12927 (37.6) | 4870/12944 (37.6)
Brisson, 2017^95^ | 1000 IU | Vitamin D vs. placebo | Vomiting | 1 | All | 0.74 (0.31 to 1.79) | 10/96 (10.4) | 13/96 (13.5)
Brisson, 2017^95^ | 2000 IU | Vitamin D vs. placebo | Vomiting | 1 | All | 1.23 (0.56 to 2.72) | 16/99 (16.2) | 13/96 (13.5)
Brisson, 2017^95^ | 3000 IU | Vitamin D vs. placebo | Vomiting | 1 | All | 0.95 (0.42 to 2.18) | 13/100 (13.0) | 13/96 (13.5)
Aloia, 2018 (PODA)^103^ | 3490 IU | Vitamin D vs. placebo | Withdrawals due to AEs | 3 | All | 0.59 (0.14 to 2.52) | 3/130 (2.3) | 5/130 (3.8)
Brisson, 2017^95^ | 1000 IU | Vitamin D vs. placebo | Withdrawals due to AEs | 1 | All | 1.00 (0.02 to 50.91) | 0/96 (0.0) | 0/96 (0.0)
Brisson, 2017^95^ | 2000 IU | Vitamin D vs. placebo | Withdrawals due to AEs | 1 | All | 0.97 (0.02 to 49.37) | 0/99 (0.0) | 0/96 (0.0)
Brisson, 2017^95^ | 3000 IU | Vitamin D vs. placebo | Withdrawals due to AEs | 1 | All | 0.96 (0.02 to 48.87) | 0/100 (0.0) | 0/96 (0.0)
Cooper, 2003^128^ | 1428.6 IU + 1000 mg Calcium | Vitamin D + calcium vs. Placebo + calcium | Withdrawals due to AEs | 2 | All | 8.75 (1.07 to 71.45) | 8/93 (8.6) | 1/94 (1.1)
Dawson-Hughes, 1997^124^ | 700 IU + 500 mg Calcium | Vitamin D + calcium vs. placebo | Withdrawals due to AEs | 3 | All | 2.20 (0.54 to 8.92) | 6/187 (3.2) | 3/202 (1.5)
Neale, 2022 (D-Health)^143^ | 2000 IU | Vitamin D vs. placebo | Withdrawals due to AEs | 5 | All | 0.97 (0.87 to 1.08) | 698/10661 (6.5) | 720/10649 (6.8)
Pittas, 2019 (D2d)^136^ | 4000 IU | Vitamin D vs. placebo | Withdrawals due to AEs | 3.5 | All | IRR=1.23 (0.80 to 1.90) | 1.51/100 p-y | 1.22/100 p-y
Rake, 2020 (VIDAL)^139^ | 3333 IU | Vitamin D vs no vitamin D | Withdrawals due to AEs | 2 | All | 0.99 (0.34 to 2.86) | 7/395 (1.8) | 7/392 (1.8)
Wood, 2012^120^ | 400 IU | Vitamin D vs placebo | Withdrawals due to AEs | 1 | All | 2.58 (0.49 to 13.60) | 5/102 (4.9) | 2/102 (2.0)
Wood, 2012^120^ | 1000 IU | Vitamin D vs placebo | Withdrawals due to AEs | 1 | All | 2.06 (0.37 to 11.52) | 4/101 (4.0) | 2/102 (2.0)

* Studies providing estimates other than ORs display effect type.

Abbreviations: AE = Adverse event; CG = Control group; GI = Gastrointestinal; HPFS = Health Professionals Follow-up Study; HR = Hazard ratio; IG = Intervention group; IU = International units; NHS = Nurses’ Health Study; NS = Not significant; NSD = No significant difference; PODA = The physical performance, osteoporosis prevention, and vitamin D in older African Americans; RECORD = Randomised evaluation of calcium or vitamin D; RR = Risk ratio; VCPPS = Vitamin D/Calcium Polyp Prevention Study; ViDa = Vitamin D Assessment Study; VITAL = VITamin D and OmegA-3 TriaL.

Appendix F Table 22 Summary of Results for Studies of Vitamin E Use

Author, Year (Study) | Quality Rating | Study Design | Study N^*^ | Supplement (daily dose) | ACM | CVD | Cancer | Harms
ATBC Study Group, 1994 (ATBC)^76^ | Good | RCT | 29133 | Vitamin E (50 mg) | ↔ | ↔? | ↓? (prostate); ↔ (other) | ↔? (hosp. for pneumonia)
de Gaetano, 2001 (PPP)^104^ | Good | RCT | 4495 | Vitamin E (300 mg) | ↔ | ↔ | ↔ | ↔ (any AE); ? (epistaxis, GI bleed, intracranial bleed, GI disease)
Hodis, 2002 (VEAPS)^127^ | Fair | RCT | 353 | Vitamin E (400 IU) | ? | ? | ? | NR
Lee, 2005 (WHS)^74^ | Good | RCT | 39876 | Vitamin E (300 IU) | ↔ | ↔ | ↔ | ↔ (epistaxis, trivial increase in risk)
Lippman, 2009 (SELECT)^80^ | Good | RCT | 34888 | Vitamin E (400 IU) | ↔ | ↔ | ↔ | ↔ (dermatitis, trivial increase in risk); ↔ (fatigue, halitosis, nail changes)
Lippman, 2009 (SELECT)^80^ | Good | RCT | 34888 | Selenium (200 mcg) + Vitamin E (400 IU) | ↔ | ↔ | ↔ | ↔ (dermatitis)
Magliano, 2006 (MAVET)^132^ | Fair | RCT | 409 | Vitamin E (500 IU) | ↔? | ? | ? | NR
McNeil, 2004 (VECAT)^130^ | Good | RCT | 1193 | Vitamin E (500 IU) | ↔? | NR | NR | ↔ (serious AE, AE WD, any AE, non-cataract ophthalmic events)
Salonen, 2000 (ASAP)^77^ | Fair | RCT | 520 | Vitamin E (182 mg) | ? | ? | NR | ↔? (AE WD)
Salonen, 2000 (ASAP)^77^ | Fair | RCT | 520 | Vitamin C (500 mg) + Vitamin E (182 mg) | ? | ? | NR | ↔? (AE WD)
Sesso, 2008 (PHS-II)^81^ | Good | RCT | 14641 | Vitamin E (200 IU) | ↔ | ↔ | ↔ | ↔ (epistaxis, skin rash, trivial increase in risk; ↔ (bruising, hematuria)
Feskanich, 2002 (NHS-I)^146^ | Fair | Cohort | 121700 | Vitamin E (NR, reported by duration of use) | NR | NR | NR | ↔ (cataract)
Zheng Selin, 2013 (COSM)^148^ | Fair | Cohort | 27343 | Vitamin E (NR) | NR | NR | NR | ↑ (cataract)

* Includes only participants randomized to an intervention group assigned to take vitamin E.

Abbreviations: ACM = All-cause mortality; AE = Adverse event; ASAP = Antioxidant Supplementation in Atherosclerosis Prevention; ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; COSM = Cohort of Swedish Men; CVD = Cardiovascular disease; GI = Gastrointestinal; hosp. = Hospitalization; IU = International unit; MAVET = Melbourne Atherosclerosis Vitamin E Trial; mcg = Microgram; mg = Milligram; NHS-I = Nurses’ Health Study I; NR = Not reported; PHS-II = Physicians’ Health Study II; PPP = Primary Prevention Project; RCT = Randomized controlled trial; SELECT = Selenium and Vitamin E Cancer Prevention Trial; VEAPS = Vitamin E Atherosclerosis Progression Study; VECAT = Vitamin E, Cataract and Age-related Maculopathy Trial; WD = Withdrawal; WHS = Women’s Health Study.

↑ Likely non-trivial increase in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

↑? Possible non-trivial increase in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↔ Evidence of no to minimal group differences (e.g., few to no statistically significant findings with reasonably precise estimates [e.g., >~20 events in all treatment arms])

↔? Limited evidence of no to minimal group differences (e.g., few to no statistically significant findings, but imprecise estimates/side CIs).

↓? Possible non-trivial decrease in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↓ Likely non-trivial decrease in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

? Insufficient evidence to evaluate (e.g., very few [e.g., <10] events).

Judgement for symbols based on totality of evidence for each study, considering statistical and clinical significance.

Appendix F Table 23 Vitamin E Meta-Analysis Results: Results of Meta-Analyses by Outcome, Primary Analysis Listed First for Each Outcome, Followed by Sensitivity Analyses

Outcome | Model/Analysis | Pooled OR (95% CI) | No. studies | N analyzed | I^2^, % | Tau^2^
All-cause mortality | MH | 1.02 (0.97 to 1.07) | 9 | 107,772 | NA | NA
All-cause mortality | Peto | 1.02 (0.97 to 1.07) | 9 | 107,772 | 0 | .00
All-cause mortality | Full ascert. (MH) | 1.02 (0.95 to 1.09) | 5 | 77,638 | NA | NA
CVD mortality | Peto | 0.88 (0.74 to 1.04) | 6 | 77,114 | 29.5 | .01
CVD mortality | MH | 0.90 (0.80 to 1.02) | 6 | 77,114 | NA | NA
CVD mortality | Full ascert. (Peto) | 0.90 (0.80 to 1.02) | 4 | 76,445 | NA | NA
Composite CVD event | MH | 0.96 (0.90 to 1.04) | 4 | 62,136 | NA | NA
Composite CVD event | Peto | 0.96 (0.90 to 1.04) | 4 | 62,136 | 0 | .00
Composite CVD event | Full ascert. (MH) | 0.96 (0.90 to 1.04) | 3 | 61,804 | NA | NA
MI | Peto | 0.94 (0.82 to 1.06) | 4 | 59,344 | 0 | .00
MI | MH | 0.94 (0.82 to 1.06) | 4 | 59,344 | NA | NA
MI | Full ascert. (Peto) | 0.93 (0.82 to 1.06) | 3 | 59,012 | NA | NA
Stroke | Peto | 0.97 (0.87 to 1.10) | 5 | 76,777 | 0 | .00
Stroke | MH | 0.97 (0.87 to 1.10) | 5 | 76,777 | NA | NA
Stroke | Full ascert. (Peto) | 0.98 (0.87 to 1.10) | 4 | 76,445 | NA | NA
Cancer mortality | MH | 1.05 (0.94 to 1.16) | 4 | 72,359 | NA | NA
Cancer mortality | Peto | 1.01 (0.85 to 1.20) | 4 | 72,359 | 47.9 | .01
Cancer mortality | Full ascert. (MH) | 1.06 (0.95 to 1.18) | 3 | 71,950 | NA | NA
Any cancer incidence | MH | 1.02 (0.98 to 1.08) | 5 | 76,777 | NA | NA
Any cancer incidence | Peto | 1.02 (0.98 to 1.08) | 5 | 76,777 | 0 | .00
Any cancer incidence | Full ascert. (MH) | 1.02 (0.97 to 1.08) | 3 | 71,950 | NA | NA
Colorectal cancer | Peto | 0.98 (0.82 to 1.16) | 3 | 71,950 | 0 | .00
Colorectal cancer | MH | 0.98 (0.82 to 1.16) | 3 | 71,950 | NA | NA
Colorectal cancer | Full ascert. (Peto) | 0.98 (0.82 to 1.16) | 3 | 71,950 | NA | NA
Lung cancer | Peto | 1.00 (0.87 to 1.14) | 4 | 86,523 | 0 | .00
Lung cancer | MH | 1.00 (0.87 to 1.14) | 4 | 86,523 | NA | NA
Lung cancer | Full ascert. (Peto)^*^ | 1.00 (0.87 to 1.14) | 4 | 86,523 | NA | NA
Breast cancer | Peto | 1.00 (0.90 to 1.13) | 2 | 40,208 | 0 | .00
Breast cancer | MH | 1.00 (0.90 to 1.13) | 2 | 40,208 | NA | NA
Breast cancer | Full ascert. (Peto) | 1.00 (0.90 to 1.12) | 1 | 86,523 | NA | NA
Prostate cancer | Peto | 0.95 (0.72 to 1.25) | 4 | 46979 | 80.1 | .05
Prostate cancer | MH | 1.01 (0.92 to 1.11) | 4 | 46979 | NA | NA
Prostate cancer | Full ascert. (Peto) | 1.01 (0.92 to 1.11) | 3 | 46,647 | NA | NA

* Full studies with full ascertainment of the outcome.

Abbreviations: CI = Confidence interval; CVD = Cardiovascular disease; MH = Mantel-Haenszel common effects model; MI = Myocardial infarction; NA = Not applicable; OR = Odds ratio; Peto = Peto odds ratio random effects REML model; REML-KH = Random effects restricted maximum likelihood model with the Knapp-Hartung adjustment.

Appendix F Table 24 Vitamin E Mortality Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | All-cause mortality | 24.1 | All | 1.03 (0.96 to 1.10) | 5065/7286 (69.5) | 5022/7287 (68.9) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | All-cause mortality | 6.1 | All | 1.02 (0.95 to 1.09) | 1800/14564 (12.4) | 1770/14569 (12.1) | 0.6
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | All-cause mortality | 11 | All | 0.99 (0.93 to 1.05) | 2993/14564 (20.6) | 3019/14569 (20.7) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | All-cause mortality | 14 | All | 1.01 (0.96 to 1.06) | 4453/14564 (30.6) | 4415/14569 (30.3) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | All-cause mortality | 16 | All | 1.01 (0.96 to 1.06) | 5433/14564 (37.3) | 5398/14569 (37.1) | NR
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | All-cause mortality | 4 | All | RR=1.07 (0.77 to 1.49) | 72/2231 (3.2) | 68/2264 (3.0) | NS
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | All-cause mortality | 3 | All | 2.11 (0.19 to 23.52) | 2/162 (1.2) | 1/170 (0.6) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | All-cause mortality | 10 | All | RR=1.04 (0.93 to 1.16) | 636/19937 (3.2) | 615/19939 (3.1) | .53
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | All-cause mortality | 5.5 | All | HR=0.94 (0.77 to 1.13) | 359/8703 (4.1) | 382/8696 (4.4) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | All-cause mortality | 7.1 | All | HR=0.96 (0.82 to 1.12) | 542/8702 (6.2) | 564/8696 (6.5) | 0.47
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | All-cause mortality | 5.5 | All | HR=0.93 (0.77 to 1.13) | 358/8737 (4.1) | 382/8696 (4.4) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | All-cause mortality | 7.1 | All | HR=1.01 (0.86 to 1.17) | 571/8737 (6.5) | 564/8696 (6.5) | 0.91
Magliano, 2006 (MAVET)^132^ | Vitamin E vs. placebo | 500 IU | All-cause mortality | 4 | All | 0.51 (0.22 to 1.16) | 9/205 (4.4) | 17/204 (8.3) | 0.10
McNeil, 2004 (VECAT)^130^ | Vitamin E vs. placebo | 500 IU | All-cause mortality | 4 | All | 1.86 (0.88 to 3.91) | 20/595 (3.4) | 11/598 (1.8) | 0.10
Salonen, 2000 (ASAP)^77^ | Vitamin C + vitamin E vs. placebo | 500 mg + 544 IU Vitamin E | All-cause mortality | 3 | All | 1.00 (0.06 to 16.16) | 1/130 (0.8) | 1/130 (0.8)
Salonen, 2000 (ASAP)^77^ | Vitamin E vs. Placebo | 182 mg | All-cause mortality | 3 | All | 3.05 (0.31 to 29.68) | 3/130 (2.3) | 1/130 (0.8)
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | All-cause mortality | 8 | All | HR=1.07 (0.97 to 1.18) | 841/7315 (11.5) | 820/7326 (11.2) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Any cancer deaths | 10 | All | RR=1.12 (0.95 to 1.32) | 308/19937 (1.5) | 275/19939 (1.4) | 0.17
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Any cancer deaths | 5.5 | All | HR=0.93 (0.67 to 1.30) | 117/8703 (1.3) | 125/8696 (1.4) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Any cancer deaths | 5.5 | All | HR=0.84 (0.60 to 1.18) | 106/8737 (1.2) | 125/8696 (1.4) | NR, NS
Magliano, 2006 (MAVET)^132^ | Vitamin E vs. placebo | 500 IU | Any cancer deaths | 4 | All | 0.35 (0.11 to 1.12) | 4/205 (2.0) | 11/204 (5.4) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Any cancer deaths | 8 | All | HR=1.13 (0.95 to 1.34) | 273/7315 (3.7) | 250/7326 (3.4) | NR
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Bladder cancer deaths | 7.1 | All | 0.50 (0.12 to 2.00) | 3/8703 (0.0) | 6/8696 (0.1) | NR
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Bladder cancer deaths | 7.1 | All | 1.00 (0.32 to 3.09) | 6/8737 (0.1) | 6/8696 (0.1) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Chronic liver disease deaths | 22.1 | All | HR=0.97 (0.68 to 1.40) | 57/7280 (0.8) | 59/7282 (0.8) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Chronic liver disease deaths | 22.1 | All | 0.96 (0.74 to 1.24) | 116/14549 (0.8) | 121/14556 (0.8)
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Colorectal cancer deaths | 6.1 | All | RR=0.92 (0.51 to 1.64) | 22/14564 (0.2) | 24/14569 (0.2) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Colorectal cancer deaths | 5.5 | All | HR=1.49 (0.52 to 4.28) | 15/8703 (0.2) | 10/8696 (0.1) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Colorectal cancer deaths | 5.5 | All | HR=1.30 (0.44 to 3.83) | 13/8737 (0.1) | 10/8696 (0.1) | NR, NS
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Colorectal cancer deaths | 8 | All | HR=0.68 (0.39 to 1.18) | 21/7315 (0.3) | 32/7326 (0.4) | NR
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | CVD deaths | 4 | All | RR=0.86 (0.49 to 1.52) | 22/2231 (1.0) | 26/2264 (1.1) | NS
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | CVD deaths | 10 | All | RR=0.76 (0.59 to 0.98) | 106/19937 (0.5) | 140/19939 (0.7) | 0.03
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | CVD deaths | 5.5 | All | HR=0.82 (0.60 to 1.13) | 117/8703 (1.3) | 142/8696 (1.6) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | CVD deaths | 5.5 | All | HR=0.84 (0.61 to 1.15) | 119/8737 (1.4) | 142/8696 (1.6) | NR, NS
Magliano, 2006 (MAVET)^132^ | Vitamin E vs. placebo | 500 IU | CVD deaths | 4 | All | 0.49 (0.09 to 2.72) | 2/205 (1.0) | 4/204 (2.0) | NR
Salonen, 2000 (ASAP)^77^ | Vitamin C + vitamin E vs. placebo | 500 mg + 544 IU Vitamin E | CVD deaths | 3 | All | 1.00 (0.06 to 16.16) | 1/130 (0.8) | 1/130 (0.8)
Salonen, 2000 (ASAP)^77^ | Vitamin E vs. Placebo | 182 mg | CVD deaths | 3 | All | 1.00 (0.06 to 16.16) | 1/130 (0.8) | 1/130 (0.8)
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | CVD deaths | 8 | All | HR=1.07 (0.90 to 1.28) | 258/7315 (3.5) | 251/7326 (3.4) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Esophageal cancer deaths | 6.1 | All | RR=0.50 (0.13 to 2.00) | 3/7286 (0.0) | 6/7287 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Esophageal cancer deaths | 6.1 | All | RR=0.50 (0.17 to 1.47) | 5/14564 (0.0) | 10/14569 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Hemorrhagic stroke deaths | 6.1 | All | 1.50 (1.03 to 2.20) | 66/14564 (0.5) | 44/14569 (0.3) | NR
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Hemorrhagic stroke deaths | 5.5 | All | HR=1.49 (0.46 to 4.84) | 12/8703 (0.1) | 8/8696 (0.1) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Hemorrhagic stroke deaths | 5.5 | All | HR=1.12 (0.32 to 3.92) | 9/8737 (0.1) | 8/8696 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Ischemic heart disease deaths | 6.1 | All | 0.94 (0.84 to 1.06) | 602/14564 (4.1) | 637/14569 (4.4) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Ischemic stroke deaths | 6.1 | All | 0.84 (0.59 to 1.19) | 56/14564 (0.4) | 67/14569 (0.5) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Laryngeal cancer deaths | 6.1 | All | RR=0.67 (0.11 to 4.00) | 2/7286 (0.0) | 3/7287 (0.0) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Lung cancer deaths | 6.1 | All | 1.02 (0.87 to 1.21) | 285/14564 (2.0) | 279/14569 (1.9) | NR
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Lung cancer deaths | 5.5 | All | HR=0.95 (0.53 to 1.69) | 39/8703 (0.4) | 41/8696 (0.5) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Lung cancer deaths | 5.5 | All | HR=0.92 (0.52 to 1.65) | 38/8737 (0.4) | 41/8696 (0.5) | NR, NS
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Lung cancer deaths | 8 | All | HR=1.05 (0.69 to 1.60) | 44/7315 (0.6) | 43/7326 (0.6) | NR
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | MI, fatal | 3 | All | 1.05 (0.07 to 16.92) | 1/162 (0.6) | 1/170 (0.6) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | MI, fatal | 10 | All | RR=0.86 (0.40 to 1.85) | 12/19937 (0.1) | 14/19939 (0.1) | 0.70
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | MI, fatal | 8 | All | HR=0.75 (0.43 to 1.31) | 22/7315 (0.3) | 30/7326 (0.4) | NR
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | Non-CVD deaths | 4 | All | RR=1.21 (0.80 to 1.81) | 50/2231 (2.2) | 42/2264 (1.9) | NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Oral cavity/pharynx cancer deaths | 6.1 | All | RR=2.51 (0.49 to 12.92) | 5/7286 (0.1) | 2/7287 (0.0) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Oral cavity/pharynx cancer deaths | 6.1 | All | RR=1.84 (0.68 to 4.97) | 11/14564 (0.1) | 6/14569 (0.0) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Other CVD deaths | 6.1 | All | 1.06 (0.83 to 1.36) | 129/14564 (0.9) | 122/14569 (0.8) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Other CVD deaths | 10 | All | 0.59 (0.34 to 1.02) | 20/19937 (0.1) | 34/19939 (0.2)
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Pancreatic cancer deaths | 6.1 | All | RR=1.11 (0.72 to 1.72) | 49/14564 (0.3) | 34/14569 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Prostate cancer deaths | 6.1 | All | 0.61 (0.29 to 1.29) | 11/7286 (0.2) | 18/7287 (0.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Prostate cancer deaths | 6.1 | All | 0.59 (0.35 to 0.99) | 23/14564 (0.2) | 39/14569 (0.3) | <0.05
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Prostate cancer deaths | 5.5 | All | 1.00 (0.02 to 50.36) | 0/8703 (0.0) | 0/8696 (0.0) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Prostate cancer deaths | 5.5 | All | 1.00 (0.02 to 50.17) | 0/8737 (0.0) | 0/8696 (0.0) | NR, NS
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Prostate cancer deaths | 8 | All | HR=1.01 (0.64 to 1.58) | 37/7315 (0.5) | 39/7326 (0.5) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Renal cell carcinoma deaths | 6.1 | All | 0.79 (0.36 to 1.73) | 11/7286 (0.2) | 14/7287 (0.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Renal cell carcinoma deaths | 6.1 | All | 1.05 (0.57 to 1.94) | 21/14564 (0.1) | 20/14569 (0.1) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Stroke deaths | 10 | All | RR=0.88 (0.49 to 1.57) | 21/19937 (0.1) | 24/19939 (0.1) | 0.66
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Stroke deaths | 8 | All | HR=0.86 (0.58 to 1.27) | 45/7315 (0.6) | 56/7326 (0.8) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Sudden death | 10 | All | 0.74 (0.49 to 1.13) | 38/19937 (0.2) | 51/19939 (0.3)
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Urothelial cancer deaths | 6.1 | All | 1.20 (0.37 to 3.93) | 6/7286 (0.1) | 5/7287 (0.1) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Urothelial cancer deaths | 6.1 | All | 1.40 (0.62 to 3.15) | 14/14564 (0.1) | 10/14569 (0.1) | NR

* Studies providing estimates other than ORs display effect type.

Abbreviations: ASAP = Antioxidant Supplementation in Atherosclerosis Prevention; ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CG = Control group; CVD = Cardiovascular disease; HR = Hazard ratio; IG = Intervention group; IU = International units; MAVET = Melbourne Atherosclerosis Vitamin E Trial; mcg = Micrograms; mg = Milligrams; MI = Myocardial infarction; NR = Not reported; NS = Not significant; PHS-II = Physicians’ Health Study II; PPP = Primary Prevention Project; RR = Risk ratio; SELECT = Selenium and Vitamin E Cancer Prevention Trial; VEAPS = Vitamin E Atherosclerosis Progression Study; WHS = Women’s Health Study.

Appendix F Table 25 Vitamin E Cardiovascular Disease Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Congestive heart failure | 10 | All | HR=0.91 (0.70 to 1.19) | 106/19913 (0.5) | 114/19902 (0.6) | 0.48
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Congestive heart failure | 8 | All | HR=1.02 (0.87 to 1.20) | 289/7315 (4.0) | 294/7326 (4.0) | NR
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | CVD events | 4 | All | RR=1.07 (0.74 to 1.56) | 56/2231 (2.5) | 53/2264 (2.3) | NS
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | CVD events | 3 | All | 0.83 (0.32 to 2.16) | 8/162 (4.9) | 10/170 (5.9) | 0.81
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | CVD events | 10 | All | RR=0.93 (0.82 to 1.05) | 482/19937 (2.4) | 517/19939 (2.6) | 0.26
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | CVD events | 5.5 | All | RR=0.99 (0.89 to 1.10) | 1041/8703 (12.0) | 1050/8696 (12.1) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | CVD events | 7.1 | All | HR=0.97 (0.86 to 1.09) | 943/8702 (10.8) | 969/8696 (11.1) | 0.51
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | CVD events | 5.5 | All | RR=0.98 (0.88 to 1.09) | 1034/8737 (11.8) | 1050/8696 (12.1) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | CVD events | 7.1 | All | HR=0.93 (0.83 to 1.05) | 909/8737 (10.4) | 969/8696 (11.1) | 0.11
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | CVD events | 8 | All | HR=1.01 (0.90 to 1.13) | 620 events/7315 | 625 events/7326 | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Heart failure | 10 | All | HR=1.25 (0.83 to 1.89) | 53/19913 (0.3) | 42/19902 (0.2) | 0.28
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Heart failure | 10 | All | HR=0.59 (0.37 to 0.92) | 30/19913 (0.1) | 51/19902 (0.3) | 0.02
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | MI | 4 | All | RR=0.89 (0.52 to 1.58) | 22/2231 (1.0) | 25/2264 (1.1) | NS
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | MI | 3 | All | 1.32 (0.35 to 5.01) | 5/162 (3.1) | 4/170 (2.4) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | MI | 10 | All | RR=1.01 (0.82 to 1.23) | 196/19937 (1.0) | 195/19939 (1.0) | 0.96
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | MI | 8 | All | HR=0.90 (0.75 to 1.07) | 240/7315 (3.3) | 271/7326 (3.7) | NR
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | MI, nonfatal | 4 | All | RR=1.01 (0.56 to 2.03) | 19/2231 (0.8) | 18/2264 (0.8) | NS
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | MI, nonfatal | 3 | All | 1.41 (0.31 to 6.40) | 4/162 (2.5) | 3/170 (1.8) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | MI, nonfatal | 10 | All | RR=1.02 (0.83 to 1.25) | 184/19937 (0.9) | 181/19939 (0.9) | 0.87
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | Other CVD | 4 | All | RR=0.94 (0.77 to 1.16) | 158/2231 (7.1) | 170/2264 (7.5) | NS
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | Peripheral artery disease | 4 | All | RR=0.54 (0.30 to 0.99) | 16/2231 (0.7) | 30/2264 (1.3) | 0.043
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | Stroke | 4 | All | RR=1.24 (0.66 to 2.31) | 22/2231 (1.0) | 18/2264 (0.8) | NS
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | Stroke | 3 | All | 0.21 (0.01 to 4.35) | 0/162 (0.0) | 2/170 (1.2) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Stroke | 10 | All | RR=0.98 (0.82 to 1.17) | 241/19937 (1.2) | 246/19939 (1.2) | 0.82
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Stroke | 5.5 | All | 1.18 (0.85 to 1.64) | 79/8703 (0.9) | 67/8696 (0.8)
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Stroke | 8 | All | HR=1.07 (0.89 to 1.29) | 237/7315 (3.2) | 227/7326 (3.1) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Stroke, Hemorrhagic | 10 | All | RR=0.92 (0.61 to 1.38) | 44/19937 (0.2) | 48/19939 (0.2) | 0.68
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Stroke, Hemorrhagic | 5.5 | All | RR=1.09 (0.37 to 3.19) | 12/8703 (0.1) | 11/8696 (0.1) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Stroke, Hemorrhagic | 5.5 | All | RR=0.63 (0.18 to 2.20) | 7/8737 (0.1) | 11/8696 (0.1) | NR, NS
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Stroke, Hemorrhagic | 8 | All | HR=1.74 (1.04 to 2.91) | 39/7315 (0.5) | 23/7326 (0.3) | <0.05
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Stroke, Ischemic | 10 | All | RR=0.99 (0.81 to 1.20) | 194/19937 (1.0) | 197/19939 (1.1) | 0.88
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Stroke, Ischemic | 5.5 | All | RR=1.20 (0.75 to 1.90) | 67/8703 (0.8) | 56/8696 (0.6) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Stroke, Ischemic | 5.5 | All | RR=0.87 (0.53 to 1.44) | 49/8737 (0.6) | 56/8696 (0.6) | NR, NS
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Stroke, Ischemic | 8 | All | HR=1.00 (0.82 to 1.22) | 191/7315 (2.6) | 196/7326 (2.7) | NR
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | Stroke, nonfatal | 4 | All | RR=1.56 (0.77 to 3.13) | 20/2231 (0.9) | 13/2264 (0.6) | NS
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Stroke, nonfatal | 10 | All | RR=0.99 (0.82 to 1.19) | 220/19937 (1.1) | 222/19939 (1.1) | 0.93
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Stroke, nonfatal | 5.5 | All | 1.08 (0.81 to 1.43) | 99/8703 (1.1) | 92/8696 (1.1) | NR
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Stroke, nonfatal | 5.5 | All | 0.76 (0.55 to 1.03) | 70/8737 (0.8) | 92/8696 (1.1) | NR
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | Transient ischemic attack | 4 | All | RR=0.96 (0.60 to 1.53) | 33/2231 (1.5) | 35/2264 (1.5) | NS

* Studies providing estimates other than ORs display effect type.

Abbreviations: CG = Control group; CVD = Cardiovascular disease; HR = Hazard ratio; IG = Intervention group; IU = International units; mcg = Microgram; mg = Milligram; MI = Myocardial infarction; NR = Not reported; NS = Not significant; PHS-II = Physicians’ Health Study II; PPP = Primary Prevention Project; RR = Risk ratio; SELECT = Selenium and Vitamin E Cancer Prevention Trial; VEAPS = Vitamin E Atherosclerosis Progression Study; WHS = Women’s Health Study.

Appendix F Table 26 Vitamin E Cancer Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
de Gaetano, 2001 (PPP)^104^ | Vitamin E vs. no vitamin E | 300 mg | Any cancer incidence | 4 | All | 1.09 (0.80 to 1.49) | 86/2231 (3.9) | 80/2264 (3.5) | NR
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | Any cancer incidence | 3 | All | 1.94 (0.64 to 5.92) | 9/162 (5.6) | 5/170 (2.9) | 0.17
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Any cancer incidence | 10 | All | RR=1.01 (0.94 to 1.08) | 1437/19937 (7.2) | 1428/19939 (7.2) | 0.87
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Any cancer incidence | 5.5 | All | HR=1.03 (0.91 to 1.17) | 856/8737 (9.8) | 824/8696 (9.5) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Any cancer incidence | 7.1 | All | HR=1.07 (0.96 to 1.19) | 1190/8737 (13.6) | 1108/8696 (12.7) | 0.13
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Any cancer incidence | 8 | All | HR=1.04 (0.95 to 1.13) | 984/7315 (13.5) | 959/7326 (13.1) | NR
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | Bile duct cancer | 3 | All | 3.17 (0.13 to 78.31) | 1/162 (0.6) | 0/170 (0.0) | NR
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | Bladder cancer | 3 | All | 0.35 (0.01 to 8.60) | 0/162 (0.0) | 1/170 (0.6) | NR
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | Breast cancer | 3 | All | 2.11 (0.19 to 23.52) | 2/162 (1.2) | 1/170 (0.6) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Breast cancer | 10 | All | RR=1.00 (0.90 to 1.12) | 616/19937 (3.1) | 614/19939 (3.1) | 0.95
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Colorectal cancer | 24.1 | All | 0.98 (0.80 to 1.19) | 204/7286 (2.8) | 209/7287 (2.9) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Colorectal cancer | 8 | All | RR=0.78 (0.55 to 1.09) | 59/14564 (0.4) | 76/14569 (0.5) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Colorectal cancer | 11 | All | 0.92 (0.71 to 1.20) | 109/14564 (0.7) | 118/14569 (0.8) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Colorectal cancer | 14 | All | 0.95 (0.77 to 1.18) | 166/14564 (1.1) | 174/14569 (1.2) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Colorectal cancer | 10 | All | RR=1.00 (0.77 to 1.31) | 107/19937 (0.5) | 107/19939 (0.5) | 0.99
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Colorectal cancer | 5.5 | All | HR=1.09 (0.69 to 1.73) | 66/8737 (0.8) | 60/8696 (0.7) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Colorectal cancer | 7.1 | All | HR=1.09 (0.72 to 1.64) | 85/8737 (1.0) | 75/8696 (0.9) | 0.60
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Colorectal cancer | 8 | All | HR=0.88 (0.64 to 1.19) | 75/7315 (1.0) | 87/7326 (1.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Esophageal cancer | 6.1 | All | RR=0.86 (0.29 to 2.56) | 6/7286 (0.1) | 7/7287 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Esophageal cancer | 6.1 | All | RR=0.85 (0.38 to 1.89) | 11/14564 (0.1) | 13/14569 (0.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Laryngeal cancer | 6.1 | All | RR=1.00 (0.51 to 1.97) | 17/7286 (0.2) | 17/7287 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Laryngeal cancer | 6.1 | All | RR=0.93 (0.55 to 1.58) | 27/14564 (0.2) | 29/14569 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Liver cancer | 22.1 | All | HR=1.18 (0.79 to 1.75) | 53/7280 (0.7) | 45/7282 (0.6) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Liver cancer | 22.1 | All | HR=1.06 (0.81 to 1.39) | 107/14549 (0.7) | 101/14556 (0.7) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Lung cancer | 6.1 | All | 0.98 (0.81 to 1.19) | 204/7286 (2.8) | 208/7287 (2.9) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Lung cancer | 24.1 | All | 0.98 (0.89 to 1.08) | 915/7286 (12.6) | 933/7287 (12.8)
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Lung cancer | 6.1 | All | RR=1.00 (0.87 to 1.14) | 433/14564 (3.0) | 443/14569 (3.0) | 0.8
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Lung cancer | 8 | All | RR=0.99 (0.87 to 1.13) | 444/14564 (3.0) | 450/14569 (3.1) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Lung cancer | 11 | All | 0.96 (0.86 to 1.07) | 682/14564 (4.7) | 711/14569 (4.9) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Lung cancer | 14 | All | 1.01 (0.92 to 1.10) | 969/14564 (6.7) | 963/14569 (6.6) | NR
Lee, 2005 (WHS)^74^ | Vitamin E vs. no vitamin E | 300 IU | Lung cancer | 10 | All | RR=1.09 (0.83 to 1.44) | 107/19937 (0.5) | 98/19939 (0.5) | 0.52
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Lung cancer | 5.5 | All | HR=1.00 (0.64 to 1.55) | 67/8737 (0.8) | 67/8696 (0.8) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Lung cancer | 7.1 | All | HR=1.11 (0.76 to 1.61) | 104/8737 (1.2) | 92/8696 (1.1) | 0.49
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Lung cancer | 8 | All | HR=0.89 (0.60 to 1.31) | 48/7315 (0.7) | 55/7326 (0.8) | NR
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | Lymphoma, non-Hodgkin’s | 3 | All | 0.35 (0.01 to 8.60) | 0/162 (0.0) | 1/170 (0.6) | NR
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | Melanoma skin cancer | 3 | All | 0.35 (0.01 to 8.60) | 0/162 (0.0) | 1/170 (0.6) | NR
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | Nasal cancer | 3 | All | 3.17 (0.13 to 78.31) | 1/162 (0.6) | 0/170 (0.0) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Oral cavity/pharyngeal cancer | 6.1 | All | RR=0.84 (0.42 to 1.66) | 15/7286 (0.2) | 18/7287 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Oral cavity/pharyngeal cancer | 6.1 | All | RR=0.97 (0.60 to 1.58) | 32/14564 (0.2) | 33/14569 (0.2) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Other cancer | 6.1 | All | 1.06 (0.92 to 1.23) | 378/14564 (2.6) | 357/14569 (2.5) | NR, NS
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | Ovarian cancer | 3 | All | 3.17 (0.13 to 78.31) | 1/162 (0.6) | 0/170 (0.0) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Pancreatic cancer | 6.1 | All | RR=0.96 (0.56 to 1.67) | 25/7286 (0.3) | 26/7287 (0.4) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Pancreatic cancer | 24.1 | All | 1.04 (0.80 to 1.35) | 114/7286 (1.6) | 110/7287 (1.5) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Pancreatic cancer | 6.1 | All | RR=1.34 (0.88 to 2.05) | 51/14564 (0.4) | 38/14569 (0.3) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Prostate cancer | 6.1 | All | 0.64 (0.44 to 0.94) | 43/7286 (0.6) | 67/7287 (0.9) | <0.05
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Prostate cancer | 24.1 | All | 0.88 (0.78 to 0.98) | 596/7286 (8.2) | 672/7287 (9.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Prostate cancer | 6.1 | All | 0.65 (0.51 to 0.84) | 99/14564 (0.7) | 151/14569 (1.0) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Prostate cancer | 8 | All | RR=0.66 (0.52 to 0.86) | 99/14564 (0.7) | 149/14569 (1.0) | <0.05
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Prostate cancer | 11 | All | 0.77 (0.65 to 0.92) | 229/14564 (1.6) | 296/14569 (2.0) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Prostate cancer | 14 | All | 0.81 (0.71 to 0.93) | 414/14564 (2.8) | 506/14569 (3.5) | NR
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | Prostate cancer | 3 | All | 3.19 (0.33 to 30.97) | 3/162 (1.9) | 1/170 (0.6) | NR
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Prostate cancer | 5.5 | All | HR=1.13 (0.95 to 1.35) | 473/8737 (5.4) | 416/8696 (4.8) | 0.06
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Prostate cancer | 7.1 | All | HR=1.17 (1.00 to 1.36) | 620/8737 (7.1) | 529/8696 (6.1) | 0.008
Sesso, 2008 (PHS-II)^81^ | Vitamin E vs. no vitamin E | 200 IU | Prostate cancer | 8 | All | HR=0.97 (0.85 to 1.09) | 493/7315 (6.7) | 515/7326 (7.0) | NR
Hodis, 2002 (VEAPS)^127^ | Vitamin E vs. placebo | 400 IU | Renal cancer | 3 | All | 3.17 (0.13 to 78.31) | 1/162 (0.6) | 0/170 (0.0) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Renal cell carcinoma | 6.1 | All | 1.00 (0.59 to 1.71) | 27/7286 (0.4) | 27/7287 (0.4) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Renal cell carcinoma | 24.1 | All | 1.02 (0.76 to 1.37) | 92/7286 (1.3) | 90/7287 (1.2) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Renal cell carcinoma | 6.1 | All | RR=1.10 (0.70 to 1.60) | 54/14564 (0.4) | 48/14569 (0.3) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Stomach cancer | 6.1 | All | RR=1.34 (0.78 to 2.29) | 32/7286 (0.4) | 24/7287 (0.3) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Stomach cancer | 24.1 | All | 1.10 (0.84 to 1.43) | 114/7286 (1.6) | 104/7287 (1.4) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Stomach cancer | 6.1 | All | RR=1.21 (0.85 to 1.74) | 69/14564 (0.5) | 57/14569 (0.4) | NR, NS
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Urinary bladder cancer | 6.1 | All | 1.10 (0.80 to 1.50) | 81/14564 (0.6) | 74/14569 (0.5) | NR, NS
Lippman, 2009 (SELECT)^80^ | Vitamin E vs. placebo | 400 IU | Urinary bladder cancer | 7.1 | All | HR=1.06 (0.72 to 1.53) | 56/8737 (0.6) | 53/8696 (0.6) | 0.79
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Urothelial cancer | 6.1 | All | 1.27 (0.83 to 1.96) | 47/7286 (0.6) | 37/7287 (0.5) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. placebo | 50 mg | Urothelial cancer | 24.1 | All | 1.03 (0.84 to 1.25) | 211/7286 (2.9) | 206/7287 (2.8) | NR
ATBC Study Group, 1994 (ATBC)^76^ | Vitamin E vs. no vitamin E | 50 mg + 20 mg Beta-carotene | Urothelial cancer | 6.1 | All | RR=1.10 (0.80 to 1.50) | 89/14564 (0.6) | 80/14569 (0.5) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Any cancer incidence | 5.5 | All | HR=1.02 (0.90 to 1.16) | 846/8703 (9.7) | 824/8696 (9.5) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Any cancer incidence | 7.1 | All | HR=1.02 (0.92 to 1.14) | 1149/8702 (13.2) | 1108/8696 (12.7) | 0.60
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Colorectal cancer | 5.5 | All | HR=1.28 (0.82 to 2.00) | 77/8703 (0.9) | 60/8696 (0.7) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Colorectal cancer | 7.1 | All | HR=1.21 (0.81 to 1.81) | 93/8702 (1.1) | 75/8696 (0.9) | 0.22
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Lung cancer | 5.5 | All | HR=1.16 (0.76 to 1.78) | 78/8703 (0.9) | 67/8696 (0.8) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Lung cancer | 7.1 | All | HR=1.11 (0.76 to 1.62) | 104/8702 (1.2) | 92/8696 (1.1) | 0.48
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Prostate cancer | 5.5 | All | HR=1.05 (0.88 to 1.25) | 437/8702 (5.0) | 416/8696 (4.8) | 0.52
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Prostate cancer | 7.1 | All | HR=1.05 (0.89 to 1.22) | 555/8702 (6.4) | 529/8696 (6.1) | 0.46
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Urinary bladder cancer | 7.1 | All | HR=1.05 (0.71 to 1.51) | 55/8703 (0.6) | 53/8696 (0.6) | 0.86

* Studies providing estimates other than ORs display effect type.

Abbreviations: ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CG = Control group; HR = Hazard ratio; IG = Intervention group; IU = International units; mcg = Microgram; mg = Milligram; NR = Not reported; NS = Not significant; PHS-II = Physicians’ Health Study II; PPP = Primary Prevention Project; RR = Risk ratio; SELECT = Selenium and Vitamin E Cancer Prevention Trial; VEAPS = Vitamin E Atherosclerosis Progression Study; WHS = Women’s Health Study.

Appendix F Table 27 Vitamin E Adverse Event Results

Author, Year (Study) | Dose | Comparison | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%)
de Gaetano, 2001 (PPP)^104^ | 300 mg | Vitamin E vs. no vitamin E | Any AE | 4 | All | 1.12 (0.87 to 1.43) | 138/2231 (6.2) | 126/2264 (5.6)
McNeil, 2004 (VECAT)^130^ | 500 IU | Vitamin E vs. placebo | Any AE | 4 | All | 1.19 (0.95 to 1.50) | 351/595 (59.0) | 327/598 (55.0)
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin E <2 yrs use vs. no vitamin E | Cataract | 12 | All | RR=1.26 (0.96 to 1.65) | 224/100000 p-y | 184/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin E 2-4 yrs use vs. no vitamin E | Cataract | 12 | All | RR=0.97 (0.68 to 1.39) | 182/100000 p-y | 184/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin E 5-9 yrs use vs. no vitamin E | Cataract | 12 | All | RR=1.13 (0.88 to 1.44) | 223/100000 p-y | 184/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin E ≥10 yrs use vs. no vitamin E | Cataract | 12 | All | RR=0.99 (0.74 to 1.32) | 216/100000 p-y | 184/100000 p-y
Sesso, 2008 (PHS-II)^81^ | 200 IU | Vitamin E vs. no vitamin E | Cataract | 8 | All | HR=0.99 (0.88 to 1.11) | 579 events/5771 | 595 events/5774
Zheng Selin, 2013 (COSM)^148^ | NR | Vitamin E vs. no vitamin E | Cataract | 8.4 | All | HR=1.57 (1.10 to 2.22) | 32/144 (22.2) | 1937/22015 (8.8)
Lippman, 2009 (SELECT)^80^ | 400 IU | Vitamin E vs. placebo | Dermatitis | 5.5 | All | RR=1.14 (0.98 to 1.32) | 591/8737 (6.8) | 516/8696 (5.9)
de Gaetano, 2001 (PPP)^104^ | 300 mg | Vitamin E vs. no vitamin E | Epistaxis | 4 | All | 1.01 (0.06 to 16.23) | 1/2231 (0.0) | 1/2264 (0.0)
Lee, 2005 (WHS)^74^ | 300 IU | Vitamin E vs. no vitamin E | Epistaxis | 10 | All | RR=1.06 (1.01 to 1.11) | ./19937 (.) | ./19939 (.)
de Gaetano, 2001 (PPP)^104^ | 300 mg | Vitamin E vs. no vitamin E | Gastrointestinal bleeding | 4 | All | 1.01 (0.44 to 2.35) | 11/2231 (0.5) | 11/2264 (0.5)
de Gaetano, 2001 (PPP)^104^ | 300 mg | Vitamin E vs. no vitamin E | GI disease | 4 | All | 1.22 (0.37 to 4.00) | 6/2231 (0.3) | 5/2264 (0.2)
de Gaetano, 2001 (PPP)^104^ | 300 mg | Vitamin E vs. no vitamin E | Intracranial bleeding | 4 | All | 5.08 (0.24 to 105.84) | 2/2231 (0.1) | 0/2264 (0.0)
ATBC Study Group, 1994 (ATBC)^76^ | 50 mg + 20 mg Beta-carotene | Vitamin E vs. no vitamin E | Non-serious: Hospitalized for pneumonia (NS) | 6.1 | All | | ./14564 (.) | ./14569 (.)
de Gaetano, 2001 (PPP)^104^ | 300 mg | Vitamin E vs. no vitamin E | Non-serious: Bleeding (NS); Ocular bleeding (NS); Other bleeding (NS) | 4 | All | | ./2231 (.) | ./2264 (.)
Lippman, 2009 (SELECT)^80^ | 400 IU | Vitamin E vs. placebo | Non-serious: Fatigue (NS); Halitosis (NS); Nail changes (NS) | 5.5 | All | | ./8737 (.) | ./8696 (.)
McNeil, 2004 (VECAT)^130^ | 500 IU | Vitamin E vs. placebo | Non-serious: Noncataract-related opthalmic event (NS) | 4 | All | 1.40 (1.00 to 1.98) | 87/595 (15.0) | 65/598 (12.0)
Sesso, 2008 (PHS-II)^81^ | 200 IU | Vitamin E vs. no vitamin E | Hematuria (NS), easy bruising (NS), epistaxis (NS), peptic ulcer (NS), constipation (NS), diarrhea (NS), gastritis (NS), nausea (NS), fatigue (NS), drowsiness (NS), skin discoloration or rashes (NS), and migraine (NS) | 8 | All | | ./7329 (.) | ./7312 (.)
McNeil, 2004 (VECAT)^130^ | 500 IU | Vitamin E vs. placebo | Serious AEs | 4 | All | 1.00 (0.76 to 1.31) | 127/595 (21.3) | 128/598 (21.4)
de Gaetano, 2001 (PPP)^104^ | 300 mg | Vitamin E vs. no vitamin E | Withdrawals due to AEs | 4 | All | | 25/2231 (1.1) | ./2264 (.)
McNeil, 2004 (VECAT)^130^ | 500 IU | Vitamin E vs. placebo | Withdrawals due to AEs | 4 | All | 0.94 (0.47 to 1.89) | 16/595 (2.7) | 17/598 (2.8)
Salonen, 2000 (ASAP)^77^ | 182 mg | Vitamin E vs. Placebo | Withdrawals due to AEs | 3 | All | 0.87 (0.31 to 2.47) | 7/130 (5.4) | 8/130 (6.2)

* Studies providing estimates other than ORs display effect type.

Abbreviations: = not reported; AE = Adverse event; ASAP = Antioxidant Supplementation in Atherosclerosis Prevention; ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CG = Control group; COSM = Cohort of Swedish Men; GI = Gastrointestinal; HR = Hazard ratio; IG = Intervention group; IU = International units; mg = Milligram; NHS-I = Nurses’ Health Study I; NS = Not significant; NR = Not reported; PHS-II = Physicians’ Health Study II; PPP = Primary Prevention Project; p-y = Person-year; RR = Risk ratio; SELECT = Selenium and Vitamin E Cancer Prevention Trial; VECAT = Vitamin E, Cataract and Age-related Maculopathy Trial; WHS = Women’s Health Study.

Appendix F Table 28 Summary of Results for Studies of Folic Acid, Either Alone or With Vitamins B12

Study | Quality Rating | Study Design | N Rand. | Supplement (daily dose) | ACM | CVD | Cancer | AE
Cole, 2007 (AFPPS)^84^ | Fair | 3x2 factorial RCT | 1,021 | Folic acid (1,000 mcg/day) | ↔? | ? | Any: ↑; Breast: NR; CRC: ?; Other: ↑; Prostate: ↑? | NR; Paradoxical effect for prostate cancer (↑?) NSD between groups on CVD outcomes.
Durga, 2007 (FACIT)^133^ | Fair | RCT | 819 | Folic acid (800 mcg/day) | ? | NR | NR | Any, GI: ?
Logan, 2008 (ukCAP)^109^ | Fair | RCT | 939 | Folic acid (500 mcg/day) | ? | ? | Breast: NR; CRC: ?; Non-CRC: ? | GI: ↔; GI bleeding, peptic ulcer: ?; Withdrawals due to AEs: ↔
Wu, 2009^110^ | Good | RCT | 672 | Folic acid (1,000 mcg/day) | ? | ? | Any: ↔; Breast: ?; CRC: ?; Lung: ?; Prostate: ? | Withdrawals due to AEs: ?
van Wijngaarden, 2014 (B-PROOF)^97^ | Fair | RCT | 2,919 | Folic acid (400 mcg/day); Vitamin B12 (500 mcg/day) | ↔ | ↔? | Any: ↑?; Any in women: ↑?; CRC: ↑; Other: ?; Breast: NR; Lung: ? | Withdrawals due to AEs: ↔?

Abbreviations: ACM = All-cause mortality; AE = Adverse event; AFPPS = Aspirin/Folate Polyp Prevention Study; B-PROOF = B-Vitamins for the PRevention Of Osteoporotic Fractures; CRC = Colorectal cancer; CVD = Cardiovascular disease; FACIT = Folic Acid and Carotid Intima-media Thickness; GI = Gastrointestinal; mcg = Micrograms; NR = Not reported; NSD = No significant difference; RCT = Randomized controlled trial; ukCAP = United Kingdom Colorectal Adenoma Prevention trial.

↑ Likely non-trivial increase in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

↑? Possible non-trivial increase in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↔ Evidence of no to minimal group differences (e.g., few to no statistically significant findings with reasonably precise estimates [e.g., >~20 events in all treatment arms])

↔? Limited evidence of no to minimal group differences (e.g., few to no statistically significant findings, but imprecise estimates/side CIs).

↓? Possible non-trivial decrease in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↓ Likely non-trivial decrease in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

? Insufficient evidence to evaluate (e.g., very few [e.g., <10] events).

Judgement for symbols based on totality of evidence for each study, considering statistical and clinical significance.

Appendix F Table 29 Folic Acid Meta-Analysis Results: Results of Meta-Analyses by Outcome, Primary Analysis Listed First for Each Outcome, Followed by Sensitivity Analyses

Outcome | Model/Analysis | Pooled OR (95% CI) | No. studies | N analyzed | I^2^, % | Tau^2^
All-cause mortality | Peto | 0.71 (0.49, 1.03) | 5 | 6,370 | 21.2 | 0.04
All-cause mortality | MH | 0.73 (0.53, 0.99) | 5 | 6,370 | NA | NA
MI | MH | 1.26 (0.86, 1.85) | 4 | 3,201 | NA | NA
Stroke | Peto | 0.95 (0.50, 1.81) | 4 | 3,201
Any cancer incidence | Peto | 1.42 (1.10, 1.84) | 3 | 4,612 | 0 | 0
Any cancer incidence | MH | 1.43 (1.10, 1.86) | 3 | 4,612 | NA | NA
Colorectal cancer | Peto | 1.16 (0.50, 2.66) | 4 | 5,538 | 37.3 | 0.27
Colorectal cancer | MH | 1.35 (0.72, 1.86) | 4 | 5,538 | NA | NA

Abbreviations: CI = Confidence interval; MH = Mantel-Haenszel common effects model; NA = Not applicable; No. = Number; OR = Odds ratio; Peto = Peto odds ratio random effects REML model.

Appendix F Table 30 Folic Acid Mortality Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect | IG n/N (%) | CG n/N (%) | p-value
Cole, 2007 (AFPPS)^84^ | Folic acid vs. placebo | 1 mg | All-cause mortality | 6.2 | All | 0.51 (0.23 to 1.10) | 10/516 (1.9) | 19/505 (3.8) | 0.09
Durga, 2007 (FACIT)^133^ | Folic acid vs. placebo | 800 mcg | All-cause mortality | 3 | All | 2.06 (0.61 to 6.88) | 8/406 (2.0) | 4/413 (1.0) | NR
Logan, 2008 (ukCAP)^109^ | Folate vs. no folate | 0.5 mg | All-cause mortality | 3 | All | 0.52 (0.22 to 1.25) | 8/470 (1.7) | 15/469 (3.2) | NR
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | All-cause mortality | 2 | All | 0.88 (0.56 to 1.37) | 37/1461 (2.5) | 42/1458 (2.9) | 0.571
Wu, 2009^110^ | Folic acid vs placebo | 1 mg | All-cause mortality | 6.5 | All | 0.45 (0.18 to 1.12) | 7/338 (2.0) | 15/334 (4.0) | 0.08
Wu, 2009^110^ | Folic acid vs placebo | 1 mg | CVD deaths | 6.5 | All | 0.14 (0.01 to 2.72) | 0/338 (0.0) | 3/334 (0.9) | 0.12

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; B-PROOF = B-Vitamins for the PRevention Of Osteoporotic Fractures; CG = Control group; CVD = Cardiovascular disease; FACIT = Folic Acid and Carotid Intima-media Thickness; IG = Intervention group; NR = Not reported; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; Vit D = Vitamin D.

Appendix F Table 31 Folic Acid Cardiovascular Disease Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Cole, 2007 (AFPPS)^84^ | Folic acid vs. placebo | 1 mg | Coronary revascularization | 6.2 | All | 0.98 (0.48 to 1.98) | 16/516 (3.1) | 16/505 (3.2) | >0.99
Wu, 2009^110^ | Folic acid vs placebo | 1 mg | CVD events | 6.5 | All | 1.42 (0.54 to 3.79) | 10/338 (3.0) | 7/334 (2.1)
Cole, 2007 (AFPPS)^84^ | Folic acid vs. placebo | 1 mg | MI | 6.2 | All | 1.73 (0.72 to 4.17) | 14/516 (2.7) | 8/505 (1.6) | 0.28
Logan, 2008 (ukCAP)^109^ | Folate vs. no folate | 0.5 mg | MI | 3 | All | 7.03 (0.36 to 136.47) | 3/470 (0.6) | 0/469 (0.0) | >0.05
Wu, 2009^110^ | Folic acid vs placebo | 1 mg | MI, nonfatal | 6.5 | All | 6.02 (0.72 to 50.26) | 6/338 (2.0) | 1/334 (0.3) | 0.12
Logan, 2008 (ukCAP)^109^ | Folate vs. no folate | 0.5 mg | Other CVD | 3 | All | 1.29 (0.48 to 3.49) | 9/470 (1.9) | 7/469 (1.5) | >0.05
Cole, 2007 (AFPPS)^84^ | Folic acid vs. placebo | 1 mg | Stroke | 6.2 | All | 1.78 (0.59 to 5.33) | 9/516 (1.7) | 5/505 (1.0) | 0.42
Logan, 2008 (ukCAP)^109^ | Folate vs. no folate | 0.5 mg | Stroke | 3 | All | 1.00 (0.06 to 16.00) | 1/470 (0.2) | 1/469 (0.2) | >0.05
van Wijngaarden, 2014 (B-PROOF) | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Stroke | 2 | Vascular subgroup (randomly selected) | 0.72 (0.45 to 1.15) | 46/295 (15.6) | 60/274 (21.9) | 0.17
van Wijngaarden, 2014 (B-PROOF) | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | MI | 2 | Vascular subgroup (randomly selected) | 1.19 (0.66 to 2.14) | 45/295 (15.3) | 43/274 (15.7) | 0.56
van Wijngaarden, 2014 (B-PROOF) | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | CVD events | 2 | Vascular subgroup (randomly selected) | 1.08 (0.86 to 1.36) | 181/295 (61.4) | 170/274 (62.0) | 0.50
van Wijngaarden, 2014 (B-PROOF) | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Stroke | 2 | Vascular subgroup (randomly selected), females only | 0.33 (0.15 to 0.71) | 16/130 (12.3) | 36/122 (29.5)
Wu, 2009^110^ | Folic acid vs placebo | 1 mg | Stroke | 6.5 | All | 1.32 (0.29 to 5.95) | 4/338 (1.0) | 3/334 (0.9) | 1.00
Wu, 2009^110^ | Folic acid vs placebo | 1 mg | Stroke, nonfatal | 6.5 | All | 1.32 (0.29 to 5.95) | 4/338 (1.0) | 3/334 (0.9) | 1.00

* Studies providing estimates other than ORs display effect type.

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; CG = Control group; CVD = Cardiovascular disease; IG = Intervention group; mg = Milligram; MI = Myocardial infarction; ukCAP = United Kingdom Colorectal Adenoma Prevention trial.

Appendix F Table 32 Folic Acid Cancer Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Cole, 2007 (AFPPS)^84^ | Folic acid vs. placebo | 1 mg | Adenomas | 6.2 | All | RR=1.35 (0.98 to 1.86) | 70/304 (23.1) | 52/303 (17.1) | 0.07
Cole, 2007 (AFPPS)^84^ | Folic acid vs. placebo | 1 mg | Any cancer incidence | 6.2 | All | 1.62 (1.05 to 2.50) | 57/516 (11.0) | 36/505 (7.1) | NR
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Any cancer incidence | 2 | All | HR=1.56 (1.04 to 2.31) | 63/1461 (4.3) | 42/1458 (2.9) | 0.038
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Any cancer incidence | 6.5 | All | HR=1.25 (1.00 to 1.57) | 171/1257 (13.6) | 143/1267 (11.3) | 0.05
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Any cancer incidence | 2 | Females | HR=2.35 (1.23 to 4.50) | 31/736 (4.2) | 13/725 (1.8) | 0.010
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Any cancer incidence | 2 | Males | HR=1.16 (0.69 to 1.94) | 32/725 (4.4) | 29/733 (4.0) | 0.580
Wu, 2009^110^ | Folic acid vs placebo | 1 mg | Any cancer incidence | 6.5 | All | 0.99 (0.55 to 1.78) | 24/338 (7.0) | 24/334 (7.0) | 0.97
Cole, 2007 (AFPPS)^84^ | Folic acid vs. placebo | 1 mg | Basal cell carcinoma | 13.5 | All | HR=0.85 (0.57 to 1.27) | 45/443 (10.2) | 50/431 (11.6) | 0.42
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Breast cancer | 2 | All | 2.34 (0.60 to 9.05) | 7/1454 (0.5) | 3/1452 (0.2) | NR
Wu, 2009^110^ | Folic acid vs placebo | 1 mg | Breast cancer | 6.5 | All | 0.84 (0.25 to 2.79) | 5/206 (2.4) | 6/208 (2.9) | 0.75
Cole, 2007 (AFPPS)^84^ | Folic acid vs. placebo | 1 mg | Colorectal cancer | 6.2 | All | 0.73 (0.16 to 3.29) | 3/516 (0.6) | 4/505 (0.8) | 0.72
Logan, 2008 (ukCAP)^109^ | Folate vs. no folate | 0.5 mg | Colorectal cancer | 3 | All | 1.00 (0.29 to 3.47) | 5/470 (1.1) | 5/469 (1.1) | NR
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Colorectal cancer | 2 | All | 2.81 (1.01 to 7.83) | 14/1454 (1.0) | 5/1452 (0.3) | NR
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Colorectal cancer | 6.5 | All | HR=1.77 (1.08 to 2.90) | 43/1257 (3.4) | 25/1267 (2.0) | 0.02
Wu, 2009^110^ | Folic acid vs placebo | 1 mg | Colorectal cancer | 6.5 | All | 0.33 (0.03 to 3.16) | 1/338 (0.3) | 3/334 (0.9) | 0.37
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Ear/nose/throat cancer | 2 | All | 3.00 (0.12 to 73.65) | 1/1454 (0.1) | 0/1452 (0.0) | NR
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Female reproductive system cancer | 2 | Females | 2.96 (0.31 to 28.55) | 3/736 (0.4) | 1/725 (0.1) | NR
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Hematological cancer | 2 | All | 0.83 (0.25 to 2.73) | 5/1454 (0.3) | 6/1452 (0.4) | NR
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Lung cancer | 2 | All | 1.00 (0.32 to 3.10) | 6/1454 (0.4) | 6/1452 (0.4) | NR
Wu, 2009^110^ | Folic acid vs placebo | 1 mg | Lung cancer | 6.5 | All | 1.32 (0.29 to 5.95) | 4/338 (1.0) | 3/334 (0.9) | 1.00
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Male reproductive system cancer | 2 | Males | 0.91 (0.37 to 2.25) | 9/725 (1.2) | 10/733 (1.4) | NR
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Melanoma skin cancer | 2 | All | 2.00 (0.37 to 10.94) | 4/1454 (0.3) | 2/1452 (0.1) | NR
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Muskuloskeletal cancer | 2 | All | 3.00 (0.12 to 73.65) | 1/1454 (0.1) | 0/1452 (0.0) | NR
Logan, 2008 (ukCAP)^109^ | Folate vs. no folate | 0.5 mg | Non-CRC cancer incidence | 3 | All | 1.13 (0.43 to 2.94) | 9/470 (1.9) | 8/469 (1.7) | >0.05
Cole, 2007 (AFPPS)^84^ | Folic acid vs. placebo | 1 mg | Other cancer | 6.2 | All | 1.73 (1.10 to 2.72) | 54/516 (10.5) | 32/505 (6.3) | 0.02
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Other GI cancer | 2 | All | 7.02 (0.86 to 57.12) | 7/1454 (0.5) | 1/1452 (0.1) | NR
Cole, 2007 (AFPPS)^84^ | Folic acid vs. placebo | 1 mg | Prostate cancer | 7 | Males | HR=2.58 (1.14 to 5.86) | 25/327 (7.6) | 9/316 (2.8) | 0.02
Wu, 2009^110^ | Folic acid vs placebo | 1 mg | Prostate cancer | 6.5 | All | 0.79 (0.23 to 2.65) | 5/132 (3.8) | 6/126 (4.8) | 0.75
van Wijngaarden, 2014 (B-PROOF)^97^ | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | 500 mcg + 400 mcg Folic acid | Urinary tract cancer | 2 | All | 0.86 (0.29 to 2.55) | 6/1454 (0.4) | 7/1452 (0.5) | NR

* Studies providing estimates other than ORs display effect type.

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; B-PROOF = B-Vitamins for the PRevention Of Osteoporotic Fractures; CG = Control group; CRC = Colorectal cancer; GI = Gastrointestinal; HR = Hazard ratio; IG = Intervention group; NR = Not reported; RR = Risk ratio; ukCAP = United Kingdom Colorectal Adenoma Prevention trial; Vit D = Vitamin D.

Appendix F Table 33 Folic Acid Adverse Event Outcomes

Author, Year (Study) | Dose | Comparison | Outcome | Followup, years | Group | Effect | IG n/N (%) | CG n/N (%)
Durga, 2007 (FACIT)^133^ | 800 mcg | Folic acid vs. placebo | Any AE | 3 | All | 0.72 (0.23 to 2.30) | 5/406 (1.2) | 7/413 (1.7)
Logan, 2008 (ukCAP)^109^ | 0.5 mg | Folate vs. no folate | Gastrointestinal bleeding | 3 | All | 0.66 (0.19 to 2.36) | 4/470 (0.8) | 6/469 (1.3)
Durga, 2007 (FACIT)^133^ | 800 mcg | Folic acid vs. placebo | Gastrointestinal symptoms | 3 | All | 0.34 (0.01 to 8.33) | 0/406 (0.0) | 1/413 (0.2)
Logan, 2008 (ukCAP)^109^ | 0.5 mg | Folate vs. no folate | Gastrointestinal symptoms | 3 | All | 1.07 (0.79 to 1.44) | 115/470 (24.3) | 109/469 (23.2)
Logan, 2008 (ukCAP)^109^ | 0.5 mg | Folate vs. no folate | Peptic ulcer | 3 | All | 0.33 (0.03 to 3.20) | 1/470 (0.2) | 3/469 (0.6)
van Wijngaarden, 2014 (B-PROOF)^97^ | 0.5 mg + 400 mcg Folic acid | Vitamin B12 + Folic Acid + Vit D vs. Vit D alone | Withdrawals due to AEs | 2 | All | 1.08 (0.50 to 2.30) | 14/1461 (1.0) | 13/1458 (0.9)
Wu, 2009^110^ | 1 mg | Folic acid vs placebo | Withdrawals due to AEs | 6.5 | All | 0.14 (0.02 to 1.13) | 1/338 (0.3) | 7/334 (2.1)
Logan, 2008 (ukCAP)^109^ | 0.5 mg | Folate vs. no folate | Withdrawals due to GI AE | 3 | All | 1.15 (0.77 to 1.71) | 59/470 (12.5) | 52/469 (11.1)

Abbreviations: AE = Adverse event; CG = Control group; FACIT = Folic Acid and Carotid Intima-media Thickness; IG = Intervention group; GI = Gastrointestinal; mcg = Microgram; mg = Milligram; ukCAP = United Kingdom Colorectal Adenoma Prevention trial.

Appendix F Table 34 Summary of Results for Studies of Vitamin B3 and B6 Use

Study | Quality Rating | Study Design | N Rand. | Supplement (daily dose) | ACM | CVD | Cancer | AE
Chen, 2015 (ONTRAC)^102^ | Good | RCT | 386 | Vitamin B3, nicotinamide (1,000 mg) | ? | ? | ? | ? Serious AE, cardiac chest pain
Feskanich, 2002 (NHS-I)^146,^ ^159^ | Fair | Cohort | 75,864 cohort from 121,700 | Vitamin B6 (NR) | NR | NR | NR | ↔? (hip fracture)

Abbreviations: ACM = All-cause mortality; AE = Adverse event; CVD = Cardiovascular disease; mg = Milligram; NHS-I = Nurses’ Health Study; NR = Not reported; ONTRAC = Oral Nicotinamide to Reduce Actinic Cancer; RCT = Randomized controlled trial.

Appendix F Table 35 Vitamin B3 Mortality Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect | IG n/N (%) | CG n/N (%) | p-value
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | All-cause mortality | 1 | All | 2.01 (0.18 to 22.36) | 2/193 (1.0) | 1/193 (0.5) | NR

Abbreviation: CG = Control group; IG = Intervention group; mg = Milligram; NR = Not reported; ONTRAC = Oral Nicotinamide to Reduce Actinic Cancer.

Appendix F Table 36 Vitamin B3 Cardiovascular Disease Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect | IG n/N (%) | CG n/N (%) | p-value
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Heart failure | 1 | All | 1.51 (0.25 to 9.13) | 3/193 (1.6) | 2/193 (1.0) | NR, NS
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | MI | 1 | All | 7.11 (0.36 to 138.58) | 3/193 (1.6) | 0/193 (0.0) | NR
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Other CVD | 1 | All | 2.02 (0.37 to 11.17) | 4/193 (2.1) | 2/193 (1.0) | NR
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Other CVD | 1 | All | 0.12 (0.01 to 0.97) | 1/193 (0.5) | 8/193 (4.1) | NR
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Stroke | 1 | All | 0.33 (0.01 to 8.19) | 0/193 (0.0) | 1/193 (0.5) | NR, NS

Abbreviation: CG = Control group; IG = Intervention group; mg = Milligram; NR = Not reported; NS = Not significant; ONTRAC = Oral Nicotinamide to Reduce Actinic Cancer.

Appendix F Table 37 Vitamin B3 Cancer Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect | IG n/N (%) | CG n/N (%) | p-value
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Any cancer incidence | 1 | All | 2.54 (0.49 to 13.25) | 5/193 (2.6) | 2/193 (1.0) | NR, NS
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Bladder cancer | 1 | All | 3.02 (0.12 to 74.49) | 1/193 (0.5) | 0/193 (0.0) | NR, NS
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Colorectal cancer | 1 | All | 3.02 (0.12 to 74.49) | 1/193 (0.5) | 0/193 (0.0) | NR, NS
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Duodenal cancer | 1 | All | 0.33 (0.01 to 8.19) | 0/193 (0.0) | 1/193 (0.5) | NR, NS
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Lung cancer | 1 | All | 1.00 (0.06 to 16.10) | 1/193 (0.5) | 1/193 (0.5) | NR, NS
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Lymphoma, non-Hodgkin’s | 1 | All | 3.02 (0.12 to 74.49) | 1/193 (0.5) | 0/193 (0.0) | NR, NS
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Neoplasms (benign, malignant, unknown) | 1 | All | 2.04 (0.60 to 6.90) | 8/193 (4.1) | 4/193 (2.1) | NR
Chen, 2015 (ONTRAC)^102^ | Vitamin B3 vs. placebo | 1000 mg | Prostate cancer | 1 | All | 3.02 (0.12 to 74.49) | 1/193 (0.5) | 0/193 (0.0) | NR, NS

Abbreviation: CG = Control group; IG = Intervention group; mg = Milligram; NR = Not reported; NS = Not significant; ONTRAC = Oral Nicotinamide to Reduce Actinic Cancer.

Appendix F Table 38 Vitamin B3, Vitamin B6, and Vitamin B12 Adverse Event Results

Author, Year (Study) | Dose | Comparison | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%)
Chen, 2015 (ONTRAC)^102^ | 1000 mg | Vitamin B3 vs. placebo | Cardiac chest pain | 1 | All | | 8/193 (4.1) | 1/193 (0.5)
Chen, 2015 (ONTRAC)^102^ | 1000 mg | Vitamin B3 vs. placebo | Serious AEs | 1 | All | | ./193 (.) | ./193 (.)
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin B12 vs. no vitamin B12 | Hip fracture | 20.9 | All
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin B6 vs. no vitamin B6 | Hip fracture | 20.9 | All
Feskanich, 2002 (NHS-I)^146^ | <2 mg/day | Vitamin B6 vs. no vitamin B6 | Hip fracture | 20.9 | All | RR 1.37 (1.12 to 1.69)
Feskanich, 2002 (NHS-I)^146^ | ≥25 mg/day | Vitamin B6 vs. no vitamin B6 | Hip fracture | 20.9 | All | RR 1.41 (1.10 to 1.80)

* Studies providing estimates other than ORs display effect type.

Abbreviations: . = not reported; AE = Adverse event; CG = Control group; IG = Intervention group; mg = Milligram; NHS-I = Nurses’ Health Study; NR = Not reported; ONTRAC = Oral Nicotinamide to Reduce Actinic Cancer.

Appendix F Table 39 Summary of Results for Studies of Vitamin C Use

Author, Year (Study) | Quality Rating | Study Design | Study N^*^ | Supplement (daily dose) | ACM | CVD | Cancer | Harms
Salonen, 2000 (ASAP)^77^ | Fair | RCT | 390 | Vitamin C (500 mg) | ? | ? | NR | ? WD AE
Salonen, 2000 (ASAP)^77^ | Fair | RCT | 390 | Vitamin C (500 mg) + Vitamin E (182 mg) | ? | ? | NR | ? WD AE
Sesso, 2008 (PHS-II)^81^ | Good | RCT | 14641 | Vitamin C (500 mg) | ↔ | ↔ | ↔ | ↔ Nonserious AE: (e.g., GI symptoms, hematuria, easy bruising, epistaxis, peptic ulcer, fatigue, drowsiness, skin symptoms, migraine; ↔ Cataracts
Feskanich, 2002 (NHS-I)^146^ | Fair | Cohort | 121700 | Vitamin C (NR) | NR | NR | NR | ↔ Cataracts
Rautiainen, 2010 (SMC)^151^ | Fair | Cohort | 38984 | Vitamin C (~1000 mg) | NR | NR | NR | ↑ Cataracts
Taylor, 2004 (HPFS)^150^ | Fair | Cohort | 51529 | Vitamin C (1 - ≥1000 mg) | NR | NR | NR | ↑? Kidney stones
Zheng Selin, 2013 (COSM)^148,^ ^247^ | Fair | Cohort | 27343 | Vitamin C (~1000 mg) | NR | NR | NR | ↑ Cataracts; ↑ Kidney stones

* Includes only participants randomized to an intervention group assigned to take vitamin C.

Abbreviations: ACM = All-cause mortality; AE = Adverse event; ASAP = Antioxidant Supplementation in Atherosclerosis Prevention; COSM = Cohort of Swedish Men; CVD = Cardiovascular disease; HPFS = Health Professionals Followup Study; mg = Milligram; NHS-I = Nurses’ Health Study I; NR = Not reported; PHS-II = Physicians’ Health Study II; RCT = Randomized controlled trial; SMC = Swedish Mammography Cohort; WD = Withdrawal.

↑ Likely non-trivial increase in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

↑? Possible non-trivial increase in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↔ Evidence of no to minimal group differences (e.g., few to no statistically significant findings with reasonably precise estimates [e.g., >~20 events in all treatment arms]).

↓ Likely non-trivial decrease in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

? Insufficient evidence to evaluate (e.g., very few [e.g., <10] events).

Judgement for symbols based on totality of evidence for each study, considering statistical and clinical significance.

Appendix F Table 40 Vitamin C Mortality Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Salonen, 2000 (ASAP)^77^ | Vitamin C vs. Placebo | 500 mg | All-cause mortality | 3 | All | 1.00 (0.06 to 16.16) | 1/130 (0.8) | 1/130 (0.8)
Salonen, 2000 (ASAP)^77^ | Vitamin C + vitamin E vs. placebo | 500 mg + 544 IU Vitamin E | All-cause mortality | 3 | All | 1.00 (0.06 to 16.16) | 1/130 (0.8) | 1/130 (0.8)
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | All-cause mortality | 8 | All | HR=1.07 (0.97 to 1.18) | 857/7329 (11.7) | 804/7312 (11.0) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Any cancer deaths | 8 | All | HR=1.06 (0.89 to 1.25) | 268/7329 (3.7) | 255/7312 (3.5) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Colorectal cancer deaths | 8 | All | HR=1.04 (0.61 to 1.78) | 27/7329 (0.4) | 26/7312 (0.4) | NR
Salonen, 2000 (ASAP)^77^ | Vitamin C vs. Placebo | 500 mg | CVD deaths | 3 | All | 1.00 (0.06 to 16.16) | 1/130 (0.8) | 1/130 (0.8)
Salonen, 2000 (ASAP)^77^ | Vitamin C + vitamin E vs. placebo | 500 mg + 544 IU Vitamin E | CVD deaths | 3 | All | 1.00 (0.06 to 16.16) | 1/130 (0.8) | 1/130 (0.8)
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | CVD deaths | 8 | All | HR=1.02 (0.85 to 1.21) | 256/7329 (3.5) | 253/7312 (3.5) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Lung cancer deaths | 8 | All | HR=0.82 (0.53 to 1.25) | 39/7329 (0.5) | 48/7312 (0.7) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | MI, fatal | 8 | All | HR=1.37 (0.79 to 2.38) | 30/7329 (0.4) | 22/7312 (0.3) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Prostate cancer deaths | 8 | All | HR=1.46 (0.92 to 2.31) | 45/7329 (0.6) | 31/7312 (0.4) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Stroke deaths | 8 | All | HR=0.77 (0.52 to 1.14) | 44/7329 (0.6) | 57/7312 (0.8) | NR

* Studies providing estimates other than ORs display effect type.

Abbreviations: ASAP = Antioxidant Supplementation in Atherosclerosis Prevention; CG = Control group; CVD = Cardiovascular disease; HR = Hazard ratio; IG = Intervention group; IU = International units; mg = Milligram; MI = Myocardial infarction; NR = Not reported; PHS-II = Physicians’ Health Study II.

Appendix F Table 41 Vitamin C Cardiovascular Disease Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect | IG n/N (%) | CG n/N (%) | p-value
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Congestive heart failure | 8 | All | HR=1.02 (0.87 to 1.20) | 293/7329 (4.0) | 290/7312 (4.0) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | CVD events | 8 | All | HR=0.99 (0.89 to 1.11) | 619 events/7329 | 626 events/7312 | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | MI | 8 | All | HR=1.04 (0.87 to 1.24) | 260/7329 (3.5) | 251/7312 (3.4) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Stroke | 8 | All | HR=0.89 (0.74 to 1.07) | 218/7329 (3.0) | 246/7312 (3.4) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Stroke, Hemorrhagic | 8 | All | HR=0.95 (0.57 to 1.56) | 30/7329 (0.4) | 32/7312 (0.4) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Stroke, Ischemic | 8 | All | HR=0.87 (0.71 to 1.07) | 180/7329 (2.5) | 207/7312 (2.8) | NR

Abbreviations: CG = Control group; CVD = Cardiovascular disease; HR = Hazard ratio; IG = Intervention group; mg = Milligram; MI = Myocardial infarction; NR = Not reported; PHS-II = Physicians’ Health Study II.

Appendix F Table 42 Vitamin C Cancer Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect | IG n/N (%) | CG n/N (%) | p-value
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Any cancer incidence | 8 | All | HR=1.01 (0.92 to 1.10) | 973/7329 (13.3) | 970/7312 (13.3) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Colorectal cancer | 8 | All | HR=0.86 (0.63 to 1.17) | 75/7329 (1.0) | 87/7312 (1.2) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Lung cancer | 8 | All | HR=0.95 (0.64 to 1.39) | 50/7329 (0.7) | 53/7312 (0.7) | NR
Sesso, 2008 (PHS-II)^81^ | Vitamin C vs. no vitamin C | 500 mg | Prostate cancer | 8 | All | HR=1.02 (0.90 to 1.15) | 508/7329 (6.9) | 500/7312 (6.8) | NR

Abbreviations: CG = Control group; HR = Hazard ratio; IG = Intervention group; mg = Milligram; NR = Not reported; PHS-II = Physicians’ Health Study II.

Appendix F Table 43 Vitamin C Adverse Event Results

Author, Year (Study) | Dose | Comparison | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%)
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin C <2 yrs use vs. no vitamin C | Cataract | 12 | All | RR=1.08 (0.88 to 1.32) | 210/100000 p-y | 188/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin C 2-4 yrs use vs. no vitamin C | Cataract | 12 | All | RR=1.01 (0.76 to 1.33) | 201/100000 p-y | 188/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin C 5-9 yrs use vs. no vitamin C | Cataract | 12 | All | RR=1.05 (0.84 to 1.31) | 213/100000 p-y | 188/100000 p-y
Feskanich, 2002 (NHS-I)^146^ | NR | Vitamin C ≥10 yrs use vs. no vitamin C | Cataract | 12 | All | RR=0.95 (0.76 to 1.20) | 200/100000 p-y | 188/100000 p-y
Rautiainen, 2010 (SMC)^151^ | 1000 mg | Vitamin C vs. no supplement | Cataract | 8.2 | All | HR=1.25 (1.05 to 1.50) | 143 events/1225 | 3/75524 p-y
Sesso, 2008 (PHS-II)^81^ | 500 mg | Vitamin C vs. no vitamin C | Cataract | 8 | All | HR=1.02 (0.91 to 1.14) | 593 events/5799 | 581 events/5746
Zheng Selin, 2013 (COSM)^148^ | Varies | Vitamin C vs. no vitamin C | Cataract | 8.4 | All | HR=1.21 (1.04 to 1.41) | 188/1652 (11.4) | 1937/22015 (8.8)
Taylor, 2004 (HPFS)^150^ | 1-99 mg | Vitamin C 1-99 mg/day vs. no use or other doses | Kidney stones | 14 | All | RR=0.95 (0.81 to 1.12) | 298 events/. | 618 events/.
Taylor, 2004 (HPFS)^150^ | 100-499 mg | Vitamin C 100-499 mg/day vs. no use or other doses | Kidney stones | 14 | All | RR=0.91 (0.78 to 1.07) | 208 events/. | 618 events/.
Taylor, 2004 (HPFS)^150^ | 500-999 mg | Vitamin C 500-999 mg/day vs. no use or other doses | Kidney stones | 14 | All | RR=1.11 (0.93 to 1.34) | 161 events/. | 618 events/.
Taylor, 2004 (HPFS)^150^ | ≥1000 mg | Vitamin C ≥1000 mg/day vs. no use or other doses | Kidney stones | 14 | All | RR=1.16 (0.97 to 1.39) | 188 events/. | 618 events/.
Zheng Selin, 2013 (COSM)^148^ | Varied | Vitamin C vs. no vitamin C | Kidney stones | 11 | All | RR=1.92 (1.33 to 2.77) | 31/907 (3.4) | 405/22448 (1.8)
Sesso, 2008 (PHS-II)^81^ | 500 mg | Vitamin C vs. no vitamin C | Non-serious: Hematuria (NS), easy bruising (NS), epistaxis (NS), peptic ulcer (NS), constipation (NS), diarrhea (NS), gastritis (NS), nausea (NS), fatigue (NS), drowsiness (NS), skin discoloration or rashes (NS), and migraine (NS) | 8 | All | | ./7329 (.) | ./7312 (.)
Salonen, 2000 (ASAP)^77^ | 500 mg | Vitamin C vs. Placebo | Withdrawals due to AEs | 3 | All | 0.74 (0.25 to 2.19) | 6/130 (4.6) | 8/130 (6.2)
Salonen, 2000 (ASAP)^77^ | 500 mg + 544 IU Vitamin E | Vitamin C + vitamin E vs. placebo | Withdrawals due to AEs | 3 | All | 0.87 (0.31 to 2.47) | 7/130 (5.4) | 8/130 (6.2)

* Studies providing estimates other than ORs display effect type.

Abbreviations: . = not reported; AE = Adverse event; ASAP = Antioxidant Supplementation in Atherosclerosis Prevention; CG = Control group; COSM = Cohort of Swedish Men; HPFS = Health Professionals Followup Study; HR = Hazard ratio; IG = Intervention group; IU = International units; mg = Milligram; NHS-I = Nurses’ Health Study I; NR = Not reported; NS = Not significant; PHS-II = Physicians’ Health Study II; p-y = Person-years; RR = Risk ratio; SMC = Swedish Mammography Cohort; yrs = Years.

Appendix F Table 44 Calcium Meta-Analysis Results

Outcome | Model/Analysis | Pooled OR (95% CI) | No. studies | N analyzed | I^2^, % | Tau^2^
All-cause mortality | MH | 1.05 (0.92 to 1.21) | 6 | 8,394 | NA | NA
All-cause mortality | Peto | 1.05 (0.92 to 1.21) | 6 | 8,394 | 0 | 0.0
All-cause mortality | REML-KH | 1.05 (0.94 to 1.19) | 6 | 8,394 | 0 | 0.0
All-cause mortality | Full ascert. (MH) | 1.05 (0.90 to 1.21) | 3 | 5,574 | NA | NA
CVD mortality | MH | 1.03 (0.84 to 1.27) | 3 | 5,574 | NA | NA
CVD mortality | Peto | 0.95 (0.66 to 1.35) | 3 | 5,574 | 28.3 | 0.04
CVD mortality | Full ascert. (MH) | 1.03 (0.84 to 1.27) | 3 | 5,574 | NA | NA
Composite CVD event | MH | 1.11 (0.90 to 1.36) | 4 | 4,076 | NA | NA
Composite CVD event | Peto | 1.11 (0.90 to 1.36) | 4 | 4,076 | 0 | 0.0
MI | MH | 1.18 (0.72 to 1.92) | 3 | 3,361 | NA | NA
MI | Peto | 1.09 (0.23 to 5.27) | 3 | 3,361 | 78.6 | 1.38
Stroke | MH | 1.21 (0.87 to 1.69) | 4 | 5,536 | NA | NA
Stroke | Peto | 1.21 (0.87 to 1.68) | 4 | 5,536 | 0 | 0.0
Stroke | Full ascert. (MH) | 1.23 (0.86 to 1.77) | 3 | 4,606 | NA | NA
Any cancer incidence | REML-KH | 0.94 (0.41 to 2.11) | 3 | 5,051 | 49.2 | 0.04
Any cancer incidence | Full ascert. (REML) | 0.94 (0.41 to 2.11) | 3 | 5,051 | 49.2 | 0.04

Abbreviations: CI = Confidence interval; CVD = Cardiovascular disease; Full ascert. = Full ascertainment; MH = Mantel-Haenszel common effects model; MI = Myocardial infarction; NA = Not applicable; No. = Number; Peto odds ratio random effects REML model; REML-KH = Random effects restricted maximum likelihood model with the Knapp-Hartung adjustment.

Appendix F Table 45 Summary of Results for Studies of Calcium Use

Author, Year (Study) | Final Quality Rating | Study Design | N | Supplement (daily dose) | ACM | CVD | Cancer | Harms
Avenell, 2012 (RECORD)^89^ | Fair | RCT | 5292 | Calcium (1000 mg) | ↔ | ↔ | ↔ | ↔ Fractures; ↑ GI sx
Baron, 2005 (CPPS)^85^ | Fair | RCT | 930 | Calcium (1200 mg) | ↔ | ↔ | Prostate: ↓? | ↔ AE WD; ↑? GI hosp
Baron, 2015 (VCPPS)^91^ | Good | RCT | 2259 | Calcium (1200 mg)^*^ | ↔ | ? | ↔ | ↔ Fractures, kidney stones
Bolland, 2008 (ACS)^82^ | Fair | RCT | 1471 | Calcium (1000 mg) | ↔ | ↑? | NR | ↑ Constipation; ? Fractures
Fedirko, 2009^114^ | Fair | RCT | 92 | Calcium (2000 mg) | NR | NR | NR | ? Any AE
Lappe, 2007^83^ | Fair | RCT | 1180 | Calcium (1500 mg) | NR | NR | ↓? | ? Serious AE, kidney stones
Lewis, 2011 (CAIFOS)^105^ | Good | RCT | 1460 | Calcium (1200 mg) | ↔ | ↔ | NR | ↑ Constipation, fractures; ? Kidney stones
Reid, 2008^106^ | Fair | RCT | 323 | Calcium (1200 mg) | ? | ? | NR | ? AE WD, constipation, fractures, kidney stones
Reid, 2008^106^ | Fair | RCT | 323 | Calcium (600 mg) | ? | ? | NR | ? AE WD, constipation, fractures, kidney stones
Feskanich, 2002 (NHS-I)^146^ | Fair | Cohort | 121700 | Vitamin D (4 dose levels) | NA | NA | NA | ↑? Kidney stones

* Only provided calcium vs. no calcium comparison in factorial design with concomitant vitamin D use in some participants.

Abbreviations: ACM = All-cause mortality; ACS = Auckland calcium study; AE = Adverse event; CAIFOS = Calcium Intake Fracture Outcome Study; CPPS = Calcium Polyp Prevention Study; CVD = Cardiovascular disease; GI = Gastrointestinal; hosp = Hospitalization; mg = Milligrams; NA = Not applicable; NHS – I = Nurses’ Health Study; NR = Not reported; RECORD = Randomized Evaluation of Calcium OR vitamin D; RCT = Randomized controlled trial; sx = Symptoms; VCPPS = Vitamin D/Calcium Polyp Prevention Study; WD = Withdrawal; WHI = Women’s Health Initiative.

↑ Likely non-trivial increase in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

↑? Possible non-trivial increase in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↔ Evidence of no to minimal group differences (e.g., few to no statistically significant findings with reasonably precise estimates [e.g., >~20 events in all treatment arms])

↔? Limited evidence of no to minimal group differences (e.g., few to no statistically significant findings, but imprecise estimates/side CIs).

↓? Possible non-trivial decrease in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and CIs minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↓ Likely non-trivial decrease in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and CIs minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

? Insufficient evidence to evaluate (e.g., very few [e.g., <10] events).

Judgement for symbols based on totality of evidence for each study, considering statistical and clinical significance.

Appendix F Table 46 Calcium Mortality Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | All-cause mortality | 6.2 | All | 1.07 (0.91 to 1.26) | 447/1311 (34.1) | 434/1332 (32.6) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | All-cause mortality | 6.2 | All | HR=1.03 (0.94 to 1.13) | 862/2617 (32.9) | 855/2675 (32.0) | 0.460
Baron, 2005 (CPPS)^85^ | Calcium vs. placebo | 1200 mg | All-cause mortality | 4 | All | 1.15 (0.64 to 2.07) | 25/464 (5.4) | 22/466 (4.7) | NR, NS
Baron, 2015 (VCPPS)^91^ | Calcium vs. no calcium | 1200 mg + 1000 IU Vitamin D | All-cause mortality | 3.8 | All | 1.08 (0.49 to 2.38) | 13/840 (1.5) | 12/835 (1.4) | 0.85
Bolland, 2008 (ACS)^82^ | Calcium vs. placebo | 1 g | All-cause mortality | 5 | All | RR=1.18 (0.73 to 1.92) | 34/732 (4.6) | 29/739 (3.9) | 0.52
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | All-cause mortality | 5 | All | 0.75 (0.46 to 1.24) | 29/730 (4.0) | 38/730 (5.2) | NR
Reid, 2008^106^ | Calcium vs. placebo | 1200 mg | All-cause mortality | 2 | All | 0.99 (0.06 to 16.05) | 1/108 (0.9) | 1/107 (0.9) | NR
Reid, 2008^106^ | Calcium vs. placebo | 600 mg | All-cause mortality | 2 | All | 0.99 (0.06 to 16.05) | 1/108 (0.9) | 1/107 (0.9) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | Any cancer deaths | 6.2 | All | 1.18 (0.87 to 1.59) | 95/1311 (7.2) | 83/1332 (6.2) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | Any cancer deaths | 6.2 | All | HR=1.13 (0.91 to 1.40) | 173/2617 (6.6) | 156/2675 (5.8) | 0.249
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Arrhythmia deaths | 5 | All | 0.33 (0.03 to 3.20) | 1/730 (0.1) | 3/730 (0.4) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Arrhythmia deaths | 9.5 | All | 0.62 (0.28 to 1.38) | 10/730 (1.4) | 16/730 (2.2) | NR, NS
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | Breast cancer deaths | 6.2 | All | 2.29 (0.70 to 7.47) | 9/1311 (0.7) | 4/1332 (0.3) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | Breast cancer deaths | 6.2 | All | 1.49 (0.69 to 3.22) | 16/2617 (0.6) | 11/2675 (0.4) | NR
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Cerebrovascular death | 5 | All | 0.75 (0.26 to 2.17) | 6/730 (0.8) | 8/730 (1.1) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Cerebrovascular death | 9.5 | All | 0.91 (0.49 to 1.68) | 20/730 (2.7) | 22/730 (3.0) | NR, NS
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | Colorectal cancer deaths | 6.2 | All | 1.19 (0.40 to 3.54) | 7/1311 (0.5) | 6/1332 (0.5) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | Colorectal cancer deaths | 6.2 | All | 1.58 (0.78 to 3.18) | 20/2617 (0.8) | 13/2675 (0.5) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | CVD deaths | 6.2 | All | 1.10 (0.88 to 1.37) | 194/1311 (14.8) | 182/1332 (13.7) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | CVD deaths | 6.2 | All | HR=1.07 (0.92 to 1.24) | 371/2617 (14.2) | 355/2675 (13.3) | 0.333
Bolland, 2008 (ACS)^82^ | Calcium vs. placebo | 1 g | CVD deaths | 5 | All | RR=0.51 (0.13 to 2.01) | 3/732 (0.4) | 6/739 (0.8) | 0.51
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | CVD deaths | 5 | All | 0.74 (0.40 to 1.38) | 18/730 (2.5) | 24/730 (3.3) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | CVD deaths | 9.5 | All | 0.80 (0.56 to 1.15) | 59/730 (8.1) | 72/730 (9.9) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Heart failure deaths | 5 | All | 0.66 (0.24 to 1.87) | 6/730 (0.8) | 9/730 (1.2) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Heart failure deaths | 9.5 | All | 0.50 (0.26 to 0.97) | 14/730 (1.9) | 27/730 (3.7) | 0.040
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Ischemic heart disease deaths | 5 | All | 1.45 (0.62 to 3.42) | 13/730 (1.8) | 9/730 (1.2) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Ischemic heart disease deaths | 9.5 | All | 0.94 (0.58 to 1.52) | 34/730 (4.7) | 36/730 (4.9) | NR, NS
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | Lung cancer deaths | 6.2 | All | 0.63 (0.31 to 1.25) | 13/1311 (1.0) | 21/1332 (1.6) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | Lung cancer deaths | 6.2 | All | 0.89 (0.53 to 1.49) | 27/2617 (1.0) | 31/2675 (1.2) | NR
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Peripheral artery disease deaths | 5 | All | 1.00 (0.06 to 16.02) | 1/730 (0.1) | 1/730 (0.1) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Peripheral artery disease deaths | 9.5 | All | 0.25 (0.03 to 2.23) | 1/730 (0.1) | 4/730 (0.5) | NR, NS
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | Prostate cancer deaths | 6.2 | All | 1.02 (0.20 to 5.04) | 3/1311 (0.2) | 3/1332 (0.2) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | Prostate cancer deaths | 6.2 | All | 0.73 (0.23 to 2.30) | 5/2617 (0.2) | 7/2675 (0.3) | NR

* Studies providing estimates other than ORs display effect type.

Abbreviations: ACS = Auckland calcium study; CAIFOS = Calcium Intake Fracture Outcome Study; CG = Control group; CVD = Cardiovascular disease; g = Gram; HR = Hazard ratio; IG = Intervention group; IU = International units; mg = Milligram; NR = Not reported; NS = Not significant; RECORD = Randomized Evaluation of Calcium OR vitamin D; RR = Risk ratio; VCPPS = Vitamin D/Calcium Polyp Prevention Study.

Appendix F Table 47 Calcium Cardiovascular Disease Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Cerebrovascular events | 5 | All | 1.21 (0.70 to 2.08) | 30/730 (4.1) | 25/730 (3.4) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Cerebrovascular events | 9.5 | All | 0.78 (0.52 to 1.16) | 45/730 (6.2) | 57/730 (7.8) | NR, NS
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg | Congestive heart failure | 6.2 | All | HR=0.75 (0.58 to 0.97) | 102 events/ 2649 (3.8) | 136 events/ 2643 (5.1) | 0.027
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg | CVD events | 6.2 | All | HR=0.92 (0.80 to 1.08) | 339 events/ 2649 (12.8) | 363 events/ 2643 (13.7) | 0.32
Baron, 2005 (CPPS)^85^ | Calcium vs. placebo | 1200 mg | CVD events | 4 | All | 1.10 (0.72 to 1.68) | 50/464 (10.8) | 46/466 (9.9) | NR, NS
Bolland, 2008 (ACS)^82^ | Calcium vs. placebo | 1 g | CVD events | 5 | All | RR=1.21 (0.84 to 1.74) | 60/732 (8.2) | 50/739 (6.8) | 0.32
Bolland, 2008 (ACS)^82^ | Calcium vs. placebo | 1 g | CVD events | 5 | All | IRR=1.43 (1.01 to 2.04) | 23.3/1000 p-y | 16.3/1000 p-y | 0.043
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | CVD events | 5 | All | HR=0.94 (0.69 to 1.27) | 104/730 (14.2) | 103/730 (14.1) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | CVD events | 9.5 | All | HR=0.92 (0.74 to 1.15) | 195/730 (26.7) | 200/730 (27.4) | NR, NS
Reid, 2008^106^ | Calcium vs. placebo | 1200 mg | CVD events | 2 | All | 7.13 (0.36 to 139.77) | 3/108 (2.8) | 0/107 (0.0) | NR, NS
Reid, 2008^106^ | Calcium vs. placebo | 600 mg | CVD events | 2 | All | 5.05 (0.24 to 106.37) | 2/108 (1.9) | 0/107 (0.0) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Heart failure | 5 | All | 0.78 (0.29 to 2.09) | 7/730 (1.0) | 9/730 (1.2) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Heart failure | 9.5 | All | 0.78 (0.44 to 1.37) | 22/730 (3.0) | 28/730 (3.8) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Ischemic heart disease | 5 | All | 0.92 (0.62 to 1.37) | 50/730 (6.8) | 54/730 (7.4) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Ischemic heart disease | 9.5 | All | 1.00 (0.72 to 1.37) | 85/730 (11.6) | 85/730 (11.6) | NR, NS
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg | MI | 6.2 | All | HR=0.97 (0.75 to 1.26) | 114 events/ 2649 (4.3) | 117 events/ 2643 (4.4) | 0.84
Baron, 2015 (VCPPS)^91^ | Calcium vs. no calcium | 1200 mg + 1000 IU Vitamin D | MI | 3.8 | All | 0.22 (0.05 to 1.02) | 2/840 (0.2) | 9/835 (1.1) | 0.03
Bolland, 2008 (ACS)^82^ | Calcium vs. placebo | 1 g | MI | 5 | All | IRR=1.67 (0.98 to 2.87) | 11.1/1000 p-y | 6.6/1000 p-y | 0.058
Bolland, 2008 (ACS)^82^ | Calcium vs. placebo | 1 g | MI | 5 | All | RR=1.49 (0.86 to 2.57) | 31/732 (4.2) | 21/739 (2.8) | 0.16
Reid, 2008^106^ | Calcium vs. placebo | 1200 mg | MI | 2 | All | 5.05 (0.24 to 106.37) | 2/108 (1.9) | 0/107 (0.0) | NR, NS
Reid, 2008^106^ | Calcium vs. placebo | 600 mg | MI | 2 | All | 3.00 (0.12 to 74.47) | 1/108 (0.9) | 0/107 (0.0) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Nonfatal CVD events | 5 | All | 1.00 (0.73 to 1.36) | 91/730 (12.5) | 91/730 (12.5) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Nonfatal CVD events | 9.5 | All | 0.93 (0.73 to 1.19) | 160/730 (21.9) | 169/730 (23.2) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Other CVD | 5 | All | 1.32 (0.68 to 2.55) | 21/730 (2.9) | 16/730 (2.2) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Other CVD | 9.5 | All | 0.97 (0.62 to 1.53) | 39/730 (5.3) | 40/730 (5.5) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Peripheral artery disease | 5 | All | 0.83 (0.36 to 1.94) | 10/730 (1.4) | 12/730 (1.6) | NR, NS
Lewis, 2011 (CAIFOS)^105^ | Calcium vs. placebo | 1200 mg | Peripheral artery disease | 9.5 | All | 1.06 (0.55 to 2.03) | 19/730 (2.6) | 18/730 (2.5) | NR, NS
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg | Stroke | 6.2 | All | HR=1.06 (0.85 to 1.32) | 160 events/ 2649 (6.0) | 149 events/ 2643 (5.6) | 0.61
Baron, 2005 (CPPS)^85^ | Calcium vs. placebo | 1200 mg | Stroke | 4 | All | 1.10 (0.48 to 2.51) | 12/464 (2.4) | 11/466 (2.6) | NR, NS
Baron, 2015 (VCPPS)^91^ | Calcium vs. no calcium | 1200 mg + 1000 IU Vitamin D | Stroke | 3.8 | All | 0.59 (0.14 to 2.50) | 3/840 (0.4) | 5/835 (0.6) | 0.51
Bolland, 2008 (ACS)^82^ | Calcium vs. placebo | 1 g | Stroke | 5 | All | RR=1.37 (0.83 to 2.28) | 34/732 (4.6) | 25/739 (3.4) | 0.23
Bolland, 2008 (ACS)^82^ | Calcium vs. placebo | 1 g | Stroke | 5 | All | IRR=1.45 (0.88 to 2.49) | 11.4/1000 p-y | 7.8/1000 p-y | 0.15
Baron, 2015 (VCPPS)^91^ | Calcium vs. no calcium | 1200 mg + 1000 IU Vitamin D | Transient ischemic attack | 3.8 | All | 0.14 (0.01 to 2.74) | 0/840 (0.0) | 3/835 (0.4) | 0.12
Reid, 2008^106^ | Calcium vs. placebo | 1200 mg | Transient ischemic attack | 2 | All | 0.99 (0.06 to 16.05) | 1/108 (0.9) | 1/107 (0.9) | NR, NS
Reid, 2008^106^ | Calcium vs. placebo | 600 mg | Transient ischemic attack | 2 | All | 0.33 (0.01 to 8.12) | 0/108 (0.0) | 1/107 (0.9) | NR, NS

* Studies providing estimates other than ORs display effect type.

Abbreviations: ACS = Auckland calcium study; CAIFOS = Calcium Intake Fracture Outcome Study; CG = Control group; CPPS = Calcium Polyp Prevention Study; CVD = Cardiovascular disease; g = Gram; HR = Hazard ratio; IG = Intervention group; IRR = Incidence rate ratio; IU = International units; mg = Milligram; NR = Not reported; NS = Not significant; p-y = Person-years; RR = Risk ratio; VCPPS = Vitamin D/Calcium Polyp Prevention Study.

Appendix F Table 48 Calcium Cancer Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Baron, 2005 (CPPS)^85^ | Calcium vs. placebo | 1200 mg | Adenomas | 4 | All | RR=0.85 (0.74 to 0.98) | 195/454 (43.0) | 234/459 (51.0) | 0.03
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | Any cancer incidence | 6.2 | All | 1.10 (0.87 to 1.39) | 163/1311 (12.4) | 152/1332 (11.4) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | Any cancer incidence | 6.2 | All | | 371 events/2617 | 352 events/2675 | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | Any cancer incidence | 6.2 | All | HR=1.06 (0.91 to 1.23) | 329/2617 (12.6) | 324/2675 (12.1) | 0.485
Baron, 2015 (VCPPS)^91^ | Calcium vs. no calcium | 1200 mg + 1000 IU Vitamin D | Any cancer incidence | 3.8 | All | 0.99 (0.65 to 1.51) | 46/840 (5.5) | 46/835 (5.5) | 0.98
Lappe, 2007^83^ | Calcium vs. placebo | 1500 mg | Any cancer incidence | 4 | All | RR=0.53 (0.27 to 1.03) | 17/445 (3.8) | 20/288 (6.9) | 0.063
Baron, 2015^91^ | Calcium vs. no calcium | 1200 mg Calcium + 1000 IU Vitamin D | Basal cell carcinoma | 3.8 | All | HR=1.01 (0.74 to 1.39) | 80/840 (9.5) | 78/835 (9.3) | 0.93
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | Breast cancer | 6.2 | All | | 21 events/1311 | 16 events/1332 | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | Breast cancer | 6.2 | All | | 41 events/2617 | 39 events/2675 | NR
Lappe, 2007^83^ | Calcium vs. placebo | 1500 mg | Breast cancer | 4 | All | 0.48 (0.16 to 1.39) | 6/445 (1.3) | 8/288 (2.8) | NR, NS
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | Colorectal cancer | 6.2 | All | | 22 events/1311 | 8 events/1332 | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | Colorectal cancer | 6.2 | All | | 46 events/2617 | 25 events/2675 | NR
Baron, 2015 (VCPPS)^91^ | Calcium vs. no calcium | 1200 mg + 1000 IU Vitamin D | Colorectal cancer | 3.8 | All | 4.98 (0.24 to 103.93) | 2/840 (0.2) | 0/835 (0.0) | 0.50
Lappe, 2007^83^ | Calcium vs. placebo | 1500 mg | Colorectal cancer | 4 | All | 0.13 (0.01 to 2.69) | 0/445 (0.0) | 2/288 (0.7) | NR
Baron, 2005 (CPPS)^85^ | Calcium vs. placebo | 1200 mg | Invasive large-bowel cancer | 4 | All | 0.33 (0.03 to 3.22) | 1/464 (0.2) | 3/466 (0.6) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | Lung cancer | 6.2 | All | | 14 events/1311 | 18 events/1332 | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | Lung cancer | 6.2 | All | | 24 events/2617 | 32 events/2675 | NR
Lappe, 2007^83^ | Calcium vs. placebo | 1500 mg | Lung cancer | 4 | All | 0.64 (0.13 to 3.22) | 3/445 (0.7) | 3/288 (1.0) | NR
Lappe, 2007^83^ | Calcium vs. placebo | 1500 mg | Lymph, leukemia, myeloma | 4 | All | 0.64 (0.16 to 2.60) | 4/445 (0.9) | 4/288 (1.4) | NR
Baron, 2015 (VCPPS)^91^ | Calcium vs. no calcium | 1200 mg + 1000 IU Vitamin D | Non-CRC cancer incidence | 3.8 | All | 0.95 (0.62 to 1.45) | 44/840 (5.2) | 46/835 (5.5) | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. placebo | 1000 mg | Prostate cancer | 6.2 | All | | 4 events/1311 | 8 events/1332 | NR
Avenell, 2012 (RECORD)^89^ | Calcium vs. no calcium | 1000 mg + 800 IU Vitamin D | Prostate cancer | 6.2 | All | | 12 events/2617 | 17 events/2675 | NR
Baron, 2005 (CPPS)^85^ | Calcium vs. placebo | 1200 mg | Prostate cancer | 6 | All | RR=0.52 (0.28 to 0.98) | 15/345 (4.3) | 27/327 (8.3) | <0.05
Baron, 2015^91^ | Calcium vs. no calcium | 1200 mg Calcium + 1000 IU Vitamin D | Squamous cell carcinoma | 3.8 | All | HR=0.60 (0.36 to 1.01) | 24/840 (2.9) | 39/835 (4.7) | 0.05

* Studies providing estimates other than ORs display effect type.

Abbreviations: . = not reported; CG = Control group; CPPS = Calcium Polyp Prevention Study; CRC = Colorectal cancer; IG = Intervention group; IU = International units; mg = Milligram; NR = Not reported; NS = Not significant; HR = Hazard ratio; RECORD = Randomized Evaluation of Calcium OR vitamin D; RR = Risk ratio; VCPPS = Vitamin D/Calcium Polyp Prevention Study.

Appendix F Table 49 Calcium Adverse Event Results

Author, Year (Study) | Dose | Comparison | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%)
Fedirko, 2009^114^ | 2 g | Calcium vs. placebo | Any AE | 0.5 | All | 1.00 (0.02 to 52.53) | 0/23 (0.0) | 0/23 (0.0)
Bolland, 2008 (ACS)^82^ | 1 g | Calcium vs. placebo | Constipation | 5 | All | 1.76 (1.31 to 2.37) | 132/732 (18.0) | 82/739 (11.1)
Lewis, 2011 (CAIFOS)^105^ | 1200 mg | Calcium vs. placebo | Constipation | 5 | All | 1.56 (1.12 to 2.17) | 98/730 (13.4) | 66/730 (9.1)
Reid, 2008^106^ | 1200 mg | Calcium vs. placebo | Constipation | 2 | All | 1.50 (0.25 to 9.16) | 3/108 (2.8) | 2/107 (1.9)
Reid, 2008^106^ | 600 mg | Calcium vs. placebo | Constipation | 2 | All | 0.99 (0.14 to 7.16) | 2/108 (1.9) | 2/107 (1.9)
Avenell, 2012 (RECORD)^89^ | 1000 mg | Calcium vs. placebo | Fractures | 3.75 | All | 0.98 (0.78 to 1.21) | 185/1311 (14.1) | 192/1332 (14.4)
Avenell, 2012 (RECORD)^89^ | 1000 mg + 800 IU Vitamin D | Calcium + vitamin D vs. placebo | Fractures | 3.75 | All | 0.94 (0.76 to 1.17) | 179/1306 (13.7) | 192/1332 (14.4)
Avenell, 2012 (RECORD)^89^ | 1000 mg + 800 IU Vitamin D | Calcium vs. no calcium | Fractures | 3.75 | All | HR=0.99 (0.86 to 1.15) | 364/2617 (13.9) | 400/2675 (15.0)
Baron, 2015 (VCPPS)^91^ | 1200 mg + 1000 IU Vitamin D | Calcium vs. no calcium | Fractures | 3.8 | All | 0.85 (0.54 to 1.33) | 37/840 (4.4) | 43/835 (5.1)
Bolland, 2008 (ACS)^82^ | 1 g | Calcium vs. placebo | Fractures | 5 | All | HR=3.55 (1.31 to 9.63) | 17/732 (2.3) | 5/739 (0.7)
Lewis, 2011 (CAIFOS)^105^ | 1200 mg | Calcium vs. placebo | Fractures | 5 | All | HR=0.87 (0.67 to 1.12) | ./730 (.) | ./730 (.)
Reid, 2008^106^ | 1200 mg | Calcium vs. placebo | Fractures | 2 | All | 0.48 (0.14 to 1.63) | 4/108 (3.7) | 8/107 (7.5)
Reid, 2008^106^ | 600 mg | Calcium vs. placebo | Fractures | 2 | All | 0.60 (0.19 to 1.90) | 5/108 (4.6) | 8/107 (7.5)
Wactawski-Wende, 2006 (WHI)^79^ | 1000 mg + 400 IU Vitamin D | Calcium + vitamin D vs. placebo | Fractures | 11.9 | All | HR=0.99 (0.94 to 1.03) | 4013/18176 (22.1) | 4018/18106 (22.2)
Avenell, 2012 (RECORD)^89^ | 1000 mg + 800 IU Vitamin D | Calcium vs. no calcium | Gastrointestinal symptoms | 3.75 | All | 1.44 (1.24 to 1.69) | 428/2617 (16.4) | 319/2675 (11.9)
Baron, 2005 (CPPS)^85^ | 1200 mg | Calcium vs. placebo | GI disease-related hospitalization | 4 | All | 1.21 (0.74 to 1.97) | 38/464 (8.2) | 32/466 (6.9)
Baron, 2015 (VCPPS)^91^ | 1200 mg + 1000 IU Vitamin D | Calcium vs. no calcium | Kidney stones | 3.8 | All | 1.33 (0.68 to 2.62) | 20/840 (2.4) | 15/835 (1.8)
Feskanich, 2002 (NHS-I)^146^ | NR | Calcium vs. no Calcium | Kidney stones | 12 | All | RR=1.20 (1.02 to 1.41) | 227 events/. | 331 events/.
Feskanich, 2002 (NHS-I)^146^ | mg/d | Calcium 1-100 mg/d vs. no Calcium | Kidney stones | 12 | All | RR=1.26 (0.79 to 2.00) | 19 events/. | 331 events/.
Feskanich, 2002 (NHS-I)^146^ | mg/d | Calcium 101-500 mg/d vs. no Calcium | Kidney stones | 12 | All | RR=1.18 (0.98 to 1.43) | 160 events/. | 331 events/.
Feskanich, 2002 (NHS-I)^146^ | mg/d | Calcium ≥500 mg/d vs. no Calcium | Kidney stones | 12 | All | RR=1.21 (0.96 to 1.52) | 98 events/. | 331 events/.
Lappe, 2007^83^ | 1500 mg | Calcium vs. placebo | Kidney stones | 4 | All | 1.95 (0.20 to 18.82) | 3/445 (0.7) | 1/288 (0.3)
Lappe, 2007^83^ | 1500 mg + 1000 IU Vitamin D | Calcium + vitamin D vs. placebo | Kidney stones | 4 | All | 0.64 (0.04 to 10.35) | 1/446 (0.2) | 1/288 (0.3)
Lappe, 2017^93^ | 1500 mg + 2000 IU Vitamin D | Calcium + vitamin D vs. placebo | Kidney stones | 4 | All | 1.60 (0.72 to 3.54) | 16/1102 (1.4) | 10/1095 (0.9)
Lewis, 2011 (CAIFOS)^105^ | 1200 mg | Calcium vs. placebo | Kidney stones | 5 | All | 1.00 (0.14 to 7.12) | 2/730 (0.3) | 2/730 (0.3)
Reid, 2008^106^ | 1200 mg | Calcium vs. placebo | Kidney stones | 2 | All | 0.33 (0.01 to 8.12) | 0/108 (0.0) | 1/107 (0.9)
Reid, 2008^106^ | 600 mg | Calcium vs. placebo | Kidney stones | 2 | All | 0.33 (0.01 to 8.12) | 0/108 (0.0) | 1/107 (0.9)
Wactawski-Wende, 2006 (WHI)^79^ | 1000 mg + 400 IU Vitamin D | Calcium + vitamin D vs. placebo | Kidney stones | 7 | All | HR=1.17 (1.02 to 1.34) | 449/18176 (0.3) | 381/18106 (0.3)
Baron, 2005 (CPPS)^85^ | 1200 mg | Calcium vs. placebo | Non-serious: Cancer-related hospitalization (NS) | 4 | All | | ./464 (.) | ./466 (.)
Baron, 2005 (CPPS)^85^ | 1200 mg | Calcium vs. placebo | Non-serious: Hospitalization (all-cause) (NS) | 4 | All | | ./464 (.) | ./466 (.)
Lappe, 2017^93^ | 1500 mg + 2000 IU Vitamin D | Calcium + vitamin D vs. placebo | Non-serious: Hypercalcemia (NS) | 4 | All | | ./1102 (.) | ./1095 (.)
Lappe, 2007^83^ | 1500 mg | Calcium vs. placebo | Serious AEs | 4 | All | 0.65 (0.01 to 32.73) | 0/445 (0.0) | 0/288 (0.0)
Lappe, 2007^83^ | 1500 mg + 1000 IU Vitamin D | Calcium + vitamin D vs. placebo | Serious AEs | 4 | All | 0.65 (0.01 to 32.65) | 0/446 (0.0) | 0/288 (0.0)
Lappe, 2017^93^ | 1500 mg + 2000 IU Vitamin D | Calcium + vitamin D vs. placebo | Serious AEs | 4 | All | 0.99 (0.02 to 50.12) | 0/1102 (0.0) | 0/1095 (0.0)
Baron, 2005 (CPPS)^85^ | 1200 mg | Calcium vs. placebo | Withdrawals due to AEs | 4 | All | 0.93 (0.42 to 2.05) | 12/464 (2.6) | 13/466 (2.8)
Lappe, 2017^93^ | 1500 mg + 2000 IU Vitamin D | Calcium + vitamin D vs. placebo | Withdrawals due to AEs | 4 | All | 1.24 (0.90 to 1.69) | 93/1102 (8.4) | 76/1095 (6.9)
Reid, 2008^106^ | 1200 mg | Calcium vs. placebo | Withdrawals due to AEs | 2 | All | 3.09 (0.61 to 15.66) | 6/108 (5.6) | 2/107 (1.9)
Reid, 2008^106^ | 600 mg | Calcium vs. placebo | Withdrawals due to AEs | 2 | All | 1.50 (0.25 to 9.16) | 3/108 (2.8) | 2/107 (1.9)

* Studies providing estimates other than ORs display effect type.

Abbreviations: . = not reported; ACS = Auckland calcium study; AE = Adverse event; CAIFOS = Calcium Intake Fracture Outcome Study; CG = Control group; CPPS = Calcium Polyp Prevention Study; g = Grams; GI = Gastrointestinal; HR = Hazard ratio; IG = Intervention group; IU = International units; mg/d = Milligrams per day; NHS – I = Nurses’ Health Study; NR = Not reported; NS = Not significant; RECORD = Randomized Evaluation of Calcium OR vitamin D; RR = Risk ratio; VCPPS = Vitamin D/Calcium Polyp Prevention Study; WHI = Women’s Health Initiative.

Appendix F Table 50 Summary of Results for Studies of Selenium Use

Author, Year (Study) | Quality Rating | Study Design | Study N^*^ | Supplement (daily dose) | ACM | CVD | Cancer | Harms
Clark, 1996 (NPC)^78^ | Fair | RCT | 1312 | Selenium (200 mcg) | ↔ | ↔ | ↓ | ↑? (AE WD)
Lippman, 2009 (SELECT)^80^ | Good | RCT | 25,984 | Selenium (200 mcg) | ↔ | ↔ | ↔ | ↑? (Dermatitis)
Lippman, 2009 (SELECT)^80^ | Good | RCT | 25,984 | Selenium (200 mcg) + Vitamin E (400 IU) | ↔ | ↔ | ↔ | ↔? (Dermatitis)
Rayman, 2012 (UK-PRECISE)^90^ | Fair | RCT | 501 | Selenium (100 mcg) | NR | NR | NR | ↔? (Serious, AE WD)
Rayman, 2012 (UK-PRECISE)^90^ | Fair | RCT | 501 | Selenium (200 mcg) | NR | NR | NR | ↔? (Serious, AE WD)
Rayman, 2012 (UK-PRECISE)^90^ | Fair | RCT | 501 | Selenium (300 mcg) | NR | NR | NR | ↔? (Serious, AE WD)
Rayman, 2018 (DK-PRECISE)^98^ | Fair | RCT | 491 | Selenium (100 mcg) | ↔ | ? | ? | ↑? (ACM, 300 mg/d only); ↔? (AE WD)
Rayman, 2018 (DK-PRECISE)^98^ | Fair | RCT | 491 | Selenium (200 mcg) | ↔ | ? | ? | ↑? (ACM, 300 mg/d only); ↔? (AE WD)
Rayman, 2018 (DK-PRECISE)^98^ | Fair | RCT | 491 | Selenium (300 mcg) | ↔ | ? | ? | ↑? (ACM, 300 mg/d only); ↔? (AE WD)
Thompson, 2016 (Sel/Cel)^99^ | Fair | RCT | 1621 | Selenium (200 mcg) | ↔ | NR | ? | ↔? (Serious, non-serious)

* Includes only participants randomized to an intervention group assigned to take selenium.

Abbreviations: ACM = All-cause mortality; AE = Adverse events; CVD = Cardiovascular disease; DK-PRECISE = Denmark PREvention of Cancer by Intervention with Selenium; mcg = Micrograms; mg/d = Milligrams per deciliter; NPC = Nutritional Prevention of Cancer; NR = Not reported; RCT = Randomized controlled trial; Sel = Selenium; Sel/Cel = Selenium and Celecoxib; SELECT = Selenium and Vitamin E Cancer Prevention Trial; UK-PRECISE = United Kingdom PREvention of Cancer by Intervention with Selenium; WD = Withdrawal.

↑ Likely non-trivial increase in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and Cis minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

↑? Possible non-trivial increase in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and Cis minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↔ Evidence of no to minimal group differences (e.g., few to no statistically significant findings with reasonably precise estimates [e.g., >~20 events in all treatment arms])

↔? Limited evidence of no to minimal group differences (e.g., few to no statistically significant findings, but imprecise estimates/side Cis).

↓? Possible non-trivial decrease in events (e.g., statistically significant effects of questionable clinical importance, or moderate to large effect size and Cis minimally overlap line of no effect or inconsistency of effects where multiple related effects are reported).

↓ Likely non-trivial decrease in events (e.g., magnitude of effect size likely to be clinically important with statistically significant effect, or large effect size and Cis minimally overlap the line of no effect; and with reasonable consistency of effects where multiple related effects are reported).

? Insufficient evidence to evaluate (e.g., very few [e.g., <10] events).

Judgement for symbols based on totality of evidence for each study, considering statistical and clinical significance.

Appendix F Table 51 Selenium Meta-Analysis Results: Results of Meta-Analyses by Outcome, Primary Analysis Listed First for Each Outcome, Followed by Sensitivity Analyses

Outcome | Model/Analysis | Pooled OR (95% CI) | No. studies | N analyzed | I^2^, % | Tau^2^
All-cause mortality | MH | 0.94 (0.83 to 1.07) | 4 | 20,832 | NA | NA
All-cause mortality | Peto | 0.94 (0.82 to 1.08) | 4 | 20,832 | 4.7 | .00
All-cause mortality | REML-KH | 0.94 (0.79 to 1.12) | 4 | 20,832 | 26.4 | .01
CVD mortality | MH | 0.93 (0.75 to 1.14) | 3 | 19,008 | NA | NA
CVD mortality | Peto | 0.93 (0.75 to 1.14) | 3 | 19,008 | 0 | .00
CVD mortality | REML-KH | 0.93 (0.74 to 1.18) | 3 | 19,008 | 14.4 | .01
Cancer mortality | MH | 0.86 (0.69 to 1.06) | 3 | 19,008 | NA | NA
Cancer mortality | Peto | 0.74 (0.42 to 1.30) | 3 | 19,008 | 71.6 | .15
Cancer mortality | REML-KH | 0.74 (0.26 to 2.08) | 3 | 19,008 | 59.4 | .10
Colorectal cancer | Peto | 0.82 (0.44 to 1.51) | 3 | 20,584 | 53.8 | .16
Colorectal cancer | MH | 0.91 (0.67 to 1.25) | 3 | 20,584 | NA | NA

Abbreviations: CI = Confidence interval; CVD = Cardiovascular disease; MH = Mantel-Haenszel common (fixed) effects model; NA = Not applicable; No. = Number; OR = Odds ratio; Peto = Peto odds ratio random effects REML model; REML-KH = Random effects restricted maximum likelihood model with the Knapp-Hartung adjustment.

Appendix F Table 52 Selenium Mortality Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | All-cause mortality | 6.3 | All | HR=0.79 (0.61 to 1.02) | 108/653 (16.5) | 129/659 (19.6) | 0.07
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | All-cause mortality | 7.6 | All | HR=0.95 (0.73 to 1.24) | 110/504 (21.8) | 111/500 (22.2) | 0.71
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | All-cause mortality | 5.5 | All | HR=0.99 (0.82 to 1.19) | 378/8752 (4.3) | 382/8696 (4.4) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | All-cause mortality | 7.1 | All | HR=0.98 (0.84 to 1.14) | 551/8752 (6.3) | 564/8696 (6.5) | 0.67
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | All-cause mortality | 5.5 | All | HR=0.94 (0.77 to 1.13) | 359/8703 (4.1) | 382/8696 (4.4) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | All-cause mortality | 7.1 | All | HR=0.96 (0.82 to 1.12) | 542/8702 (6.2) | 564/8696 (6.5) | 0.47
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 300 mcg | All-cause mortality | 5 | All | HR=1.62 (0.66 to 3.96) | 12/119 (10.1) | 8/126 (6.3) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 300 mcg | All-cause mortality | 15.9 | All | HR=1.59 (1.02 to 2.46) | 47/119 (39.5) | 35/126 (27.8) | <0.05
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 300 mcg | All-cause mortality | 15.9 | Females | HR=1.52 (0.74 to 3.14) | 17 events/60 | 13 events/66 | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 300 mcg | All-cause mortality | 15.9 | Males | HR=1.64 (0.95 to 2.84) | 30 events/59 | 22 events/60 | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 200 mcg | All-cause mortality | 5 | All | HR=0.64 (0.21 to 1.94) | 5/122 (4.1) | 8/126 (6.3) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 200 mcg | All-cause mortality | 15.9 | All | HR=0.99 (0.62 to 1.59) | 35/122 (28.7) | 35/126 (27.8) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 200 mcg | All-cause mortality | 15.9 | Females | HR=0.78 (0.34 to 1.84) | 9 events/56 | 13 events/66 | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 200 mcg | All-cause mortality | 15.9 | Males | HR=1.02 (0.58 to 1.79) | 26 events/66 | 22 events/60 | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 100 mcg | All-cause mortality | 5 | All | HR=0.75 (0.26 to 2.16) | 6/124 (4.8) | 8/126 (6.3) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 100 mcg | All-cause mortality | 15.9 | All | HR=1.15 (0.73 to 1.80) | 41/124 (33.1) | 35/126 (27.8) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 100 mcg | All-cause mortality | 15.9 | Females | HR=1.38 (0.65 to 2.89) | 15 events/54 | 13 events/66 | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 100 mcg | All-cause mortality | 15.9 | Males | HR=0.94 (0.53 to 1.67) | 26 events/70 | 22 events/60 | NR, NS
Thompson, 2016 (Sel/Cel)^99^ | Selenium vs. placebo | 200 mcg | All-cause mortality | 3 | All | 1.07 (0.54 to 2.13) | 17/910 (1.9) | 16/914 (1.8) | NR
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Any cancer deaths | 6.3 | All | HR=0.48 (0.31 to 0.76) | 29/653 (4.4) | 57/659 (8.6) | 0.001
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Any cancer deaths | 7.4 | All | HR=0.59 (0.39 to 0.87) | 40/621 (6.4) | 66/629 (10.5) | 0.008
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Any cancer deaths | 5.5 | All | HR=1.02 (0.74 to 1.41) | 128/8752 (1.5) | 125/8696 (1.4) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Any cancer deaths | 5.5 | All | HR=0.93 (0.67 to 1.30) | 117/8703 (1.3) | 125/8696 (1.4) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 300 mcg | Any cancer deaths | 5 | All | HR=2.17 (0.65 to 7.21) | 8/119 (6.7) | 4/126 (3.2) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 300 mcg | Any cancer deaths | 15.9 | All | HR=1.78 (0.94 to 3.34) | 24/119 (20.2) | 16/126 (12.7) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 200 mcg | Any cancer deaths | 5 | All | HR=0.77 (0.17 to 3.46) | 3/122 (2.5) | 4/126 (3.2) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 200 mcg | Any cancer deaths | 15.9 | All | HR=0.94 (0.46 to 1.90) | 15/122 (12.3) | 16/126 (12.7) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 100 mcg | Any cancer deaths | 5 | All | HR=0.75 (0.17 to 3.36) | 3/124 (2.4) | 4/126 (3.2) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 100 mcg | Any cancer deaths | 15.9 | All | HR=1.22 (0.63 to 2.36) | 20/124 (16.1) | 16/126 (12.7) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Bladder cancer deaths | 7.1 | All | 0.50 (0.12 to 1.99) | 3/8752 (0.0) | 6/8696 (0.1) | NR
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Bladder cancer deaths | 7.1 | All | 0.50 (0.12 to 2.00) | 3/8703 (0.0) | 6/8696 (0.1) | NR
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Colorectal cancer deaths | 5.5 | All | HR=1.00 (0.32 to 3.16) | 10/8752 (0.1) | 10/8696 (0.1) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Colorectal cancer deaths | 5.5 | All | HR=1.49 (0.52 to 4.28) | 15/8703 (0.2) | 10/8696 (0.1) | NR, NS
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | CVD deaths | 6.3 | All | HR=0.96 (0.64 to 1.44) | 47/653 (7.2) | 46/659 (7.0) | 0.83
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | CVD deaths | 7.6 | All | HR=1.22 (0.76 to 1.95) | 40/504 (7.9) | 31/500 (6.2) | 0.41
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | CVD deaths | 5.5 | All | HR=0.91 (0.66 to 1.24) | 129/8752 (1.5) | 142/8696 (1.6) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | CVD deaths | 5.5 | All | HR=0.82 (0.60 to 1.13) | 117/8703 (1.3) | 142/8696 (1.6) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 300 mcg | CVD deaths | 5 | All | HR=2.17 (0.40 to 11.85) | 4/119 (3.4) | 2/126 (1.6) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 300 mcg | CVD deaths | 15.9 | All | HR=1.51 (0.69 to 3.33) | 14/119 (11.8) | 11/126 (8.7) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 200 mcg | CVD deaths | 5 | All | HR=0.52 (0.05 to 5.72) | 1/122 (0.8) | 2/126 (1.6) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 200 mcg | CVD deaths | 15.9 | All | HR=1.00 (0.44 to 2.31) | 11/122 (9.0) | 11/126 (8.7) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 100 mcg | CVD deaths | 5 | All | HR=1.00 (0.14 to 7.11) | 2/124 (1.6) | 2/126 (1.6) | NR, NS
Rayman, 2018 (DK-PRECISE)^98^ | Selenium vs. placebo | 100 mcg | CVD deaths | 15.9 | All | HR=0.62 (0.24 to 1.61) | 7/124 (5.6) | 11/126 (8.7) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Hemorrhagic stroke deaths | 5.5 | All | HR=1.12 (0.32 to 3.93) | 9/8752 (0.1) | 8/8696 (0.1) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Hemorrhagic stroke deaths | 5.5 | All | HR=1.49 (0.46 to 4.84) | 12/8703 (0.1) | 8/8696 (0.1) | NR, NS
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Lung cancer deaths | 6.3 | All | HR=0.47 (0.23 to 0.93) | 12/653 (1.8) | 25/659 (3.8) | 0.03
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Lung cancer deaths | 5.5 | All | HR=1.10 (0.63 to 1.91) | 45/8752 (0.5) | 41/8696 (0.5) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Lung cancer deaths | 5.5 | All | HR=0.95 (0.53 to 1.69) | 39/8703 (0.4) | 41/8696 (0.5) | NR, NS
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | MI, fatal | 7.6 | All | HR=1.08 (0.42 to 2.80) | 9/504 (1.8) | 8/500 (1.6) | 0.88
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Prostate cancer deaths | 5.5 | All | 2.98 (0.12 to 73.19) | 1/8752 (0.0) | 0/8696 (0.0) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Prostate cancer deaths | 5.5 | All | 1.00 (0.02 to 50.36) | 0/8703 (0.0) | 0/8696 (0.0) | NR, NS

* Studies providing estimates other than ORs display effect type.

Abbreviations: CG = Control group; CVD = Cardiovascular disease; DK-PRECISE = Denmark PREvention of Cancer by Intervention with Selenium; mcg = Microgram; HR = Hazard ratio; IG = Intervention group; IU = International units; MI = Myocardial infarction; NPC = Nutritional Prevention of Cancer; NR = Not reported; NS = Not significant; OR = Odds ratio; SELECT = Selenium and Vitamin E Cancer Prevention Trial.

Appendix F Table 53 Selenium Cardiovascular Disease Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%) | p-value
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Cerebrovascular events | 7.6 | All | HR=1.02 (0.65 to 1.59) | 40/504 (7.9) | 37/500 (7.4) | 0.94
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | CHD events | 7.6 | All | HR=1.04 (0.73 to 1.49) | 63/504 (12.5) | 59/500 (11.8) | 0.81
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Coronary artery bypass graft | 7.6 | All | HR=1.30 (0.59 to 2.84) | 15/504 (3.0) | 11/500 (2.2) | 0.51
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | CVD events | 7.6 | All | HR=1.03 (0.78 to 1.37) | 103/504 (20.4) | 96/500 (19.2) | 0.81
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | CVD events | 5.5 | All | RR=1.02 (0.92 to 1.13) | 1080/8752 (12.3) | 1050/8696 (12.1) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | CVD events | 7.1 | All | HR=0.97 (0.86 to 1.09) | 939/8752 (10.7) | 969/8696 (11.1) | 0.45
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | CVD events | 5.5 | All | RR=0.99 (0.89 to 1.10) | 1041/8703 (12.0) | 1050/8696 (12.1) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | CVD events | 7.1 | All | HR=0.97 (0.86 to 1.09) | 943/8702 (10.8) | 969/8696 (11.1) | 0.51
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | MI | 7.6 | All | HR=0.94 (0.61 to 1.44) | 41/504 (8.1) | 43/500 (8.6) | 0.77
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | MI, nonfatal | 7.6 | All | HR=0.91 (0.56 to 1.47) | 32/504 (6.3) | 35/500 (7.0) | 0.69
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Other CVD | 7.6 | All | HR=0.98 (0.28 to 3.39) | 5/504 (1.0) | 5/500 (1.0) | 0.87
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Percutaneous transluminal coronary angioplasty | 7.6 | All | HR=1.36 (0.43 to 4.31) | 7/504 (1.4) | 5/500 (1.0) | 0.60
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Stroke | 7.6 | All | HR=1.02 (0.63 to 1.65) | 35/504 (6.9) | 32/500 (6.4) | 0.92
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Stroke | 5.5 | All | 0.92 (0.65 to 1.30) | 62/8752 (0.7) | 67/8696 (0.8)
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Stroke | 5.5 | All | 1.18 (0.85 to 1.64) | 79/8703 (0.9) | 67/8696 (0.8)
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Stroke, Hemorrhagic | 5.5 | All | RR=0.99 (0.33 to 2.98) | 11/8752 (0.1) | 11/8696 (0.1) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Stroke, Hemorrhagic | 5.5 | All | RR=1.09 (0.37 to 3.19) | 12/8703 (0.1) | 11/8696 (0.1) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Stroke, Ischemic | 5.5 | All | RR=0.90 (0.55 to 1.49) | 51/8752 (0.6) | 56/8696 (0.6) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Stroke, Ischemic | 5.5 | All | RR=1.20 (0.75 to 1.90) | 67/8703 (0.8) | 56/8696 (0.6) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Stroke, nonfatal | 5.5 | All | 0.79 (0.58 to 1.07) | 73/8752 (0.8) | 92/8696 (1.1) | NR
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Stroke, nonfatal | 5.5 | All | 1.08 (0.81 to 1.43) | 99/8703 (1.1) | 92/8696 (1.1) | NR

* Studies providing estimates other than ORs display effect type.

Abbreviations: CG = Control group; CHD = Coronary heart disease; CVD = Cardiovascular disease; HR = Hazard ratio; IG = Intervention group; IU = International units; mcg = Micrograms; MI = Myocardial infarction; NPC = Nutritional Prevention of Cancer; NR = Not reported; NS = Not significant; OR = Odds ratio; RR = Risk ratio; SELECT = Selenium and Vitamin E Cancer Prevention Trial.

Appendix F Table 54 Selenium Cancer Results

Author, Year (Study) | Comparison | Supplement (daily dose) | Outcome | Followup, years | Group | Effect | IG n/N (%) | CG n/N (%) | p-value
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Any cancer incidence | 6.3 | All | HR=0.61 (0.46 to 0.82) | 77/653 (11.8) | 119/659 (18.1) | <0.001
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Any cancer incidence | 7.4 | All | HR=0.75 (0.58 to 0.97) | 105/621 (16.9) | 137/629 (21.8) | 0.03
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Any cancer incidence | 7.4 | Females | HR=1.20 (0.66 to 2.20) | 23/161 (14.3) | 20/157 (12.7) | 0.55
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Any cancer incidence | 7.4 | Males | HR=0.67 (0.50 to 0.89) | 82/460 (17.8) | 117/472 (24.8) | 0.005
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Any cancer incidence | 5.5 | All | HR=1.01 (0.89 to 1.15) | 837/8752 (9.6) | 824/8696 (9.5) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Any cancer incidence | 7.1 | All | HR=1.02 (0.92 to 1.14) | 1132/8752 (12.9) | 1108/8696 (12.7) | 0.59
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Any cancer incidence | 5.5 | All | HR=1.02 (0.90 to 1.16) | 846/8703 (9.7) | 824/8696 (9.5) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Any cancer incidence | 7.1 | All | HR=1.02 (0.92 to 1.14) | 1149/8702 (13.2) | 1108/8696 (12.7) | 0.60
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Breast cancer | 6.3 | Females | HR=2.95 (0.80 to 10.90) | 9/172 (5.2) | 3/161 (1.9) | 0.11
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Breast cancer | 7.4 | Females | HR=1.89 (0.69 to 5.14) | 11/161 (6.8) | 6/157 (3.8) | 0.21
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Carcinomas | 6.3 | All | HR=0.54 (0.39 to 0.75) | 59/653 (9.0) | 104/659 (15.8) | <0.001
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Colorectal cancer | 6.3 | All | HR=0.39 (0.17 to 0.90) | 8/653 (1.2) | 19/659 (2.9) | 0.03
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Colorectal cancer | 7.4 | All | HR=0.46 (0.21 to 1.02) | 9/621 (1.4) | 19/629 (3.0) | 0.057
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Colorectal cancer | 5.5 | All | HR=1.05 (0.66 to 1.67) | 63/8752 (0.7) | 60/8696 (0.7) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Colorectal cancer | 7.1 | All | HR=0.96 (0.63 to 1.46) | 74/8752 (0.8) | 75/8696 (0.9) | 0.79
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Colorectal cancer | 5.5 | All | HR=1.28 (0.82 to 2.00) | 77/8703 (0.9) | 60/8696 (0.7) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Colorectal cancer | 7.1 | All | HR=1.21 (0.81 to 1.81) | 93/8702 (1.1) | 75/8696 (0.9) | 0.22
Thompson, 2016 (Sel/Cel)^99^ | Selenium vs. placebo | 200 mcg | Colorectal cancer | 3 | All | 1.26 (0.34 to 4.70) | 5/910 (0.5) | 4/914 (0.4) | NR
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Esophageal cancer | 6.3 | All | HR=0.30 (0.06 to 1.49) | 2/653 (0.3) | 6/659 (0.9) | 0.14
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Esophageal cancer | 7.4 | All | HR=0.40 (0.08 to 2.07) | 2/621 (0.3) | 5/629 (0.8) | 0.28
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Head and neck cancer | 6.3 | All | HR=0.77 (0.27 to 2.24) | 6/653 (0.9) | 8/659 (1.2) | 0.64
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Head and neck cancer | 7.4 | All | HR=1.27 (0.47 to 3.42) | 9/621 (1.4) | 7/629 (1.1) | 0.63
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Leukemia/lymphoma | 6.3 | All | HR=1.50 (0.49 to 4.60) | 8/653 (1.2) | 5/659 (0.8) | 0.48
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Leukemia/lymphoma | 7.4 | All | HR=1.25 (0.43 to 3.61) | 8/621 (1.3) | 6/629 (1.0) | 0.68
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Lung cancer | 6.3 | All | HR=0.56 (0.31 to 1.01) | 17/653 (2.6) | 31/659 (4.7) | 0.05
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Lung cancer | 7.4 | All | HR=0.74 (0.44 to 1.24) | 25/621 (4.0) | 35/629 (5.6) | 0.26
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Lung cancer | 5.5 | All | HR=1.12 (0.73 to 1.72) | 75/8752 (0.9) | 67/8696 (0.8) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Lung cancer | 7.1 | All | HR=1.02 (0.70 to 1.50) | 94/8752 (1.1) | 92/8696 (1.1) | 0.89
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Lung cancer | 5.5 | All | HR=1.16 (0.76 to 1.78) | 78/8703 (0.9) | 67/8696 (0.8) | NR, NS
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Lung cancer | 7.1 | All | HR=1.11 (0.76 to 1.62) | 104/8702 (1.2) | 92/8696 (1.1) | 0.48
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Melanoma skin cancer | 6.3 | All | HR=0.92 (0.34 to 2.45) | 8/653 (1.2) | 8/659 (1.2) | 0.87
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Melanoma skin cancer | 7.4 | All | HR=1.18 (0.49 to 2.85) | 11/621 (1.8) | 9/629 (1.4) | 0.71
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Noncarcinomas | 6.3 | All | HR=1.16 (0.60 to 2.27) | 19/653 (2.9) | 16/659 (2.4) | 0.65
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Other carcinomas | 6.3 | All | HR=0.54 (0.18 to 1.62) | 5/653 (0.8) | 9/659 (1.4) | 0.27
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Other carcinomas | 7.4 | All | HR=0.67 (0.24 to 1.88) | 6/621 (1.0) | 9/629 (1.4) | 0.44
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Other noncarcinomas | 6.3 | All | HR=0.99 (0.20 to 4.94) | 3/653 (0.5) | 3/659 (0.5) | 0.99
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Other noncarcinomas | 7.4 | All | HR=0.59 (0.14 to 2.47) | 3/621 (0.5) | 5/629 (0.8) | 0.47
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Prostate cancer | 6.3 | All | HR=0.35 (0.18 to 0.65) | 13/481 (2.7) | 35/498 (7.0) | 0.001
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Prostate cancer | 7.4 | All | HR=0.48 (0.28 to 0.80) | 22/457 (4.8) | 42/470 (8.9) | 0.005
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Prostate cancer | 5.5 | All | HR=1.04 (0.90 to 1.18) | 432/8752 (4.9) | 416/8696 (4.8) | 0.62
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Prostate cancer | 7.1 | All | HR=1.09 (0.93 to 1.27) | 575/8752 (6.6) | 529/8696 (6.1) | 0.18
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Prostate cancer | 5.5 | All | HR=1.05 (0.88 to 1.25) | 437/8702 (5.0) | 416/8696 (4.8) | 0.52
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Prostate cancer | 7.1 | All | HR=1.05 (0.89 to 1.22) | 555/8702 (6.4) | 529/8696 (6.1) | 0.46
Thompson, 2016 (Sel/Cel)^99^ | Selenium vs. placebo | 200 mcg | Squamous cell carcinoma | 3 | All | HR=1.34 (0.76 to 2.37) | 10.9/1000 p-y | 8.2/1000 p-y | 0.32
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Urinary bladder cancer | 6.3 | All | HR=1.27 (0.44 to 3.67) | 8/653 (1.2) | 6/659 (0.9) | 0.66
Clark, 1996 (NPC)^78^ | Selenium vs. placebo | 200 mcg | Urinary bladder cancer | 7.4 | All | HR=1.28 (0.50 to 3.25) | 10/621 (1.6) | 8/629 (1.3) | 0.60
Lippman, 2009 (SELECT)^80^ | Selenium vs. placebo | 200 mcg | Urinary bladder cancer | 7.1 | All | HR=1.13 (0.78 to 1.63) | 60/8752 (0.7) | 53/8696 (0.6) | 0.52
Lippman, 2009 (SELECT)^80^ | Selenium + vitamin E vs. placebo | 200 mcg + 400 IU Vitamin E | Urinary bladder cancer | 7.1 | All | HR=1.05 (0.71 to 1.51) | 55/8703 (0.6) | 53/8696 (0.6) | 0.86

Abbreviation: CG = Control group; HR = Hazard ratio; IG = Intervention group; IU = International unit; mcg = Microgram; NPC = Nutritional Prevention of Cancer; NR = Not reported; NS = Not significant; Sel/Cel = Selenium and Celecoxib; SELECT = Selenium and Vitamin E Cancer Prevention Trial.

Appendix F Table 55 Selenium Adverse Event Results

Author, Year (Study) | Dose | Comparison | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%)
Lippman, 2009 (SELECT)^80^ | 200 mcg | Selenium vs. placebo | Dermatitis | 5.5 | All | RR=1.17 (1.00 to 1.35) | 605/8752 (6.9) | 516/8696 (5.9)
Lippman, 2009 (SELECT)^80^ | 200 mcg + 400 IU Vitamin E | Selenium + vitamin E vs. placebo | Dermatitis | 5.5 | All | RR=1.07 (0.92 to 1.25) | 554/8703 (6.4) | 516/8696 (5.9)
Lippman, 2009 (SELECT)^80^ | 200 mcg | Selenium vs. placebo | Non-serious: Fatigue (NS); Halitosis (NS); Nail changes (NS) | 5.5 | All | | ./8737 (.) | ./8696 (.)
Lippman, 2009 (SELECT)^80^ | 200 mcg + 400 IU Vitamin E | Selenium + vitamin E vs. placebo | Non-serious: Fatigue (NS); Halitosis (NS); Nail changes (NS) | 5.5 | All | | ./8737 (.) | ./8696 (.)
Thompson, 2016 (Sel/Cel)^99^ | 200 mcg | Selenium vs. placebo | Non-serious: Brittle hair and/or nails (NS) | 3 | All | HR=0.86 (0.53 to 1.39) | 12.2/1000 p-y | 13.8/1000 p-y
Rayman, 2012 (UK-PRECISE)^90^ | 100 mcg | Selenium vs. placebo | Serious AEs | 0.5 | All | 0.93 (0.02 to 47.45) | 0/120 (0.0) | 0/112 (0.0)
Rayman, 2012 (UK-PRECISE)^90^ | 200 mcg | Selenium vs. placebo | Serious AEs | 0.5 | All | 0.90 (0.02 to 45.92) | 0/124 (0.0) | 0/112 (0.0)
Rayman, 2012 (UK-PRECISE)^90^ | 300 mcg | Selenium vs. placebo | Serious AEs | 0.5 | All | 0.96 (0.02 to 48.66) | 0/117 (0.0) | 0/112 (0.0)
Thompson, 2016 (Sel/Cel)^99^ | 200 mcg | Selenium vs. placebo | Serious AEs | 3 | All | HR=1.00 (0.83 to 1.21) | 101.3/1000 p-y | 100.3/1000 p-y
Clark, 1996 (NPC)^78^ | 200 mcg | Selenium vs. placebo | Withdrawals due to AEs | 6.3 | All | 1.53 (0.77 to 3.04) | 21/653 (3.2) | 14/659 (2.1)
Rayman, 2012 (UK-PRECISE)^90^ | 100 mcg | Selenium vs. placebo | Withdrawals due to AEs | 0.5 | All | 0.93 (0.13 to 6.73) | 2/120 (1.7) | 2/112 (1.8)
Rayman, 2012 (UK-PRECISE)^90^ | 200 mcg | Selenium vs. placebo | Withdrawals due to AEs | 0.5 | All | 0.45 (0.04 to 5.00) | 1/124 (0.8) | 2/112 (1.8)
Rayman, 2012 (UK-PRECISE)^90^ | 300 mcg | Selenium vs. placebo | Withdrawals due to AEs | 0.5 | All | 4.04 (0.84 to 19.44) | 8/117 (6.8) | 2/112 (1.8)
Rayman, 2018 (DK-PRECISE^98^ | 300 mcg | Selenium vs. placebo | Withdrawals due to AEs | 5 | All | 1.17 (0.50 to 2.77) | 12/119 (10.1) | 11/126 (8.7)
Rayman, 2018 (DK-PRECISE)^98^ | 200 mcg | Selenium vs. placebo | Withdrawals due to AEs | 5 | All | 1.93 (0.88 to 4.24) | 19/122 (15.6) | 11/126 (8.7)
Rayman, 2018 (DK-PRECISE)^98^ | 100 mcg | Selenium vs. placebo | Withdrawals due to AEs | 5 | All | 1.78 (0.80 to 3.93) | 18/124 (14.5) | 11/126 (8.7)

* Studies providing estimates other than ORs display effect type.

Abbreviations: . = not reported; AE = Adverse event; CG = Control group; DK-PRECISE = Denmark PREvention of Cancer by Intervention with Selenium; HR = Hazard ratio; IG = Intervention group; IU = International units; mcg = Microgram; NPC = Nutritional Prevention of Cancer; NS = Not significant; p-y = Person-years; RR = Risk ratio; Sel/Cel = Selenium and Celecoxib; SELECT = Selenium and Vitamin E Cancer Prevention Trial; UK-PRECISE = United Kingdom PREvention of Cancer by Intervention with Selenium.

Appendix F Table 56 Zinc Adverse Event Results

Author, Year (Study) | Dose | Comparison | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%)
Coehlo, 2013^145^ | 220 mg | Zinc vs. placebo | Serious AEs | 0.75 | All | 1.02 (0.02 to 51.91) | 0/99 (0.0)^†^ | 0/101 (0.0)^†^
Hemila, 2020^138^ | 78 mg | Zinc vs. placebo | Any AE | 0.03 | All | 3.81 (1.57 to 9.24) | 29/46 (63.0) | 13/42 (31.0)
Coehlo, 2013^145^ | 220 mg | Zinc vs. placebo | Withdrawals due to AEs | 0.75 | All | 0.51 (0.05 to 5.66) | 1/99 (1.0)^†^ | 2/101 (2.0)^†^
Hemila, 2020^138^ | 78 mg | Zinc vs. placebo | Withdrawals due to AEs | 0.03 | All | 2.8 (0.11 to 70.68) | 1/46 (2.2) | 0/42 (0.0)

* Studies providing estimates other than ORs display effect type.

† Randomized crossover trial; N analyzed represents the sample receiving the supplement or placebo at any time.

Abbreviations: AE = Adverse event; CG = Control group; IG = Intervention group; mg = Milligram; NHS-I = Nurses’ Health Study; NR = Not reported; OR = Odds ratio.

Appendix F Table 57 Magnesium Adverse Event Results

Author, Year (Study) | Dose | Comparison | Outcome | Followup, years | Group | Effect^*^ | IG n/N (%) | CG n/N (%)
Schutten, 2021^144^ | 350 mg | Magnesium vs. placebo | Any AE | 0.46 | All | 3.00 (0.12 to 77.31) | 1/25 (4.0) | 0/24 (0.0)
Schutten, 2021^144^ | 350 mg | Magnesium vs. placebo | Serious AEs | 0.46 | All | 0.96 (0.02 to 50.35) | 0/25 (0.0) | 0/24 (0.0)
Alonso, 2020^137^ | 400 mg | Magnesium vs. placebo | Gastrointestinal symptoms | 0.19 | All | 15.0 (3 to 74.96) | 15/29 (50.0) | 2/30 (7.0)
Alonso, 2020^137^ | 400 mg | Magnesium vs. placebo | Withdrawals due to AEs | 0.19 | All | 3.21 (0.13 to 82.07) | 1/29 (3.4) | 0/30 (0.0)

* Studies providing estimates other than ORs display effect type.

Abbreviations: AE = Adverse event; CG = Control group; IG = Intervention group; mg = Milligram; NHS-I = Nurses’ Health Study; NR = Not reported; OR = Odds ratio.