# Appendix E Detailed Results Figures

Appendix E Figure 1 Forest Plot Showing Odds Ratios of All-Cause Mortality for Multivitamins

Abbreviations: CG = Control group; CI = Confidence interval; CTNS = Clinical Trial of Nutritional Supplements and Age-Related Cataract; IG = Intervention group; MAVIS = Mineral and Vitamin Intervention Trial; OR = Odds ratio; PHS-II = Physicians’ Health Study; REACT = Roche European American Cataract Trial; REML = Random effects restricted maximum likelihood model; SUVIMAX = The Supplémentation en Vitamines et Minéraux Antioxydants.

This figure is a forest plot showing odds ratios of all-cause mortality for multivitamins

Appendix E Figure 2 Forest Plot Showing Odds Ratios of CVD Outcomes for Multivitamins

Abbreviations: CG = Control group; CI = Confidence interval; CTNS = Clinical Trial of Nutritional Supplements and Age-Related Cataract; IG = Intervention group; PHS-II = Physicians’ Health Study; REACT = Roche European American Cataract Trial.

This figure is a forest plot showing odds ratios of CVD outcomes for multivitamins

Appendix E Figure 3 Forest Plot Showing Odds Ratios of Primary Cancer Outcomes for Multivitamins

Abbreviations: CG = Control group; CI = Confidence interval; CTNS = Clinical Trial of Nutritional Supplements and Age-Related Cataract; IG = Intervention group; OR = Odds ratio; PHS-II = Physicians’ Health Study; REACT = Roche European American Cataract Trial; REML = Random effects restricted maximum likelihood model; SUVIMAX = The Supplémentation en Vitamines et Minéraux Antioxydants.

This figure is a forest plot showing odds ratios of primary cancer outcomes for multivitamins

Appendix E Figure 4 Forest Plot Showing Odds Ratios of All-Cause Mortality for Beta-Carotene

Abbreviations: ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CARET = The Beta-Carotene and Retinol Efficacy Trial; CG = Control group; CI = Confidence interval; IG = Intervention group; mg/d = Milligram per day; NSCPS = Nambour Skin Cancer Prevention Study; OR = Odds ratio; PHS-I = Physicians’ Health Study-I; SCPS = Skin Cancer Prevention Study; WHS = Women’s Health Study; Yr = Year.

This figure is a forest plot showing odds ratios of all-cause mortality for beta-carotene

Appendix E Figure 5 Forest Plot Showing Odds Ratios of Primary Cardiovascular Outcomes for Beta-Carotene

Abbreviations: ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CG = Control group; CI = Confidence interval; CVD = Cardiovascular disease; IG = Intervention group; mg/d = Milligram per day; MI = Myocardial infarction; NSCPS = Nambour Skin Cancer Prevention Study; OR = Odds ratio; PHS-I = Physicians’ Health Study-I; SCPS = Skin Cancer Prevention Study; WHS = Women’s Health Study; Yr = Year.

This figure is a forest plot showing odds ratios of primary cardiovascular outcomes for beta-carotene

Appendix E Figure 6 Forest Plot Showing Odds Ratios of Primary Cancer Outcomes for Beta-Carotene

Abbreviations: ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CARET = The Beta-Carotene and Retinol Efficacy Trial; CG = Control group; CI = Confidence interval; IG = Intervention group; mg/d = Milligram per day; NSCPS = Nambour Skin Cancer Prevention Study; OR = Odds ratio; PHS-I = Physicians’ Health Study-I; SCPS = Skin Cancer Prevention Study; WHS = Women’s Health Study; Yrs = Years.

This figure is a forest plot showing odds ratios of primary cancer outcomes for beta-carotene

Appendix E Figure 7 Forest Plot Showing Odds Ratios of All-Cause Mortality for Vitamin D, With or Without Calcium

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; IU/d =International units per day; KOS = Kuopio Osteoporosis Risk Factor and Prevention Study; OR = Odds ratio; OSTPRE-FPS = Osteoporosis Risk Factor and Prevention Fracture Prevention Study; PODA = The physical performance, osteoporosis prevention, and vitamin D in older African Americans; RECORD = Randomised evaluation of calcium or vitamin D; VCPPS = Vitamin D/Calcium Polyp Prevention Study; VITAL = VITamin D and OmegA-3 TriaL; ViDa = Vitamin D Assessment Study; WHI = Women’s Health Initiative.

This figure is a forest plot showing odds ratios of all-cause mortality for vitamin D, with or without calcium

Appendix E Figure 8 Forest Plot Showing Odds Ratios of Cancer Mortality and Cancer Incidence for Vitamin D, With or Without Calcium

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; IU/day = International units per day; KOS = Kuopio Osteoporosis Risk Factor and Prevention Study; OR = Odds ratio; RECORD = Randomised evaluation of calcium or vitamin D; VCPPS = Vitamin D/Calcium Polyp Prevention Study; VITAL = VITamin D and OmegA-3 TriaL; ViDa = Vitamin D Assessment Study; WHI = Women’s Health Initiative.

This figure is a forest plot showing odds ratios of cancer mortality and cancer incidence for vitamin D, with or without calcium

Appendix E Figure 9 Forest Plot Showing Odds Ratios of Site-Specific Cancer Incidence for Vitamin D, With or Without Calcium

Abbreviations: CG = Control group; CI = Confidence interval; IG = Intervention group; IU/d = Internatioinal units per day; OR = Odds ratio; REML = Random effects restricted maximum likelihood model; VCPPS = Vitamin D/Calcium Polyp Prevention Study; VITAL = VITamin D and OmegA-3 TriaL; WHI = Women’s Health Initiative.

This figure is a forest plot showing odds ratios of site-specific cancer incidence for vitamin D, with or without calcium

Appendix E Figure 10 Forest Plot Showing Odds Ratios of Primary Cardiovascular Outcomes for Vitamin D, With or Without Calcium

Abbreviations: CG = Control group; CI = Confidence interval; CVD = Cardiovascular disease; IG = Intervention group; IU/d = International units per day; KOS = Kuopio Osteoporosis Risk Factor and Prevention Study; MI = Myocardial infarction; OR = Odds ratio; RECORD = Randomised evaluation of calcium or vitamin D; VCPPS = Vitamin D/Calcium Polyp Prevention Study; VITAL = VITamin D and OmegA-3 TriaL; ViDa = Vitamin D Assessment Study; WHI = Women’s Health Initiative.

This figure is a forest plot showing odds ratios of primary cardiovascular outcomes for vitamin D, with or without calcium

Appendix E Figure 11 Forest Plot Showing Odds Ratios of All-Cause Mortality for Vitamin E

Abbreviations: ASAP = Antioxidant Supplementation in Atherosclerosis Prevention; ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CG = Control group; CI = Confidence interval; IG = Interval group; IU/d = International units per day; MAVET = Melbourne Atherosclerosis Vitamin E Trial; OR = Odds ratio; PHS-II = Physicians’ Health Study II; PPP = Primary Prevention Project; SELECT = Selenium and Vitamin E Cancer Prevention Trial; VEAPS = Vitamin E Atherosclerosis Progression Study; VECAT = Vitamin E, Cataract and Age-related Maculopathy Trial; WHS = Women’s Health Study.

This figure is a forest plot showing odds ratios of all-cause mortality for vitamin E

Appendix E Figure 12 Forest Plot Showing Odds Ratios of Primary Cardiovascular Outcomes for Vitamin E

Abbreviations: ASAP = Antioxidant Supplementation in Atherosclerosis Prevention; CG = Control group; CI = Confidence interval; CVD = Cardiovascular disease; IG = Intervention group; IU/day = International units per day; MAVET = Melbourne Atherosclerosis Vitamin E Trial; MI = Myocardial infarction; PHS-II = Physicians’ Health Study II; PPP = Primary Prevention Project; SELECT = Selenium and Vitamin E Cancer Prevention Trial; VEAPS = Vitamin E Atherosclerosis Progression Study; WHS = Women’s Health Study.

This figure is a forest plot showing odds ratios of primary cardiovascular outcomes for vitamin E

Appendix E Figure 13 Forest Plot Showing Odds Ratios of Primary Cancer Outcomes for Vitamin E

Abbreviations: ATBC = Alpha-Tocopherol Beta Carotene Cancer Prevention; CG = Control group; CI = Confidence interval; IG = Intervention group; IU/d = International units per day; MAVET = Melbourne Atherosclerosis Vitamin E Trial; OR = Odds ratio; PHS-II = Physicians’ Health Study II; PPP = Primary Prevention Project; SELECT = Selenium and Vitamin E Cancer Prevention Trial; VEAPS = Vitamin E Atherosclerosis Progression Study; WHS = Women’s Health Study.

This figure is a forest plot showing odds ratios of primary cancer outcomes for vitamin E

Appendix E Figure 14 Forest Plot Showing Odds Ratios of All-Cause Mortality for Folic Acid

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; B-PROOF = B-Vitamins for the PRevention Of Osteoporotic Fractures; CG = Control group; CI = Confidence interval; FACIT = Folic Acid and Carotid Intima-media Thickness; HPFS = Health Professionals Follow-Up Study; IG = Intervention group; mg/d = Milligrams per day; OR = Odds ratio; REML = Random effects restricted maximum likelihood model; ukCAP = United Kingdom Colorectal Adenoma Prevention trial.

This figure is a forest plot showing odds ratios of all-cause mortality for folic acid

Appendix E Figure 15 Forest Plot Showing Odds Ratios of Cardiovascular Outcomes for Folic Acid^*^ * van Wijngaarden, 2014 (B-PROOF) administered 500 mcg/day vitamin B12 in combination with folic acid

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; calcOR = Calculated odds ratio; CG = Control group; CI = Confidence interval; CVD = Cardiovascular disease; FA-B12 = Folic acid given with Vitamin B-12; IG = Intervention group; mg/d = Milligrams per day; ukCAP = United Kingdom Colorectal Adenoma Prevention trial.

This figure is a forest plot showing odds ratios of cardiovascular outcomes for folic acid

Appendix E Figure 16 Forest Plot Showing Odds Ratios of Cancer Incidence and Colorectal Cancer Outcomes for Folic Acid

Abbreviations: AFPPS = Aspirin/Folate Polyp Prevention Study; B-PROOF = B-Vitamins for the PRevention Of Osteoporotic Fractures; CG = Control group; CI = Confidence interval; IG = Intervention group; mg/d = Milligrams per day; NHS = Nurses’ Health Study; OR = Odds ratio; ukCAP = United Kingdom Colorectal Adenoma Prevention trial.

This figure is a forest plot showing odds ratios of cancer incidence and colorectal cancer outcomes for folic acid

Appendix E Figure 17 Forest Plot Showing Odds Ratios of All-Cause Mortality for Calcium

Abbreviations: ACS = Auckland calcium study; CAIFOS = Calcium Intake Fracture Outcome Study; CG = Control group; CI = Confidence interval; CPPS = Calcium Polyp Prevention Study; IG = Intervention group; mg/d = Milligrams per day; OR = Odds ratio; RECORD = Randomized Evaluation of Calcium OR vitamin D; VCPPS = Vitamin D/Calcium Polyp Prevention Study.

This figure is a forest plot showing odds ratios of all-cause mortality for calcium

Appendix E Figure 18 Forest Plot Showing Odds Ratios of Primary Cardiovascular Outcomes for Calcium

Abbreviations: ACS = Auckland calcium study; CAIFOS = Calcium Intake Fracture Outcome Study; CG = Control group; CI = Confidence interval; CPPS = Calcium Polyp Prevention Study; CVD = Cardiovascular disease; IG = Intervention group; mg/d = Milligrams per day; OR = Odds ratio; RECORD = Randomized Evaluation of Calcium OR vitamin D; VCPPS = Vitamin D/Calcium Polyp Prevention Study.

This figure is a forest plot showing odds ratios of primary cardiovascular outcomes for calcium

Appendix E Figure 19 Forest Plot Showing Odds Ratios of Primary Cancer Outcomes for Calcium (Without Pooling)

Abbreviations: calcOR = Calculated odds ratio, based on raw event rates in each group; CG = Control group; CI = Confidence interval; CPPS = Calcium Polyp Prevention Study; mg/d = Milligrams per day; RECORD = Randomized Evaluation of Calcium OR vitamin D; RR = Risk ratio; VCPPS = Vitamin D/Calcium Polyp Prevention Study; WD = Withdrawal; WHI = Women’s Health Initiative.

This figure is a forest plot showing odds ratios of primary cancer outcomes for calcium (without pooling)

Appendix E Figure 20 Forest Plot Showing Odds Ratios of All-Cause Mortality for Selenium

Abbreviations: CG = Control group; CI = Confidence interval; DK-PRECISE = Denmark PREvention of Cancer by Intervention with Selenium; mcg/d = Micrograms per day; NPC = Nutritional Prevention of Cancer; OR = Odds ratio; Sel/Cel = Selenium and Celecoxib; SELECT = Selenium and Vitamin E Cancer Prevention Trial, Yrs. = Years.

This figure is a forest plot showing odds ratios of all-cause mortality for selenium

Appendix E Figure 21 Forest Plot Showing Odds Ratios of Cardiovascular Mortality for Selenium

Abbreviations: CG = Control group; CI = Confidence interval; DK-PRECISE = Denmark PREvention of Cancer by Intervention with Selenium; IG = Intervention group; mcg/d = Micrograms per day; NPC = Nutritional Prevention of Cancer; OR = Odds ratio; REML = Random effects restricted maximum likelihood model; Sel/Cel = Selenium and Celecoxib; SELECT = Selenium and Vitamin E Cancer Prevention Trial.

This figure is a forest plot showing odds ratios of cardiovascular mortality for selenium

Appendix E Figure 22 Forest Plot Showing Odds Ratios of Primary Cancer Outcomes for Selenium

Abbreviations: ACM = All-cause mortality; AE = Adverse events; CVD = Cardiovascular disease; DK-PRECISE = Denmark PREvention of Cancer by Intervention with Selenium; mcg = Micrograms; mg/d = Milligrams per deciliter; NPC = Nutritional Prevention of Cancer; NR = Not reported; RCT = Randomized controlled trial; Sel = Selenium; Sel/Cel = Selenium and Celecoxib; SELECT = Selenium and Vitamin E Cancer Prevention Trial; UK-PRECISE = United Kingdom PREvention of Cancer by Intervention with Selenium; WD = Withdrawal.

This figure is a forest plot showing odds ratios of primary cancer outcomes for selenium