# Appendix D Contextual Question

## Contextual Question. What Is the Effect of Vitamin and Mineral Supplementation on Cardiovascular Disease Risk Factors (e.g., High Blood Pressure, Abnormal Lipid Levels, Metabolic Syndrome, Atrial Fibrillation, Renal Disease, or Type 2 Diabetes Mellitus) and Precancerous Outcomes (e.g., Adenoma or Cervical Dysplasia)?

### Cardiovascular Disease Risk Factors

#### Blood Pressure

A very large body of trial evidence evaluates the effect of vitamin and mineral supplementation on blood pressure. The strongest signals for benefit are for vitamin C, magnesium, calcium, and multivitamins. For these supplements, pooled effects were on the order of 1 to 4 mm Hg SBP and 1 to 2 mm Hg DBP. However, evidence of benefit is from short-term trials with wide variations in doses and pooled effects often have high statistical heterogeneity. The largest body of evidence is for vitamin D with or without calcium which showed no effect. Few studies have been conducted for vitamin K supplementation and similarly showed no effect. Evidence is insufficient for selenium.

##### Vitamin C

An umbrella review of systematic reviews identified one systematic review of 29 RCTs (N=1,407), finding that vitamin C is associated with moderate blood pressure reduction.^198,^ ^199^ This review found a statistically significant pooled effect of −3.84/-1.48 mm Hg, but with high statistical heterogeneity (SBP −3.84 mm Hg [95 CI%, −5.29 to −2.38], I^2^=69%; DBP −1.48 mm Hg [95% CI, −2.86 to −0.10], I^2^=81%). Included trials were primarily short-term (median 8 weeks) and had a median vitamin C dose of 500 mg/day. Participants had a wide range of baseline blood pressures.

##### Magnesium

A meta-analysis of 34 trials (N=2,028) of adults with and without hypertension found that magnesium supplementation was associated with small statistically significant reductions blood pressure (SBP −2 mm Hg [95% CI, −3.58 to −0.43], I^2^=62%; DBP −1.78 mm Hg [95% CI, −2.82 to −0.73 to]; I^2^=64%).^200^ The median dose was 368 mg/d with a median treatment duration of 3 months. A more narrowly scoped meta-analysis of magnesium supplementation in adults with diabetes or diabetes risk factors (k=19, N=NR) by Verma and Garg^201^ found a statistically significant moderate benefit for SBP [−3.06 mm Hg (95% CI, −5.51, to −0.60); I^2^=59%) but no statistically significant association with DBP [−1.40 mm Hg (95% CI, −3.02 to 0.29); I^2^= 65%]. Trial duration ranged from 4 to 24 weeks and most doses of elemental calcium were between 360 and 394 mg/d.

##### Calcium

A systematic review of 16 studies of normotensive individuals (N=3,048) found that calcium supplementation was associated with a very small but statistically significant reduction in blood pressure of −1.43/-0.98 mm Hg (SBP −1.43 mm Hg [95% CI, −2.15 to −0.72], I^2^=0%; DBP −0.98 mm Hg [95% CI, −1.46 to −0.50], I^2^=49%).^202^ The dose of calcium in these studies was most commonly 1,000 to 2,000 mg/day and the median followup was 3.5 months. Subgroup analyses suggested larger blood pressure reduction with higher calcium doses and in younger participants.

##### Multivitamin

One systematic review of 8 RCTs (N=2,011) found that multivitamins were associated with a very small statistically significant reduction in continuous blood pressure of 1.31/0.71 mm Hg and that reductions were greater in those with chronic conditions, including hypertension, obesity, or gastrointestinal disease (SBP −1.31 mm Hg [95% CI, −2.48 to −0.14], I^2^=28%; DBP: −0.71 mm Hg [95% CI, −1.43 to 0.00]; I^2^=31%).^203^ Followup in these studies ranged widely, from 1 to 86 months. In 4 RCTs of adults without hypertension (N=22,852), multivitamins were not associated with a reduced risk of incident hypertension [OR 0.92 (95% CI, 0.80 to 1.05); I^2^=67%].

##### Vitamin D With or Without Calcium

A large body of evidence from trial-level and individual patient-level meta-analyses shows that supplementation with vitamin D alone or with calcium does not reduce continuous measures of blood pressure.^204–209^ Meta-analyses of vitamin D supplementation alone include data from more than 46 RCTs and over 4,700 participants and represent a heterogeneous body of literature where populations had varied baseline 25(OH)D concentrations, and interventions were of varied dose and duration. The most reliable data for exploration of subgroup effects—individual patient data meta-analyses—show no baseline factors associated with more favorable blood pressure outcomes.^204,^ ^205^ One meta-analysis of 39 trials (N=NR) that restricted inclusion to studies with 3 months minimum duration showed a statistically significant but exceedingly small benefit for blood pressure reduction of SBP/DBP −0.102/−0.07 mm Hg (SBP −0.102 mm Hg [95% CI, −0.20 to −0.03], I^2^=NR; DBP −0.07 mm Hg [95% CI, −0.14 to −0.006], I^2^=NR ).^210^ Vitamin D administered jointly with calcium similarly showed no effect on blood pressure. A meta-analysis of eight trials (N=36,806) found a non-statistically significant pooled effect of +0.61/−0.22 mm Hg with study followup ranging from 15 weeks to 7 years.^208^ This meta-analysis includes results from the very large (N=36,282) Women’s Health Initiative (WHI) trial which evaluated a calcium dose of 1000 mg/d plus 400 IU/day of vitamin D. In WHI, the mean change in blood pressure showed no statistically significant change over median 7 years followup between the intervention and placebo groups (SBP: 0.22 mm Hg [95% CI, −0.05 to 0.49]; DBP: 0.11 mm Hg [95% CI, −0.04 to 0.27).^211^ Similarly, there was no statistically significant change in the risk of incident hypertension in the 17,122 nonhypertensive participants at baseline over median 7 years followup (HR 1.01 [95% CI, 0.96 to 1.06]).

##### Vitamin K

A 2019 systematic review of vitamin K supplementation found no effect on blood pressure outcomes in a meta-analysis of 4 studies (N=590).^212^ These trials evaluated interventions of various vitamin K doses and formulations of ranging from 24 to 156 weeks.

##### Selenium

There is sparse evidence about the effect of selenium on blood pressure. A systematic review by Kuruppu and colleagues^213^ identified no RCTs of selenium supplementation alone that report blood pressure outcomes. Similarly, a systematic review by Rees and colleagues^191^ identified only one short term study of selenium on blood pressure. The focus of this study was on high protein diets for weight loss, where the intervention group receive chicken breasts enriched with selenium; no blood pressure effect was found.

#### Lipids

A number of systematic reviews have examined the effect of vitamin and mineral supplementation on lipids. The strongest signal for benefit is from magnesium which showed both an LDL reduction (pooled MD −10.67 [95% CI, −19.11 to −2.23]) and an HDL increase (pooled MD 3.2 mg/dL [95% CI, 1.46 to 4.94]). LDL reductions are also seen for zinc, vitamin D, and possibly selenium. Similar to the blood pressure literature, evidence of benefit is typically from short-term trials with wide variations in doses and pooled effects often have high statistical heterogeneity. There is also a wide variation of baseline serum levels of the vitamin or mineral of interest suggesting clinical heterogeneity. Synthesized evidence for vitamin D plus calcium, vitamin K, and vitamin C suggest no benefit for any lipid outcome.

##### Magnesium

A systematic review of 21 studies (N=NR) reporting lipid outcomes associated with magnesium supplementation showed a substantial benefit.^201^ Pooled estimates showed statistically significant HDL increases of 3.2 mg/dL (95% CI, 1.46 to 4.94, I^2^=67%) and LDL decreases of −10.67 (95% CI, −19.11 to −2.23, I^2^=71). Statistical heterogeneity was somewhat high for both outcomes. Studies were of 4 to 24 weeks duration and doses ranged from 300 to 729 mg elemental calcium per day.

##### Zinc

A large systematic review of zinc supplementation including 24 trials and 14,515 people suggests a large benefit for LDL (−6.87 mg/dL [95% CI, −11.16 to −2.58], I^2^=31%) but no statistically significant HDL benefit.^214^ This body of evidence encompasses a wide range of patients, including many with obesity and/or diabetes in addition to healthy adults. A small number of studies were conducted in individuals with kidney disease, heart disease, or cancer. Study duration ranged from 1 month to 7.5 years and the dose range was highly variable at 15 to 240 mg zinc per day. A newer systematic review of zinc supplementation that included a slightly smaller number of studies (k=20) confirmed findings of statistically significant reductions in some lipid measures.^215^

##### Vitamin D

Several systematic reviews, comprising over 40 RCTs and 3,000 people, consistently show that vitamin D is associated with a small to moderate statistically significant reduction in LDL on the order of about 3 to 4 mg/dL.^205,^ ^210,^ ^216^ This synthesized literature has shown mixed findings for HDL benefit. These studies represent somewhat heterogeneous interventions in terms of dose and duration where the median study duration was 6 months and the median dose was 2800 to 2900 mg/day; the baseline levels of 25(OH)D also varied widely in these studies.

##### Selenium

A systematic review of 12 trials (N=NR) showed generally no lipid benefit for selenium supplementation.^191^ While one contributing trial of 6 months, UK PRECISE, showed a statistically significant benefit for non-HDL when results for intervention arms of various doses were combined (−7.73 mg/dL [95% CI, −15.85 to 0], I^2^=NR), no other pooled estimates for lipid parameters were statistically significant in the systematic review.

##### Vitamin D+Calcium

Fewer studies evaluated the combined supplementation of calcium and vitamin D and reported lipid change.^217^ These studies generally showed no benefit for lipid reduction, including 5-year results from the large WHI trial which tested 1,000 mg calcium + 400 IU vitamin D per day.^218^

##### Vitamin K

One systematic review of 7 RCTs (N=676) evaluating vitamin K supplementation found no benefit for LDL, HDL, or TC.^212^ Studies were of 4 to 152 weeks duration with most being less than 24 weeks. A large range of doses and formulations were tested in these studies.

##### Vitamin C

A large systematic review of vitamin C supplementation (k=40; N=1981) showed no benefit for any lipid parameter in overall analyses of a wide range of participants.^219^ Subgroup analyses indicated potential benefit in some population subgroups for some lipid outcomes, but these results were not consistent across lipid outcomes. Trials tested a wide range of vitamin C dose (125 to 4500 mg/d) and durations ranged from 2 to 240 weeks.

#### Diabetes Incidence

Overall, relatively little trial evidence has accrued evaluating the association of vitamin or mineral supplementation with incident diabetes. The largest body of evidence is for selenium which shows a statistically significant harm in a recent meta-analysis of 5 trials. The effect of vitamin D supplementation on incident diabetes has been tested in several recent trials of adults with prediabetes and these trials consistently show that vitamin D is likely not associated with any benefit, but no pooled analyses are available. For zinc, very limited evidence from just one trial of adults with prediabetes in a setting not relevant to the US suggests benefit.

##### Selenium

Two systematic reviews show a small but consistent association between selenium supplementation and increased risk for incident diabetes.^191,^ ^192^ The systematic review by Vinceti and colleagues includes the same 4 RCTs as the systematic review by Rees and colleagues and adds one newer trial. Pooled analyses of 5 RCTs (N=22,265) of selenium supplementation of 200 mcg/d was associated with a statistically significant 11 percent increase in risk for new diabetes with median followup from 3 to 7.9 years (1.11 [95% CI 1.01 to 1.22]; I^2^=0%).^192^ Most of the evidence is from the SELECT trial which only recruited men; diabetes incidence was a prespecified secondary outcome in this study.

##### Vitamin D

Three recent trials of varying vitamin D doses and formulations suggest that vitamin D supplementation is likely not associated with a meaningful reduction in incident diabetes in populations with prediabetes.^136,^ ^220,^ ^221^ The largest of these trials, D2d, was a US study of 2,434 adults with prediabetes who were randomized to 4,000 IU vitamin D per day over a median followup of 2.5 years.^136^ D2d had no baseline serum 25-hydroxyvitamin D eligibility criterion and a high percentage of participants were considered to have adequate levels at baseline. The hazard ratio for incident diabetes was 0.88 (95% CI, 0.75 to 1.04). A smaller Norwegian trial of 511 participants with prediabetes and generally with adequate vitamin D status showed similar results over five years followup (HR 0.90 [95% CI, 0.69 to 1.18]).^220^ In this study, participants in the intervention group received weekly doses of a vitamin D 20,000 capsule. Finally, a Japanese trial of 1,256 participants with impaired glucose tolerance and a range of baseline vitamin D levels reported a hazard ratio of 0.87 (95% CI, 0.68 to 1.09) for incident diabetes over 2.6 years followup.^221^ This trial evaluated a daily dose of 0.75 mcg eldecalcitol which is an active form of vitamin D analog.

##### Zinc

Very limited RCT evidence from one Sri Lankan trial of 200 people suggests that zinc supplementation may delay progression to diabetes in those with prediabetes.^222^ This trial randomized adults with prediabetes to 20 mg elemental zinc daily or placebo for one year and found a substantial reduction in diabetes incidence in those taking zinc (OR 0.28 [95 CI, 0.13 to 0.64]). Diabetes was a secondary outcome in this trial with 36 incident events (11 in the zinc group and 25 in the placebo group). Additional evidence from more relevant settings to the US is needed to confirm this finding.

#### Atrial Fibrillation

Virtually all of the evidence for supplementation for atrial fibrillation is in the context of hospitalized or post-surgical patients.^223,^ ^224^ Only limited RCT evidence is available to assess the association of supplementation with prevention of atrial fibrillation in generally healthy adults. This evidence is focused on vitamin D with or without calcium and suggests no benefit.

##### Vitamin D+Calcium

A secondary analysis of 16,801 postmenopausal women from the Women’s Health Initiative trial found no association of vitamin D and calcium supplementation with new atrial fibrillation over an average followup of 4.5 years (HR 1.02 [95% CI, 0.92 to 1.13]).^225^ The supplementation intervention consisted of 1,000 mg/d of elemental calcium and 400 IU/d of vitamin D3.

##### Vitamin D

Two recent trials of vitamin D show no association between supplementation and incident atrial fibrillation or arrhythimas. A substudy of VITAL, the VITAL Rhythm Study (N=25,119), evaluated new diagnoses of atrial fibrillation on annual followup questionnaires over a mean duration of 5.3 years and found no association between 2,000 IU/day of vitamin D3 and clinically-detected incident atrial fibrillation (HR 1.09 [95% CI 0.96 to 1.24]; 900 total confirmed atrial fibrillation diagnoses).^226^ The ViDA trial of 5,108 adults in New Zealand evaluated the effect of monthly doses of 100,000 IU vitamin D3 on CVD events over a median followup of 3.3 years.^92^ ViDA found no association between vitamin D supplementation and arrhythmias, but this outcome was not restricted to atrial fibrillation (HR 0.93 [95% CI, 0.62 to 1.39]).

#### Renal Outcomes

Relatively little evidence is available regarding the effect of supplementation to maintain or improve renal function in generally healthy adults. Most of the evidence on supplementation is available in patients with established CKD or diabetic nephropathy, which suggests some potential benefit for reduced proteinuria or albuminuria.^227,^ ^228^ The sparse evidence available in relevant general healthy populations is in the context of monitoring renal function as potential harm of supplementation. A few of these studies suggest there may be a small increase in blood or serum creatinine in individuals randomized to calcium. However, these are intermediate measures of kidney function with an unknown clinical significance of small increases. Studies of vitamin D supplementation generally show no association with renal measures in healthy populations or individuals with type 2 diabetes.

##### Calcium and Vitamin D

The Vitamin D/Calcium Polyp Prevention Study—an included study in our review—tested 1,000 IU/day vitamin D, 1,000 mg/d calcium, or both for preventing recurrent colorectal adenoma.^91^ Blood creatinine concentration was measured as a prespecified interim outcome for safety to assess potential renal effects. In the 1,675 participants in the full factorial trial, creatinine values were slightly higher at 1 year in the calcium group than in the control group (mean 0.013 (0.006 SE) mg/dL, p=0.03) but were not different in the vitamin D group compared to control.^229^ No other measures of renal function were measured in this trial and the clinical significance of a small increase at one year is unknown. Similarly, a 2 year trial of 1,000 mg/day or 2,000 mg/day calcium for bone loss prevention found a statistically significant increase in serum creatinine (p <0.01) in both calcium groups compared to control.^230^ In contrast, a US-based RCT of 438 adults age 60 years or older evaluated 750 mg calcium or 15 mcg vitamin D3 for the primary aim of bone loss prevention and measured serum creatinine as a safety outcome.^231^ No significant differences in serum creatinine were found between the calcium, vitamin D and placebo groups at 4 years. Finally, VITAL conducted a substudy (VITAL-DKD) to evaluate vitamin D for the prevention and treatment of CKD in trial participants with type 2 diabetes at baseline (N=1,312).^232^ Over 5 years of followup, vitamin D was not associated with a statistically significant difference in estimated eGFR compared to placebo (0.9 mL/min/1.73^2^ [95% CI, −0.7 to 2.6]).

#### Precancerous Outcomes

##### Colorectal Adenomas

There is a small and disparate body of evidence for single or multivitamins to prevent colorectal adenomas. These trials are typically conducted in populations with a history of prior adenoma. The number of studies for any one supplement or supplement combination is relatively small and editorials have noted that the follow-up periods of 3 to 5 years may not be adequate to detect an effect.^233^ Calcium appears to be the most promising supplement, suggesting at best a modest benefit, and there is a possible signal that multivitamins may have some benefit.

Calcium. A systematic review of 5 trials (N=2,234) of calcium 1200 to 2000 mg/day found a statistically significant 17 percent reduction in recurrent colorectal adenoma (RR 0.83 [95% CI, 0.75 to 0.93] with low heterogeneity [I^2^=8.5%]).^234^ However, results showed no association with the likelihood for recurrent adenomas that were advanced (RR 1.01 [95% CI, 0.74 to 1.38], I^2^=17.5%). This systematic review included two studies of 1200 mg/d calcium by the same investigator group that were conducted 16 years apart and showed conflicting results. The earlier 1999 trial, the Calcium Polyp Prevention Study^235^ showed a significant benefit for recurrent colorectal adenoma (RR 0.81 [95% CI, 0.67 to 0.99] that was not replicated in the later 2015 trial, the Vitamin D/Calcium Polyp Prevention Study (VCPPS) (0.95 [95% CI, 0.85 to 1.06]).^91^ Barry and colleagues hypothesized that effect modification by BMI present in both trials, which showed risk reduction in those with normal BMI and no effect or risk increase in those with overweight or obesity, might explain the conflicting results, with higher BMI in the later trial which is consistent with US trends.^236^

Multivitamins. The body of evidence for multivitamins to prevent new or recurrent colorectal adenoma is mixed, with results ranging from substantial statistically significant benefit to suggestion of harm. A pooled analysis of eight trials of multivitamins (containing various combinations of beta carotene, vitamin A, vitamin C, vitamin E, and selenium) for a duration of 1 to 6.3 years (N=17,620) did not rule out a potential benefit for a combined outcome of new or recurrent colorectal adenoma (RR 0.82 [95% CI, 0.60 to 1.1]).^237^ However, statistical and methodologic heterogeneity in this body of literature was high and authors reported that estimated effect seemed to depend on the risk of bias of the contributing trials, with low risk of bias studies suggesting potential harm. Only two of eight contributing studies found statistically significant benefit, and these had sample sizes of less than 150 participants each. On the other hand, an Italian trial (N=411) of a multivitamin comprised of vitamin A, vitamin C, vitamin E, zinc and selenium not included in this meta-analysis because of a later publication date showed a statistically significant 39 percent reduction in recurrent colorectal adenoma (HR 0.61 (95% CI, [0.41 to 0.92]), although the 50 percent reduction in advanced recurrent colorectal adenoma was not statistically significant (HR 0.50 [95% CI, 0.24 to 1.01]).^96^

Folic acid. A small body of evidence evaluating folic acid for the prevention of primary or recurrent colorectal adenoma shows mixed results, although the most relevant studies suggest no benefit. The Aspirin/Folate Polyp Prevention Study (AFPPS), conducted in the US and Canada, found no benefit for 1 mg/d folic acid over 3 to 5 years on recurrent colorectal adenoma or advanced recurrent adenoma in a 2x2 trial also evaluating aspirin (RR 1.04 [95% CI, 0.90 to 1.20] and RR 1.32 [95% CI, 0.90 to 1.92], respectively).^84^ The ukCAP trial, conducted in the United Kingdom, showed similar results for 0.5 mg/d folic acid over 3 years (RR 1.07 [95% CI, 0.85 to 1.34] for recurrent adenoma and RR 1.32 [95% CI, 0.90 to 1.92]) for advanced recurrent adenoma.^109^ A secondary study of participants from the NHS and HPFS with some design limitations also found no suggestion of benefit for 1 mg/d folic acid for 3 to 6.5 years (RR 0.82 [95% CI, 0.59 to 1.13] for recurrent adenoma and RR 1.08 [95% CI, 0.54 to 2.16]) for advanced recurrent adenoma).^110^ In contrast, a 2013 Chinese trial showed substantial benefit for folic acid supplementation for primary prevention of colorectal adenoma and advanced colorectal adenoma (RR 0.74 [95% CI, 0.65 to 0.85] and RR 0.67 [95% CI, 0.58 to 0.76]); however, the lack of folate-fortified foods available in China could explain differences in results compared with the North American-based AFPPS.^238^ A very small US trial of 93 participants conducted in one VA Medical Center reported that adenoma recurrence was twice that in the placebo group compared to the folic acid group, but data are not shown; this trial used a 5 mg/d dose of folic acid and participants were almost exclusively men.^239^ Fortification of the food supply with folate became mandatory in the US in 1998 to increase maternal folate levels during pregnancy to protect against neural tube defects; most studies were accruing followup after this time.^240^

Selenium. A small number of trials have investigated selenium for the prevention of new or recurrent colorectal adenoma. A 2016 US trial of 1,824 participants found no effect for 200 mcg/d selenium over 33 month followup for recurrent colorectal adenoma or advanced recurrent adenomas (RR 1.03 [95% CI, 0.91 to 1.16] and RR 1.02 [95% CI, 0.74 to 1.43], respectively).^99^ A substudy from SELECT in a primary prevention population similarly showed no effect, although analyses were limited to men reporting that they underwent endoscopy during the trial which only included 18.4 percent of the overall population.^241^

Vitamin E. Two primary prevention studies of vitamin E, each with design limitations, show mixed results of either no effect or harm for colorectal adenomas. The SELECT substudy which also evaluated selenium, found no effect for their vitamin E arm.^241^ Another secondary analysis in a primary prevention population, this of the ATBC study, found that vitamin E was associated with an increased risk of colorectal adenoma (RR 1.66 [95% CI, 1.19 to 2.32]).^181^ This analysis is likely subject to detection bias as there was no systematic CRC screening; cases were identified through pathology labs in study areas and symptoms which may have led to colonoscopy referrals were more common in those randomized to vitamin E.

Beta carotene. One secondary analysis of the primary prevention ATBC study found no effect of beta-carotene on colorectal adenomas (RR 0.98 [95% CI, 0.71 to 1.35]).^181^ This analysis may be subject to detection bias as there was no systematic CRC screening.

Vitamin D. Evidence from two trials suggests that vitamin D is not associated with incident or recurrent colorectal adenomas over 3 to 5 years followup. VITAL included a prespecified ancillary study of the association of 2,000 IU/day of vitamin D with colorectal adenomas (N=25,871).^242^ Over a median followup of 5.3 years, there was no association between vitamin D supplementation and adenomas (OR 1.08 [95% CI, 0.92 to 1.27]). The much smaller VCPPS trial (N=2,259) evaluated the effect of 1000 IU/day vitamin D on recurrent colorectal adenoma in a 2x2 factorial design. No benefit was seen for vitamin D for either recurrent colorectal adenoma over 3 to 5 years followup (RR 0.99 [95% CI, 0.89 to 1.09]) or advanced recurrent colorectal adenoma (RR 0.99 [95% CI, 0.75 to 1.29]).^91^

##### Mammographic Breast Density

A very small number of RCTs evaluate whether supplementation can reduce mammographic breast density which is a strong risk factor for breast cancer. These studies investigated vitamin D with or without calcium and findings were not promising. A Canadian study of 405 premenopausal women tested three doses of vitamin D (1,000 IU/day; 2,000 IU/day; 3,000 IU/day) compared to placebo over one year.^95^ No differences in mammographic breast density were found between the 1,000 IU/day and 2,000 IU/day doses compared to placebo, and the 3,000 IU/day dose showed significantly less density decline compared to placebo, but the difference was judged not to be clinically significant. Likewise, an ancillary study to WHI found no effect of 1,000 mg/day calcium plus 400 IU/day VitD over one year on mammographic breast density.^243^

##### Cervical Intraepithelial Neoplasia

Extremely limited RCT evidence is available regarding the use of supplements for the regression or prevention of recurrent cervical intraepithelial neoplasia (CIN), a precursor lesion for cervical cancer. While promising, these studies are very small and have not been replicated by different investigator groups. Two Iranian studies of 58 women each evaluated 50,000 IU vitamin D every 2 weeks for 6 months in women with various histories of CIN. A 2017 study of women with CIN1 found that 84.6 percent of those in the vitamin D group showed CIN1 regression compared to 53.8 percent in the placebo group (p=0.01).^244^ A 2018 study by the same investigator group in women with CIN 2/3 treated with loop electrical excision found that recurrence of CIN1/2/3 was lower in those in the vitamin D group compared with placebo (18.5% vs 48.1%, p=0.02) but the difference between groups for CIN2/3 recurrence was not statistically significant (3.7% vs 14.8%, p=0.15).^245^ Another Iranian study of the same size found that folate supplementation of 5 mg/day reduced CIN1 regression compared to placebo (83.3% vs 52.0%, p=0.019).^246^ The clinical significance of these findings are unknown given high rates of spontaneous regression.^246^ These data can only be considered exploratory, given the very small number of participants (174 women total across all 3 studies), short time frame (6 months each), and the lack of independent replication.