# Appendix C Excluded Studies

Reason for Exclusion^*^
E1. Study relevance
E2. Setting
E3. Population
E4. Study quality
E5. Study design
E5a. Comparative effectiveness
E6. Outcomes – No relevant outcomes
E6a. No CVD or cancer outcome
E7. Precedes search period
E8. Non-English publication
E9. Source document only
E10. Non-RCT harms on CVD or cancer
E11. High dose > upper limit
E12. No relevant intervention/agent
E13. Publication type (i.e., conference abstract)
E14. Short-terms harms-only trial for agent with no evidence of benefit (KQ1 or KQ3 outcomes)

* Assigned at full-text phase.

Abbreviation: E = exclude.

1 Adebamowo, SN, Feskanich, D, . Multivitamin use and risk of stroke incidence and mortality amongst women. European Journal of Neurology. 24(10): 1266–1273. 2017. PMID: 28758316. 10.1111/ene.13358 KQ1E5, KQ2E6, KQ3E12, KQ4E1228758316
2 Afitska, K, Clavel, J, . Magnesium citrate supplementation decreased blood pressure and Hba1c in normomagnesemic subjects with metabolic syndrome: A 12-week, placebo-controlled, double-blinded pilot trial. Magnes Res. 34(3): 130–139. 2021. PMID: 34859788. 10.1684/mrh.2021.0489 KQ1E12, KQ2E12, KQ3E3, KQ4E334859788
3 Age-Related Eye Disease Study Research, Group. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E, beta carotene, and zinc for age-related macular degeneration and vision loss: AREDS report no. 8. Arch Ophthalmol. 119(10): 1417–36. 2001. PMID: 11594942. 10.1001/archopht.119.10.1417 KQ1E6, KQ2E6, KQ3E11, KQ4E1111594942
4 Age-Related Eye Disease Study Research, Group. The Age-Related Eye Disease Study (AREDS): design implications. AREDS report no. 1. Control Clin Trials. 20(6): 573–600. 1999. PMID: 10588299. 10.1016/s0197-2456(99)00031-8 KQ1E6, KQ2E6, KQ3E11, KQ4E1110588299
5 Algotar, AM, Stratton, MS, . Phase 3 clinical trial investigating the effect of selenium supplementation in men at high-risk for prostate cancer. Prostate. 73(3): 328–35. 2013. PMID: 22887343. 10.1002/pros.22573 KQ1E12, KQ2E12, KQ3E4, KQ4E422887343
6 Ambrosini, GL, Alfonso, H, . Plasma retinol and total carotenes and fracture risk after long-term supplementation with high doses of retinol. Nutrition. 30(5): 551–6. 2014. PMID: 24698346. 10.1016/j.nut.2013.10.007 KQ1E12, KQ2E12, KQ3E6, KQ4E624698346
7 Ambrosini, GL, Bremner, AP, . No dose-dependent increase in fracture risk after long-term exposure to high doses of retinol or beta-carotene. Osteoporos Int. 24(4): 1285–93. 2013. PMID: 22986930. 10.1007/s00198-012-2131-6 KQ1E12, KQ2E12, KQ3E5a, KQ4E5a22986930
8 Andersen, R, Molgaard, C, . Effect of vitamin D supplementation on bone and vitamin D status among Pakistani immigrants in Denmark: a randomised double-blinded placebo-controlled intervention study. Br J Nutr. 100(1): 197–207. 2008. PMID: 18208636. 10.1017/S000711450789430X KQ1E12, KQ2E12, KQ3E6, KQ4E618208636
9 Anderson, JJ, Kruszka, B, . Calcium Intake From Diet and Supplements and the Risk of Coronary Artery Calcification and its Progression Among Older Adults: 10-Year Follow-up of the Multi-Ethnic Study of Atherosclerosis (MESA). J Am Heart Assoc. 5(10): 11. 2016. PMID: 27729333. KQ1E12, KQ2E12, KQ3E5, KQ4E627729333
10 Araghi, SO, Jong, JCK, . Long-term Effect of Folic Acid and Vitamin B12 Supplementation on Fracture Risk and Cardiovascular Disease: Follow-up Study of B-PROOF Trial (P24-031-19). Current Developments in Nutrition. 3(Suppl 1). 2019. PMID: 31223693. 10.1093/cdn/nzz044.P24-031-19 KQ1E12, KQ2E12, KQ3E13, KQ4E13
11 Armitage, J. Niacin causes serious unexpected side-effects, but no worthwhile benefits, for patients who are at increased risk of heart attacks and strokes. 2013. KQ1E12, KQ2E12, KQ3E3, KQ4E3
12 Bagheri Hosseinabadi, M, Khanjani, N, . The Effects of Antioxidant Vitamins on Proinflammatory Cytokines and Some Biochemical Parameters of Power Plant Workers: A Double-Blind Randomized Controlled Clinical Trial. Bioelectromagnetics. 42(1): 18–26. 2021. PMID: 32931612. 10.1002/bem.22294 KQ1E12, KQ2E12, KQ3E2, KQ4E232931612
13 Barrington, WE, Schenk, JM, . Difference in Association of Obesity With Prostate Cancer Risk Between US African American and Non-Hispanic White Men in the Selenium and Vitamin E Cancer Prevention Trial (SELECT). JAMA Oncology. 1(3): 342–9. 2015. PMID: 26181184. 10.1001/jamaoncol.2015.0513 KQ1E1, KQ2E1, KQ3E1, KQ4E126181184
14 Bassuk, SS, Chandler, PD, . The VITamin D and OmegA-3 TriaL (VITAL): Do Results Differ by Sex or Race/Ethnicity?. Am J Lifestyle Med. 15(4): 372–391. 2021. PMID: 34366734. 10.1177/1559827620972035 KQ1E12, KQ2E12, KQ3E5, KQ4E534366734
15 Bassuk, SS, Manson, JE, . Baseline characteristics of participants in the VITamin D and OmegA-3 TriaL (VITAL). Contemp Clin Trials. 47. 235–43. 2016. PMID: 26767629. 10.1016/j.cct.2015.12.022 KQ1E12, KQ2E12, KQ3E6, KQ4E626767629
16 Bislev, LS, Sundekilde, UK, . Circulating Levels of Muscle-Related Metabolites Increase in Response to a Daily Moderately High Dose of a Vitamin D3 Supplement in Women with Vitamin D Insufficiency-Secondary Analysis of a Randomized Placebo-Controlled Trial. Nutrients. 12(5): 04. 2020. PMID: 32375334. 10.3390/nu12051310 KQ1E12, KQ2E12, KQ3E6, KQ4E632375334
17 Bolland, MJ, Barber, A, . Differences between self-reported and verified adverse cardiovascular events in a randomised clinical trial. BMJ Open. 3(3): 18. 2013. PMID: 23512838. 10.1136/bmjopen-2012-002334 KQ1E12, KQ2E12, KQ3E6, KQ4E623512838
18 Bolton-Smith, C, McMurdo, ME, . Two-year randomized controlled trial of vitamin K1 (phylloquinone) and vitamin D3 plus calcium on the bone health of older women. J Bone Miner Res. 22(4): 509–19. 2007. PMID: 17243866. 10.1359/jbmr.070116 KQ1E12, KQ2E12, KQ3E6, KQ4E617243866
19 Bonithon-Kopp, C, Kronborg, O, . Calcium and fibre supplementation in prevention of colorectal adenoma recurrence: a randomised intervention trial. European Cancer Prevention Organisation Study Group. Lancet. 356(9238): 1300–6. 2000. PMID: 11073017. 10.1016/s0140-6736(00)02813-0 KQ1E12, KQ2E12, KQ3E6a, KQ4E611073017
20 Brasky, TM, White, E, . Long-Term, Supplemental, One-Carbon Metabolism-Related Vitamin B Use in Relation to Lung Cancer Risk in the Vitamins and Lifestyle (VITAL) Cohort. J Clin Oncol. 35(30): 3440–3448. 2017. PMID: 28829668. 10.1200/JCO.2017.72.7735 KQ1E12, KQ2E12, KQ3E5, KQ4E628829668
21 Brigo, F, Storti, M, . Vitamin E is ineffective in preventing stroke. Evid Based Med. 18(6): 239–240. 2013. PMID: 24009329. 10.1136/eb-2013-101517 KQ1E12, KQ2E12, KQ3E5, KQ4E524009329
22 Bunout, D, Barrera, G, . Effects of vitamin D supplementation and exercise training on physical performance in Chilean vitamin D deficient elderly subjects. Exp Gerontol. 41(8): 746–52. 2006. PMID: 16797903. 10.1016/j.exger.2006.05.001 KQ1E12, KQ2E12, KQ3E3, KQ4E316797903
23 Campbell, AJ, Robertson, MC, . Randomised controlled trial of prevention of falls in people aged > or =75 with severe visual impairment: the VIP trial. BMJ. 331(7520): 817. 2005. PMID: 16183652. 10.1136/bmj.38601.447731.55 KQ1E12, KQ2E12, KQ3E12, KQ4E1216183652
24 Cangussu, LM, Nahas-Neto, J, . Effect of vitamin D supplementation alone on muscle function in postmenopausal women: a randomized, double-blind, placebo-controlled clinical trial. Osteoporos Int. 26(10): 2413–21. 2015. PMID: 25956283. 10.1007/s00198-015-3151-9 KQ1E12, KQ2E12, KQ3E2, KQ4E225956283
25 Chailurkit, LO, Saetung, S, . Discrepant influence of vitamin D status on parathyroid hormone and bone mass after two years of calcium supplementation. Clin Endocrinol (Oxf). 73(2): 167–72. 2010. PMID: 20148911. 10.1111/j.1365-2265.2010.03779.x KQ1E12, KQ2E12, KQ3E2, KQ4E220148911
26 Chandler, PD, Giovannucci, EL, . Null association between vitamin D and PSA levels among black men in a vitamin D supplementation trial. Cancer Epidemiol Biomarkers Prevent. 23(9): 1944–7. 2014. PMID: 24974387. 10.1158/1055-9965.EPI-14-0522 KQ1E12, KQ2E12, KQ3E6, KQ4E624974387
27 Chapuy, MC, Arlot, ME, . Vitamin D3 and calcium to prevent hip fractures in elderly women. N Engl J Med. 327(23): 1637–42. 1992. PMID: 1331788. 10.1056/NEJM199212033272305 KQ1E12, KQ2E12, KQ3E4, KQ4E41331788
28 Chen, L, Dong, Y, . Vitamin D3 Supplementation Increases Long-Chain Ceramide Levels in Overweight/Obese African Americans: A Post-Hoc Analysis of a Randomized Controlled Trial. Nutrients. 12(4): 02. 2020. KQ1E12, KQ2E12, KQ3E6, KQ4E6
29 Cheng, TY, Goodman, GE, . Estimated intake of vitamin D and its interaction with vitamin A on lung cancer risk among smokers. Int J Cancer. 135(9): 2135–45. 2014. PMID: 24622914. 10.1002/ijc.28846 KQ1E12, KQ2E12, KQ3E6, KQ4E624622914
30 Cherniack, EP, Florez, HJ, . The response of elderly veterans to daily vitamin D3 supplementation of 2,000 IU: a pilot efficacy study. J Am Geriatr Soc. 59(2): 286–90. 2011. PMID: 21288233. 10.1111/j.1532-5415.2010.03242.x KQ1E12, KQ2E12, KQ3E4, KQ4E421288233
31 Chew, EY, Clemons, TE, . Long-term effects of vitamins C and E, beta-carotene, and zinc on age-related macular degeneration: AREDS report no. 35. Ophthalmology. 120(8): 1604–11.e4. 2013. PMID: 23582353. 10.1016/j.ophtha.2013.01.021 KQ1E6, KQ2E6, KQ3E11, KQ4E1123582353
32 Crew, KD, Anderson, GL, . Randomized Double-Blind Placebo-Controlled Biomarker Modulation Study of Vitamin D Supplementation in Premenopausal Women at High Risk for Breast Cancer (SWOG S0812). Cancer Prevention Research. 12(7): 481–490. 2019. PMID: 31138522. 10.1158/1940-6207.CAPR-18-0444 KQ1E12, KQ2E12, KQ3E6, KQ4E5a31138522
33 Crockett, SD, Barry, EL, . Calcium and vitamin D supplementation and increased risk of serrated polyps: results from a randomised clinical trial. Gut 2018. PMID: 29496722. 10.1136/gutjnl-2017-315242 KQ1E12, KQ2E12, KQ3E6, KQ4E629496722
34 Cunha, AR, D’El-Rei, J, . Oral magnesium supplementation improves endothelial function and attenuates subclinical atherosclerosis in thiazide-treated hypertensive women. J Hypertens. 35(1): 89–97. 2017. PMID: 27759579. KQ1E12, KQ2E12, KQ3E6, KQ4E627759579
35 Curhan, GC, Willett, WC, . A prospective study of the intake of vitamins C and B6, and the risk of kidney stones in men. J Urol. 155(6): 1847–51. 1996. PMID: 8618271. KQ1E12, KQ2E12, KQ3E5, KQ4E128618271
36 Dai, Q, Zhu, X, . Magnesium status and supplementation influence vitamin D status and metabolism: results from a randomized trial. Am J Clin Nutr. 108(6): 1249–1258. 2018. PMID: 30541089. 10.1093/ajcn/nqy274 KQ1E12, KQ2E12, KQ3E6, KQ4E630541089
37 Das, M, Tomar, N, . Effect of vitamin D supplementation on cathelicidin, IFN-gamma, IL-4 and Th1/Th2 transcription factors in young healthy females. Eur J Clin Nutr. 68(3): 338–43. 2014. PMID: 24398649. 10.1038/ejcn.2013.268 KQ1E12, KQ2E12, KQ3E6, KQ4E624398649
38 Dawson-Hughes, B, Harris, SS, . Rates of bone loss in postmenopausal women randomly assigned to one of two dosages of vitamin D. Am J Clin Nutr. 61(5): 1140–5. 1995. PMID: 7733040. 10.1093/ajcn/61.4.1140 KQ1E12, KQ2E12, KQ3E5a, KQ4E5a7733040
39 de Boer, IH, Prince, DK, . The Multi-Ethnic Study of Atherosclerosis individual response to vitamin D trial: Building a randomized clinical trial into an observational cohort study. Contemp Clin Trials. 103. 106318. 2021. PMID: 33588078. 10.1016/j.cct.2021.106318 KQ1E12, KQ2E12, KQ3E6, KQ4E633588078
40 Demark-Wahnefried, W. Modest cancer prevention benefit with long-term multivitamin supplementation: physicians’ Health Study II results warrant cautious interpretation. Evidence based medicine. 18(6): 214–215. 2013. KQ1E5, KQ2E5, KQ3E5, KQ4E523416420
41 Dhesi, JK, Jackson, SH, . Vitamin D supplementation improves neuromuscular function in older people who fall. Age Ageing. 33(6): 589–95. 2004. PMID: 15501836. 10.1093/ageing/afh209 KQ1E12, KQ2E12, KQ3E3, KQ4E315501836
42 Donlon, CM, LeBoff, MS, . Baseline characteristics of participants in the VITamin D and OmegA-3 TriaL (VITAL): Effects on Bone Structure and Architecture. Contemp Clin Trials. 67. 56–67. 2018. PMID: 29408561. 10.1016/j.cct.2018.02.003 KQ1E12, KQ2E12, KQ3E6, KQ4E629408561
43 Ebbing, M, Vollset, SE. Long-term supplementation with multivitamins and minerals did not improve male US physicians’ cardiovascular health or prolong their lives. Evid Based Med. 18(6): 218–219. 2013. PMID: 23585077. 10.1136/eb-2012-101178 KQ1E5, KQ2E5, KQ3E5, KQ4E523585077
44 El Bilbeisi, AH, El Afifi, A, . Effects of vitamin D supplementation along with and without endurance physical activity on calcium and parathyroid hormone levels in metabolic syndrome patients: A randomized controlled trial. Clinical Nutrition Open Science. 35. 1–11. 2021. 10.1016/j.nutos.2020.12.002 KQ1E12, KQ2E12, KQ3E2, KQ4E2
45 El-Hajj Fuleihan, G, Baddoura, R, . Effect of vitamin D replacement on indexes of insulin resistance in overweight elderly individuals: a randomized controlled trial. Am J Clin Nutr. 104(2): 315–23. 2016. PMID: 27413130. 10.3945/ajcn.116.132589 KQ1E12, KQ2E12, KQ3E2, KQ4E227413130
46 Erratum: Effect of vitamin D3supplements on development of advanced cancer: a secondary analysis of the VITAL Randomized Clinical Trial (JAMA Netw Open. (2020) 3: 11 (e2025850) DOI: 10.1001/jamanetworkopen.2020.25850). JAMA Network Open. 3(12). 2020. PMID: 33306110. 10.1001/jamanetworkopen.2020.32460 KQ1E12, KQ2E12, KQ3E6, KQ4E633306110
47 Ernst, JB, Tomaschitz, A, . Vitamin D Supplementation and Hemoglobin Levels in Hypertensive Patients: A Randomized Controlled Trial. International Journal of Endocrinology Print. 2016. 6836402. 2016. PMID: 27006655. 10.1155/2016/6836402 KQ1E12, KQ2E12, KQ3E6, KQ4E627006655
48 Eslami, Vasmaleii F, Habibian, M, . The effectiveness of Vitamin D supplementation with Pilates Training on Vitamin D status and insulin resistance in overweight men. A clinical trial study. Modares journal of medical sciences: pathobiology. 23(5): 17–28. 2021. PMID: CN-02309354. KQ1E12, KQ2E12, KQ3E2, KQ4E2
49 Farag, HAM, Hosseinzadeh-Attar, MJ, . Effects of vitamin D supplementation along with endurance physical activity on lipid profile in metabolic syndrome patients: A randomized controlled trial. Diabetes and Metabolic Syndrome: Clinical Research and Reviews. 13(2): 1093–1098. 2019. PMID: 31336450. 10.1016/j.dsx.2019.01.029 KQ1E2, KQ2E2, KQ3E2, KQ4E231336450
50 Fernández, RG, Alonso, MD, . Folic acid and endothelial function in patients with hypertension with high blood pressure. Revista de la Federacion Argentina de Cardiologia. 42(2): 127–134. 2013. KQ1E8, KQ2E8, KQ3E8, KQ4E8
51 Ferraro, PM, Curhan, GC, . Total, Dietary, and Supplemental Vitamin C Intake and Risk of Incident Kidney Stones. Am J Kidney Dis. 67(3): 400–7. 2016. PMID: 26463139. 10.1053/j.ajkd.2015.09.005 KQ1E12, KQ2E12, KQ3E5, KQ4E526463139
52 Ferraro, PM, Taylor, EN, . Vitamin B6 intake and the risk of incident kidney stones. Urolithiasis. 46(3): 265–270. 2018. PMID: 28674784. 10.1007/s00240-017-0999-5 KQ1E12, KQ2E12, KQ3E12, KQ4E1228674784
53 Ferreira, PP, Cangussu, L, . Vitamin D supplementation improves the metabolic syndrome risk profile in postmenopausal women. Climacteric. 1–8. 2019. PMID: 31134822. 10.1080/13697137.2019.1611761 KQ1E2, KQ2E2, KQ3E2, KQ4E230721639
54 Figueiredo, JC, Levine, AJ, . Colorectal adenomas in a randomized folate trial: the role of baseline dietary and circulating folate levels. Cancer Epidemiol Biomarkers Prev. 17(10): 2625–31. 2008. PMID: 18843003. 10.1158/1055-9965.EPI-08-0382 KQ1E12, KQ2E12, KQ3E12, KQ4E1218843003
55 Gallagher, JC, Jindal, PS, . Vitamin D supplementation in young White and African American women. J Bone Miner Res. 29(1): 173–81. 2014. PMID: 23761326. 10.1002/jbmr.2010 KQ1E12, KQ2E12, KQ3E3, KQ4E323761326
56 Gallagher, JC. The effects of calcitriol on falls and fractures and physical performance tests. J Steroid Biochem Mol Biol. 89-90(1-5): 497–501. 2004. PMID: 15225827. 10.1016/j.jsbmb.2004.03.059 KQ1E12, KQ2E12, KQ3E6, KQ4E615225827
57 Gibbs, DC, Fedirko, V, . Inflammation Modulation by Vitamin D and Calcium in the Morphologically Normal Colorectal Mucosa of Patients with Colorectal Adenoma in a Clinical Trial. Cancer Prevention Research. 14(1): 65–76. 2021. PMID: 32917645. 10.1158/1940-6207.CAPR-20-0140 KQ1E12, KQ2E12, KQ3E6, KQ4E632917645
58 Gold, DR, Litonjua, AA, . Lung VITAL: Rationale, design, and baseline characteristics of an ancillary study evaluating the effects of vitamin D and/or marine omega-3 fatty acid supplements on acute exacerbations of chronic respiratory disease, asthma control, pneumonia and lung function in adults. Contemp Clin Trials. 47. 185–95. 2016. PMID: 26784651. 10.1016/j.cct.2016.01.003 KQ1E12, KQ2E12, KQ3E6, KQ4E626784651
59 Goossens, ME, Zeegers, MP, . Phase III randomised chemoprevention study with selenium on the recurrence of non-invasive urothelial carcinoma. The SELEnium and BLAdder cancer Trial. Eur J Cancer. 69. 9–18. 2016. PMID: 27814472. 10.1016/j.ejca.2016.09.021 KQ1E12, KQ2E12, KQ3E3, KQ4E327814472
60 Goswami, R, Vatsa, M, . Skeletal muscle strength in young Asian Indian females after vitamin D and calcium supplementation: a double-blind randomized controlled clinical trial. J Clin Endocrinol Metab. 97(12): 4709–16. 2012. PMID: 22904178. 10.1210/jc.2012-2340 KQ1E12, KQ2E12, KQ3E2, KQ4E222904178
61 Graat JM, Schouten EG, Kok FJ. Effect of daily vitamin E and multivitamin-mineral supplementation on acute respiratory tract infections in elderly persons: a randomized controlled trial. JAMA. 288(6,0098-7484 (Print),0098-7484 (Linking)): 715–721. 2002. KQ1E6, KQ2E6, KQ3E6, KQ4E612169075
62 Greenberg, ER, Baron, JA, . A clinical trial of antioxidant vitamins to prevent colorectal adenoma. Polyp Prevention Study Group. N Engl J Med. 331(3): 141–7. 1994. PMID: 8008027. 10.1056/NEJM199407213310301 KQ1E6, KQ2E6a, KQ3E6, KQ4E6a8008027
63 Grimnes, G, Figenschau, Y, . Vitamin D, insulin secretion, sensitivity, and lipids: results from a case-control study and a randomized controlled trial using hyperglycemic clamp technique. Diabetes. 60(11): 2748–57. 2011. PMID: 21911741. 10.2337/db11-0650 KQ1E12, KQ2E12, KQ3E3, KQ4E321911741
64 Grodstein, F, O’Brien, J, . Long-term multivitamin supplementation and cognitive function in men: a randomized trial. Ann Intern Med. 159(12): 806–814. 2013. PMID: 24490265. 10.7326/0003-4819-159-12-201312170-00006 KQ1E6, KQ2E6, KQ3E12, KQ4E1224490265
65 Guyton, JR, Brown, BG, . Lipid-altering efficacy and safety of ezetimibe/simvastatin coadministered with extended-release niacin in patients with type IIa or type IIb hyperlipidemia. J Am Coll Cardiol. 51(16): 1564–72. 2008. PMID: 18420099. 10.1016/j.jacc.2008.03.003 KQ1E12, KQ2E12, KQ3E5a, KQ4E5a18420099
66 Hansen, KE, Johnson, RE, . Treatment of Vitamin D Insufficiency in Postmenopausal Women: A Randomized Clinical Trial. JAMA Intern Med. 175(10): 1612–21. 2015. PMID: 26237520. 10.1001/jamainternmed.2015.3874 KQ1E12, KQ2E12, KQ3E3, KQ4E326237520
67 Harris, SS, Dawson-Hughes, B. Effects of Hydration and Calcium Supplementation on Urine Calcium Concentration in Healthy Postmenopausal Women. J Am Coll Nutr. 34(4): 340–6. 2015. PMID: 25856469. 10.1080/07315724.2014.959207 KQ1E12, KQ2E12, KQ3E6, KQ4E625856469
68 Harwood, RH, Sahota, O, . A randomised, controlled comparison of different calcium and vitamin D supplementation regimens in elderly women after hip fracture: The Nottingham Neck of Femur (NONOF) Study. Age Ageing. 33(1): 45–51. 2004. PMID: 14695863. 10.1093/ageing/afh002 KQ1E12, KQ2E12, KQ3E3, KQ4E314695863
69 Heikkinen, A, Parviainen, MT, . Effects of postmenopausal hormone replacement therapy with and without vitamin D3 on circulating levels of 25-hydroxyvitamin D and 1,25-dihydroxyvitamin D. Calcif Tissue Int. 62(1): 26–30. 1998. PMID: 9405729. 10.1007/s002239900389 KQ1E12, KQ2E12, KQ3E6, KQ4E69405729
70 Hin, H, Tomson, J, . Optimum dose of vitamin D for disease prevention in older people: BEST-D trial of vitamin D in primary care. Osteoporos Int. 28(3): 841–851. 2017. PMID: 27986983. 10.1007/s00198-016-3833-y KQ1E12, KQ2E12, KQ3E6, KQ4E627986983
71 Hodis, HN, Mack, WJ, . High-dose B vitamin supplementation and progression of subclinical atherosclerosis: a randomized controlled trial. Stroke. 40(3): 730–6. 2009. PMID: 19118243. 10.1161/STROKEAHA.108.526798 KQ1E12, KQ2E12, KQ3E11, KQ4E1119118243
72 Hofstad, B, Almendingen, K, . Growth and recurrence of colorectal polyps: a double-blind 3-year intervention with calcium and antioxidants. Digestion. 59(2): 148–56. 1998. PMID: 9586828. 10.1159/000007480 KQ1E6, KQ2E6a, KQ3E12, KQ4E129586828
73 Huang, J, Weinstein, SJ, . A prospective study of serum Vitamin E and 28-year risk of lung cancer. J Natl Cancer Inst. 112(2). 2021. PMID: 31077299. 10.1093/JNCI/DJZ077 KQ1E12, KQ2E12, KQ3E5, KQ4E631077299
74 Hunter, D, Major, P, . A randomized controlled trial of vitamin D supplementation on preventing postmenopausal bone loss and modifying bone metabolism using identical twin pairs. J Bone Miner Res. 15(11): 2276–83. 2000. PMID: 11092410. 10.1359/jbmr.2000.15.11.2276 KQ1E12, KQ2E12, KQ3E6, KQ4E611092410
75 Janssen, HC, Samson, MM, . Muscle strength and mobility in vitamin D-insufficient female geriatric patients: a randomized controlled trial on vitamin D and calcium supplementation. Aging Clin Exp Res. 22(1): 78–84. 2010. PMID: 20305368. 10.1007/bf03324819 KQ1E12, KQ2E12, KQ3E3, KQ4E320305368
76 Jaszewski, R, Misra, S, . Folic acid supplementation inhibits recurrence of colorectal adenomas: a randomized chemoprevention trial. World J Gastroenterol. 14(28): 4492–8. 2008. PMID: 18680228. 10.3748/wjg.14.4492 KQ1E12, KQ2E12, KQ3E6, KQ4E418680228
77 Johnson, AR, Munoz, A, . High dose zinc increases hospital admissions due to genitourinary complications. J Urol. 177(2): 639–43. 2007. PMID: 17222649. 10.1016/j.juro.2006.09.047 KQ1E12, KQ2E12, KQ3E11, KQ4E1117222649
78 Jorde, R, Sneve, M, . Effects of vitamin D supplementation on symptoms of depression in overweight and obese subjects: randomized double blind trial. J Intern Med. 264(6): 599–609. 2008. PMID: 18793245. 10.1111/j.1365-2796.2008.02008.x KQ1E12, KQ2E12, KQ3E6, KQ4E6a18793245
79 Jorde, R, Sneve, M, . No improvement in cardiovascular risk factors in overweight and obese subjects after supplementation with vitamin D3 for 1 year. J Intern Med. 267(5): 462–72. 2010. PMID: 20141565. 10.1111/j.1365-2796.2009.02181.x KQ1E12, KQ2E12, KQ3E6, KQ4E620141565
80 Kakigi, CL, Singh, K, . Self-reported Calcium Supplementation and Age-Related Macular Degeneration. JAMA Ophthalmol. 133(7): 746–54. 2015. PMID: 25856252. 10.1001/jamaophthalmol.2015.0514 KQ1E12, KQ2E12, KQ3E5, KQ4E525856252
81 Karamali, M, Nourgostar, S, . The favorable effects of long-term selenium supplementation on regression of cervical tissues and metabolic profiles of patients with cervical intraepithelial neoplasia: a randomised, double-blind, placebo-controlled trial - Expression of concern. Br J Nutr. 1. 2021. PMID: 34353382. 10.1017/S0007114521002014 KQ1E12, KQ2E12, KQ3E2, KQ4E234353382
82 Kearns, MD, Binongo, JN, . The effect of a single, large bolus of vitamin D in healthy adults over the winter and following year: a randomized, double-blind, placebo-controlled trial. Eur J Clin Nutr. 69(2): 193–7. 2015. PMID: 25271011. 10.1038/ejcn.2014.209 KQ1E12, KQ2E12, KQ3E6, KQ4E6a25271011
83 Kennedy, Do, Stevenson, Ej, . Multivitamins and minerals modulate whole-body energy metabolism and cerebral blood-flow during cognitive task performance: a double-blind, randomised, placebo-controlled trial. Nutr Metab (Lond). 13. 1–16. 2016. KQ1E6, KQ2E5a, KQ3E12, KQ4E1226752997
84 Kim, H, Chandler, P, . Obesity and efficacy of vitamin D3 supplementation in healthy black adults. CCC. 31(4): 303–307. 2020. KQ1E12, KQ2E12, KQ3E6, KQ4E632052217
85 Kim, HN, Kim, SH, . Effects of zinc, magnesium, and chromium supplementation on cardiometabolic risk in adults with metabolic syndrome: A double-blind, placebo-controlled randomised trial. Journal of Trace Elements in Medicine and Biology. 48. 166–171. 2018. PMID: 29773176. 10.1016/j.jtemb.2018.03.022 KQ1E12, KQ2E12, KQ3E14, KQ4E1429773176
86 Kim, SH, Brodsky, IG, . Effect of Vitamin D Supplementation on Kidney Function in Adults with Prediabetes: A Secondary Analysis of a Randomized Trial. Clinical Journal of The American Society of Nephrology: CJASN. 16(8): 1201–1209. 2021. PMID: 34362787. 10.2215/CJN.00420121 KQ1E12, KQ2E12, KQ3E6, KQ4E634362787
87 Kjaergaard, M, Waterloo, K, . Effect of vitamin D supplement on depression scores in people with low levels of serum 25-hydroxyvitamin D: nested case-control study and randomised clinical trial. Br J Psychiatry. 201(5): 360–8. 2012. PMID: 22790678. 10.1192/bjp.bp.111.104349 KQ1E12, KQ2E12, KQ3E3, KQ4E322790678
88 Koitaya, N, Sekiguchi, M, . Low-dose vitamin K2 (MK-4) supplementation for 12 months improves bone metabolism and prevents forearm bone loss in postmenopausal Japanese women. J Bone Miner Metab. 32(2): 142–50. 2014. PMID: 23702931. 10.1007/s00774-013-0472-7 KQ1E12, KQ2E12, KQ3E12, KQ4E1223702931
89 Kok, DE, Dhonukshe-Rutten, RA, . The effects of long-term daily folic acid and vitamin B12 supplementation on genome-wide DNA methylation in elderly subjects. Clin Epigenetics. 7. 121. 2015. PMID: 26568774. 10.1186/s13148-015-0154-5 KQ1E12, KQ2E12, KQ3E6, KQ4E626568774
90 Laaksi, I, Ruohola, JP, . Vitamin D supplementation for the prevention of acute respiratory tract infection: a randomized, double-blinded trial among young Finnish men. J Infect Dis. 202(5): 809–14. 2010. PMID: 20632889. 10.1086/654881 KQ1E12, KQ2E12, KQ3E6, KQ4E6a20632889
91 Lagari, VS, Gomez-Marin, O, . Differences in vitamin D3 dosing regimens in a geriatric community-dwelling population. Endocr Pract. 18(6): 847–54. 2012. PMID: 22784845. 10.4158/EP12081.OR KQ1E12, KQ2E12, KQ3E5a, KQ4E5a22784845
92 Larsen, ER, Mosekilde, L, . Vitamin D and calcium supplementation prevents osteoporotic fractures in elderly community dwelling residents: a pragmatic population-based 3-year intervention study. J Bone Miner Res. 19(3): 370–8. 2004. PMID: 15040824. 10.1359/JBMR.0301240 KQ1E12, KQ2E12, KQ3E6, KQ4E615040824
93 Latham, NK, Anderson, CS, . A randomized, controlled trial of quadriceps resistance exercise and vitamin D in frail older people: the Frailty Interventions Trial in Elderly Subjects (FITNESS). J Am Geriatr Soc. 51(3): 291–9. 2003. PMID: 12588571. 10.1046/j.1532-5415.2003.51101.x KQ1E3, KQ2E3, KQ3E3, KQ4E312588571
94 Law, M, Withers, H, . Vitamin D supplementation and the prevention of fractures and falls: results of a randomised trial in elderly people in residential accommodation. Age Ageing. 35(5): 482–6. 2006. PMID: 16641143. 10.1093/ageing/afj080 KQ1E12, KQ2E12, KQ3E3, KQ4E316641143
95 LeBoff, MS, Murata, EM, . VITamin D and OmegA-3 TriaL (VITAL): Effects of Vitamin D Supplements on Risk of Falls in the US Population. J Clin Endocrinol Metab. 105(9): 01. 2020. KQ1E12, KQ2E12, KQ3E6, KQ4E6
96 Leenders, Tjm, Liefers, Wj, . Patients with hypertension and higher body mass index have tower Vitamin D levels after supplementation. Pharm Weekbl. 151(24): 34–37. 2016. KQ1E8, KQ2E8, KQ3E8, KQ4E8
97 Levine N, Moon TE, Cartmel B, Bangert JL, . Trial of retinol and isotretinoin in skin cancer prevention: a randomized, double-blind, controlled trial. Southwest Skin Cancer Prevention Study Group. Cancer Epidemiol Biomarkers Prev. 6(11,1055-9965 (Print),1055-9965 (Linking)): 957–961. 1997. KQ1E6, KQ2E6, KQ3E6, KQ4E69367070
98 Lewis, Rm, Redzic, M, . The effects of season-long vitamin D supplementation on collegiate swimmers and divers. Int J Sport Nutr Exerc Metab. 23(5): 431–440. 2013. PMID: 23475128. KQ1E12, KQ2E12, KQ3E6, KQ4E623475128
99 Limburg, PJ, Wei, W, . Randomized, placebo-controlled, esophageal squamous cell cancer chemoprevention trial of selenomethionine and celecoxib. Gastroenterology. 129(3): 863–73. 2005. PMID: 16143126. 10.1053/j.gastro.2005.06.024 KQ1E12, KQ2E12, KQ3E2, KQ4E216143126
100 Liu, S, Barry, EL, . Effects of supplemental calcium and vitamin D on the APC/beta-catenin pathway in the normal colorectal mucosa of colorectal adenoma patients. Mol Carcinog. 56(2): 412–424. 2017. PMID: 27254743. 10.1002/mc.22504 KQ1E12, KQ2E12, KQ3E6, KQ4E627254743
101 Logan, VF, Gray, AR, . Long-term vitamin D3 supplementation is more effective than vitamin D2 in maintaining serum 25-hydroxyvitamin D status over the winter months. Br J Nutr. 109(6): 1082–8. 2013. PMID: 23168298. 10.1017/S0007114512002851 KQ1E12, KQ2E12, KQ3E6, KQ4E6a23168298
102 Lyons, RA, Johansen, A, . Preventing fractures among older people living in institutional care: a pragmatic randomised double blind placebo controlled trial of vitamin D supplementation. Osteoporos Int. 18(6): 811–8. 2007. PMID: 17473911. 10.1007/s00198-006-0309-5 KQ1E12, KQ2E12, KQ3E3, KQ4E317473911
103 MacLennan, R, Macrae, F, . Randomized trial of intake of fat, fiber, and beta carotene to prevent colorectal adenomas. J Natl Cancer Inst. 87(23): 1760–6. 1995. PMID: 7473832. 10.1093/jnci/87.23.1760 KQ1E12, KQ2E12, KQ3E6, KQ4E67473832
104 Maharshi, V, Kumar, VL, . Effect of ascorbic acid supplementation on pulmonary functions in healthy adults: a randomized controlled pilot study. J Basic Clin Physiol Pharmacol. 16. 16. 2021. PMID: 34914338. 10.1515/jbcpp-2021-0243 KQ1E12, KQ2E12, KQ3E2, KQ4E234914338
105 Makariou, SE, Elisaf, M, . No effect of vitamin D administration plus dietary intervention on emerging cardiovascular risk factors in patients with metabolic syndrome. Journal of Nutrition and Intermediary Metabolism. 16. 2019. 10.1016/j.jnim.2019.100093 KQ1E12, KQ2E12, KQ3E6, KQ4E6
106 Manson, JE, Bassuk, SS, . Vitamin D, Marine n-3 Fatty Acids, and Primary Prevention of Cardiovascular Disease Current Evidence. Circ Res. 126(1): 112–128. 2020. KQ1E12, KQ2E12, KQ3E12, KQ4E1231895658
107 Marshall, JR, Tangen, CM, . Phase III trial of selenium to prevent prostate cancer in men with high-grade prostatic intraepithelial neoplasia: SWOG S9917. Cancer Prev Res (Phila). 4(11): 1761–9. 2011. PMID: 21896650. 10.1158/1940-6207.CAPR-10-0343 KQ1E12, KQ2E12, KQ3E3, KQ4E321896650
108 Martineau, AR, Hanifa, Y, . Double-blind randomised controlled trial of vitamin D3 supplementation for the prevention of acute respiratory infection in older adults and their carers (ViDiFlu). Thorax. 70(10): 953–60. 2015. PMID: 26063508. 10.1136/thoraxjnl-2015-206996 KQ1E12, KQ2E12, KQ3E5a, KQ4E5a26063508
109 Mason, C, Xiao, L, . Vitamin D3 supplementation during weight loss: a double-blind randomized controlled trial. Am J Clin Nutr. 99(5): 1015–25. 2014. PMID: 24622804. 10.3945/ajcn.113.073734 KQ1E12, KQ2E12, KQ3E6, KQ4E6a24622804
110 Mazahery, H, Stonehouse, W, . The effect of monthly 50,000 IU or 100,000 IU vitamin D supplements on vitamin D status in premenopausal Middle Eastern women living in Auckland. Eur J Clin Nutr. 69(3): 367–72. 2015. PMID: 25491499. 10.1038/ejcn.2014.264 KQ1E12, KQ2E12, KQ3E6, KQ4E6a25491499
111 McCullough, ML, Bostick, RM, . Vitamin D status and impact of vitamin D3 and/or calcium supplementation in a randomized pilot study in the Southeastern United States. J Am Coll Nutr. 28(6): 678–86. 2009. PMID: 20516268. 10.1080/07315724.2009.10719801 KQ1E12, KQ2E12, KQ3E6, KQ4E6a20516268
112 McKeown-Eyssen, G, Holloway, C, . A randomized trial of vitamins C and E in the prevention of recurrence of colorectal polyps. Cancer Res. 48(16): 4701–5. 1988. PMID: 3293777. KQ1E12, KQ2E12, KQ3E6, KQ4E63293777
113 Melhus, H, Michaelsson, K, . Excessive dietary intake of vitamin A is associated with reduced bone mineral density and increased risk for hip fracture. Ann Intern Med. 129(10): 770–8. 1998. PMID: 9841582. 10.7326/0003-4819-129-10-199811150-00003 KQ1E12, KQ2E12, KQ3E5, KQ4E129841582
114 Meyer, HE, Smedshaug, GB, . Can vitamin D supplementation reduce the risk of fracture in the elderly? A randomized controlled trial. J Bone Miner Res. 17(4): 709–15. 2002. PMID: 11918228. 10.1359/jbmr.2002.17.4.709 KQ1E12, KQ2E12, KQ3E3, KQ4E311918228
115 Mooney, LA, Madsen, AM, . Antioxidant vitamin supplementation reduces benzo(a)pyrene-DNA adducts and potential cancer risk in female smokers. Cancer Epidemiol Biomarkers Prev. 14(1): 237–42. 2005. PMID: 15668500. KQ1E12, KQ2E12, KQ3E4, KQ4E615668500
116 Moreira-Pfrimer, LD, Pedrosa, MA, . Treatment of vitamin D deficiency increases lower limb muscle strength in institutionalized older people independently of regular physical activity: a randomized double-blind controlled trial. Ann Nutr Metab. 54(4): 291–300. 2009. PMID: 19729890. 10.1159/000235874 KQ1E12, KQ2E12, KQ3E3, KQ4E319729890
117 Morgia, G, Voce, S, . Association between selenium and lycopene supplementation and incidence of prostate cancer: Results from the post-hoc analysis of the procomb trial. Phytomedicine. 34. 1–5. 2017. PMID: 28899491. 10.1016/j.phymed.2017.06.008 KQ1E12, KQ2E12, KQ3E12, KQ4E1228899491
118 Nadra, R. Study of the Relationship between Calcium Supplementation and Human Systolic Blood Pressure. International medical journal. 25(2): 83–85. 2018. KQ1E12, KQ2E12, KQ3E6, KQ4E6
119 Nguyen, S, Baggerly, L, . 25-Hydroxyvitamin D in the Range of 20 to 100 ng/mL and Incidence of Kidney Stones. Am J Public Health. 104(9): 1783–1787. 2014. PMID: 24134366. KQ1E12, KQ2E12, KQ3E5, KQ4E524134366
120 Nieves, JW, Cosman, F, . Skeletal effects of vitamin D supplementation in postmenopausal black women. Calcif Tissue Int. 91(5): 316–24. 2012. PMID: 22923289. 10.1007/s00223-012-9638-x KQ1E12, KQ2E12, KQ3E3, KQ4E322923289
121 Nygaard, B, Frandsen, NE, . Effects of high doses of cholecalciferol in normal subjects: a randomized double-blinded, placebo-controlled trial. PLoS ONE [Electronic Resource]. 9(8): e102965. 2014. PMID: 25166750. 10.1371/journal.pone.0102965 KQ1E12, KQ2E12, KQ3E6, KQ4E625166750
122 Osman, MT, Rahman, T, . Effects of adding tocotrienol-tocopherol mixed fraction and vitamin C on inflammatory status in hypercholesterolaemic patients in the low coronary risk category. Biomedical Research and Therapy. 3(3). 2016. 10.7603/s40730-016-0013-9 KQ1E2, KQ2E2, KQ3E2, KQ4E2
123 Paik, JM, Curhan, GC, . Calcium supplement intake and risk of cardiovascular disease in women. Osteoporos Int. 25(8): 2047–56. 2014. PMID: 24803331. 10.1007/s00198-014-2732-3 KQ1E12, KQ2E12, KQ3E5, KQ4E624803331
124 Phan, BA, Munoz, L, . Effects of niacin on glucose levels, coronary stenosis progression, and clinical events in subjects with normal baseline glucose levels (<100 mg/dl): a combined analysis of the Familial Atherosclerosis Treatment Study (FATS), HDL-Atherosclerosis Treatment Study (HATS), Armed Forces Regression Study (AFREGS), and Carotid Plaque Composition by MRI during lipid-lowering (CPC) study. Am J Cardiol. 111(3): 352–5. 2013. PMID: 23168285. 10.1016/j.amjcard.2012.09.034 KQ1E12, KQ2E12, KQ3E3, KQ4E323168285
125 Pilz, S, Frisch, S, . Effect of vitamin D supplementation on testosterone levels in men. Horm Metab Res. 43(3): 223–5. 2011. PMID: 21154195. 10.1055/s-0030-1269854 KQ1E12, KQ2E12, KQ3E6, KQ4E621154195
126 Ponz de Leon, M, Roncucci, L. Chemoprevention of colorectal tumors: role of lactulose and of other agents. Scand J Gastroenterol Suppl. 222. 72–5. 1997. PMID: 9145453. 10.1080/00365521.1997.11720724 KQ1E6, KQ2E6, KQ3E12, KQ4E129145453
127 Porthouse, J, Cockayne, S, . Randomised controlled trial of calcium and supplementation with cholecalciferol (vitamin D3) for prevention of fractures in primary care. BMJ. 330(7498): 1003. 2005. PMID: 15860827. 10.1136/bmj.330.7498.1003 KQ1E12, KQ2E12, KQ3E4, KQ4E615860827
128 Pradhan, AD, Manson, JE. Update on the Vitamin D and OmegA-3 trial (VITAL). J Steroid Biochem Mol Biol. 155(Pt B): 252–6. 2016. PMID: 25864623. 10.1016/j.jsbmb.2015.04.006 KQ1E12, KQ2E12, KQ3E6, KQ4E625864623
129 Prince, RL, Austin, N, . Effects of ergocalciferol added to calcium on the risk of falls in elderly high-risk women. Arch Intern Med. 168(1): 103–8. 2008. PMID: 18195202. 10.1001/archinternmed.2007.31 KQ1E12, KQ2E12, KQ3E3, KQ4E318195202
130 Qin, B, Xu, B, . Intake of vitamin D and calcium, sun exposure, and risk of breast cancer subtypes among black women. Am J Clin Nutr. 111(2): 396–405. 2020. KQ1E5, KQ2E5, KQ3E5, KQ4E531826233
131 Ranasinghe, P, Wathurapatha, WS, . Zinc supplementation in prediabetes: A randomized double-blind placebo-controlled clinical trial. J Diabetes. 10(5): 386–397. 2018. PMID: 29072815. 10.1111/1753-0407.12621 KQ1E2, KQ2E2, KQ3E2, KQ4E229072815
132 Retallick-Brown, H, Blampied, N, . A Pilot Randomized Treatment-Controlled Trial Comparing Vitamin B6 with Broad-Spectrum Micronutrients for Premenstrual Syndrome. Journal of Alternative & Complementary Medicine. 26(2): 88–97. 2020. KQ1E5a, KQ2E5a, KQ3E5a, KQ4E5a31928364
133 Rist, Pm, Cook, Nr, . Effect of vitamin D and marine omega-3 fatty acid supplements on stroke outcomes. Stroke. 51(Suppl 1). 2020. PMID: CN-02300736. KQ1E12, KQ2E12, KQ3E6, KQ4E6
134 Roncucci, L, Di Donato, P, . Antioxidant vitamins or lactulose for the prevention of the recurrence of colorectal adenomas. Colorectal Cancer Study Group of the University of Modena and the Health Care District 16. Dis Colon Rectum. 36(3): 227–34. 1993. PMID: 8449125. 10.1007/bf02053502 KQ1E6, KQ2E6a, KQ3E12, KQ4E128449125
135 Savinova, OV, Fillaus, K, . Effects of niacin and omega-3 fatty acids on the apolipoproteins in overweight patients with elevated triglycerides and reduced HDL cholesterol. Atherosclerosis. 240(2): 520–525. 2015. PMID: 25932792. 10.1016/j.atherosclerosis.2015.04.793 KQ1E12, KQ2E12, KQ3E6, KQ4E625932792
136 Schwetz, V, Scharnagl, H, . Vitamin D supplementation and lipoprotein metabolism: A randomized controlled trial. J Clin Lipidol. 12(3): 588–596.e4. 2018. PMID: 29653812. 10.1016/j.jacl.2018.03.079 KQ1E12, KQ2E12, KQ3E6, KQ4E629653812
137 Scragg, R, Slow, S, . Long-term high-dose vitamin D3 supplementation and blood pressure in healthy adults: a randomized controlled trial. Hypertension. 64(4): 725–30. 2014. PMID: 24980662. 10.1161/HYPERTENSIONAHA.114.03466 KQ1E12, KQ2E12, KQ3E6, KQ4E624980662
138 Search and rescue for hypotheses surviving AIM-HIGH, the niacin therapy earthquake: still problematic after the primary publication. J Clin Lipidol. 6(4): 312–317. 2012. KQ1E12, KQ2E12, KQ3E13, KQ4E1322836067
139 Shaeffer, Kl. The effect of calcium supplementation on blood pressure and hemodynamic variables in hypertensive males. 1996. KQ1E12, KQ2E12, KQ3E6, KQ4E6
140 Shaughnessy, AF. Vitamin D does not affect isolated systolic hypertension. Am Fam Physician. 88(11): 739–744. 2013. KQ1E12, KQ2E12, KQ3E5, KQ4E5
141 Sneve, M, Figenschau, Y, . Supplementation with cholecalciferol does not result in weight reduction in overweight and obese subjects. Eur J Endocrinol. 159(6): 675–84. 2008. PMID: 19056900. 10.1530/EJE-08-0339 KQ1E12, KQ2E12, KQ3E6, KQ4E6a19056900
142 Song, M, Lee, IM, . No Association Between Vitamin D Supplementation and Risk of Colorectal Adenomas or Serrated Polyps in a Randomized Trial. Clin Gastroenterol Hepatol 2020. KQ1E12, KQ2E12, KQ3E6, KQ4E6
143 Song, S, Lee, CJ, . Effect of Niacin on Carotid Atherosclerosis in Patients at Low-Density Lipoprotein-Cholesterol Goal but High Lipoprotein (a) Level: a 2-Year Follow-Up Study. Journal of Lipid & Atherosclerosis. 8(1): 58–66. 2019. KQ1E12, KQ2E12, KQ3E6, KQ4E632821700
144 Song, Y, Manson, JE, . Effect of combined folic acid, vitamin B(6), and vitamin B(12) on colorectal adenoma. J Natl Cancer Inst. 104(20): 1562–75. 2012. PMID: 23066166. 10.1093/jnci/djs370 KQ1E3, KQ2E3, KQ3E12, KQ4E1223066166
145 Stampfer, M, Willett, W. Folate supplements for stroke prevention: targeted trial trumps the rest. JAMA. 313(13): 1321–2. 2015. PMID: 25770867. 10.1001/jama.2015.1961 KQ1E5, KQ2E5, KQ3E5, KQ4E525770867
146 Stratton, MS, Algotar, AM, . Oral selenium supplementation has no effect on prostate-specific antigen velocity in men undergoing active surveillance for localized prostate cancer. Cancer Prev Res (Phila). 3(8): 1035–43. 2010. 10.1158/1940-6207.CAPR-09-0143 KQ1E12, KQ2E12, KQ3E4, KQ4E420647337
147 Tarleton, EK, Littenberg, B, . Role of magnesium supplementation in the treatment of depression: A randomized clinical trial. PLoS ONE [Electronic Resource]. 12(6): e0180067. 2017. PMID: 28654669. 10.1371/journal.pone.0180067 KQ1E12, KQ2E12, KQ3E6, KQ4E528654669
148 Taylor, A, Jacques, PF, . Long-term intake of vitamins and carotenoids and odds of early age-related cortical and posterior subcapsular lens opacities. Am J Clin Nutr. 75(3): 540–9. 2002. PMID: 11864861. 10.1093/ajcn/75.3.540 KQ1E5, KQ2E6, KQ3E5, KQ4E611864861
149 Thorpe, DL, Beeson, WL, . Dietary patterns and hip fracture in the Adventist Health Study 2: combined vitamin D and calcium supplementation mitigate increased hip fracture risk among vegans. Am J Clin Nutr. 114(2): 488–495. 2021. PMID: 33964850. 10.1093/ajcn/nqab095 KQ1E12, KQ2E12, KQ3E1, KQ4E133964850
150 Todd, JJ, McSorley, EM, . Oral spray wintertime vitamin D3 supplementation has no impact on inflammation in Gaelic footballers. Scand J Med Sci Sports. 27(11): 1300–1307. 2017. PMID: 27704631. 10.1111/sms.12785 KQ1E12, KQ2E12, KQ3E6, KQ4E627704631
151 Tran, B, Armstrong, BK, . Recruitment and results of a pilot trial of vitamin D supplementation in the general population of Australia. J Clin Endocrinol Metab. 97(12): 4473–80. 2012. PMID: 23066119. 10.1210/jc.2012-2682 KQ1E12, KQ2E12, KQ3E6, KQ4E623066119
152 Tuomainen, Tp, Virtanen, Jk, . Glucose Metabolism Effects of Vitamin D in Prediabetes: the VitDmet Randomized Placebo-Controlled Supplementation Study. J Diabetes Res. 2015. 672653. 2015. PMID: 26106626. 10.1155/2015/672653 KQ1E12, KQ2E12, KQ3E6, KQ4E626106626
153 Valimaki, VV, Loyttyniemi, E, . How well are the optimal serum 25OHD concentrations reached in high-dose intermittent vitamin D therapy? a placebo-controlled study on comparison between 100 000 IU and 200 000 IU of oral D3 every 3 months in elderly women. Clin Endocrinol (Oxf). 84(6): 837–44. 2016. PMID: 26725707. 10.1111/cen.13014 KQ1E12, KQ2E12, KQ3E6, KQ4E6a26725707
154 Vermandere, K, Bostick, RM, . Effects of Supplemental Calcium and Vitamin D on Circulating Biomarkers of Gut Barrier Function in Patients with Colon Adenoma: A Randomized Clinical Trial. Cancer Prevention Research. 14(3): 393–402. 2021. PMID: 33229339. 10.1158/1940-6207.CAPR-20-0461 KQ1E12, KQ2E12, KQ3E6, KQ4E633229339
155 Viljakainen, HT, Vaisanen, M, . Wintertime vitamin D supplementation inhibits seasonal variation of calcitropic hormones and maintains bone turnover in healthy men. J Bone Miner Res. 24(2): 346–52. 2009. PMID: 18847321. 10.1359/jbmr.081009 KQ1E12, KQ2E12, KQ3E6, KQ4E618847321
156 Wakai, E, Ikemura, K, . Risk factors for the development of hypermagnesemia in patients prescribed magnesium oxide: A retrospective cohort study. Journal of Pharmaceutical Health Care and Sciences. 5(1). 2019. 10.1186/s40780-019-0133-7 KQ1E12, KQ2E12, KQ3E12, KQ4E12
157 Waterhouse, M, Tran, B, . Environmental, personal, and genetic determinants of response to vitamin D supplementation in older adults. J Clin Endocrinol Metab. 99(7): E1332–40. 2014. PMID: 24694335. 10.1210/jc.2013-4101 KQ1E12, KQ2E12, KQ3E6, KQ4E624694335
158 Weinstein, SJ, Mondul, AM, . Circulating 25-hydroxyvitamin D up to 3 decades prior to diagnosis in relation to overall and organ-specific cancer survival. Eur J Epidemiol. 33(11): 1087–1099. 2018. PMID: 30073448. 10.1007/s10654-018-0428-2 KQ1E12, KQ2E12, KQ3E5, KQ4E630073448
159 Witham, Md, Price, Rjg, . 102 effect of vitamin d supplementation on orthostatic hypotension – data from the vitdish trial. Age Ageing. 43(suppl_1): i27. 2014. KQ1E13, KQ2E13, KQ3E13, KQ4E13
160 Witham, MD, Price, RJ, . Cholecalciferol treatment to reduce blood pressure in older patients with isolated systolic hypertension: the VitDISH randomized controlled trial. JAMA Intern Med. 173(18): 1672–9. 2013. PMID: 23939263. KQ1E12, KQ2E12, KQ3E3, KQ4E323939263
161 Witham, MD, Price, RJ, . Effect of vitamin D supplementation on orthostatic hypotension: data from the vitamin D in isolated systolic hypertension randomized controlled trial. J Hypertens. 32(8): 1693–9; discussion 1699. 2014. PMID: 24879494. 10.1097/HJH.0000000000000223 KQ1E12, KQ2E12, KQ3E6, KQ4E624879494
162 Wongwiwatthananukit, S, Sansanayudh, N, . Effects of vitamin D2 supplementation on insulin sensitivity and metabolic parameters inmetabolic syndrome patients. J Endocrinol Invest. 36(8): 558–563. 2013. PMID: 23385553. 10.3275/8817 KQ1E2, KQ2E2, KQ3E2, KQ4E223385553
163 Woo, KS, Yip, TWC, . Vitamins B-12 and C Supplementation Improves Arterial Reactivity and Structure in Passive Smokers: Implication in Prevention of Smoking-Related Atherosclerosis. Journal of Nutrition, Health & Aging. 25(2): 248–254. 2021. PMID: 33491041. 10.1007/s12603-020-1529-7 KQ1E12, KQ2E12, KQ3E2, KQ4E233491041
164 Wood, AD, Secombes, KR, . A parallel group double-blind RCT of vitamin D3 assessing physical function: is the biochemical response to treatment affected by overweight and obesity?. Osteoporos Int. 25(1): 305–15. 2014. PMID: 23982800. 10.1007/s00198-013-2473-8 KQ1E12, KQ2E12, KQ3E6, KQ4E6a23982800
165 Zeichner, SB, Cavalcante, M, . Supplement use and gastrointestinal bleeding. Asian Journal of Pharmaceutical and Clinical Research. 7(SUPPL. 2): 194–201. 2014. KQ1E12, KQ2E12, KQ3E5, KQ4E5
166 Zhang, SM, Cook, NR, . Effect of combined folic acid, vitamin B6, and vitamin B12 on cancer risk in women: a randomized trial. JAMA. 300(17): 2012–21. 2008. PMID: 18984888. 10.1001/jama.2008.555 KQ1E3, KQ2E3, KQ3E12, KQ4E1218984888
167 Zhu, K, Bruce, D, . Randomized controlled trial of the effects of calcium with or without vitamin D on bone structure and bone-related chemistry in elderly women with vitamin D insufficiency. J Bone Miner Res. 23(8): 1343–8. 2008. PMID: 18410225. 10.1359/jbmr.080327 KQ1E12, KQ2E12, KQ3E3, KQ4E318410225
168 Zhu, K, Devine, A, . Effects of calcium and vitamin D supplementation on hip bone mineral density and calcium-related analytes in elderly ambulatory Australian women: a five-year randomized controlled trial. J Clin Endocrinol Metab. 93(3): 743–9. 2008. PMID: 18089701. 10.1210/jc.2007-1466 KQ1E12, KQ2E12, KQ3E6, KQ4E618089701
169 Zschabitz, S, Cheng, TY, . B vitamin intakes and incidence of colorectal cancer: results from the Women’s Health Initiative Observational Study cohort. Am J Clin Nutr. 97(2): 332–43. 2013. PMID: 23255571. 10.3945/ajcn.112.034736 KQ1E12, KQ2E12, KQ3E5, KQ4E623255571