# Appendix B Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

- Aloia, J, Fazzari, M, . Vitamin D Supplementation in Elderly Black Women Does Not Prevent Bone Loss: a Randomized Controlled Trial. J Bone Miner Res. 33(11): 1916–1922. 2018. PMID: 29905969. 10.1002/jbmr.3521 29905969
  - Owusu, JE, Islam, S, . Cognition and Vitamin D in Older African-American Women- Physical performance and Osteoporosis prevention with vitamin D in older African Americans Trial and Dementia. J Am Geriatr Soc. 67(1): 81–86. 2019. PMID: 30359476. 10.1111/jgs.15607 30359476
- Aloia, JF, Talwar, SA, . A randomized controlled trial of vitamin D3 supplementation in African American women. Arch Intern Med. 165(14): 1618–23. 2005. PMID: 16043680. 10.1001/archinte.165.14.1618 16043680
- Avenell, A, Campbell, MK, . Effect of multivitamin and multimineral supplements on morbidity from infections in older people (MAVIS trial): pragmatic, randomised, double blind, placebo controlled trial. BMJ. 331(7512): 324–9. 2005. PMID: 16081445. 10.1136/bmj.331.7512.324 16081445
- Avenell A, MacLennan GS, Jenkinson DJ, McPherson GC, . Long-term follow-up for mortality and cancer in a randomized placebo-controlled trial of vitamin D(3) and/or calcium (RECORD trial). J Clin Endocrinol Metab. 97(2): 614–622. 2012.22112804
  - Ford, JA, MacLennan, GS, . Cardiovascular disease and vitamin D supplementation: trial analysis, systematic review, and meta-analysis. Am J Clin Nutr. 100(3): 746–55. 2014. PMID: 25057156. 10.3945/ajcn.113.082602 25057156
  - Grant, AM, Avenell, A, . Oral vitamin D3 and calcium for secondary prevention of low-trauma fractures in elderly people (Randomised Evaluation of Calcium Or vitamin D, RECORD): a randomised placebo-controlled trial. Lancet. 365(9471): 1621–1628. 2005. PMID: 15885294.15885294
- Baeksgaard, L, Andersen, KP, . Calcium and vitamin D supplementation increases spinal BMD in healthy, postmenopausal women. Osteoporos Int. 8(3): 255–60. 1998. PMID: 9797910. 10.1007/s001980050062 9797910
- Baron, JA, Barry, EL, . A Trial of Calcium and Vitamin D for the prevention of colorectal adenomas. N Engl J Med. 373(16): 1519–30. 2015. PMID: 26465985. 10.1056/NEJMoa1500409 26465985
  - Calderwood, AH, Baron, JA, . No Evidence for Posttreatment Effects of Vitamin D and Calcium Supplementation on Risk of Colorectal Adenomas in a Randomized Trial. Cancer Prevention Research. 12(5): 295–304. 2019. PMID: 30833381. 10.1158/1940-6207.CAPR-19-0023 30833381
- Baron JA, Beach M, Wallace K, Grau MV, . Risk of prostate cancer in a randomized clinical trial of calcium supplementation. Cancer Epidemiol Biomarkers Prev. 14(3): 586–589. 2005.15767334
  - Baron, JA, Beach, M, . Calcium supplements for the prevention of colorectal adenomas. Calcium Polyp Prevention Study Group. N Engl J Med. 340(2): 101–107. 1999. PMID: 9887161.9887161
  - Passarelli, MN, Karagas, MR, . Risk of keratinocyte carcinomas with vitamin D and calcium supplementation: a secondary analysis of a randomized clinical trial. Am J Clin Nutr. 112(6): 1532–1539. 2020. PMID: 33022713. 10.1093/ajcn/nqaa267 33022713
- Bolland MJ, Barber PA, Doughty RN, Mason B, . Vascular events in healthy older women receiving calcium supplementation: randomised controlled trial. BMJ. 336(7638): 262–266. 2008.18198394
  - Reid, IR, Horne, A, . Effects of calcium supplementation on body weight and blood pressure in normal older women: a randomized controlled trial. J Clin Endocrinol Metab. 90(7): 3824–3829. 2005. PMID: 15827103.15827103
  - Reid, IR, Mason, B, . Randomized controlled trial of calcium in healthy older women. Am J Med. 119(9): 777–785. 2006. PMID: 16945613.16945613
- Bonelli, L, Puntoni, M, . Antioxidant supplement and long-term reduction of recurrent adenomas of the large bowel. A double-blind randomized trial. J Gastroenterol. 48(6): 698–705. 2013. PMID: 23065023. 10.1007/s00535-012-0691-z 23065023
- Brisson, J, Berube, S, . A Randomized Double-Blind Placebo-Controlled Trial of the Effect of Vitamin D3 Supplementation on Breast Density in Premenopausal Women. Cancer Epidemiol Biomarkers Prevent. 26(8): 1233–1241. 2017. PMID: 28515107. 10.1158/1055-9965.EPI-17-0249 28515107
- Chen, AC, Martin, AJ, . A phase 3 randomized trial of nicotinamide for skin-cancer chemoprevention. N Engl J Med. 373(17): 1618–1626. 2015. PMID: 26488693. 10.1056/NEJMoa1506197 26488693
- Chylack LT, Brown NP, Bron A, Hurst M, . The Roche European American Cataract Trial (REACT): a randomized clinical trial to investigate the efficacy of an oral antioxidant micronutrient mixture to slow progression of age-related cataract. Ophthalmic Epidemiol. 9(1,0928-6586 (Print),0928-6586 (Linking)): 49–80. 2002.11815895
- Clark LC, Combs GF, Turnbull BW, Slate EH, . Effects of selenium supplementation for cancer prevention in patients with carcinoma of the skin. A randomized controlled trial. Nutritional Prevention of Cancer Study Group. JAMA. 276(24,0098-7484 (Print),0098-7484 (Linking)): 1957–1963. 1996.8971064
  - Clark, LC, Dalkin, B, . Decreased incidence of prostate cancer with selenium supplementation: results of a double-blind cancer prevention trial. Br J Urol. 81(5): 730–734. 1998. PMID: 9634050.9634050
  - Combs, GF, Jr, Clark, . Reduction of cancer mortality and incidence by selenium supplementation. Med Klin (Munich). 92 Suppl 3(): 42–45. 1997. PMID: 9342915.9342915
  - Duffield-Lillico, AJ, Dalkin, BL, . Selenium supplementation, baseline plasma selenium status and incidence of prostate cancer: an analysis of the complete treatment period of the Nutritional Prevention of Cancer Trial. BJU Int. 91(7): 608–612. 2003. PMID: 12699469.12699469
  - Duffield-Lillico, AJ, Reid, ME, . Baseline characteristics and the effect of selenium supplementation on cancer incidence in a randomized clinical trial: a summary report of the Nutritional Prevention of Cancer Trial. Cancer Epidemiol Biomarkers Prev. 11(7): 630–639. 2002. PMID: 12101110.12101110
  - Reid, ME, Duffield-Lillico, AJ, . Selenium supplementation and lung cancer incidence: an update of the nutritional prevention of cancer trial. Cancer Epidemiol Biomarkers Prev. 11(11): 1285–1291. 2002. PMID: 12433704.12433704
  - Reid, ME, Duffield-Lillico, AJ, . The nutritional prevention of cancer: 400 mcg per day selenium treatment. Nutr Cancer. 60(2): 155–163. 2008. PMID: 18444146.18444146
  - Stranges, S, Marshall, JR, . Effects of selenium supplementation on cardiovascular disease incidence and mortality: secondary analyses in a randomized clinical trial. Am J Epidemiol. 163(8): 694–699. 2006. PMID: 16495471.16495471
- Clinical Trial of Nutritional, Supplements, Age-Related Cataract Study, Group, . A randomized, double-masked, placebo-controlled clinical trial of multivitamin supplementation for age-related lens opacities. Clinical trial of nutritional supplements and age-related cataract report no. 3. Ophthalmology. 115(4): 599–607 e1. 2008. PMID: 18387406. 10.1016/j.ophtha.2008.01.005 18387406
- Coelho, C, Witt, SA, . Zinc to treat tinnitus in the elderly: a randomized placebo controlled crossover trial. Otology & Neurotology. 34(6): 1146–54. 2013. PMID: 23598691. 10.1097/MAO.0b013e31827e609e 23598691
- Cole BF, Baron JA, Sandler RS, Haile RW, . Folic acid for the prevention of colorectal adenomas: a randomized clinical trial. JAMA. 297(21): 2351–2359. 2007.17551129
  - Figueiredo, JC, Grau, MV, . Folic acid and risk of prostate cancer: results from a randomized clinical trial. J Natl Cancer Inst. 101(6): 432–435. 2009. PMID: 19276452.19276452
  - Passarelli, MN, Barry, EL, . Risk of basal cell carcinoma in a randomized clinical trial of aspirin and folic acid for the prevention of colorectal adenomas. Br J Dermatol. 179(2): 337–344. 2018. PMID: 29570772. 10.1111/bjd.16571 29570772
- Cooper, L, Clifton-Bligh, PB, . Vitamin D supplementation and bone mineral density in early postmenopausal women. Am J Clin Nutr. 77(5): 1324–9. 2003. PMID: 12716689. 10.1093/ajcn/77.5.1324 12716689
- Dawson-Hughes, B, Dallal, GE, . Effect of vitamin D supplementation on wintertime and overall bone loss in healthy postmenopausal women. Ann Intern Med. 115(7): 505–12. 1991. PMID: 1883119. 10.7326/0003-4819-115-7-505 1883119
- Dawson-Hughes, B, Harris, SS, . Effect of calcium and vitamin D supplementation on bone density in men and women 65 years of age or older. N Engl J Med. 337(10): 670–6. 1997. PMID: 9278463. 10.1056/NEJM199709043371003 9278463
- de Gaetano, G, Collaborative Group of the Primary Prevention, Project. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. 357(9250): 89–95. 2001. PMID: 11197445. 10.1016/s0140-6736(00)03539-x 11197445
- Dean AJ, Bellgrove MA, Hall T, Phan WM, . Effects of vitamin D supplementation on cognitive and emotional functioning in young adults--a randomised controlled trial. PLoS One. 6(11): e25966. 2011.22073146
- Dukas, L, Bischoff, HA, . Alfacalcidol reduces the number of fallers in a community-dwelling elderly population with a minimum calcium intake of more than 500 mg daily. J Am Geriatr Soc. 52(2): 230–6. 2004. PMID: 14728632. 10.1111/j.1532-5415.2004.52060.x 14728632
- Durga, J, van Boxtel, MP, . Effect of 3-year folic acid supplementation on cognitive function in older adults in the FACIT trial: a randomised, double blind, controlled trial. Lancet. 369(9557): 208–16. 2007. PMID: 17240287. 10.1016/S0140-6736(07)60109-3 17240287
- Fedirko, V, Bostick, RM, . Effects of vitamin D and calcium supplementation on markers of apoptosis in normal colon mucosa: a randomized, double-blind, placebo-controlled clinical trial. Cancer Prev Res (Phila). 2(3): 213–23. 2009. PMID: 19258546. 10.1158/1940-6207.CAPR-08-0157 19258546
  - Hopkins, MH, Owen, J, . Effects of supplemental vitamin D and calcium on biomarkers of inflammation in colorectal adenoma patients: a randomized, controlled clinical trial. Cancer Prev Res (Phila). 4(10): 1645–54. 2011. PMID: 21724580. 10.1158/1940-6207.CAPR-11-0105 21724580
- Ferraro, PM, Taylor, EN, . Vitamin D Intake and the Risk of Incident Kidney Stones. J Urol. 197(2): 405–410. 2017. PMID: 27545576. 10.1016/j.juro.2016.08.084 27545576
- Feskanich D, Singh V, Willett WC, Colditz GA. Vitamin A intake and hip fractures among postmenopausal women. JAMA. 287(1,0098-7484 (Print),0098-7484 (Linking)): 47–54. 2002.11754708
  - Chasan-Taber, L, Willett, WC, . A prospective study of vitamin supplement intake and cataract extraction among U.S. women. Epidemiology. 10(6): 679–84. 1999. PMID: 10535780.10535780
  - Curhan, GC, Willett, WC, . Comparison of dietary calcium with supplemental calcium and other nutrients as factors affecting the risk for kidney stones in women. Ann Intern Med. 126(7): 497–504. 1997. PMID: 9092314. 10.7326/0003-4819-126-7-199704010-00001 9092314
  - Meyer, HE, Willett, WC, . Association of High Intakes of Vitamins B6 and B12 From Food and Supplements With Risk of Hip Fracture Among Postmenopausal Women in the Nurses’ Health Study. JAMA Network Open. 2(5): e193591. 2019. PMID: 31074816. 10.1001/jamanetworkopen.2019.3591 31074816
- Gallagher, JC, Fowler, SE, . Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab. 86(8): 3618–28. 2001. PMID: 11502787. 10.1210/jcem.86.8.7703 11502787
- Glendenning, P, Zhu, K, . Effects of three-monthly oral 150,000 IU cholecalciferol supplementation on falls, mobility, and muscle strength in older postmenopausal women: a randomized controlled trial. J Bone Miner Res. 27(1): 170–6. 2012. PMID: 21956713. 10.1002/jbmr.524 21956713
- Grady, D, Halloran, B, . 1,25-Dihydroxyvitamin D3 and muscle strength in the elderly: a randomized controlled trial. J Clin Endocrinol Metab. 73(5): 1111–7. 1991. PMID: 1939527. 10.1210/jcem-73-5-1111 1939527
- Green A, Williams G, Neale R, Hart V, . Daily sunscreen application and betacarotene supplementation in prevention of basal-cell and squamous-cell carcinomas of the skin: a randomised controlled trial. Lancet. 354(9180,0140-6736 (Print),0140-6736 (Linking)): 723–729. 1999.10475183
  - Green, A, Battistutta, D, . The Nambour Skin Cancer and Actinic Eye Disease Prevention Trial: design and baseline characteristics of participants. Control Clin Trials. 15(6): 512–522. 1994. PMID: 7851112.7851112
- Greenberg ER, Baron JA, Stukel TA, Stevens MM, . A clinical trial of beta carotene to prevent basal-cell and squamous-cell cancers of the skin. The Skin Cancer Prevention Study Group. N Engl J Med. 323(12,0028-4793 (Print),0028-4793 (Linking)): 789–795. 1990.2202901
  - Greenberg, ER, Baron, JA, . Mortality associated with low plasma concentration of beta carotene and the effect of oral supplementation. JAMA. 275(9): 699–703. 1996. PMID: 8594267.8594267
  - Greenberg, ER, Baron, JA, . The Skin Cancer Prevention Study: design of a clinical trial of beta-carotene among persons at high risk for nonmelanoma skin cancer. Control Clin Trials. 10(2): 153–166. 1989. PMID: 2666024.2666024
- Hennekens CH, Buring JE, Manson JE, Stampfer M, . Lack of effect of long-term supplementation with beta carotene on the incidence of malignant neoplasms and cardiovascular disease. N Engl J Med. 334(18): 1145–1149. 1996.8602179
  - Cook, NR, Le, IM, . Effects of beta-carotene supplementation on cancer incidence by baseline characteristics in the Physicians’ Health Study (United States). Cancer Causes Control. 11(7): 617–626. 2000. PMID: 10977106.10977106
  - Liu, S, Ajani, U, . Long-term beta-carotene supplementation and risk of type 2 diabetes mellitus: a randomized controlled trial. JAMA. 282(11): 1073–1075. 1999. PMID: 10493207.10493207
  - The Steering Committee of the Physicians’ Health Study Research Group, . Preliminary Report: Findings from the aspirin component of the ongoing physicians’ health study. N Engl J Med. 318(4): 262–264. 1988. PMID: 3275899.3275899
- Hercberg S, Galan P, Preziosi P, Bertrais S, . The SU.VI.MAX Study: a randomized, placebo-controlled trial of the health effects of antioxidant vitamins and minerals. Arch Intern Med. 164(21): 2335–2342. 2004.15557412
  - Ezzedine, K, Latreille, J, . Incidence of skin cancers during 5-year follow-up after stopping antioxidant vitamins and mineral supplementation. Eur J Cancer. 46(18): 3316–3322. 2010. PMID: 20605091.20605091
  - Hercberg, S, Czernichow, S, . Antioxidant vitamins and minerals in prevention of cancers: lessons from the SU.VI.MAX study. Br J Nutr. 96(): Suppl-30. 2006. PMID: 16923246.16923246
  - Hercberg, S, Ezzedine, K, . Antioxidant supplementation increases the risk of skin cancers in women but not in men. J Nutr. 137(9): 2098–2105. 2007. PMID: 17709449.17709449
  - Hercberg, S, Galan, P, . Background and rationale behind the SU.VI.MAX Study, a prevention trial using nutritional doses of a combination of antioxidant vitamins and minerals to reduce cardiovascular diseases and cancers. SUpplementation en VItamines et Mineraux AntioXydants Study. Int J Vitam. Nutr Res. 68(1): 3–20. 1998. PMID: 9503043.9503043
  - Hercberg, S, Kesse-Guyot, E, . Incidence of cancers, ischemic cardiovascular diseases and mortality during 5-year follow-up after stopping antioxidant vitamins and minerals supplements: a postintervention follow-up in the SU.VI.MAX Study. Int J Cancer. 127(8): 1875–1881. 2010. PMID: 20104528.20104528
  - Hercberg, S, Preziosi, P, . A primary prevention trial using nutritional doses of antioxidant vitamins and minerals in cardiovascular diseases and cancers in a general population: the SU.VI.MAX study--design, methods, and participant characteristics. SUpplementation en VItamines et Mineraux AntioXydants. Control Clin Trials. 19(4): 336–351. 1998. PMID: 9683310.9683310
  - Meyer, F, Galan, P, . Antioxidant vitamin and mineral supplementation and prostate cancer prevention in the SU.VI.MAX trial. Int J Cancer. 116(2): 182–186. 2005. PMID: 15800922.15800922
  - Pouchieu, C, Deschasaux, M, . Prospective association between red and processed meat intakes and breast cancer risk: modulation by an antioxidant supplementation in the SU.VI.MAX randomized controlled trial. Int J Epidemiol. 43(5): 1583–1592. 2014. PMID: 24994839. 10.1093/ije/dyu134 24994839
- Hodis, HN, Mack, WJ, . Alpha-tocopherol supplementation in healthy individuals reduces low-density lipoprotein oxidation but not atherosclerosis: the Vitamin E Atherosclerosis Prevention Study (VEAPS). Circulation. 106(12): 1453–9. 2002. PMID: 12234947. 10.1161/01.cir.0000029092.99946.08 12234947
- Kenny, AM, Biskup, B, . Effects of vitamin D supplementation on strength, physical function, and health perception in older, community-dwelling men. J Am Geriatr Soc. 51(12): 1762–7. 2003. PMID: 14687355. 10.1046/j.1532-5415.2003.51561.x 14687355
- Komulainen, M, Kroger, H, . Prevention of femoral and lumbar bone loss with hormone replacement therapy and vitamin D3 in early postmenopausal women: a population-based 5-year randomized trial. J Clin Endocrinol Metab. 84(2): 546–52. 1999. PMID: 10022414. 10.1210/jcem.84.2.5496 10022414
- Lappe JM, Travers-Gustafson D, Davies KM, Recker RR, . Vitamin D and calcium supplementation reduces cancer risk: results of a randomized trial. Am J Clin Nutr. 85(6): 1586–1591. 2007.17556697
  - Lappe, JM, Davies, KM, . Vitamin D status in a rural postmenopausal female population. J Am Coll Nutr. 25(5): 395–402. 2006. PMID: 17031008.17031008
- Lappe, J, Watson, P, . Effect of Vitamin D and Calcium Supplementation on Cancer Incidence in Older Women: A Randomized Clinical Trial. JAMA. 317(12): 1234–1243. 2017. PMID: 28350929. 10.1001/jama.2017.2115 28350929
- Lee, IM, Cook, NR, . Vitamin E in the primary prevention of cardiovascular disease and cancer: the Women’s Health Study: a randomized controlled trial. JAMA. 294(1): 56–65. 2005. PMID: 15998891.15998891
  - Chae, CU, Albert, CM, . Vitamin E supplementation and the risk of heart failure in women. Circulation: Heart Failure. 5(2): 176–182. 2012. PMID: 22438520.22438520
  - Lee IM, Cook NR, Manson JE, Buring JE, . Beta-carotene supplementation and incidence of cancer and cardiovascular disease: the Women’s Health Study. J Natl Cancer Inst. 91(24): 2102–2106. 1999.10601381
- Lewis, JR, Calver, J, . Calcium supplementation and the risks of atherosclerotic vascular disease in older women: results of a 5-year RCT and a 4.5-year follow-up. J Bone Miner Res. 26(1): 35–41. 2011. PMID: 20614474. 10.1002/jbmr.176 20614474
  - Prince, RL, Devine, A, . Effects of calcium supplementation on clinical fracture and bone structure: results of a 5-year, double-blind, placebo-controlled trial in elderly women. Arch Intern Med. 166(8): 869–75. 2006. PMID: 16636212. 10.1001/archinte.166.8.869 16636212
- Lim LS, Harnack LJ, Lazovich D, Folsom AR. Vitamin A intake and the risk of hip fracture in postmenopausal women: the Iowa Women’s Health Study. Osteoporos Int. 15(7,0937-941X (Print),0937-941X (Linking)): 552–559. 2004.14760518
- Lippman SM, Klein EA, Goodman PJ, Lucia MS, . Effect of selenium and vitamin E on risk of prostate cancer and other cancers: the Selenium and Vitamin E Cancer Prevention Trial (SELECT). JAMA. 301(1): 39–51. 2009.19066370
  - Dunn, BK, Richmond, ES, . A nutrient approach to prostate cancer prevention: The Selenium and Vitamin E Cancer Prevention Trial (SELECT). Nutr Cancer. 62(7): 896–918. 2010. PMID: 20924966.20924966
  - Dunn, BK, Ryan, A, . Selenium and Vitamin E Cancer Prevention Trial: a nutrient approach to prostate cancer prevention. Recent Results Cancer Res. 181(): 183–193. 2009. PMID: 19213568.19213568
  - Klein, EA, Thompson, IM, . SELECT: the Selenium and Vitamin E Cancer Prevention Trial: rationale and design. Prostate Cancer Prostatic Dis. 3(3): 145–151. 2000. PMID: 12497090.12497090
  - Klein, EA, Thompson, IM, . Vitamin E and the risk of prostate cancer: the Selenium and Vitamin E Cancer Prevention Trial (SELECT). JAMA. 306(14): 1549–1556. 2011. PMID: 21990298.21990298
  - Kristal, AR, Darke, AK, . Baseline selenium status and effects of selenium and vitamin e supplementation on prostate cancer risk. J Natl Cancer Inst. 106(3): djt456. 2014. PMID: 24563519.24563519
  - Lippman, SM, Goodman, PJ, . Designing the Selenium and Vitamin E Cancer Prevention Trial (SELECT). J Natl Cancer Inst. 97(2): 94–102. 2005. PMID: 15657339.15657339
  - Lotan, Y, Goodman, P, . Evaluation of vitamin E and selenium supplementation on the prevention of bladder cancer in swog-coordinated select. J Urol. 187(6): 2005–2010. 2012. PMID: 22498220.22498220
  - Walsh, PC. Re: Vitamin e and the risk of prostate cancer: The Selenium and Vitamin e Cancer Prevention Trial (SELECT). J Urol. 187(5): 1640–1641. 2012. PMID: 22494720.22494720
  - Wyatt, G. Vitamin E increases prostate cancer risk in middle-aged men relative to placebo: no significant association observed with selenium, either alone or in combination with vitamin E. Evid Based Nurs. 15(3): 90–91. 2012. PMID: 22411161.22411161
- Lips, P, Graafmans, WC, . Vitamin D supplementation and fracture incidence in elderly persons. A randomized, placebo-controlled clinical trial. Ann Intern Med. 124(4): 400–6. 1996. PMID: 8554248. 10.7326/0003-4819-124-4-199602150-00003 8554248
  - Ooms, ME, Roos, JC, . Prevention of bone loss by vitamin D supplementation in elderly women: a randomized double-blind trial. J Clin Endocrinol Metab. 80(4): 1052–8. 1995. PMID: 7714065. 10.1210/jcem.80.4.7714065 7714065
- Logan, RF, Grainge, MJ, . Aspirin and folic acid for the prevention of recurrent colorectal adenomas. Gastroenterology. 134(1): 29–38. 2008. PMID: 18022173. 10.1053/j.gastro.2007.10.014 18022173
- Magliano, D, McNeil, J, . The Melbourne Atherosclerosis Vitamin E Trial (MAVET): a study of high dose vitamin E in smokers. Eur J Cardiovasc Prev Rehabil. 13(3): 341–7. 2006. PMID: 16926662. 10.1097/01.hjr.0000219108.10167.46 16926662
- Manson, JE, Cook, NR, . Vitamin D Supplements and Prevention of Cancer and Cardiovascular Disease. N Engl J Med. 2018. PMID: 30415629. 10.1056/NEJMoa1809944 30415629
  - Brenner, H, Kuznia, S, . Prevention of Advanced Cancer by Vitamin D3 Supplementation: Interaction by Body Mass Index Revisited. Nutrients. 13(5): 22. 2021. PMID: 33922032. 10.3390/nu13051408 33922032
  - Chandler, PD, Chen, WY, . Effect of Vitamin D3 Supplements on Development of Advanced Cancer: A Secondary Analysis of the VITAL Randomized Clinical Trial. JAMA Netw Open. 3(11): e2025850. 2020. 10.1001/jamanetworkopen.2020.25850 33206192
  - Djousse, L, Cook, NR, . Supplementation With Vitamin D and Omega-3 Fatty Acids and Incidence of Heart Failure Hospitalization: VITAL-Heart Failure. Circulation. 141(9): 784–786. 2020. PMID: 31709816. 10.1161/CIRCULATIONAHA.119.044645 31709816
  - Manson, Bassuk JE, Lee SS, Cook IM, . The VITamin D and OmegA-3 TriaL (VITAL): rationale and design of a large randomized controlled trial of vitamin D and marine omega-3 fatty acid supplements for the primary prevention of cancer and cardiovascular disease. Contemp Clin Trials. 33(1): 159–71. 2012.21986389
- McNeil, JJ, Robman, L, . Vitamin E supplementation and cataract: randomized controlled trial. Ophthalmology. 111(1): 75–84. 2004. PMID: 14711717. 10.1016/j.ophtha.2003.04.009 14711717
- Moon TE, Levine N, Cartmel B, Bangert JL, . Effect of retinol in preventing squamous cell skin cancer in moderate-risk subjects: a randomized, double-blind, controlled trial. Southwest Skin Cancer Prevention Study Group. Cancer Epidemiol Biomarkers Prev. 6(11,1055-9965 (Print),1055-9965 (Linking)): 949–956. 1997.9367069
  - Moon, TE, Levine, N, . Design and recruitment for retinoid skin cancer prevention (SKICAP) trials. The Southwest Skin Cancer Prevention Study Group. Cancer Epidemiol Biomarkers Prev. 4(6): 661–669. 1995. PMID: 8547834.8547834
- Murdoch, DR, Slow, S, . Effect of vitamin D3 supplementation on upper respiratory tract infections in healthy adults: the VIDARIS randomized controlled trial. JAMA. 308(13): 1333–9. 2012. PMID: 23032549. 10.1001/jama.2012.12505 23032549
- Neale, RE, Baxter, C, . The D-Health Trial: a randomised controlled trial of the effect of vitamin D on mortality. The Lancet Diabetes & Endocrinology. 10(2): 120–128. 2022. PMID: 35026158. 10.1016/S2213-8587(21)00345-4 35026158
- Omenn GS, Goodman GE, Thornquist MD, Balmes J, . Effects of a combination of beta carotene and vitamin A on lung cancer and cardiovascular disease. N Engl J Med. 334(18): 1150–1155. 1996.8602180
  - Goodman, GE, Omenn, GS, . The Carotene and Retinol Efficacy Trial (CARET) to prevent lung cancer in high-risk populations: pilot study with cigarette smokers. Cancer Epidemiol Biomarkers Prev. 2(4): 389–396. 1993. PMID: 8348063.8348063
  - Goodman, GE, Thornquist, MD, . The Beta-Carotene and Retinol Efficacy Trial: incidence of lung cancer and cardiovascular disease mortality during 6-year follow-up after stopping beta-carotene and retinol supplements. J Natl Cancer Inst. 96(23): 1743–1750. 2004. PMID: 15572756.15572756
  - Neuhouser, ML, Barnett, MJ, . Dietary supplement use and prostate cancer risk in the Carotene and Retinol Efficacy Trial. Cancer Epidemiol Biomarkers Prev. 18(8): 2202–2206. 2009. PMID: 19661078.19661078
  - Omenn, GS, Goodman, G, . The beta-carotene and retinol efficacy trial (CARET) for chemoprevention of lung cancer in high risk populations: smokers and asbestos-exposed workers. Cancer Res. 54(7 Suppl): 2038s–2043s. 1994. PMID: 8137335.8137335
  - Omenn, GS, Goodman, GE, . Risk factors for lung cancer and for intervention effects in CARET, the Beta-Carotene and Retinol Efficacy Trial. J Natl Cancer Inst. 88(21): 1550–1559. 1996. PMID: 8901853.8901853
  - Omenn, GS, Goodman, GE, . The Carotene and Retinol Efficacy Trial (CARET) to prevent lung cancer in high-risk populations: pilot study with asbestos-exposed workers. Cancer Epidemiol Biomarkers Prev. 2(4): 381–387. 1993. PMID: 8348062.8348062
- Pike, J, Chandra, RK. Effect of vitamin and trace element supplementation on immune indices in healthy elderly. Int J Vitam Nutr Res. 65(2): 117–21. 1995. PMID: 7591530.7591530
- Pittas, AG, Dawson-Hughes, B, . Vitamin D Supplementation and Prevention of Type 2 Diabetes. N Engl J Med. 2019. PMID: 31173679. 10.1056/NEJMoa1900906 31173679
  - Chatterjee, R, Fuss, P, . Vitamin D Supplementation for Prevention of Cancer: The D2d Cancer Outcomes (D2dCA) Ancillary Study. J Clin Endocrinol Metab. 106(9): 2767–2778. 2021. PMID: 33693713. 10.1210/clinem/dgab153 33693713
- Rautiainen, S, Lindblad, BE, . Vitamin C supplements and the risk of age-related cataract: a population-based prospective cohort study in women. Am J Clin Nutr. 91(2): 487–93. 2010. PMID: 19923367. 10.3945/ajcn.2009.28528 19923367
- Rayman MP, Blundell-Pound G, Pastor-Barriuso R, Guallar E, . A randomized trial of selenium supplementation and risk of type-2 diabetes, as assessed by plasma adiponectin. PLoS One. 7(9): e45269. 2012.23028897
- Rayman, MP, Winther, KH, . Effect of long-term selenium supplementation on mortality: Results from a multiple-dose, randomised controlled trial. Free Radic Biol Med. 127(): 46–54. 2018. PMID: 29454039. 10.1016/j.freeradbiomed.2018.02.015 29454039
  - Cold, F, Winther, KH, . Randomised controlled trial of the effect of long-term selenium supplementation on plasma cholesterol in an elderly Danish population. Br J Nutr. 114(11): 1807–18. 2015. PMID: 26420334. 10.1017/S0007114515003499 26420334
  - Winther, KH, Bonnema, SJ, . Does selenium supplementation affect thyroid function? Results from a randomized, controlled, double-blinded trial in a Danish population. Eur J Endocrinol. 172(6): 657–67. 2015. PMID: 25740851. 10.1530/EJE-15-0069 25740851
- Reid, IR, Ames, R, . Randomized controlled trial of calcium supplementation in healthy, nonosteoporotic, older men. Arch Intern Med. 168(20): 2276–82. 2008. PMID: 19001206. 10.1001/archinte.168.20.2276 19001206
- Rucklidge, JJ, Frampton, CM, . Vitamin-mineral treatment of attention-deficit hyperactivity disorder in adults: double-blind randomised placebo-controlled trial. Br J Psychiatry. 204(): 306–15. 2014. PMID: 24482441. 10.1192/bjp.bp.113.132126 24482441
- Salonen JT, Nyyssonen K, Salonen R, Lakka HM, . Antioxidant Supplementation in Atherosclerosis Prevention (ASAP) study: a randomized trial of the effect of vitamins E and C on 3-year progression of carotid atherosclerosis. J Intern Med. 248(5,0954-6820 (Print),0954-6820 (Linking)): 377–386. 2000.11123502
- Salovaara, K, Tuppurainen, M, . Effect of vitamin D(3) and calcium on fracture risk in 65- to 71-year-old women: a population-based 3-year randomized, controlled trial--the OSTPRE-FPS. J Bone Miner Res. 25(7): 1487–95. 2010. PMID: 20200964. 10.1002/jbmr.48 20200964
- Sanders, KM, Stuart, AL, . Annual high-dose oral vitamin D and falls and fractures in older women: a randomized controlled trial. JAMA. 303(18): 1815–22. 2010. PMID: 20460620. 10.1001/jama.2010.594 20460620
- Schutten, JC, Joris, PJ, . Long-term magnesium supplementation improves glucocorticoid metabolism: A post-hoc analysis of an intervention trial. Clin Endocrinol (Oxf). 94(2): 150–157. 2021. PMID: 33030273. 10.1111/cen.14350 33030273
- Scragg, R, Stewart, AW, . Effect of Monthly High-Dose Vitamin D Supplementation on Cardiovascular Disease in the Vitamin D Assessment Study : A Randomized Clinical Trial. JAMA Cardiol. 2(6): 608–616. 2017. PMID: 28384800. 10.1001/jamacardio.2017.0175 28384800
  - Malihi, Z, Lawes, CMM, . Monthly high-dose vitamin D supplementation does not increase kidney stone risk or serum calcium: results from a randomized controlled trial. Am J Clin Nutr. 109(6): 1578–1587. 2019. PMID: 31005969. 10.1093/ajcn/nqy378 31005969
  - Malihi, Z, Lawes, CMM, . Monthly high-dose vitamin D3 supplementation and self-reported adverse events in a 4-year randomized controlled trial. Clinical Nutrition. 38(4): 1581–1587. 2019. PMID: 30146166. 10.1016/j.clnu.2018.07.034 30146166
  - Scragg, R, Khaw, KT, . Monthly High-Dose Vitamin D Supplementation and Cancer Risk: A Post Hoc Analysis of the Vitamin D Assessment Randomized Clinical Trial. JAMA Oncology. 4(11): e182178. 2018. PMID: 30027269. 10.1001/jamaoncol.2018.2178 30027269
  - Scragg, RKR. Overview of results from the Vitamin D Assessment (ViDA) study. J Endocrinol Invest. 2019. PMID: 31124042. 10.1007/s40618-019-01056-z 31124042
- Sesso HD, Buring JE, Christen WG, Kurth T, . Vitamins E and C in the prevention of cardiovascular disease in men: the Physicians’ Health Study II randomized controlled trial. JAMA. 300(18): 2123–2133. 2008.18997197
  - Christen, William G, Glynn, Robert J, . Age-Related Cataract in a Randomized Trial of Vitamins E and C in Men. Arch Ophthalmol. 128(11): 1397–1405. 2010.21060040
  - Christen, WG, Gaziano, JM, . Design of Physicians’ Health Study II--a randomized trial of beta-carotene, vitamins E and C, and multivitamins, in prevention of cancer, cardiovascular disease, and eye disease, and review of results of completed trials. Ann Epidemiol. 10(2): 125–134. 2000. PMID: 10691066.10691066
  - Gaziano, J, Sesso, HD, . Multivitamins in the prevention of cancer in men: the Physician’s Health Study II randomized controlled trial. JAMA. 308(18): 1871–1880. 2012. PMID: 23162860.23162860
  - Gaziano, JM, Glynn, RJ, . Vitamins E and C in the prevention of prostate and total cancer in men: the Physicians’ Health Study II randomized controlled trial. JAMA. 301(1): 52–62. 2009. PMID: 19066368.19066368
  - Sesso, HD, Christen, WG, . Multivitamins in the prevention of cardiovascular disease in men: the Physicians’ Health Study II randomized controlled trial. JAMA. 308(17): 1751–1760. 2012. PMID: 23117775.23117775
  - Wang, L, Sesso, HD, . Vitamin E and C supplementation and risk of cancer in men: posttrial follow-up in the Physicians’ Health Study II randomized trial. Am J Clin Nutr. 100(3): 915–23. 2014. PMID: 25008853. 10.3945/ajcn.114.085480 25008853
- Sesso, Rist HD, Aragaki PM, Rautiainen AK, . Effect of cocoa flavanol supplementation for prevention of cardiovascular disease events: The COSMOS randomized clinical trial. Am J Clin Nutr. 2022. 10.1093/ajcn/nqac055
- Taylor, EN, Stampfer, MJ, . Dietary factors and the risk of incident kidney stones in men: new insights after 14 years of follow-up. J Am Soc Nephrol. 15(12): 3225–32. 2004. PMID: 15579526. 10.1097/01.ASN.0000146012.44570.20 15579526
- The Alpha-Tocopherol Beta Carotene Cancer Prevention Study Group. The effect of vitamin E and beta carotene on the incidence of lung cancer and other cancers in male smokers. The Alpha-Tocopherol, Beta Carotene Cancer Prevention Study Group. N Engl J Med. 330(15): 1029–1035. 1994.8127329
  - Albanes, D, Heinonen, OP, . Alpha-Tocopherol and beta-carotene supplements and lung cancer incidence in the alpha-tocopherol, beta-carotene cancer prevention study: effects of base-line characteristics and study compliance. J Natl Cancer Inst. 88(21): 1560–1570. 1996. PMID: 8901854.8901854
  - Albanes, D, Heinonen, OP, . Effects of alpha-tocopherol and beta-carotene supplements on cancer incidence in the Alpha-Tocopherol Beta-Carotene Cancer Prevention Study. Am J Clin Nutr. 62(6 Suppl): 1427S–1430S. 1995. PMID: 7495243.7495243
  - Albanes, D, Malila, N, . Effects of supplemental alpha-tocopherol and beta-carotene on colorectal cancer: results from a controlled trial (Finland). Cancer Causes Control. 11(3): 197–205. 2000. PMID: 10782653.10782653
  - Heinonen, OP, Albanes, D, . Prostate cancer and supplementation with alpha-tocopherol and beta-carotene: incidence and mortality in a controlled trial. J Natl Cancer Inst. 90(6): 440–446. 1998. PMID: 9521168.9521168
  - Heinonen, OP, Huttenen, JK, . The Alpha-Tocopherol, Beta-Carotene Lung Cancer Prevention Study: design, methods, participant characteristics, and compliance. Ann Epidemiol. 4(1): 1–10. 1994. PMID: 8205268.8205268
  - Hemila, H, Kaprio, J. Subgroup analysis of large trials can guide further research: A case study of vitamin E and pneumonia. Clin Epidemiol. 3(1): 51–59. 2011. PMID: 21386974.21386974
  - Hemila, H, Kaprio, J. Vitamin E supplementation and pneumonia risk in males who initiated smoking at an early age: effect modification by body weight and dietary vitamin C. Nutr J. 7(): 33. 2008. PMID: 19019244.19019244
  - Hemila, H, Virtamo, J, . Vitamin E and beta-carotene supplementation and hospital-treated pneumonia incidence in male smokers. Chest. 125(2): 557–565. 2004. PMID: 14769738.14769738
  - Hemila, H. Effect of beta-Carotene Supplementation on the Risk of Pneumonia Is Heterogeneous in Males: Effect Modification by Cigarette Smoking. J Nutr Sci Vitaminol (Tokyo). 64(5): 374–378. 2018. PMID: 30381628. 10.3177/jnsv.64.374 30381628
  - Kataja-Tuomola, M, Sundell, JR, . Effect of alpha-tocopherol and beta-carotene supplementation on the incidence of type 2 diabetes. Diabetologia. 51(1): 47–53. 2008. PMID: 17994292.17994292
  - Lai, GY, Weinstein, SJ, . Effects of alpha-tocopherol and beta-carotene supplementation on liver cancer incidence and chronic liver disease mortality in the ATBC study. Br J Cancer. 111(12): 2220–3. 2014. PMID: 25314069. 10.1038/bjc.2014.514 25314069
  - Malila, N, Taylor, PR, . Effects of alpha-tocopherol and beta-carotene supplementation on gastric cancer incidence in male smokers (ATBC Study, Finland). Cancer Causes Control. 13(7): 617–623. 2002. PMID: 12296509.12296509
  - Middha, P, Weinstein, SJ, . beta-Carotene Supplementation and Lung Cancer Incidence in the Alpha-Tocopherol, Beta-Carotene Cancer Prevention Study: The Role of Tar and Nicotine. Nicotine Tob Res. 21(8): 1045–1050. 2019. PMID: 29889248. 10.1093/ntr/nty115 29889248
  - Rautalahti, MT, Virtamo, JR, . The effects of supplementation with alpha-tocopherol and beta-carotene on the incidence and mortality of carcinoma of the pancreas in a randomized, controlled trial. Cancer. 86(1): 37–42. 1999. PMID: 10391561.10391561
  - Virtamo, J, Edwards, BK, . Effects of supplemental alpha-tocopherol and beta-carotene on urinary tract cancer: incidence and mortality in a controlled trial (Finland). Cancer Causes Control. 11(10): 933–939. 2000. PMID: 11142528.11142528
  - Virtamo, J, Pietinen, P, . Incidence of cancer and mortality following alpha-tocopherol and beta-carotene supplementation: a postintervention follow-up. JAMA. 290(4): 476–485. 2003. PMID: 12876090.12876090
  - Virtamo, J, Taylor, PR, . Effects of alpha-tocopherol and beta-carotene supplementation on cancer incidence and mortality: 18-year postintervention follow-up of the Alpha-tocopherol, Beta-carotene Cancer Prevention Study. Int J Cancer. 135(1): 178–85. 2014. PMID: 24338499. 10.1002/ijc.28641 24338499
  - Wright, ME, Virtamo, J, . Effects of alpha-tocopherol and beta-carotene supplementation on upper aerodigestive tract cancers in a large, randomized controlled trial. Cancer. 109(5): 891–898. 2007. PMID: 17265529.17265529
- Thompson, PA, Ashbeck, EL, . Selenium Supplementation for Prevention of Colorectal Adenomas and Risk of Associated Type 2 Diabetes. J Natl Cancer Inst. 108(12): 12. 2016. PMID: 27530657. 10.1093/jnci/djw152 27530657
- Toss, G, Magnusson, P. Is a daily supplementation with 40 microgram vitamin D3 sufficient? A randomised controlled trial. Eur J Nutr. 51(8): 939–45. 2012. PMID: 22086300. 10.1007/s00394-011-0271-7 22086300
- Trivedi DP, Doll R, Khaw KT. Effect of four monthly oral vitamin D3 (cholecalciferol) supplementation on fractures and mortality in men and women living in the community: randomised double blind controlled trial. BMJ. 326(7387,1468-5833 (Electronic),0959-535X (Linking)): 469. 2003.12609940
- Uusi-Rasi, K, Patil, R, . Exercise and vitamin D in fall prevention among older women: a randomized clinical trial. JAMA Intern Med. 175(5): 703–11. 2015. PMID: 25799402. 10.1001/jamainternmed.2015.0225 25799402
- van Wijngaarden, JP, Swart, KM, . Effect of daily vitamin B-12 and folic acid supplementation on fracture incidence in elderly individuals with an elevated plasma homocysteine concentration: B-PROOF, a randomized controlled trial. Am J Clin Nutr. 100(6): 1578–86. 2014. PMID: 25411293. 10.3945/ajcn.114.090043 25411293
  - Oliai Araghi, S, Kiefte-de Jong, JC, . Folic Acid and Vitamin B12 Supplementation and the Risk of Cancer: Long-term Follow-up of the B Vitamins for the Prevention of Osteoporotic Fractures (B-PROOF) Trial. Cancer Epidemiol Biomarkers Prevent. 28(2): 275–282. 2019. PMID: 30341095. 10.1158/1055-9965.EPI-17-1198 30341095
  - van Dijk, SC, Enneman, AW, . Effects of 2-year vitamin B12 and folic acid supplementation in hyperhomocysteinemic elderly on arterial stiffness and cardiovascular outcomes within the B-PROOF trial. J Hypertens. 33(9): 1897–906; discussion 1906. 2015. PMID: 26147383. 10.1097/HJH.0000000000000647 26147383
  - van Wijngaarden, JP, Dhonukshe-Rutten, RA, . Rationale and design of the B-PROOF study, a randomized controlled trial on the effect of supplemental intake of vitamin B12 and folic acid on fracture incidence. BMC Geriatr. 11(): 80. 2011. PMID: 22136481. 10.1186/1471-2318-11-80 22136481
- Virtanen, JK, Nurmi, T, . Vitamin D supplementation and prevention of cardiovascular disease and cancer in the Finnish Vitamin D Trial-a randomized controlled trial. Am J Clin Nutr. 04(): 04. 2022. PMID: 34982819. 10.1093/ajcn/nqab419 34982819
- Wactawski-Wende J, Kotchen JM, Anderson GL, Assaf AR, . Calcium plus vitamin D supplementation and the risk of colorectal cancer. N Engl J Med. 354(7,1533-4406 (Electronic),0028-4793 (Linking)): 684–696. 2006.16481636
  - Bolland, MJ, Grey, A, . Calcium and vitamin D supplements and health outcomes: a reanalysis of the Women’s Health Initiative (WHI) limited-access data set. Am J Clin Nutr. 94(4): 1144–1149. 2011. PMID: 21880848.21880848
  - Bolland, MJ, Grey, A, . Calcium supplements with or without vitamin D and risk of cardiovascular events: reanalysis of the Women’s Health Initiative limited access dataset and meta-analysis. BMJ. 342(): d2040. 2011. PMID: 21505219.21505219
  - Bolland, MJ, Grey, A, . Risk of cardiovascular events with calcium/vitamin D: a reanalysis of the Women’s Health Initiative. J Bone Miner Res. 25(): S50. 2010.
  - Brunner, RL, Wactawski-Wende, J, . The effect of calcium plus vitamin D on risk for invasive cancer: results of the Women’s Health Initiative (WHI) calcium plus vitamin D randomized clinical trial. Nutr Cancer. 63(6): 827–841. 2011. PMID: 21774589.21774589
  - Cauley, JA, Chlebowski, RT, . Calcium plus vitamin D supplementation and health outcomes five years after active intervention ended: the Women’s Health Initiative. Journal of Women’s Health. 22(11): 915–29. 2013. PMID: 24131320. 10.1089/jwh.2013.4270 24131320
  - Chlebowski, RT, Johnson, KC, . Calcium plus vitamin D supplementation and the risk of breast cancer. J Natl Cancer Inst. 100(22): 1581–1591. 2008. PMID: 19001601.19001601
  - de Boer, I, Tinker, LF, . Calcium plus vitamin D supplementation and the risk of incident diabetes in the Women’s Health Initiative. Diabetes Care. 31(4): 701–707. 2008. PMID: 18235052.18235052
  - Ding, EL, Mehta, S, . Interaction of estrogen therapy with calcium and vitamin D supplementation on colorectal cancer risk: reanalysis of Women’s Health Initiative randomized trial. Int J Cancer. 122(8): 1690–1694. 2008. PMID: 18092326.18092326
  - Donneyong, MM, Hornung, CA, . Risk of heart failure among postmenopausal women: a secondary analysis of the randomized trial of vitamin D plus calcium of the women’s health initiative. Circulation: Heart Failure. 8(1): 49–56. 2015. PMID: 25398967. 10.1161/CIRCHEARTFAILURE.114.001738 25398967
  - Fu, T, Tang, JY, . Calcium plus vitamin D supplementation and the risk of nonmelanoma and melanoma skin cancer. J Invest Dermatol. 131(Suppl 1): S35. 2011.
  - Hays, J, Hunt, JR, . The Women’s Health Initiative recruitment methods and results. Ann Epidemiol. 13(9 Suppl): S18–S77. 2003. PMID: 14575939.14575939
  - Hsia, J, Heiss, G, . Calcium/vitamin D supplementation and cardiovascular events. Circulation. 115(7): 846–854. 2007. PMID: 17309935.17309935
  - Jackson, RD, LaCroix, AZ, . Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med. 354(7): 669–683. 2006. PMID: 16481635.16481635
  - LaCroix, AZ, Kotchen, J, . Calcium plus vitamin D supplementation and mortality in postmenopausal women: the Women’s Health Initiative calcium-vitamin D randomized controlled trial. J Gerontol A Biol Sci Med Sci. 64(5): 559–567. 2009. PMID: 19221190.19221190
  - Prentice, RL, Pettinger, MB, . Health risks and benefits from calcium and vitamin D supplementation: Women’s Health Initiative clinical trial and cohort study. Osteoporos Int. 2012. PMID: 23208074.23208074
  - Radford, LT, Bolland, MJ, . Subgroup analysis for the risk of cardiovascular disease with calcium supplements. Bonekey Rep. 2(): 293. 2013. PMID: 23951541. 10.1038/bonekey.2013.27 23951541
  - Tang, JY, Fu, T, . Calcium plus vitamin D supplementation and the risk of nonmelanoma and melanoma skin cancer: post hoc analyses of the women’s health initiative randomized controlled trial. J Clin Oncol. 29(22): 3078–3084. 2011. PMID: 21709199.21709199
  - Tao, MH, Dai, Q, . Calcium plus vitamin D supplementation and lung cancer incidence among postmenopausal women in the Women’s Health Initiative. Lung Cancer. 110(): 42–47. 2017. PMID: 28676217. 10.1016/j.lungcan.2017.06.002 28676217
  - The Women’s Health Initiative Study Group. Design of the Women’s Health Initiative clinical trial and observational study. The Women’s Health Initiative Study Group. Control Clin Trials. 19(1): 61–109. 1998.9492970
- Witham, MD, Ireland, S, . Vitamin D therapy to reduce blood pressure and left ventricular hypertrophy in resistant hypertension: randomized, controlled trial. Hypertension. 63(4): 706–12. 2014. PMID: 24420547. 10.1161/HYPERTENSIONAHA.113.02177 24420547
- Wood, ME, Liu, H, . The Influence of Vitamin D on Mammographic Density: Results from CALGB 70806 (Alliance) a Randomized Clinical Trial. Cancer Prevention Research. 14(7): 753–762. 2021. PMID: 33849913. 10.1158/1940-6207.CAPR-20-0581 33849913
- Wood, AD, Secombes, KR, . Vitamin D3 supplementation has no effect on conventional cardiovascular risk factors: a parallel-group, double-blind, placebo-controlled RCT. J Clin Endocrinol Metab. 97(10): 3557–68. 2012. PMID: 22865902. 10.1210/jc.2012-2126 22865902
- Wu, K, Platz, EA, . A randomized trial on folic acid supplementation and risk of recurrent colorectal adenoma. Am J Clin Nutr. 90(6): 1623–31. 2009. PMID: 19864409. 10.3945/ajcn.2009.28319 19864409
- Zheng, SelinJ, Rautiainen, S, . High-Dose Supplements of Vitamins C and E, Low-Dose Multivitamins, and the Risk of Age-related Cataract: A Population-based Prospective Cohort Study of Men. Am J Epidemiol. 177(6): 548–55. 2013. PMID: 23420353.23420353
  - Thomas, LD, Elinder, CG, . Ascorbic Acid Supplements and Kidney Stone Incidence Among Men: A Prospective Study. JAMA Intern Med. 173(5): 386–8. 2013. PMID: 23381591.23381591
- Zittermann, A, Frisch, S, . Vitamin D supplementation enhances the beneficial effects of weight loss on cardiovascular disease risk markers. Am J Clin Nutr. 89(5): 1321–7. 2009. PMID: 19321573. 10.3945/ajcn.2008.27004 19321573