# Appendix A Literature Search Strategies for Primary Literature

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- pt = publication type
- * = truncation
- kw = keyword
- tu = Therapeutic Use
- py = publication year
- lim = limit
- mj = major
- ajd = adjacent
- PDAT = publication date

## MEDLINE

Database: Ovid MEDLINE(R) and Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Daily and Versions(R) <1946 to August 29, 2019>

Search Strategy:

------------------------------------------------------------

1. Calcium, dietary/ or Calcium Carbonate/
2. Calcium Compounds/tu [Therapeutic Use]
3. calcium citrate/tu
4. (dietary calcium or calcium supplement$ or calcium monotherapy).ti,ab.
5. folic acid/
6. (folic acid or folate).ti,ab.
7. (methyltetrahydrofolic or methyltetrahydrofolate or methyl tetrahydrofolic or methyl tetrahydrofolate or mthf).ti,ab.
8. (Vitamin B 9 or Vitamin B9).ti,ab.
9. exp Thiamine/
10. (Thiamine or Thiamin or Vitamin B 1 or Vitamin B1 or Aneurin).ti,ab.
11. Riboflavin/
12. (Riboflavin or Vitamin B 2 or Vitamin B2).ti,ab.
13. exp Vitamin B 6/
14. (Vitamin B 6 or Vitamin B6 or Pyridoxin$).ti,ab.
15. exp Vitamin B 12/
16. (Vitamin B 12 or Vitamin B12).ti,ab.
17. (Cobalamin or Cyanocobalamin or Cobamides or Hydroxocobalamin).ti,ab.
18. Vitamin D/
19. Vitamin D.ti,ab.
20. Cholecalciferol/
21. Cholecalciferol.ti,ab.
22. Dihydroxycholecalciferols/
23. Dihydroxycholecalciferol$.ti,ab.
24. Calcitriol/
25. Calcitriol.ti,ab.
26. Ergocalciferols/
27. Ergocalciferol$.ti,ab.
28. exp Vitamin E/
29. (Vitamin E or Tocopherol$ or Tocotrienol$).ti,ab.
30. exp Ascorbic acid/
31. (Ascorbic acid or Vitamin C or ascorbate or Dehydroascorbate).ti,ab.
32. Vitamin A/
33. Vitamin A.ti,ab.
34. beta carotene/
35. (beta carotene or Betacarotene).ti,ab.
36. Retinol.ti,ab.
37. retinoids/
38. iron, dietary/
39. (iron adj5 dietary).ti,ab.
40. (iron adj5 supplement$).ti,ab.
41. zinc/
42. (zinc adj5 dietary).ti,ab.
43. (zinc adj5 supplement$).ti,ab.
44. Magnesium/ or Magnesium Compounds/
45. (magnesium adj5 dietary).ti,ab.
46. (magnesium adj5 supplement$).ti,ab.
47. Niacin/
48. Niacin.ti,ab.
49. Nicotinic acids/
50. nicotinic acid$.ti,ab.
51. Selenium/
52. Selenium compounds/
53. Selenium.ti,ab.
54. Vitamins/
55. Minerals/
56. (Vitamin$ adj5 dietary).ti,ab.
57. (Vitamin$ adj5 supplement$).ti,ab.
58. (mineral$ adj5 dietary).ti,ab.
59. (mineral$ adj5 supplement$).ti,ab.
60. (Multivitamin$ or Multi-vitamin$).ti,ab.
61. (multimineral$ or multi-mineral$).ti,ab.
62. or/1-61
63. exp Cardiovascular Diseases/
64. (cardi$ disease$ or heart disease$).ti,ab.
65. cardiomyopath$.ti,ab.
66. myocardial infarction.ti,ab.
67. (heart arrest or heart attack$).ti,ab.
68. (coronary arter$ disease or coronary heart disease).ti,ab.
69. isch?emi$.ti,ab.
70. arrhythmia$.ti,ab.
71. ((heart or myocardial or cardiac or systolic or diastolic or ventricular) adj1 (failure$ or dysfunction)).ti,ab.
72. angina.ti,ab.
73. vascular disease$.ti,ab.
74. (cerebrovascular disease$ or cerebrovascular disorder$).ti,ab.
75. aneurysm.ti,ab.
76. arterial occlusive disease.ti,ab.
77. stroke.ti,ab.
78. cerebrovascular accident$.ti,ab.
79. (diabetic angiopath$ or diabetic foot or diabetic retinopathy$).ti,ab.
80. (hypertensi$ or high blood pressure).ti,ab.
81. prehypertensi$.ti,ab.
82. hypotension/
83. (hypotens$ or low blood pressure).ti,ab.
84. carotid artery disease$.ti,ab.
85. ((thromb$ or embolic or emboli or embolism$ or embolus) adj1 (vein or veins or venous or venules or pulmonary or lung)).ti,ab.
86. peripheral arter$ disease$.ti,ab.
87. atherosclero$.ti,ab.
88. exp Hyperlipidemias/
89. hyperlipid?emia$.ti,ab.
90. (hypercholesterol$ or high cholesterol or elevated cholesterol).ti,ab.
91. exp Neoplasms/
92. (neoplas$ or cancer$ or tumor or tumors or tumour or tumours or malignan$ or carcinoma$ or adenocarcinoma$ or blastoma$ or squamous or metastatic or meta-static or sarcoma$ or myeloma$ or adenoma$ or glioblastoma$ or lymphoma$ or schwannoma$ or Leukemia$ or Leukaemia$ or Hepatoma$ or Metastas$ or oncology or glioma$ or carcinogen$ or cholangiocarcinoma$ or Neurofibroma$ or Osteosarcoma$ or Teratoma$ or melanoma$).ti,ab.
93. or/63-92
94. safety/
95. safety.ti,ab.
96. adverse$.ti,ab.
97. adverse effects.fs.
98. side effect$.ti,ab.
99. product surveillance, postmarketing/
100. Long Term Adverse Effects/
101. Adverse Drug Reaction Reporting Systems/
102. drug toxicity/
103. drug toxicity.ti,ab.
104. harm$.ti,ab.
105. exp Sarcoidosis/
106. (sarcoid$ or neurosarcoidosis or besnier or schaumann syndrome).ti,ab.
107. exp Urolithiasis/ or exp Cholelithiasis/
108. (stone or stones).ti,ab.
109. (lithiasis or nephrolithiasis or cholelithiasis or urolithiasis or choledocholithiasis or hepatolithiasis or calculus or calculi).ti,ab.
110. exp Hemorrhage/
111. (bleeding or h?emorrhage).ti,ab.
112. or/94-111
113. (randomized controlled trial or controlled clinical trial).pt. or clinical trials as topic.sh. or (randomized or randomised or placebo or randomly).ti,ab. or trial.ti.
114. (RCT or placebo or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or random$).ti,ab. not medline.st.
115. 113 or 114
116. 62 and 93 and 115
117. case-control studies/ or retrospective studies/ or cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or Cross-Sectional Studies/
118. (case control$ or cohort or longitudinal or follow up or followup or prospective$ or retrospective$ or comparison group$ or control group$ or observational or nonrandom$ or database$ or population$ or cross sectional).ti,ab.
119. 117 or 118
120. 115 or 119
121. 62 and 112 and 120
122. 116 or 121
123. limit 122 to (english language and yr="2013 -Current")
124. 123 not (animals/ not humans/)
125. 124 not ((infant/ or child/ or adolescence/) not (adult/ or aged/ or middle aged/))
126. meta analysis.pt. or (metaanaly$ or meta analy$).ti,ab.
127. (62 and 93) or (62 and 112)
128. 126 and 127
129. limit 127 to systematic reviews
130. 128 or 129
131. limit 130 to (english language and yr="2013 -Current")
132. 125 or 131

## PUBMED- [publisher supplied references only]

### RCTs

(dietary calcium[tiab] OR calcium supplement*[tiab] OR calcium monotherapy[tiab] OR folic acid[tiab] OR folate[tiab] OR methyltetrahydrofolic[tiab] OR methyltetrahydrofolate[tiab] OR methyl tetrahydrofolic[tiab] OR methyl tetrahydrofolate[tiab] OR mthf[tiab] OR Vitamin B 9[tiab] OR Vitamin B9[tiab] OR Thiamine[tiab] OR Thiamin[tiab] OR Vitamin B 1[tiab] OR Vitamin B1[tiab] OR Aneurin[tiab] OR Riboflavin[tiab] OR Vitamin B 2[tiab] OR Vitamin B2[tiab] OR Vitamin B 6[tiab] OR Vitamin B6[tiab] OR Pyridoxin*[tiab] OR Vitamin B 12[tiab] OR Vitamin B12[tiab] OR Cobalamin[tiab] OR Cyanocobalamin[tiab] OR Cobamides[tiab] OR Hydroxocobalamin[tiab] OR Vitamin D[tiab] OR Cholecalciferol[tiab] OR Dihydroxycholecalciferol*[tiab] OR Calcitriol[tiab] OR Ergocalciferol*[tiab] OR Vitamin E[tiab] OR Tocopherol*[tiab] OR Tocotrienol*[tiab] OR Ascorbic acid[tiab] OR Vitamin C[tiab] OR ascorbate[tiab] OR Dehydroascorbate[tiab] OR Vitamin A[tiab] OR beta carotene[tiab] OR Betacarotene[tiab] OR Retinol[tiab] OR Niacin[tiab] OR nicotinic acid*[tiab] OR Selenium[tiab] OR Multivitamin*[tiab] OR Multi-vitamin*[tiab] OR multimineral*[tiab] OR multi-mineral*[tiab] OR ((Iron[tiab] OR zinc[tiab] OR magnesium[tiab] OR Vitamin*[tiab] OR mineral*[tiab]) AND (dietary[tiab] OR supplement*[tiab])))

AND publisher[sb]

AND (RCT[tiab] OR placebo[tiab] OR sham[tiab] OR dummy[tiab] OR single blind*[tiab] OR double blind*[tiab] OR allocated[tiab] OR allocation[tiab] OR triple blind*[tiab] OR treble blind*[tiab] OR random*[tiab])

AND (cardiovascular disease*[tiab] OR heart disease*[tiab] OR cardiomyopath*[tiab] OR myocardial infarction[tiab] OR heart arrest[tiab] OR heart attack*[tiab] OR coronary artery disease[tiab] OR coronary heart disease[tiab] OR ischemi*[tiab] OR ischaemi*[tiab] OR arrhythmia*[tiab] OR ((heart[tiab] OR myocardial[tiab] OR cardiac[tiab] OR systolic[tiab] OR diastolic[tiab] OR ventricular[tiab]) AND (failure*[tiab] OR dysfunction[tiab])) OR angina[tiab] OR vascular disease*[tiab] OR cerebrovascular disease*[tiab] OR cerebrovascular disorder*[tiab] OR aneurysm[tiab] OR arterial occlusive disease[tiab] OR stroke[tiab] OR cerebrovascular accident*[tiab] OR diabetic angiopath*[tiab] OR diabetic foot[tiab] OR diabetic retinopathy*[tiab] OR hypertensi*[tiab] OR high blood pressure[tiab] OR prehypertensi*[tiab] OR hypotens*[tiab] OR low blood pressure[tiab] OR carotid artery disease*[tiab] OR ((thromb*[tiab] OR embolic[tiab] OR emboli[tiab] OR embolism*[tiab] OR embolus[tiab]) AND (vein[tiab] OR veins[tiab] OR venous[tiab] OR venules[tiab] OR pulmonary[tiab] OR lung[tiab])) OR peripheral artery disease*[tiab] OR atherosclero*[tiab] OR hyperlipidemia*[tiab] OR hyperlipidaemia*[tiab] OR hypercholesterol*[tiab] OR high cholesterol[tiab] OR elevated cholesterol[tiab] OR neoplas*[tiab] OR cancer*[tiab] OR tumor[tiab] OR tumors[tiab] OR tumour[tiab] OR tumours[tiab] OR malignan*[tiab] OR carcinoma*[tiab] OR adenocarcinoma*[tiab] OR blastoma*[tiab] OR squamous[tiab] OR metastatic[tiab] OR meta-static[tiab] OR sarcoma*[tiab] OR myeloma*[tiab] OR adenoma*[tiab] OR glioblastoma*[tiab] OR lymphoma*[tiab] OR schwannoma*[tiab] OR Leukemia*[tiab] OR Leukaemia*[tiab] OR Hepatoma*[tiab] OR Metastas*[tiab] OR oncology[tiab] OR glioma*[tiab] OR carcinogen*[tiab] OR cholangiocarcinoma*[tiab] OR Neurofibroma*[tiab] OR Osteosarcoma*[tiab] OR Teratoma*[tiab] OR melanoma*[tiab])

AND (“2013/01/01”[PDAT] : “3000/12/31”[PDAT])

AND English

### Harms

(dietary calcium[tiab] OR calcium supplement*[tiab] OR calcium monotherapy[tiab] OR folic acid[tiab] OR folate[tiab] OR methyltetrahydrofolic[tiab] OR methyltetrahydrofolate[tiab] OR methyl tetrahydrofolic[tiab] OR methyl tetrahydrofolate[tiab] OR mthf[tiab] OR Vitamin B 9[tiab] OR Vitamin B9[tiab] OR Thiamine[tiab] OR Thiamin[tiab] OR Vitamin B 1[tiab] OR Vitamin B1[tiab] OR Aneurin[tiab] OR Riboflavin[tiab] OR Vitamin B 2[tiab] OR Vitamin B2[tiab] OR Vitamin B 6[tiab] OR Vitamin B6[tiab] OR Pyridoxin*[tiab] OR Vitamin B 12[tiab] OR Vitamin B12[tiab] OR Cobalamin[tiab] OR Cyanocobalamin[tiab] OR Cobamides[tiab] OR Hydroxocobalamin[tiab] OR Vitamin D[tiab] OR Cholecalciferol[tiab] OR Dihydroxycholecalciferol*[tiab] OR Calcitriol[tiab] OR Ergocalciferol*[tiab] OR Vitamin E[tiab] OR Tocopherol*[tiab] OR Tocotrienol*[tiab] OR Ascorbic acid[tiab] OR Vitamin C[tiab] OR ascorbate[tiab] OR Dehydroascorbate[tiab] OR Vitamin A[tiab] OR beta carotene[tiab] OR Betacarotene[tiab] OR Retinol[tiab] OR Niacin[tiab] OR nicotinic acid*[tiab] OR Selenium[tiab] OR Multivitamin*[tiab] OR Multi-vitamin*[tiab] OR multimineral*[tiab] OR multi-mineral*[tiab] OR ((Iron[tiab] OR zinc[tiab] OR magnesium[tiab] OR Vitamin*[tiab] OR mineral*[tiab]) AND (dietary[tiab] OR supplement*[tiab])))

AND publisher[sb]

AND ((RCT[tiab] OR placebo[tiab] OR sham[tiab] OR dummy[tiab] OR single blind*[tiab] OR double blind*[tiab] OR allocated[tiab] OR allocation[tiab] OR triple blind*[tiab] OR treble blind*[tiab] OR random*[tiab]) OR (case control*[tiab] OR cohort[tiab] OR longitudinal[tiab] OR follow up[tiab] OR followup[tiab] OR prospective*[tiab] OR retrospective*[tiab] OR comparison group*[tiab] OR control group*[tiab] OR observational[tiab] OR nonrandom*[tiab] OR database*[tiab] OR population*[tiab] OR cross sectional[tiab]))

AND (safety[tiab] OR adverse*[tiab] OR side effect*[tiab] OR drug toxicity[tiab] OR harm*[tiab] OR sarcoid*[tiab] OR neurosarcoidosis[tiab] OR besnier[tiab] OR schaumann syndrome[tiab] OR stone[tiab] OR stones[tiab] OR lithiasis[tiab] OR nephrolithiasis[tiab] OR cholelithiasis[tiab] OR urolithiasis[tiab] OR choledocholithiasis[tiab] OR hepatolithiasis[tiab] OR calculus[tiab] OR calculi[tiab] OR bleeding[tiab] OR hemorrhage[tiab] OR haemorrhage[tiab])

AND (“2013/01/01”[PDAT] : “3000/12/31”[PDAT])

AND English

#### Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL) and Systematic Reviews

#1 “cardiovascular disease”.ti,ab,kw
#2 “cardiovascular diseases”:ti,ab,kw
#3 “heart disease”:ti,ab,kw
#4 “heart diseases”:ti,ab,kw
#5 Arrhythmia*:ti,ab,kw
#6 Cardiomyopath*:ti,ab,kw
#7 “Heart Arrest”:ti,ab,kw
#8 ((heart or myocardial or cardiac or systolic or diastolic or ventricular) NEAR/1 (failure* or dysfunction)):ti,ab,kw
#9 Isch*emi*:ti,ab,kw
#10 “myocardial infarction”:ti,ab,kw
#11 (“coronary artery disease” or “coronary heart disease”):ti,ab,kw
#12 “heart attack”:ti,ab,kw
#13 “heart attacks”:ti,ab,kw
#14 “Vascular Diseases”:ti,ab,kw
#15 “Vascular Disease”:ti,ab,kw
#16 Aneurysm*:ti,ab,kw
#17 “Arterial Occlusive”:ti,ab,kw
#18 Cerebrovascular:ti,ab,kw
#19 “Carotid Artery”:ti,ab,kw
#20 stroke:ti,ab,kw
#21 “Diabetic Angiopathies”:ti,ab,kw
#22 “Diabetic Angiopathy”:ti,ab,kw
#23 “diabetic foot”:ti,ab,kw
#24 “diabetic retinopathy”:ti,ab,kw
#25 Hypertensi*:ti,ab,kw
#26 “high blood pressure”:ti,ab,kw
#27 hypotensi*:ti,ab,kw
#28 “low blood pressure”:ti,ab,kw
#29 “Peripheral Vascular”:ti,ab,kw
#30 “Peripheral Arterial”:ti,ab,kw
#31 “Peripheral artery”:ti,ab,kw
#32 Prehypertension:ti,ab,kw
#33 ((thromb* or embolic or emboli or embolism* or embolus) NEAR/1 (vein or veins or venous or venules or pulmonary or lung)):ti,ab,kw
#34 Hyperlipid*emia*:ti,ab,kw
#35 Hypercholesterolemi*:ti,ab,kw
#36 “High cholesterol”:ti,ab,kw
#37 “elevated cholesterol”:ti,ab,kw
#38 atherosclero*:ti,ab,kw
#39 (neoplas* or cancer* or tumor or tumors or tumour or tumours or malignan* or carcinoma* or adenocarcinoma* or blastoma* or squamous or metastatic or meta-static or sarcoma* or myeloma* or adenoma* or glioblastoma* or lymphoma* or schwannoma* or Leukemia* or Leukaemia* or Hepatoma* or Metastas* or oncology or glioma* or carcinogen* or cholangiocarcinoma* or Neurofibroma* or Osteosarcoma* or Teratoma* or melanoma*):ti,ab,kw
#40 “Intestinal Polyps”:ti,ab,kw
#41 “colorectal polyps”:ti,ab,kw
#42 “Colon polyps”:ti,ab,kw
#43 “Colonic polyps”:ti,ab,kw
#44 {OR #1-#43}
#45 (Calcium near/2 dietary):ti,ab,kw
#46 (calcium next supplement*):ti,ab,kw
#47 calcium monotherapy:ti,ab,kw
#48 “folic acid”:ti,ab,kw
#49 folate:ti,ab,kw
#50 (methyltetrahydrofolic or methyltetrahydrofolate or methyl tetrahydrofolic or methyl tetrahydrofolate or mthf):ti,ab,kw
#51 Thiamine:ti,ab,kw
#52 thiamin:ti,ab,kw
#53 “Vitamin B 1”:ti,ab,kw
#54 “vitamin b1”:ti,ab,kw
#55 Aneurin:ti,ab,kw
#56 Riboflavin:ti,ab,kw
#57 “Vitamin B 2”:ti,ab,kw
#58 “Vitamin B2”:ti,ab,kw
#59 “Vitamin B 6”:ti,ab,kw
#60 “Vitamin B6”:ti,ab,kw
#61 Pyridoxin*:ti,ab,kw
#62 “Vitamin B 12”:ti,ab,kw
#63 “Vitamin B12”:ti,ab,kw
#64 Cobamides:ti,ab,kw
#65 Hydroxocobalamin:ti,ab,kw
#66 Cobalamin:ti,ab,kw
#67 Cyanocobalamin:ti,ab,kw
#68 “Vitamin D”:ti,ab,kw
#69 Cholecalciferol:ti,ab,kw
#70 Dihydroxycholecalciferol*:ti,ab,kw
#71 Calcitriol:ti,ab,kw
#72 Ergocalciferol*:ti,ab,kw
#73 “Vitamin E”:ti,ab,kw
#74 Tocopherol*:ti,ab,kw
#75 Tocotrienol*:ti,ab,kw
#76 “Ascorbic acid”:ti,ab,kw
#77 “Vitamin C”:ti,ab,kw
#78 ascorbate:ti,ab,kw
#79 “Vitamin A”:ti,ab,kw
#80 (“beta carotene" or betacarotene):ti,ab,kw
#81 Retinol:ti,ab,kw
#82 (iron near/2 dietary):ti,ab,kw
#83 (iron next supplement*):ti,ab,kw
#84 zinc:ti,ab,kw
#85 Magnesium:ti,ab,kw
#86 Niacin:ti,ab,kw
#87 (Nicotinic near/2 acid*):ti,ab,kw
#88 Selenium:ti,ab,kw
#89 ((vitamin* or mineral*) near/2 dietary):ti,ab,kw
#90 ((vitamin* or mineral*) near/2 supplement*):ti,ab,kw
#91 (Multivitamin* or multi-vitamin* or “multi vitamin” or “multi vitamins”):ti,ab,kw
#92 (Multimineral* or multi-mineral* or “multi mineral” or “multi minerals”):ti,ab,kw
#93 {OR #45-#92}
#94 #44 and #93 with Publication Year from 2013 to 2019, in Trials
#95 #44 and #93 with Cochrane Library publication date Between Jan 2013 and Aug 2019, in Cochrane Reviews

#### Embase (via embase.com)

#1 ‘calcium’/mj
#2 ‘calcium intake’/mj
#3 ‘dietary calcium’:ti,ab OR ‘calcium supplement*’:ti,ab OR ‘calcium monotherapy’:ti,ab
#4 ‘folic acid supplements’:ti
#5 ‘folic acid’/mj
#6 ‘folic acid’:ti,ab OR ‘folate’:ti,ab
#7 methyltetrahydrofolic:ti,ab OR methyltetrahydrofolate:ti,ab OR ‘methyl tetrahydrofol*’:ti,ab OR mthf:ti,ab
#8 ‘vitamin b9’/exp
#9 ‘vitamin b 9’:ti,ab OR ‘vitamin b9’:ti,ab
#10 ‘thiamine’/exp/mj
#11 ‘thiamin’:ti,ab OR ‘vitamin b 1’:ti,ab OR ‘vitamin b1’:ti,ab OR ‘aneurin’:ti,ab
#12 ‘riboflavin’/exp/mj
#13 ‘riboflavin’:ti,ab OR ‘vitamin b 2’:ti,ab OR ‘vitamin b2’:ti,ab
#14 ‘pyridoxine’/mj
#15 ‘vitamin b 6’:ti,ab OR ‘vitamin b6’:ti,ab OR pyridoxin*.ti,ab
#16 ‘cyanocobalamin’/mj
#17 ‘vitamin b 12’:ti,ab OR ‘vitamin b12’:ti,ab OR ‘cobalamin’:ti,ab OR ‘cyanocobalamin’:ti,ab OR ‘cobamides’:ti,ab OR ‘hydroxocobalamin’:ti,ab
#18 ‘vitamin d’/exp/mj
#19 ‘vitamin d’:ti,ab OR cholecalciferol:ti,ab OR dihydroxycholecalciferol*:ti,ab OR calcitriol:ti,ab OR ergocalciferol*:ti,ab
#20 ‘alpha tocopherol’/mj
#21 ‘vitamin e’:ti,ab OR tocopherol*:ti,ab OR tocotrienol*:ti,ab
#22 ‘ascorbic acid’/exp/mj
#23 ‘ascorbic acid’:ti,ab OR ‘vitamin c’:ti,ab OR ascorbate:ti,ab OR dehydroascorbate:ti,ab
#24 ‘retinol’/mj
#25 ‘beta carotene’/mj
#26 ‘vitamin a’:ti,ab OR ‘beta carotene’:ti,ab OR betacarotene:ti,ab OR retinol:ti,ab
#27 ‘iron’/mj
#28 ((iron NEAR/5 dietary):ti,ab) OR ((iron NEAR/5 supplement*):ti,ab)
#29 ‘zinc’/mj OR ‘zinc sulfate’/mj OR ‘zinc derivative’/mj OR ‘zinc acetate’/mj
#30 ((zinc NEAR/5 dietary):ti,ab) OR ((zinc NEAR/5 supplement*):ti,ab)
#31 ‘magnesium sulfate’/mj OR ‘magnesium’/mj OR ‘pyroglutamate magnesium’/mj OR ‘magnesium ion’/mj
#32 ((magnesium NEAR/5 dietary):ti,ab) OR ((magnesium NEAR/5 supplement*):ti,ab)
#33 ‘nicotinamide’/mj OR ‘nicotinic acid derivative’/mj
#34 ‘nicotinic acid’/mj
#35 niacin:ti,ab OR ‘nicotinic acid*’:ti,ab
#36 ‘selenium’/mj OR ‘selenoamino acid’/exp/mj
#37 selenium:ti,ab
#38 ‘vitamin supplementation’/de OR ‘mineral supplementation’/de OR ‘multivitamin’/exp
#39 ((vitamin* NEAR/5 dietary):ti,ab) OR ((vitamin* NEAR/5 supplement*):ti,ab) OR ((mineral* NEAR/5 dietary):ti,ab) OR ((mineral* NEAR/5 supplement*):ti,ab)
#40 multivitamin*:ti,ab OR ‘multi-vitamin*’:ti,ab OR multimineral*:ti,ab OR ‘multi-mineral*’:ti,ab
#41 #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40
#42 ‘cardiovascular disease’/exp/mj
#43 ‘cardi* disease*’:ti,ab OR ‘heart disease*’:ti,ab OR cardiomyopath*:ti,ab OR ‘myocardial infarction’:ti,ab OR ‘heart arrest’:ti,ab OR ‘heart attack*’:ti,ab OR ‘coronary arter* disease’:ti,ab OR ‘coronary heart disease’:ti,ab OR isch*emi*:ti,ab OR arrhythmia*:ti,ab OR (((heart OR myocardial OR cardiac OR systolic OR diastolic OR ventricular) NEAR/1 (failure* OR dysfunction)):ti,ab) OR angina:ti,ab OR ‘vascular disease*’:ti,ab OR ‘cerebrovascular disease*’:ti,ab OR ‘cerebrovascular disorder*’:ti,ab OR aneurysm:ti,ab OR ‘arterial occlusive disease’:ti,ab OR stroke:ti,ab OR ‘cerebrovascular accident*’:ti,ab OR ‘diabetic angiopath*’:ti,ab OR ‘diabetic foot’:ti,ab OR ‘diabetic retinopathy*’:ti,ab OR hypertensi*:ti,ab OR ‘high blood pressure’:ti,ab OR prehypertensi*:ti,ab OR hypotens*:ti,ab OR ‘low blood pressure’:ti,ab OR ‘carotid artery disease*’:ti,ab OR (((thromb* OR embolic OR emboli OR embolism* OR embolus) NEAR/1 (vein OR veins OR venous OR venules OR pulmonary OR lung)):ti,ab) OR ‘peripheral arter* disease*’:ti,ab OR atherosclero*:ti,ab
#44 (((heart OR myocardial OR cardiac OR systolic OR diastolic OR ventricular) NEAR/1 (failure* OR dysfunction)):ti,ab) OR (((thromb* OR embolic OR emboli OR embolism* OR embolus) NEAR/1 (vein OR veins OR venous OR venules OR pulmonary OR lung)):ti,ab)
#45 ‘hyperlipidemia’/exp/mj
#46 hyperlipid*emia*:ti,ab OR hypercholesterol*:ti,ab OR ‘high cholesterol’:ti,ab OR ‘elevated cholesterol’:ti,ab
#47 ‘neoplasm’/exp/mj
#48 neoplas*:ti,ab OR cancer*:ti,ab OR tumor:ti,ab OR tumors:ti,ab OR tumour:ti,ab OR tumours:ti,ab OR malignan*:ti,ab OR carcinoma*:ti,ab OR adenocarcinoma*:ti,ab OR blastoma*:ti,ab OR squamous:ti,ab OR metastatic:ti,ab OR ‘meta static’:ti,ab OR sarcoma*:ti,ab OR myeloma*:ti,ab OR adenoma*:ti,ab OR glioblastoma*:ti,ab OR lymphoma*:ti,ab OR schwannoma*:ti,ab OR leukemia*:ti,ab OR leukaemia*:ti,ab OR hepatoma*:ti,ab OR metastas*:ti,ab OR oncology:ti,ab OR glioma*:ti,ab OR carcinogen*:ti,ab OR cholangiocarcinoma*:ti,ab OR neurofibroma*:ti,ab OR osteosarcoma*:ti,ab OR teratoma*:ti,ab OR melanoma*:ti,ab
#49 #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48
#50 ‘adverse event’/exp/mj OR ‘drug toxicity’/exp/mj OR ‘side effect’/exp/mj
#51 harm*:ti,ab OR advers*:ti,ab OR ‘side effect*’:ti,ab OR ‘drug toxicity’:ti,ab
#52 ‘sarcoidosis’/exp/mj
#53 sarcoid*:ti,ab OR neurosarcoidosis:ti,ab OR besnier:ti,ab OR ‘schaumann syndrome’:ti,ab
#54 ‘stone formation’/exp/mj
#55 stone:ti,ab OR stones:ti,ab OR lithiasis:ti,ab OR nephrolithiasis:ti,ab OR cholelithiasis:ti,ab OR urolithiasis:ti,ab OR choledocholithiasis:ti,ab OR hepatolithiasis:ti,ab OR calculus:ti,ab OR calculi:ti,ab
#56 ‘bleeding’/exp/mj
#57 h$emorrhag*:ti,ab OR bleed*:ti,ab
#58 #50 OR #51 OR #52 OR #53 OR #54 OR #55 OR #56 OR #57
#59 ‘randomized controlled trial’/exp OR ‘randomized controlled trial (topic)’/mj OR ‘randomization’/exp OR ‘single blind procedure’/de OR ‘double blind procedure’/de OR ‘triple blind procedure’/de OR ‘crossover procedure’/de OR ‘placebo’/de
#60 rct:ti,ab OR sham:ti,ab OR dummy:ti,ab OR ‘single blind*’:ti,ab OR ‘double blind*’:ti,ab OR allocated:ti,ab OR allocation:ti,ab OR ‘triple blind*’:ti,ab OR ‘treble blind*’:ti,ab OR randomized:ti,ab OR randomised:ti,ab OR placebo:ti,ab OR randomly:ti,ab OR trial:ti
#61 #59 OR #60
#62 #41 AND #49 AND #61
#63 #41 AND #49 AND #61 AND [2013-2019]/py
#64 ‘observational study’/de OR ‘clinical study’/de OR ‘case control study’ OR ‘family study’/de OR ‘retrospective study’/de OR ‘prospective study’/de OR ‘cohort analysis’/de OR ‘cross-sectional study’/de
#65 ((cohort OR ‘case control’ OR ‘follow up’ OR observational OR epidemiologic* OR ‘cross sectional’) NEAR/1 (study OR studies)):ti,ab
#66 #64 OR #65
#67 #61 OR #66
#68 #41 AND #58 AND #67
#69 #41 AND #58 AND #67 AND [2013-2019]/py
#70 #63 OR #69
#71 (#63 OR #69) AND [english]/lim NOT ((‘animal’/exp OR ‘nonhuman’/de) NOT ‘human’/exp)
#72 #71 NOT (([adolescent]/lim OR [child]/lim OR [infant]/lim OR [preschool]/lim OR [school]/lim) NOT ([adult]/lim OR [aged]/lim OR [middle aged]/lim OR [very elderly]/lim OR [young adult]/lim))

Appendix A Table 1 Inclusion and Exclusion Criteria

| Included | Excluded
Populations | KQs 1, 3: Community-dwelling adults (age ≥18 years), including those:; - Without chronic disease and without nutritional deficiencies; - With high blood pressure or abnormal lipid levels without known cardiovascular disease (e.g., coronary, cerebrovascular, or peripheral artery disease) or type 2 diabetes mellitus; KQs 2, 4: Community-dwelling adults without chronic disease | Populations that only include pregnant women, infants, persons with chronic diseases other than overweight or obesity (e.g., cancer, cardiovascular disease, type 2 diabetes mellitus, HIV, end-stage renal disease, tuberculosis, arthritis, or chronic pain), persons with known clinical nutritional deficiencies, persons taking prescribed medications, persons who had intestinal or stomach surgery or have known malabsorption syndromes that may influence nutritional absorption or status, or persons who are institutionalized or hospitalized; Studies will be excluded if ≥50% of patients have known nutritional deficiencies, cardiovascular disease, type 2 diabetes mellitus, personal history of cancer (other than nonmelanoma skin cancer) or are taking prescription medications that may influence nutritional absorption or status
Setting | Trials conducted in countries rated as “very high” on the 2017 Human Development Index (as defined by the United Nations Development Programme) | Trials conducted in countries not categorized as “very high” on the 2017 Human Development Index, as there is concern for nutritional deficiencies in developing countries
Interventions | KQs 1, 2: Supplementation with multivitamins/minerals, defined as three or more vitamins, minerals, or combinations of both without added herbs, hormones, or drugs, each at a dose less than the tolerable upper intake level, as determined by the Food and Nutrition Board; KQs 3, 4: Supplementation with single nutrients and functionally related pairs (i.e., calcium; folic acid; vitamins B1, B2, B6, B12, D, E, C, and A; iron; zinc; magnesium; niacin; calcium/vitamin D; calcium/magnesium; folic acid/vitamin B12; selenium; beta-carotene; and folic acid/vitamin B6), each at a dose less than the tolerable upper intake level, as determined by the Food and Nutrition Board | Supplementation with other types of dietary supplements (e.g., herbal supplements, omega-3 fatty acids, amino acids, enzymes, proprietary products, fiber, garlic, or turmeric), or vitamin-derived agents with dermatologic indication (i.e., tretinoin, isotretinoin); interventions to increase dietary intake of a single nutrient (e.g., iron)
Comparisons | Placebo, no intervention, or usual diet | Supplementation with other vitamins or minerals
Outcomes | KQs 1, 3:; - Cancer incidence (any cancer or site-specific).; - Cardiovascular disease incidence (including coronary heart, peripheral artery, and cerebrovascular disease); - Cardiovascular disease events (myocardial infarction and ischemic and hemorrhagic stroke), heart failure; - Mortality (all-cause, cardiovascular disease–related, or cancer-related); KQs 2, 4:; - Serious adverse events (as defined by the study, or those likely requiring medical attention, such as kidney stones, sarcoidosis, and hip fracture); - Withdrawals due to adverse events; - Nonserious adverse events based on self-report or objective measurements, reported by at least 5% of the study sample taking the supplement; - Paradoxical effects on main outcomes (from trial evidence included for KQs 1 and 3) | KQs 1, 3: Intermediate measures of cardiovascular disease risk factors (i.e., systolic and diastolic blood pressure, lipid measures, and glucose measures), precancerous lesions; Nonmelanoma skin cancer will not be considered in studies that target populations with a history of previous skin cancer; KQs 2, 4: Intermediate or laboratory measures (e.g., hypercalciuria)
Timing | All-cause mortality: Minimum of 1 year of followup; All other outcomes: No minimum followup | Less than 1 year of followup (all-cause mortality only)
Study Designs | KQs 1, 3: Randomized, controlled trials; KQs 2, 4: Randomized, controlled trials or, for serious harms only, large (n ≥1,000) comparative observational studies (cohort or case-control) or postmarket surveillance data; Only randomized, controlled trials will be considered for studies showing paradoxical harmful effects on main outcomes (cancer incidence and cardiovascular disease incidence or events) | All other study designs

Appendix A Table 2 Single Screening Terms

Single Screening Terms | No. (%)^*^
Adolesc | 1274 (7.30)
Allele | 257 (1.47)
Animal | 1190 (6.82)
Arthrit | 301 (1.72)
Braz | 129 (0.74)
Child | 1661 (9.51)
Chin | 950 (5.44)
Fiber | 275 (1.56)
Garlic | 39 (0.22)
Hepati | 426 (2.44)
Herbal | 181 (1.04)
HIV | 238 (1.36)
India | 304 (1.74)
Infant | 889 (5.09)
Infect | 895 (5.13)
Iran | 228 (1.31)
Isotretinoin | 5 (0.29)
Mexic | 46 (0.26.3)
Mice | 206 (1.18)
Neonat | 444 (2.54)
Niger | 49 (0.28)
Peru | 18 (0.10)
Polymorphism | 594 (3.40)
Preg | 1957 (11.21)
Rats | 257 (1.47)
Rheum | 226 (1.29)
Russ | 24 (0.14)
South Africa | 33 (0.19)
Transplant | 444 (2.54)
Tretinoin | 84 (0.48)
Turk | 63 (0.36)
Turmeric | 18(0.10)

* Counts are not mutually exclusive.

Appendix A Table 3 Recommended Dietary Allowance (RDA) and Upper Intake Levels for Included Micronutrients^153,^ ^197^

Vitamin or mineral | Other Names | Group | Age (years) | RDA | UL
Vitamin A (mcg/d)^*^; Conversion factor 1IU supplemental beta-carotene=0.3 mcg RAE | Vitamin A Retinol, Retinal | Males | 9-13 | 600 mcg/d RAE | 1700 mcg/d RAE (5,667 IU)
Vitamin A (mcg/d)^*^; Conversion factor 1IU supplemental beta-carotene=0.3 mcg RAE | Vitamin A Retinol, Retinal | Males | 14-18 | 900 mcg/d RAE | 2800 mcg/d RAE (9,333 IU)
Vitamin A (mcg/d)^*^; Conversion factor 1IU supplemental beta-carotene=0.3 mcg RAE | Vitamin A Retinol, Retinal | Males | ≥19 | 900 mcg/d RAE | 3000 mcg/d RAE (10,000 IU)
Vitamin A (mcg/d)^*^; Conversion factor 1IU supplemental beta-carotene=0.3 mcg RAE | Vitamin A Retinol, Retinal | Females | 9-13 | 600 mcg/d RAE | 1700 mcg/d RAE (5,667 IU)
Vitamin A (mcg/d)^*^; Conversion factor 1IU supplemental beta-carotene=0.3 mcg RAE | Vitamin A Retinol, Retinal | Females | 14-18 | 700 mcg/d RAE | 2800 mcg/d RAE (9,333 IU)
Vitamin A (mcg/d)^*^; Conversion factor 1IU supplemental beta-carotene=0.3 mcg RAE | Vitamin A Retinol, Retinal | Females | ≥19 | 700 mcg/d RAE | 3000 mcg/d RAE (10,000 IU)
Vitamin B_1_ (mg/d) | Thiamine, thiamin, aneurine | Males | 9-13 | 0.9 | ND
Vitamin B_1_ (mg/d) | Thiamine, thiamin, aneurine | Males | ≥14 | 1.2 | ND
Vitamin B_1_ (mg/d) | Thiamine, thiamin, aneurine | Females | 9-13 | 0.9 | ND
Vitamin B_1_ (mg/d) | Thiamine, thiamin, aneurine | Females | 14-18 | 1.0 | ND
Vitamin B_1_ (mg/d) | Thiamine, thiamin, aneurine | Females | ≥19 | 1.1 | ND
Vitamin B_2_ (mg/d) | Riboflavin | Males | 9-13 | 0.9 | ND
Vitamin B_2_ (mg/d) | Riboflavin | Males | ≥14 | 1.3 | ND
Vitamin B_2_ (mg/d) | Riboflavin | Females | 9-13 | 0.9 | ND
Vitamin B_2_ (mg/d) | Riboflavin | Females | 14-18 | 1.0 | ND
Vitamin B_2_ (mg/d) | Riboflavin | Females | ≥19 | 1.1 | ND
Vitamin B_6_ (mg/d) | None | Males | 9-13 | 1.0 | 60
Vitamin B_6_ (mg/d) | None | Males | 14-18 | 1.3 | 80
Vitamin B_6_ (mg/d) | None | Males | 19-50 | 1.3 | 100
Vitamin B_6_ (mg/d) | None | Males | ≥51 | 1.7 | 100
Vitamin B_6_ (mg/d) | None | Females | 9-13 | 1.0 | 60
Vitamin B_6_ (mg/d) | None | Females | 14-18 | 1.2 | 80
Vitamin B_6_ (mg/d) | None | Females | 19-50 | 1.3 | 100
Vitamin B_6_ (mg/d) | None | Females | ≥51 | 1.5 | 100
Vitamin B_12_ (mcg/d) | Cobalamin | Males | 9-13 | 1.8 | ND
Vitamin B_12_ (mcg/d) | Cobalamin | Males | ≥14 | 2.4 | ND
Vitamin B_12_ (mcg/d) | Cobalamin | Females | 9-13 | 1.8 | ND
Vitamin B_12_ (mcg/d) | Cobalamin | Females | ≥14 | 2.4 | ND
Vitamin C (mg/d) | L-ascorbic acid, ascorbate,; Dehydroascorbic acid (DHA) | Males | 9-13 | 45 | 1200
Vitamin C (mg/d) | L-ascorbic acid, ascorbate,; Dehydroascorbic acid (DHA) | Males | 14-18 | 75 | 1800
Vitamin C (mg/d) | L-ascorbic acid, ascorbate,; Dehydroascorbic acid (DHA) | Males | ≥19 | 90 | 2000
Vitamin C (mg/d) | L-ascorbic acid, ascorbate,; Dehydroascorbic acid (DHA) | Females | 4-8 | 75 | 1200
Vitamin C (mg/d) | L-ascorbic acid, ascorbate,; Dehydroascorbic acid (DHA) | Females | 9-18 | 65 | 1800
Vitamin C (mg/d) | L-ascorbic acid, ascorbate,; Dehydroascorbic acid (DHA) | Females | ≥19 | 75 | 2000
Vitamin D (mcg/d (IU)) | Calciferol, cholecalciferol (Vit D3),; Calcitriol (synthetic Vit D3); Alfacalcidol (Vit D3); Ergocalciferol (Vit D2) | Males | 9-70 | 15 mcg/d | 100 mcg/d (4000 IU/d)
Vitamin D (mcg/d (IU)) | Calciferol, cholecalciferol (Vit D3),; Calcitriol (synthetic Vit D3); Alfacalcidol (Vit D3); Ergocalciferol (Vit D2) | Males | >70 | 20 mcg/d | 100 mcg/d (4000 IU/d)
Vitamin D (mcg/d (IU)) | Calciferol, cholecalciferol (Vit D3),; Calcitriol (synthetic Vit D3); Alfacalcidol (Vit D3); Ergocalciferol (Vit D2) | Females | 9-70 | 15 mcg/d | 100 mcg/d (4000 IU/d)
Vitamin D (mcg/d (IU)) | Calciferol, cholecalciferol (Vit D3),; Calcitriol (synthetic Vit D3); Alfacalcidol (Vit D3); Ergocalciferol (Vit D2) | Females | >70 | 20 mcg/d | 100 mcg/d (4000 IU/d)
Vitamin E (mg/d) | α-tocopherol | Males | 9-13 | 11 | 600
Vitamin E (mg/d) | α-tocopherol | Males | 14-18 | 15 | 800
Vitamin E (mg/d) | α-tocopherol | Males | ≥19 | 15 | 1000
Vitamin E (mg/d) | α-tocopherol | Females | 9-13 | 11 | 600
Vitamin E (mg/d) | α-tocopherol | Females | 14-18 | 15 | 800
Vitamin E (mg/d) | α-tocopherol | Females | ≥19 | 15 | 1000
Calcium (mg/d) | calcium carbonate,; calcium gluconate,; calcium citrate | Males | 9-13 | 1300 | 3000
Calcium (mg/d) | calcium carbonate,; calcium gluconate,; calcium citrate | Males | 19-30 | 1000 | 2500
Calcium (mg/d) | calcium carbonate,; calcium gluconate,; calcium citrate | Males | 51-70 | 1000 | 2000
Calcium (mg/d) | calcium carbonate,; calcium gluconate,; calcium citrate | Males | ≥71 | 1200 | 2000
Calcium (mg/d) | calcium carbonate,; calcium gluconate,; calcium citrate | Females | 9-13 | 1300 | 3000
Calcium (mg/d) | calcium carbonate,; calcium gluconate,; calcium citrate | Females | 19-30 | 1000 | 2500
Calcium (mg/d) | calcium carbonate,; calcium gluconate,; calcium citrate | Females | ≥51 | 1200 | 2000
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, and pteroylmonoglutamic acid, folate | Males | 9-13 | 300 | 600
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, and pteroylmonoglutamic acid, folate | Males | 14-18 | 400 | 800
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, and pteroylmonoglutamic acid, folate | Males | ≥19 | 400 | 1000
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, and pteroylmonoglutamic acid, folate | Females | 9-13 | 300 | 600
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, and pteroylmonoglutamic acid, folate | Females | 14-18 | 400 | 800
Folic acid (mcg/d) | Vitamin M, vitamin B_9_, vitamin B_c_, folacin, pteroyl-L-glutamic acid, pteroyl-L-glutamate, and pteroylmonoglutamic acid, folate | Females | ≥19 | 400 | 1000
Iron (mg/d) | None | Males | 9-13 | 8 | 40
Iron (mg/d) | None | Males | 14-18 | 11 | 45
Iron (mg/d) | None | Males | ≥19 | 8 | 45
Iron (mg/d) | None | Females | 9-13 | 8 | 40
Iron (mg/d) | None | Females | 14-18 | 15 | 45
Iron (mg/d) | None | Females | 19-30 | 18 | 45
Iron (mg/d) | None | Females | 31-50 | 15 | 45
Iron (mg/d) | None | Females | ≥51 | 8 | 45
Magnesium (mg/d) | Magnesia, Magnesia; Carbonica, Magnesia; Muriatica, Magnesium; Gluconate, Milk of Magnesia | Males | 9-13 | 240 | 350
Magnesium (mg/d) | Magnesia, Magnesia; Carbonica, Magnesia; Muriatica, Magnesium; Gluconate, Milk of Magnesia | Males | 14-18 | 410 | 350
Magnesium (mg/d) | Magnesia, Magnesia; Carbonica, Magnesia; Muriatica, Magnesium; Gluconate, Milk of Magnesia | Males | 19-30 | 400 | 350
Magnesium (mg/d) | Magnesia, Magnesia; Carbonica, Magnesia; Muriatica, Magnesium; Gluconate, Milk of Magnesia | Males | ≥31 | 420 | 350
Magnesium (mg/d) | Magnesia, Magnesia; Carbonica, Magnesia; Muriatica, Magnesium; Gluconate, Milk of Magnesia | Females | 9-13 | 240 | 350
Magnesium (mg/d) | Magnesia, Magnesia; Carbonica, Magnesia; Muriatica, Magnesium; Gluconate, Milk of Magnesia | Females | 14-18 | 360 | 350
Magnesium (mg/d) | Magnesia, Magnesia; Carbonica, Magnesia; Muriatica, Magnesium; Gluconate, Milk of Magnesia | Females | 19-30 | 310 | 350
Magnesium (mg/d) | Magnesia, Magnesia; Carbonica, Magnesia; Muriatica, Magnesium; Gluconate, Milk of Magnesia | Females | ≥31 | 320 | 350
Niacin (mg/d) | Vitamin B3, nicotinic acid,; Nicotinamide, vitamin PP | Males | 9-13 | 12 | 20
Niacin (mg/d) | Vitamin B3, nicotinic acid,; Nicotinamide, vitamin PP | Males | 14-18 | 16 | 30
Niacin (mg/d) | Vitamin B3, nicotinic acid,; Nicotinamide, vitamin PP | Males | ≥19 | 16 | 35
Niacin (mg/d) | Vitamin B3, nicotinic acid,; Nicotinamide, vitamin PP | Females | 9-13 | 12 | 20
Niacin (mg/d) | Vitamin B3, nicotinic acid,; Nicotinamide, vitamin PP | Females | 14-18 | 14 | 30
Niacin (mg/d) | Vitamin B3, nicotinic acid,; Nicotinamide, vitamin PP | Females | ≥19 | 14 | 35
Selenium (mcg/d) | High-selenium yeast, selenized yeast, chelated selenium | Males | 9-13 | 40 | 280
Selenium (mcg/d) | High-selenium yeast, selenized yeast, chelated selenium | Males | ≥14 | 55 | 400
Selenium (mcg/d) | High-selenium yeast, selenized yeast, chelated selenium | Females | 9-13 | 40 | 280
Selenium (mcg/d) | High-selenium yeast, selenized yeast, chelated selenium | Females | ≥14 | 55 | 400
Zinc (mg/d) | Zinc acetate | Males | 9-13 | 8 | 23
Zinc (mg/d) | Zinc acetate | Males | 14-18 | 11 | 34
Zinc (mg/d) | Zinc acetate | Males | ≥19 | 11 | 40
Zinc (mg/d) | Zinc acetate | Females | 9-13 | 8 | 23
Zinc (mg/d) | Zinc acetate | Females | 14-18 | 9 | 34
Zinc (mg/d) | Zinc acetate | Females | ≥19 | 8 | 40

* Beta-carotene is a provitamin A carotenoid, meaning the body converts it to Vit A. Beta-carotene is thought to not cause toxicity and has no designated upper limit.

Abbreviations: IU = International unit; RAE = Retinol activity equivalents; RDA = Recommended daily allowance (Average daily level of intake sufficient to meet the nutrient requirements of nearly all (97%–98%) healthy individuals, often used to plan nutritionally adequate diets for individuals); UL= Tolerable upper intake level (Maximum daily intake unlikely to cause adverse health effects).

Appendix A Table 4 Study Design-Specific Quality Rating Criteria

Study Design | Adapted Quality Criteria
Randomized and non-randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^47^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.

Appendix A Figure 1 Literature Flow Diagram

*Studies may appear in more than one Key Question.

This figure is a flow chart that summarizes the search and selection of articles in this review. There were 37,078 citations identified through literature databases. An additional 116 citations were identified from outside sources, and 103 citations were identified from the USPSTF Vitamin, Mineral, and Multivitamin Supplement review from 2014. After duplicates were removed, 17,459 unique citations were screened at the title/abstract stage. The full-text of 379 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=9), Key Question 2 (k=12), Key Question 3 (k=58), and Key Question 4 (k=66). Reasons for excluding the other articles are available in Appendix C.