# References

1 Curry SJ, Krist AH, Owens DK, . Screening for atrial fibrillation with electrocardiography: US Preventive Services Task Force recommendation statement. JAMA. 2018 Aug 7;320(5):478–84. doi: 10.1001/jama.2018.10321. PMID: 30088016.30088016
2 Jonas DE, Kahwati LC, Yun JDY, . Screening for atrial fibrillation with electrocardiography: an evidence review for the U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Rockville, MD: Agency for Healthcare Research and Quality; 2018. PMID: 3022227930222279.
3 January CT, Wann LS, Alpert JS, . 2014 AHA/ACC/HRS guideline for the management of patients with atrial fibrillation: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and the Heart Rhythm Society. J Am Coll Cardiol. 2014 Dec 02;64(21):e1–76. doi: 10.1016/j.jacc.2014.03.022. PMID: 24685669.24685669
4 January CT, Wann LS, Calkins H, . 2019 AHA/ACC/HRS focused update of the 2014 AHA/ACC/HRS guideline for the management of patients with atrial fibrillation: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines and the Heart Rhythm Society. Heart Rhythm. 2019 Aug;16(8):e66–e93. doi: 10.1016/j.hrthm.2019.01.024. PMID: 30703530.30703530
5 Staerk L, Sherer JA, Ko D, . Atrial fibrillation: epidemiology, pathophysiology, and clinical outcomes. Circ Res. 2017 Apr 28;120(9):1501–17. doi: 10.1161/circresaha.117.309732. PMID: 28450367.28450367
6 Kumar K. Overview of atrial fibrillation. In: Zimetbaum PJ, Saperia GM, eds. UpToDate. Vol. 2020. Alphen aan den Rijn, Netherlands: Wolters Kluwer; 2020.
7 Hindricks G, Potpara T, Dagres N, . 2020 ESC Guidelines for the diagnosis and management of atrial fibrillation developed in collaboration with the European Association of Cardio-Thoracic Surgery (EACTS). Eur Heart J. 2020 Aug 29 doi: 10.1093/eurheartj/ehaa612. PMID: 32860505.32860505
8 Noseworthy PA, Kaufman ES, Chen LY, . Subclinical and device-detected atrial fibrillation: pondering the knowledge gap: a scientific statement from the American Heart Association. Circulation. 2019 Dec 17;140(25):e944–e63. doi: 10.1161/cir.0000000000000740. PMID: 31694402.31694402
9 Virani SS, Alonso A, Benjamin EJ, . Heart disease and stroke statistics-2020 update: a report from the American Heart Association. Circulation. 2020 Mar 3;141(9):e139–e596. doi: 10.1161/cir.0000000000000757. PMID: 31992061.31992061
10 Burstein B, Nattel S. Atrial fibrosis: mechanisms and clinical relevance in atrial fibrillation. J Am Coll Cardiol. 2008 Feb 26;51(8):802–9. doi: 10.1016/j.jacc.2007.09.064. PMID: 18294563.18294563
11 Kistler PM, Sanders P, Fynn SP, . Electrophysiologic and electroanatomic changes in the human atrium associated with age. J Am Coll Cardiol. 2004 Jul 7;44(1):109–16. doi: 10.1016/j.jacc.2004.03.044. PMID: 15234418.15234418
12 Allessie M, Ausma J, Schotten U. Electrical, contractile and structural remodeling during atrial fibrillation. Cardiovasc Res. 2002 May;54(2):230–46. PMID: 12062329.12062329
13 Nattel S, Burstein B, Dobrev D. Atrial remodeling and atrial fibrillation: mechanisms and implications. Circ Arrhythm Electrophysiol. 2008 Apr;1(1):62–73. doi: 10.1161/CIRCEP.107.754564. PMID: 19808395.19808395
14 Ikeda T, Murai H, Kaneko S, . Augmented single-unit muscle sympathetic nerve activity in heart failure with chronic atrial fibrillation. J Physiol. 2012 Feb 1;590(Pt 3):509–18. doi: 10.1113/jphysiol.2011.223842. PMID: 22144576.22144576
15 Segerson NM, Sharma N, Smith ML, . The effects of rate and irregularity on sympathetic nerve activity in human subjects. Heart Rhythm. 2007 Jan;4(1):20–6. doi: 10.1016/j.hrthm.2006.09.017. PMID: 17198984.17198984
16 Nabauer M, Gerth A, Limbourg T, . The Registry of the German Competence NETwork on Atrial Fibrillation: patient characteristics and initial management. Europace. 2009 Apr;11(4):423–34. doi: 10.1093/europace/eun369. PMID: 19153087.19153087
17 Savelieva I, Camm AJ. Clinical relevance of silent atrial fibrillation: prevalence, prognosis, quality of life, and management. J Interv Card Electrophysiol. 2000 Jun;4(2):369–82. PMID: 10936003.10936003
18 Watson T, Shantsila E, Lip GY. Mechanisms of thrombogenesis in atrial fibrillation: Virchow’s triad revisited. Lancet. 2009 Jan 10;373(9658):155–66. doi: 10.1016/S0140-6736(09)60040-4. PMID: 19135613.19135613
19 Wolf PA, Abbott RD, Kannel WB. Atrial fibrillation as an independent risk factor for stroke: the Framingham Study. Stroke. 1991 Aug;22(8):983–8. PMID: 1866765.1866765
20 Marijon E, Le Heuzey JY, Connolly S, . Causes of death and influencing factors in patients with atrial fibrillation: a competing-risk analysis from the randomized evaluation of long-term anticoagulant therapy study. Circulation. 2013 Nov 12;128(20):2192–201. doi: 10.1161/circulationaha.112.000491. PMID: 24016454.24016454
21 Chamberlain AM, Agarwal SK, Folsom AR, . A clinical risk score for atrial fibrillation in a biracial prospective cohort (from the Atherosclerosis Risk in Communities [ARIC] study). Am J Cardiol. 2011 Jan;107(1):85–91. doi: 10.1016/j.amjcard.2010.08.049. PMID: 21146692.21146692
22 Schnabel RB, Sullivan LM, Levy D, . Development of a risk score for atrial fibrillation (Framingham Heart Study): a community-based cohort study. Lancet. 2009 Feb 28;373(9665):739–45. doi: 10.1016/S0140-6736(09)60443-8. PMID: 19249635.19249635
23 Alonso A, Krijthe BP, Aspelund T, . Simple risk model predicts incidence of atrial fibrillation in a racially and geographically diverse population: the CHARGE-AF consortium. J Am Heart Assoc. 2013 Mar 18;2(2):e000102. doi: 10.1161/jaha.112.000102. PMID: 23537808.23537808
24 Benjamin EJ, Muntner P, Alonso A, . Heart disease and stroke statistics-2019 update: a report from the American Heart Association. Circulation. 2019 Mar 5;139(10):e56–e528. doi: 10.1161/cir.0000000000000659. PMID: 30700139.30700139
25 Centers for Medicare & Medicaid Services. Medicare beneficiary prevalence for chronic conditions for 2004 through 2013. 2015. https://www.ccwdata.org/web/guest/medicare-charts/medicare-chronic-condition-charts/#b2_cardio_2004_2013. Accessed October 13, 2021.
26 Go AS, Hylek EM, Phillips KA, . Prevalence of diagnosed atrial fibrillation in adults: national implications for rhythm management and stroke prevention: the AnTicoagulation and Risk Factors in Atrial Fibrillation (ATRIA) Study. JAMA. 2001 May 9;285(18):2370–5. PMID: 11343485.11343485
27 Williams BA, Chamberlain AM, Blankenship JC, . Trends in atrial fibrillation incidence rates within an integrated health care delivery system, 2006 to 2018. JAMA Netw Open. 2020 Aug 3;3(8):e2014874. doi: 10.1001/jamanetworkopen.2020.14874. PMID: 32857147.32857147
28 Schnabel RB, Yin X, Gona P, . 50 year trends in atrial fibrillation prevalence, incidence, risk factors, and mortality in the Framingham Heart Study: a cohort study. Lancet. 2015 Jul 11;386(9989):154–62. doi: 10.1016/s0140-6736(14)61774-8. PMID: 25960110.25960110
29 Loehr LR, Soliman EZ, Poon AK, . The prevalence of atrial fibrillation on 48-hour ambulatory electrocardiography in African Americans compared to Whites: The Atherosclerosis Risk in Communities (ARIC) study. Am Heart J. 2019 Oct;216:1–8. doi: 10.1016/j.ahj.2019.06.017. PMID: 31352135.31352135
30 Heckbert SR, Austin TR, Jensen PN, . Differences by race/ethnicity in the prevalence of clinically detected and monitor-detected atrial fibrillation: MESA. Circ Arrhythm Electrophysiol. 2020 Jan;13(1):e007698. doi: 10.1161/circep.119.007698. PMID: 31934795.31934795
31 Harris K, Edwards D, Mant J. How can we best detect atrial fibrillation? J R Coll Physicians Edinb. 2012;42 Suppl 18:5–22. doi: 10.4997/JRCPE.2012.S02. PMID: 22518390.22518390
32 Benjamin EJ, Virani SS, Callaway CW, . Heart disease and stroke statistics-2018 update: a report from the American Heart Association. Circulation. 2018 Mar 20;137(12):e67–e492. doi: 10.1161/cir.0000000000000558. PMID: 29386200.29386200
33 Diederichsen SZ, Haugan KJ, Brandes A, . Incidence and predictors of atrial fibrillation episodes as detected by implantable loop recorder in patients at risk: From the LOOP study. Am Heart J. 2019 Oct 20 doi: 10.1016/j.ahj.2019.09.009. PMID: 31699295.31699295
34 Stroke Risk in Atrial Fibrillation Working Group. Independent predictors of stroke in patients with atrial fibrillation: a systematic review. Neurology. 2007 Aug 7;69(6):546–54. doi: 10.1212/01.wnl.0000267275.68538.8d. PMID: 17679673.17679673
35 Dulli DA, Stanko H, Levine RL. Atrial fibrillation is associated with severe acute ischemic stroke. Neuroepidemiology. 2003 Mar–Apr;22(2):118–23. doi: 10.1159/000068743. PMID: 12629277.12629277
36 Lamassa M, Di Carlo A, Pracucci G, . Characteristics, outcome, and care of stroke associated with atrial fibrillation in Europe: data from a multicenter multinational hospital-based registry (The European Community Stroke Project). Stroke. 2001 Feb;32(2):392–8. PMID: 11157172.11157172
37 Lin HJ, Wolf PA, Kelly-Hayes M, . Stroke severity in atrial fibrillation. The Framingham Study. Stroke. 1996 Oct;27(10):1760–4. PMID: 8841325.8841325
38 Menke J, Luthje L, Kastrup A, . Thromboembolism in atrial fibrillation. Am J Cardiol. 2010 Feb 15;105(4):502–10. doi: 10.1016/j.amjcard.2009.10.018. PMID: 20152245.20152245
39 Potpara TS, Polovina MM, Marinkovic JM, . A comparison of clinical characteristics and long-term prognosis in asymptomatic and symptomatic patients with first-diagnosed atrial fibrillation: the Belgrade Atrial Fibrillation Study. Int J Cardiol. 2013 Oct 12;168(5):4744–9. doi: 10.1016/j.ijcard.2013.07.234. PMID: 23958417.23958417
40 Tsang TS, Barnes ME, Pellikka PA, . Silent atrial fibrillation in Olmsted County: a community-based study. Can J Cardiol. 2011;27(5):S122–S.
41 Siontis KC, Gersh BJ, Killian JM, . Typical, atypical, and asymptomatic presentations of new-onset atrial fibrillation in the community: Characteristics and prognostic implications. Heart Rhythm. 2016 Jul;13(7):1418–24. doi: 10.1016/j.hrthm.2016.03.003. PMID: 26961300.26961300
42 Boriani G, Laroche C, Diemberger I, . Asymptomatic atrial fibrillation: clinical correlates, management, and outcomes in the EORP-AF Pilot General Registry. Am J Med. 2015 May;128(5):509–18.e2. doi: 10.1016/j.amjmed.2014.11.026. PMID: 25534423.25534423
43 Link MS, Giugliano RP, Ruff CT, . Stroke and mortality risk in patients with various patterns of atrial fibrillation: results from the ENGAGE AF-TIMI 48 Trial (Effective Anticoagulation With Factor Xa Next Generation in Atrial Fibrillation-Thrombolysis in Myocardial Infarction 48). Circ Arrhythm Electrophysiol. 2017 Jan;10(1) doi: 10.1161/circep.116.004267. PMID: 28077507.28077507
44 Ganesan AN, Chew DP, Hartshorne T, . The impact of atrial fibrillation type on the risk of thromboembolism, mortality, and bleeding: a systematic review and meta-analysis. Eur Heart J. 2016 May 21;37(20):1591–602. doi: 10.1093/eurheartj/ehw007. PMID: 26888184.26888184
45 Boriani G, Proietti M, Laroche C, . Changes to oral anticoagulant therapy and risk of death over a 3-year follow-up of a contemporary cohort of European patients with atrial fibrillation final report of the EURObservational Research Programme on Atrial Fibrillation (EORP-AF) pilot general registry. Int J Cardiol. 2018 Nov 15;271:68–74. doi: 10.1016/j.ijcard.2018.05.034. PMID: 30001945.30001945
46 Mahajan R, Perera T, Elliott AD, . Subclinical device-detected atrial fibrillation and stroke risk: a systematic review and meta-analysis. Eur Heart J. 2018 Apr 21;39(16):1407–15. doi: 10.1093/eurheartj/ehx731. PMID: 29340587.29340587
47 Brambatti M, Connolly SJ, Gold MR, . Temporal relationship between subclinical atrial fibrillation and embolic events. Circulation. 2014 May 27;129(21):2094–9. doi: 10.1161/circulationaha.113.007825. PMID: 24633881.24633881
48 Uittenbogaart SB, Lucassen WAM, van Etten-Jamaludin FS, . Burden of atrial high-rate episodes and risk of stroke: a systematic review. Europace. 2018 Sep 1;20(9):1420–7. doi: 10.1093/europace/eux356. PMID: 29309554.29309554
49 Go AS, Reynolds K, Yang J, . Association of burden of atrial fibrillation with risk of ischemic stroke in adults with paroxysmal atrial fibrillation: the KP-RHYTHM study. JAMA Cardiol. 2018 Jul 1;3(7):601–8. doi: 10.1001/jamacardio.2018.1176. PMID: 29799942.29799942
50 Wolf PA, Kannel WB, McGee DL, . Duration of atrial fibrillation and imminence of stroke: the Framingham study. Stroke. 1983 Sep–Oct;14(5):664–7. PMID: 6658948.6658948
51 Lin HJ, Wolf PA, Benjamin EJ, . Newly diagnosed atrial fibrillation and acute stroke. The Framingham Study. Stroke. 1995 Sep;26(9):1527–30. PMID: 7660392.7660392
52 Hannon N, Sheehan O, Kelly L, . Stroke associated with atrial fibrillation--incidence and early outcomes in the north Dublin population stroke study. Cerebrovasc Dis. 2010;29(1):43–9. doi: 10.1159/000255973. PMID: 19893311.19893311
53 Packer DL, Bardy GH, Worley SJ, . Tachycardia-induced cardiomyopathy: a reversible form of left ventricular dysfunction. Am J Cardiol. 1986 Mar 01;57(8):563–70. PMID: 3953440.3953440
54 Nerheim P, Birger-Botkin S, Piracha L, . Heart failure and sudden death in patients with tachycardia-induced cardiomyopathy and recurrent tachycardia. Circulation. 2004 Jul 20;110(3):247–52. doi: 10.1161/01.CIR.0000135472.28234.CC. PMID: 15226218.15226218
55 Kirchhof P, Camm AJ, Goette A, . Early rhythm-control therapy in patients with atrial fibrillation. N Engl J Med. 2020 Oct 1;383(14):1305–16. doi: 10.1056/NEJMoa2019422. PMID: 32865375.32865375
56 Philippsen TJ, Christensen LS, Hansen MG, . Detection of subclinical atrial fibrillation in high-risk patients using an insertable cardiac monitor. JACC Clin Electrophysiol. 2017 Dec 26;3(13):1557–64. doi: 10.1016/j.jacep.2017.06.020. PMID: 29759838.29759838
57 Taggar JS, Coleman T, Lewis S, . Accuracy of methods for detecting an irregular pulse and suspected atrial fibrillation: A systematic review and meta-analysis. Eur J Prev Cardiol. 2016 Aug;23(12):1330–8. doi: 10.1177/2047487315611347. PMID: 26464292.26464292
58 Cook DA, Oh SY, Pusic MV. Accuracy of physicians’ electrocardiogram interpretations: a systematic review and meta-analysis. JAMA Intern Med. 2020 Sep 28 doi: 10.1001/jamainternmed.2020.3989. PMID: 32986084.32986084
59 Hart RG, Pearce LA, Aguilar MI. Meta-analysis: antithrombotic therapy to prevent stroke in patients who have nonvalvular atrial fibrillation. Ann Intern Med. 2007 Jun 19;146(12):857–67. PMID: 17577005.17577005
60 Ogilvie IM, Newton N, Welner SA, . Underuse of oral anticoagulants in atrial fibrillation: a systematic review. Am J Med. 2010 Jul;123(7):638–45 e4. doi: 10.1016/j.amjmed.2009.11.025. PMID: 20609686.20609686
61 Ogilvie IM, Welner SA, Cowell W, . Characterization of the proportion of untreated and antiplatelet therapy treated patients with atrial fibrillation. Am J Cardiol. 2011 Jul 1;108(1):151–61. doi: 10.1016/j.amjcard.2011.02.353. PMID: 21545990.21545990
62 Dogliotti A, Paolasso E, Giugliano RP. Current and new oral antithrombotics in non-valvular atrial fibrillation: a network meta-analysis of 79 808 patients. Heart. 2014 Mar;100(5):396–405. doi: 10.1136/heartjnl-2013-304347. PMID: 24009224.24009224
63 Sanders GD, Lowenstern A, Borre E, . AHRQ Comparative Effectiveness Reviews. Stroke Prevention in Patients With Atrial Fibrillation: A Systematic Review Update. Rockville (MD): Agency for Healthcare Research and Quality (US); 2018.
64 U.S. Food and Drug Administration. WATCHMAN LAA Closure Technology approval letter. 2015. https://www.fda.gov/medical-devices/recently-approved-devices/watchman-left-atrial-appendage-closure-device-delivery-system-and-watchman-flx-left-atrial-appendage. Accessed October 13, 2021.
65 Tolat A, Lippman N. Update on the non-pharmacological management of stroke prevention in patients with atrial fibrillation. J Clin Med. 2018 Feb 12;7(2) doi: 10.3390/jcm7020032. PMID: 29439542.29439542
66 Freedman B, Camm J, Calkins H, . Screening for atrial fibrillation: a report of the AF-SCREEN international collaboration. Circulation. 2017 May 09;135(19):1851–67. doi: 10.1161/circulationaha.116.026693. PMID: 28483832.28483832
67 Hobbs FR, Taylor CJ, Jan Geersing G, . European Primary Care Cardiovascular Society (EPCCS) consensus guidance on stroke prevention in atrial fibrillation (SPAF) in primary care. Eur J Prev Cardiol. 2016 Mar;23(5):460–73. doi: 10.1177/2047487315571890. PMID: 25701017.25701017
68 King S, Fitzgerald A, Bartlett C, . Evidence summary for screening for atrial fibrillation in adults. External review against programme appraisal criteria for the UK National Screening Committee. 2019. https://legacyscreening.phe.org.uk/atrialfibrillation. Accessed October 13, 2021.
69 Murphy A, Banerjee A, Breithardt G, . The World Heart Federation roadmap for nonvalvular atrial fibrillation. Glob Heart. 2017 Dec;12(4):273–84. doi: 10.1016/j.gheart.2017.01.015. PMID: 28336387.28336387
70 Brieger D, Amerena J, Attia J, . National Heart Foundation of Australia and the Cardiac Society of Australia and New Zealand: Australian Clinical Guidelines for the Diagnosis and Management of Atrial Fibrillation 2018. Heart Lung Circ. 2018 Oct;27(10):1209–66. doi: 10.1016/j.hlc.2018.06.1043. PMID: 30077228.30077228
71 Meschia JF, Bushnell C, Boden-Albala B, . Guidelines for the primary prevention of stroke: a statement for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2014 Dec;45(12):3754–832. doi: 10.1161/STR.0000000000000046. PMID: 25355838.25355838
72 Lip GYH, Banerjee A, Boriani G, . Antithrombotic therapy for atrial fibrillation: CHEST guideline and expert panel report. Chest. 2018 Nov;154(5):1121–201. doi: 10.1016/j.chest.2018.07.040. PMID: 30144419.30144419
73 You JJ, Singer DE, Howard PA, . Antithrombotic therapy for atrial fibrillation: antithrombotic therapy and prevention of thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. 2012;141(2 Suppl):e513S–75S.
74 Andrade JG, Verma A, Mitchell LB, . 2018 focused update of the Canadian Cardiovascular Society Guidelines for the Management of Atrial Fibrillation. Can J Cardiol. 2018 Nov;34(11):1371–92. doi: 10.1016/j.cjca.2018.08.026. PMID: 30404743.30404743
75 Gladstone DJ, Wachter R, Schmalstieg-Bahr K, . Screening for atrial fibrillation in the older population: a randomized clinical trial. JAMA Cardiol. 2021 Feb 24 doi: 10.1001/jamacardio.2021.0038. PMID: 33625468.33625468
76 Svennberg E, Friberg L, Frykman V, . Clinical outcomes in systematic screening for atrial fibrillation (STROKESTOP): a multicentre, parallel group, unmasked, randomised controlled trial. Lancet. 2021 Aug 27 doi: 10.1016/s0140-6736(21)01637-8. PMID: 34469764.34469764
77 Svennberg E, Engdahl J, Al-Khalili F, . Mass screening for untreated atrial fibrillation: the STROKESTOP Study. Circulation. 2015 Jun 23;131(25):2176–84. doi: 10.1161/circulationaha.114.014343. PMID: 25910800.25910800
78 Friberg L, Engdahl J, Frykman V, . Population screening of 75- and 76-year-old men and women for silent atrial fibrillation (STROKESTOP). Europace. 2013 Jan;15(1):135–40. doi: 10.1093/europace/eus217. PMID: 22791299.22791299
79 Okumura K, Akao M, Yoshida T, . Low-Dose Edoxaban in Very Elderly Patients with Atrial Fibrillation. N Engl J Med. 2020 Oct 29;383(18):1735–45. doi: 10.1056/NEJMoa2012883. PMID: 32865374.32865374
80 Frasure-Smith N, Lesperance F, Talajic M, . Anxiety sensitivity moderates prognostic importance of rhythm-control versus rate-control strategies in patients with atrial fibrillation and congestive heart failure: insights from the Atrial Fibrillation and Congestive Heart Failure Trial. Circ Heart Fail. 2012 May 1;5(3):322–30. doi: 10.1161/circheartfailure.111.964122. PMID: 22441774.22441774
81 United Nations Development Programme. Statistical update 2018: human development indices and indicators. New York City, NY: United Nations Development Programme; 2018. http://hdr.undp.org/en/content/human-development-indices-indicators-2018-statistical-update
82 Sterne JAC, Savović J, Page MJ, . RoB 2: a revised tool for assessing risk of bias in randomised trials. BMJ. 2019 Aug 28;366:l4898. doi: 10.1136/bmj.l4898. PMID: 31462531.31462531
83 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure manual, Appendix VI. Criteria for assessing internal validity of individual studies. Rockville, MD: U.S. Preventive Services Task Force; 2017. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual/procedure-manual-appendix-vi-criteria-assessing-internal-validity-individual-studies. Accessed October 13, 2021.
84 West SL, Gartlehner G, Mansfield AJ, . Comparative effectiveness review methods: clinical heterogeneity. Methods Research Paper. AHRQ Publication No. 10-EHC070-EF. Rockville MD: Agency for Healthcare Research and Quality; September 2010. PMID: 2143333721433337. https://effectivehealthcare.ahrq.gov/products/clinical-heterogeneity-methods/research
85 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986 Sep;7(3):177–88. PMID: 3802833.3802833
86 Higgins JP, Thomas J, Chandler J, Cumpston M, Li T, Page MJ, et al., eds. Cochrane handbook for systematic reviews of interventions. Chichester, UK: John Wiley & Sons; 2019. https://training.cochrane.org/handbook/current. Accessed October 13, 2021.
87 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
88 Higgins JP, Thompson SG, Deeks JJ, . Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 06;327(7414):557–60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
89 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure manual, Appendix XII. Summary of evidence table for evidence reviews. Rockville, MD: U.S. Preventive Services Task Force; 2017. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual/procedure-manual-appendix-xii-summary-evidence-table-evidence-reviews. Accessed October 13, 2021.
90 U.S. Preventive Services Task Force. Atrial fibrillation: screening: final research plan. Rockville, MD: U.S. Preventive Services Task Force; 2020. https://www.uspreventiveservicestaskforce.org/uspstf/document/final-research-plan/screening-atrial-fibrillation. Accessed October 13, 2021.
91 Hobbs FD, Fitzmaurice DA, Mant J, . A randomised controlled trial and cost-effectiveness study of systematic screening (targeted and total population screening) versus routine practice for the detection of atrial fibrillation in people aged 65 and over. The SAFE study. Health Technol Assess. 2005 Oct;9(40):iii–iv, ix–x, 1–74. PMID: 16202350.16202350
92 Fitzmaurice DA, McCahon D, Baker J, . Is screening for AF worthwhile? Stroke risk in a screened population from the SAFE study. Fam Pract. 2014 Jun;31(3):298–302. doi: 10.1093/fampra/cmu011. PMID: 24728774.24728774
93 Fitzmaurice DA, Hobbs FD, Jowett S, . Screening versus routine practice in detection of atrial fibrillation in patients aged 65 or over: cluster randomised controlled trial. BMJ. 2007 Aug 25;335(7616):383. doi: 10.1136/bmj.39280.660567.55. PMID: 17673732.17673732
94 Mant J, Fitzmaurice DA, Hobbs FD, . Accuracy of diagnosing atrial fibrillation on electrocardiogram by primary care practitioners and interpretative diagnostic software: analysis of data from screening for atrial fibrillation in the elderly (SAFE) trial. BMJ. 2007 Aug 25;335(7616):380. doi: 10.1136/bmj.39227.551713.AE. PMID: 17604299.17604299
95 Swancutt D, Hobbs R, Fitzmaurice D, . A randomised controlled trial and cost effectiveness study of systematic screening (targeted and total population screening) versus routine practice for the detection of atrial fibrillation in the over 65s: (SAFE) [ISRCTN19633732]. BMC Cardiovasc Disord. 2004 Jul 29;4:12. doi: 10.1186/1471-2261-4-12. PMID: 15283871.15283871
96 van Walraven C, Hart RG, Connolly S, . Effect of age on stroke prevention therapy in patients with atrial fibrillation: the atrial fibrillation investigators. Stroke. 2009 Apr;40(4):1410–6. doi: 10.1161/strokeaha.108.526988. PMID: 19182090.19182090
97 Ezekowitz MD, Bridgers SL, James KE, . Warfarin in the prevention of stroke associated with nonrheumatic atrial fibrillation. Veterans Affairs Stroke Prevention in Nonrheumatic Atrial Fibrillation Investigators. N Engl J Med. 1992 Nov 12;327(20):1406–12. doi: 10.1056/nejm199211123272002. PMID: 1406859.1406859
98 Stroke prevention in atrial fibrillation study. Final results. Circulation. 1991 Aug;84(2):527–39. PMID: 1860198.1860198
99 Connolly SJ, Laupacis A, Gent M, . Canadian Atrial Fibrillation Anticoagulation (CAFA) Study. J Am Coll Cardiol. 1991 Aug;18(2):349–55. PMID: 1856403.1856403
100 Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators. The effect of low-dose warfarin on the risk of stroke in patients with nonrheumatic atrial fibrillation. N Engl J Med. 1990 Nov 29;323(22):1505–11. doi: 10.1056/nejm199011293232201. PMID: 2233931.2233931
101 Stroke Prevention in Atrial Fibrillation Study Group Investigators. Preliminary report of the Stroke Prevention in Atrial Fibrillation Study. N Engl J Med. 1990 Mar 22;322(12):863–8. doi: 10.1056/nejm199003223221232. PMID: 2407959.2407959
102 Petersen P, Boysen G, Godtfredsen J, . Placebo-controlled, randomised trial of warfarin and aspirin for prevention of thromboembolic complications in chronic atrial fibrillation. The Copenhagen AFASAK study. Lancet. 1989 Jan 28;1(8631):175–9. PMID: 2563096.2563096
103 Coleman CI, Sobieraj DM, Winkler S, . Effect of pharmacological therapies for stroke prevention on major gastrointestinal bleeding in patients with atrial fibrillation (Structured abstract). Int J Clin Pract. 2012;66(1):53–63. PMID: DARE-12012000802.22093613
104 Aguilar Maria I, Hart R. Oral anticoagulants for preventing stroke in patients with non-valvular atrial fibrillation and no previous history of stroke or transient ischemic attacks. Cochrane Database Syst Rev. 2005(3) doi: 10.1002/14651858.CD001927.pub2. PMID: CD001927.
105 Morgan S, Mant D. Randomised trial of two approaches to screening for atrial fibrillation in UK general practice. Br J Gen Pract. 2002 May;52(478):373–4, 7–80. PMID: 12014534.12014534
106 Tereshchenko LG, Henrikson CA, Cigarroa J, . Comparative effectiveness of interventions for stroke prevention in atrial fibrillation: a network meta-analysis. J Am Heart Assoc. 2016 May;5(5) doi: 10.1161/jaha.116.003206. PMID: 27207998.27207998
107 Risk factors for stroke and efficacy of antithrombotic therapy in atrial fibrillation. Analysis of pooled data from five randomized controlled trials. Arch Intern Med. 1994 Jul 11;154(13):1449–57. PMID: 8018000.8018000
108 Halcox JPJ, Wareham K, Cardew A, . Assessment of remote heart rhythm sampling using the AliveCor heart monitor to screen for atrial fibrillation: the REHEARSE-AF study. Circulation. 2017 Nov 7;136(19):1784–94. doi: 10.1161/circulationaha.117.030583. PMID: 28851729.28851729
109 Steinhubl SR, Waalen J, Edwards AM, . Effect of a home-based wearable continuous ECG monitoring patch on detection of undiagnosed atrial fibrillation: the mSToPS randomized clinical trial. JAMA. 2018 Jul 10;320(2):146–55. doi: 10.1001/jama.2018.8102. PMID: 29998336.29998336
110 Bassand JP, Accetta G, Al Mahmeed W, . Risk factors for death, stroke, and bleeding in 28,628 patients from the GARFIELD-AF registry: rationale for comprehensive management of atrial fibrillation. PLoS One. 2018;13(1):e0191592. doi: 10.1371/journal.pone.0191592. PMID: 29370229.29370229
111 Kaasenbrood F, Hollander M, de Bruijn SH, . Opportunistic screening versus usual care for diagnosing atrial fibrillation in general practice: a cluster randomised controlled trial. Br J Gen Pract. 2020 Jan 27 doi: 10.3399/bjgp20X708161. PMID: 31988084.31988084
112 Himmelreich JCL, Karregat EPM, Lucassen WAM, . Diagnostic accuracy of a smartphone-operated, single-lead electrocardiography device for detection of rhythm and conduction abnormalities in primary care. Ann Fam Med. 2019 Sep;17(5):403–11. doi: 10.1370/afm.2438. PMID: 31501201.31501201
113 Kearley K, Selwood M, Van den Bruel A, . Triage tests for identifying atrial fibrillation in primary care: a diagnostic accuracy study comparing single-lead ECG and modified BP monitors. BMJ Open. 2014 May 2;4(5):e004565. doi: 10.1136/bmjopen-2013-004565. PMID: 24793250.24793250
114 Wiesel J, Arbesfeld B, Schechter D. Comparison of the Microlife blood pressure monitor with the Omron blood pressure monitor for detecting atrial fibrillation. Am J Cardiol. 2014 Oct 1;114(7):1046–8. doi: 10.1016/j.amjcard.2014.07.016. PMID: 25212546.25212546
115 Marazzi G, Iellamo F, Volterrani M, . Comparison of Microlife BP A200 Plus and Omron M6 blood pressure monitors to detect atrial fibrillation in hypertensive patients. Adv Ther. 2012 Jan;29(1):64–70. doi: 10.1007/s12325-011-0087-0. PMID: 22198902.22198902
116 Uittenbogaart SB, Verbiest-van Gurp N, Lucassen WAM, . Opportunistic screening versus usual care for detection of atrial fibrillation in primary care: cluster randomised controlled trial. BMJ. 2020 Sep 16;370:m3208. doi: 10.1136/bmj.m3208. PMID: 32938633.32938633
117 Sabar MI, Ara F, Henderson A, . A study to assess a novel automated electrocardiogram technology in screening for atrial fibrillation. Pacing Clin Electrophysiol. 2019 Oct;42(10):1383–9. doi: 10.1111/pace.13800. PMID: 31482579.31482579
118 Donal E, Lund LH, Oger E, . New echocardiographic predictors of clinical outcome in patients presenting with heart failure and a preserved left ventricular ejection fraction: a subanalysis of the Ka (Karolinska) Ren (Rennes) Study. Eur J Heart Fail. 2015 Jul;17(7):680–8. doi: 10.1002/ejhf.291. PMID: 26033771.26033771
119 Lahtela H, Rubboli A, Schlitt A, . Heparin bridging vs. uninterrupted oral anticoagulation in patients with Atrial Fibrillation undergoing Coronary Artery Stenting. Results from the AFCAS registry. Circ J. 2012;76(6):1363–8. PMID: 22447005.22447005
120 Van Gelder IC, Hagens VE, Bosker HA, . A comparison of rate control and rhythm control in patients with recurrent persistent atrial fibrillation. N Engl J Med. 2002 Dec 5;347(23):1834–40. doi: 10.1056/NEJMoa021375. PMID: 12466507.12466507
121 EAFT Study Group (European Atrial Fibrillation Trial). Secondary prevention in non-rheumatic atrial fibrillation after transient ischaemic attack or minor stroke. Lancet. 1993;342:1255.7901582
122 Bogun F, Anh D, Kalahasty G, . Misdiagnosis of atrial fibrillation and its clinical consequences. Am J Med. 2004 Nov 1;117(9):636–42. doi: 10.1016/j.amjmed.2004.06.024. PMID: 15501200.15501200
123 Jonas DE, Reddy S, Middleton JC, . Screening for cardiovascular disease risk with resting or exercise electrocardiography: evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2018 Jun 12;319(22):2315–28. doi: 10.1001/jama.2018.6897. PMID: 29896633.29896633
124 Svendsen JH, Diederichsen SZ, Højberg S, . Implantable loop recorder detection of atrial fibrillation to prevent stroke (The LOOP Study): a randomised controlled trial. Lancet. 2021 Aug 27 doi: 10.1016/s0140-6736(21)01698-6. PMID: 34469766.34469766
125 Chen LY, Chung MK, Allen LA, . Atrial fibrillation burden: moving beyond atrial fibrillation as a binary entity: a scientific statement from the American Heart Association. Circulation. 2018 May 15;137(20):e623–e44. doi: 10.1161/cir.0000000000000568. PMID: 29661944.29661944
126 Armstrong PW, Westerhout CM. Composite end points in clinical research: a time for reappraisal. Circulation. 2017 Jun 6;135(23):2299–307. doi: 10.1161/circulationaha.117.026229. PMID: 28584030.28584030
127 Choi SW, Cheung CW. The case of the misleading composite - one outcome is better than two. Anaesthesia. 2016 Sep;71(9):1101–3. doi: 10.1111/anae.13590. PMID: 27440444.27440444
128 Gómez G, Gómez-Mateu M, Dafni U. Informed choice of composite end points in cardiovascular trials. Circ Cardiovasc Qual Outcomes. 2014 Jan;7(1):170–8. doi: 10.1161/circoutcomes.113.000149. PMID: 24425702.24425702
129 Bunch TJ, Steinberg BA. Revisiting rate versus rhythm control in atrial fibrillation - timing matters. N Engl J Med. 2020 Oct 1;383(14):1383–4. doi: 10.1056/NEJMe2027180. PMID: 32865379.32865379
130 Heartline. You’re Invited to Join the Heartline Study. 2020. https://www.heartline.com/. Accessed October 13, 2021.
131 Perez MV, Mahaffey KW, Hedlin H, . Large-scale assessment of a smartwatch to identify atrial fibrillation. N Engl J Med. 2019 Nov 14;381(20):1909–17. doi: 10.1056/NEJMoa1901183. PMID: 31722151.31722151
132 Guo Y, Wang H, Zhang H, . Mobile photoplethysmographic technology to detect atrial fibrillation. J Am Coll Cardiol. 2019 Nov 12;74(19):2365–75. doi: 10.1016/j.jacc.2019.08.019. PMID: 31487545.31487545
133 Guo Y, Wang H, Zhang H, . Population-based screening or targeted screening based on initial clinical risk assessment for atrial fibrillation: a report from the Huawei Heart Study. J Clin Med. 2020 May 15;9(5) doi: 10.3390/jcm9051493. PMID: 32429241.32429241
134 Gage BF, Waterman AD, Shannon W, . Validation of clinical classification schemes for predicting stroke: results from the National Registry of Atrial Fibrillation. JAMA. 2001 Jun 13;285(22):2864–70. PMID: 11401607.11401607
135 Lip GY, Nieuwlaat R, Pisters R, . Refining clinical risk stratification for predicting stroke and thromboembolism in atrial fibrillation using a novel risk factor-based approach: the euro heart survey on atrial fibrillation. Chest. 2010 Feb;137(2):263–72. doi: 10.1378/chest.09-1584. PMID: 19762550.19762550
136 Piccini JP, Stevens SR, Chang Y, . Renal dysfunction as a predictor of stroke and systemic embolism in patients with nonvalvular atrial fibrillation: validation of the R(2)CHADS(2) index in the ROCKET AF (Rivaroxaban Once-daily, oral, direct factor Xa inhibition Compared with vitamin K antagonism for prevention of stroke and Embolism Trial in Atrial Fibrillation) and ATRIA (AnTicoagulation and Risk factors In Atrial fibrillation) study cohorts. Circulation. 2013 Jan 15;127(2):224–32. doi: 10.1161/circulationaha.112.107128. PMID: 23212720.23212720
137 Hippisley-Cox J, Coupland C, Brindle P. Derivation and validation of QStroke score for predicting risk of ischaemic stroke in primary care and comparison with other risk scores: a prospective open cohort study. BMJ. 2013;346:f2573. doi: 10.1136/bmj.f2573. PMID: 23641033.23641033
138 Singer DE, Chang Y, Borowsky LH, . A new risk scheme to predict ischemic stroke and other thromboembolism in atrial fibrillation: the ATRIA study stroke risk score. J Am Heart Assoc. 2013 Jun 21;2(3):e000250. doi: 10.1161/JAHA.113.000250. PMID: 23782923.23782923
139 Pisters R, Lane DA, Nieuwlaat R, . A novel user-friendly score (HAS-BLED) to assess 1-year risk of major bleeding in patients with atrial fibrillation: the Euro Heart Survey. Chest. 2010 Nov;138(5):1093–100. doi: 10.1378/chest.10-0134. PMID: 20299623.20299623
140 Gage BF, Yan Y, Milligan PE, . Clinical classification schemes for predicting hemorrhage: results from the National Registry of Atrial Fibrillation (NRAF). Am Heart J. 2006 Mar;151(3):713–9. doi: 10.1016/j.ahj.2005.04.017. PMID: 16504638.16504638
141 Fang MC, Go AS, Chang Y, . A new risk scheme to predict warfarin-associated hemorrhage: the ATRIA (Anticoagulation and Risk Factors in Atrial Fibrillation) Study. J Am Coll Cardiol. 2011 Jul 19;58(4):395–401. doi: 10.1016/j.jacc.2011.03.031. PMID: 21757117.21757117
142 National Institute for Health and Care Excellence. Atrial fibrillation: the management of atrial fibrillation. National Institute for Health and Care Excellence (UK). London: 2014.
143 Culebras A, Messe SR, Chaturvedi S, . Summary of evidence-based guideline update: prevention of stroke in nonvalvular atrial fibrillation: report of the Guideline Development Subcommittee of the American Academy of Neurology. Neurology. 2014 Feb 25;82(8):716–24.24566225
144 Antithrombotic agents for the prevention of stroke and systemic embolism in patients with atrial fibrillation. Canadian Agency for Drugs and Technologies in Health. Ottawa (ON): 2013.
145 Scottish Intercollegiate Guidelines Network (SIGN). SIGN 129: Antithrombotics: indications and management. Edinburgh: Healthcare Improvement Scotland; 2013.
146 Jonas DE, Kahwati LC, Yun JDY, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Screening for Atrial Fibrillation With Electrocardiography: An Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2018.
147 Nyaga VN, Arbyn M, Aerts M. Metaprop: a Stata command to perform meta-analysis of binomial data. Arch Public Health. 2014;72(1):39. doi: 10.1186/2049-3258-72-39. PMID: 25810908.25810908
148 Lowres N, Olivier J, Chao TF, . Estimated stroke risk, yield, and number needed to screen for atrial fibrillation detected through single time screening: a multicountry patient-level meta-analysis of 141,220 screened individuals. PLoS Med. 2019 Sep;16(9):e1002903. doi: 10.1371/journal.pmed.1002903. PMID: 31553733.31553733
149 Turakhia MP, Ullal AJ, Hoang DD, . Feasibility of extended ambulatory electrocardiogram monitoring to identify silent atrial fibrillation in high-risk patients: the Screening Study for Undiagnosed Atrial Fibrillation (STUDY-AF). Clin Cardiol. 2015 May;38(5):285–92. doi: 10.1002/clc.22387. PMID: 25873476.25873476
150 Meschia JF, Merrill P, Soliman EZ, . Racial disparities in awareness and treatment of atrial fibrillation: the REasons for Geographic and Racial Differences in Stroke (REGARDS) study. Stroke. 2010 Apr;41(4):581–7. doi: 10.1161/strokeaha.109.573907. PMID: 20190000.20190000
151 Grubb NR, Elder D, Broadhurst P, . Atrial fibrillation case finding in over 65s with cardiovascular risk factors - results of initial Scottish clinical experience. Int J Cardiol. 2019 Aug 1;288:94–9. doi: 10.1016/j.ijcard.2019.03.062. PMID: 31047704.31047704
152 Engdahl J, Andersson L, Mirskaya M, . Stepwise screening of atrial fibrillation in a 75-year-old population: implications for stroke prevention. Circulation. 2013 Feb 26;127(8):930–7. doi: 10.1161/circulationaha.112.126656. PMID: 23343564.23343564
153 Kim NR, Choi CK, Kim HS, . Screening for atrial fibrillation using a smartphone-based electrocardiogram in Korean elderly. Chonnam Med J. 2020 Jan;56(1):50–4. doi: 10.4068/cmj.2020.56.1.50. PMID: 32021842.32021842
154 Furberg CD, Psaty BM, Manolio TA, . Prevalence of atrial fibrillation in elderly subjects (the Cardiovascular Health Study). Am J Cardiol. 1994 Aug 01;74(3):236–41. PMID: 8037127.8037127
155 Bacchini M, Bonometti S, Del Zotti F, . Opportunistic screening for atrial fibrillation in the pharmacies: a population-based cross-sectional study. High Blood Press Cardiovasc Prev. 2019 Aug;26(4):339–44. doi: 10.1007/s40292-019-00334-4. PMID: 31385256.31385256
156 Berge T, Lyngbakken MN, Ihle-Hansen H, . Prevalence of atrial fibrillation and cardiovascular risk factors in a 63-65 years old general population cohort: the Akershus Cardiac Examination (ACE) 1950 Study. BMJ Open. 2018 Aug 1;8(7):e021704. doi: 10.1136/bmjopen-2018-021704. PMID: 30068617.30068617
157 Busch MC, Gross S, Alte D, . Impact of atrial fibrillation detected by extended monitoring-a population-based cohort study. Ann Noninvasive Electrocardiol. 2017 Nov;22(6) doi: 10.1111/anec.12453. PMID: 28440600.28440600
158 Chan N-y, Choy C-c. Screening for atrial fibrillation in 13 122 Hong Kong citizens with smartphone electrocardiogram. Heart. 2016 October 12, 2016 doi: 10.1136/heartjnl-2016-309993.
159 Chan NY, Choy CC, Chan CK, . Effectiveness of a nongovernmental organization-led large-scale community atrial fibrillation screening program using the smartphone electrocardiogram: An observational cohort study. Heart Rhythm. 2018 Sep;15(9):1306–11. doi: 10.1016/j.hrthm.2018.06.006. PMID: 29890321.29890321
160 Claes N, Van Laethem C, Goethals M, . Prevalence of atrial fibrillation in adults participating in a large-scale voluntary screening programme in Belgium. Acta Cardiol. 2012 Jun;67(3):273–8. doi: 10.2143/ac.67.3.2160714. PMID: 22870733.22870733
161 Diouf I, Magliano DJ, Carrington MJ, . Prevalence, incidence, risk factors and treatment of atrial fibrillation in Australia: the Australian Diabetes, Obesity and Lifestyle (AusDiab) longitudinal, population cohort study. Int J Cardiol. 2016 Feb 15;205:127–32. doi: 10.1016/j.ijcard.2015.12.013. PMID: 26730844.26730844
162 Doliwa PS, Frykman V, Rosenqvist M. Short-term ECG for out of hospital detection of silent atrial fibrillation episodes. Scand Cardiovasc J. 2009 Jun;43(3):163–8. doi: 10.1080/14017430802593435. PMID: 19096977.19096977
163 Frewen J, Finucane C, Cronin H, . Factors that influence awareness and treatment of atrial fibrillation in older adults. QJM. 2013 May;106(5):415–24. doi: 10.1093/qjmed/hct060. PMID: 23504411.23504411
164 Gudmundsdottir KK, Fredriksson T, Svennberg E, . Stepwise mass screening for atrial fibrillation using N-terminal B-type natriuretic peptide: the STROKESTOP II study. Europace. 2020 Jan 1;22(1):24–32. doi: 10.1093/europace/euz255. PMID: 31790147.31790147
165 Kropp CM, Huber NL, Sager D, . Mobile-ECG screening in rural pharmacies: rates of atrial fibrillation and associated risk factors. Heart Lung. 2020 Feb 1 doi: 10.1016/j.hrtlng.2020.01.004. PMID: 32014313.32014313
166 Kvist LM, Vinter N, Urbonaviciene G, . Diagnostic accuracies of screening for atrial fibrillation by cardiac nurses versus radiographers. Open Heart. 2019;6(1):e000942. doi: 10.1136/openhrt-2018-000942. PMID: 30997131.30997131
167 Lindberg T, Bohman DM, Elmstahl S, . Prevalence of unknown and untreated arrhythmias in an older outpatient population screened by wireless long-term recording ECG. Clin Interv Aging. 2016;11:1083–90. doi: 10.2147/cia.s110532. PMID: 27570450.27570450
168 Lowres N, Neubeck L, Salkeld G, . Feasibility and cost-effectiveness of stroke prevention through community screening for atrial fibrillation using iPhone ECG in pharmacies. The SEARCH-AF study. Thromb Haemost. 2014 Jun;111(6):1167–76. doi: 10.1160/th14-03-0231. PMID: 24687081.24687081
169 Mandalenakis Z, Lennartsson ST, Fu M, . The incidence of atrial fibrillation and the added value of thumb ECG for detecting new cases. Scand Cardiovasc J. 2018 Oct;52(5):256–61. doi: 10.1080/14017431.2018.1509120. PMID: 30303692.30303692
170 Omboni S, Verberk WJ. Opportunistic screening of atrial fibrillation by automatic blood pressure measurement in the community. BMJ Open. 2016 Apr 12;6(4):e010745. doi: 10.1136/bmjopen-2015-010745. PMID: 27072571.27072571
171 Schnabel RB, Wilde S, Wild PS, . Atrial fibrillation: its prevalence and risk factor profile in the German general population. Dtsch Arztebl Int. 2012 Apr;109(16):293–9. doi: 10.3238/arztebl.2012.0293. PMID: 22577476.22577476
172 Zaprutko T, Zaprutko J, Baszko A, . Feasibility of atrial fibrillation screening with mobile health technologies at pharmacies. J Cardiovasc Pharmacol Ther. 2020 Mar;25(2):142–51. doi: 10.1177/1074248419879089. PMID: 31578088.31578088
173 Bury G, Swan D, Cullen W, . Screening for atrial fibrillation in general practice: a national, cross-sectional study of an innovative technology. Int J Cardiol. 2015 Jan 15;178:247–52. doi: 10.1016/j.ijcard.2014.10.037. PMID: 25464263.25464263
174 Chan PH, Wong CK, Pun L, . Diagnostic performance of an automatic blood pressure measurement device, Microlife WatchBP Home A, for atrial fibrillation screening in a real-world primary care setting. BMJ Open. 2017 Jun 15;7(6):e013685. doi: 10.1136/bmjopen-2016-013685. PMID: 28619766.28619766
175 Chan PH, Wong CK, Pun L, . Head-to-head comparison of the AliveCor Heart monitor and Microlife WatchBP Office AFIB for atrial fibrillation screening in a primary care setting. Circulation. 2017 Jan 3;135(1):110–2. doi: 10.1161/circulationaha.116.024439. PMID: 28028066.28028066
176 Chan PH, Wong CK, Poh YC, . Diagnostic performance of a smartphone-based photoplethysmographic application for atrial fibrillation screening in a primary care setting. J Am Heart Assoc. 2016 Jul 21;5(7) doi: 10.1161/jaha.116.003428. PMID: 27444506.27444506
177 Clua-Espuny JL, Lechuga-Duran I, Bosch-Princep R, . Prevalence of undiagnosed atrial fibrillation and of that not being treated with anticoagulant drugs: the AFABE study. Rev Esp Cardiol (Engl Ed). 2013 Jul;66(7):545–52. doi: 10.1016/j.rec.2013.03.003. PMID: 24776203.24776203
178 Deif B, Lowres N, Freedman SB. Screening for atrial fibrillation above age 65 detects an asymptomatic subset at high risk of stroke. Int J Cardiol. 2013 Apr 15;164(3):371–2. doi: 10.1016/j.ijcard.2012.08.002. PMID: 22964080.22964080
179 Ghazal F, Theobald H, Rosenqvist M, . Validity of daily self-pulse palpation for atrial fibrillation screening in patients 65 years and older: A cross-sectional study. PLoS Med. 2020 Mar;17(3):e1003063. doi: 10.1371/journal.pmed.1003063. PMID: 32231369.32231369
180 Ghazal F, Theobald H, Rosenqvist M, . Assessment of N-terminal pro-B-type natriuretic peptide level in screening for atrial fibrillation in primary health care. PLoS One. 2019;14(2):e0212974. doi: 10.1371/journal.pone.0212974. PMID: 30807614.30807614
181 Hill JD, Mottram EM, Killeen PD. Study of the prevalence of atrial fibrillation in general practice patients over 65 years of age. J R Coll Gen Pract. 1987 Apr;37(297):172–3. PMID: 3694577.3694577
182 Kaasenbrood F, Hollander M, Rutten FH, . Yield of screening for atrial fibrillation in primary care with a hand-held, single-lead electrocardiogram device during influenza vaccination. Europace. 2016 Oct;18(10):1514–20. doi: 10.1093/europace/euv426. PMID: 26851813.26851813
183 Orchard J, Lowres N, Freedman SB, . Screening for atrial fibrillation during influenza vaccinations by primary care nurses using a smartphone electrocardiograph (iECG): A feasibility study. Eur J Prev Cardiol. 2016 Oct;23(2 suppl):13–20. doi: 10.1177/2047487316670255. PMID: 27892421.27892421
184 Orchard J, Neubeck L, Freedman B, . eHealth tools to provide structured assistance for atrial fibrillation screening, management, and guideline-recommended therapy in metropolitan general practice: the AF - SMART Study. J Am Heart Assoc. 2019 Jan 8;8(1):e010959. doi: 10.1161/jaha.118.010959. PMID: 30590964.30590964
185 Quinn GR, Severdija ON, Chang Y, . Methodologic differences across studies of patients with atrial fibrillation lead to varying estimates of stroke risk. J Am Heart Assoc. 2018 Jun 9;7(12) doi: 10.1161/jaha.117.007537. PMID: 29886417.29886417
186 Salvatori V, Becattini C, Laureti S, . Holter monitoring to detect silent atrial fibrillation in high-risk subjects: the Perugia General Practitioner Study. Intern Emerg Med. 2015 Aug;10(5):595–601. doi: 10.1007/s11739-015-1241-5. PMID: 25944128.25944128
187 Tieleman RG, Plantinga Y, Rinkes D, . Validation and clinical use of a novel diagnostic device for screening of atrial fibrillation. Europace. 2014 Sep;16(9):1291–5. doi: 10.1093/europace/euu057. PMID: 24825766.24825766
188 Wheeldon NM, Tayler DI, Anagnostou E, . Screening for atrial fibrillation in primary care. Heart. 1998 Jan;79(1):50–5. PMID: 9505919.9505919
189 Martinez C, Katholing A, Freedman SB. Adverse prognosis of incidentally detected ambulatory atrial fibrillation. A cohort study. Thromb Haemost. 2014 Aug;112(2):276–86. doi: 10.1160/th4-04-0383. PMID: 24953051.24953051
190 Thind M, Holmes DN, Badri M, . Embolic and other adverse outcomes in symptomatic versus asymptomatic patients with atrial fibrillation (from the ORBIT-AF Registry). Am J Cardiol. 2018 Nov 15;122(10):1677–83. doi: 10.1016/j.amjcard.2018.07.045. PMID: 30227964.30227964
191 Chen JY, Zhang AD, Lu HY, . CHADS2 versus CHA2DS2-VASc score in assessing the stroke and thromboembolism risk stratification in patients with atrial fibrillation: a systematic review and meta-analysis. J Geriatr Cardiol. 2013 Sep;10(3):258–66. doi: 10.3969/j.issn.1671-5411.2013.03.004. PMID: 24133514.24133514
192 Orchard J, Li J, Freedman B, . Atrial fibrillation screen, management, and guideline-recommended therapy in the rural primary care setting: a cross-sectional study and cost-effectiveness analysis of ehealth tools to support all stages of screening. J Am Heart Assoc. 2020 Sep 15;9(18):e017080. doi: 10.1161/jaha.120.017080. PMID: 32865129.32865129
193 Healey JS, Alings M, Ha A, . Subclinical atrial fibrillation in older patients. Circulation. 2017 Oct 3;136(14):1276–83. doi: 10.1161/circulationaha.117.028845. PMID: 28778946.28778946
194 Charitos EI, Pürerfellner H, Glotzer TV, . Clinical classifications of atrial fibrillation poorly reflect its temporal persistence: insights from 1,195 patients continuously monitored with implantable devices. J Am Coll Cardiol. 2014 Jul 1;63(25 Pt A):2840–8. doi: 10.1016/j.jacc.2014.04.019. PMID: 24814497.24814497
195 Healey JS, Connolly SJ, Gold MR, . Subclinical atrial fibrillation and the risk of stroke. N Engl J Med. 2012 Jan 12;366(2):120–9. doi: 10.1056/NEJMoa1105575. PMID: 22236222.22236222
196 Todd D, Hernandez-Madrid A, Proclemer A, . How are arrhythmias detected by implanted cardiac devices managed in Europe? Results of the European Heart Rhythm Association Survey. Europace. 2015 Sep;17(9):1449–53. doi: 10.1093/europace/euv310. PMID: 26443791.26443791
197 Freedman B, Boriani G, Glotzer TV, . Management of atrial high-rate episodes detected by cardiac implanted electronic devices. Nat Rev Cardiol. 2017 Dec;14(12):701–14. doi: 10.1038/nrcardio.2017.94. PMID: 28682320.28682320
198 Kirchhof P, Benussi S, Kotecha D, . 2016 ESC guidelines for the management of atrial fibrillation developed in collaboration with EACTS. Eur Heart J. 2016 Oct 7;37(38):2893–962. doi: 10.1093/eurheartj/ehw210. PMID: 27567408.27567408
199 Glotzer TV, Hellkamp AS, Zimmerman J, . Atrial high rate episodes detected by pacemaker diagnostics predict death and stroke: report of the Atrial Diagnostics Ancillary Study of the MOde Selection Trial (MOST). Circulation. 2003 Apr 1;107(12):1614–9. doi: 10.1161/01.Cir.0000057981.70380.45. PMID: 12668495.12668495
200 Hindricks G, Pokushalov E, Urban L, . Performance of a new leadless implantable cardiac monitor in detecting and quantifying atrial fibrillation: Results of the XPECT trial. Circ Arrhythm Electrophysiol. 2010 Apr;3(2):141–7. doi: 10.1161/circep.109.877852. PMID: 20160169.20160169
201 Pollak WM, Simmons JD, Interian A, Jr., . Clinical utility of intraatrial pacemaker stored electrograms to diagnose atrial fibrillation and flutter. Pacing Clin Electrophysiol. 2001 Apr;24(4 Pt 1):424–9. doi: 10.1046/j.1460-9592.2001.00424.x. PMID: 11341078.11341078
202 Boriani G, Glotzer TV, Santini M, . Device-detected atrial fibrillation and risk for stroke: an analysis of >10,000 patients from the SOS AF project (Stroke preventiOn Strategies based on Atrial Fibrillation information from implanted devices). Eur Heart J. 2014 Feb;35(8):508–16. doi: 10.1093/eurheartj/eht491. PMID: 24334432.24334432
203 Martin DT, Bersohn MM, Waldo AL, . Randomized trial of atrial arrhythmia monitoring to guide anticoagulation in patients with implanted defibrillator and cardiac resynchronization devices. Eur Heart J. 2015 Jul 7;36(26):1660–8. doi: 10.1093/eurheartj/ehv115. PMID: 25908774.25908774
204 Witt CT, Kronborg MB, Nohr EA, . Early detection of atrial high rate episodes predicts atrial fibrillation and thromboembolic events in patients with cardiac resynchronization therapy. Heart Rhythm. 2015 Dec;12(12):2368–75. doi: 10.1016/j.hrthm.2015.07.007. PMID: 26164377.26164377
205 Van Gelder IC, Healey JS, Crijns H, . Duration of device-detected subclinical atrial fibrillation and occurrence of stroke in ASSERT. Eur Heart J. 2017 May 1;38(17):1339–44. doi: 10.1093/eurheartj/ehx042. PMID: 28329139.28329139
206 Lopes RD, Alings M, Connolly SJ, . Rationale and design of the Apixaban for the Reduction of Thrombo-Embolism in Patients With Device-Detected Sub-Clinical Atrial Fibrillation (ARTESiA) trial. Am Heart J. 2017 Jul;189:137–45. doi: 10.1016/j.ahj.2017.04.008. PMID: 28625370.28625370
207 Kirchhof P, Blank BF, Calvert M, . Probing oral anticoagulation in patients with atrial high rate episodes: Rationale and design of the Non-vitamin K antagonist Oral anticoagulants in patients with Atrial High rate episodes (NOAH-AFNET 6) trial. Am Heart J. 2017 Aug;190:12–8. doi: 10.1016/j.ahj.2017.04.015. PMID: 28760205.28760205
208 Welton NJ, McAleenan A, Thom HH, . Screening strategies for atrial fibrillation: a systematic review and cost-effectiveness analysis. Health Technol Assess. 2017 May;21(29):1–236. doi: 10.3310/hta21290. PMID: 28629510.28629510
209 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001 Apr;20(3 Suppl):21–35. PMID: 11306229.11306229
210 Halcox JPJ, Wareham K. Response by Halcox and Wareham to letter regarding article, “assessment of remote heart rhythm sampling using the AliveCor Heart Monitor to screen for atrial fibrillation: the REHEARSE-AF Study”. Circulation. 2018 May 15;137(20):2193–4. doi: 10.1161/circulationaha.118.033773. PMID: 29760234.29760234
211 Hart RG, Benavente O, McBride R, . Antithrombotic therapy to prevent stroke in patients with atrial fibrillation: a meta-analysis. Ann Intern Med. 1999 Oct 05;131(7):492–501. PMID: 10507957.10507957