# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Howard Tracer, MD, AHRQ Medical Officer; Tracy Wolf, MD, MPH, Scientific Director, USPSTF Division, AHRQ; current and former members of the U.S. Preventive Services Task Force; expert peer reviewers Alvaro Alonso, MD, PhD, Emory University, Michael LeFevre, MD, MSPH, University of Missouri, Marco Perez, MD, Stanford University, Emma Svennberg, MD, PhD, Karolinska Institute, Larisa Tereshchenko, MD, PhD, Oregon Health & Sciences University; Federal partner reviewers (Centers for Disease Control and Prevention, National Heart, Lung, and Blood Institute, National Institute of Nursing Research); and RTI International–University of North Carolina EPC staff: Carol Woodell, BSPH; Christiane Voisin, MSLS; Sharon Barrell, MA; and Loraine Monroe.