# Chapter 4 Discussion

## Summary of Evidence

We identified some direct evidence evaluating the benefits (KQ 1) or harms (KQ 4) of screening for AF, but study limitations and applicability concerns may preclude definitive conclusions from this evidence. We identified evidence related to comparative diagnostic yield (KQ 2) and test accuracy (KQ 3) with heterogeneity in findings largely based on screening test strategy used. We identified no new evidence for benefits of treatment with anticoagulation (KQ 5) and identified one new observational study in addition to existing RCTs offering evidence for harms of anticoagulation (KQ 6). Table 6 summarizes the evidence synthesized in this report by KQ and provides our EPC’s assessment of the consistency, precision, study limitations, SOE, and applicability.

Table 6 Summary of Evidence, Screening for Atrial Fibrillation

Key Question | No. of Studies; Study Designs; (No. of Participants) | Summary of Findings | Consistency and Precision | Limitations | Strength of Evidence | Applicability
KQ 1 Benefits of screening | 1 RCT (27,975)^76–78^; Designed and to address KQ 1; 2 RCTs (1,857)^75,^ ^108^; Not designed to address KQ 1 but reported some health outcomes | Intermittent screening ECG twice daily for 2 weeks compared with no screening (1 RCT) ^76^ ^–^ ^78^; Composite benefit/harm endpoint:^*^; Events/100 person-years; 5.45 (5.29 to 5.61) vs. 5.68 (5.52 to 5.85); HR 0.96 (95% CI, 0.92 to 1.00; P=0.045);; Secondary outcomes HR (95% CI); - Ischemic stroke: 0.92 (0.83 to 1.01); - All-cause mortality: 0.96 (0.92 to 1.01); - Systemic embolism: 1.10 (0.76 to 1.59); - Ischemic stroke or systemic embolism: 0.92 (0.84 to 1.02) as randomized; 0.76 (0.67 to 0.85), as treated^†^; Intermittent screening ECG twice weekly for 12 months compared with no screening (1 RCT) ^108^; Composite of stroke, TIA, or systemic embolism: 6 (screened) vs. 10 (not screened) events; HR, 0.61; 95% CI, 0.22 to 1.69; Continuous ECG for 2 weeks, twice (total 4 weeks) compared with no screening (1 RCT) ^75^; 1 death (no screening), 2 ischemic strokes (screening), 1 TIA (screening), 0 systemic embolism | Consistent; imprecise^ǂ^ | Fair quality studies; in largest trial ~12% had known AF at baseline and only 51.3% of pesons randomized to screening participated, with no formal outcome assessment masking or central adjudication, primary outcome changed to a composite endpoint that included both benefit and harm outcomes; the other two trials were designed for KQ2 and not powered for health outcomes were not masked and had some measurement bias; reporting bias detected (one of the KQ2 studies was also designed to report KQ1 outcomes per trial registry entry but no results published) | Insufficient for addressing question of direct benefits of screening in persons without known AF | Adults with mean age in 70s and 80s with stroke risks in range recommended for anticoagulation if no contraindication; unclear applicability to screening in persons in primary care practice settings given population recruitment in only trial powered for health outcomes with clear differences between participants and nonparticipants that make predicting the bias from poor fidelity challenging
KQ 2 Identifying new cases of AF | 7 RCTs (74,386)^75–78,^ ^91–95,^ ^108,^ ^109,^ ^111,^ ^116^ | Various ECG screening compared with no screening:; One-time (3 RCTs): ARDs 0.06% to 0.6%; Intermittent (2 RCTs): ARDs 1.0% and 2.8%; Continuous (2 RCTs): ARDs 3.0% and 4.8% | Consistent,^§^ imprecise^ǁ^ | Fair quality, study inclusion/exclusion criteria focused on persons without known AF but most did not routinely assess for potential symptoms at study entry; fidelity low to modest in intervention arms | Moderate for increased detection, with higher detection seen with intermittent and continuous approaches | Applicable to older adults^¶^ without known AF for various screening modalities (one-time ECG, intermittent ECG, continuous patch ECG, pulse palpation combined with one-time ECG and oscillometric BP with AF detection)
KQ 2 Identifying new cases of AF | 2 RCTs (12,867)^91–95,^ ^105^ | ECG screening vs. pulse palpation reminders: ARD −0.02% in 1 trial and 0.3% in other trial (not statistically significant in either) | Consistent, imprecise | Fair quality; fidelity of pulse assessment was 29% in one trial and 69% in the other trial; fidelity of ECG screening was 73% in one trial and 53% in the other trial | Low for no difference in detection | Applicable to one-time ECG screening only, reminders in either paper charts or electronic records
KQ 2 Identifying new cases of AF | 1 RCT (9,869)^91–95^ | Pulse palpation reminders vs. no screening: ARD 0.6% (95% CI, 0.1% to 1.0%) | Single study, consistency unknown, precise | Fair quality; fidelity of pulse palpation in response to reminders was 69% | Low for increased detection | Older adults, reminders in either paper charts or electronic records
KQ 3 Accuracy of screening tests^#^ | 7 studies (4,544)^56,^ ^91,^ ^112–117^ | Various screening strategies compared with 12-lead ECG interpreted by cardiologist; Sensitivity range: 0.80 to 1.0^**^; Specificity range: 0.76 to 1.0. | Consistent^**^ precise | Four studies were fair quality due to concerns about applicability and selection bias related to method of enrollment in two studies, and lack of masking of index and reference test results in other study and reference standard in one study; most studies used one-time reference standards that may underestimate the prevalence of paroxysmal AF | Moderate to low depending on screening approach^††^ | Applicable to adults and for the following screening modalities: 6-lead ECG, GP-interpreted ECG (12-lead or less than 12-lead), oscillometric BP monitor with automatic AF detection, single-lead ECG with automatic AF detection
KQ 3 Accuracy of screening tests^#^ | 1 study (399)^75^ | Oscillometric BP monitor with AF detection feature compared with continuous ECG (4 weeks); Sensitivity 0.35, specificity 0.81 | Consistent^**^ precise | | Moderate to low depending on screening approach^††^
KQ 4 Harms of screening | 4 RCTs (43,633^ǂǂ^)^75–78,^ ^91–95,^ ^109^; 1 cohort (5,214)^§§^ | Anxiety (1 RCT): Mean scores not significantly different for invitation to ECG screening compared with pulse palpation reminders | Consistent; imprecise | Fair quality; anxiety scores not reported for comparison of invitation to ECG screening vs. no screening | Insufficient for anxiety | Applicable to older adults for the following screening modalities: GP-interpreted ECG (anxiety), continuous ECG monitoring patch (non-AF arrythmias, initiation of OACs and procedures, and skin irritation), intermittent ECG (initiation of OACs and procedures, bleeding outcomes)
KQ 4 Harms of screening | 4 RCTs (43,633^ǂǂ^)^75–78,^ ^91–95,^ ^109^; 1 cohort (5,214)^§§^ | Bleeding outcomes (2 RCTs); - 0 intracranial hemorrhages or major bleeding events after 6 months in the smaller of the RCTs; - In larger RCT after a median followup of 6.9 years, hemorrhagic stroke HR 0.88 (95% CI, 0.70 to 1.11) and hospitalization for major bleeding HR 0.98 (95% CI, 0.91 to 1.06) | Consistency unknown; imprecise | Fair quality; no centralized outcome adjudication, studies underpowered for rare events | Insufficient for bleeding outcomes
KQ 4 Harms of screening | 4 RCTs (43,633^ǂǂ^)^75–78,^ ^91–95,^ ^109^; 1 cohort (5,214)^§§^ | Non-AF arrhythmias (1 RCT and 1 cohort): detected in 2.6% of participants who received screening in cohort study and between 0 and 3.9% in the RCT depending on the type of arrhythmia; arrythmias were considered clinically actionable in both studies. | Consistent; precise | Fair quality; no masking | Moderate for increased detection, clinical consequences unknown^¶¶^
KQ 4 Harms of screening | 4 RCTs (43,633^ǂǂ^)^75–78,^ ^91–95,^ ^109^; 1 cohort (5,214)^§§^ | Initiation of anticoagulation, antiarrhythmics, and procedures (2 RCTs and1 cohort):^ǁǁ^ generally higher among participants who received screening compared with controls who did not get screened but only statistically significant for higher OAC use in 2 of the 3 studies. | Consistent; imprecise | Fair quality, no masking | Low for increased initiation, clinical consequences unknown^¶¶^
KQ 4 Harms of screening | 4 RCTs (43,633^ǂǂ^)^75–78,^ ^91–95,^ ^109^; 1 cohort (5,214)^§§^ | Skin irritation from patch (2 RCTs): 1.2% (95% CI, 0.5% to 2.7%) to 1.5% (95% CI, 1.1% to 2.0%) of participants | Consistent, precise | Fair quality; no masking, methods of ascertainment of skin irritation not reported | Moderate for increased skin irritation
KQ 5: Benefits of anti-coagulation treatment | 5 RCTs (2,415)^97–102^; 5 SRs^59,^ ^96,^ ^104,^ ^106,^ ^107^ | Warfarin (mean 1.5 years) vs. placebo/control:; Reduced all-cause mortality: pooled RR, 0.68; 95% CI, 0.50 to 0.93; Reduced ischemic stroke: pooled RR, 0.32; 95% CI, 0.20 to 0.51; Previously published SRs: Similar findings reported for warfarin compared with placebo. In a network meta-analysis, 4 DOACs^##^ were also more effective than placebo/control (adjusted ORs from 0.32 to 0.44). | Consistent, precise | All warfarin trials were fair quality and stopped early; 3 of the 5 trials were open label; 4 of the 5 trials had inadequate or unclear methods of allocation concealment. Reporting bias not detected.; Limitations of the network meta-analysis include (1) the lack of sensitivity analyses removing the studies with greater focus on secondary prevention, (2) limited ability to adjust for population characteristics (because some included studies were older and did not report CHADS_2_ scores, and they were estimated from baseline characteristics), and (3) heterogeneity of doses in intervention and control groups. | Moderate for benefit | Adults with AF and no history of stroke or TIA; uncertain whether the results are applicable to asymptomatic screen-detected persons with AF; Most participants had AF for more than a year and few had paroxysmal AF; estimates for lifelong treatment not available
KQ 6: Harms of anti-coagulation treatment | 5 RCTs (2,415)^97–102^; 6 SRs^59,^ ^96,^ ^103,^ ^104,^ ^106,^ ^107^; 1 prospective cohort study (26,628)^110^ | Warfarin (mean 1.5 years) vs. placebo/control:; Major bleeding: pooled RR, 1.8; 95% CI, 0.85 to 3.7; Intracranial hemorrhage: pooled RR, 1.9; 95% CI, 0.56 to 6.7; Previously published SRs: Similar findings reported for warfarin compared with placebo. In a network meta-analysis, the adjusted ORs for major bleeding comparing 4 DOACs^##^ with placebo/controls ranged from 1.38 to 2.21; CIs were wide and included the null.^***^; Anticoagulation compared with no antiocagulation over 2 years in cohort study: first bleeding event adjusted HR, 1.73 [95% CI, 1.33 to 2.25] | Consistent, imprecise^†††^ | All warfarin trials were fair quality and stopped early; 3 of the 5 trials were open label; 4 of the 5 trials had inadequate or unclear methods of allocation concealment; reporting bias not detected.; Limitations of the network meta-analysis include 1) the lack of sensitivity analyses removing the studies with greater focus on secondary prevention, 2) limited ability to adjust for population characteristics (because some included studies were older and did not report CHADS_2_ scores, and they were estimated from baseline characteristics), and 3) heterogeneity of doses in intervention and control groups. | Moderate for harm^ǂǂǂ^ | Adults with AF and no history of stroke or TIA

* Includes both benefit and harm outcomes: ischemic stroke, hemorrhagic stroke, systemic arterial embolism, all-cause death, and bleeding leading to hospitalization.

† When nonparticipants in the invitation to screening group were excluded (i.e., the as-treated analysis), a larger net benefit is observed; however, nonparticipants had worse socioeconomic status and lower education, higher alcohol use, and higher prevalence of comorbidities compared with participants that increase both stroke risk and risk for major bleeding. Thus, the as-treated analysis, while mitigating for poor intervention fidelity, could overestimate the benefit because participants were, on average, slightly younger and healthier.

ǂ For detecting a small benefit; based on optimal information size (OIS) criteria would require a trial with 36,896 participants to detect a relative risk reduction of 20 percent (RR, 0.80) given incidence in comparator group (2%) using two-tailed alpha=.05, power=0.8. Even more participants would be required to detect a smaller risk reduction.

§ We rated as consistent because of consistency in detection based on duration and intensity of screening strategy.

ǁ We rated as imprecise because the number of events (i.e., cases detected) was low across all studies, and the estimates for some individual studies were imprecise. Further, based on OIS criteria for average detection rate in no-screening group (1.2%), a single trial would require a sample size of 74,668 to detect a 20% relative increase in AF detection, two-tailed alpha=.05, power=0.8, and even more participants to detect a smaller increase in detection.

¶ Subgroup findings from one of the studies (SAFE trial)^91^ suggested that screening may not increase detection among females; no subgroup findings were reported by the other four studies, all of which included females; thus, this finding is uncertain.

# We did not include the Phillippsen et al study when considering SOE; this study compared a 72-hour Holter monitor to an insertable cardiac monitor that was left in place for a median of 588 days; the Holter monitor was placed approximately 1 month after the insertable monitor was placed, and it is uncertain whether AF events occurring after Holter monitoring period were prevalent cases or new onset.

** Consistent for oscillometric BP with automated AF detection algorithm with exception of one study^114^ for which sensitivity was reported as 0.30 for one brand of oscillometric monitor and for which study author disclosed conflict of interest. The evidence for single-lead ECG was less consistent, resulting in a low SOE for that strategy.

†† Moderate for oscillometric BP with automated AF detection and GP ECG interpretation, and 6-lead ECG; low for single-lead ECG with automated AF detection. Sensitivity influenced by reference standard used; continuous ECG reference standards are more likely to detect paroxysmal AF, resulting in lower sensitivity for one-time or intermittent index tests.

ǂǂ The number of participants included a subset of 1,940 of the 14,802 participants who were in the SAFE study, although study reporting relating to anxiety outcomes was unclear.

§§ Includes 1,738 participants who were also part of the mSToPS RCT (immediate and delayed monitoring groups combined).^109^

ǁǁ Findings were only statistically significantly higher in the cohort study, except for use of OACs, which was also significantly higher in the RCT (RR 4.4 [95% CI, 1.5 to 12.8]).

¶¶ The detection of clinically actionable non-AF arrythmias could be considered a benefit if it results in treatment or intervention that prevents an untoward outcome. However, it could be a harm if additional treatment or procedures (and related side effects or adverse events) were provided for an arrythmia that might never have caused symptoms or issues. Similarly, the initiation of treatments or subsequent procedures could be considered a benefit or harm depending on the health consequences of such actions.

## The four direct oral coagulants (DOACs) are apixaban, dabigatran, edoxaban, and rivaroxaban.

*** The network meta-analysis also found no statistically significant differences for the four DOACs in comparison to one another. Compared with VKAs, three of the DOACs (apixaban, dabigatran, and edoxaban) were associated with a lower risk of bleeding (range of ORs [95% CIs] from 0.64 [0.46 to 0.90] to 0.85 [0.65 to 1.11]), but the difference was only statistically significant for edoxaban (0.64 [0.46 to 0.90]). For rivaroxaban compared with VKAs, the odds of major bleeding was 1.03 (95% CI, 0.68 to 1.57).

††† Given the event rate in control group (~1%), a properly powered trial to detect a 60 percent increase in major bleeding (RR, 1.6) would require 11,838 participants (two-tailed alpha=.05, power= 0.8).

ǂǂǂ Although findings were imprecise and quality was fair, we graded the SOE as moderate considering evidence on dose response (with higher INRs increasing bleeding risk) and evidence on treatment of conditions other than AF that shows consistent evidence of bleeding risk.

Abbreviations: AF=atrial fibrillation; BP=blood pressure; CHA_2_DS_2_=Congestive heart failure, Hypertension, Age >=75 years, Diabetes mellitus, Prior stroke or TIA or thromboembolism; CI=confidence interval; DOAC=direct oral anticoagulant; ECG=electrocardiogram; GP=general practitioner; HR=hazard ratio; KQ=key question; mSToPS=mHealth Screening to Prevent Strokes; NA=not applicable; No.=number; OAC=oral anticoagulant; OIS=optimal information size; OR=odds ratio; RCT=randomized, controlled trial; RD=risk difference; RR=risk ratio; SAFE=Screening for Atrial Fibrillation in the Elderly; SOE=strength of evidence; SR=systematic review; TIA=transient ischemic attack; VKA=vitamin K antagonist; vs.=versus.

## Benefits of Screening (KQ 1)

STROKESTOP is the only included trial that was designed and powered to evaluate health outcomes such as stroke. Authors reported a small but statistically significant, difference favoring the screening group in the intention-to-treat analysis using a composite endpoint that included both benefit and harm outcomes, despite uptake of screening by only half of those randomized to the invitation to screening. Although the as-treated analysis reported for ischemic strokes and systemic thromboembolism can partially mitigate the bias resulting from poor uptake in the intention-to-treat analysis, the as-treated analysis is observational, and those who participated in screening were slightly younger and healthier than those who were invited but did not participate. Extrapolating findings from participants to nonparticipants is challenging because the characteristics that make someone likely to benefit from anticoagulation also increase bleeding risk from anticoagulation. Thus, understanding the benefits and harms across the full spectrum of the population is critical to drawing conclusions about the net benefit of an intervention. We also note that 12 percent of persons randomized in this study had known AF at baseline, limiting the applicability of this study to asymptomatic populations without known AF. Some of the benefit observed may be attributable to engaging persons with already known AF in care. The other two studies reporting health outcomes from screening compared with no screening were not powered for such outcomes; events were rare or absent in these studies, and they cannot contribute meaningfully to our understanding. We also note the potential for reporting bias for this KQ because one of the studies reporting KQ 2 outcomes (IDEAL-MD) had major cardiovascular events and all-cause mortality designated as secondary outcomes, but these have not been reported.^111^ For all of these reasons, we assessed the SOE for this KQ as insufficient for establishing the direct benefit of screening asymptomatic persons with known AF.

## Diagnostic Yield, Test Accuracy, and Harms of Screening (KQs 2, 3, and 4)

We found that screening with various ECG strategies can identify more cases of AF compared with no screening, but the difference in detection rate varied with method of screening used. Intermittent or continuous tests yielded more cases than one-time testing strategies, likely due to the identification of paroxysmal AF episodes. However, when one-time ECG screening was compared with pulse palpation reminders, no difference in cases identified was observed, though fidelity was quite low in the pulse palpation reminder group in one of the two studies.^105^ The studies using pulse palpation reminders included flags in the patient’s medical record encouraging providers (physicians and nurses) to conduct pulse palpation. Whether more instances of pulse palpation occurred in the pulse palpation reminder groups beyond usual vital sign measurement and physical exam in usual practice is not known. We rated the evidence for comparative diagnostic yield as consistent but imprecise and assessed the SOE as moderate for increased detection for screening with various ECG strategies compared with no screening. Our certainty is greater for intermittent and continuous screening strategies than for one-time screening approaches.

Critical to the identification of new cases of AF is the accuracy of tests used for screening: interpreting AF rhythms as normal results in false negatives (a reflection of a test’s sensitivity) and interpreting normal rhythms as AF results in false positives (a reflection of a test’s specificity). We found that the sensitivity and specificity of various one-time screening strategies based on ECG technology or based on oscillometric blood pressure monitoring with automated AF detection features varied in comparison to a reference standard of a 12-lead ECG interpreted by a cardiologist or a reference standard of continuous patch ECG. This variation may be the result of differences in the underlying populations tested, differences in thresholds used for defining positive index or reference tests, or fidelity with which screening was conducted in accordance with device manufacturer instructions. Further, the clinical importance of the variation within and across screening strategies is uncertain. We assessed the SOE as moderate for oscillometric blood pressure with automated AF detection features, six-lead ECG with automated detection features, and GP-interpreted ECGs and as low for single-lead ECG with automated AF detection features. Based on our findings from CQ 1 (Appendix B), if we assume the prevalence of undiagnosed AF in the population is 1.3 percent, then among 1,000 persons screened, the number of false-negative tests ranges from zero to nine, the number of false-positive tests ranges from zero to 237, the number of true positives ranges from four to 13, and the number of true negatives ranges from 750 to 987 depending on the strategy used. Given the relatively low prevalence of undiagnosed AF, screening may generate many more false positives relative to true positives and relative to false negatives. Estimates of true positives, true negatives, false positives, and false negatives for lower- and higher-prevalence settings are provided in Appendix H Table 2.

Potential harms of screening (KQ 4) include misinterpretation of ECGs leading to false reassurance (i.e., consequences of false-negative results) and false alarms (i.e., consequences of false-positive results) that lead to anxiety, further testing, and possible initiation of unnecessary treatment (e.g., ablation for rhythm control in asymptomatic persons) or known risks of appropriate treatment (i.e., bleeding from anticoagulation). Data from SCREEN-AF and STROKESTOP suggest no increased risk of serious bleeding events including hemorrhagic stroke, but such events were rare, and estimates were imprecise, precluding a definitive conclusion about bleeding harms from screening.

We identified one RCT that showed anxiety was not significantly different between participants who received ECG screening and those participants whose providers received pulse palpation reminders, but a direct comparison of screened to not screened participants was not reported. Although our review identified evidence to estimate the potential number of screening tests with inaccurate results (i.e., false positives and false negatives), evidence is limited with respect to the consequences of those inaccurate screening results. Whether false reassurance resulting from a false negative is clinically important depends on the benefits of treatment in screen-detected persons with AF. We also lack robust evidence on the consequences of false alarms resulting from false-positive results. False-positive results may result in patient anxiety; further testing; and, in some cases, initiation of unnecessary anticoagulation that confers a risk of major bleeding if positive screening results are not confirmed. A study using a database from a U.S. hospital that evaluated 2,298 ECGs (from 1,085 patients) with a computerized interpretation of AF found that ECGs from 382 patients (35%) had been misinterpreted; physicians did not correct the computerized misinterpretation and initiated inappropriate and potentially harmful treatments, and they pursued unnecessary additional testing for 92 patients (8.5%).^122^

Findings unrelated to the target condition are another potential result of screening. Based on the mSToPS study, the detection of medically actionable non-AF arrythmias was 2.6 percent among those screened with two rounds of 14-day continuous ambulatory ECG monitoring and was between 0 and 3.9 percent in the SCREEN-AF study. Whether these findings required further diagnostic testing, treatment, or both was not reported.^109^ Further, whether additional findings unrelated to AF result in benefits or harms is uncertain. Another evidence review for the USPSTF on screening for cardiovascular disease risk with ECG (not limited to use of ECG to screen for AF) found that the frequency of ECG abnormalities on resting 12-lead ECGs ranged from 31 to 55 percent across studies; the studies did not report how often the identified abnormalities resulted in additional testing or treatments.^123^ Potential harms could result from, for example, unnecessary stress tests and angiographies initiated to follow up on ECG abnormalities suggestive of ischemia (but determined to be false positives). However, potential benefits could result from appropriate care provided for off-target conditions (e.g., non-AF arrhythmias, ischemia) identified through screening.

Another potential harm of screening is overdiagnosis (i.e., diagnosis of a condition that never would have caused any symptoms or problems), particularly with respect to the identification of brief episodes of paroxysmal AF or subclinical AF. Whether all AF that is identified through screening will benefit from treatment is uncertain. In the mSToPS trial, 60 percent of participants in the screening group had AF detected through the two rounds of 14-day patch monitoring, while the rest had AF diagnosed clinically, either before or after the monitoring episodes. Of those detected by patch monitoring, the longest individual run of AF (defined as 30 seconds or longer) was less than 5 minutes in 7.2 percent and was less than 6 hours in 62 percent of participants. In SCREEN-AF, 87 percent of AF cases in the screening group were detected from screening, and nearly all were paroxysmal AF. The median duration of the longest episode was 5.7 hours, and 15 percent had an episode of AF that lasted 24 hours or longer. Studies reported higher rates of initiation of anticoagulation treatment, antiarrhythmics, and procedures compared with persons who were not screened, although estimates for some were imprecise and whether similar rates of initiation occurred in screen-detected vs. clinically detected cases is unknown. In overdiagnosed cases, this treatment may be unnecessary and result in harms. The recently published Atrial Fibrillation Detected by Continuous ECG Monitoring Using Implantable Loop Recorder to Prevent Stroke in High-Risk Individuals (LOOP) offers some context for this issue but was not eligible for inclusion in this review because 25 percent of the enrolled population had a prior history of stroke, TIA, or embolism and because this screening approach may not be feasible for primary care settings.^124^ In this study, detection of AF in the group randomized to the implantable monitor for 3 years was 31.8 percent and was 12.2 percent in the control group (HR, 3.17 [95% CI, 2.81 to 3.59]). However, no statistically significant differences were observed in stroke or systemic embolism (4.5% vs. 5.6%; HR, 0.80 [95% CI, 0.61 to 1.05]), all-cause death (11.2% vs. 11.3%; HR, 1.00 [95% CI, 0.84 to 1.19]), hemorrhagic stroke (0.8% vs. 0.8%; HR, 0.97 [95% CI, 0.49 to 1.92]), or major bleeding (4.3% vs. 3.5%; HR 1.26 [95% CI, 0.95 to 1.69]).^80^ These findings suggest overdiagnosis and highlight the need for more research to understand the benefits and harms of treating screen-detected AF.

## Benefits and Harms of Anticoagulation Treatment (KQs 5 and 6)

Among trials enrolling persons with clinical AF, we found consistent evidence that compared with placebo anticoagulation reduces the risk of stroke and all-cause mortality for persons with AF who do not have a history of stroke or TIA (i.e., for primary prevention). For a population with baseline annual stroke risk of 4 percent (e.g., such as those with CHA_2_DS_2_-VASc scores of 3 to 4), warfarin was associated with a corresponding NNT of 24 (95% CI, 17 to 36) to prevent one ischemic stroke over an average of 1.5 years of followup. For a population of 1,000 adults age 65 years or older with an annual stroke risk of 4 percent, the results translate to an absolute reduction of approximately 28 ischemic strokes per year and an absolute reduction of 16 deaths per year compared with placebo. A previously published network meta-analysis^106^ included in our review also found that DOACs (apixaban, dabigatran, edoxaban, and rivaroxaban) were more effective compared with placebo and not statistically different from VKAs for a composite outcome (any stroke and systemic embolism) or for all-cause mortality. Further, our surveillance of the literature after the search was completed also identified a recent study comparing low-dose edoxaban with placebo among elderly persons with AF that reported findings consistent with the included evidence.^79^ We assessed the evidence on benefits of anticoagulation as consistent and precise with moderate SOE that anticoagulation offers benefits. Although we aimed to determine the benefits of treatment for screen-detected older adults with AF without prior history of TIA or stroke, we found no trials or systematic reviews that focused on this population, and it is uncertain whether benefits of anticoagulation for clinical AF can be applied to those who are screen detected.

Based on evidence from KQ 2, screening is likely to detect more cases of AF compared with no screening, and many of those cases are likely to be paroxysmal cases. Screening for AF may also occur unwittingly through wearable or implanted devices. The AHA, the Canadian Cardiovascular Society (CCS), and the European Society of Cardiology (ESC) have commented on subclinical AF (Appendix B CQ 2) in scientific statements; however, we note these statements and the studies that informed them are based on persons with implanted cardiac devices (i.e., defibrillators and pacemakers) who have underlying cardiac conditions. They may not be applicable to primary care practice populations with screen-detected AF or persons with AF detected through wearable monitors. The CCS guidelines recommend that patients with subclinical AF longer than 24 hours with at least one stroke risk factor should receive OAC.^74^ Additionally, patients with subclinical AF of shorter duration who are at high risk should also be considered for OAC. In contrast, the AHA statements currently recommend mainly using vascular risk factors (e.g., CHA_2_DS_2_-VASc score) when deciding to use OAC for stroke prevention in AF.^8,^ ^125^ The AHA cited concerns that cutoffs for length of AF episodes in studies were arbitrary and not empirically derived; the effect of brief AF episodes is unknown; the lack of correlation between clinical burden of AF (e.g., symptoms and impact on quality of life) and AF burden as measured by time spent in AF during long-term monitoring, and some studies did not differentiate participants with AF vs. atrial flutter.^8^ However, the AHA statements indicate that the duration of AF may be a consideration in the decision to anticoagulate.^8^ Although the ESC has recognized that AF burden may influence stroke risk, they conclude that the current evidence is weak and AF burden should not be a major factor in decision making related to stroke prevention treatment.^7^ However, they suggest consideration for use in selected patients at high risk when AF diagnosis can be verified and a net clinical benefit is present.^7^

With respect to harms of anticoagulation treatment, the evidence from trials and systematic reviews of trials suggests warfarin and DOACs are associated with a higher risk of major bleeding when compared with placebo; however, these results were imprecise and did not exclude a null effect. However, the one new study identified for this report (GARFIELD-AF cohort of over 26,000 persons) also suggests an association between treatment and bleeding, and its estimate was more precise and excluded a null effect (HR, 1.73 [95% CI, 1.33 to 2.25]). Further, a dose-response effect (persons with higher INRs experience more bleeding) and evidence outside of this review suggesting increased risk of bleeding from anticoagulation for conditions other than AF led us to assess the evidence as having moderate strength that anticoagulation increases the risk of major bleeding compared with placebo.

## Limitations of the Evidence

The only study designed and powered to assess the direct benefits of screening (STROKESTOP) had numerous limitations. First, nearly half of those invited to participate in screening declined. Second, the outcomes evaluated were diagnosed through routine clinical care without formal masking and were not based on standard diagnostic criteria with central, blinded adjudication, as is typical for large trials involving vascular outcomes. Third, the trial protocol was amended to specify a composite endpoint combining both benefit and harm events that cannot be interpreted without evaluating the individual outcomes contributing to the composite, all of which were imprecise and not statistically significant. Whether benefit and harm endpoints should be combined into a “net benefit” composite is an area of debate and violates standard assumptions required for the use of composite endpoints.^126–128^ Lastly, this study enrolled persons with known AF, many of whom were already taking oral anticoagulants. Although the proportion of overall participants with known AF was relatively low (about 12%), the applicability of findings to asymptomatic persons without known AF is unclear because part of any benefit observed may be attributable to connecting persons with known AF to further care.

The studies of screening other than STROKESTOP that reported on detection of AF excluded persons with known AF; however, some persons with prior stroke or TIA or with unrecognized or unreported symptoms were included. For example, one trial included for KQ 2 (mSToPs) that recruited participants directly from a health plan only enrolled 2,820 participants of the 102,000 that were eligible and invited to enroll; whether persons that were symptomatic at baseline may have enrolled at higher rates compared with those without symptoms is not known. Thus, the applicability of the current evidence is for persons with undetected or undiagnosed AF as studies did not routinely assess for and exclude persons with possible symptoms. Some studies assessing whether one-time screening approaches can identify more cases of AF were conducted 10 to 15 years ago, and changes in technology and overall awareness of the condition may limit the usefulness of their findings. Further, the fidelity of the screening intervention was poor to modest in the studies evaluating one-time approaches to screening.

Trials of warfarin treatment were limited to 1.5 years of followup and estimates of the benefits of longer-term use are not available. We do not have direct evidence for the effectiveness of DOACs compared with no treatment because such trials would not be ethical. Further, treatment trials enrolled participants with clinical, persistent AF, and the applicability of treatment benefits and harms to screen-detected populations, including those with paroxysmal AF and subclinical AF, are not known.

## Future Research Needs

The STROKESTOP study was an important contribution to the evidence base related to screening for AF, but limitations prevent drawing definitive conclusions about the benefits and harms of screening on health outcomes solely based on it. Additional randomized trials of asymptomatic persons without known AF comparing screening for AF with no screening that report important health outcomes, such as stroke incidence, acute coronary syndrome, heart failure, all-cause mortality, and major bleeding, are needed to fully evaluate the benefits and harms of screening. Currently, six RCTs (Appendix H Table 1) are ongoing that will offer this additional direct evidence. Three studies are evaluating intermittent ECG with a handheld device or continuous ECG; these studies are more likely to detect cases of paroxysmal or subclinical AF compared with the RCTs that are evaluating a one-time ECG test strategy. In addition to providing direct evidence about screening, differences in outcomes across studies using these two different approaches to screening may offer evidence to help quantify overdiagnosis resulting from the identification of subclinical AF and brief episodes of paroxysmal AF.

Research related to new consumer devices marketed for heart rhythm monitoring and their role in screening for AF may also be warranted given their increased marketing to and use by consumers for monitoring overall health and wellness. Such tools increase the opportunity for AF detection, but management based on detection through these tools is not yet defined.^129^ The Heartline Study, a collaboration between Johnson & Johnson and Apple, is an example of a virtual, randomized controlled study designed to directly enroll consumers to evaluate the use of iPhone applications and the Apple Watch for the early detection of AF, impact on medication adherence for OACs in persons previously diagnosed with AF, and supporting other analyses to identify and prevent other medical conditions beyond those involving the heart.^130^

The Apple Heart Study, published in 2019, is another example. This study was an uncontrolled, siteless, pragmatic trial sponsored by Apple that used photoplethysmography, an optical sensor-based technology, embedded in the Apple Watch (Series 3 and earlier), synched to an Apple iPhone, with an algorithm to detect possible AF.^131^ The study recruited participants age 22 years or older from among persons downloading the Apple Watch application from the Apple App Store, and 67,259 (16%) were age 55 years or older. Participants with previously known AF or who were current users of OACs were excluded. Among participants age 55 years or older, 1,331 (2.0%) received an irregular pulse notification, which based on the study protocol was triggered if at least five of six consecutive tachograms were irregular, generally equivalent to at least an hour or more of an irregular rhythm. However, only 295 (22.2%) of those receiving a notification returned the confirmatory ECG patch monitor. Of those who returned the patch monitor, 110 (37.3%) were confirmed to have AF. Extrapolating the confirmation rate of 37 percent back to all participants age 55 years or older who received an irregular pulse notification suggests 492 cases of previously unknown AF for a prevalence of 0.7 percent. This prevalence is lower than what we calculated in our pooled estimates (CQ 1, Appendix A) and may reflect a population with fewer AF risks than a general community or clinic-based population but also a longer threshold of abnormal rhythm for triggering the initial notification. Similar to the Apple Heart Study, the Huawei Heart Study was also designed to investigate general population screening using a smartphone device–based photoplethysmography among persons in China.^132,^ ^133^ We note a recently published retrospective analysis of patients who presented for clinical evaluation related to receiving an abnormal pulse detection from their Apple Watch (Series 4 and earlier) at a large health system located across five states over a 5-month period spanning 2018 to 2019. Of the 264 patients presenting for evaluation, 22 percent had preexisting diagnosis of AF and only 33 had self-recorded ECG, a feature only available on the Series 4 model. Of the 264 patients, 33 percent reported experiencing no symptoms. A clinically actionable cardiovascular diagnosis was established in 30 patients (11.4%), of which 13 (4.9%) were AF.

In addition to direct evidence for screening benefits and harms, more research is needed to evaluate the benefit of early treatment. Specifically, more research related to anticoagulation among persons with subclinical AF or brief episodes of paroxysmal AF because the existing evidence regarding treatment benefits and harms is focused on persons with clinical AF that was not screen detected. Two RCTs (Appendix H Table 1) are ongoing that are evaluating a DOAC compared with standard of care (aspirin or placebo) among participants with cardiac implantable electronic devices. These trials include exploratory and subgroup analyses that will report on differences in health outcomes (stroke, major bleeding) based on duration and pattern of subclinical AF and atrial high-rate episodes. These analyses may inform our understanding of the benefits and harms of treating screen-detected AF and the threshold of AF burden at which to initiate OAC, although the patient population (persons with implanted cardiac devices) may not be representative of a general primary care population. Two other RCTs (Appendix H Table 1) are evaluating DOACs compared with standard-of-care AF treatment among persons with a low or intermediate risk of stroke; one of these (BRAIN-AF) includes neurocognitive decline as an endpoint in addition to stroke, death, and bleeding events.

In addition, more research on the benefits of early rate and/or rhythm control in screen-detected, asymptomatic persons with AF is required. Most guidelines recommend rate and/or rhythm control to manage symptoms. And previous studies of rhythm control did not find better outcomes compared with rate control alone. However, these studies largely included persons with long-standing AF and relied mostly on antiarrhythmic medication. The recently published EAST-AFNET trial of early rhythm control suggests a potential cardiovascular benefit of this strategy, but with some additional harms from increased serious adverse events related to rhythm control therapy.^58^ Unlike previous trials that largely included persons with long standing AF and relied only on medication, this trial included persons with AF without symptoms (30% of enrolled). The median number of days from diagnosis was 36 and a majority of persons had either first episode AF or paroxysmal AF. Further, this trial offered ablation as one of the available interventions and nearly one in five participants assigned to the intervention group received ablation.

## Limitations of the Review

This review was limited to studies published in English and conducted in very highly developed countries that we rated as fair or good methodological quality. We only considered screening approaches that were feasible to conduct in primary care settings or referable from primary care settings. Further, we limited our evaluation of health outcomes to stroke, stroke-related mortality, and cardiovascular outcomes. Outcomes related to cognitive decline and dementia, frailty, and noncardiovascular outcomes might be considered in future studies. For this review, we considered non-AF findings and treatment and procedures of false-positive AF results as potential harms (e.g., because procedures have inherent disutility, inconvenience, and costs). We acknowledge that treatment offered for medically actionable non-AF findings may offer benefit for some persons. Such benefits may be captured in studies designed to address the direct benefit of screening (KQ 1). Lastly, we did not evaluate the comparative effectiveness of anticoagulation treatments.

## Conclusions

The available direct evidence for health outcomes has numerous limitations, precluding a definitive conclusion about screening benefits and harms. Screening with intermittent or continuous ECG strategies in primary care settings can detect more cases of previously unknown AF compared with no screening, but spot one-time ECG screening may not detect more cases than pulse palpation reminders. In low-prevalence settings, spot one-time screening tests may generate more false-positive than true-positive results. In persons with clinically detected AF, warfarin and DOACs reduce the risk of first stroke and all-cause mortality compared with placebo; the evidence also suggests they increase the risk of major bleeding, although estimates for this harm are imprecise. No trials have assessed the benefits and harms of anticoagulation treatment among screen-detected populations.