# Chapter 3 Results

We screened 5,963 titles and abstracts and 242 full-text articles to identify 26 unique studies from 33 publications (N=113,784) for inclusion (Figure 2).^56,^ ^59,^ ^75–78,^ ^91–117^ Twelve of these studies were new to this update.^56,^ ^75–77,^ ^109–118^ The list of articles excluded during full-text review is in Appendix D, and quality assessments are in Appendix E. We identified three RCTs reporting on the benefits of screening (KQ 1); eight RCTs reporting the diagnostic yield of screening compared with no screening or nonsystematic screening (KQ 2), nine studies reporting on the accuracy of various index screening strategies compared with a reference test (KQ 3), four RCTs and 1 cohort study reporting on the harms of screening (KQ 4), 10 studies reporting on the health benefits of treatment with anticoagulation (KQ 5), and 12 studies reporting on the harms of treatment with anticoagulation (KQ 6).

Figure 2 Literature Flow Diagram for Systematic Review of Screening for Atrial Fibrillation

Abbreviation: KQ =key question

Figure 2 is titled “Literature Flow Diagram for Systematic Review of Screening for Atrial Fibrillation.” This figure is a flow chart that summarizes the search and selection of articles. We identified 6,983 records through electronic database searches and 10 records by other sources, including hand search for screening at the title and abstract level. This resulted in a total of 5,963 titles and abstracts screened after duplicates removed. Additionally, 26 records were included from the previous review. Resulting in a total of 242 articles assessed for eligibility at full-text review. After full-text review, 209 were excluded: 17 that were systematic reviews that we used for hand search, 18 for ineligible publication type, 6 for ineligible country, 47 for ineligible population, 19 for ineligible intervention, 39 for ineligible comparator, 9 for ineligible outcome, 29 for ineligible study design, 4 for being a duplicate or superseded, 9 for being a study protocol or in progress, 7 for abstract only, 4 for ineligible setting, and 1 for other. Thirty-three articles representing 26 studies were included in the synthesis of the systematic review. Three studies in 5 articles were identified for KQ 1. Eight studies in 14 articles were identified for KQ 2. Nine studies in 13 articles were identified for KQ 3. Four studies in 10 articles were identified for KQ 4. Ten studies in 11 articles were identified for KQ 5. Twelve studies in 13 articles were identified for KQ 6.

## KQ 1 Does Screening for AF With Selected Tests Improve Health Outcomes in Asymptomatic Older Adults?

Three RCTs randomized persons to screening vs. no screening and reported health outcomes; however, only one of these studies was designed and powered for evaluating health outcomes such as stroke.^76–78^ The other two RCTs were powered for evaluating differences in the detection of AF (a KQ 2 outcome) but did report a limited amount of information related to health outcomes.^75,^ ^108^ Study, population, and intervention characteristics are described in detail in Appendix F Tables 1 through 3.

The STROKESTOP RCT randomized all adults age 75 or 76 years living in two regions of Sweden to an invitation to screening (n=14,387) or to a control group that did not receive an invitation to screening (n=14,381).^76–78^ A similar number of participants in both groups died or emigrated before the study started, resulting in 13,979 participants analyzed in the invitation-to-screening group and 13,996 in the control group. Because study participants were identified through civic registers, study authors applied no clinical inclusion or exclusion criteria. At baseline, 12.1 percent of the intervention group and 12.8 percent of the control group had known AF. Further, approximately 11 percent of both groups had a history of stroke, TIA, or systemic embolism, and 9 percent had been dispensed an oral anticoagulant within 6 months before study enrollment. The mean CHA_2_DS_2_VASC score across the population was 3.5. Of those invited to screening, 51.3 percent participated in the screening intervention, which was 2 weeks of twice-daily intermittent single-lead ECG monitoring with a handheld device for 30 seconds.

We assessed the STROKESTOP study as fair quality. The intervention was not blinded to participants. Outcome ascertainment was through national health registries, and persons retrieving data from these health registries were not formally blinded to group allocation. Diagnoses representing outcomes in the health registries were from data collected during routine care and were not centrally adjudicated. Further, providers assigning diagnoses were also not formally blinded, although the only way they would know the group allocation is if the participant disclosed it. Lastly, the primary outcome was originally specified as ischemic stroke in 2012 but was changed in 2017 before any data analysis to a composite endpoint that included ischemic stroke, hemorrhagic stroke, systemic embolism, bleeding leading to hospitalization, and all-cause mortality. The authors justified this change because of a 40 percent decrease in stroke incidence over this period attributed to increased stroke prevention with DOACs and because a “net benefit” composite outcome that combined benefits with harms was deemed a more clinically relevant outcome.^76–78^

At a median followup of 6.9 years, the rate of composite endpoint events in STROKESTOP for the intent-to-treat analysis was significantly lower in the invitation-to-screening group (5.45 events/100 person-years) compared with the control group (5.68 events/100 person-years) with an unadjusted hazard ratio (HR) of 0.96 (95% CI, 0.92 to 1.00; p=0.045).^76–78^ For the outcome of ischemic stroke or system thromboembolism, the HR was 0.92 (95% CI, 0.84 to 1.02). No significant differences were observed between the invitation-to-screening group and the control group for any of the individual outcomes contributing to the composite endpoint or for any other combined outcomes reported by study authors (Appendix F Table 4). In a post hoc analysis comparing persons who participated in screening with those in the control group, the adjusted HR was 0.72 (95% CI, 0.68 to 0.76) for ischemic stroke or systemic thromboembolism. However, this as-treated analysis should be interpreted with caution because study authors reported significantly fewer comorbidities and medications and more favorable sociodemographic characteristics for those who participated in screening compared with those who were invited but did not participate.

One fair-quality RCT of 1,001 participants with a primary outcome of time to diagnosis of AF (a KQ 2 outcome) reported limited information on health outcomes among secondary outcomes but was not designed or powered to evaluate them.^108^ The Assessment of REmote HEArt Rhythm Sampling using the AliveCor heart monitor to scrEen for Atrial Fibrillation (REHEARSE-AF) compared twice-weekly 30-second single-lead ECG using a handheld device (n=500) with no screening (n=501) for 12 months; this trial is described in more detail in the KQ 2 section. For all-cause mortality, the authors reported three deaths in the screening group and five in the no-screening group (p=0.51). For a composite of stroke, TIA, and systemic embolism, there were 6 vs. 10 events, respectively (hazard ratio [HR], 0.6 [95% CI, 0.2 to 1.7]; p=0.34).

Lastly, one fair-quality RCT of 856 participants with a primary outcome of AF detection (a KQ 2 outcome) also reported limited information on health outcomes. The SCREEN-AF RCT compared two 2-week intervals of continuous patch ECG monitoring and twice-daily home blood pressure monitoring with AF detection to no screening.^75^ After 6 months of followup, two ischemic strokes and one TIA occurred in the screening group and zero occurred in the control group; one death (cardiovascular related) occurred in the control group and zero occurred in the screening group.

As of October 2021, six ongoing trials are assessing the direct benefits of screening for AF; a summary of these studies is included in Appendix H Table 1. Three studies are evaluating intermittent ECG with a handheld device (over 2 to 4 weeks) or continuous ECG (with patch monitor over 2 weeks), two are evaluating one-time ECG screening with a handheld device, and one is using a PPG-based screening with ECG patch, but it is unclear whether the approach is one-time, intermittent, or continuous.

## KQ 2 Does Systematic Screening for AF With Selected Tests Identify Older Adults With Previously Undiagnosed AF More Effectively Than Usual Care?

We included eight fair-quality RCTs (described in 14 articles, N=86,590).^75–78,^ ^91–95,^ ^105,^ ^108,^ ^109,^ ^111,^ ^116^ Five of the RCTs were new in this update.^75–78,^ ^109,^ ^111,^ ^116^ Detailed study, population, and intervention characteristics are provided in Appendix F Table 1 through Appendix F Table 3.

### Study Characteristics

The characteristics of the included trials are summarized in Table 1. Three trials were conducted in the United Kingdom,^91,^ ^105,^ ^108,^ ^109^ two in the Netherlands,^111,^ ^116^ one in Sweden,^76–78^ one in the United States,^109^ and one that enrolled participants from both Canada and Germany.^75^ All trials enrolled persons at least age 65 years or older; the mean age of participants was 72 to 80 years, and the percentage of enrolled females ranged from 39 percent to 59 percent. None of the trials reported information about the race or ethnicity of participants.

Table 1 Summary of Characteristics of Included Randomized, Controlled Trials of Screening for Atrial Fibrillation (KQ 2)

Author, Year; Trial Name, Registry No. | Study Design | Country | Recruitment Setting | Mean age (SD) in years | N (%) Female | Intervention Groups; (N randomized) | Study Duration | Study Quality
Gladstone et al, 2021^75^; SCREEN-AF; NCT02392754 | Parallel-group RCT | Canada and Germany | Primary care clinics | 80 (4.0) | 487 (57) | No screening, care as usual (422); A single-lead adhesive patch continuous ECG (Zio XT, iRhythm Technologies) worn for 2 weeks at baseline and again at 3 months for a total of 4 weeks; automated home BP monitor with automated AF detection used twice daily during each of the 2-week ECG monitoring periods (434) | 6 months | Fair
Halcox et al 2017^108^; REHEARSE-AF; ISRCTN10709813 | Parallel-group RCT | U.K. | General practices (number unknown) | 72.6 (5.4) | 535 (53) | No screening, care as usual (501); Twice-weekly 30-second, single-lead ECG using a handheld device (AliveCor Heart Monitor), plus additional recordings if symptomatic for 12 months (500) | 1 year | Fair
Hobbs et al 2005^91^; Fitzmaurice et al, 2007;^93^; Fitzmaurice et al, 2014;^92^; Mant et al, 2007;^94^; Swancutt et al, 2004^95^; SAFE; ISRCTN19633732 | Cluster-group RCT | U.K. | 50 primary care practices (25 intervention and 25 control) | 75.3 (7.2) | 8,500 (57.4) | No screening, care as usual (4,936); Reminder flag was placed in the chart encouraging clinicians to record pulse during routine visits; patients with irregular pulses invited to attend a nurse-led screening clinic and have 12-lead ECG (4,933); Patients invited by letter to attend a nurse-led screening clinic where their radial pulse was palpated, and a 12-lead ECG was performed (4,933) | 1 year | Fair
Kaasenbrood et al 2020^111^; IDEAL-MD | Cluster-group RCT | The Nether-lands | 31 general practices (15 intervention and 16 control) | Intervention: 74.3 (7.3); Control: 74.5 (7.3) | Intervention: 4,680 (54.5); Control: 4,610 (54.1) | No screening, care as usual (8,526); Intervention practices instructed to screen all persons age 65 years without a diagnosis of AF during visits to the practice over the course of the study using a single-lead ECG device, which registers lead one for 1 minute and indicates whether an irregular rhythm is detected. Implementation left to the discretion of practices (8,581). | 1 year | Fair
Morgan et al 2002^105^ | Parallel-group RCT | U.K. | 4 general practices | 75.5 (NR) | 1,756 (58.8) | Reminder flag was placed in the notes for a 6-month period. Nurses and physicians were encouraged to record pulse during routine visits; if pulse was suspicious for AF, they decided whether to request ECG depending on the history and clinical context (1,502).; Patients invited by letter to attend a nurse-led screening clinic where their radial pulse was palpated, and a single lead II rhythm strip was performed (1,499) | 6 months | Fair
Steinhubl et al 2018^109^; mSToPS; NCT02506244 | Parallel-group RCT | U.S. | Site-less clinical trial involving a large health insurance plan’s members Individuals were recruited by email or direct mail. | 72.4 (7.3) | 1,026 (38.6) | Delayed monitoring using same screening as below but initiated 4 months after enrollment date (1,293); Single-use, 14-day, ambulatory ECG monitoring skin patch. Participants wore an initial patch upon enrollment for 2 weeks and a second patch 3 months later for another 2 weeks (1,366). | 4 months | Fair
Svennberg et al 2021^76–78^; STROKESTOP; NCT01593553 | Parallel-group RCT | Sweden | Population registers in two regions | 75- and 76-year-olds only | 15,273 (54.6) | No invitation to screening (14,381 randomized/13,996 enrolled); Invitation to screening: index ECG at study entry, if NSR then single-lead handheld ECG recorder twice daily for 30 seconds over 14 days (14,387 randomized/13,979 enrolled) | Median 6.9 years | Fair
Uittenbogaart et al, 2020^116^; D2AF; NL4776 | Cluster-group RCT | The Nether-lands | 96 primary care practices (47 intervention, 49 control) | Intervention: 75.2 (6.8); Control: 75.0 (6.9) | 10,248 (53.4) | No screening, care as usual (9,789); Reminder in chart of 200 eligible patients randomly selected at each practice to conduct pulse palpation, oscillometric blood pressure monitor with AF detection feature, and single-lead handheld ECG with optional Holter monitoring if all three index tests were negative (9,400) | 1 year | Fair

Abbreviations: AF=atrial fibrillation; BP=blood pressure; D2AF=Detecting and Diagnosing Atrial Fibrillation; ECG=electrocardiograph; IDEAL-MD=Improving DEtection of Atrial fibriLlation in Primary Care With the MyDiagnostick; KQ=key question; mSToPS=mHealth Screening to Prevent Strokes; N=number of participants; NR=not reported; NSR=normal sinus rhythm; RCT=randomized, controlled trial; REHEARSE-AF=REmote HEArt Rhythm Sampling using the AliveCor heart monitor to scrEen for Atrial Fibrillation; SAFE=Screening for Atrial Fibrillation in the Elderly; SD=standard deviation; U.K.=United Kingdom; U.S.=United States.

Six studies enrolled participants from primary care practices.^75,^ ^91–95,^ ^105,^ ^108,^ ^111,^ ^116^ Of the other two studies, one study^109^ was a siteless trial that recruited participants via mail or email from a large health insurance plan roster, and the other study used population registers to randomize all persons ages 75 or 76 living in a specific geographic region of the country, regardless of baseline symptom status or presence of known AF.^76–78^ All of the other studies excluded persons with known AF from participation. In one trial,^111^ all participants in the intervention group completed a questionnaire screening for symptoms potentially related to AF in the previous month before screening. The other studies did not report methods of ascertaining asymptomatic status before screening. One study^75^ required all participants to have hypertension, and the prevalence of hypertension in the four other studies reporting this characteristic at baseline ranged from 36 percent to 77 percent.^76–78,^ ^108,^ ^109,^ ^111,^ ^116^ No studies explicitly excluded persons with a history of TIA or stroke; the prevalence of these conditions in the five studies reporting this at baseline ranged from^108,^ ^111,^ ^116^ 6.5 percent to 11 percent.^76–78,^ ^108,^ ^109,^ ^111,^ ^116^ Two of these studies also reported the baseline prevalence of heart failure (1.4% and 4.0%).^108,^ ^116^ Five studies^75–78,^ ^108,^ ^109,^ ^111^ reported baseline mean or median CHA_2_DS_2_-VASc stroke risk scores, which ranged from 3 to 4.

Of the included trials, all of them assessed screening strategies that used ECG. Seven trials compared screening with no screening, but the frequency of screening differed among trials.^75–78,^ ^91–95,^ ^108,^ ^109,^ ^111,^ ^116^ Three trials evaluated a one-time ECG.^91–95,^ ^111,^ ^116^ The Screening for Atrial Fibrillation in the Elderly (SAFE) study was a cluster randomized trial (14,802 participants) that randomized 50 primary care practices to screening vs. no screening with 1-year followup.^91–95^ Within the 25 practices randomized to screening, individual participants were then further randomized to ECG screening or pulse palpation reminders. Those in the ECG screening arm were invited by mail to attend a nurse-led screening clinic where their radial pulse was palpated, and a limb-lead, thoracic-lead, and a 12-lead ECG were performed. For the practices assigned to either screening group, primary care physicians and other members of the healthcare team attended educational days covering the importance of detecting AF and available treatment options. The Improving DEtection of Atrial FibriLlation in Primary Care with the MyDiagnostick (IDEAL-MD) study was a cluster randomized trial that randomized 31 general practices (8,526 participants) to ECG screening or no screening with 1-year followup.^111^ Within the 15 practices randomized to ECG screening, eligible patients were identified and screened during practice visits with a single-lead ECG using a handheld device. The 16 control practices were informed of the study aim, but no specific intervention was assigned. The Detecting and Diagnosing Atrial Fibrillation (D2AF) was a cluster-randomized RCT within 96 primary care practices (17,976 participants) that evaluated a combined strategy of three tests: pulse palpation, oscillometric BP measurement with automated AF detection, and handheld single-lead ECG with automated AF detection compared with usual care over 1-year followup.^116^

Two trials evaluated screening with intermittent hand-held ECG.^76–78,^ ^108^ The REmote HEArt Rhythm Sampling using the AliveCor heart monitor to scrEen for Atrial Fibrillation (REHEARSE-AF) trial randomized 1,001 participants with a CHA_2_DS_2_-VASc score of 2 or more recruited from general practices to twice-weekly screening with a single-lead ECG using a handheld device or to no screening for a 1-year duration; followup was also 1 year.^108^ STROKESTOP randomized over 28,000 persons age 75 or 76 identified from the population registries of two geographic regions.^76–78^ Of those who were randomized to the invitation to the screening program, 51.3 percent enrolled and received an index ECG at baseline followed by 2 weeks of intermittent handheld single-lead ECG monitoring; followup was a median of 6.9 years. Those with AF at baseline who were not already taking direct oral anticoagulants (DOACs) and those with newly identified AF were offered structured followup with a cardiologist.

Two trials evaluated screening with continuous ECG.^75,^ ^109^ The mHealth Screening to Prevent Strokes (mSToPS) trial randomized 2,659 participants recruited by email or mail from a large health insurance plan to screening with a 14-day continuous ambulatory ECG monitoring with a patch initiated immediately after enrollment and again in 3 months or to delayed monitoring 4 months after enrollment (i.e., no screening).^109^ Outcomes were reported after 4 months followup from baseline. SCREEN-AF randomized 856 participants to a similar intervention, with the addition of a home blood pressure monitor with automated AF detection to be used twice daily during each 2-week ECG monitoring period.^75^ Followup in this study was 6 months.

Two trials compared ECG screening with pulse palpation chart reminders.^91–95,^ ^105^ The SAFE trial, previously described, used paper or computer flags placed in patient medical records to encourage providers to conduct pulse palpation; those with an irregular pulse were invited to attend a screening clinic and have an ECG performed. The second trial, Morgan et al, randomized 3,001 participants from four primary care practices to ECG screening or pulse palpation reminders.^105^ Those in the ECG screening group were invited by mail to attend a nurse-led screening clinic where their radial pulse was palpated and a lead II ECG rhythm strip was performed. Those unable to attend the clinic were offered screening at home. For those in the other group, a reminder flag was placed in their medical records. Nurses or physicians who assessed the pulse during routine care of the patient were asked to indicate on the flag whether the pulse was suspicious of AF and whether they wished to investigate further with an ECG. Nurses conducting screenings received 2 hours of training in the clinical assessment of the pulse rhythm.

### Results of Included Trials

All trials reported on detection of AF cases for the screening intervention groups compared with control groups (either no screening or pulse palpation reminders). Detailed results are provided in Appendix F Table 4. Followup lasted 1 year for SAFE, REHEARSE-AF, IDEAL-MD, and D2AF; 4 months for mSToPS; and 6 months for SCREEN-AF, STROKESTOP, and the Morgan et al trial. In SAFE, two cardiologists masked to allocation assessed whether ECGs showed AF in the screening arms; a third arbitrated any disagreements. Medical records were reviewed for participants in the control group to identify new cases of AF.^91,^ ^93^ The Morgan et al trial reported AF ascertainment by a single observer (masking not reported) who reviewed medical records of participants for new diagnoses, investigations, and treatment.^105^ In REHEARSE-AF, an unmasked study cardiologist confirmed all AF diagnoses made in the intervention group; participants in the control group were diagnosed by local clinicians with validation by a study cardiologist.^108^ In STROKESTOP, study authors defined AF as at least one 30-second episode of AF or at least two episodes between 10 and 29 seconds during the 2-week screening period for persons randomized to the screening intervention.^76–78^ However; the proportion with AF reported 6 months after baseline and at later followup time points was based on health registry data derived from clinical records.^76^ In mSToPS, rhythms from 14-day continuous ECG monitoring were analyzed using an FDA-approved algorithm, and these results underwent additional technical review for report generation and quality assurance after which the report was independently reviewed by the principal investigator.^109^ New AF was defined as 30 seconds or more of AF or atrial flutter detected by device or a new clinical diagnosis recorded in claims data. In SCREEN-AF, devices from the continuous ECG monitoring were centrally interpreted with results then provided back to the participants’ primary care physicians.^75^ New clinical diagnoses were ascertained during study visits, with central adjudication based on ECG tracings and hospital records. In IDEAL-MD, AF was confirmed by a general practitioner (GP) and research cardiologist, and AF was considered newly diagnosed whether screen detected or diagnosed otherwise.^111^ In D2AF, AF diagnoses were ascertained by extraction of diagnosis information from the electronic medical records of participants randomized.^116^

Findings are summarized in Figure 3. Of the studies using one-time approaches to screening (D2AF, IDEAL-MD, SAFE), risk differences (RDs) ranged from 0.06 to 0.60 percentage points and risk ratios (RR) ranged from 1.04 to 1.58 compared with no screening; findings were only statistically significant in the SAFE trial. Fidelity with respect to the proportion of participants randomized to receive screening that were screened was low to modest in these trials (D2AF, 45%; IDEAL-MD, 11%, SAFE, 53%). The two trials comparing one-time ECG screening with pulse palpation reminders did not find a statistically significant difference in new cases of AF between study arms.^91,^ ^105^ The fidelity of pulse palpation among participants randomized to pulse palpation reminders was also low to modest in these trials (Morgan et al,^105^ 29%; SAFE, 69%). However, more cases of AF were detected in the SAFE trial when comparing pulse palpation reminders with no screening.^91^

Figure 3 Comparative Diagnostic Yield From Randomized Controlled Trials of Screening for Atrial Fibrillation (KQ 2)

Figure Note: To calculate the ARD in percentage points, multiply value by 100 (e.g., 0.0010 multiplied by 100=0.1 percentage points).

* This study enrolled participants from a population registry without regard to AF status; at baseline, 12.1% of the intervention group and 12.8% of the control group had known AF.

Abbreviations: ARD=absolute risk difference; CI=confidence interval; ECG=electrocardiograph; D2AF=Detecting and Diagnosing Atrial Fibrillation; ECG=electrocardiograph; IDEAL-MD=Improving DEtection of Atrial FibriLlation in Primary Care with the MyDiagnostick; KQ=key question; mSToPS=mHealth Screening to Prevent Strokes; No.=number; RD=risk difference; REHEARSE-AF=REmote HEArt Rhythm Sampling using the AliveCor heart monitor to scrEen for Atrial Fibrillation; RR=risk ratio; SAFE=Screening for Atrial Fibrillation in the Elderly.

Figure 3 is titled “Comparative Diagnostic Yield from Randomized Controlled Trials of Screening for Atrial Fibrillation (KQ 2).” This figure displays a forest plot reporting the absolute risk difference of diagnostic yield divided by screening type. One study report on one-time screening of a systematic blood pressure monitor and electrocardiograph versus a no screening comparator (D2AF, 2020). The absolute risk difference comparing a one-time approach to screening with no screening was 0.0010 (95% CI, -0.0027 to 0.0046). Six studies reported on a systematic electrocardiograph approach versus a no screening comparator (IDEAL-MD, 2020; SAFE, 2007; mSToPS, 2018; REHEARSE-AF, 2017; STROKESTOP, 2021; SCREEN-AF, 2021). The absolute risk difference comparing a one-time systematic ECG approach with no screening ranged from 0.0006 to 0.0055 (IDEAL-MD, 2020; SAFE, 2007). Of the studies using one-time approaches to screening compared to no screening; findings were only statistically significant in the SAFE trial. The absolute risk difference comparing an intermittent or continuous systematic electrocardiograph approach with no screening ranged from 0.0104 to 0.0483 (STROKESTOP, 2021; SCREEN-AF, 2021). Findings were statistically significant in all four trials that compared intermittent or continuous approaches with no screening. Two studies compared a one-time, systematic electrocardiograph screening with pulse palpation reminders (Morgan, 2002; SAFE, 2007) and reported an absolute risk difference that ranged from -0.0002 to 0.0033. The two trials comparing ECG screening with pulse palpation reminders did not find a statistically significant difference in new cases of AF between study arms. One study compared a one-time, pulse palpation reminder with no screening (SAFE, 2007) and reported an absolute risk difference of 0.0057 (95% CI, 0.0013 to 0.0100).

Relative to one-time ECG screening, more cases of AF were detected with intermittent ECG compared with no screening. In REHEARSE-AF, 19 (3.8%) persons had AF detected from screening twice daily for 12 months compared with 5 (1.0%) in the no-screening group (ARD 2.8%; 95% CI, 0.9% to 4.7%). Notably, 11 (58%) of the new AF cases reported symptoms at the time of diagnosis compared with all of the new AF cases in the no-screening group.^108^ In STROKESTOP, which evaluated twice-daily screening for 2 weeks, 1,991 (14.5%) cases of AF were detected by 6 months after baseline compared with 1,850 (13.4%) cases in the no-screening group. The ARD for new cases of AF was 1.0 percent (95% CI, 0.2% to 1.9%).^76–78^ As previously noted, most of the cases of AF in both groups were known at baseline.

Relative to one-time screening, more cases of AF were also detected for continuous ECG screening over two 2-week intervals. In mSToPS, by 4 months followup, 53 (3.9%) cases of AF were detected with screening compared with 12 (0.9%) in the control group (ARD 3.0% [95% CI, 1.8% to 4.1%]).^109^ Notably, 12 (17%) participants who had AF during monitoring recalled symptoms potentially associated with AF when prompted.^109^ The mSToPS trial reported a median time to first detection of AF of 2.0 days (interquartile range [IQR], 1.0 to 5.0) and median AF burden (percentage of monitored time in AF) of 0.9% (IQR, <1% to 4%).^109^ Of 109 new cases of AF in the monitored cohort group (immediate or delayed groups) reported at 1 year, 65 (60%) were first found to have AF by ECG patch (as opposed to a clinical diagnosis prior to or after monitoring).^109^ The trial reported that the longest individual episode of AF was less than 5 minutes in 7.2 percent and was 5 minutes to 6 hours in 55 percent, was 6 to 24 hours in 25 percent, and was more than 24 hours in 13 percent. In SCREEN-AF, by 6 months followup, 23 (5.4%) AF cases were detected in the screening group compared with two (0.5%) in the no-screening group (ARD, 4.8% [95% CI, 2.6% to 7.0%]; number needed to screen 21).^75^ Of the 23 cases detected in the screening group, 20 cases (18 paroxysmal, 2 persistent) were detected through screening, and three presented clinically. Among those in the screening group, the median duration of the longest episode of AF was 5.7 hours (IQR, 2.9 to 12.9) with 50 percent of cases spending more than 6 hours in AF and 15 percent spending more than 24 hours in AF.

#### Subgroup Findings

The SAFE trial reported subgroup analyses by sex and age for ECG screening or pulse palpation reminders compared with no screening.^91^ The subgroup analyses reported that screening may not increase detection of new cases among females. Males in the ECG (44 vs. 16; OR, 2.68 [95% CI, 1.52 to 4.73]) and pulse palpation reminder groups (38 vs. 16; OR, 2.33 [95% CI, 1.30 to 4.15]) had greater odds of having AF diagnosed than males in the no-screening group. The odds were not significantly increased for females in either screening group compared with no screening (30 vs. 31; OR, 0.98 [95% CI, 0.59 to 1.61] and 37 vs. 31; OR, 1.20 [95% CI, 0.74 to 1.92], respectively). Patients ages 65 to 74 years and those older than 75 years had similar odds of having AF diagnosed in both the ECG screening (30 vs. 18; OR, 1.62 [95% CI, 0.91 to 2.88] and 44 vs. 29; OR, 1.56 [95% CI, 0.98 to 2.49], respectively) and pulse palpation reminder groups (31 vs. 18; OR, 1.63 [95% CI, 0.92 to 2.89] and 44 vs. 29; OR, 1.60 [95% CI, 1.00 to 2.56], respectively) compared with no screening. The other trials included for KQ 2 did not report any subgroup analyses.

## KQ 3 What Is the Accuracy of Selected Tests for Diagnosing AF in Asymptomatic Adults?

We identified nine studies reported in 13 articles (N=4,978) on the accuracy of primary-case feasible screening tests (Table 2).^56,^ ^75,^ ^91,^ ^112–117^ All are new to this update because this KQ was not included in the previous report. Detailed study, population, and screening test characteristics are provided in Appendix F Table 5 through Appendix F Table 7.

Table 2 Summary of Characteristics of Included Test Accuracy Studies (KQ 3)

Author, Year; Trial Name; Registry No. | Recruitment Setting (Total N) | Inclusion Criteria | Mean age (SD) | N (%) Female | Index Test(s) Description | Reference Test(s) Description | Study Quality
Gladstone et al, 2021^75^; SCREEN-AF; NCT02392754 | Primary care clinics in Canada and Germany (399) | Age ≥75 years who are not receiving OAC with a history of HTN, in sinus rhythm | 79.8 (3.8) | 255 (58.8) | Oscillometric BP monitor (Micfolife WatchBP-Home A) with automated AF detection used twice daily during each of the 2-week ECG monitoring periods. Test is considered positive if at least 2 of the 3 readings are positive for AF. | Single-lead adhesive patch continuous ECG; worn at baseline for 2 weeks and again at 3 months for a total of 4 weeks. AF defined as ≥1 episode of continuous AF or atrial flutter lasting more than 5 minutes on cECG or by a single 12-lead ECG | Good
Himmelreich et al, 2019^112^ | 10 general practices in the Netherlands (106) | Age ≥18 years with 12-lead ECG ordered by their primary care physician for nonacute indications | 69.3 (10.7) | 62 (58) | Single lead, handheld ECG (KardiaMobile) smartphone-connected device with automated AF detection during an office visit for 30s^*^ | 12-lead-ECG independently interpreted by two cardiologists, disagreements resolved by a third cardiologist | Good
Hobbs et al, 2005^91^; SAFE; ISRCTN-19633732 | 25 general practices in the U.K. (1,452) | Age ≥ 65 years | 75.3 (7.2)^†^ | 8,500 (57.4) | 1) GP interpreted 12-lead ECG; 2) GP interpreted limb-lead II ECG; 3) GP interpreted thoracic-lead ECG | 12-lead ECG independently interpreted by 2 cardiologists | Good
Kearley et al, 2014^113^ | 6 general practices in the U.K.(999) | Age ≥75 years | 79.7 (NR) | 507^ǂ^ (50.7)^ǂ^ | 1) Modified oscillometric BP monitor (Microlife WatchBP); device flashes for irregular pulse during automatic BP measurement during an in-office visit^§^; 2) Single-lead ECG with autoanalysis function (OMRON model HCG-801) for unspecified duration during an office visit; in addition to the ECG recording, generates a text indicating the presence of possible AF^ǁ^ | 12-lead ECG interpreted by 2 cardiologists, with disagreements resolved by a third cardiologist | Fair
Marazzi et al, 2012^115^ | Hypertension clinic in Italy (383) | None specified | 67 (10.5) | 230 (46) | 1) Osciillometric BP monitor (Microlife BP A200 Plus) with automated AF detection based on 3 sequential BP measurements administered during an office visit; 2) Oscillometric BP monitor (OMRON M6) with automated AF detection during an office visit | 12-lead ECG interpreted by cardiologist | Good
Philippsen et al, 2017^56^; NCT02041832 | Hospital-based diabetes and cardiology outpatient clinics in Denmark (82) | Age ≥65 years receiving treatment for diabetes mellitus and hypertension, with stable medications for at least 1 month | 71 (4) | 30^ǂ^ (37)^ǂ^ | 2-channel, 72-hour Holter monitoring analyzed by trained staff and adjudicated by 2 cardiologists. AF defined as ≥1 episode of irregular rhythm without P waves lasting at least 30 seconds | Continuous ECG monitoring with an insertable cardiac monitor over median of 588 days interpreted by 2 electrophysiologists. AF defined as at least 1 episode of irregular rhythm without P waves lasting at least 2 minutes. | Good
Sabar et al, 2019^117^; NCT02401451 | Outpatient hospital cardiology clinic (632) | Age ≥18 years attending the outpatient cardiology department for routine 12-lead ECGs or other appointments | 66 (range 18-97) | 384 (51) | 6-lead ECG (RhythmPad, Cardiocity) automated diagnostic report produced using a custom detection algorithm after a single 10-second screening | Single 10-second, 12-lead ECG screening (GE MAC550 machine, Chicago, IL) interpreted by two blinded cardiologists | Fair
Uittenbogaart et al, 2020^116^; NL4776 | 96 primary care practices in the Netherlands (742) | Age ≥65 years | 75^†^ | NR (53.4^†^) | Combined approach that included pulse palpation, oscillometric blood pressure monitor with automated AF detection (WatchBP Home A, Microlife) and single lead handheld ECG (MyDiagnostick) | 12-lead ECG interpreted by cardiologists (only 10% random sample of index test negative participants received reference test) | Fair
Wiesel et al, 2014^114^ | Two outpatient cardiology clinics in the U.S. (148) | Age ≥50 years | 74 (NR) | 75^ǂ^ (41)^ǂ^ | 1) Oscillometric blood pressure monitor (OMRON M6 Comfort) with automated irregular rhythm detection feature during an office visit; 2) Oscillometric blood pressure monitor (Microlife BP A 200) with automated AF detection based on 3 sequential BP measurements during an office visit.^¶^ | 12-lead ECG interpreted by a cardiologist | Fair

* Rhythms classified by algorithm as AF, normal, unreadable, or no classification. For this analysis, screening was considered positive for any “possible AF” tracings and was considered negative for all other tracings. The AF classification refers to both atrial fibrillation and atrial flutter.

† For entire study population, not all study participants from the trial were included in the KQ 3 analyses.

ǂ Calculated value.

§ Inconclusive results treated as “positive.”

ǁ “analysis impossible” text messages were counted as positive tests. Inconclusive results treated as “positive.”

¶ Test is considered positive if at least 2 of the 3 readings are positive for AF.

Abbreviations: AF=atrial fibrillation; BP=blood pressure; ECG=electrocardiograph; GP=general practitioner; ISRCTN=International Standard Randomised Controlled Trial Number; KQ=key question; NCT=National Clinical Trial Number; N=number; NL=Netherlands Trial Registry; NR=not reported; SAFE=Screening for Atrial Fibrillation in the Elderly; SD=standard deviation; U.K.=United Kingdom; U.S.=United States.

### Study Characteristics

We rated five studies as good methodological quality^56,^ ^75,^ ^91,^ ^112,^ ^115^ and four studies as fair methodological quality.^113,^ ^114,^ ^116,^ ^117^ One study was conducted in the United States,^114^ one study was conducted in Canada and Germany,^75^ and the rest were conducted in various European countries. One study was conducted over the years 2000 through 2003,^91^ and rest were conducted in 2011 or later. Five studies enrolled participants from general practices,^75,^ ^91,^ ^112,^ ^113,^ ^116^ while the others enrolled participants from outpatient specialty clinics (e.g., cardiology, diabetes and hypertension clinics). The mean age of study participants ranged from 66 to 80 years, and the percentage of participants who were female ranged from 37 to 59 percent. The proportion of participants with known AF at enrollment ranged from 0 to 27 percent. Only two studies reported on predicted stroke or bleeding risk at baseline; in these studies, the median CHA_2_DS_2_-VASc score was 4.^56,^ ^75^

The screening tests evaluated in these studies varied. Four studies evaluated the accuracy of oscillometric blood pressure monitors with automated irregular pulse/AF detection features against a reference standard of a 12-lead ECG interpreted by one or more cardiologists^113–115^ or against a reference standard of continuous patch ECG for two 2-week intervals (total 4 weeks).^75^ Two studies evaluated single-lead ECG devices with AF detection features against a reference standard of a 12-lead ECG interpreted by two independent cardiologists.^112,^ ^113^ One study evaluated a six-lead ECG automated diagnostic report produced using a custom algorithm compared with a reference standard of a 12-lead ECG interpreted by cardiology.^117^ One study evaluated GP interpretation of a 12-lead ECG conducted in a primary care office setting against interpretation by two independent cardiologists.^91^ This study also evaluated the accuracy of GP-interpreted single limb or thoracic leads against the same reference standard (i.e., cardiologist interpretation). One study evaluated the accuracy of a combined test with three components: pulse palpation, oscillometric BP with automated AF detection, single-lead ECG with automated AF detection compared with a reference standard of 12-lead ECG interpreted by cardiology. Of note, in this study, only a 10% random sample of persons with negative index test received the reference standard. Lastly, one study evaluated the accuracy of a two-channel, 72-hour Holter monitor adjudicated by two cardiologists against a reference standard of an insertable cardiac monitor interpreted by two electrophysiologists.^56^

### Results of Included Studies

Accuracy results are summarized in Table 3 with additional details in Appendix F Table 8. Across the included tests, we estimate that in a population of 1,000 persons with a prevalence of undiagnosed AF of 1.3 percent (based on CQ 1), the number of true-positive tests would range from 4 to 13, false-positive tests would range from 0 to 237, false-negative tests would range from 0 to 9, and true-negative tests would range from 750 to 987.

Table 3 Results of Included Test Accuracy Studies (KQ 3)

Study | Sensitivity (95% CI) | Specificity (95% CI) | Per 1,000 tests (1.3% prevalence of AF)
Study | Sensitivity (95% CI) | Specificity (95% CI) | No. of false negatives | No. of false positives
Oscillometric BP monitor with automated AF detection vs. 12-lead ECG interpreted by cardiology
Kearley et al, 2014^113^; (Microlife Watch BP Home A device) | 0.95 (0.88 to 0.99) | 0.90 (0.88 to 0.92) | 1 | 99
Marazzi et al, 2012^115^; (Microlife BP A200 device) | 0.92 (NR) | Calculated: 0.95; Study reported: 0.97 (NR) | 1 | 49
Marazzi et al, 2012^115^; (OMRON M6 device) | 1.0 (NR) | 0.94 (NR) | 0 | 59
Wiesel et al, 2014^114^; (Microlife BP A200 device) | 1.0 (0.86 to 1.0)^*^ | 0.92 (0.86 to 0.96) | 0 | 79
Wiesel et al, 2014^114^; (OMRON M6 device) | 0.30 (0.15 to 0.49)^*^ | 0.97 (0.93 to 0.99) | 9 | 30
Oscillometric BP monitor with automated AF detection vs. continuous ECG monitoring
SCREEN-AF, 2021^75^; (Microlife Watch BP Home A device) | 0.35 (0.15 to 0.59) | 0.81 (0.77 to 0.85) | 9 | 188
Single-lead ECG with automated AF detection vs. 12-lead ECG interpreted by cardiology
Himmelreich et al, 2019^112^; (KardiaMobile device) | 0.88 (0.47 to 1.0) | 1.0 (0.96 to 1.0) | 2 | 0
Kearley et al, 2014^113^; (OMRON device) | 0.99 (0.93 to 1.0) | 0.76 (0.73 to 0.79) | <1 | 237
Six-lead ECG with automated AF detection vs. 12-lead ECG interpreted by cardiology
Sabar et al, 2019^117^; (RhythmPad 6-lead ECG) | 0.95 (NR) | 0.99 (NR) | 1 | 10
GP-interpreted ECG vs. 12-lead ECG-interpreted by cardiology
SAFE, 2005^91^; (12-lead) | 0.80 (0.71 to 0.87) | 0.92 (0.90 to 0.93) | 3 | 79
SAFE, 2005^91^; (Single limb lead) | 0.83 (0.75 to 0.88) | 0.88 (0.87 to 0.90) | 2 | 118
SAFE, 2005^91^; (Single thoracic lead) | 0.85 (0.79 to 0.91) | 0.86 (0.84 to 0.88) | 2 | 138
Combined pulse palpation, oscillometric BP and single lead ECG both with automated AF detection vs. 12-lead ECG interpreted by cardiology
D2AF, 2020^116^; (MyDiagnostick device and MIcrolife Watch BP Home A device) | Cannot determine^†^ | Cannot determine^†^ | Cannot determine^†^ | Cannot determine^†^
72-hour continuous Holter monitoring vs. continuous ECG monitoring with insertable cardiac monitor over median 588 days ^ǂ^
Philippsen et al, 2017^56^ | Calculated: 0.12 | Calculated: 1 | NA | NA

* The author of this study disclosed holding a patent for the AF detection algorithm present in the Microlife BP device; we note that the sensitivity of the OMRON oscillometric device was markedly lower in this study when compared with the estimate for Microlife, and when compared with the OMRON device reported in the study by Marazzi et al.^115^

† The study only performed a 12-lead referent test on a random sample of participants who tested negative on the index screening test; thus data to determine sensitivity and specificity was not available. However, based on data reported, we calculated the positive predictive value to be 6% and the negative predictive value to be 100%; suggesting a test with very high sensitivity, but poor specificity.

ǂ Holter monitoring occurred approximately 1 month after ICM placement. When limited to the same 72-hour monitoring window, sensitivity was 1.0.

Abbreviations: AF=atrial fibrillation; BP=blood pressure; CI=confidence interval; D2AF= Detecting and Diagnosing Atrial Fibrillation; ECG=electrocardiograph; ICM=insertable cardiac monitor; KQ=key question; SAFE=Screening for Atrial Fibrillation in the Elderly.

#### Oscillometric BP Monitor With AF Detection vs. 12-Lead ECG Cardiology Interpretation

In four comparisons of two devices reported across three studies, sensitivity ranged from 0.92 to 1.0.^113–115^ In a fifth comparison reported by one of the studies, sensitivity for one of the two devices evaluated was reported as 0.3 (95% CI, 0.15 to 0.49).^114^ This estimate differed markedly from the sensitivity reported by the other monitor reported in the same study and from the same monitor used in a different study.^115^ We note the author of this study disclosed that he holds a patent for the AF detection algorithm for the device that demonstrated a higher sensitivity in his study.^114^ We could not identify any other characteristics that might explain this outlying finding. Specificity across all five comparisons ranged from 0.90 to 0.97.

#### Oscillometric BP Monitor With AF Detection vs. Continuous ECG

In the one study reporting the comparison of intermittent twice-daily oscillometric blood pressure monitor with AF detection feature and a reference continuous ECG monitored for a total of 4 weeks, the sensitivity was 0.35 (95% CI, 0.15 to 0.59) and the specificity was 0.81 (95% CI, 0.77 to 0.85).^75^ The lower sensitivity observed for this comparison is likely because of the use of a different reference standard, which is better suited for identifying paroxysmal AF than a one-time 12-lead ECG.

#### Single-Lead ECG With AF Detection vs. 12-Lead ECG Cardiology Interpretation

In one study,^112^ the sensitivity was 0.88 (95% CI, 0.47 to 1.0) and the specificity was 1.0 (95% CI, 0.96 to 1.0), while in a second study,^113^ the sensitivity was 0.99 (95% CI, 0.93 to 1.0) and specificity was 0.76 (95% CI, 0.73 to 0.79). These studies used different single-lead ECG devices and varied by population enrolled (one study included only persons age 18 years or older from general practices with nonacute indications for 12-lead ECG,^112^ while the other study enrolled persons age 75 years or older without other inclusion criteria).

#### Six-Lead ECG With AF Detection vs. 12-Lead ECG Cardiology Interpretation

In one study,^117^ the sensitivity was 0.95 and the specificity was 0.99 (95% CI NR). The study used a six-lead ECG device and enrolled participants (mean age 66) from outpatient cardiology clinics for routine ECG or other appointments.

#### GP ECG Interpretation vs. 12-Lead ECG Cardiology Interpretation

In the SAFE trial, interpretation of ECGs by GPs at each of the 25 participating intervention practices was compared with 12-lead ECG interpretation by a cardiologist.^91,^ ^94^ The sensitivity of GP-interpreted ECG compared with 12-lead ECG interpreted by a cardiologist ranged from 0.80 to 0.85 depending on whether the index test was a 12-lead, single-limb lead or a single thoracic-lead ECG. The specificity ranged from 0.86 to 0.92. Combining GP interpretation with interpretive software increased the sensitivity (0.92 [95% CI, 0.87 to 0.97]) but specificity was similar (0.91 [95% CI, 0.90 to 0.93]). The accuracy of individual GP interpretation varied greatly; sensitivity ranged from 0.5 to 1.0, and the proportion of false-positive readings for individual GPs ranged from 0 to 0.44.

#### Combined Strategy of Pulse Palpation, Oscillometric BP Measurement, and Single-Lead ECG With AF Detection

In the D2AF trial, a separate analysis of the screening intervention group evaluated the accuracy of combined strategy of pulse palpation with oscillometric BP measurement with automated AF detection and single-lead ECG with automated AF detection.^116^ The index test was considered positive if any one component of the test was positive. Of the 4,106 participants screened, 488 has a positive index text and of those 448 had a 12-lead ECG reference standard performed. Of those 448, 26 were confirmed to have AF. Of the 294 randomly sampled persons with negative index tests, zero were confirmed to have AF on 12-lead ECG. We were unable to calculate the sensitivity and specificity of the screening approach based on how the study was designed and reported. However, we calculated the positive predictive value of this screening approach to be six percent, and the negative predictive value to be 100 percent.

#### Holter Monitor vs. Insertable Cardiac Monitor

One study evaluated a two-channel, 72-hour continuous Holter monitoring compared with an insertable cardiac monitor.^56^ The Holter monitor was administered approximately 1 month after the insertable cardiac monitor was placed. Two cases of paroxysmal, but subclinical (i.e., no symptoms), AF were detected by Holter monitoring; these cases were also detected by the insertable cardiac monitor, suggesting a sensitivity of 1.0 when only considering the same 72-hour monitoring period covered by both devices. Over the entire duration of insertable cardiac monitoring (mean 588 days), an additional 15 cases of subclinical paroxysmal AF were detected for an overall sensitivity of 0.12. It is unclear whether these additional cases were prevalent cases of paroxysmal AF missed by the 72-hour Holter monitoring window or new onset paroxysmal AF cases. The specificity of Holter monitoring was 1.0. For those with newly identified AF, the median time to first AF episode based on insertable cardiac monitoring was 91 days (IQR, 41 to 251).

## KQ 4 What Are the Harms of Screening for AF in Older Adults?

We identified four RCTs that reported harms of screening; all were described in the KQ 1 and KQ 2 sections of this report and are in Table 1. One of them (SAFE^91^) was included in the prior review for the USPSTF, and three (mSToPS,^109^ STROKESTOP,^77,^ ^78,^ ^119^ SCREEN-AF^75^) are new to this update. The mSToPS study also included a prospective cohort component that reports outcomes relevant to this KQ. Detailed study characteristics are provided in Appendix F Table 9.

### Study Characteristics

In brief, the SAFE trial randomized 50 practices to screening or no screening and further randomized participants at the screening practices to invitations to attend a nurse-led screening clinic with pulse palpation and single- and 12-lead ECG or chart reminders encouraging clinician pulse palpation.^91^ The mSToPS trial randomized 2,659 participants to screening with two rounds of a 14-day continuous ambulatory ECG patch or delayed monitoring (i.e., no screening).^109^

After 4 months, the delayed monitoring group received the intervention. Parallel to the RCT component of mSToPS, study authors assembled an observational cohort consisting of 5,318 participants matched to participants in the RCT component. Participants in all components (immediate monitoring, delayed monitoring, matched controls with no monitoring) were followed over 1 year in a prospective cohort study. STROKESTOP randomized 28,768 participants to an invitation to twice-daily intermittent ECG screening with a handheld device or to a control group.{, #11220;, #8;, #55} Lastly, SCREEN-AF randomized 856 participants to continuous ECG for a total of 4 weeks, with the addition of a home blood pressure monitor with automated AF detection to be used twice daily during each 2-week ECG monitoring period.{, #11215}

### Results of Included Studies

Outcomes reported by studies varied. SAFE reported anxiety, STROKESTOP and SCREEN-AF reported bleeding outcomes, mSToPS and SCREEN-AF reported frequency of non-AF arrhythmias and skin irritation from the ECG patch, and mSToPS, STROKESTOP, and SCREEN-AF reported subsequent procedures or medication use. Detailed results are provided in Appendix F Table 10. No eligible studies were identified that assessed labeling or consequences of subsequent procedures or interventions initiated because of screening with ECG, or harms related to false-positive results. We remind readers that diagnostic accuracy, including the estimated number of false-positive results, is reported in the KQ 3 results section of this report.

#### Anxiety

The SAFE study assessed anxiety using the Spielberger Six-Item Anxiety Questionnaire (S6AQ), a measure of general anxiety, but did not collect anxiety data from patients within the no-screening arm of the study.^91^ The study evaluated anxiety in the invitation for ECG screening and pulse palpation reminder screening groups at three different time points among 750 patients (out of more than 9,000 in the screening groups) before randomization, 1,940 patients immediately after ECG screening, and 535 patients 17 months after baseline.^91,^ ^120^ Anxiety levels were not significantly different between the groups at baseline, immediately after screening, or at 17 months after adjusting for baseline scores (Appendix F Table 10). When comparing screen-positive and screen-negative respondents, anxiety scores collected 17 months after initial chart review were significantly different (p=0.028), with screen-positive participants having higher mean anxiety scores (38.12 [95% CI, 35.89 to 40.35]) than screen-negative participants (34.61 [95% CI, 32.41 to 36.81]) (unadjusted p=0.028), although relatively few participants were included in that analysis (142 screen-positive and 128 screen-negative participants), and most participants did not have clinically meaningful levels of anxiety symptoms (i.e., greater than 39 to 40); thus, the clinical importance of the difference is likely low.^91^

#### Bleeding Outcomes

In STROKESTOP, the rate of hemorrhagic stroke was 0.16 events per 100 person-years in the invitation-to-screening group compared with 0.18 in the control group (HR 0.88 [95% CI, 0.70 to 1.11]).^76^ The rate of hospitalization for major bleeding was 1.71 events per 100 person-years in the invitation-to-screening group compared with 1.74 in the control group (HR 0.98 [95% CI, 0.91 to 1.06]). In SCREEN-AF, authors reported zero intracranial hemorrhages.^75^ Further, among those with AF or who were prescribed oral anticoagulations, zero major bleeding events were observed.

#### Frequency of Non-AF Arrhythmias

The mSToPS trial reported potentially actionable arrhythmias other than AF in 70 participants (2.6%), including nonsustained ventricular tachycardia, prolonged or symptomatic supraventricular tachycardia, significant pause or high-degree atrioventricular block, and very frequent ectopy.^109^ The study did not report whether identification of those arrhythmias led to subsequent benefits or harms. Similarly, SCREEN-AF reported the frequency of various non-AF arrythmias, which ranged from 0 percent to 3.9 percent depending on the type of arrhythmia (Appendix F Table 10).^75^ Similar to mSToPS, the arrhythmias identified would likely be considered clinically actionable, but it is not known whether further action led to benefit or harm.

#### Subsequent Procedures or Interventions

The mSToPS cohort study reported the number of treatments and procedures over the course of 12 months for the combined screening groups (1,738 participants in the immediate and delayed intervention group) and matched controls (3,476 participants; matched on age, sex, and CHA_2_DS_2_-VASc) with 12 month followup data but did not report on benefits or harms from those treatments or procedures. The study authors also do not report whether those undergoing further treatment or procedures were diagnosed clinically or were screen detected through patch monitoring.^109^ Participants in the combined screening groups had higher rates of initiation of anticoagulation for AF, antiarrhythmic medication use, cardioversion procedures, cardiac ablations, pacemaker or defibrillator placements, and outpatient cardiology visits compared with matched controls who did not receive any screening intervention.(Appendix F Table 10). In the SCREEN-AF trial, no statistically significant differences were reported for ED visits, hospitalizations, or pacemaker implantations, although all of these events were rare in both the screening and control groups.^75^ A significantly higher number of participants initiated oral anticoagulant therapy in the screening group compared with the control group (ARD 3.2% [95% CI, 1.1 to 5.3]; RR 4.4 [95% CI, 1.5 to 2.8]). In STROKESTOP, a numerically higher number of participants initiated oral anticoagulants in the invitation-to-screening group at all time points through 7 years of followup (e.g., 11.3% vs. 10.8% at 1-year followup), but these differences were not statistically significant.^76^

#### Skin Irritation

The mSToPS trial reported that 40 participants (1.5%) had skin irritation from wearing an ECG patch. Of those, 32 discontinued wearing the patch, and two sought medical attention and received topical therapy. In SCREEN-AF, five participants (1.2% [95% CI, 0.5% to 2.7%]) reported skin irritation from the patch.^75^ The methods of ascertainment of skin irritation were not reported in either trial, and it is unclear whether participants were systematically asked about or evaluated for skin irritation.

#### Subgroup Findings

We did not find eligible studies reporting whether harms of screening differed for subgroups defined by stroke risk (e.g., based on CHA_2_DS_2_-VASc score), age, sex, or race/ethnicity.

## KQ 5 What Are the Benefits of Anticoagulation Therapy on Health Outcomes in Asymptomatic, Screen-Detected Older Adults With AF?

We found no new trials or systematic reviews that addressed this KQ. For the current review, this KQ was updated to reflect the current standard of care for stroke prevention, which includes anticoagulation but not antiplatelet therapy. Therefore, this section has been revised from the prior review to remove evidence pertaining solely to antiplatelet therapy. In our prior review, our meta-analysis of four trials of aspirin vs. no aspirin found no statistically significant differences in all-cause mortality, cardiovascular mortality, all ischemic stroke, disabling stroke, and ischemic stroke or intracranial hemorrhage.^2^

Although we aimed to determine the benefits of treatment for screen-detected older adults with AF, we found no trials or systematic reviews that focused solely on this population. We included five RCTs of persons who were not screen detected;^97–102^ most had long-standing, persistent nonvalvular AF; few had a history of TIA or stroke (<8%); and prevalence of baseline or past symptoms (e.g., palpitations, dyspnea) was generally not reported. Three trials evaluated warfarin^97,^ ^99,^ ^100^ and two (described in three articles) evaluated both warfarin and aspirin.^98,^ ^101,^ ^102^ The characteristics of the included RCTs are summarized in Tables 4 and 5, and the results are summarized in Figure 4 and Appendix F Table 11.

Table 4 Characteristics of Included Randomized, Controlled Trials for KQ 5 and KQ 6: Part 1

First Author, Year; Trial Name | G1 (N); G2 (N); G3 (N) | Source of Patients | Country | Mean Followup, yr | Mean Age | % Female | % Non-White | Study Quality
Petersen et al, 1989^102^; AFASAK | Warfarin, adjusted dose (335); Aspirin 75 mg daily (336); Placebo (336) | Those with chronic AF from 2 outpatient ECG laboratories | Denmark | 1.2 | 74 (median) | 46 | NR | Fair
The Boston Area Trial for Atrial Fibrillation Investigators, 1990^100^; BAATAF | Warfarin, adjusted dose (212); Control^*^ (208) | 32 centers and 3 private medical offices | U.S. | 2.2 | 68 | 28 | NR | Fair
Stroke Prevention in Atrial Fibrillation Investigators, 1990 & 1991^98,^ ^101^; SPAF I | Warfarin, adjusted dose (210); Aspirin 325 mg/day (206); Placebo (211) | 15 centers | U.S. | 1.3 | 67 | 29 | 16 | Fair
Connolly et al, 1991^99^; CAFA | Warfarin, dose adjusted per subject (187); Placebo (191) | 11 centers (hospitals, outpatient laboratories, and direct clinician referrals) | Canada | 1.3 | 68 | 25 | NR | Fair
Ezekowitz et al, 1992^97^; SPINAF | Warfarin, adjusted dose (4-mg/day and adjusted to meet PT ratios) (260); Placebo (265)^†^ | 16 Department of Veterans Affairs medical centers | U.S. | 1.7 | 67 | 0 | NR | Fair

* Control group was allowed to take aspirin.

† Study reported findings separately for patients with and without previous cerebral infarctions. Patients with previous cerebral infarction: warfarin (21) vs. control (25).

Abbreviations: AF=atrial fibrillation; AFASAK=Atrial Fibrillation, ASpirin, and AntiKoagulation; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation study; ECG=electrocardiograph; G=group; KQ=key question; N=sample size; NR=not reported; SPAF=Stroke Prevention in Atrial Fibrillation Study; SPINAF=Stroke Prevention in Nonrheumatic Atrial Fibrillation study; U.S.=United States.

Table 5 Characteristics of Included Randomized, Controlled Trials for KQ 5 and KQ 6: Part 2

First Author, Year; Trial Name | % TIA; % Stroke | % Heart Failure; % Heart Valve Disease; % Coronary Artery Disease; % Hypertension; % Diabetes Mellitus | Target INR (PT) | % Time in Therapeutic Range
Petersen et al, 1989^102^; AFASAK | 2; 4 | 52; NR; 8 prior myocardial infarction; 32; 12 | 2.8 to 4.2 (NR) | 73
The Boston Area Trial for Atrial Fibrillation Investigators, 1990^100^; BAATAF | NR; 3 | 26; 23 mitral regurgitation >1+; 52; 51; 15 | 1.5 to 2.7 (1.2 to 1.5) | 83
Stroke Prevention in Atrial Fibrillation Investigators, 1990 & 1991^98,^ ^101^; SPAF I | 7 stroke or TIA | 19; 6 mitral valve prolapse; 8 prior myocardial infarction; 52; 16 | 2 to 4.5 (1.3 to 1.8) | 71 within target prothrombin time
Connolly et al, 1991^99^; CAFA | 4 stroke or TIA | 22; NR; 13 prior myocardial infarction; 39; 12 | 2 to 3 (NR) | 44
Ezekowitz et al, 1992^97^; SPINAF | NR; 8 | 30; 15 mitral regurgitation>1+; 19 prior myocardial infarction; 58; 18 | 1.4 to 2.8 (1.2 to 1.5) | 56

Abbreviations: AFASAK=Atrial Fibrillation, ASpirin, and AntiKoagulation; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation study; INR=international normalized ratio; NR=not reported; PT=prothrombin time; SPAF=Stroke Prevention in Atrial Fibrillation Study; SPINAF=Stroke Prevention in Nonrheumatic Atrial Fibrillation study; TIA=transient ischemic attack.

Figure 4 Benefits and Harms of Warfarin Compared With Placebo/Control

Figure Notes: All-cause mortality: SPINAF includes only those without a history of stroke. AFASAK includes data from a previously published meta-analysis that they obtained data from the original study authors.

Major bleeding: AFASAK did not specify bleeding severity of most bleeding events; it reported 1 fatal intracerebral hemorrhage in the warfarin group and only reported bleeding events leading to withdrawal from the study, 21 for warfarin and 0 for placebo. BAATAF defines major bleeding as intracranial bleeding, fatal bleeding, or bleeding that led to a blood transfusion (four or more units of blood within 48 hours). SPAF I defines major bleeding as bleeding that involved the central nervous system, management requiring hospitalization with transfusion and/or surgery, or permanent residual impairment. CAFA defines major bleeding as life-threatening bleeding. SPINAF defines major bleeding as bleeding that required a blood transfusion, an emergency procedure, or removal of a hematoma or bleeding that led to ICU admission.

Intracranial Hemorrhage: SPAF I events included one fatal intracerebral hemorrhage and one subdural hematoma with full recovery in the warfarin group, and two subdural hematomas with full recovery in the placebo group.

Abbreviations: AFASAK=Atrial Fibrillation, ASpirin, and AntiKoagulation; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation study; CG=control group; CI=confidence interval; ICU=intensive care unit; IG=intervention group; INR=international normalized ratio; No.=number; RR=risk ratio; SPAF=Stroke Prevention in Atrial Fibrillation Study; SPINAF=Stroke Prevention in Nonrheumatic Atrial Fibrillation study.

Figure 4 is titled “Benefits and Harms of Warfarin Compared with Placebo/Control.” This figure displays a forest plot reporting the risk ratio for all-cause mortality, cardiovascular-related mortality, all ischemic stroke, moderately to severely disabling stroke, all ischemic stroke or intracranial hemorrhage, major bleeding, major extracranial bleeding, and intracranial hemorrhage in five studies (AFASAK I, 1989; BAATAF, 1990; SPAF I, 1991, CAFA, 1991; SPINAF, 1992). Across trials, 154 all-cause mortality events occurred. Warfarin treatment was associated with a lowered risk of all-cause mortality compared with controls, but the difference was not statistically significant with the pooled risk ratio being 0.68 (95% CI, 0.50 to 0.93). Across trials, 84 cardiovascular-related mortality events occurred. Warfarin treatment was associated with a lowered risk of cardiovascular-related mortality compared with controls, but the difference was not statistically significant with the pooled risk ratio being 0.66 (95% CI, 0.33 to 1.29). Across trials, 96 all ischemic stroke events occurred. Warfarin treatment was associated with a lowered risk of cardiovascular-related mortality compared with controls with the difference being statistically significant with the pooled risk ratio being 0.32 (95% CI, 0.20 to 0.51). Across trials, 38 moderately to severely disabling stroke events and 104 all ischemic stroke or intracranial hemorrhage occurred. Warfarin treatment was associated with a lowered risk of both moderately to severely disabling stroke and all ischemic stroke or intracranial hemorrhage with the difference being statistically significant with the risk ratio being 0.38 (95% CI, 0.19 to 0.78) and 0.38 (95% CI, 0.25 to 0.59), respectively. Across trials, 31 major bleeding events occurred. Warfarin treatment was associated with an increased risk of major bleeding compared with controls, but the CI was wide, and the difference between groups was not statistically significant with the pooled risk ratio being 1.8 (95% CI, 0.85 to 3.7). Across trials, 23 major extracranial bleeding events occurred. Warfarin treatment was associated with an increased risk of major extracranial bleeding compared with controls, but the CI was wide, and the difference between groups was not statistically significant with the pooled risk ratio being 1.6 (95% CI, 0.67 to 3.6). Across trials 8 intracranial hemorrhage events occurred. Warfarin treatment was associated with an increased risk of intracranial hemorrhage compared with controls, but the CI was wide, and the difference between groups was not statistically significant with the pooled risk ratio being 1.9 (95% CI, 0.56 to 6.7).

In addition to the included RCTs, we included five systematic reviews comparing warfarin to placebo (Appendix F Table 13): two were traditional systematic reviews with meta-analyses,^59,^ ^104^ two were meta-analyses of individual patient data,^96,^ ^107^ and one was a network meta-analysis.^106^ The systematic reviews included a total of 38 unique studies (including the 5 RCTs in our review). Many of the studies included in other systematic reviews were not eligible for this review because they evaluated secondary prevention (i.e., evaluated treatments for persons with a history of TIA or stroke in addition to addressing primary prevention) or because they compared one active treatment to another active treatment (most of the 21 studies included in the network meta-analysis were such studies).

### Study Characteristics of Included RCTs

Five trials (described in 6 articles) evaluated warfarin.^97–102^ All trials were rated fair quality. Four of the five trials compared warfarin with a placebo (Atrial Fibrillation, ASpirin, and AntiKoagulation study [AFASAK I],^102^ Canadian Atrial Fibrillation Anticoagulation [CAFA],^99^ Stroke Prevention in Atrial Fibrillation [SPAF I],^98,^ ^101^ Stroke Prevention in Nonrheumatic Atrial Fibrillation [SPINAF]^97^) and one (Boston Area Anticoagulation Trial for Atrial Fibrillation [BAATAF])^100^ compared warfarin with no treatment. BAATAF allowed participants in the no-treatment group to take aspirin (and 46% of all patient years in the control group were contributed by participants taking aspirin), but use of aspirin or other antithrombotic medications was not permitted in the four placebo-controlled trials. Two trials (AFASAK I and SPAF I) were three-arm studies that included aspirin arms (in addition to warfarin and placebo or no treatment). Two trials were double blind (CAFA, SPINAF), and three were open label (AFASAK I, BAATAF, SPAF I). Three trials were conducted in the United States (BAATAF, SPAF I, and SPINAF), one in Canada (CAFA), and one in Denmark (AFASAK I). Mean duration of followup ranged from 1.2 to 2.2 years. All five trials began in the 1980s and were completed by 1992. All five trials were stopped early, primarily because of evidence favoring warfarin for stroke reduction.

None of the trials focused on participants who were detected by screening in primary care or the general population. The mean age of participants ranged from 67 to 74 years. Most participants were men, with four out of five trials enrolling fewer than 30 percent women. Just one trial reported any information about the race or ethnicity of participants (16% were non-White in SPAF I). Few participants had a history of TIA or stroke (range 3% to 8%). The baseline prevalence of hypertension and diabetes ranged from 32 to 58 percent and 12 to 18 percent, respectively. AFASAK I and SPINAF did not include participants with paroxysmal AF; the other three trials reported that 7 percent to 34 percent had paroxysmal AF. Most participants in the trials had AF for more than a year. Three trials (CAFA, SPAF I, and BAATAF) reported that between 19 percent and 32 percent had AF for less than a year; SPINAF I reported that 12 percent had AF less than 6 months (and a mean duration of AF of 8 years); and AFASAK I did not report information about the duration of AF before enrollment. Baseline stroke risk (e.g., CHADS_2_) was not reported by any of the trials because stroke risk scores used in current practice were not yet developed; some future publications have used the baseline characteristics of subjects to estimate that the mean CHADS_2_ scores of participants in these trials ranged from 1 to 1.6.^106^

All trials titrated doses of warfarin on the basis of either prothrombin time (PT) or international normalized ratio (INR). The INR target ranges spanned from 1.4 to 4.5. The mean INRs achieved ranged from 2 to 2.6. The reported time in therapeutic range (TTR) spanned from 44 percent (CAFA) to 83 percent (BAATAF), and three trials reported TTR over 70 percent (SPAF I, AFASAK I, and BAATAF).

### Results of Included RCTs

In our meta-analysis, warfarin treatment over an average of 1.5 years was associated with reductions in all-cause mortality (pooled RR, 0.68 [95% CI, 0.50 to 0.93]; I^2^=0%; 5 trials; 2,415 participants), ischemic stroke (pooled RR, 0.32 [95% CI, 0.20-0.51]; I^2^=0%), and moderately to severely disabling stroke (pooled RR, 0.38 [95% CI, 0.19 to 0.78]; I^2^=0%) compared with controls (Figure 4). For a population with baseline annual stroke risk of 4 percent, such as patients with CHA_2_DS_2_-VASc scores between 3 and 4, the results indicate that warfarin was associated with a NTT of 24 (95% CI, 17 to 36) to prevent one ischemic stroke over 1.5 years. For a population of 1,000 adults age 65 years or older with an annual stroke risk of 4 percent, this translates to an absolute reduction of 28 ischemic strokes per year and an absolute reduction of 16 deaths per year. Our meta-analyses found no statistically significant difference between groups for cardiovascular-related mortality or TIA, but trials reported relatively few events for those outcomes and CIs were wide (Figure 4 and Appendix G Figure 1).

### Results of Previously Published Systematic Reviews and Meta-Analyses

Results of previously published systematic reviews^59,^ ^96,^ ^104,^ ^106,^ ^107^ were consistent with our findings and are summarized in Appendix F Table 13. Here we highlight the findings from those reviews that provide additional information (beyond what we have described already in this KQ). Overall, the included systematic reviews provide some additional details about subgroups (from individual patient data meta-analyses) and some information about head-to-head comparisons, including comparisons with DOACs.

One systematic review from the Cochrane collaboration evaluated warfarin compared with placebo for primary prevention.^104^ It included the same five RCTs in our review but obtained unpublished data excluding the 3 to 8 percent of participants with prior stroke or TIA. The findings were very similar to those of our meta-analyses: they reported OR, 0.69 (95% CI, 0.50 to 0.94) for all-cause mortality vs. our pooled RR, 0.68 (95% CI, 0.50 to 0.93).

#### Subgroup Findings

Two individual patient data meta-analyses used the Atrial Fibrillation Investigators database from clinical trials evaluating warfarin.^96,^ ^107^ That database included all five warfarin trials described in this report (AFASAK I, CAFA, SPAF I, SPINAF, BAATAF). One evaluated subgroups based on sex and history of hypertension for warfarin,^107^ and one evaluated whether benefits vary by age for warfarin.^96^

The individual patient data meta-analysis that evaluated subgroups based on sex and history of hypertension^107^ used the same five RCTs evaluating warfarin that we included in our analysis. It reported that the efficacy of warfarin was consistent across subgroups. Warfarin was associated with a reduction in stroke for both males and females, without a statistically significant difference between them (relative risk reduction, 60% [35% to 76%] and 84% [55% to 95%], respectively).

The individual patient data meta-analysis that evaluated subgroups based on age^96^ used the same five RCTs evaluating warfarin that we included in our analysis, but also included a secondary prevention trial (EAFT, which involved 439 participants treated with warfarin or placebo).^121^ Warfarin was associated with a reduced risk of ischemic stroke (compared with placebo/control) for all ages; for the assessment of relative benefit with increasing age, the interaction did not reach statistical significance (e.g., HR, 0.22 [95% CI, 0.11 to 0.41] for 50-year-olds; HR, 0.53 [0.35 to 0.81] for 90-year-olds, interaction of age and warfarin, p=0.07).

#### Previously Published Network Meta-Analysis

The one included network meta-analysis used 21 RCTs (96,017 participants) of treatment for nonvalvular AF.^106^ It was not limited to primary prevention populations, but most of the data were from studies in which most of the particiants had no history of stroke or TIA. Four of the 21 RCTs reported that more than 35 percent of their participants had a history of stroke or TIA: 100 percent in the European Atrial Fibrillation Trial (EAFT) (warfarin vs. aspirin vs. placebo), 64 percent in the Japanese Rivaroxaban Once Daily Oral Direct Factor Xa Inhibition Compared with Vitamin K Antagonism for Prevention of Stroke and Embolism Trial in Atrial Fibrillation (rivaroxaban vs. warfarin), 55 percent in the Rivaroxaban Once Daily Oral Direct Factor Xa Inhibition Compared with Vitamin K Antagonism for Prevention of Stroke and Embolism Trial in Atrial Fibrillation (rivaroxaban vs. warfarin), and 38 percent in SPAF III (low-intensity fixed-dose warfarin adjusted to INR, 1.2 to 1.5 combined with aspirin 325 mg once daily vs. adjusted-dose warfarin with target INR, 2.0 to 3.0). The percentage of participants with a history of stroke or TIA was less than 10 percent in nine trials (AFASAK I, BAATAF, SPAF I, CAFA, SPAF II, AFASAK II, the Primary Prevention of Arterial Thromboembolism in Nonrheumatic Atrial Fibrillation study, Swedish Atrial Fibrillation Trial, and JAST) and ranged from 13 to 28 percent in the other eight included trials. Limitations of the network meta-analysis include (1) the lack of sensitivity analyses removing the studies with greater focus on secondary prevention, (2) limited ability to adjust for population characteristics (because some included studies were older and did not report CHADS_2_ scores, and they were estimated from baseline characteristics), and (3) heterogeneity of doses in intervention and control groups.

The primary efficacy outcome was the combination of stroke (of any type) and systemic embolism. All-cause mortality was the secondary efficacy outcome. The authors provided both unadjusted results and results adjusted for population characteristics (CHADS_2_ scores, TTR, duration of followup). The analysis found that all treatments (VKAs, all four DOACs) reduced the risk of the primary and secondary efficacy outcomes compared with placebo/control (Appendix F Table 13). Effect sizes for VKAs compared with placebo/control were nearly identical to those from our pairwise meta-analyses for warfarin compared with placebo or no treatment. For the four DOACs (apixaban, dabigatran, edoxaban, and rivaroxaban) included in the analysis, the authors reported statistically significant associations with reduction in the primary outcome compared with placebo (unadjusted ORs from 0.27 to 0.38; adjusted ORs from 0.32 to 0.44), but no statistically significant differences for the four DOACs in comparison with one another. In adjusted analyses, the DOACs were not statistically different from VKAs for either efficacy outcome.

## KQ 6 What Are the Harms of Anticoagulation Therapy in Asymptomatic, Screen-Detected Older Adults With AF?

We did not identify any studies focused exclusively on asymptomatic, screen-detected older adults with AF. The five RCTs reported for KQ 5 among persons with clinical, mostly persistent AF also reported on harms.^97–102^ We also included six systematic reviews (5 were also included for KQ 5): three were traditional systematic reviews with meta-analyses,^59,^ ^103,^ ^104^ two were individual patient data meta-analyses,^96,^ ^107^ and one was a network meta-analysis.^106^ For this update, we identified one new cohort study that reported harms.^110^ We remind readers that harms of anticoagulation therapy apply to persons with accurately diagnosed AF, but also to persons treated with anticoagulation because of a false-positive screening test that was either not confirmed with an appropriate diagnostic test or who may have received an inaccurate diagnosis even after subsequent diagnostic testing. Screening test accuracy including estimates of false-positive screening test are described in the KQ 3 section of this report.

### Study Characteristics

The five RCTs included for this KQ were previously described in the KQ 5 section and are summarized in Tables 4 and 5. The included cohort study, GARFIELD-AF, is a fair-quality, ongoing, prospective, patient registry of newly diagnosed nonvalvular AF from 1,048 primary and specialty clinics across 32 countries (n=28,628).^110^ Participants were 18 years or older with at least one stroke risk factor. Median age (IQR) was 71 years (63 to 78 years), and 44 percent were female. Participants received warfarin, DOACs, antiplatelet agents, combination therapies or no treatment. Results are reported for 2 years of followup. Study characteristics are detailed in Appendix F Table 12.

### Results of Included RCTs

#### Major Bleeding

Across trials, 31 major bleeding events occurred, 20 in warfarin groups and 11 in placebo/control groups. Warfarin treatment over an average of 1.5 years was associated with an increased risk of major bleeding compared with controls, but the CI was wide, and the difference between groups was not statistically significant (pooled RR, 1.8 [95% CI, 0.85 to 3.7]; I^2^=0%; 5 trials; 2,415 participants) (Figure 4).

#### Major Extracranial Bleeding

Across trials, 23 events occurred, 14 in warfarin groups and nine in control groups. Warfarin treatment over an average of 1.6 years was associated with an increased risk of major extracranial bleeding compared with controls, but the CI was wide, and the difference between groups was not statistically significant (pooled RR, 1.6 [95% CI, 0.67 to 3.6]; I^2^=0%; 4 trials; 1,744 participants) (Figure 4).

#### Intracranial Hemorrhage

Eight intracranial hemorrhages occurred, six in warfarin groups and two in control groups. Warfarin treatment over an average of 1.5 years was associated with an increased risk of intracranial hemorrhage compared with controls, but the CI was wide, and the difference between groups was not statistically significant (pooled RR, 1.9 [95% CI, 0.56 to 6.7]; I^2^=0%; 5 trials; 2,415 participants) (Figure 4).

#### Minor Bleeding

A total of 222 minor bleeding events occurred, 136 in warfarin groups and 86 in control groups. Warfarin treatment over an average of 1.6 years was associated with an increase in minor bleeding compared with controls (pooled RR, 1.6 [95% CI, 1.2 to 2.0]; I^2^=0%; 4 trials; 1,744 participants) (Appendix G Figure 2).

### Results of Observational Studies

In GARFIELD-AF, major bleeding was reported in 1.3 percent of participants (0.71 events per 100 person-years [95% CI, 0.64 to 0.79]). Nonmajor bleeding was reported in 1.8 percent of participants (n=500). Of all bleeding events, 6.9 percent (n=60) were fatal. The adjusted HR for first occurence of major bleeding was 1.73 (95% CI, 1.33 to 2.25) for participants receiving treatment compared with participants receiving no treatment. This estimate was adjusted for age, race/ethnicity other than Caucasian/Hispanic/Latino, smoking, diabetes, history of stroke, TIA or systemic embolism, history of bleeding, cardiac failure, renal disease, nonparoxysmal AF, and vascular disease (Appendix F Table 12).

### Results of Previously Published Systematic Reviews and Meta-analyses

Results of six previously published systematic reviews^59,^ ^96,^ ^103,^ ^104,^ ^106,^ ^107^ were consistent with our findings and are summarized in Appendix F Table 13. Here we highlight the findings from those reviews that provide additional information (beyond what we have described already in this KQ). Overall, the included systematic reviews provide some additional details about subgroups (from individual patient data meta-analyses) and some information about active treatment comparisons, including comparisons with DOACs.

One systematic review from the Cochrane collaboration evaluated warfarin for primary prevention.^104^ It included the same five RCTs in our review but obtained unpublished data excluding the 3 to 8 percent of participants with prior stroke or TIA. The findings were very similar to those of our meta-analyses, they reported OR for intracranial hemorrhage 2.38 [95% CI, 0.54 to 10.5] vs. our pooled RR result, 1.94 [95% CI, 0.56 to 6.68]).

#### Subgroups

Two of the individual patient data meta-analyses provided information about whether the risk of harms varies for subgroups.^96,^ ^107^ Both used the Atrial Fibrillation Investigators database of clinical trials evaluating warfarin or aspirin. That database included all five warfarin compared with placebo/control trials described in this report (AFASAK I, CAFA, SPAF I, SPINAF, BAATAF).

One meta-analysis of individual patient data concluded that the small number of patients with intracranial bleeding does not allow for reliable conclusions about whether the risk varies for subgroups.^107^ They also reported that the six warfarin-treated patients who had intracranial bleeding had higher blood pressure than warfarin-treated patients who did not have intracranial bleeding (169/93 vs. 141/83 mm Hg, p=0.001 for systolic and p=0.016 for diastolic). The mean age for patients with intracranial bleeding events was higher than for those without bleeding, but the difference between groups was not statistically significantly different (73 vs. 69 years, p-value not significant and not reported).

The other individual patient data meta-analysis evaluated subgroups based on age for risk of serious hemorrhage (intracranial hemorrhages or major bleeding).^96^ The analyses used the same five RCTs evaluating warfarin that we included, but also included a secondary prevention trial (EAFT). They found that warfarin did not interact significantly with patient age for serious hemorrhage (data not reported by study; shown in figures only).

#### Previously Published Network Meta-Analysis

The one included network meta-analysis used 21 RCTs (96,017 participants) of treatment for nonvalvular AF and is described in KQ 5.^106^ The primary safety outcome was major bleeding (the combination of major extracranial bleeding and intracranial hemorrhage). The authors provided both unadjusted results and results adjusted for population characteristics (CHADS_2_ scores, TTR, duration of followup). Effect sizes for VKAs compared with placebo/control were nearly identical to those from our pairwise meta-analyses for warfarin compared with placebo/control (Appendix F Table 13). Similarly, for the four DOACs (apixaban, dabigatran, edoxaban, and rivaroxaban), the authors reported adjusted ORs ranging from 1.38 to 2.21 for major bleeding in indirect comparisons to placebo/no treatment controls; the CIs were wide and findings were not statistically significant (Appendix F Table 13). Further, there were no statistically significant differences between any of the four DOACs with respect to bleeding. Compared with VKAs, three of the DOACs (apixaban, dabigatran, and edoxaban) were associated with a lower odds of bleeding (range of adjusted ORs from 0.64 to 0.85, but the difference was only statistically significant for edoxaban (adjusted OR, 0.64 [95% CI, 0.46 to 0.90]). For rivaroxaban compared with VKAs, the odds of major bleeding was higher but not statistically significant (adjusted OR, 1.03 [95% CI, 0.68 to 1.57]).