# Chapter 2 Methods

## Key Questions and Analytic Framework

The EPC investigators, USPSTF members, and the Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope and KQs for this review.

The analytic framework illustrates the KQs that guided the review (Figure 1).

1. Does screening for AF with selected tests improve health outcomes (i.e., reduce all-cause mortality, reduce morbidity or mortality from stroke, or improve quality of life) in asymptomatic older adults?
  a. Does improvement in health outcomes vary for subgroups defined by stroke risk (e.g., based on CHA_2_DS_2_-VASc score), age, sex, or race/ethnicity?
2. Does systematic screening for AF with selected tests identify older adults with previously undiagnosed AF more effectively than usual care?
3. What is the accuracy of selected screening tests for diagnosing AF in asymptomatic adults?
4. What are the harms of screening for AF with selected tests in older adults?
  a. Do the harms of screening vary for subgroups defined by stroke risk (e.g., based on CHA_2_DS_2_-VASc score), age, sex, or race/ethnicity?
5. What are the benefits of anticoagulation therapy on health outcomes in asymptomatic, screen-detected older adults with AF?
  a. Do the benefits of anticoagulation vary for subgroups defined by stroke or bleeding risk (e.g., based on CHA_2_DS_2_-VASc or HAS-BLED score), age, sex, race/ethnicity, or AF burden (i.e., number of episodes, duration of episodes, and proportion of time spent in AF)?
6. What are the harms of anticoagulation therapy in asymptomatic, screen-detected older adults with AF?
  a. Do the harms of anticoagulation therapy vary for subgroups defined by stroke risk or bleeding risk (e.g., based on CHA_2_DS_2_-VASc or HAS-BLED score), age, sex, race/ethnicity, or AF burden?

Figure 1 Analytic Framework

Figure 1 is titled “Analytic Framework.” This figure is the proposed analytic framework depicting the six key questions about screening with electrocardiography (ECG) within the context of the eligible populations, screenings/interventions, comparisons, outcomes, timing, and settings. In general, the figure illustrates the overarching question (key question 1): whether screening asymptomatic adults ages 50 or older with selected tests for atrial fibrillation leads to improved health outcomes. Health outcomes include all-cause mortality, stroke, stroke-related morbidity and mortality, and quality of life. The framework starts on the left with the patient population of interest: asymptomatic adults ages 50 or older. Moving from left to right, the figure depicts the ability of screening with selected tests to diagnose atrial fibrillation compared to usual care (key question 2), the diagnostic accuracy of selected screening tests (key question 3), and the potential harms of screening with selected tests (key question 4). For older adults with screen-detected atrial fibrillation, whether treatment with anticoagulation improves health outcomes (key question 5) or results in harms (key question 6) completes the framework on the right.

In addition to our KQs, we also looked for evidence related to two CQs.

1. What is the prevalence of previously unrecognized or undiagnosed AF in unselected or explicitly asymptomatic adults? Does the prevalence vary by age, primary care vs. community setting, method of diagnosis (e.g., single electrocardiogram vs. ambulatory ECG monitoring), sex, or race/ethnicity?
2. What is the stroke risk for the following populations?
  - Asymptomatic older adults with previously unrecognized or undiagnosed AF
  - Older adults with paroxysmal vs. persistent AF
  - Older adults with paroxysmal AF who have a lower vs. higher AF burden

We do not show these questions in the analytic framework because they were not analyzed using the same systematic review process as the KQs. They are intended to provide additional background information. Findings related to the CQs are summarized in Appendix B.

## Data Sources and Searches

We searched for English-language articles published through October 5, 2020, in MEDLINE^®^ via PubMed, the Cochrane Library, and the following clinical trial registries: Cochrane Central Register of Controlled Trials, clinicaltrials.gov, and the World Health Organization International Clinical Trials Registry Platform, which consolidates many non-U.S. clinical trials registries. Our literature search also included websites for the National Institute for Health and Care Excellence, the National Institutes of Health, the Centers for Disease Control and Prevention, the National Institute for Health Research (United Kingdom), and websites of relevant professional societies. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations and interventions. Appendix C1 describes the search strategies in detail. To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies meeting our inclusion criteria. We also manually reviewed all literature suggested by peer reviewers or Federal partners and, if appropriate, incorporated studies into the final review.

Since October 2020, we conducted active surveillance of the literature through article alerts and targeted searches of journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. We contacted study authors of ongoing studies relevant to KQ 1 to ascertain study completion status. The last surveillance was conducted on October 31, 2021, and four potentially relevant studies were identified through surveillance. Two of these studies have been incorporated into this report because we considered them essential to understanding the evidence and the related USPSTF recommendation.^75–78^ The third study was a phase 3 RCT comparing lower-dose (15 mg) edoxaban with placebo in elderly Japanese persons with AF who were not candidates for typical doses of oral anticoagulation.^79^ Findings from this study were similar to those reported by other studies of anticoagulation included in this report and did not change conclusions or the strength of evidence for the KQs on the benefits or harms of treatment (KQs 5 and 6). We deemed the fourth study not eligible for inclusion for an ineligible population and intervention;^80^ however, its findings offer contextual information regarding overdiagnosis, and the results are briefly summarized in the discussion section of this report.

## Study Selection

We developed inclusion and exclusion criteria for selecting studies based on populations, interventions, comparators, outcomes, timing, settings, and study designs; these are described in detail in Appendix C2. Based on public comments on the draft research plan for this update and discussions with the USPSTF, we expanded inclusion and exclusion criteria for this update in the following ways compared with the prior evidence report:^2^

- We expanded the eligible population to include adults age 50 years or older because some persons between ages 50 and 65 years would likely be eligible for stroke prevention if they had AF.
- We expanded the eligible screening approaches to non-ECG-based technologies, for example, photoplethysmography and AF-detection algorithms designed for use with oscillometric blood pressure monitors. We also specified that consumer-directed devices would be eligible for inclusion.
- We added diagnostic test accuracy studies, described eligible index tests and reference test comparators, and specified accuracy outcomes.
- We removed antiplatelet agents from the list of eligible treatments because this class of drugs is not recommended for treatment of AF to prevent strokes.

We included English-language studies conducted in countries categorized as very high on the Human Development Index.^81^ We excluded studies focused on adults with a history of stroke or TIA. For KQs 1, 2, and 4, we focused on unselected or explicitly asymptomatic adults age 50 years or older without known AF. For these KQs, we included randomized, controlled trials (RCTs) or nonrandomized, controlled trials of screening for AF (compared with no screening or nonsystematic screening) that reported health outcomes (KQ 1) including mortality, stroke, stroke-related morbidity and quality of life, comparative diagnostic yield (KQ 2), or harms (KQ 4). For the KQ on accuracy (KQ 3), we excluded diagnostic case-control study designs because of high risk of spectrum bias and excluded studies for which persons who were symptomatic or had known AF comprised 50 percent or more of the study population. For KQs 1 through 4, we included test accuracy studies or systematic reviews assessing index tests feasible for use in or referable from primary care including single-point-in-time tests typically conducted in an office setting (e.g., single- or 12-lead ECG, rhythm assessment via photoplethysmography or algorithms built into oscillometric blood pressure monitors), intermittent ambulatory strategies using ECG or other technologies, and two-stage screening approaches involving a single test followed by a second test. Pulse palpation and other components of a standard physical examination (e.g., heart auscultation) were not eligible as test strategies. For KQs 1 and 2, we required a no-screening or usual care (which could include pulse palpation) comparator. For KQ 3, we required studies to use one of the following reference tests: 12-lead ECG interpreted by cardiologist, continuous ambulatory ECG interpreted by cardiologist, or implantable cardiac monitor. For the KQs on treatment effectiveness and harms, we included RCTs and controlled trials or systematic reviews of RCTs comparing anticoagulation with placebo or no treatment that reported health outcomes (KQ 5) or harms (KQ 6). For the KQs on harms of screening and treatment, we also included large prospective cohort studies (i.e., enrolling >500 patients) or systematic reviews of prospective cohort studies. We excluded studies performed in emergency department, inpatient, and preprocedural settings.

Two independent reviewers screened titles and abstracts and then full-text articles for selection; disagreements were resolved by discussion or by a third reviewer. We included studies that we rated as fair or good methodological quality. We reassessed studies included in the prior 2018 review^2^ against the study selection and criteria for this update.

## Quality Assessment and Data Extraction

For each included study, one reviewer extracted relevant study characteristics (i.e., population, intervention, comparator) and data for eligible outcomes into a structured form. A second reviewer checked all data for completeness and accuracy, and the lead investigator reviewed all extracted information for consistency across included studies. We contacted study authors to clarify study data when needed.

Two senior reviewers independently assessed each study’s methodological quality using the Cochrane ROB 2.0 instrument^82^ and the predefined criteria developed by the USPSTF (Appendix C3),^83^ which uses study methodological quality ratings of poor, fair, and good. In addition to assessing the methodological quality of any newly identified studies, we reassessed the methodological quality of all previously included studies to ensure consistency of the approach. Disagreements in study quality ratings were resolved through discussion.

## Data Synthesis and Analysis

We synthesized data in tabular and narrative formats. For each KQ, we assessed whether a quantitative synthesis was appropriate by evaluating the number of studies available and the clinical and methodological heterogeneity present among available studies based on established guidance, which includes evaluating the similarities in study population, medication, dose, and frequency and similarities in timing and specification of outcomes.^84^ For KQ 2, too few studies were available for each screening strategy and comparison to conduct meta-analyses; therefore, we did not pool data from multiple studies, but we calculated absolute risk differences (ARDs) and risk ratios (RRs) for the comparative detection of previously undiagnosed AF. For KQs 5 and 6, we conducted quantitative synthesis with random-effects models using the inverse-variance weighted method (DerSimonian and Laird) to estimate pooled effects.^85^ We calculated RRs and 95 percent confidence intervals (CIs) for all-cause mortality, cardiovascular-related mortality, all ischemic stroke, moderately to severely disabling stroke, TIA, major bleeding, major extracranial bleeding, intracerebral hemorrhage, minor bleeding, and a composite outcome of all ischemic stroke or intracerebral hemorrhage. Statistical significance was assumed when 95 percent CIs of pooled results did not cross the null. All testing was two sided. We calculated a number needed to treat (NTT) for statistically significant pooled results based on the RR.^86^ For KQs 5 and 6, the I^2^ statistic was calculated to assess statistical heterogeneity in effects between studies.^87,^ ^88^ An I^2^ from 0 to 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, 50 to 90 percent may represent substantial heterogeneity, and 75 percent or greater represents considerable heterogeneity.^87,^ ^88^ We conducted all quantitative analyses using Stata version 16 (StataCorp).

We assessed the overall strength of evidence (SOE) as high, moderate, low, or insufficient based on the consistency of results between studies, precision of findings, study limitations, and reporting bias for each comparison and major outcome of interest, using methods developed for the USPSTF (and the EPC program).^89^ We also assessed the applicability of the findings to U.S. primary care populations and settings. Two senior investigators independently developed initial SOE and applicability assessments for each relevant outcome; discrepancies were resolved through discussion and consultation with a third senior investigator. We evaluated the consistency domain by visually inspecting the forest plot and with the I^2^ statistic for pooled outcomes and by assessing the range of estimates and CIs of individual studies when pooling was not possible. We also assessed whether any inconsistencies could be explained by study population or study design characteristics. We evaluated the precision domain for bodies of RCT evidence by calculating the optimal information size (i.e., sample size needed in a single adequately powered trial required to generate a precise estimate) and by evaluating whether the CIs around estimates crossed clinically meaningful thresholds of benefit or harm.

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF website for public comment from March 26, 2020, to April 22, 2020. In response, we added language to clarify the populations of interest and subgroups, specifically the age of eligible populations (which was decreased to age 50 years). We also provided additional detail to specify eligible index and reference tests and removed “with electrocardiography” from the title, analytic framework, and KQs to reflect the use of technologies other than ECG for screening. The final version of the research plan was posted on the USPSTF website on July 16, 2020.^90^ A draft report was reviewed by five content experts, three representatives of Federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments received. In response to these comments, we provided additional information regarding the rationale for screening, clarified limitations of included studies, and expanded the future research needs section. The draft evidence report was posted on the USPSTF website for public comment from April 20, 2021, to May 17, 2021. We reviewed all citations submitted for consideration. As a result, we updated one of the CQs with additional findings, and we confirmed the relevance of one study that was published shortly before the draft report was posted and the relevance of an additional study pending publication. Both additional studies have been incorporated into this final report.

## USPSTF Involvement

This review was funded by AHRQ. Staff of AHRQ and members of the USPSTF participated in developing the scope of work and reviewed draft reports, but the authors are solely responsible for the content.