# Chapter 1 Introduction

## Purpose

This report will be used by the United States Preventive Services Task Force (USPSTF) to update its 2018 statement on screening for atrial fibrillation (AF) with electrocardiography (ECG).^1^ At that time, the USPSTF concluded that the current evidence was insufficient (I statement) to assess the balance of benefits and harms of screening for AF with ECG. The USPSTF made the 2018 recommendation based on a 2018 systematic review conducted by the RTI–University of North Carolina Evidence-based Practice Center (EPC).^2^ In 2018, the USPSTF found inadequate direct evidence assessing the benefit of screening on health outcomes and inadequate evidence for the detection of AF with ECG compared with usual care. The USPSTF found adequate evidence that anticoagulation treatment reduces stroke and adequate evidence of small to moderate harms for screening and anticoagulation treatment. This 2020 report systematically evaluates the current evidence on screening for AF in populations and settings relevant to primary care in the United States.

## Condition Definition

AF is a common supraventricular tachyarrhythmia characterized by structural or electrophysiological abnormalities leading to alteration of atrial tissue and resulting in abnormal impulse formation, or propagation, or both.^3–5^ Electrocardiographic features of AF include (1) “irregularly irregular” R-R intervals (intervals from the onset of one R wave to the onset of the next one, one complete cardiac cycle), meaning they follow no repetitive pattern, and (2) no distinct P waves (the waves on an ECG associated with atrial depolarization).^5,^ ^6^ Recent 2020 guidelines from the European Society of Cardiology define clinical AF as symptomatic or asymptomatic ECG tracing of AF on a surface ECG of at least 30 seconds duration.^7^ Paroxysmal, persistent, and permanent are helpful labels to describe clinical AF. Paroxysmal AF terminates spontaneously or with intervention within 7 days of onset; episodes may recur and last from seconds, to minutes, to days. Persistent AF is continuous AF for more than 7 days, and permanent AF is when the clinician and patient make a joint decision to stop further attempts to restore sinus rhythm.^3^ In addition to these labels, the increased use of implantable and wearable devices has resulted in the term subclinical AF, which refers to episodes of device-detected atrial tachyarrhythmia, that are not clinically apparent because they do not result in symptoms but that may be confirmed as clinical AF by clinician review of the intracardiac electrograms or by surface ECG.^7–9^

## Etiology, Natural History, and Risk Factors

Underlying heart disease (e.g., ischemic heart disease, valvular heart disease, cardiomyopathies, heart failure) can lead to inflammation, fibrosis, and hypertrophy in the atrial architecture, leading to increased left atrial pressure with subsequent atrial dilation and changes in wall stress.^10,^ ^11^ Multiple electrophysiological mechanisms may contribute to the initiation and perpetuation of AF in an individual with an anatomical vulnerability; the natural history of the condition generally involves a gradual worsening over time.^12,^ ^13^ Suboptimal ventricular rate control, loss of atrial contraction, variability in ventricular filling, and sympathetic activation can lead to the adverse hemodynamic effects of AF, resulting in reduced cardiac output with potential for fatigue, palpitations, dyspnea, hypotension, syncope, or heart failure.^14–16^ However, some patients have AF with no obvious symptoms.^17^ In addition, persons may attribute mild, nonspecific symptoms of AF (e.g., fatigue) to other causes.

AF reduces cardiac blood flow, which, along with changes in blood composition involving platelets, other coagulation proteins, and inflammatory cytokines, predisposes patients to thrombus formation, particularly in the left atrial appendage, which confers an increased risk of stroke and systemic thromboembolism in patients with AF.^18^ Before widespread anticoagulant use, AF was associated with a fivefold increase in the risk of stroke, after adjustment for other factors.^19^ Although stroke is a major potential complication resulting from AF, the Randomized Evaluation of Long-Term Anticoagulation Therapy clinical trial that compared dabigatran with warfarin reported that stroke accounted for only 7 percent of deaths among persons with AF; sudden cardiac death accounted for 22.3 percent, progressive heart failure for 15.1 percent, and noncardiovascular death for 35.8 percent.^20^

Risk factors for AF include diabetes, previous cardiothoracic surgery, smoking, prior stroke, advanced age, underlying heart disease, hypertension, sleep apnea, obesity, alcohol/drug use, electrocardiographic features such as left ventricular hypertrophy and left atrial enlargement, and hyperthyroidism.^5,^ ^9^ Several large longitudinal study cohorts have contributed to externally validated models that aim to predict the risk of future AF, including the Atherosclerosis Risk in Communities (ARIC) Study,^21^ the Framingham Heart Study (FHS),^22^ and the Cohorts for Heart and Aging Research in Genomic Epidemiology (CHARGE-AF).^23^ Such models include age, race, height, weight, systolic and diastolic blood pressure, current smoking, use of antihypertensive medication, diabetes, and history of myocardial infarction and heart failure as predictors of future AF risk.

## Prevalence and Burden of Disease

### Prevalence

AF is the most common arrhythmia.^24^ In the United States, estimates of the number of persons with clinical AF ranged from 2.7 million to 6.1 million in 2010.^24^ The estimated prevalence of clinical AF among U.S. Medicare beneficiaries in 2016 was 8.6 million.^25^ As part of Contextual Question (CQ) 1 (Appendix A), we estimated the prevalence of unknown AF as 1.3 percent based on 34 studies using one-time screening approaches conducted among persons without a preexisting diagnosis of AF. We estimated the prevalence as three to four percent based on 13 studies when intermittent or continuous approaches to screening were used.

Based on data from the Anticoagulation and Risk Factors in Atrial Fibrillation (ATRIA) study of 1.89 million adult California health plan members, in the 1990s, prevalence was shown to increase with age, from less than 0.2 percent for those younger than age 55 years to about 10 percent for those age 85 years or older with a higher prevalence in men compared with women (Appendix A Table 1).^26^ A recent cohort study of over 500,000 patients from an integrated health care delivery system in Pennsylvania reported significantly increased AF incidence between 2006 (4.74 cases per 1,000 person-years) and 2018 (6.82 cases per 1,000 person-years) with increases observed across all age groups and for both sexes but with the largest increases occurring in the age group 85 years or older.^27^ During 50 years of observation in the Framingham Heart Study, researchers observed a fourfold increase in the age-adjusted prevalence of AF.^28^ This rising prevalence is likely related to changes in diagnostic tools and strategies in routine medical care that result in more AF case finding.

Whether AF prevalence differs by race/ethnicity is uncertain. The ATRIA study identified differences in AF prevalence based on race using available ICD-9 codes from clinical databases containing Kaiser Permanente of Northern California health plan member data. Although African American and White patients ages 50 to 59 years had similar prevalence of AF, higher prevalence was reported among White patients compared with African Americans in older age groups: 1.8 percent vs. 1.3 percent in patients ages 60 to 69 years, 5.2 percent vs. 4.4 percent in patients ages 70 to 79 years, and 9.9 percent vs. 7.7 percent in patients age 80 years or older.^26^ A 2019 analysis reported by the ARIC study used 48-hour ambulatory ECG to estimate AF prevalence.^29^ The mean age in this analysis was 78 years, and 62 percent of the enrolled population was African American. The authors reported a lower adjusted AF prevalence among African Americans (2.7%) compared with White persons (5.0%); these estimates were adjusted for gender, coronary heart disease, diabetes, hypertension, and age. A 2020 analysis reported by the MESA study, a community-based cohort of 6,814 Americans, mean age 74 years, found higher prevalence of clinically detected AF among Whites compared with African Americans, Hispanics, and Chinese after 14.4 years of followup: 11.3 percent vs. 6.6 percent, 7.8 percent, and 9.9 percent, respectively.^30^ However, when the same individuals from the MESA cohort were screened with 14-day ambulatory ECG the prevalence differences among race/ethnic groups (White, African American, Hispanic, and Chinese) were no longer statistically significant in both unadjusted and adjusted analyses: 7.1 percent vs. 6.4 percent, 6.9 percent, and 5.2 percent, respectively.^30^ Based on these findings, the role of clinical bias in differential detection of AF by race/ethnicity warrants further investigation.

About 25 percent of AF is paroxysmal. Thus, assessing the overall prevalence of AF—particularly paroxysmal AF—is challenging because episodes of arrhythmia may be brief and undetected.^31^ Further, the increased use of implantable cardiac devices has resulted in more awareness regarding device-detected, subclinical AF.^8,^ ^32^ In a 2019 study conducted in Denmark, the prevalence of AF was assessed with an implantable loop recorder over 40 months in persons age 70 years or older considered high risk for AF (i.e., comorbid hypertension, diabetes, heart failure, previous stroke).^33^ The cumulative incidence of AF in this study was 5.7 percent for AF episodes lasting longer than 24 hours and 33.8 percent for AF episodes lasting 6 minutes or longer.^33^

### Burden of Disease

In 2017, AF was the underlying cause of death for 26,077 persons with the age-adjusted mortality rate of 6.6 per 100,000 persons.^24^ According to Medicare and MarketScan databases from 2004 through 2006, persons with clinical AF were approximately twice as likely to be hospitalized as age- and sex-matched control individuals (37.5% vs. 17.5%) and more likely to die during hospitalization (2.1% vs. 0.1%) than were similar patients without AF.^24^ Furthermore, in 2014, among the 3,865,447 inpatient stays with any diagnosis of AF, 398,890 stays had AF listed as a principal reason for the inpatient stay (10.3%).^24^ This analysis also revealed that care for AF adds approximately $8,700 per year to the cost of a patient’s healthcare (compared with a patient without AF) and accounts for $26 billion in U.S. healthcare expenditures annually.^24^

Increasing age is an independent predictor of stroke in persons with AF. Age is associated with an increased risk of stroke of about 1.5 percent per decade; the annual stroke incidence increases from 1.3 percent in those ages 50 to 59 years to 5.1 percent in those ages 80 to 89 years.^34^ Strokes due to AF are associated with a poor prognosis as measured by both 28-day and 3-month mortality, disability, and discharge to institution rather than home.^35–37^ Approximately 30 percent of patients with AF who have a stroke die within 1 year of the stroke, and up to 30 percent of survivors are permanently disabled.^38^

The clinical importance of asymptomatic AF, including subclinical AF and paroxysmal AF, with respect to the risk of stroke is uncertain. We discuss this in detail in Appendix B (CQ 2). Briefly, four cohort studies suggest a similar or possibly higher incidence of stroke among persons with asymptomatic AF compared with symptomatic AF, but these studies have many limitations, precluding a definitive conclusion.^39–42^ Three studies, including one systematic review, reported a somewhat lower risk of stroke among persons with paroxysmal AF compared with permanent AF.^43–45^ The risk of stroke for persons with paroxysmal AF may be related to AF burden, which refers to time spent in AF relative to time not spent in AF. There is some evidence that patients with high AF burden may have increased stroke risk compared with persons with low AF burden.^46–49^ However, there is little consensus about how to define AF burden and what constitutes high vs. low burden. Although there are early indications that patients with subclinical AF episodes of at least 24 hours’ duration may have increased stroke risk, there is less clarity for subclinical AF episodes of shorter duration. However, data related to subclinical AF comes largely from persons with implanted cardiac devices who likely represent a very small proportion of persons with AF, and about whom outcomes and observations may differ because of the underlying conditions which prompted the need for an implanted device.

## Rationale for Screening and Screening Strategies

The primary rationale for screening for AF is to identify asymptomatic persons before a thromboembolic event occurs. Of patients who have a stroke because of AF, it is estimated that 20 percent or more are diagnosed with AF at the time of the stroke or shortly thereafter.^50–52^ No guidelines recommend the use of rate or rhythm control in asymptomatic persons, except in persons with a resting heart rate over 110 beats per minute because prolonged increased ventricular rates may increase the risk of cardiomyopathy.^53,^ ^54^ A trial published in October 2020 of early rhythm control in persons with AF with either medication or ablation suggests a lower risk of a composite outcome (death, stroke, hospitalization with worsening heart failure, hospitalization for acute coronary syndrome) compared with usual care (3.9 events per 100 person-years vs. 5.0 events per 100 person-years; hazard ratio [HR], 0.79 (96% CI, 0.66 to 0.94) but with a somewhat higher risk of serious adverse events of special interest related to rhythm-control therapy (4.9% vs. 1.4%).^55^ Thus, other rationale for screening may exist.

Although AF is common, important to the consideration of screening for AF is the prevalence of AF among persons without symptoms and without a prior history of stroke who do not already carry a diagnosis of AF, which provides an estimate of the potentially preventable burden that might be identified through screening. In Appendix B (CQ 1), we describe studies that used various approaches to estimate the prevalence of AF among population- or community-based samples and clinic-based samples of persons not already known to have a diagnosis of AF. The studies providing these estimates did not include control groups and thus overestimate the potential yield of screening because cases may also be detected through usual medical care. We address the comparative diagnostic yield of screening compared with no screening as key question 2 (KQ 2) in this review. Among 35 studies using a one-time testing approach (e.g., a one-time single- or 12-lead ECG), the pooled prevalence was 1.3 percent among both clinic- and community-based samples. Among 12 studies using continuous or intermittent ambulatory ECG tests, where diagnosis of AF was defined as greater than 30 seconds of AF in all but one study, the prevalence ranged from 2.7 to 3.7 percent, likely reflecting the identification of more cases of paroxysmal AF. One additional study of an insertable cardiac monitor over 588 days (N=82) yielded a 21 percent prevalence based on AF episodes greater than 2 minutes or longer; however, these may reflect incident as well as prevalent cases.^56^

Approaches to screening vary; they include a one-time, standard 12-lead ECG, in-office devices that record fewer than 12 leads, pulse oximetry and blood measure monitors with automated AF detection algorithms, ambulatory heart rate and rhythm monitors (e.g., continuous Holter monitoring, intermittent looping memory monitors, mobile cardiac telemetry units, patch monitors), and pulse palpation. Since the previous review for the USPSTF, several consumer-directed, “wearable” devices and smartphone applications have become available. These devices rely on traditional ECG technology (i.e., capturing electrical signals across various numbers of sensors) or photoplethysmography, which relies on optical sensors to detect changes in peripheral blood volume to infer heart rate and rhythm. Some of these devices have received U.S. Food and Drug Administration (FDA) 510(k) medical device clearance to be marketed for use as an ECG device or for the detection of arrhythmias, including AF.

A 2015 systematic review evaluated the accuracy of methods for identifying an irregular pulse and found that pulse palpation had the lowest accuracy among various methods, largely because of its lower specificity (sensitivity: 0.92; specificity: 0.82).^57^ Healthcare professionals, including medical assistants, nurses, and physicians, often perform pulse measurement or palpation using automated or manual approaches during routine or acute care encounters. When an irregular pulse is detected during usual medical care, a diagnostic evaluation that includes a standard 12-lead ECG typically is performed and may result in AF case-finding. A 2020 systematic review and meta-analysis of physician interpretation of ECG under controlled, educational test settings suggest a median accuracy of 68.5 percent for practicing physicians and 74.9 percent for cardiologists.^58^ Although a 12-lead ECG interpreted by one or more cardiologists is likely sufficient to serve as a reference standard for determining the accuracy for diagnosing persistent AF, determining the accuracy of tests for diagnosing paroxysmal AF requires the use of continuous ambulatory ECG monitoring as a reference standard.

## Treatments/Interventions

Oral anticoagulant medications can prevent thromboembolic events in AF patients by reducing the formation of clots in the left atrium and atrial appendage.^59^ Oral anticoagulants to prevent stroke and reduce all-cause mortality in persons with AF include warfarin (a vitamin K antagonist [VKA]) and the newer target-specific anticoagulants, also known as direct oral anticoagulants (DOACs).^3^ Dabigatran etexilate (Pradaxa®) is the only currently available oral direct thrombin inhibitor in the United States. Oral Factor Xa inhibitors include apixaban (Eliquis®), edoxaban (Savaysa®), and rivaroxaban (Xarelto®).^3,^ ^60,^ ^61^ Antiplatelet agents are not recommended as a stroke prevention option for persons with AF.^4,^ ^62^ Individualized assessment of the balance of potential benefits (i.e., risk reduction in stroke or embolism) vs. potential harms (i.e., risk increase in major bleeding) is recommended when choosing a therapeutic strategy. This assessment is aided by the use of validated risk prediction tools for stroke risk (Appendix A Table 2), which include the CHA_2_DS_2_-VASc score (Congestive heart failure, Hypertension, Age ≥75 years [doubled], Diabetes mellitus, prior Stroke or transient ischemic attack [TIA] or thromboembolism [doubled], Vascular disease, Age 65-74 years, Sex Category. Several prediction tools for bleeding risk (Appendix A Table 3) are also available and include the HAS-BLED (Hypertension, Abnormal renal and liver function, Stroke, Bleeding, Labile international normalized ratios, Elderly, Drugs or alcohol, and HEMORR_2_HAGES (Hepatic or renal disease, Ethanol abuse, Malignancy, Older age, Reduced platelet count or function, Rebleeding risk, Hypertension, Anemia, Genetic factors, Excessive fall risk, Stroke).^3^ These tools were developed to aid in the assessment of stroke and bleeding risk, which is complicated because many risk factors for anticoagulation-related bleeding are also risk factors for stroke in patients with AF. The stroke risk prediction tools (specifically CHA_2_DS_2_-VASc) were developed and validated primarily in populations (some hospitalized) with clinical AF; thus, their applicability to screen-detected populations is uncertain. Although most guidelines recommend the use of stroke risk prediction tools for informing decisions about anticoagulation, most have modest predictive ability. Based on a 2018 AHRQ Effective Health Care Program Systematic Review of stroke prevention in AF, the most commonly recommended approach (categorical CHA_2_DS_2_-VASc score) was found to have a c-statistic of 0.64 (95% CI, 0.58 to 0.70) based on 13 studies of 496,683 patients.^63^

In patients with a high risk for stroke who may not be candidates for long-term anticoagulation, left atrial appendage closure is an available option for treatment. An FDA-approved device, the WATCHMAN^TM^, offers a nonpharmacologic alternative to oral anticoagulation.^64^ This catheter-delivered heart implant is designed to reduce the risk of thromboembolism by closing off the left atrial appendage, which is the primary site of clot formation in patients with AF. Other devices are under development.^65^ The 2019 joint guidelines from the American Heart Association (AHA), the American College of Cardiology, and the Heart Rhythm Society state that percutaneous left atrial appendage occlusion may be considered in patients with AF at increased risk of stroke who have contraindications to long-term anticoagulation, but that oral anticoagulation remains the preferred therapy for stroke prevention for most patients with AF and increased stroke risk.^4^ The proportion of persons with screen-detected AF with contraindications to long-term anticoagulation who would be candidates for left atrial appendage closure is not definitively known but is likely low.

## Current Clinical Practice

In recent years, several U.S. and international professional organizations have issued recommendations for AF screening and management (Appendix A Table 4). Multiple organizations recommend active screening for AF with pulse palpation (and confirming the diagnosis with ECG) in persons age 65 years or older, including the AF-SCREEN International Collaboration,^66^ the European Primary Care Cardiovascular Society,^67^ the European Society of Cardiology (ESC) in collaboration with the European Association of Cardio-Thoracic Surgery (EACTS) and European Heart Rhythm Association (EHRA),^7^ the United Kingdom (U.K.) National Screening Committee (NSC),^68^ the World Heart Foundation,^69^ the National Heart Foundation of Australia and the Cardiac Society of Australia and New Zealand (NHFA CSANZ),^70^ and the AHA in collaboration with the American Stroke Association.^71^

Several of these organizations also advocate for the use of screening approaches other than pulse palpation.^7,^ ^66,^ ^68,^ ^70^ Specifically, the ESC/EACTS/EHRA,^7^ AF-SCREEN,^66^ and NHFA CSANZ^70^ each support the use of opportunistic ECG (rhythm strip or single lead) for adults age 65 or older as an alternative to pulse palpation, and the first two^7,^ ^66^ suggest considering systematic ECG screening for patients age 75 years or older or those at high stroke risk. The 2019 U.K. NSC guidelines mentioned earlier recommend modified blood pressure monitors (if available) administered by nurses in primary care settings in addition to pulse palpation as appropriate screening tests.^68^

Professional organizations have consistently recommended the use of risk prediction tools to guide the appropriate use of stroke prevention therapy in patients with AF. Recent guidelines recommend using the CHA_2_DS_2_-VASc score to assess stroke risk.^4^ In general, guidelines recommend no therapy for those at lowest risk of stroke (based on the CHA_2_DS_2_-VASc score) and recommend anticoagulant therapy for those at high risk (e.g., CHA_2_DS_2_-VASc score ≥2 for males and ≥3 for females).^4,^ ^72^ DOACs are recommended over warfarin in the most recent guidelines for those without contraindications.^3,^ ^4,^ ^7,^ ^66,^ ^70,^ ^73,^ ^74^ Antiplatelet agents, such as aspirin, are no longer recommended as a primary strategy for stroke prevention in AF.^4,^ ^7^