# Appendix H Additional Information

Appendix H Table 1 Summary of Relevant Ongoing Studies

Trial Name; Registry No.; Design | Population Enrolled | Intervention and Comparator | Status and Estimated Completion Date | Outcomes | Results Published
Potentially relevant direct evidence (KQ 1) studies
GUARD-AF; NCT04126486; RCT | Age ≥70 years in primary care;; N=52,000 | - Ambulatory ECG (Zio XT patch monitor) for 2 weeks; - Standard care | Recruiting; 6/2021; (estimated) | Incidence of all strokes and bleeding leading to hospitalization within 24 months (primary endpoint) | No
Potentially relevant direct evidence and comparative diagnostic yield (KQ 1 and KQ 2) studies
VITAL-AF; NCT03515057; Cluster RCT | Age ≥65 years in primary care;; N=35,308 | - One time single-lead handheld ECG during primary care clinic visit; - Standard care | Active, not recruiting; 10/2021; (estimated) | Incident AF over 12 months, ischemic stroke or major hemorrhage over 2 years | No for main results, preliminary KQ 2 results presented at an AHA conference in Nov 2020.
eBRAVE-AF; NCT04250220; RCT | Age ≥50 years and a policy holder of a large health insurance company;; N=4,400 | - PPG-based screening using a smartphone and ECG patch; - Symptom based AF-screening | Recruiting; 03/2021; (estimated) | Newly detected AF at 6 months, newly prescribed oral anticoagulation, stroke, and thromboembolic events. | No
The Effect of a Case-finding App on the Detection Rate of Atrial Fibrillation in Primary Care Patients; NCT04545723; cluster-RCT | Age≥65 years in primary care;; N=8,765 | - FibriCheck app-based screening during a primary care clinic visit; - Standard opportunistic screening with pulse palpation and a 12-lead ECG when a irregular rhythm is found | Not yet recruiting; 05/2022; (estimated) | Newly detected AF at 4 weeks, thromboembolic complications, death, and compliance. | No
STROKESTOP II; NCT02743416; Unclear whether RCT or cohort | Age 75 or 76 years in primary care;; N=8,000 | - Initial screening with NT-proBNP; - If NT-proBNP >125 ng/L (high risk group): intermittent ECG recordings twice daily for 2 weeks; - If NT-proBNP<125 ng/L (low risk group): one initial single-lead ECG; - Standard care | Active, not recruiting; 4/2023; (estimated) | Incidence of stroke in low-risk group compared with control group at 5 years (primary endpoint); also evaluating detection of AF | No for main results, several ancillary and baseline enrollment papers have been published.
SAFER; ISRCTN16939438; Cluster RCT | Age≥65 years in primary care;; Feasibility study: N=4,800; RCT: N=126,000 | - Intermittent single-lead ECG at home over 2 to 4 weeks; - Standard care | Feasibility study 3/2021; (estimated); Full RCT; 9/2026; (estimated) | Stroke, MI, all-cause mortality, risk of serious bleeding, cost-effectiveness | No
Potentially relevant treatment benefits and harms (KQs 5 and 6) studies
NOAH-AFNET 6; NCT02618577; EudraCT (2015-003997-33), and ISRCTN (17309850); RCT | Age ≥65 years with CIED for any reason, AHRE ≥180 beats/min and ≥6 min. At least 1 additional stroke risk factor;; N=3,400 | - Edoxaban; - Standard care (ASA or placebo) | 3/2022 | Composite of stroke, systemic embolism, or cardiovascular death; major bleeding events; exploratory analyses by duration or pattern of AHRE. | No
ARTESiA; NCT01938248; RCT | Age ≥55 years with CIED, SCAF ≥175 beats/min and ≥6 min but <24 hrs. At least 1 additional stroke risk factor;; N=4,000 | - Apixaban; - Aspirin | 12/2022 | Composite of stroke or systemic embolism; major bleeding; subgroup analysis of long vs. short SCAF episodes. | No
BRAIN-AF; RCT | Age ≥30 to ≤62 years with nonvalvular atrial fibrillation and low-risk of stroke; N=3,250 | - Rivaroxaban; - Standard of care | 02/2022 | Composite endpoint of stroke, TIA, and neurocognitive decline; death; systemic embolic events; neurocognitive decline; and hospitalization for cardiovascular or bleeding event. | No
SINGLE-AF; NCT04437654; RCT | Age 19-80 years with CHA2DS2-VASc score 1 for male or 3 for female among nonvalvular atrial fibrillation patients;; N=1,800 | - Apixaban; - Standard of care except anticoagulation | 07/2026 | Composite of stroke or systemic embolism, major bleeding, and death. | No

Abbreviations: AF=atrial fibrillation; AHRE=atrial high rate episodes; ARTESiA=Apixaban for the Reduction of Thrombo-Embolism in Patients With Device-Detected Sub-Clinical Atrial Fibrillation; ASA=American Stroke Association; CABG=coronary artery bypass graft; CIED=cardiac implanted electronic device; ECG=electrocardiograph; IDEAL-MD=Improving DEtection of Atrial fibriLlation in Primary Care With the MyDiagnostick; GUARD-AF=reducing Stroke by Screening for UndiaAgnosed atrial Fibrillation in Elderly inDividuals; KQ=key question; mSToPS=mHealth Screening to Prevent Strokes; N=number of participants; NOAH-AFNET 6=Non-vitamin K Antagonist Oral Anticoagulants in Patients with Atrial High Rate Episodes; NT-proBNP=N-terminal pro beta type natriuretic peptide; PCA=primary coronary angioplasty; RCT=randomized, controlled trial; SCAF=subclinical atrial fibrillation; TIA=transient ischemic attack; VITAL-AF=Screening for Atrial Fibrillation Among Older Patients in Primary Care Clinics.

Appendix H Table 2 Estimates of True Positives, False Positives, True Negatives, and False Negatives per 1,000 Tests Based on Sensitivity and Specificity of Various Screening Strategies Reported in KQ 3 for Prevalence of Undiagnosed Atrial Fibrillation of 0.5%, 1.3%, and 4%

Study | Sensitivity | Specificity | TP | | | FP | | | TN | | | FN
AF Prevalence | Sensitivity | Specificity | 0.5% | 1.3% | 4% | 0.5% | 1.3% | 4% | 0.5% | 1.3% | 4% | 0.5% | 1.3% | 4%
Oscillometric BP monitor with automated AF detection vs. 12-lead ECG interpreted by cardiology
Kearley et al, 2014^113^ (Microlife) | 0.95 | 0.90 | 5 | 12 | 38 | 100 | 99 | 96 | 896 | 888 | 864 | 0 | 1 | 2
Marazzi et al, 2012^115^ (Microlife) | 0.92 | 0.95 | 5 | 12 | 37 | 50 | 49 | 48 | 945 | 938 | 912 | 0 | 1 | 3
Marazzi et al, 2012^115^ (OMRON) | 1.0 | 0.94 | 5 | 13 | 40 | 60 | 59 | 58 | 935 | 928 | 902 | 0 | 0 | 0
Wiesel et al, 2014^114^ (Microlife) | 1.0 | 0.92 | 5 | 13 | 40 | 80 | 79 | 77 | 915 | 908 | 883 | 0 | 0 | 0
Wiesel et al, 2014^114^ (OMRON) | 0.30 | 0.97 | 2 | 4 | 12 | 30 | 30 | 29 | 965 | 957 | 931 | 4 | 9 | 28
Oscillometric BP monitor with automated AF detection vs. continuous ECG
Gladstone et al, 2021^75^ (Microlife) | 0.35 | 0.81 | 2 | 5 | 14 | 189 | 188 | 182 | 806 | 799 | 778 | 3 | 9 | 26
Single-lead ECG with automated AF detection vs. 12-lead ECG interpreted by cardiology
Himmelreich et al, 2019^112^ (KardiaMobile) | 0.88 | 1.0 | 4 | 11 | 35 | 0 | 0 | 0 | 995 | 987 | 960 | 1 | 2 | 5
Kearley et al, 2014^113^ (OMRON) | 0.99 | 0.76 | 5 | 13 | 40 | 239 | 237 | 230 | 756 | 750 | 730 | 0 | 0 | 0
Six-lead ECG with automated AF detection vs. 12-lead ECG interpreted by cardiology
Sabar et al, 2019^117^ (RhythmPad 6-lead ECG) | 0.95 | 0.99 | 5 | 12 | 38 | 10 | 10 | 10 | 985 | 977 | 950 | 0 | 1 | 2
GP-interpreted ECG vs. 12-lead ECG interpreted by cardiology
Hobbs et al, 2005^91^ SAFE (12-lead) | 0.80 | 0.92 | 4 | 10 | 32 | 80 | 79 | 77 | 915 | 908 | 883 | 1 | 3 | 8
Hobbs et al, 2005^91^ SAFE (Single-limb lead) | 0.83 | 0.88 | 4 | 11 | 33 | 119 | 118 | 115 | 876 | 869 | 845 | 1 | 2 | 7
Hobbs et al, 2005^91^ SAFE (Single-thoracic lead) | 0.85 | 0.86 | 4 | 11 | 34 | 139 | 138 | 134 | 856 | 849 | 826 | 1 | 2 | 6
Combined pulse palpation, oscillometric BP monitor and single lead ECG both with automated AF detection vs. 12 lead ECG interpreted by cardiology
*Uittenbogaart et al, 2020^116^ D2AF | CD | CD | CD | CD | CD | CD | CD | CD | CD | CD | CD | CD | CD | CD

* The study only performed a 12-lead reference test on a random sample of participants who tested negative on the index screening test; thus data to determine sensitivity and specificity was not available. However, based on data reported, we calculated the positive predictive value to be 6% and the negative predictive value to be 100%; suggesting a test with very high sensitivity, but poor specificity.

Abbreviations: AF=atrial fibrillation; BP=blood pressure; CD=cannot determine since referent 12-lead ECG only performed on a random sample of persons screening negative on index test; D2AF=Detecting and Diagnosing Atrial Fibrillation; ECG=electrocardiograph; FN=false negatives; FP=false positives; GP=general practitioner; SAFE=Screening for Atrial Fibrillation in the Elderly; TN=true negative; TP=true positive; vs.=versus.