# Appendix G Additional Results

Appendix G Figure 1 Meta-Analysis of Warfarin vs. Placebo/Control for Transient Ischemic Attack

Abbreviations: AFASAK=Atrial Fibrillation, ASpirin, and AntiKoagulation; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation study; CG=control group; CI=confidence interval; IG=intervention group; RR=risk ratio; SPAF=Stroke Prevention in Atrial Fibrillation Study.

Appendix G Figure G1 is titled “Meta-analysis of Warfarin Versus Placebo/Control for Transient Ischemic Attack.” This figure displays a forest plot reporting the risk ratio for transient ischemic attack in four studies (AFASAK I, 1989; BAATAF, 1990; SPAF I, 1991; CAFA, 1991). Across trials, 19 transient ischemic attack events occurred, 7 in the intervention group and 12 in the control group. Warfarin treatment was associated with a lowered risk of transient ischemic attack compared with controls, but the difference was not statistically significant with the pooled risk ratio being 0.66 (95% CI, 0.26 to 1.68). No individual studies reported a significant difference between treatment and control.

Appendix G Figure 2 Meta-Analysis of Warfarin vs. Placebo/Control for Minor Bleeding

Abbreviations: BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation study; CG=control group; CI=confidence interval; IG=intervention group; RR=risk ratio; SPAF=Stroke Prevention in Atrial Fibrillation Study; SPINAF=Stroke Prevention in Nonrheumatic Atrial Fibrillation study.

Appendix G Figure G2 is titled “Meta-analysis of Warfarin Versus Placebo/Control for Minor Bleeding.” This figure displays a forest plot reporting the risk ratio for minor bleeding in four studies (BAATAF, 1990; SPAF I, 1991; CAFA, 1991; SPINAF, 1992). Across trials, 222 minor bleeding events occurred, 136 in the intervention group and 86 in the control group. Warfarin treatment was associated with a statistically significant increased risk of minor bleeding compared with controls with the pooled risk ratio being 1.58 (95% CI, 1.23 to 2.02).