# Appendix F Detailed Evidence Tables

Appendix F Table 1 Study Characteristics of Included Randomized, Controlled Trials Evaluating Benefits and Harms of Screening for Atrial Fibrillation (KQ 1 and KQ 2)

Appendix F Table 2 Population Characteristics of Included Randomized, Controlled Trials Evaluating Benefits and Harms of Screening for Atrial Fibrillation (KQ 1 and KQ 2)

Appendix F Table 3 Intervention Characteristics of Included Randomized, Controlled Trials Evaluating Benefits and Harms of Screening for Atrial Fibrillation (KQ 1 and KQ 2)

Appendix F Table 4 Results of Included Randomized, Controlled Trials Evaluating Benefits of Screening for Atrial Fibrillation (KQ 1 and KQ 2)

Appendix F Table 5 Study Characteristics of Included Test Accuracy Studies (KQ 3)

Appendix F Table 6 Population Characteristics of Included Test Accuracy Studies (KQ 3)

Appendix F Table 7 Test Characteristics of Included Test Accuracy Studies (KQ 3)

Appendix F Table 8 Results of Included Test Accuracy Studies (KQ 3)

Appendix F Table 9 Study and Population Characteristics of Included Studies Evaluating Harms of Screening for Atrial Fibrillation (KQ 4)

Appendix F Table 10 Results of Included Studies Reporting Harms of Screening for Atrial Fibrillation (KQ 4)

Appendix F Table 11 Results of Included Randomized, Controlled Trials for Benefits of Anticoagulation (KQ 5)

Appendix F Table 12 Results of Included Studies for Harms of Anticoagulation (KQ 6)

Appendix F Table 13 Summary of Included Systematic Reviews, Individual Patient Data Meta-Analyses, and Network Meta-Analyses on Benefits and Harms of Treatment for Atrial Fibrillation