# Appendix E Study Quality Assessment Tables

Appendix E Table 1 Quality Assessment of Randomized, Controlled Trials (KQ 1 and KQ 2): Part 1

Author, Year; Trial Name | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | What was the reported intervention fidelity? | Did the study have cross-overs or contamination raising concern for bias? | What was the overall attrition? | What was the differential attrition? | Did the study have differential attrition or overall high attrition raising concern for bias?
Fitzmaurice, 2014;^92^; Fitzmaurice, 2007;^93^; Mant, 2007;^94^; Hobbs, 2005;^91^; Swancutt, 2004^95^; SAFE | Yes | No | Yes for age and sex; unclear otherwise | 53% of patients invited for systematic screening underwent ECG; 69% of those randomized to pulse palpation reminders had pulse assessment recorded. | NR, but not suspected | 0.6% missing data | 0.1% | No
Gladstone, 2021; SCREEN-AF^75^ | Yes | Yes | No | Yes | No | 7.4% | NR | No
Halcox, 2017;^108^; Halcox, 2018^210^; REHEARSE-AF | Unclear, method of sequence generation NR but was centralized process with interactive voice response | NR | Yes | 74% submitted single-lead ECG recordings every week; 80% of participants in screening group submitted at least 1 weekly ECG during 90% or more of the study weeks | No | G1: 5/500 (1%); G2: NR | NR | No
Kaasenbrood, 2020^111^; NR | Yes | No | Probably yes | 10.7% of the eligible population at intervention practice were screened | Probably Yes | NA, cluster RCT | NA, cluster RCT | NA, cluster RCT
Morgan, 2002^105^ | Yes | Unclear | Yes for age and sex; unclear otherwise | 73% of those invited for screening had ECG, 29% of those assigned to pulse palpation reminders had pulse assessment recorded. | NR | NR | NR | Unclear
Steinhubl, 2018^109^; mSToPS | Yes | Probably yes | Yes | 34% in the immediate monitoring group and 35% in the delayed monitoring group did not wear a patch | Unclear | NA, cluster RCT | NA, cluster RCT | NA, cluster RCT
Svennberg, 2021; STROKESTOP^76,^ ^77,^ ^118^ | Yes | Probably yes | Yes | 51.3% of persons assigned to screening group participated in the intervention | NR | 793 (2.8%) died, emigrated, or moved out of region before study start; of those starting study, all were included in the analysis | 2.8% in screened group; 2.7% in not screened group | No
Uittenbogaart et al, 2020^116^; D2AF; NL4776 | Yes | Yes | Probably yes | 45% of those assigned to intervention practices got screened | Unclear | NA, cluster RCT | NA, cluster RCT | NA, cluster RCT

Abbreviations: D2AF=Detecting and Diagnosing Atrial Fibrillation; ECG=electrocardiogram; G=group; KQ=key question; mSToPS=mHealth Screening to Prevent Strokes; NA=not applicable; NR=not reported; RCT=randomized, controlled trial; REHEARSE-AF=Assessment of REmote HEArt Rhythm Sampling using the AliveCor heart monitor to scrEen for Atrial Fibrillation; SAFE=Screening for Atrial Fibrillation in the Elderly.

Appendix E Table 2 Quality Assessment of Randomized, Controlled Trials (KQ 1 and KQ 2): Part 2

First Author, Year; Trial Name | Were outcome measurements equal, valid, and reliable? | Were patients masked? | Were providers masked? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | Was the method to handle missing data adequate? | Did the study use acceptable statistical methods? | Quality Rating | Comments
Fitzmaurice, 2014;^92^; Fitzmaurice, 2007;^93^; Mant, 2007;^94^; Hobbs, 2005;^91^; Swancutt, 2004^95^; SAFE | Yes | No | No | Yes | Yes | Excluded; complete records only | Yes | Fair | Practices randomized to screening intervention or not (and randomization again within intervention group for opportunistic vs. systematic); no concealment of allocation; baseline comparison only provided for age and sex (no information on other variables or on practice characteristics, although randomization was stratified by practice size); good approach to determining when AF was previously diagnosed
Gladstone, 2021; SCREEN-AF^75^ | Yes | Yes | Yes | No | Yes | Yes | Yes | Fair | Blinding of intervention not conducted, but likely minimal impact.
Halcox, 2017;^108^; Halcox, 2018^210^; REHEARSE-AF | Uncertain but seems that approach to confirming AF may have differed between groups | No | No | No | Yes (for primary outcome of AF detection) | NR | Yes | Fair | Moderate risk of measurement bias with lack of any masking and uncertainty about what workup was done to confirm AF. Underpowered for KQ 1 outcomes.
Kaasenbrood, 2020^111^; NR | Probably yes | No | Probably yes | Probably yes | Probably yes | NR | Probably yes | Fair | Clustering did not affect regression results, so not included in final model; poor fidelity of intervention in the screening practices.
Morgan, 2002^105^ | Unclear, single observer reviewed medical records | No | No | NR | Unclear (6 months and few new cases of AF) | NR | Yes | Fair | The main outcomes describe total numbers of AF cases detected (inclusive of both previously known AF and newly diagnosed AF), so their main outcomes are not relevant for our questions; they also report incident cases, but they give somewhat limited details on methods of medical record review process for determining whether patients had previously diagnoses AF, and it was done by a single person (and masking NR); given that there were only 12 vs. 7 new cases (few events) and the study only covered 6 months of screening, the study provides limited information, although it shows pretty good uptake/fidelity; allocation concealment NR; baseline comparison only provided for age and sex.
Steinhubl, 2018^109^; mSToPS | Probably yes | Yes | Probably yes | Probably yes | Yes | Probably yes | Yes | Fair | Somewhat poor fidelity in screening group.
Svennberg, 2021; STROKESTOP^76,^ ^77,^ ^118^ | Unclear, clinical outcomes based on national registry data based on diagnoses made clinically; diagnoses were not centrally adjudicated as is typical for vascular events in trials | No | Unclear | Unclear whether clinicians making diagnoses or research staff working with registry data were masked | Yes | Not applicable | Yes, but primary outcome was changed part way through the study (authors provided some justification) | Fair | Poor fidelity in the screened group, outcome assessment masking not formalized, outcomes not centrally adjudicated and based on clinical data, primary outcome changed to a composite endpoint (with some author justification because of newer studies suggesting lower risk of stroke than what was used to initially power the study).
Uittenbogaart et al, 2020^116^; NL4776 | Yes | No | No | Unclear | Yes | Probably yes | Yes | Fair | Poor fidelity in the screening arm.

Abbreviations: AF=atrial fibrillation; KQ=key question; mSToPS=mHealth Screening to Prevent Strokes; NR=not reported; REHEARSE-AF=Assessment of REmote HEArt Rhythm Sampling using the AliveCor heart monitor to scrEen for Atrial Fibrillation; SAFE=Screening for Atrial Fibrillation in the Elderly; vs.=versus.

Appendix E Table 3 Quality Assessment of Randomized, Controlled Trials (KQ 5 and KQ 6): Part 1

First Author, Year; Trial Name | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | What was the reported intervention fidelity? | What was the reported adherence to the intervention? | Did the study have cross-overs or contamination raising concern for bias? | What was the overall attrition? | What was the differential attrition? | Did the study have differential attrition or overall high attrition raising concern for bias?
Connolly et al, 1991^99^; CAFA study | Unclear, method of sequence generation NR | NR | Yes | NA | NR | No (<3%) | Lost to followup NR (implied 0 or very low); 25% discontinued medication | NR; 4% | No
Ezekowitz et al, 1992^97^ | Unclear | Unclear | Yes | NA | NR | NR | 4% lost to followup; 16% dropped out | 2%; 3% | No
Petersen et al, 1989^102^; AFASAK | Yes | Unclear | Yes | NA | NR | No | Unable to determine amount of missing data (lost to followup NR); number of withdrawals is reported (222/1,007=22%) but it indicates that these subjects were still followed up for outcomes | Unable to determine for missing data (lost to followup); for withdrawals, 126 (38%) warfarin vs. 44 (12%) aspirin vs. 52 (16%) placebo and most of the difference was due to refusal to continue the medication | Unclear
Stroke Prevention in Atrial Fibrillation Study Group, 1991^98,^ ^101^; SPAF | Yes | Unclear | Yes | NA | 88% of participants averaged over 80% adherence by pill count | NR | 0% lost to followup; 1.5% of scheduled followup visits not completed | 0%; NR; 11.2% discontinued warfarin vs. 5% for aspirin, vs. 6.6% for placebo | No
The Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators, 1990^100^; BAATAF | Yes | Yes | Yes | NA | NR, although high time in therapeutic range over 80% suggests high adherence | Yes, aspirin allowed in control group (but not in warfarin group) and was being taken during 46% of all patient-years in control group | 0% lost to followup; 10% of warfarin group discontinued the medication (NA for control; no placebo control) | 0%; NA | No

Abbreviations: AFASAK=Atrial Fibrillation, ASpirin, and AntiKoagulation; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation Study; NA=not applicable; NR=not reported; SPAF=Stroke Prevention in Atrial Fibrillation Study Group; vs.=versus.

Appendix E Table 4 Quality Assessment of Randomized, Controlled Trials (KQ 5 and KQ 6): Part 2

First Author, Year; Trial Name | Were outcome measurements equal, valid, and reliable? | Were patients masked? | Were providers masked? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | What was the method used to handle missing data? | Did the study use acceptable statistical methods? | Quality Rating | Comments
Connolly et al, 1991^99^; CAFA study | Yes | Yes | Yes, except for person seeing PT/INR and making dose adjustments | Yes | Yes (mean followup 15.2months) | NR | Yes | Fair | Stopped early because of other positive studies with similar design and objectives; planned 630 participants and 2.5 years followup (378 analyzed)
Ezekowitz et al, 1992^97^ | Yes | Yes | No, for those adjusting doses; yes for cardiologist and neurologist | Yes | Yes (mean followup 1.7 to 1.8 years) | Censored | Yes | Fair | Warfarin vs. placebo; Stopped early with DSMB involvement and prespecified interim analyses showing benefit of warfarin and other similar studies being stopped early
Petersen et al, 1989^102^; AFASAK | Yes | No for warfarin; Yes for ASA and placebo | No for warfarin; Yes for ASA and placebo | Yes | Yes | NR | Yes | Fair | Thromboembolic endpoints were clinically confirmed, and also classified by a neurologist using a priori criteria. Information on missing data NR, unable to determine attrition; open label for warfarin
Stroke Prevention in Atrial Fibrillation Study Group, 1991^98,^ ^101^; SPAF | Yes | No | No | Yes | Yes (mean followup 1.3 years) | NA | Yes | Fair | Placebo arm was stopped early (multi-arm trial, and the warfarin and aspirin arms continued); open-label warfarin (although aspirin and placebo were given in a double-blind fashion); allocation concealment unclear
The Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators, 1990^100^; BAATAF | Yes | No | No | Yes | Yes (mean followup 2.2 years) | NA, reported no missing data | Yes | Fair | Stopped early because of evidence favoring warfarin over control (had already enrolled target number of participants, but had not reached the mean 4.1 years planned); contamination with aspirin in control group (might lead to underestimation of both benefits and harms of warfarin); no placebo; open label

Abbreviations: AFASAK=Atrial Fibrillation, ASpirin, and AntiKoagulation; ASA=American Society of Anesthesiologists; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation Study; DSMB=Data and Safety Monitoring Board; INR=International Normalized Ratio; NA=not applicable; NR=not reported; PT=prothrombin time; SPAF=Stroke Prevention in Atrial Fibrillation Study Group.

Appendix E Table 5 Quality Assessment of Randomized, Controlled Trials: Additional Questions for Studies Reporting Harms (KQ 6)

First Author, Year; Trial Name | Were harms pre-specified and defined? | Were ascertainment techniques for harms adequately described? | Were ascertainment techniques for harms equal, valid, and reliable? | Was duration of followup adequate for harms assessment? | Quality Rating | Comments
Connolly et al, 1991^99^; CAFA study | Yes | Yes | Yes | Yes (mean followup 15.2 months) | Fair | Self-report of bleeding events
Ezekowitz et al, 1992^97^ | Yes | Yes | Yes | Yes (mean followup 1.7 to 1.8 years) | Fair
Petersen et al, 1989^102^; AFASAK | Yes | Yes | Yes | Yes | Fair
Stroke Prevention in Atrial Fibrillation Study Group, 1991^98,^ ^101^; SPAF | Yes | Yes | Yes | Yes (mean followup 1.3 years) | Fair
The Boston Area Anticoagulation Trial for Atrial Fibrillation Investigators, 1990^100^; BAATAF | Yes | Yes | Yes | Yes (mean followup 2.2 years) | Fair

Abbreviations: AFASAK=Atrial Fibrillation, ASpirin, and AntiKoagulation; BAATAF=Boston Area Anticoagulation Trial for Atrial Fibrillation; CAFA=Canadian Atrial Fibrillation Anticoagulation Study; SPAF=Stroke Prevention in Atrial Fibrillation Study Group.

Appendix E Table 6 Quality Assessment of Diagnostic Test Accuracy Studies (KQ 3): Part 1

Study Author (Year) | Overall Study Quality | Comments
Gladstone et al (2021)^75^ | Good | No serious concerns for bias in any domains.
Himmelreich et al (2019)^112^ | Good | No serious concerns for bias in any domains.
Hobbs et al (2005)^91^ | Good | This analysis was embedded within a larger RCT comparing systematic and opportunistic screening to no screening. All study-related ECGs were used in the accuracy analysis. No serious concerns for bias in any domains.
Kearley et al (2014)^113^ | Fair | This study was given a fair rating for the following reasons: (1) the exclusion criteria were vague and could have introduced selection bias by allowing general practitioners to exclude patients considered inappropriate for participation without specifying what those reasons were other than terminal illness; (2) of the 2,673 patients recruited for study involvement, there is no specific description of how many patients were nonresponders; (3) there is no description of how many patients were excluded from the study because the practice discontinued involvement in the study; (4) there is no description of why practices discontinued involvement in the study; 5) nurse palpation vs. 12 lead ECG is included in the patient recruitment flowchart but is not described in the methods or reported in the results; 6) handling of missing triage testing data was not discussed in the methods or results.
Marazzi et al (2012)^115^ | Good
Philippsen et al (2017)^56^ | Good | No serious concerns for bias in any domains.
Sabar et al (2019)^117^ | Fair | Consecutive patients from outpatient cardiology clinics recruited for participation but no information about clinical status (e.g., existing AF); thus, the applicability is unclear.
Uittenbogaart et al, 2020^116^ | Fair | Only intervention practices were instructed to conduct confirmatory ECG for positive screens, so readers of the confirmatory ECGs would conceivably know these participants had screened positive. It appears usual care practices diagnosed patients through a different pathway that did not include the expert ECG readers. Primarily only participants in the screening practices who screened positive received ECG (the reference standard)—a 10% random sample who screened negative also received reference ECG; its unclear which patients in the usual care practices received ECG.
Weisel et al (2014)^114^ | Fair | Unclear method of enrollment, unclear whehter test results were masked.

Abbreviations: EECG=electrocardiogram; KQ=key question; RCT=randomized, controlled trial; vs.=versus.

Appendix E Table 7 Quality Assessment of Diagnostic Test Accuracy Studies (KQ 3): Part 2

Study Author(s) (Year(s) | Consider patients evaluated (prior testing, presentation, intended use of index test and setting). Is there concern that the included patients do not match the review question? | Consider index test. Is there concern that the index test, its conduct, or interpretation differ from the review question? | Consider reference test. Is there concern that the target condition as defined by the reference standard does not match the review question?
Gladstone et al (2021)^75^ | Yes | No | No
Himmelreich et al (2019)^112^ | Yes | No | No
Hobbs et al (2005)^91^ | Yes | No | No
Kearley et al (2014)^113^ | Yes | No | No
Marazzi et al (2012)^115^ | Unclear | No | No
Philippsen et al (2017)^56^ | Yes | No | No
Sabar et al (2019)^117^ | Unclear | No | No
Uittenbogaart et al, 2020^116^ | Yes | No | No
Weisel et al (2014)^114^ | Yes | No | No

Abbreviation: KQ=key question.

Appendix E Table 8 Quality Assessment of Diagnostic Test Accuracy Studies (KQ 3): Part 3

Study Author(s) (Year(s) | Was a consecutive or random sample of patients enrolled? | Was a case-control design avoided? | Did the study avoid inappropriate exclusions? | Could the selection of patients have introduced bias?
Gladstone et al (2021)^75^ | Yes | Yes | Yes | No
Himmelreich et al (2019)^112^ | Yes | Yes | Yes | No
Hobbs et al (2005)^91^ | Yes | Yes | Yes | No
Kearley et al (2014)^113^ | Yes | Yes | Yes | Yes
Marazzi et al (2012)^115^ | Yes | Yes | Yes | No
Philippsen et al (2017)^56^ | Unclear | Yes | Yes | No
Sabar et al (2019)^117^ | Yes | Yes | Yes | No
Uittenbogaart et al, 2020^116^ | Yes | Yes | Yes | No
Weisel et al (2014)^114^ | Unclear | Yes | Yes | No

Abbreviations: KQ=key question.

Appendix E Table 9 Quality Assessment of Diagnostic Test Accuracy Studies (KQ 3): Part 4

Study Author(s) (Year) | Were the index test results interpreted without knowledge of the results of the reference standard? | If a threshold was used, was it prespecified? | Could the conduct or interpretation of the index test have introduced bias?
Gladstone et al (2021)^75^ | Yes | Yes | No
Himmelreich et al (2019)^112^ | Yes | Yes | No
Hobbs et al (2005)^91^ | Yes | Unclear | No
Kearley et al (2017)^113^ | Yes | Yes | No
Marazzi et al (2012)^115^ | Yes | Yes | No
Philippsen et al (2017)^56^ | Yes | Yes | No
Sabar et al (2019)^117^ | Yes | Yes | No
Uittenbogaart et al, 2020^116^ | Yes | Yes | No
Weisel et al (2014)^114^ | Unclear | Unclear | No

Abbreviations: KQ=key question.

Appendix E Table 10 Quality Assessment of Diagnostic Test Accuracy Studies (KQ 3): Part 5

Study Author (Year) | Is the reference standard likely to correctly classify the target condition? | Were the reference standard results interpreted without knowledge of the results of the index test? | Could the reference standard, its conduct, or its interpretation have introduced bias?
Gladstone et al (2021)^75^ | Yes | Yes | No
Himmelreich et al (2019)^112^ | Yes | Yes | No
Hobbs et al (2005)^91^ | Yes | Yes | No
Kearley et al (2014)^113^ | Yes | Yes | No
Marazzi et al (2012)^115^ | Yes | Yes | No
Philippsen et al (2017)^56^ | Yes | Yes | No
Sabar et al (2019)^117^ | Yes | Yes | No
Uittenbogaart et al, 2020^116^ | Yes | Unclear | Yes
Weisel et al (2014)^114^ | Yes | Yes | No

Abbreviations: KQ=key question.

Appendix E Table 11 Quality Assessment of Diagnostic Test Accuracy Studies (KQ 3): Part 6

Study Author(s) (Year(s)) | Was there an appropriate interval between index test(s) and reference standard? | Did all patients receive a reference standard? | Did all patients receive the same reference standard? | Were all patients included in the analysis?
Gladstone et al (2021)^75^ | Yes | No | Yes | No
Himmelreich et al (2019)^112^ | Yes | Yes | Yes | No
Hobbs et al (2005)^91^ | Yes | Yes | Yes | Yes
Kearley et al (2014)^113^ | Yes | Yes | Yes | Yes
Marazzi et al (2012)^115^ | Yes | Yes | Yes | Yes
Philippsen et al (2017)^56^ | Yes | Yes | Yes | Yes
Sabar et al (2019)^117^ | Yes | Yes | Yes | Yes
Uittenbogaart et al, 2020^116^ | Yes | No (random sample received it) | Yes | Yes
Weisel et al (2014)^114^ | Yes | Yes | Yes | Unclear

Abbreviations: KQ=key question.

Appendix E Table 12 Quality Assessment of Systematic Reviews, Network Meta-Analyses, and IDP Meta-Analyses (KQ 5 and KQ 6)

Author, Year | Was the review based on a focused question of interest? | Was a comprehensive literature search (including grey literature) clearly described? | Were there explicit a priori inclusion/exclusion criteria for the selection of studies? | Did at least 2 people indepen-dently review studies? | Were the characteristics of the included studies provided? | Was the internal validity (quality) of included studies adequately assessed? | Was hetero-geneity assessed and addressed? | Was the approach used to synthesize the information adequate and appropriate? | Were the authors’ conclusions supported by the evidence? | Was publication bias assessed? | Quality Rating
Aguilar Maria, 2005^104^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
Atrial Fibrillation Investigators, 1994^107^ | Yes | No, but they identified all relevant known studies | Yes | NR | No | No | Yes (it is an IPD meta-analysis allowing greater assessment of heterogeneity (e.g., analyses of women separated) | Yes | Yes | NR | Fair
Coleman, 2012^103^ | Yes | Yes for published literature; no mention of grey literature | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes (some statistical tests reported, although not described in methods) | Fair
Hart, 2007^59^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Teresh-chenko, 2016^106^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
van Walraven, 2009^96^ | Yes | No, but they identified all relevant known studies (IPD analysis of data from a central database of clinical trials on patients with AF) | Yes | NR | Partially | No | Yes | Yes | Yes | NR | Fair

Abbreviations: AF=atrial fibrillation; IPD=individual patient data; KQ=key question; NR=not reported.

Appendix E Table 13 Relevance of Systematic Reviews and Meta-Analyses for the Benefits and Harms of Anticoagulation Therapy (KQ 5 and KQ 6)

First Author, Year | Review type (IPD, aggregate data SR, NMA)? | Did the review meet our initial eligibility criteria? | Did the review focus only on studies of primary prevention (with no or few participants with history of stroke or TIA)? | Did the review include all relevant trials on warfarin? | If the review is an NMA, did it include the relevant trials for newer OACs? | Has the review been updated? | Comments
Aguilar, 2009^104^ | SR with MA | Yes | Yes | Yes | NA | No | Cochrane review. Focuses on patients without history of stroke or TIA and got unpublished results from the Atrial Fibrillation Investigators that removed the 3% to 8% of participants with prior TIA or stroke from the studies.
Atrial Fibrillation Investigators, 1994^107^ | IPD | Yes | Yes | Yes | NA | No | Used the Atrial Fibrillation Investigators database; used only the 5 warfarin trials (2 of those also included ASA)
Coleman, 2012^103^ | SR with MA | Yes | No, combines primary prevention and secondary prevention studies; studies in the review were not selected because of history of stroke/TIA | No, it did not include SPAF-1 or CAFA (but those did not report MGIB) | NA | No | Combined studies of primary and secondary prevention (participants had a TIA or stroke) and does not provide any analyses separating them^a^ possibly limiting applicability
Hart, 2007^59^ | SR with MA | Yes | No, but separated (primary vs. secondary prevention) results for absolute risk reduction of stroke | Yes | NA | No (it is an update of a 1999 review)^211^ | Although the meta-analyses reporting relative reductions include both primary and secondary prevention studies, they stratify those for the absolute reduction data (in Tables 2 and 3)
Teresh-chenko, 2016^106^ | NMA | Yes | No, but most of the evidence is from trials focused mostly on primary prevention (4 of the 21 included trials had over 35% secondary prevention)^b^ | Yes | Yes, all the newer relevant trials included (although this excluded phase II trials of DOACs) | No | Includes some contribution of data from people with a history of TIA or stroke. DOAC phase II studies were excluded.
van Walraven, 2009^96^; Atrial Fibrillation Investigators | IPD | Yes | No, included 1 secondary prevention trial (EAFT), 1 trial with over a third having previous stroke or TIA (SPAF3), and one with around 20% secondary prevention (NASPEAF) but sensitivity analyses provided serial exclusion of individual studies (and those did not alter estimates) | Yes | NA | No | Used the Atrial Fibrillation Investigators database; included head-to-head and placebo-controlled studies

Abbreviations: ASA=American Society of Anesthesiologists; CAFA=Canadian Atrial Fibrillation Anticoagulation study; DOAC=direct oral anticoagulant; EAFT=European Atrial Fibrillation Trial; IPD=Individual patient data; JAST=Journal of Analytical Science and Technology; KQ=key question; LASAF=low-dose aspirin, stroke atrial fibrillation trial; MA=meta-analysis; MGIB=major gastrointestinal bleed; NA=not applicable; NASPEAF=National Study for Prevention of Embolism in Atrial Fibrillation Science; SPAF=Stroke Prevention in Atrial Fibrillation Study; SR=systematic review; TIA=transient ischemic attack.

a One quarter studies in VKA meta-analysis, and one third in the aspirin meta-analysis were secondary prevention studies.

b The percentage of participants with a history of TIA or stroke was 100% in EAFT (VKA vs. aspirin vs. placebo), 64% in JROCKET (rivaroxaban vs. VKA), 55% in ROCKET AF (rivaroxaban vs. VKA), and 38% in SPAF III. It was <10% in 9 trials (AFASAK I, BAATAF, SPAF I, CAFA, SPAF II, AFASAK II, PATAF, SAFT, and JAST) and ranged from 13% to 28% in the other 8 included trials.

Appendix E Table 14 Quality Assessment of Observational Cohort Studies Reporting Harms (KQ 6): Part 1

First Author, Year, Study Name | Is there potential for confounding | Was the analysis based on splitting participants’ follow up? | Were intervention discontinuations or switches likely to be related to factors that are prognostic for the outcome? | Use of an appropriate analysis method that controlled for important confounding domains? | Were confounding domains that were controlled for measured validly and reliably? | Control for any post-intervention variables? | Use an appropriate analysis method that adjusted for time-varying confounding? | Were confounding domains that were adjusted for measured validly and reliably? | Bias Due to Confounding | Comment
Bassand, 2018; GARFIELD-AF^110^ | Yes | No | NA | Probably no | Probably yes | No | Probably yes | Probably yes | Moderate | Uncertain that all important confounders were included

Abbreviations: GARFIELD-AF=Global Anticoagulant Registry in the FIELD-Atrial Fibrillation; KQ=key question; NA=not applicable.

Appendix E Table 15 Quality Assessment of Observational Cohort Studies Reporting Harms (KQ 6): Part 2

First Author, Year, Study Name | Was selection of participants into the study (or into the analysis) based on participant characteristics observed after the start of intervention? | Were the post-intervention variables that influenced selection likely to be associated with intervention? | Were the post-intervention variables that influenced selection likely to be influenced by the outcome or a cause of the outcome? | Do start of followup and start of intervention coincide for most participants? | Were adjustment techniques used that are likely to correct for the presence of selection biases? | Bias Due to Selection | Comment
Bassand, 2018; GARFIELD-AF^110^ | No | | | Yes | | Low

Abbreviations: GARFIELD-AF=Global Anticoagulant Registry in the FIELD-Atrial Fibrillation; KQ=key question.

Appendix E Table 16 Quality Assessment of Observational Cohort Studies Reporting Harms (KQ 6): Part 3

First Author, Year, Study Name | Were intervention groups clearly defined? | Was the information used to define intervention groups recorded at the start of the intervention? | Could classification of intervention status have been affected by knowledge of the outcome or risk of the outcome? | Bias Due to Classification | Comment
Bassand, 2018; GARFIELD-AF^110^ | Yes | Yes | No | Low

Abbreviations: GARFIELD-AF=Global Anticoagulant Registry in the FIELD-Atrial Fibrillation; KQ=key question.

Appendix E Table 17 Quality Assessment of Observational Cohort Studies Reporting Harms (KQ 6): Part 4

First Author, Year, Study Name | Were there deviations from the intended intervention beyond what would be expected in usual practice? | Were these deviations from intended intervention unbalanced between groups and likely to have affected the outcome? | Were important co-interventions balanced across inter-vention groups? | Was the intervention implemented successfully for most participants? | Did study participants adhere to the assigned intervention regimen? | Was an appropriate analysis used to estimate the effect of starting and adhering to the intervention? | Bias Due to Deviations | Comment
Bassand, 2018; GARFIELD-AF^110^ | Probably no | No | No information | No information | No information | No information | No information

Abbreviations: GARFIELD-AF=Global Anticoagulant Registry in the FIELD-Atrial Fibrillation; KQ=key question.

Appendix E Table 18 Quality Assessment of Observational Cohort Studies Reporting Harms (KQ 6): Part 5

First Author, Year, Study Name | Were outcome data available for all, or nearly all, participants? | Were participants excluded due to missing data on intervention status? | Were participants excluded due to missing data on other variables needed for the analysis? | Are the proportion of participants and reasons for missing data similar across interventions? | Is there evidence that results were robust to the presence of missing data? | Bias Due to Missing Data | Comment
Bassand, 2018; GARFIELD-AF^110^ | Yes | No | No | Yes | Yes | Low

Abbreviations: GARFIELD-AF=Global Anticoagulant Registry in the FIELD-Atrial Fibrillation; KQ=key question.

Appendix E Table 19 Quality Assessment of Observational Cohort Studies Reporting Harms (KQ 6): Part 6

First Author, Year, Study Name | Could the outcome measure have been influenced by knowledge of the intervention received? | Were outcome assessors aware of the intervention received by study participants? | Were the methods of outcome assessment comparable across intervention groups? | Were any systematic errors in measurement of the outcome related to intervention received? | Bias due to Measurement of Outcomes | Comment
Bassand, 2018; GARFIELD-AF^110^ | Probably yes | No information | Yes | No information | Moderate | Outcome assessment not specified as blinded to use of OACs.

Abbreviations: GARFIELD-AF=Global Anticoagulant Registry in the FIELD-Atrial Fibrillation; KQ=key question; OAC=oral anticoagulant.

Appendix E Table 20 Quality Assessment of Observational Cohort Studies Reporting Harms (KQ 6): Part 7

First Author, Year, Study Name | Multiple outcome measurements within the outcome domain? | Multiple analyses of the intervention-outcome relationship? | Different subgroups? | Bias Due to Selection of Reported Result | Comment
Bassand, 2018; GARFIELD-AF^110^ | No | No | No | Low

Abbreviations: GARFIELD-AF=Global Anticoagulant Registry in the FIELD-Atrial Fibrillation; KQ=key question.

Appendix E Table 21 Quality Assessment of Observational Cohort Studies Reporting Harms (KQ 6): Part 8

First Author, Year, Study Name | Overall Risk of Bias | Comment
Bassand, 2018; GARFIELD-AF^110^ | Moderate | Some risk of bias due to confounding and some concerns over outcome ascertainment because not blinded and ascertainment of bleeding might be more rigorous for participants known to be taking OACs

Abbreviations: GARFIELD-AF=Global Anticoagulant Registry in the FIELD-Atrial Fibrillation; KQ=key question; OAC=oral anticoagulant.