# Appendix D Excluded Studies

List of Exclusion Codes:

X1 Systematic review used for handsearch
X2 Ineligible publication type
X3 Ineligible country
X4 Ineligible population
X5 Ineligible intervention
X6 Ineligible comparator
X7 Ineligible outcome
X8 Ineligible study design
X9 Duplicate or superseded
X10 Study protocol or in progress
X11 Abstract only
X12 Non-English full text
X13 Other
X14 Poor quality
X15 Ineligible setting
X16 Other

1 ETNA AF-Europe: first 1-year follow-up snapshot analysis of 1,215 AF patients treated with edoxaban in routine clinical practice in Belgium. Acta Clin Belg. 2020;75:4–5. doi: 10.1080/00015385.2020.1705029. PMID: CN-02163896. Exclusion Code: X11.
2 Adderley NJ, Ryan R, Nirantharakumar K, . Prevalence and treatment of atrial fibrillation in UK general practice from 2000 to 2016. Heart. 2019 Jan;105(1):27–33. doi: 10.1136/heartjnl-2018-312977. PMID: 29991504. Exclusion Code: X7.29991504
3 Aguilar M, Hart R. Antiplatelet therapy for preventing stroke in patients with non-valvular atrial fibrillation and no previous history of stroke or transient ischemic attacks. Cochrane Database Syst Rev. 2005 Oct 19(4):CD001925. doi: 10.1002/14651858.CD001925.pub2. PMID: 16235290. Exclusion Code: X5.16235290
4 Alharbi M, Straiton N, Smith S, . Data management and wearables in older adults: a systematic review. Maturitas. 2019 Jun;124:100–10. doi: 10.1016/j.maturitas.2019.03.012. PMID: 30910279. Exclusion Code: X6.30910279
5 Al-Kaisey AM, Koshy AN, Ha FJ, . Accuracy of wrist-worn heart rate monitors for rate control assessment in atrial fibrillation. Int J Cardiol. 2019 doi: 10.1016/j.ijcard.2019.11.120. PMID: CN-02048453. Exclusion Code: X4.
6 Al-Kaisey AM, Koshy AN, Ha FJ, . Accuracy of wrist-worn heart rate monitors for rate control assessment in atrial fibrillation. Int J Cardiol. 2020 Feb 1;300:161–4. doi: 10.1016/j.ijcard.2019.11.120. PMID: 31787389. Exclusion Code: X4.31787389
7 An Y, Ogawa H, Yamashita Y, . Causes of death in Japanese patients with atrial fibrillation: the Fushimi Atrial Fibrillation Registry. Eur Heart J Qual Care Clin Outcomes. 2019 Jan 1;5(1):35–42. doi: 10.1093/ehjqcco/qcy033. PMID: 30020445. Exclusion Code: X7.30020445
8 Ananthan K. The efficacy and feasibility of atrial fibrillation screening using photoplethysmography-based smart devices. J Am Coll Cardiol. 2020 Mar 24;75(11):1365–6. doi: 10.1016/j.jacc.2019.09.074. PMID: 32192669. Exclusion Code: X2.32192669
9 Atrial Fibrillation Investigators. The efficacy of aspirin in patients with atrial fibrillation. Analysis of pooled data from 3 randomized trials. Arch Intern Med. 1997 Jun 9;157(11):1237–40. PMID: 9183235. Exclusion Code: X5.9183235
10 Attia ZI, Noseworthy PA, Lopez-Jimenez F, . An artificial intelligence-enabled ECG algorithm for the identification of patients with atrial fibrillation during sinus rhythm: a retrospective analysis of outcome prediction. Lancet. 2019 Sep 7;394(10201):861–7. doi: 10.1016/s0140-6736(19)31721-0. PMID: 31378392. Exclusion Code: X5.31378392
11 Attia ZI, Noseworthy PA, Lopez-Jimenez F, . An artificial intelligence-enabled ECG algorithm for the identification of patients with atrial fibrillation during sinus rhythm: a retrospective analysis of outcome prediction. Lancet. 2019 Sep 7;394(10201):861–7. doi: 10.1016/s0140-6736(19)31721-0. PMID: 31378392. Exclusion Code: X9.31378392
12 Auer J, Primus C. A smartwatch to identify atrial fibrillation. N Engl J Med. 2020 Mar 5;382(10):974. doi: 10.1056/NEJMc1916858. PMID: 32130825. Exclusion Code: X2.32130825
13 Badi MK, Vilanilam GK, Gupta V, . Pharmacotherapy for patients with atrial fibrillation and cerebral microbleeds. J Stroke Cerebrovasc Dis. 2019 Aug;28(8):2159–67. doi: 10.1016/j.jstrokecerebrovasdis.2019.04.027. PMID: 31103554. Exclusion Code: X8.31103554
14 Bandorski D, Bogossian H, Ecke A, . Evaluation of the prognostic value of electrocardiography parameters and heart rhythm in patients with pulmonary hypertension. Cardiol J. 2016;23(4):465–72. doi: 10.5603/CJ.a2016.0044. PMID: 27367480. Exclusion Code: X4.27367480
15 Barrett PM, Komatireddy R, Haaser S, . Comparison of 24-hour Holter monitoring with 14-day novel adhesive patch electrocardiographic monitoring. Am J Med. 2014 Jan;127(1):95.e11–7. doi: 10.1016/j.amjmed.2013.10.003. PMID: 24384108. Exclusion Code: X4.24384108
16 Bashar SK, Han D, Hajeb-Mohammadalipour S, . Atrial fibrillation detection from wrist photoplethysmography signals using smartwatches. Sci Rep. 2019 Oct 21;9(1):15054. doi: 10.1038/s41598-019-49092-2. PMID: 31636284. Exclusion Code: X4.31636284
17 Bleda AL, Melgarejo-Meseguer FM, Gimeno-Blanes FJ, . Enabling heart self-monitoring for all and for AAL-portable device within a complete telemedicine system. Sensors (Basel). 2019 Sep 14;19(18) doi: 10.3390/s19183969. PMID: 31540042. Exclusion Code: X8.31540042
18 Bo M, Li Puma F, Badinella Martini M, . Effects of oral anticoagulant therapy in older medical in-patients with atrial fibrillation: a prospective cohort observational study. Aging Clin Exp Res. 2017 Jun;29(3):491–7. doi: 10.1007/s40520-016-0569-7. PMID: 27100358. Exclusion Code: X6.27100358
19 Boriani G, Proietti M, Laroche C, . Changes to oral anticoagulant therapy and risk of death over a 3-year follow-up of a contemporary cohort of European patients with atrial fibrillation final report of the EURObservational Research Programme on Atrial Fibrillation (EORP-AF) pilot general registry. Int J Cardiol. 2018 Nov 15;271:68–74. doi: 10.1016/j.ijcard.2018.05.034. PMID: 30001945. Exclusion Code: X6.30001945
20 Brangier A, Ferland G, Rolland Y, . Vitamin K antagonists and cognitive decline in older adults: a 24-month follow-up. Nutrients. 2018 May 24;10(6) doi: 10.3390/nu10060666. PMID: 29794977. Exclusion Code: X6.29794977
21 Brasier N, Raichle CJ, Dörr M, . Detection of atrial fibrillation with a smartphone camera: first prospective, international, two-centre, clinical validation study (DETECT AF PRO). Europace. 2019 Jan 1;21(1):41–7. doi: 10.1093/europace/euy176. PMID: 30085018. Exclusion Code: X8.30085018
22 Busch MC, Gross S, Alte D, . Impact of atrial fibrillation detected by extended monitoring-a population-based cohort study. Ann Noninvasive Electrocardiol. 2017 Nov;22(6) doi: 10.1111/anec.12453. PMID: 28440600. Exclusion Code: X6.28440600
23 Caceres BA, Hickey KT, Bakken SB, . Mobile electrocardiogram monitoring and health-related quality of life in patients with atrial fibrillation: findings from the iPhone Helping Evaluate Atrial Fibrillation Rhythm Through Technology (iHEART) Study. J Cardiovasc Nurs. 2020 Feb 3 doi: 10.1097/jcn.0000000000000646. PMID: 32015256. Exclusion Code: X7.32015256
24 Cai W, Chen Y, Guo J, . Accurate detection of atrial fibrillation from 12-lead ECG using deep neural network. Comput Biol Med. 2020 Jan;116:103378. doi: 10.1016/j.compbiomed.2019.103378. PMID: 31778896. Exclusion Code: X5.31778896
25 Camm AJ, Accetta G, Mahmeed WA, . Impact of gender on event rates at 1-year in patients with newly diagnosed non-valvular atrial fibrillation: contemporary perspective from the GARFIELD-AF registry. BMJ open. 2017;7(3) (no pagination) doi: 10.1136/bmjopen-2016-014579. PMID: CN-01338615. Exclusion Code: X5.
26 Chan PH, Wong CK, Poh YC, . Diagnostic performance of a smartphone-based photoplethysmographic application for atrial fibrillation screening in a primary care setting. J Am Heart Assoc. 2016 Jul 21;5(7) doi: 10.1161/jaha.116.003428. PMID: 27444506. Exclusion Code: X6.27444506
27 Chan PH, Wong CK, Pun L, . Diagnostic performance of an automatic blood pressure measurement device, Microlife WatchBP Home A, for atrial fibrillation screening in a real-world primary care setting. BMJ Open. 2017 Jun 15;7(6):e013685. doi: 10.1136/bmjopen-2016-013685. PMID: 28619766. Exclusion Code: X6.28619766
28 Chan PH, Wong CK, Pun L, . Head-to-head comparison of the AliveCor Heart monitor and Microlife WatchBP Office AFIB for atrial fibrillation screening in a primary care setting. Circulation. 2017 Jan 3;135(1):110–2. doi: 10.1161/circulationaha.116.024439. PMID: 28028066. Exclusion Code: X6.28028066
29 Chan PH, Wong CK, Pun L, . Diagnostic performance of an automatic blood pressure measurement device, Microlife WatchBP Home A, for atrial fibrillation screening in a real-world primary care setting. BMJ Open. 2017 Jun 15;7(6):e013685. doi: 10.1136/bmjopen-2016-013685. PMID: 28619766. Exclusion Code: X9.28619766
30 Chao TF, Lip GYH, Lin YJ, . Major bleeding and intracranial hemorrhage risk prediction in patients with atrial fibrillation: Attention to modifiable bleeding risk factors or use of a bleeding risk stratification score? A nationwide cohort study. Int J Cardiol. 2018 Mar 1;254:157–61. doi: 10.1016/j.ijcard.2017.11.025. PMID: 29407081. Exclusion Code: X6.29407081
31 Chen E, Jiang J, Su R, . A new smart wristband equipped with an artificial intelligence algorithm to detect atrial fibrillation. Heart Rhythm. 2020 May;17(5 Pt B):847–53. doi: 10.1016/j.hrthm.2020.01.034. PMID: 32354449. Exclusion Code: X3.32354449
32 Cheng W, Liu W, Li B, . Relationship of anticoagulant therapy with cognitive impairment among patients with atrial fibrillation: a meta-analysis and systematic review. J Cardiovasc Pharmacol. 2018 Jun;71(6):380–7. doi: 10.1097/fjc.0000000000000575. PMID: 29528873. Exclusion Code: X1.29528873
33 Chon KH, McManus DD. Detection of atrial fibrillation using a smartwatch. Nat Rev Cardiol. 2018 Nov;15(11):657–8. doi: 10.1038/s41569-018-0057-1. PMID: 29985453. Exclusion Code: X2.29985453
34 Christesen AMS, Vinter N, Mortensen LS, . Inequality in oral anticoagulation use and clinical outcomes in atrial fibrillation: a Danish nationwide perspective. Eur Heart J Qual Care Clin Outcomes. 2018 Jul 1;4(3):189–99. doi: 10.1093/ehjqcco/qcy011. PMID: 30102321. Exclusion Code: X6.30102321
35 Cunha S, Antunes E, Antoniou S, . Raising awareness and early detection of atrial fibrillation, an experience resorting to mobile technology centred on informed individuals. Res Social Adm Pharm. 2019 Aug 20 doi: 10.1016/j.sapharm.2019.08.036. PMID: 31473110. Exclusion Code: X4.31473110
36 Cunha S, Antunes E, Antoniou S, . Raising awareness and early detection of atrial fibrillation, an experience resorting to mobile technology centred on informed individuals. Res Social Adm Pharm. 2020 Jun;16(6):787–92. doi: 10.1016/j.sapharm.2019.08.036. PMID: 31473110. Exclusion Code: X4.31473110
37 De Silva K, Chow C, Kumar S. A smartwatch to identify atrial fibrillation. N Engl J Med. 2020 Mar 5;382(10):974. doi: 10.1056/NEJMc1916858. PMID: 32130824. Exclusion Code: X2.32130824
38 Desteghe L, Raymaekers Z, Lutin M, . Performance of handheld electrocardiogram devices to detect atrial fibrillation in a cardiology and geriatric ward setting. Europace. 2017 Jan;19(1):29–39. doi: 10.1093/europace/euw025. PMID: 26893496. Exclusion Code: X4.26893496
39 Diamantino AC, Nascimento BR, Beaton AZ, . Atrial fibrillation detection with a portable device during cardiovascular screening in primary care. Heart. 2020 Feb 4 doi: 10.1136/heartjnl-2019-316277. PMID: 32019822. Exclusion Code: X4.32019822
40 Diederichsen SZ, Haugan KJ, Brandes A, . Natural history of subclinical atrial fibrillation detected by implanted loop recorders. J Am Coll Cardiol. 2019 Dec 3;74(22):2771–81. doi: 10.1016/j.jacc.2019.09.050. PMID: 31779791. Exclusion Code: X4.31779791
41 Diederichsen SZ, Haugan KJ, Kronborg C, . A comprehensive evaluation of rhythm monitoring strategies in screening for atrial fibrillation: insights from patients at risk long-term monitored with implantable loop recorder. Circulation. 2020 Mar 2 doi: 10.1161/circulationaha.119.044407. PMID: 32114796. Exclusion Code: X5.32114796
42 Diemberger I, De Caterina R. ETNA-AF-Europe: first 1-year follow-up snapshot analysis of more than 12,500 AF patients treated with edoxaban in routine clinical practice. G Ital Cardiol. 2019;20(12):163S-. PMID: CN-02095102. Exclusion Code: X10.
43 Ding EY, Han D, Whitcomb C, . Accuracy and usability of a novel algorithm for detection of irregular pulse using a smartwatch among older adults: observational study. JMIR Cardio. 2019 May 15;3(1):e13850. doi: 10.2196/13850. PMID: 31758787. Exclusion Code: X4.31758787
44 Ding M, Fratiglioni L, Johnell K, . Atrial fibrillation and use of antithrombotic medications in older people: A population-based study. Int J Cardiol. 2017 Dec 15;249:173–8. doi: 10.1016/j.ijcard.2017.07.012. PMID: 29121723. Exclusion Code: X7.29121723
45 Diouf I, Magliano DJ, Carrington MJ, . Prevalence, incidence, risk factors and treatment of atrial fibrillation in Australia: The Australian Diabetes, Obesity and Lifestyle (AusDiab) longitudinal, population cohort study. Int J Cardiol. 2016 Feb 15;205:127–32. doi: 10.1016/j.ijcard.2015.12.013. PMID: 26730844. Exclusion Code: X6.26730844
46 Doliwa PS, Frykman V, Rosenqvist M. Short-term ECG for out of hospital detection of silent atrial fibrillation episodes. Scand Cardiovasc J. 2009 Jun;43(3):163–8. doi: 10.1080/14017430802593435. PMID: 19096977. Exclusion Code: X6.19096977
47 Dörr M, Nohturfft V, Brasier N, . The WATCH AF Trial: SmartWATCHes for detection of atrial fibrillation. JACC Clin Electrophysiol. 2019 Feb;5(2):199–208. doi: 10.1016/j.jacep.2018.10.006. PMID: 30784691. Exclusion Code: X8.30784691
48 Dörr M, Nohturfft V, Brasier N, . Reply: Watch out: the many limitations in Smartwatch-driven AF detection. JACC Clin Electrophysiol. 2019 Apr;5(4):526–7. doi: 10.1016/j.jacep.2019.03.001. PMID: 31000111. Exclusion Code: X11.31000111
49 Duarte R, Stainthorpe A, Greenhalgh J, . Lead-I ECG for detecting atrial fibrillation in patients with an irregular pulse using single time point testing: a systematic review and economic evaluation. Health Technol Assess. 2020 Jan;24(3):1–164. doi: 10.3310/hta24030. PMID: 31933471. Exclusion Code: X1.31933471
50 Duarte R, Stainthorpe A, Mahon J, . Lead-I ECG for detecting atrial fibrillation in patients attending primary care with an irregular pulse using single-time point testing: A systematic review and economic evaluation. PLoS One. 2019;14(12):e0226671. doi: 10.1371/journal.pone.0226671. PMID: 31869370. Exclusion Code: X1.31869370
51 Eerikäinen LM, Bonomi AG, Dekker LRC, . Atrial fibrillation episodes detected using photoplethysmography: do we know which are true? J Am Coll Cardiol. 2020 Mar 24;75(11):1365. doi: 10.1016/j.jacc.2019.10.064. PMID: 32192670. Exclusion Code: X2.32192670
52 Eerikainen LM, Bonomi AG, Schipper F, . Detecting atrial fibrillation and atrial flutter in daily life using photoplethysmography data. IEEE J Biomed Health Inform. 2019 Nov 4 doi: 10.1109/jbhi.2019.2950574. PMID: 31689222. Exclusion Code: X5.31689222
53 Eerikainen LM, Bonomi AG, Schipper F, . Detecting atrial fibrillation and atrial flutter in daily life using photoplethysmography data. IEEE J Biomed Health Inform. 2020 Jun;24(6):1610–8. doi: 10.1109/jbhi.2019.2950574. PMID: 31689222. Exclusion Code: X8.31689222
54 Eerikainen LM, Bonomi AG, Schipper F, . Comparison between electrocardiogram- and photoplethysmogram-derived features for atrial fibrillation detection in free-living conditions. Physiol Meas. 2018 Aug 8;39(8):084001. doi: 10.1088/1361-6579/aad2c0. PMID: 29995641. Exclusion Code: X8.29995641
55 Frisch DR, Weiss M, Dikdan SJ, . Improved accuracy and confidence with multiple-lead recordings from a single-lead mobile electrocardiographic device. Pacing Clin Electrophysiol. 2019 Sep;42(9):1191–6. doi: 10.1111/pace.13775. PMID: 31400010. Exclusion Code: X4.31400010
56 Galarnyk M, Quer G, McLaughlin K, . Usability of a wrist-worn smartwatch in a direct-to-participant randomized pragmatic clinical trial. Digit Biomark. 2019 Sep–Dec;3(3):176–84. doi: 10.1159/000504838. PMID: 32095776. Exclusion Code: X7.32095776
57 Gettel C, Goldberg EM. Is the risk of bleeding among older adults with atrial fibrillation lower with antiplatelet compared with oral anticoagulants? Ann Emerg Med. 2018 Nov;72(5):547–9. doi: 10.1016/j.annemergmed.2017.10.011. PMID: 29174831. Exclusion Code: X2.29174831
58 Ghosh SK, Tripathy RK, Paternina MRA, . Detection of atrial fibrillation from single lead ECG signal using multirate cosine filter bank and deep neural network. J Med Syst. 2020 May 10;44(6):114. doi: 10.1007/s10916-020-01565-y. PMID: 32388733. Exclusion Code: X8.32388733
59 Giebel GD, Gissel C. Accuracy of mHealth devices for atrial fibrillation screening: systematic review. JMIR Mhealth Uhealth. 2019 Jun 16;7(6):e13641. doi: 10.2196/13641. PMID: 31199337. Exclusion Code: X7.31199337
60 Gilani M, Eklund JM, Makrehchi M. Automated detection of atrial fibrillation episode using novel heart rate variability features. Conf Proc IEEE Eng Med Biol Soc. 2016 Aug;2016:3461–4. doi: 10.1109/embc.2016.7591473. PMID: 28269045. Exclusion Code: X4.28269045
61 Giron NA, Millan CA, Lopez DM. Systematic review on features extracted from PPG signals for the detection of atrial fibrillation. Stud Health Technol Inform. 2019;261:266–73. PMID: 31156128. Exclusion Code: X1.31156128
62 Golive A, May HT, Bair TL, . The population-based long-term impact of anticoagulant and antiplatelet therapies in low-risk patients with atrial fibrillation. Am J Cardiol. 2017 Jul 1;120(1):75–82. doi: 10.1016/j.amjcard.2017.03.256. PMID: 28483209. Exclusion Code: X8.28483209
63 Grubb NR, Elder D, Broadhurst P, . Atrial fibrillation case finding in over 65s with cardiovascular risk factors - results of initial Scottish clinical experience. Int J Cardiol. 2019 Aug 1;288:94–9. doi: 10.1016/j.ijcard.2019.03.062. PMID: 31047704. Exclusion Code: X6.31047704
64 Grubb NR, Elder D, Broadhurst P, . Atrial fibrillation case finding in over 65 s with cardiovascular risk factors - results of initial Scottish clinical experience. Int J Cardiol. 2019 Aug 1;288:94–9. doi: 10.1016/j.ijcard.2019.03.062. PMID: 31047704. Exclusion Code: X2.31047704
65 Guan J, Wang A, Song W, . Screening for arrhythmia with the new portable single-lead electrocardiographic device (SnapECG): an application study in community-based elderly population in Nanjing, China. Aging Clin Exp Res. 2020 Mar 6 doi: 10.1007/s40520-020-01512-4. PMID: 32144732. Exclusion Code: X3.32144732
66 Gudmundsdottir KK, Fredriksson T, Svennberg E, . Stepwise mass screening for atrial fibrillation using N-terminal B-type natriuretic peptide: the STROKESTOP II study. Europace. 2020 Jan 1;22(1):24–32. doi: 10.1093/europace/euz255. PMID: 31790147. Exclusion Code: X6.31790147
67 Gudmundsdottir KK, Holmen A, Fredriksson T, . Decentralising atrial fibrillation screening to overcome socio-demographic inequalities in uptake in STROKESTOP II. J Med Screen. 2020 Mar 30:969141320908316. doi: 10.1177/0969141320908316. PMID: 32228146. Exclusion Code: X5.32228146
68 Gulati S, Solheim O, Carlsen SM, . Risk of intracranial hemorrhage (RICH) in users of oral antithrombotic drugs: nationwide pharmacoepidemiological study. PLoS One. 2018;13(8):e0202575. doi: 10.1371/journal.pone.0202575. PMID: 30138389. Exclusion Code: X4.30138389
69 Gullon A, Formiga F, Diez-Manglano J, . Influence of frailty on anticoagulant prescription and clinical outcomes after 1-year follow-up in hospitalised older patients with atrial fibrillation. Intern Emerg Med. 2019 Jan;14(1):59–69. doi: 10.1007/s11739-018-1938-3. PMID: 30191535. Exclusion Code: X6.30191535
70 Guo Y, Lane DA, Chen Y, . Mobile health technology facilitates population screening and integrated care management in patients with atrial fibrillation. Eur Heart J. 2020 May 1;41(17):1617–9. doi: 10.1093/eurheartj/ehaa161. PMID: 32357234. Exclusion Code: X2.32357234
71 Guo Y, Wang H, Zhang H, . Population-based screening or targeted screening based on initial clinical risk assessment for atrial fibrillation: a report from the Huawei Heart Study. J Clin Med. 2020 May 15;9(5) doi: 10.3390/jcm9051493. PMID: 32429241. Exclusion Code: X3.32429241
72 Haberman ZC, Jahn RT, Bose R, . Wireless smartphone ECG enables large-scale screening in diverse populations. J Cardiovasc Electrophysiol. 2015 May;26(5):520–6. doi: 10.1111/jce.12634. PMID: 25651872. Exclusion Code: X4.25651872
73 Hall A, Mitchell ARJ, Wood L, . Effectiveness of a single lead AliveCor electrocardiogram application for the screening of atrial fibrillation: A systematic review. Medicine (Baltimore). 2020 Jul 24;99(30):e21388. doi: 10.1097/md.0000000000021388. PMID: 32791751. Exclusion Code: X1.32791751
74 Han TS, Fry CH, Fluck D, . Anticoagulation therapy in patients with stroke and atrial fibrillation: a registry-based study of acute stroke care in Surrey, UK. BMJ Open. 2018 Jul 11;8(7):e022558. doi: 10.1136/bmjopen-2018-022558. PMID: 29997144. Exclusion Code: X8.29997144
75 Harrison SL, Lane DA, Guo Y, . The potential for photoplethysmographic (PPG)-based smart devices in atrial fibrillation detection. Expert Rev Med Devices. 2020 Apr;17(4):253–5. doi: 10.1080/17434440.2020.1740085. PMID: 32138559. Exclusion Code: X11.32138559
76 Hartikainen S, Lipponen JA, Hiltunen P, . Effectiveness of the chest strap electrocardiogram to detect atrial fibrillation. Am J Cardiol. 2019 May 15;123(10):1643–8. doi: 10.1016/j.amjcard.2019.02.028. PMID: 30878151. Exclusion Code: X15.30878151
77 Hartikainen S, Lipponen JA, Hiltunen P, . Effectiveness of the chest strap electrocardiogram to detect atrial fibrillation. Am J Cardiol. 2019 May 15;123(10):1643–8. doi: 10.1016/j.amjcard.2019.02.028. PMID: 30878151. Exclusion Code: X8.30878151
78 Haverkamp HT, Fosse SO, Schuster P. Accuracy and usability of single-lead ECG from smartphones - a clinical study. Indian Pacing Electrophysiol J. 2019 Jul – Aug;19(4):145–9. doi: 10.1016/j.ipej.2019.02.006. PMID: 30794928. Exclusion Code: X4.30794928
79 Hernandez I, Zhang Y, Saba S. Comparison of the effectiveness and safety of apixaban, dabigatran, rivaroxaban, and warfarin in newly diagnosed atrial fibrillation. Am J Cardiol. 2017 Nov 15;120(10):1813–9. doi: 10.1016/j.amjcard.2017.07.092. PMID: 28864318. Exclusion Code: X8.28864318
80 Hochstadt A, Chorin E, Viskin S, . Continuous heart rate monitoring for automatic detection of atrial fibrillation with novel bio-sensing technology. J Electrocardiol. 2019 Jan – Feb;52:23–7. doi: 10.1016/j.jelectrocard.2018.10.096. PMID: 30476634. Exclusion Code: X4.30476634
81 Huang Z, Chen Y, Pan M. Time-frequency characterization of atrial fibrillation from surface ECG based on Hilbert-Huang transform. J Med Eng Technol. 2007 Sep–Oct;31(5):381–9. doi: 10.1080/03091900601165314. PMID: 17701784. Exclusion Code: X4.17701784
82 Insulander P, Carnlöf C, Schenck-Gustafsson K, . Device profile of the Coala Heart Monitor for remote monitoring of the heart rhythm: overview of its efficacy. Expert Rev Med Devices. 2020 Mar;17(3):159–65. doi: 10.1080/17434440.2020.1732814. PMID: 32101067. Exclusion Code: X1.32101067
83 Jaakkola J, Jaakkola S, Lahdenoja O, . Mobile phone detection of atrial fibrillation with mechanocardiography: the MODE-AF study (Mobile Phone Detection of Atrial Fibrillation). Circulation. 2018 Apr 3;137(14):1524–7. doi: 10.1161/circulationaha.117.032804. PMID: 29526834. Exclusion Code: X8.29526834
84 Jang JP, Lin HT, Chen YJ, . Role of remote monitoring in detection of atrial arrhythmia, stroke reduction, and use of anticoagulation therapy-a systematic review and meta-analysis. Circ J. 2020 Oct 2 doi: 10.1253/circj.CJ-20-0633. PMID: 33012748. Exclusion Code: X1.33012748
85 Jonas DE, Kahwati LC, Yun JDY, . Screening for atrial fibrillation with electrocardiography: evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2018 Aug 7;320(5):485–98. doi: 10.1001/jama.2018.4190. PMID: 30088015. Exclusion Code: X1.30088015
86 Jun M, James MT, Ma Z, . Warfarin initiation, atrial fibrillation, and kidney function: comparative effectiveness and safety of warfarin in older adults with newly diagnosed atrial fibrillation. Am J Kidney Dis. 2017 Jun;69(6):734–43. doi: 10.1053/j.ajkd.2016.10.018. PMID: 27998624. Exclusion Code: X8.27998624
87 Kaisti M, Panula T, Leppanen J, . Clinical assessment of a non-invasive wearable MEMS pressure sensor array for monitoring of arterial pulse waveform, heart rate and detection of atrial fibrillation. NPJ Digit Med. 2019;2:39. doi: 10.1038/s41746-019-0117-x. PMID: 31304385. Exclusion Code: X4.31304385
88 Kaleschke G, Hoffmann B, Drewitz I, . Prospective, multicentre validation of a simple, patient-operated electrocardiographic system for the detection of arrhythmias and electrocardiographic changes. Europace. 2009 Oct;11(10):1362–8. doi: 10.1093/europace/eup262. PMID: 19797150. Exclusion Code: X4.19797150
89 Kalidas V, Tamil LS. Detection of atrial fibrillation using discrete-state Markov models and random forests. Comput Biol Med. 2019 Oct;113:103386. doi: 10.1016/j.compbiomed.2019.103386. PMID: 31446318. Exclusion Code: X4.31446318
90 Karaoğuz MR, Yurtseven E, Aslan G, . The quality of ECG data acquisition, and diagnostic performance of a novel adhesive patch for ambulatory cardiac rhythm monitoring in arrhythmia detection. J Electrocardiol. 2019 May–Jun;54:28–35. doi: 10.1016/j.jelectrocard.2019.02.012. PMID: 30851474. Exclusion Code: X3.30851474
91 Karunadas CP, Mathew C. Comparison of arrhythmia detection by conventional Holter and a novel ambulatory ECG system using patch and Android App, over 24 h period. Indian Pacing Electrophysiol J. 2019 Dec 19 doi: 10.1016/j.ipej.2019.12.013. PMID: 31866554. Exclusion Code: X4.31866554
92 Karunadas CP, Mathew C. Comparison of arrhythmia detection by conventional Holter and a novel ambulatory ECG system using patch and Android App, over 24 h period. Indian Pacing Electrophysiol J. 2020 Mar–Apr;20(2):49–53. doi: 10.1016/j.ipej.2019.12.013. PMID: 31866554. Exclusion Code: X3.31866554
93 Kemp Gudmundsdottir K, Fredriksson T, Svennberg E, . Stepwise mass screening for atrial fibrillation using N-terminal B-type natriuretic peptide: the STROKESTOP II study. Europace. 2019 doi: 10.1093/europace/euz255. PMID: CN-02052182. Exclusion Code: X6.
94 Kim NR, Choi CK, Kim HS, . Screening for atrial fibrillation using a smartphone-based electrocardiogram in Korean elderly. Chonnam Med J. 2020 Jan;56(1):50–4. doi: 10.4068/cmj.2020.56.1.50. PMID: 32021842. Exclusion Code: X6.32021842
95 Kimura K. STroke Secondary Prevention With Catheter ABLation and EDoxaban for patients with non-valvular atrial fibrillation: STABLED study. 2018 PMID: CN-02083183. Exclusion Code: X5.
96 Kohlman-Trigoboff D. Review article: Large-scale assessment of a smartwatch to identify atrial fibrillation. Perez, M, Mahaffey, K, Hedlin, H., . J Vasc Nurs. 2020 Jun;38(2):93–4. doi: 10.1016/j.jvn.2020.04.001. PMID: 32534659. Exclusion Code: X2.32534659
97 Kollias A, Destounis A, Kalogeropoulos P, . Atrial fibrillation detection during 24-hour ambulatory blood pressure monitoring: comparison with 24-hour electrocardiography. Hypertension. 2018 Jul;72(1):110–5. doi: 10.1161/hypertensionaha.117.10797. PMID: 29735633. Exclusion Code: X4.29735633
98 Koltowski L, Balsam P, Gllowczynska R, . Kardia Mobile applicability in clinical practice: a comparison of Kardia Mobile and standard 12-lead electrocardiogram records in 100 consecutive patients of a tertiary cardiovascular care center. Cardiol J. 2019 Jan 15 doi: 10.5603/CJ.a2019.0001. PMID: 30644079. Exclusion Code: X4.30644079
99 Kristensen AN, Jeyam B, Riahi S, . The use of a portable three-lead ECG monitor to detect atrial fibrillation in general practice. Scand J Prim Health Care. 2016 Jul 13:1–5. doi: 10.1080/02813432.2016.1207151. PMID: 27409151. Exclusion Code: X4.26846179
100 Kropp CM, Huber NL, Sager D, . Mobile-ECG screening in rural pharmacies: rates of atrial fibrillation and associated risk factors. Heart Lung. 2020 Feb 1 doi: 10.1016/j.hrtlng.2020.01.004. PMID: 32014313. Exclusion Code: X6.32014313
101 Kvist LM, Vinter N, Urbonaviciene G, . Diagnostic accuracies of screening for atrial fibrillation by cardiac nurses versus radiographers. Open Heart. 2019;6(1):e000942. doi: 10.1136/openhrt-2018-000942. PMID: 30997131. Exclusion Code: X5.30997131
102 Lai D, Bu Y, Su Y, . Non-standardized patch-based ECG lead together with deep learning based algorithm for automatic screening of atrial fibrillation. IEEE J Biomed Health Inform. 2020 Jun;24(6):1569–78. doi: 10.1109/jbhi.2020.2980454. PMID: 32175879. Exclusion Code: X11.32175879
103 Lambert CT, Bumgarner JM, Tarakji KG. Atrial fibrillation detection with wearable devices. JAMA. 2019 Jun 18;321(23):2367–8. doi: 10.1001/jama.2019.4538. PMID: 31211339. Exclusion Code: X2.31211339
104 Leggio M, Villano A, Fusco A. Smartphone-based clinical diagnostics and atrial fibrillation: the need to avoid being out of sight. J Intern Med. 2019 Sep;286(3):358–60. doi: 10.1111/joim.12916. PMID: 31069873. Exclusion Code: X2.31069873
105 Li G, Lip GYH, Holbrook A, . Direct comparative effectiveness and safety between non-vitamin K antagonist oral anticoagulants for stroke prevention in nonvalvular atrial fibrillation: a systematic review and meta-analysis of observational studies. Eur J Epidemiol. 2019 Feb;34(2):173–90. doi: 10.1007/s10654-018-0415-7. PMID: 29948370. Exclusion Code: X8.29948370
106 Lin CT, Chang KC, Lin CL, . An intelligent telecardiology system using a wearable and wireless ECG to detect atrial fibrillation. IEEE Trans Inf Technol Biomed. 2010 May;14(3):726–33. doi: 10.1109/titb.2010.2047401. PMID: 20371411. Exclusion Code: X8.20371411
107 Linden K, Mailey J, Kearney A, . Advances in clinical cardiology 2019: a summary of key clinical trials. Adv Ther. 2020 Jun;37(6):2620–45. doi: 10.1007/s12325-020-01355-5. PMID: 32361851. Exclusion Code: X2.32361851
108 Lindholt JS, Rasmussen LM, Søgaard R, . Baseline findings of the population-based, randomized, multifaceted Danish cardiovascular screening trial (DANCAVAS) of men aged 65-74 years. Br J Surg. 2019;106(7):862–71. doi: 10.1002/bjs.11135. PMID: CN-01940085. Exclusion Code: X5.30919411
109 Linz D, Pluymaekers N, Hendriks JM. TeleCheck-AF for COVID-19. Eur Heart J. 2020 Jun 1;41(21):1954–5. doi: 10.1093/eurheartj/ehaa404. PMID: 32379309. Exclusion Code: X2.32379309
110 Lown M, Brown M, Brown C, . Machine learning detection of atrial fibrillation using wearable technology. PLoS One. 2020;15(1):e0227401. doi: 10.1371/journal.pone.0227401. PMID: 31978173. Exclusion Code: X4.31978173
111 Lown M, Yue AM, Shah BN, . Screening for atrial fibrillation using economical and accurate technology (From the SAFETY Study). Am J Cardiol. 2018 Oct 15;122(8):1339–44. doi: 10.1016/j.amjcard.2018.07.003. PMID: 30131106. Exclusion Code: X4.30131106
112 Lux J, Stevens P, Hanotier P, . In a fall context, is the risk of hemorrhage (intracranial or other) increased in elderly patients with atrial fibrillation and treated with anticoagulants, compared to those who have no anticoagulant? Acta Clin Belg. 2020;74:31-. doi: 10.1080/17843286.2019.1687975. PMID: CN-02099607. Exclusion Code: X11.
113 Mandalenakis Z, Lennartsson ST, Fu M, . The incidence of atrial fibrillation and the added value of thumb ECG for detecting new cases. Scand Cardiovasc J. 2018 Oct;52(5):256–61. doi: 10.1080/14017431.2018.1509120. PMID: 30303692. Exclusion Code: X7.30303692
114 McManus D, Chong JW, Soni A, . PULSE-SMART: pulse-based arrhythmia discrimination using a novel smartphone application. J Cardiovasc Electrophysiol. 2016 Jan;27(1):51–7. doi: 10.1111/jce.12842. PMID: 26391728. Exclusion Code: X4.26391728
115 Millan CA, Giron NA, Lopez DM. Analysis of relevant features from photoplethysmographic signals for atrial fibrillation classification. Int J Environ Res Public Health. 2020 Jan 13;17(2) doi: 10.3390/ijerph17020498. PMID: 31941071. Exclusion Code: X6.31941071
116 Miyazawa K, Li YG, Rashed WA, . Secondary stroke prevention and guideline adherent antithrombotic treatment in patients with atrial fibrillation: insights from the Gulf Survey of atrial fibrillation events (Gulf SAFE). Int J Cardiol. 2019 Jan 1;274:126–31. doi: 10.1016/j.ijcard.2018.07.120. PMID: 30064925. Exclusion Code: X6.30064925
117 Moran PS, Teljeur C, Ryan M, . Systematic screening for the detection of atrial fibrillation. Cochrane Database Syst Rev. 2016 Jun 3;2016(6):Cd009586. doi: 10.1002/14651858.CD009586.pub3. PMID: 27258214. Exclusion Code: X1.27258214
118 Nakagawara J, Ikeda T, Ogawa S, . Real-world outcomes of rivaroxaban treatment in patients with nonvalvular atrial fibrillation and worsening renal function. J Cardiol. 2019 Dec;74(6):501–6. doi: 10.1016/j.jjcc.2019.06.003. PMID: 31371191. Exclusion Code: X8.31371191
119 Nault I, Andre P, Plourde B, . Validation of a novel single lead ambulatory ECG monitor - Cardiostat - compared to a standard ECG Holter monitoring. J Electrocardiol. 2019 Mar – Apr;53:57–63. doi: 10.1016/j.jelectrocard.2018.12.011. PMID: 30641305. Exclusion Code: X4.30641305
120 Nault I, André P, Plourde B, . Validation of a novel single lead ambulatory ECG monitor - Cardiostat™ - compared to a standard ECG Holter monitoring. J Electrocardiol. 2019 Mar–Apr;53:57–63. doi: 10.1016/j.jelectrocard.2018.12.011. PMID: 30641305. Exclusion Code: X4.30641305
121 Nct. Systematic ECG screening for atrial fibrillation among 75 year old subjects in the region of Stockholm and Halland, Sweden. https://clinicaltrials.gov/show/NCT01593553. 2012 PMID: CN-02038658. Exclusion Code: X10.
122 Nct. Blinded randomized trial of anticoagulation to prevent ischemic stroke and neurocognitive impairment in AF. https://clinicaltrials.gov/show/NCT02387229. 2015 PMID: CN-02046218. Exclusion Code: X10.
123 Nct. eHealth-based Bavarian alternative detection of atrial fibrillation: a randomized controlled trial (eBRAVE-AF). https://clinicaltrials.gov/show/NCT04250220. 2020 PMID: CN-02064600. Exclusion Code: X10.
124 Nct. The effect of a case-finding app on the detection rate of atrial fibrillation in primary care patients. https://clinicaltrials.gov/show/NCT04545723. 2020 PMID: CN-02163584. Exclusion Code: X10.
125 Nct. The Efficacy and Safety of Non-vItamiN K antaGonist oraL Anticoagulants for intermEdiate Stroke Risk in Patients With Atrial Fibrillation (SINGLE-AF). https://clinicaltrials.gov/show/NCT04437654. 2020 PMID: CN-02133726. Exclusion Code: X10.
126 Nct. Effect of wearable devices on patient-reported outcomes and clinical utilization: a randomized, controlled trial. https://clinicaltrials.gov/show/NCT04468321. 2020 PMID: CN-02130099. Exclusion Code: X10.
127 Nct. MyHeartLab free living study. https://clinicaltrials.gov/show/NCT04314947. 2020 PMID: CN-02089214. Exclusion Code: X10.
128 Nishida T, Okumura Y, Yokoyama K, . Oral anticoagulant use and clinical outcomes in elderly Japanese patients: findings from the SAKURA AF Registry. Heart Vessels. 2019 Dec;34(12):2021–30. doi: 10.1007/s00380-019-01446-6. PMID: 31183513. Exclusion Code: X6.31183513
129 Nolker G, Mayer J, Boldt LH, . Performance of an implantable cardiac monitor to detect atrial fibrillation: results of the DETECT AF Study. J Cardiovasc Electrophysiol. 2016 Dec;27(12):1403–10. doi: 10.1111/jce.13089. PMID: 27565119. Exclusion Code: X4.27565119
130 O’Brien EC, Holmes DN, Thomas L, . Therapeutic strategies following major, clinically relevant nonmajor, and nuisance bleeding in atrial fibrillation: findings from ORBIT-AF. J Am Heart Assoc. 2018 Jun 9;7(12) doi: 10.1161/jaha.117.006391. PMID: 29886422. Exclusion Code: X6.29886422
131 O’Brien EC, Holmes DN, Thomas LE, . Prognostic significance of nuisance bleeding in anticoagulated patients with atrial fibrillation. Circulation. 2018 Aug 28;138(9):889–97. doi: 10.1161/circulationaha.117.031354. PMID: 29678813. Exclusion Code: X6.29678813
132 Okubo Y, Nakano Y, Yoshihiro I, . Efficacy of novel patch type device for screening silent atrial fibrillation. Circulation. 2019;140 doi: 10.1161/circ.140.suppl_1.11216. PMID: CN-02084939. Exclusion Code: X11.
133 Okumura K, Lip GYH, Akao M, . Edoxaban for the management of elderly Japanese patients with atrial fibrillation ineligible for standard oral anticoagulant therapies: rationale and design of the ELDERCARE-AF study. Am Heart J. 2017 Dec;194:99–106. doi: 10.1016/j.ahj.2017.08.017. PMID: 29223441. Exclusion Code: X10.29223441
134 Okumura K, Akao M, Yoshida T, . Low-Dose Edoxaban in Very Elderly Patients with Atrial Fibrillation. N Engl J Med. 2020;383(18):1735–45. doi: 10.1056/NEJMoa2012883. Exclusion Code: X1632865374
135 Omboni S, Verberk WJ. Opportunistic screening of atrial fibrillation by automatic blood pressure measurement in the community. BMJ Open. 2016 Apr 12;6(4):e010745. doi: 10.1136/bmjopen-2015-010745. PMID: 27072571. Exclusion Code: X6.27072571
136 Orchard J, Li J, Freedman B, . Atrial fibrillation screen, management, and guideline-recommended therapy in the rural primary care setting: a cross-sectional study and cost-effectiveness analysis of ehealth tools to support all stages of screening. J Am Heart Assoc. 2020 Sep 15;9(18):e017080. doi: 10.1161/jaha.120.017080. PMID: 32865129. Exclusion Code: X6.32865129
137 Osca Asensi J, Izquierdo de Francisco MT, Cano Pérez Ó, . The RITHMI study: diagnostic ability of a heart rhythm monitor for automatic detection of atrial fibrillation. Rev Esp Cardiol (Engl Ed). 2020 Aug 10 doi: 10.1016/j.rec.2020.05.034. PMID: 32792313. Exclusion Code: X4.32792313
138 O’Sullivan JW, Grigg S, Crawford W, . Accuracy of smartphone camera applications for detecting atrial fibrillation: a systematic review and meta-analysis. JAMA Netw Open. 2020 Apr 1;3(4):e202064. doi: 10.1001/jamanetworkopen.2020.2064. PMID: 32242908. Exclusion Code: X1.32242908
139 Otto CM. Heartbeat: diagnosis of subclinical atrial fibrillation by physicians and patients. Heart. 2019 Jun;105(11):809–11. doi: 10.1136/heartjnl-2019-315232. PMID: 31092678. Exclusion Code: X2.31092678
140 Otto CM. Heartbeat: smartwatch devices for detection of atrial fibrillation. Heart. 2020 May;106(9):627–8. doi: 10.1136/heartjnl-2020-316958. PMID: 32291312. Exclusion Code: X5.32291312
141 Pala E, Bustamante A, Clua-Espuny JL, . N-terminal Pro B-type natriuretic peptide’s usefulness for paroxysmal atrial fibrillation detection among populations carrying cardiovascular risk factors. Front Neurol. 2019;10 doi: 10.3389/fneur.2019.01226. PMID: CN-02052220. Exclusion Code: X6.
142 Papakonstantinou PE, Asimakopoulou NI, Papadakis JA, . Frailty status affects the decision for long-term anticoagulation therapy in elderly patients with atrial fibrillation. Drugs Aging. 2018 Oct;35(10):897–905. doi: 10.1007/s40266-018-0587-6. PMID: 30203312. Exclusion Code: X8.30203312
143 Pastori D, Farcomeni A, Saliola M, . Temporal trends of time in therapeutic range and incidence of cardiovascular events in patients with non-valvular atrial fibrillation. Eur J Intern Med. 2018 Aug;54:34–9. doi: 10.1016/j.ejim.2018.04.007. PMID: 29655807. Exclusion Code: X6.29655807
144 Perez MV, Mahaffey KW, Hedlin H, . Large-scale assessment of a smartwatch to identify atrial fibrillation. N Engl J Med. 2019;381(20):1909–17. doi: 10.1056/NEJMoa1901183. PMID: CN-02004593. Exclusion Code: X9.31722151
145 Perez MV, Mahaffey KW, Hedlin H, . Large-scale assessment of a smartwatch to identify atrial fibrillation. N Engl J Med. 2019 Nov 14;381(20):1909–17. doi: 10.1056/NEJMoa1901183. PMID: 31722151. Exclusion Code: X4.31722151
146 Pluymaekers N, Hermans ANL, van der Velden RMJ, . Implementation of an on-demand app-based heart rate and rhythm monitoring infrastructure for the management of atrial fibrillation through teleconsultation: TeleCheck-AF. Europace. 2020 Sep 4 doi: 10.1093/europace/euaa201. PMID: 32887994. Exclusion Code: X8.32887994
147 Poh MZ, Poh YC, Chan PH, . Diagnostic assessment of a deep learning system for detecting atrial fibrillation in pulse waveforms. Heart. 2018 Dec;104(23):1921–8. doi: 10.1136/heartjnl-2018-313147. PMID: 29853485. Exclusion Code: X6.29853485
148 Poli L, Grassi M, Zedde M, . Anticoagulants resumption after warfarin-related intracerebral haemorrhage: the multicenter study on cerebral hemorrhage in Italy (MUCH-Italy). Thromb Haemost. 2018 Mar;118(3):572–80. doi: 10.1055/s-0038-1627454. PMID: 29433151. Exclusion Code: X4.29433151
149 Prasitlumkum N, Cheungpasitporn W, Chokesuwattanaskul A, . Diagnostic accuracy of smart gadgets/wearable devices in detecting atrial fibrillation: a systematic review and meta-analysis. Arch Cardiovasc Dis. 2020 Sep 10 doi: 10.1016/j.acvd.2020.05.015. PMID: 32921618. Exclusion Code: X1.32921618
150 Proesmans T, Mortelmans C, Van Haelst R, . Mobile phone-based use of the photoplethysmography technique to detect atrial fibrillation in primary care: diagnostic accuracy study of the FibriCheck App. JMIR Mhealth Uhealth. 2019 Mar 27;7(3):e12284. doi: 10.2196/12284. PMID: 30916656. Exclusion Code: X4.30916656
151 Proietti M, Laroche C, Opolski G, . ‘Real-world’ atrial fibrillation management in Europe: observations from the 2-year follow-up of the EURObservational Research Programme-Atrial Fibrillation General Registry Pilot Phase. Europace. 2017 May 1;19(5):722–33. doi: 10.1093/europace/euw112. PMID: 27194538. Exclusion Code: X6.27194538
152 Qiu J, Wang Y. A smartwatch to identify atrial fibrillation. N Engl J Med. 2020 Mar 5;382(10):974–5. doi: 10.1056/NEJMc1916858. PMID: 32130826. Exclusion Code: X2.32130826
153 Quinn FR, Gladstone DJ, Ivers NM, . Diagnostic accuracy and yield of screening tests for atrial fibrillation in the family practice setting: a multicentre cohort study. CMAJ Open. 2018 Jul–Sep;6(3):E308–e15. doi: 10.9778/cmajo.20180001. PMID: 30072410. Exclusion Code: X6.30072410
154 Rajakariar K, Koshy AN, Sajeev JK, . Accuracy of a smartwatch based single-lead electrocardiogram device in detection of atrial fibrillation. Heart. 2020 Jan 7 doi: 10.1136/heartjnl-2019-316004. PMID: 31911507. Exclusion Code: X15.31911507
155 Ramkumar S, Nerlekar N, D’Souza D, . Atrial fibrillation detection using single lead portable electrocardiographic monitoring: a systematic review and meta-analysis. BMJ Open. 2018 Sep 17;8(9):e024178. doi: 10.1136/bmjopen-2018-024178. PMID: 30224404. Exclusion Code: X1.30224404
156 Reading M, Baik D, Beauchemin M, . Factors influencing sustained engagement with ECG self-monitoring: perspectives from patients and health care providers. Appl Clin Inform. 2018 Oct;9(4):772–81. doi: 10.1055/s-0038-1672138. PMID: 30304745. Exclusion Code: X8.30304745
157 Reiffel JA, Verma A, Kowey PR, . Rhythm monitoring strategies in patients at high risk for atrial fibrillation and stroke: a comparative analysis from the REVEAL AF study. Am Heart J. 2020 Jan;219:128–36. doi: 10.1016/j.ahj.2019.07.016. PMID: 31862084. Exclusion Code: X6.31862084
158 Ribeiro ALP, Paixao GMM, Gomes PR, . Tele-electrocardiography and bigdata: the CODE (Clinical Outcomes in Digital Electrocardiography) study. J Electrocardiol. 2019 Nov – Dec;57s:S75–s8. doi: 10.1016/j.jelectrocard.2019.09.008. PMID: 31526573. Exclusion Code: X5.31526573
159 Rincon F, Grassi PR, Khaled N, . Automated real-time atrial fibrillation detection on a wearable wireless sensor platform. Conf Proc IEEE Eng Med Biol Soc. 2012;2012:2472–5. doi: 10.1109/embc.2012.6346465. PMID: 23366426. Exclusion Code: X4.23366426
160 Samol A, Bischof K, Luani B, . Patient directed recording of a bipolar three-lead electrocardiogram using a smartwatch with ECG Function. J Vis Exp. 2019 Dec 11(154) doi: 10.3791/60715. PMID: 31885372. Exclusion Code: X5.31885372
161 Sato H, Ishikawa K, Kitabatake A, . Low-dose aspirin for prevention of stroke in low-risk patients with atrial fibrillation: Japan Atrial Fibrillation Stroke Trial. Stroke. 2006 Feb;37(2):447–51. doi: 10.1161/01.STR.0000198839.61112.ee. PMID: 16385088. Exclusion Code: X5.16385088
162 Savickas V, Stewart AJ, Rees-Roberts M, . Opportunistic screening for atrial fibrillation by clinical pharmacists in UK general practice during the influenza vaccination season: A cross-sectional feasibility study. PLoS Med. 2020 Jul;17(7):e1003197. doi: 10.1371/journal.pmed.1003197. PMID: 32678820. Exclusion Code: X6.32678820
163 Schack T, Safi Harb Y, Muma M, . Computationally efficient algorithm for photoplethysmography-based atrial fibrillation detection using smartphones. Conf Proc IEEE Eng Med Biol Soc. 2017 Jul;2017:104–8. doi: 10.1109/embc.2017.8036773. PMID: 29059821. Exclusion Code: X4.29059821
164 Schnabel RB, Pecen L, Ojeda FM, . Gender differences in clinical presentation and 1-year outcomes in atrial fibrillation. Heart. 2017 Jul;103(13):1024–30. doi: 10.1136/heartjnl-2016-310406. PMID: 28228467. Exclusion Code: X6.28228467
165 Selder JL, Breukel L, Blok S, . A mobile one-lead ECG device incorporated in a symptom-driven remote arrhythmia monitoring program. The first 5,982 Hartwacht ECGs. Neth Heart J. 2019 Jan;27(1):38–45. doi: 10.1007/s12471-018-1203-4. PMID: 30523617. Exclusion Code: X4.30523617
166 Seshadri DR, Bittel B, Browsky D, . Accuracy of the Apple Watch 4 to measure heart rate in patients with atrial fibrillation. IEEE J Transl Eng Health Med. 2020;8:2700204. doi: 10.1109/jtehm.2019.2950397. PMID: 32128290. Exclusion Code: X9.32128290
167 Seshadri DR, Bittel B, Browsky D, . Accuracy of Apple Watch for detection of atrial fibrillation. Circulation. 2020 Feb 25;141(8):702–3. doi: 10.1161/circulationaha.119.044126. PMID: 32091929. Exclusion Code: X4.32091929
168 Shao M, Zhou Z, Bin G, . A wearable electrocardiogram telemonitoring system for atrial fibrillation detection. Sensors (Basel). 2020 Jan 22;20(3) doi: 10.3390/s20030606. PMID: 31979184. Exclusion Code: X8.31979184
169 Solosenko A, Petrenas A, Paliakaite B, . Detection of atrial fibrillation using a wrist-worn device. Physiol Meas. 2019 Feb 22;40(2):025003. doi: 10.1088/1361-6579/ab029c. PMID: 30695758. Exclusion Code: X4.30695758
170 Sološenko A, Petrėnas A, Paliakaitė B, . Detection of atrial fibrillation using a wrist-worn device. Physiol Meas. 2019 Feb 22;40(2):025003. doi: 10.1088/1361-6579/ab029c. PMID: 30695758. Exclusion Code: X5.30695758
171 Steinberg BA, Piccini JP. Screening for atrial fibrillation with a wearable device. JAMA. 2018 Jul 10;320(2):139–41. doi: 10.1001/jama.2018.8513. PMID: 29998323. Exclusion Code: X8.29998323
172 Sterne JA, Bodalia PN, Bryden PA, . Oral anticoagulants for primary prevention, treatment and secondary prevention of venous thromboembolic disease, and for prevention of stroke in atrial fibrillation: systematic review, network meta-analysis and cost-effectiveness analysis. Health Technol Assess. 2017 Mar;21(9):1–386. doi: 10.3310/hta21090. PMID: 28279251. Exclusion Code: X1.28279251
173 Sterne JA, Bodalia PN, Bryden PA, . Oral anticoagulants for primary prevention, treatment and secondary prevention of venous thromboembolic disease, and for prevention of stroke in atrial fibrillation: systematic review, network meta-analysis and cost-effectiveness analysis. Health Technol Assess. 2017 Mar;21(9):1–386. doi: 10.3310/hta21090. PMID: 28279251. Exclusion Code: X5.28279251
174 Subic A, Cermakova P, Religa D, . Treatment of atrial fibrillation in patients with dementia: a cohort study from the Swedish Dementia Registry. J Alzheimers Dis. 2018;61(3):1119–28. doi: 10.3233/jad-170575. PMID: 29286925. Exclusion Code: X8.29286925
175 Svendsen JH. Atrial fibrillation detected by continuous ECG monitoring (LOOP). Clinicaltrials.gov. 2017 PMID: CN-01369861. Exclusion Code: X2.
176 Svendsen JH, Diederichsen SZ, Højberg S, . Implantable loop recorder detection of atrial fibrillation to prevent stroke (The LOOP Study): a randomised controlled trial. Lancet. 2021. doi: 10.1016/s0140-6736(21)01698-6. Exclusion Code: X4
177 Tepper PG, Liu X, Hamilton M, . Ischemic stroke in nonvalvular atrial fibrillation at warfarin initiation: assessment via a large insurance database. Stroke. 2017 Jun;48(6):1487–94. doi: 10.1161/strokeaha.116.015535. PMID: 28446621. Exclusion Code: X8.28446621
178 Tieleman RG, Plantinga Y, Rinkes D, . Validation and clinical use of a novel diagnostic device for screening of atrial fibrillation. Europace. 2014 Sep;16(9):1291–5. doi: 10.1093/europace/euu057. PMID: 24825766. Exclusion Code: X4.24825766
179 Tison GH, Sanchez JM, Ballinger B, . Passive detection of atrial fibrillation using a commercially available smartwatch. JAMA Cardiol. 2018 May 1;3(5):409–16. doi: 10.1001/jamacardio.2018.0136. PMID: 29562087. Exclusion Code: X8.29562087
180 Torfs T, Smeets CJ, Geng D, . Clinical validation of a low-power and wearable ECG patch for long term full-disclosure monitoring. J Electrocardiol. 2014 Nov–Dec;47(6):881–9. doi: 10.1016/j.jelectrocard.2014.08.012. PMID: 25201418. Exclusion Code: X4.25201418
181 Torres-Soto J, Ashley EA. Multi-task deep learning for cardiac rhythm detection in wearable devices. NPJ Digit Med. 2020;3:116. doi: 10.1038/s41746-020-00320-4. PMID: 32964139. Exclusion Code: X5.32964139
182 Towhari J, Masud N, Alanazi H. Evaluation of the diagnostic accuracy of smartphone electrocardiogram recorder compared to standard 12 lead electrocardiography in hospital settings. Saudi Med J. 2019 Jun;40(6):575–81. doi: 10.15537/smj.2019.6.24206. PMID: 31219492. Exclusion Code: X7.31219492
183 Towhari J, Masud N, Alanazi H. Evaluation of the diagnostic accuracy of smartphone electrocardiogram recorder compared to standard 12 lead electrocardiography in hospital settings. Saudi Med J. 2019 Jun;40(6):575–81. doi: 10.15537/smj.2019.6.24206. PMID: 31219492. Exclusion Code: X15.31219492
184 Turakhia MP, Desai M, Perez MV. A Smartwatch to identify atrial fibrillation. Reply. N Engl J Med. 2020 Mar 5;382(10):975–6. doi: 10.1056/NEJMc1916858. PMID: 32130828. Exclusion Code: X2.32130828
185 Valent F. New oral anticoagulant prescription rate and risk of bleeding in an Italian region. Pharmacoepidemiol Drug Saf. 2017 Oct;26(10):1205–12. doi: 10.1002/pds.4279. PMID: 28758284. Exclusion Code: X8.28758284
186 Valiaho ES, Kuoppa P, Lipponen JA, . Wrist band photoplethysmography in detection of individual pulses in atrial fibrillation and algorithm-based detection of atrial fibrillation. Europace. 2019 Jul 1;21(7):1031–8. doi: 10.1093/europace/euz060. PMID: 31505594. Exclusion Code: X8.31505594
187 van Doorn S, Tavenier A, Rutten FH, . Risk of cardiac and non-cardiac adverse events in community-dwelling older patients with atrial fibrillation: a prospective cohort study in the Netherlands. BMJ Open. 2018 Aug 23;8(8):e021681. doi: 10.1136/bmjopen-2018-021681. PMID: 30139900. Exclusion Code: X6.30139900
188 Vanassche T, Lauw MN, Eikelboom JW, . Risk of ischaemic stroke according to pattern of atrial fibrillation: analysis of 6563 aspirin-treated patients in ACTIVE-A and AVERROES. Eur Heart J. 2015;36(5):281–7. doi: 10.1093/eurheartj/ehu307. PMID: CN-02083160. Exclusion Code: X4.25187524
189 Wasserlauf J, You C, Patel R, . Smartwatch performance for the detection and quantification of atrial fibrillation. Circ Arrhythm Electrophysiol. 2019 Jun;12(6):e006834. doi: 10.1161/circep.118.006834. PMID: 31113234. Exclusion Code: X6.31113234
190 Wegner FK, Kochhauser S, Ellermann C, . Prospective blinded evaluation of the smartphone-based AliveCor Kardia ECG monitor for atrial fibrillation detection: the PEAK-AF study. Eur J Intern Med. 2019 Dec 2 doi: 10.1016/j.ejim.2019.11.018. PMID: 31806411. Exclusion Code: X4.31806411
191 Wegner FK, Kochhäuser S, Ellermann C, . Prospective blinded evaluation of the smartphone-based AliveCor Kardia ECG monitor for atrial fibrillation detection: the PEAK-AF study. Eur J Intern Med. 2020 Mar;73:72–5. doi: 10.1016/j.ejim.2019.11.018. PMID: 31806411. Exclusion Code: X15.31806411
192 Welton NJ, McAleenan A, Thom HH, . Screening strategies for atrial fibrillation: a systematic review and cost-effectiveness analysis. Health Technol Assess. 2017 May;21(29):1–236. doi: 10.3310/hta21290. PMID: 28629510. Exclusion Code: X1.28629510
193 Willey V, Franchino-Elder J, Fu AC, . Treatment and persistence with oral anticoagulants among newly diagnosed patients with non-valvular atrial fibrillation: a retrospective observational study in a US commercially insured and Medicare Advantage population. BMJ Open. 2018 Jun 30;8(6):e020676. doi: 10.1136/bmjopen-2017-020676. PMID: 29961012. Exclusion Code: X8.29961012
194 Witt D, Kellogg R, Snyder M, . Windows into human health through wearables data analytics. Curr Opin Biomed Eng. 2019 Mar;9:28–46. doi: 10.1016/j.cobme.2019.01.001. PMID: 31832566. Exclusion Code: X1.31832566
195 Wong KC, Klimis H, Lowres N, . Diagnostic accuracy of handheld electrocardiogram devices in detecting atrial fibrillation in adults in community versus hospital settings: a systematic review and meta-analysis. Heart. 2020 Aug;106(16):1211–7. doi: 10.1136/heartjnl-2020-316611. PMID: 32393588. Exclusion Code: X1.32393588
196 Wu Z, Feng X, Yang C. A deep learning method to detect atrial fibrillation based on continuous wavelet transform. Conf Proc IEEE Eng Med Biol Soc. 2019 Jul;2019:1908–12. doi: 10.1109/embc.2019.8856834. PMID: 31946271. Exclusion Code: X4.31946271
197 Wyatt KD. A Smartwatch to identify atrial fibrillation. N Engl J Med. 2020 Mar 5;382(10):975. doi: 10.1056/NEJMc1916858. PMID: 32130827. Exclusion Code: X2.32130827
198 Yamashita Y, Uozumi R, Hamatani Y, . Current status and outcomes of direct oral anticoagulant use in real-world atrial fibrillation patients-Fushimi AF Registry. Circ J. 2017 Aug 25;81(9):1278–85. doi: 10.1253/circj.CJ-16-1337. PMID: 28428449. Exclusion Code: X6.28428449
199 Yao X, Gersh BJ, Sangaralingham LR, . Risk of cardiovascular events and incident atrial fibrillation in patients without prior atrial fibrillation: implications for expanding the indications for anticoagulation. Am Heart J. 2018 May;199:137–43. doi: 10.1016/j.ahj.2018.02.005. PMID: 29754652. Exclusion Code: X8.29754652
200 Yenikomshian M, Jarvis J, Patton C, . Cardiac arrhythmia detection outcomes among patients monitored with the Zio patch system: a systematic literature review. Curr Med Res Opin. 2019 Oct;35(10):1659–70. doi: 10.1080/03007995.2019.1610370. PMID: 31045463. Exclusion Code: X1.31045463
201 Yeung C, Drew D, Hammond S, . Extended cardiac monitoring in patients with severe sleep apnea and no history of atrial fibrillation (the Reveal XT-SA Study). Am J Cardiol. 2018 Dec 1;122(11):1885–9. doi: 10.1016/j.amjcard.2018.08.032. PMID: 30274768. Exclusion Code: X4.30274768
202 Zaprutko T, Zaprutko J, Baszko A, . Feasibility of atrial fibrillation screening with mobile health technologies at pharmacies. J Cardiovasc Pharmacol Ther. 2020 Mar;25(2):142–51. doi: 10.1177/1074248419879089. PMID: 31578088. Exclusion Code: X6.31578088
203 Zaprutko T, Zaprutko J, Baszko A, . Feasibility of atrial fibrillation screening with mobile health technologies at pharmacies. J Cardiovasc Pharmacol Ther. 2020 Mar;25(2):142–51. doi: 10.1177/1074248419879089. PMID: 31578088. Exclusion Code: X6.31578088
204 Zeng D, Jiang C, Su C, . Anticoagulation in atrial fibrillation and cognitive decline: a systematic review and meta-analysis. Medicine (Baltimore). 2019 Feb;98(7):e14499. doi: 10.1097/md.0000000000014499. PMID: 30762777. Exclusion Code: X7.30762777
205 Zhang H, Zhang J, Li HB, . Validation of single centre pre-mobile atrial fibrillation apps for continuous monitoring of atrial fibrillation in a real-world setting: pilot cohort study. J Med Internet Res. 2019 Dec 3;21(12):e14909. doi: 10.2196/14909. PMID: 31793887. Exclusion Code: X3.31793887
206 Zhang L, Kumar KS, He H, . Fully organic compliant dry electrodes self-adhesive to skin for long-term motion-robust epidermal biopotential monitoring. Nat Commun. 2020 Sep 17;11(1):4683. doi: 10.1038/s41467-020-18503-8. PMID: 32943621. Exclusion Code: X5.32943621
207 Zimerman A, Sheridan B, Cooke S, . Trends in new diagnoses of atrial fibrillation after release of an ECG-capable Smartwatch. Circulation. 2020 Aug 25;142(8):814–6. doi: 10.1161/circulationaha.119.045562. PMID: 32833515. Exclusion Code: X8.32833515
208 Zink MD, Napp A, Gramlich M. Experience in screening for atrial fibrillation and monitoring arrhythmia using a single-lead ECG stick. Herzschrittmacherther Elektrophysiol. 2020 Sep;31(3):246–53. doi: 10.1007/s00399-020-00711-w. PMID: 32785743. Exclusion Code: X11.32785743
209 Zwart LA, Jansen RW, Ruiter JH, . Opportunistic screening for atrial fibrillation with a single lead device in geriatric patients. J Geriatr Cardiol. 2020 Mar;17(3):149–54. doi: 10.11909/j.issn.1671-5411.2020.03.007. PMID: 32280331. Exclusion Code: X6.32280331