# Appendix C Detailed Methods

## Appendix C1 Update Search Strategies

### MEDLINE^®^ via PubMed

#### Main Update Search (5/1/2017 through 2/19/2020)

Search | Query
#1 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Atrial Fibrillation”[Mesh] OR “Atrial Flutter”[Mesh] OR atrial fibril*[tiab] OR atrium fibril*[tiab] OR a-fib[tiab] OR afib[tiab] OR “atrial flutter”[tiab] OR “auricular flutter”[tiab])
#2 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Electrocardiography”[Mesh] OR electrocardiogram*[tiab] OR electrocardiograph*[tiab] OR electrocardiography[tiab] OR EKG[tiab] OR ECG[tiab] OR holter[tiab] OR “mobile cardiac outpatient telemetry”[tiab] OR patch monitor*[tiab] OR single lead[tiab] OR 12-lead[tiab])
#3 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND #2)
#4 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Mass Screening”[Mesh] OR screen*[tiab])
#5 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 AND #4)
#6 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “Controlled Clinical Trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH])
#7 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#5 AND #6)
#8 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])))
#9 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#5 AND #8)
#10 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 OR #9)
#11 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 AND Humans[Mesh:NOEXP]) OR (#10 NOT Animals[Mesh:NOEXP])
#12 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 AND Humans[Mesh:NOEXP]) OR (#10 NOT Animals[Mesh:NOEXP]) Filters: English
#13 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 AND Humans[Mesh:NOEXP]) OR (#10 NOT Animals[Mesh:NOEXP]) Filters: English; Adult: 19+ years
#14 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 AND Humans[Mesh:NOEXP]) OR (#10 NOT Animals[Mesh:NOEXP]) Filters: English; Adult: 19+ years; Aged: 65+ years
#15 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 AND Humans[Mesh:NOEXP]) OR (#10 NOT Animals[Mesh:NOEXP]) Filters: Publication date from 2017/05/01 to 2020/12/31; English; Adult: 19+ years; Aged: 65+ years
#16 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 AND #4) Filters: Systematic Reviews
#17 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 AND #4) Filters: Systematic Reviews; Meta-Analysis
#18 (https://www.ncbi.nlm.nih.gov/pubmed) | Search ((#17 AND Humans[Mesh:NOEXP]) OR (#17 NOT Animals[Mesh:NOEXP]))
#19 (https://www.ncbi.nlm.nih.gov/pubmed) | Search ((#17 AND Humans[Mesh:NOEXP]) OR (#17 NOT Animals[Mesh:NOEXP])) Filters: English
#20 (https://www.ncbi.nlm.nih.gov/pubmed) | Search ((#17 AND Humans[Mesh:NOEXP]) OR (#17 NOT Animals[Mesh:NOEXP])) Filters: English; Adult: 19+ years
#21 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Anticoagulants”[Mesh] OR “Dabigatran”[Mesh] OR “Rivaroxaban”[Mesh] OR “Warfarin”[Mesh] OR anticoagulant*[tiab] OR apixaban OR Coumadin OR Dabigatran OR Edoxaban OR Eliquis OR NOAC* OR Pradaxa OR Rivaroxaban OR Savaysa OR “vitamin k agonist”[All Fields] OR “vitamin k agonists”[All Fields] OR VKA OR warfarin OR Xarelto)
#22 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND #21)
#23 (https://www.ncbi.nlm.nih.gov/pubmed) | Search “Factor Xa Inhibitors”[Mesh] OR “factor xa”[tiab]
#24 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND #23)
#25 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Antithrombins”[Mesh] OR antithrombin*[tiab] OR thrombin inhibit*[tiab])
#26 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND #25)
#27 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Aspirin”[Mesh] OR “Aspirin, Dipyridamole Drug Combination”[Mesh] OR “clopidogrel”[Supplementary Concept] OR “Dipyridamole”[Mesh] OR “acetylsalicylic acid” OR Aggrenox OR anti-platelet* OR antiplatelet* OR ASA[tiab] OR aspirin OR clopidogrel OR Dipyridamole OR Plavix)
#28 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND #27)
#29 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#22 OR #24 OR #26 OR #28)
#30 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 AND Humans[Mesh:NOEXP]) OR (#29 NOT Animals[Mesh:NOEXP])
#31 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 AND Humans[Mesh:NOEXP]) OR (#29 NOT Animals[Mesh:NOEXP]) Filters: English
#32 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 AND Humans[Mesh:NOEXP]) OR (#29 NOT Animals[Mesh:NOEXP]) Filters: English; Adult: 19+ years
#33 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 AND Humans[Mesh:NOEXP]) OR (#29 NOT Animals[Mesh:NOEXP]) Filters: Publication date from 2017/05/01 to 2020/12/31; English; Adult: 19+ years
#34 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#33 AND #6)
#35 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#33 AND #8)
#36 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 AND Humans[Mesh:NOEXP]) OR (#29 NOT Animals[Mesh:NOEXP]) Filters: Systematic Reviews; Publication date from 2017/05/01 to 2020/12/31; English; Adult: 19+ years
#37 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#29 AND Humans[Mesh:NOEXP]) OR (#29 NOT Animals[Mesh:NOEXP]) Filters: Systematic Reviews; Meta-Analysis; Publication date from 2017/05/01 to 2020/12/31; English; Adult: 19+ years

#### Supplemental Search for Emerging Technologies (Inception through 2/19/2020)

Search | Query
#1 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Atrial Fibrillation”[Mesh] OR “Atrial Flutter”[Mesh] OR atrial fibril*[tiab] OR atrium fibril*[tiab] OR a-fib[tiab] OR afib[tiab] OR “atrial flutter”[tiab] OR “auricular flutter”[tiab])
#2 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“Fitness Trackers”[Mesh] OR “Mobile Applications”[Mesh] OR “Photoplethysmography”[Mesh] OR “Smartphone”[Mesh] OR “Telemedicine”[Mesh] OR “Wearable Electronic Devices”[Mesh:NOEXP])
#3 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND #2)
#4 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (“1-lead”[tiab] OR “single lead”[tiab] OR “3-lead”[tiab] OR “three lead” OR AliveCor[tiab] OR app[tiab] OR (apple[tiab] AND watch*[tiab]) OR “digital treatment”[tiab] OR “Cardiio Rhythm”[tiab] OR FibriCheck[tiab] OR Fitbit*[tiab] OR (fitness[tiab] AND tracker*[tiab]) OR “Galaxy Gear”[All Fields] OR “iRhythm Zio”[All Fields] OR KardiaMobile[tiab] OR mHealth[tiab] OR “mobile health”[tiab] OR ((mobile[tiab] AND (app[tiab] OR application*[tiab] OR apps[tiab])) OR Photoplethysmography[tiab] OR PPG[tiab] OR “portable device”[tiab] OR “portable devices”[tiab] OR smartphone*[tiab] OR ((smart[tiab] AND phone*[tiab]) OR (smart[tiab] AND watch*[tiab]) OR smartwatch*[tiab] OR telehealth[tiab] OR telemedicine[tiab] OR verily[tiab] OR wearable*[tiab] OR (“wristband device”[All Fields] OR “wristband devices”[All Fields]))
#5 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 AND #4)
#6 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#3 OR #5)
#7 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#6 AND Humans[Mesh:NOEXP]) OR (#6 NOT Animals[Mesh:NOEXP])
#8 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#6 AND Humans[Mesh:NOEXP]) OR (#6 NOT Animals[Mesh:NOEXP]) Filters: English
#9 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#6 AND Humans[Mesh:NOEXP]) OR (#6 NOT Animals[Mesh:NOEXP]) Filters: Systematic Reviews; English
#10 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#6 AND Humans[Mesh:NOEXP]) OR (#6 NOT Animals[Mesh:NOEXP]) Filters: Systematic Reviews; Meta-Analysis; English
#11 (https://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 NOT #10)

#### Supplemental Search for Diagnostic Accuracy (2/1/2014 through 4/22/2020)

Because the KQ on diagnostic accuracy (KQ 3) was new to this update, we conducted supplementary searches focused on screening accuracy (dates: 2/1/2014 to 4/22/2020). We relied on a good-quality systematic review conducted by Welton et al^208^ to identify potentially relevant diagnostic accuracy studies conducted before 2014.

Search Number | Query | Filters
1 | (“Atrial Fibrillation”[Mesh] OR “Atrial Flutter”[Mesh] OR atrial fibril*[tiab] OR atrium fibril*[tiab] OR a-fib[tiab] OR afib[tiab] OR “atrial flutter”[tiab] OR “auricular flutter”[tiab])
2 | (“Electrocardiography”[Mesh] OR “continuous ambulatory ECG”[tiab] OR “continuous ambulatory EKG”[All Fields] OR electrocardiogram*[tiab] OR electrocardiograph*[tiab] OR electrocardiography[tiab] OR EKG[tiab] OR ECG[tiab] OR “1-lead”[tiab] OR “single lead”[tiab] OR “3-lead”[tiab] OR “three lead”[tiab] OR “12-lead”[tiab] OR “twelve lead”[tiab] OR “event loop recorder”[tiab] OR Holter[tiab] OR “mobile cardiac telemetry”[tiab] OR patch monitor*)
3 | ((apple[tiab] AND watch*[tiab]) OR “digital treatment”[tiab] OR “Cardiio Rhythm”[tiab] OR FibriCheck[tiab] OR Fitbit*[tiab] OR (fitness[tiab] AND tracker*[tiab]) OR “Galaxy Gear”[All Fields] OR “iRhythm Zio”[All Fields] OR KardiaMobile[tiab] OR mHealth[tiab] OR “mobile health”[tiab] OR (mobile[tiab] AND (app[tiab] OR application*[tiab] OR apps[tiab])) OR Photoplethysmography[tiab] OR PPG[tiab] OR “portable device”[tiab] OR “portable devices”[tiab] OR smartphone*[tiab] OR (smart[tiab] AND phone*[tiab]) OR (smart[tiab] AND watch*[tiab]) OR smartwatch*[tiab] OR verily[tiab] OR wearable*[tiab] OR “wristband device”[All Fields] OR “wristband devices”[All Fields])
4 | (#1 AND (#2 OR #3))
5 | (“Sensitivity and Specificity”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “ROC Curve”[Mesh] OR “Reproducibility of Results”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR ((pre-test[tw] or pretest[tw]) AND probability[tw]) OR “predictive value”[tw] OR sensitivity[tw] OR specificity[tw] OR accuracy[tw] OR ROC[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw])
6 | (#4 AND #5)
7 | ((diagnos*[tiab] or screening[tiab]) AND (accurate*[tiab] or accuracy[tiab]))
8 | (#4 AND #7)
9 | (diagnos*[tiab] or underdiagnose*[tiab] or detect*[tiab] or identif*[tiab] or screen*[tiab])
10 | (#4 AND #9)
11 | (diagnos*[tiab] or detect*[tiab]) AND (rate[tiab] or yield[tiab] or PAF[tiab])
12 | (#4 AND #11)
13 | (“diagnosis” [Subheading] OR “Diagnosis, Computer-Assisted”[Mesh] OR “Early Diagnosis”[Mesh])
14 | (#4 AND #13)
15 | (#6 OR #8 OR #10 OR #12 OR #14)
16 | ((#15 AND Humans[Mesh:NOEXP]) OR (#15 NOT Animals[Mesh:NOEXP]))
17 | ((#15 AND Humans[Mesh:NOEXP]) OR (#15 NOT Animals[Mesh:NOEXP])) | English
18 | ((#15 AND Humans[Mesh:NOEXP]) OR (#15 NOT Animals[Mesh:NOEXP])) | English, Adult: 19+ years
19 | (address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control”[tw] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR “retrospective cohort”[tw] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] or horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murinae) | English, Adult: 19+ years
20 | #18 NOT #19 | English, Adult: 19+ years
28 | “Evaluation Study” [Publication Type] OR “Validation Study” [Publication Type]
29 | #20 AND #28
30 | (“Comparative Study”[pt] OR “Evaluation Study” [Publication Type] OR “Validation Study” [Publication Type] OR “Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])))
31 | #20 AND #30
32 | (“2014/02/01”[Date - Publication]: “3000”[Date - Publication])
33 | #29 AND #32

### Cochrane Library

#### Main Update Search (1/1/2017–2/21/2020)

ID | Search
#1 | [mh “Atrial Fibrillation”] OR [mh “Atrial Flutter”] OR atrial fibril*:ti,ab OR atrium fibril*:ti,ab OR a-fib:ti,ab OR afib:ti,ab OR “atrial flutter”:ti,ab OR “auricular flutter”:ti,ab
#2 | [mh “Electrocardiography”] OR electrocardiograph*:ti,ab OR electrocardiogram*:ti,ab OR EKG:ti,ab OR ECG:ti,ab OR holter:ti,ab OR “mobile cardiac outpatient telemetry”:ti,ab OR patch monitor*:ti,ab OR “single lead”:ti,ab OR “12-lead”:ti,ab
#3 | #1 AND #2
#4 | [mh “Mass Screening”] OR screen*:ti,ab
#5 | #3 AND #4
#6 | #5 with Publication Year from 2017 to 2020, with Cochrane Library publication date Between May 2017 and Jan 2020, in Trials
#7 | #6 NOT “conference abstract”:pt
#8 | #6 AND “conference abstract”:pt
#9 | [mh “Anticoagulants”] OR [mh “Dabigatran”] OR [mh “Rivaroxaban”] OR [mh “Warfarin”] OR anticoagulant*:ti,ab OR apixaban OR Coumadin OR Dabigatran OR Edoxaban OR Eliquis OR NOAC* OR Pradaxa OR Rivaroxaban OR Savaysa OR “vitamin k agonist”:ti,ab,kw OR “vitamin k agonists”:ti,ab,kw OR VKA OR warfarin OR Xarelto
#10 | #1 AND #9
#11 | [mh “Factor Xa Inhibitors”] OR “factor xa”:ti,ab
#12 | #1 AND #11
#13 | [mh “Antithrombins”] OR antithrombin*:ti,ab OR thrombin inhibit*:ti,ab
#14 | #1 AND #13
#15 | [mh “Aspirin”] OR [mh “Aspirin, Dipyridamole Drug Combination”] OR [mh “Dipyridamole”] OR “acetylsalicylic acid” OR Aggrenox OR anti-platelet* OR antiplatelet* OR ASA:ti,ab OR aspirin OR clopidogrel OR Dipyridamole OR Plavix
#16 | #1 AND #15
#17 | #10 OR #12 OR #14 OR #16
#18 | #17 with Publication Year from 2017 to 2020, in Trials
#19 | #18 NOT “conference abstract”:pt
#20 | #18 AND “conference abstract”:pt

#### Supplemental Emerging Technologies Search (Inception to 2/21/2020)

ID | Search
#1 | [mh “Atrial Fibrillation”] OR [mh “Atrial Flutter”] OR atrial fibril*:ti,ab OR atrium fibril*:ti,ab OR a-fib:ti,ab OR afib:ti,ab OR “atrial flutter”:ti,ab OR “auricular flutter”:ti,ab
#2 | [mh “Fitness Trackers”] OR [mh “Mobile Applications”] OR [mh “Photoplethysmography”] OR [mh “Smartphone”] OR [mh “Telemedicine”] OR [mh ^”Wearable Electronic Devices”]
#3 | #1 AND #2
#4 | “1-lead”:ti,ab OR “single lead”:ti,ab OR “3-lead”:ti,ab OR “three lead”:ti,ab OR AliveCor:ti,ab OR app:ti,ab OR (apple:ti,ab AND watch*:ti,ab) OR “digital treatment”:ti,ab OR “Cardiio Rhythm”:ti,ab OR FibriCheck:ti,ab OR Fitbit*:ti,ab OR (fitness:ti,ab AND tracker*:ti,ab) OR “Galaxy Gear”:ti,ab,kw OR “iRhythm Zio”:ti,ab,kw OR KardiaMobile:ti,ab OR mHealth:ti,ab OR “mobile health”:ti,ab OR (mobile:ti,ab AND (app:ti,ab OR application*:ti,ab OR apps:ti,ab)) OR Photoplethysmography:ti,ab OR PPG:ti,ab OR “portable device”:ti,ab OR “portable devices”:ti,ab OR smartphone*:ti,ab OR (smart:ti,ab AND phone*:ti,ab) OR (smart:ti,ab AND watch*:ti,ab) OR smartwatch*:ti,ab OR telehealth:ti,ab OR telemedicine:ti,ab OR Verily:ti,ab OR wearable*:ti,ab OR “wristband device”:ti,ab,kw OR “wristband devices”:ti,ab,kw
#5 | #1 AND #4
#6 | #3 OR #5
#7 | #6 AND “conference abstract”:pt
#8 | #6 NOT “conference abstract”:pt

#### Supplemental Diagnostic Accuracy Search (1/1/2014–2/21/2020)

ID | Search
1 | [mh “Atrial Fibrillation”] OR [mh “Atrial Flutter”] OR atrial fibril*:ti,ab OR atrium fibril*:ti,ab OR a-fib:ti,ab OR afib:ti,ab OR “atrial flutter”:ti,ab OR “auricular flutter”:ti,ab
#2 | [mh “Electrocardiography”] OR electrocardiogram*:ti,ab OR electrocardiograph*:ti,ab OR EKG:ti,ab OR ECG:ti,ab OR “1-lead”:ti,ab OR “single lead”:ti,ab OR “3-lead”:ti,ab OR “three lead”:ti,ab OR “12-lead”:ti,ab OR “twelve lead”:ti,ab OR “event loop recorder”:ti,ab OR Holter:ti,ab OR “mobile cardiac telemetry”:ti,ab OR patch monitor*:ti,ab
#3 | (apple:ti,ab AND watch*:ti,ab) OR “digital treatment”:ti,ab OR “Cardiio Rhythm”:ti,ab OR FibriCheck:ti,ab OR Fitbit*:ti,ab OR (fitness:ti,ab AND tracker*:ti,ab) OR “Galaxy Gear”:ti,ab,kw OR “iRhythm Zio”:ti,ab,kw OR KardiaMobile:ti,ab OR mHealth:ti,ab OR “mobile health”:ti,ab OR (mobile:ti,ab AND (app:ti,ab OR application*:ti,ab OR apps:ti,ab)) OR Photoplethysmography:ti,ab OR PPG:ti,ab OR “portable device”:ti,ab OR “portable devices”:ti,ab OR smartphone*:ti,ab OR (smart:ti,ab AND phone*:ti,ab) OR (smart:ti,ab AND watch*:ti,ab) OR smartwatch*:ti,ab OR Verily:ti,ab OR wearable*:ti,ab OR “wristband device”:ti,ab,kw OR “wristband devices”:ti,ab,kw
#4 | #1 AND (#2 OR #3)
#5 | [mh “Sensitivity and Specificity”] OR [mh “Predictive Value of Tests”] OR [mh “ROC Curve”] OR [mh “Reproducibility of Results”] OR [mh “False Negative Reactions”] OR [mh “False Positive Reactions”] OR ((“pre-test”:ti,ab,kw OR “pretest”:ti,ab,kw) AND “probability”:ti,ab,kw) OR “predictive value”:ti,ab,kw OR “sensitivity”:ti,ab,kw OR “specificity”:ti,ab,kw OR “accuracy”:ti,ab,kw OR “ROC”:ti,ab,kw OR “false positive”:ti,ab,kw OR “false negative”:ti,ab,kw OR “likelihood ratio”:ti,ab,kw
#6 | #4 AND #5
#7 | (diagnos*:ti,ab or screening:ti,ab) AND (accurate*:ti,ab or accuracy:ti,ab)
#8 | #4 AND #7
#9 | diagnos*:ti,ab or underdiagnose*:ti,ab or detect*:ti,ab or identif*:ti,ab or screen*:ti,ab
#10 | #4 AND #9
#11 | (diagnos*:ti,ab OR detect*:ti,ab) AND (rate:ti,ab OR yield:ti,ab OR PAF:ti,ab)
#12 | #4 AND #11
#13 | [mh /DI] OR [mh “Diagnosis, Computer-Assisted”] OR [mh “Early Diagnosis”]
#14 | #4 AND #13
#15 | #6 OR #8 OR #10 OR #12 OR #14
#16 | #15 with Publication Year from 2014 to 2020, in Trials
#17 | #16 AND “conference abstract”:pt
#18 | #16 NOT “conference abstract”:pt

### Gray Literature Searches (5/1/2017–2/25/2020)

#### ClinicalTrials.gov

##### Advanced Search

Limit to

Adults and English

[underlined: Screening]

CONDITION box: “Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter” AND Other:

Electrocardiograph* OR electrocardiogram* OR EKG OR ECG OR holter OR “mobile cardiac outpatient telemetry” OR patch monitor* OR “single lead” OR 12-lead AND screen*| Adult | Studies updated from 05/01/2017 to 02/24/2020

[underlined: Treatment]

CONDITION box: “Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter”

TREATMENT box: Anticoagulants OR Dabigatran OR Rivaroxaban OR Warfarin OR anticoagulant* OR apixaban OR Coumadin OR Dabigatran OR Edoxaban OR Eliquis OR NOAC* OR Pradaxa OR Rivaroxaban OR Savaysa OR “vitamin k agonist” OR “vitamin k agonists” OR VKA OR warfarin OR Xarelto OR “Factor Xa Inhibitors” OR “factor xa” OR Antithrombins OR antithrombin* OR thrombin inhibit* OR Aspirin OR clopidogrel OR Dipyridamole OR “acetylsalicylic acid” OR Aggrenox OR anti-platelet* OR antiplatelet* OR ASA OR aspirin OR Plavix| Adult | Studies updated from 05/01/2017 to 02/24/2020

EXPERT SEARCH STATEMENT: AREA[ConditionSearch] (EXPAND[Concept] “Atrial Fibrillation” OR EXPAND[Concept] “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR EXPAND[Concept] “atrial flutter” OR EXPAND[Concept] “auricular flutter”) AND AREA[InterventionSearch] (Anticoagulants OR Dabigatran OR Rivaroxaban OR Warfarin OR anticoagulant* OR apixaban OR Coumadin OR Dabigatran OR Edoxaban OR Eliquis OR NOAC* OR Pradaxa OR Rivaroxaban OR Savaysa OR “vitamin k agonist” OR “vitamin k agonists” OR VKA OR warfarin OR Xarelto OR “Factor Xa Inhibitors” OR “factor xa” OR Antithrombins OR antithrombin* OR thrombin inhibit* OR Aspirin OR clopidogrel OR Dipyridamole OR “acetylsalicylic acid” OR Aggrenox OR anti-platelet* OR antiplatelet* OR ASA OR aspirin OR Plavix) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] (“Adult” OR “Older Adult”) AND AREA[LastUpdatePostDate] EXPAND[Term] RANGE[05/01/2017, 02/24/2020]

[underlined: Emerging Technologies]

CONDITION box: “Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter”

OTHER TERMS box: “Fitness Trackers” OR “Mobile Applications” OR Photoplethysmography OR Smartphone OR Telemedicine OR “Wearable Electronic Devices” OR “1-lead” OR “single lead” OR “3-lead” OR “three lead” OR AliveCor OR app OR (apple AND watch*) OR “digital treatment” OR “Cardiio Rhythm” OR FibriCheck OR Fitbit* OR (fitness AND tracker*) OR “Galaxy Gear” OR “iRhythm Zio” OR KardiaMobile OR mHealth OR “mobile health” OR (mobile AND (app OR application* OR apps)) OR Photoplethysmography OR PPG OR “portable device” OR “portable devices” OR smartphone* OR (smart AND phone*) OR (smart AND watch*) OR smartwatch* OR telehealth OR telemedicine OR verily OR wearable* OR “wristband device” OR “wristband devices” | Adult | Studies updated from 05/01/2017 to 02/24/2020

EXPERT SEARCH STATEMENT: EXPAND[Concept] (“Fitness Trackers” OR “Mobile Applications” OR “Photoplethysmography” OR “Smartphone” OR “Telemedicine” OR “Wearable Electronic Devices” OR “1-lead” OR “single lead” OR “3-lead” OR “three lead” OR “AliveCor” OR “app” OR “apple” AND “watch*” OR “digital treatment” OR “Cardiio Rhythm” OR “FibriCheck” OR “Fitbit*” OR “fitness” AND “tracker*” OR “Galaxy Gear” OR “iRhythm Zio” OR “KardiaMobile” OR “mHealth” OR “mobile health” OR “mobile” AND (“app” OR “application*” OR “apps”) OR “Photoplethysmography” OR “PPG” OR “portable device” OR “portable devices” OR “smartphone*” OR “smart” AND “phone*” OR “smart” AND “watch*” OR “smartwatch*” OR “telehealth” OR “telemedicine” OR “verily” OR “wearable*” OR ““wristband device”” OR “wristband devices”) | EXPAND[Concept] “Atrial Fibrillation” OR EXPAND[Concept] “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR EXPAND[Concept] “atrial flutter” OR EXPAND[Concept] “auricular flutter” | Adult, Older Adult

[underlined: Diagnostic Accuracy Gap Search]

CONDITION box: “Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter”

OTHER TERMS box: (“Electrocardiography” OR “continuous ambulatory ECG” OR “continuous ambulatory EKG” OR electrocardiogram* OR electrocardiograph* OR electrocardiography OR EKG OR ECG OR “1-lead” OR “single lead” OR “3-lead” OR “three lead” OR “12-lead” OR “twelve lead” OR “event loop recorder” OR Holter OR “mobile cardiac telemetry” OR patch monitor* OR (apple AND watch*) OR “digital treatment” OR “Cardiio Rhythm” OR FibriCheck OR Fitbit* OR (fitness AND tracker*) OR “Galaxy Gear” OR “iRhythm Zio” OR KardiaMobile OR mHealth OR “mobile health” OR (mobile AND (app OR application* OR apps)) OR Photoplethysmography OR PPG OR “portable device” OR “portable devices” OR smartphone* OR (smart AND phone*) OR (smart AND watch*) OR smartwatch* OR verily OR wearable* OR “wristband device” OR “wristband devices”) AND (“Sensitivity and Specificity” OR “Predictive Value of Tests” OR “ROC Curve” OR “Reproducibility of Results” OR ((pre-test or pretest) AND probability) OR “predictive value” OR sensitivity OR specificity OR accuracy OR ROC OR “false positive” OR “false negative” OR “likelihood ratio” OR “ROC Curve” OR ((pre-test or pretest) AND probability) OR “predictive value” OR sensitivity OR specificity OR accuracy OR ROC OR “false positive” OR “false negative” OR “likelihood ratio” OR ((diagnos* or screening) AND (accurate* OR accuracy)) OR diagnos* or underdiagnose* or detect* or identif* or screen*)| Adult | Studies updated from 02/01/2014 to 02/24/2020

EXPERT SEARCH STATEMENT: (EXPAND[Concept] “Electrocardiography” OR “continuous ambulatory ECG” OR “continuous ambulatory EKG” OR electrocardiogram* OR electrocardiograph* OR electrocardiography OR EKG OR ECG OR “1-lead” OR “single lead” OR “3-lead” OR “three lead” OR “12-lead” OR “twelve lead” OR “event loop recorder” OR Holter OR “mobile cardiac telemetry” OR patch monitor* OR apple AND watch* OR “digital treatment” OR “Cardiio Rhythm” OR FibriCheck OR Fitbit* OR fitness AND tracker* OR “Galaxy Gear” OR “iRhythm Zio” OR KardiaMobile OR mHealth OR “mobile health” OR mobile AND (app OR application* OR apps) OR Photoplethysmography OR PPG OR “portable device” OR “portable devices” OR smartphone* OR smart AND phone* OR smart AND watch* OR smartwatch* OR verily OR wearable* OR “wristband device” OR “wristband devices”) AND (EXPAND[Concept] “Sensitivity and Specificity” OR EXPAND[Concept] “Predictive Value of Tests” OR EXPAND[Concept] “ROC Curve” OR EXPAND[Concept] “Reproducibility of Results” OR pre-test or pretest AND probability OR EXPAND[Concept] “predictive value” OR sensitivity OR specificity OR accuracy OR ROC OR EXPAND[Concept] “false positive” OR EXPAND[Concept] “false negative” OR EXPAND[Concept] “likelihood ratio” OR EXPAND[Concept] “ROC Curve” OR pre-test or pretest AND probability OR EXPAND[Concept] “predictive value” OR sensitivity OR specificity OR accuracy OR ROC OR EXPAND[Concept] “false positive” OR EXPAND[Concept] “false negative” OR EXPAND[Concept] “likelihood ratio” OR diagnos* or screening AND (accurate* OR accuracy) OR diagnos* or underdiagnose* or detect* or identif* or screen*) | EXPAND[Concept] “Atrial Fibrillation” OR EXPAND[Concept] “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR EXPAND[Concept] “atrial flutter” OR EXPAND[Concept] “auricular flutter” | Adult, Older Adult | Last update posted from 02/01/2014 to 02/24/2020

#### WHO ICRTRP Advanced Search (through 2/25/2020)

[underlined: Screening:]

Recruitment status: ALL

Date of registration is between 05/01/2017-02/24/2020

Condition box: “Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter”

Title box: Electrocardiograph* OR electrocardiogram* OR EKG OR ECG OR holter OR “mobile cardiac outpatient telemetry” OR patch monitor* OR “single lead” OR 12-lead AND screen*

[underlined: Treatment:]

Recruitment status: ALL

Date of registration is between 05/01/2017-02/24/2020

Condition box: “Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter”

Intervention box (Due to character limit in search box, split up to two searches to accommodate all intervention terms):

[underlined: Search 1]=Anticoagulants OR Dabigatran OR Rivaroxaban OR Warfarin OR anticoagulant* OR apixaban OR Coumadin OR Dabigatran OR Edoxaban OR Eliquis OR NOAC OR Pradaxa OR Rivaroxaban OR Savaysa OR “vitamin k agonist” OR “vitamin k agonists” OR VKA

[underlined: Search 2]=warfarin OR Xarelto OR “Factor Xa Inhibitors” OR “factor xa” OR antithrombin* OR thrombin inhibit* OR Aspirin OR clopidogrel OR Dipyridamole OR “acetylsalicylic acid” OR Aggrenox OR anti-platelet* OR antiplatelet* OR ASA OR aspirin OR Plavix

[underlined: Emerging Technologies and Diagnostic Accuracy Supplemental Searches]

Recruitment status: ALL

Condition box: “Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter”

Intervention box: Screening OR Diagnosis OR Electrocardiogram OR Electrocardiograph OR ECG OR EKG OR Smartphone OR Smartwatch OR “Wearable technology” OR “Mobile applications” OR Photoplethysmography

#### Other Websites Searched (as of 2/25/2020)

- AF-Screen International Collaboration
- American Academy of Family Physicians
- American Academy of Neurology
- American Heart Association
- American College of Cardiology
- American College of Chest Physicians
  American College of Physicians
- American Stroke Association
- Canadian Cardiovascular Society
- Canadian Agency for Drugs and Technologies in Health
- Centers for Disease Control and Prevention (United States)
- European Heart Rhythm Society
- European Society of Cardiology
- European Primary Care Cardiovascular Society
- Heart Rhythm Society (United States)
- National Institutes of Health (United States)
- National Institute for Health and Care Excellence (United Kingdom)
- National Institute for Health Research (United Kingdom)
- Scottish Intercollegiate Guidelines Network
- United Kingdom National Screening Committee
  World Heart Federation

### Update Searches, October 5–6, 2020

#### MEDLINE via PubMed, Main Searches (September 19, 2019–October 5, 2020)

Search Number | Query | Filters
1 | (“Atrial Fibrillation”[Mesh] OR “Atrial Flutter”[Mesh] OR atrial fibril*[tiab] OR atrium fibril*[tiab] OR a-fib[tiab] OR afib[tiab] OR “atrial flutter”[tiab] OR “auricular flutter”[tiab])
2 | (“Electrocardiography”[Mesh] OR electrocardiogram*[tiab] OR electrocardiograph*[tiab] OR electrocardiography[tiab] OR EKG[tiab] OR ECG[tiab] OR holter[tiab] OR “mobile cardiac outpatient telemetry”[tiab] OR patch monitor*[tiab] OR single lead[tiab] OR 12-lead[tiab])
3 | (#1 AND #2)
4 | (“Mass Screening”[Mesh] OR screen*[tiab])
5 | (#3 AND #4)
6 | (((randomized[title/abstract] OR randomised[title/abstract]) AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “Controlled Clinical Trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH])
7 | (#5 AND #6)
8 | (“Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])))
9 | (#5 AND #8)
10 | (#7 OR #9)
11 | (#10 AND Humans[Mesh:NOEXP]) OR (#10 NOT Animals[Mesh:NOEXP])
12 | (#10 AND Humans[Mesh:NOEXP]) OR (#10 NOT Animals[Mesh:NOEXP]) | English
13 | (#10 AND Humans[Mesh:NOEXP]) OR (#10 NOT Animals[Mesh:NOEXP]) | English, Adult: 19+ years
14 | #13 AND (“2019/09/19”[Date - Publication] : “3000”[Date - Publication]) | English, Adult: 19+ years
15 | (#3 AND #4) | Systematic Review
16 | (#3 AND #4) | Meta-Analysis, Systematic Review
17 | (#3 AND #4) | Meta-Analysis, Systematic Review, English
18 | (#3 AND #4) | Meta-Analysis, Systematic Review, English, Adult: 19+ years
19 | (#18 AND Humans[Mesh:NOEXP]) OR (#18 NOT Animals[Mesh:NOEXP]) | Meta-Analysis, Systematic Review, English, Adult: 19+ years
20 | #19 NOT #14
21 | (“Anticoagulants”[Mesh] OR “Dabigatran”[Mesh] OR “Rivaroxaban”[Mesh] OR “Warfarin”[Mesh] OR anticoagulant*[tiab] OR apixaban OR Coumadin OR Dabigatran OR Edoxaban OR Eliquis OR NOAC* OR Pradaxa OR Rivaroxaban OR Savaysa OR “vitamin k agonist”[All Fields] OR “vitamin k agonists”[All Fields] OR VKA OR warfarin OR Xarelto)
22 | (#1 AND #21)
23 | “Factor Xa Inhibitors”[Mesh] OR “factor xa”[tiab]
24 | (#1 AND #23)
25 | (“Antithrombins”[Mesh] OR antithrombin*[tiab] OR thrombin inhibit*[tiab])
26 | (#1 AND #25)
27 | (“Aspirin”[Mesh] OR “Aspirin, Dipyridamole Drug Combination”[Mesh] OR “clopidogrel”[Supplementary Concept] OR “Dipyridamole”[Mesh] OR “acetylsalicylic acid” OR Aggrenox OR anti-platelet* OR antiplatelet* OR ASA[tiab] OR aspirin OR clopidogrel OR Dipyridamole OR Plavix)
28 | (#1 AND #27)
29 | (#22 OR #24 OR #26 OR #28)
30 | (#29 AND Humans[Mesh:NOEXP]) OR (#29 NOT Animals[Mesh:NOEXP])
31 | (#29 AND Humans[Mesh:NOEXP]) OR (#29 NOT Animals[Mesh:NOEXP]) | English
32 | (#29 AND Humans[Mesh:NOEXP]) OR (#29 NOT Animals[Mesh:NOEXP]) | English, Adult: 19+ years
33 | #32 AND (“2019/09/19”[Date - Publication] : “3000”[Date - Publication])
34 | #33 AND #6
35 | #33 AND #8
36 | #32 AND (“2019/09/19”[Date - Publication] : “3000”[Date - Publication]) | Systematic Review
37 | #32 AND (“2019/09/19”[Date - Publication] : “3000”[Date - Publication]) | Meta-Analysis, Systematic Review
38 | (#13 OR #20 OR #32) AND (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields])

#### MEDLINE via PubMed, Emerging Technologies Searches (September 19, 2019–October 5, 2020)

Search Number | Query | Filters
1 | (“Atrial Fibrillation”[Mesh] OR “Atrial Flutter”[Mesh] OR atrial fibril*[tiab] OR atrium fibril*[tiab] OR a-fib[tiab] OR afib[tiab] OR “atrial flutter”[tiab] OR “auricular flutter”[tiab])
2 | (“Fitness Trackers”[Mesh] OR “Mobile Applications”[Mesh] OR “Photoplethysmography”[Mesh] OR “Smartphone”[Mesh] OR “Telemedicine”[Mesh] OR “Wearable Electronic Devices”[Mesh:NOEXP])
3 | (#1 AND #2)
4 | (“1-lead”[tiab] OR “single lead”[tiab] OR “3-lead”[tiab] OR “three lead” OR AliveCor[tiab] OR app[tiab] OR (apple[tiab] AND watch*[tiab]) OR “digital treatment”[tiab] OR “Cardiio Rhythm”[tiab] OR FibriCheck[tiab] OR Fitbit*[tiab] OR (fitness[tiab] AND tracker*[tiab]) OR “Galaxy Gear”[All Fields] OR “iRhythm Zio”[All Fields] OR KardiaMobile[tiab] OR mHealth[tiab] OR “mobile health”[tiab] OR ((mobile[tiab] AND (app[tiab] OR application*[tiab] OR apps[tiab])) OR Photoplethysmography[tiab] OR PPG[tiab] OR “portable device”[tiab] OR “portable devices”[tiab] OR smartphone*[tiab] OR ((smart[tiab] AND phone*[tiab]) OR (smart[tiab] AND watch*[tiab]) OR smartwatch*[tiab] OR telehealth[tiab] OR telemedicine[tiab] OR verily[tiab] OR wearable*[tiab] OR (“wristband device”[All Fields] OR “wristband devices”[All Fields]))
5 | (#1 AND #4)
6 | (#3 OR #5)
7 | (#6 AND Humans[Mesh:NOEXP]) OR (#6 NOT Animals[Mesh:NOEXP])
8 | (#6 AND Humans[Mesh:NOEXP]) OR (#6 NOT Animals[Mesh:NOEXP]) | English
9 | (#6 AND Humans[Mesh:NOEXP]) OR (#6 NOT Animals[Mesh:NOEXP]) | Systematic Review, English
10 | (#6 AND Humans[Mesh:NOEXP]) OR (#6 NOT Animals[Mesh:NOEXP]) | Meta-Analysis, Systematic Review, English
11 | #7 AND (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields])
12 | #7 AND (“2019/09/19”[Date - Publication] : “3000”[Date - Publication])
13 | #10 AND (“2019/09/19”[Date - Publication] : “3000”[Date - Publication])

#### Medline via PubMed Supplemental Search for Diagnostic Accuracy (November 1, 2019–October 5, 2020)

Search Number | Query | Filters
1 | (“Atrial Fibrillation”[Mesh] OR “Atrial Flutter”[Mesh] OR atrial fibril*[tiab] OR atrium fibril*[tiab] OR a-fib[tiab] OR afib[tiab] OR “atrial flutter”[tiab] OR “auricular flutter”[tiab])
2 | (“Electrocardiography”[Mesh] OR “continuous ambulatory ECG”[tiab] OR “continuous ambulatory EKG” OR electrocardiogram*[tiab] OR electrocardiograph*[tiab] OR electrocardiography[tiab] OR EKG[tiab] OR ECG[tiab] OR “1-lead”[tiab] OR “single lead”[tiab] OR “3-lead”[tiab] OR “three lead”[tiab] OR “12-lead”[tiab] OR “twelve lead”[tiab] OR “event loop recorder”[tiab] OR Holter[tiab] OR “mobile cardiac telemetry”[tiab] OR patch monitor*)
3 | ((apple[tiab] AND watch*[tiab]) OR “digital treatment”[tiab] OR “Cardiio Rhythm”[tiab] OR FibriCheck[tiab] OR Fitbit*[tiab] OR (fitness[tiab] AND tracker*[tiab]) OR “Galaxy Gear” OR “iRhythm Zio” OR KardiaMobile[tiab] OR mHealth[tiab] OR “mobile health”[tiab] OR (mobile[tiab] AND (app[tiab] OR application*[tiab] OR apps[tiab])) OR Photoplethysmography[tiab] OR PPG[tiab] OR “portable device”[tiab] OR “portable devices”[tiab] OR smartphone*[tiab] OR (smart[tiab] AND phone*[tiab]) OR (smart[tiab] AND watch*[tiab]) OR smartwatch*[tiab] OR verily[tiab] OR wearable*[tiab] OR “wristband device” OR “wristband devices”)
5 | #2 OR #3
6 | #1 AND #5
7 | (“Sensitivity and Specificity”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “ROC Curve”[Mesh] OR “Reproducibility of Results”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR ((pre-test[tw] or pretest[tw]) AND probability[tw]) OR “predictive value”[tw] OR sensitivity[tw] OR specificity[tw] OR accuracy[tw] OR ROC[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw])
8 | #6 AND #7
9 | ((diagnos*[tiab] or screening[tiab]) AND (accurate*[tiab] or accuracy[tiab]))
10 | #6 AND #9
11 | (diagnos*[tiab] OR underdiagnose*[tiab] OR detect*[tiab] OR identif*[tiab] OR screen*[tiab])
12 | #6 AND #11
13 | (diagnos*[tiab] OR detect*[tiab]) AND (rate[tiab] OR yield[tiab] OR PAF[tiab])
14 | #6 AND #13
15 | (“diagnosis” [Subheading] OR “Diagnosis, Computer-Assisted”[Mesh] OR “Early Diagnosis”[Mesh])
16 | #6 AND #15
17 | #8 OR #10 OR #12 OR #14 OR #16
18 | (#17 AND Humans[Mesh:NOEXP]) OR (#17 NOT Animals[Mesh:NOEXP])
19 | (#17 AND Humans[Mesh:NOEXP]) OR (#17 NOT Animals[Mesh:NOEXP]) | English
20 | (#17 AND Humans[Mesh:NOEXP]) OR (#17 NOT Animals[Mesh:NOEXP]) | English, Adult: 19+ years
21 | (address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control”[tw] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[tw] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR “retrospective cohort”[tw] OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] or horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murinae)
22 | #20 NOT #21
23 | “Evaluation Study” [Publication Type] OR “Validation Study” [Publication Type]
24 | #22 AND #23
25 | (“Comparative Study”[pt] OR “Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort AND (study OR studies)))
26 | #22 AND #25
27 | #24 OR #26
28 | (“2019/11/20”[Date - Publication] : “3000”[Date - Publication])
29 | #27 AND #28
30 | #20 NOT #21 | Systematic Review
31 | #20 NOT #21 | Meta-Analysis, Systematic Review
32 | #31 AND #28
33 | #22 AND (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields]) AND (“2014/02/01”[Date - Publication] : “3000”[Date - Publication])

#### Cochrane Library Main Search, Limited by Entry into Cochrane Library Between November 21, 2019–October 5, 2020

ID | Search
#1 | [mh “Atrial Fibrillation”] OR [mh “Atrial Flutter”] OR atrial fibril*:ti,ab OR atrium fibril*:ti,ab OR a-fib:ti,ab OR afib:ti,ab OR “atrial flutter”:ti,ab OR “auricular flutter”:ti,ab
#2 | [mh “Electrocardiography”] OR electrocardiograph*:ti,ab OR electrocardiogram*:ti,ab OR EKG:ti,ab OR ECG:ti,ab OR holter:ti,ab OR “mobile cardiac outpatient telemetry”:ti,ab OR patch monitor*:ti,ab OR “single lead”:ti,ab OR “12-lead”:ti,ab
#3 | #1 AND #2
#4 | [mh “Mass Screening”] OR screen*:ti,ab
#5 | #3 AND #4
#6 | #5 NOT “conference abstract”:pt
#7 | [mh “Anticoagulants”] OR [mh “Dabigatran”] OR [mh “Rivaroxaban”] OR [mh “Warfarin”] OR anticoagulant*:ti,ab OR apixaban OR Coumadin OR Dabigatran OR Edoxaban OR Eliquis OR NOAC* OR Pradaxa OR Rivaroxaban OR Savaysa OR “vitamin k agonist”:ti,ab,kw OR “vitamin k agonists”:ti,ab,kw OR VKA OR warfarin OR Xarelto
#8 | #1 AND #7
#9 | [mh “Factor Xa Inhibitors”] OR “factor xa”:ti,ab
#10 | #1 AND #9
#11 | [mh “Antithrombins”] OR antithrombin*:ti,ab OR thrombin inhibit*:ti,ab
#12 | #1 AND #11
#13 | [mh “Aspirin”] OR [mh “Aspirin, Dipyridamole Drug Combination”] OR [mh “Dipyridamole”] OR “acetylsalicylic acid” OR Aggrenox OR anti-platelet* OR antiplatelet* OR ASA:ti,ab OR aspirin OR clopidogrel OR Dipyridamole OR Plavix
#14 | #1 AND #13
#15 | #8 OR #10 OR #12 OR #14
#16 | #15
#17 | #15 NOT “conference abstract”:pt
#18 | #15 AND “conference abstract”:pt

#### Cochrane Library Emerging Technologies Search, Limited by Entry into Cochrane Library Between November 21, 2019–October 5, 2020

ID | Search
#1 | [mh “Atrial Fibrillation”] OR [mh “Atrial Flutter”] OR atrial fibril*:ti,ab OR atrium fibril*:ti,ab OR a-fib:ti,ab OR afib:ti,ab OR “atrial flutter”:ti,ab OR “auricular flutter”:ti,ab
#2 | [mh “Fitness Trackers”] OR [mh “Mobile Applications”] OR [mh “Photoplethysmography”] OR [mh “Smartphone”] OR [mh “Telemedicine”] OR [mh ^”Wearable Electronic Devices”]
#3 | #1 AND #2
#4 | “1-lead”:ti,ab OR “single lead”:ti,ab OR “3-lead”:ti,ab OR “three lead”:ti,ab OR AliveCor:ti,ab OR app:ti,ab OR (apple:ti,ab AND watch*:ti,ab) OR “digital treatment”:ti,ab OR “Cardiio Rhythm”:ti,ab OR FibriCheck:ti,ab OR Fitbit*:ti,ab OR (fitness:ti,ab AND tracker*:ti,ab) OR “Galaxy Gear”:ti,ab,kw OR “iRhythm Zio”:ti,ab,kw OR KardiaMobile:ti,ab OR mHealth:ti,ab OR “mobile health”:ti,ab OR (mobile:ti,ab AND (app:ti,ab OR application*:ti,ab OR apps:ti,ab)) OR Photoplethysmography:ti,ab OR PPG:ti,ab OR “portable device”:ti,ab OR “portable devices”:ti,ab OR smartphone*:ti,ab OR (smart:ti,ab AND phone*:ti,ab) OR (smart:ti,ab AND watch*:ti,ab) OR smartwatch*:ti,ab OR telehealth:ti,ab OR telemedicine:ti,ab OR Verily:ti,ab OR wearable*:ti,ab OR “wristband device”:ti,ab,kw OR “wristband devices”:ti,ab,kw
#5 | #1 AND #4
#6 | #3 OR #5
#7 | #6 AND “conference abstract”:pt
#8 | #6 NOT “conference abstract”:pt

#### Cochrane Library Diagnostic Accuracy Search, Limited by Entry into Cochrane Library Between November 21, 2019–October 5, 2020—No New Results

ID | Search
#1 | [mh “Atrial Fibrillation”] OR [mh “Atrial Flutter”] OR atrial fibril*:ti,ab OR atrium fibril*:ti,ab OR a-fib:ti,ab OR afib:ti,ab OR “atrial flutter”:ti,ab OR “auricular flutter”:ti,ab
#2 | [mh “Electrocardiography”] OR electrocardiogram*:ti,ab OR electrocardiograph*:ti,ab OR EKG:ti,ab OR ECG:ti,ab OR “1-lead”:ti,ab OR “single lead”:ti,ab OR “3-lead”:ti,ab OR “three lead”:ti,ab OR “12-lead”:ti,ab OR “twelve lead”:ti,ab OR “event loop recorder”:ti,ab OR Holter:ti,ab OR “mobile cardiac telemetry”:ti,ab OR patch monitor*:ti,ab
#3 | (apple:ti,ab AND watch*:ti,ab) OR “digital treatment”:ti,ab OR “Cardiio Rhythm”:ti,ab OR FibriCheck:ti,ab OR Fitbit*:ti,ab OR (fitness:ti,ab AND tracker*:ti,ab) OR “Galaxy Gear”:ti,ab,kw OR “iRhythm Zio”:ti,ab,kw OR KardiaMobile:ti,ab OR mHealth:ti,ab OR “mobile health”:ti,ab OR (mobile:ti,ab AND (app:ti,ab OR application*:ti,ab OR apps:ti,ab)) OR Photoplethysmography:ti,ab OR PPG:ti,ab OR “portable device”:ti,ab OR “portable devices”:ti,ab OR smartphone*:ti,ab OR (smart:ti,ab AND phone*:ti,ab) OR (smart:ti,ab AND watch*:ti,ab) OR smartwatch*:ti,ab OR Verily:ti,ab OR wearable*:ti,ab OR “wristband device”:ti,ab,kw OR “wristband devices”:ti,ab,kw
#4 | #1 AND (#2 OR #3)
#5 | [mh “Sensitivity and Specificity”] OR [mh “Predictive Value of Tests”] OR [mh “ROC Curve”] OR [mh “Reproducibility of Results”] OR [mh “False Negative Reactions”] OR [mh “False Positive Reactions”] OR ((“pre-test”:ti,ab,kw OR “pretest”:ti,ab,kw) AND “probability”:ti,ab,kw) OR “predictive value”:ti,ab,kw OR “sensitivity”:ti,ab,kw OR “specificity”:ti,ab,kw OR “accuracy”:ti,ab,kw OR “ROC”:ti,ab,kw OR “false positive”:ti,ab,kw OR “false negative”:ti,ab,kw OR “likelihood ratio”:ti,ab,kw
#6 | #4 AND #5
#7 | (diagnos*:ti,ab or screening:ti,ab) AND (accurate*:ti,ab or accuracy:ti,ab)
#8 | #4 AND #7
#9 | diagnos*:ti,ab or underdiagnose*:ti,ab or detect*:ti,ab or identif*:ti,ab or screen*:ti,ab
#10 | #4 AND #9
#11 | (diagnos*:ti,ab OR detect*:ti,ab) AND (rate:ti,ab OR yield:ti,ab OR PAF:ti,ab)
#12 | #4 AND #11
#13 | [mh /DI] OR [mh “Diagnosis, Computer-Assisted”] OR [mh “Early Diagnosis”]
#14 | #4 AND #13
#15 | #6 OR #8 OR #10 OR #12 OR #14
#16 | #15 AND “conference abstract”:pt
#17 | #15 NOT “conference abstract”:pt

### Gray Literature Search Update

#### ClinicalTrials.gov, October 6, 2020 (all limited to last update between February 25, 2020–October 6, 2020)

WHO ICTRP searches were not updated due to current unavailability of the database.

[underlined: Screening]

CONDITION box: “Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter”

AND

Other Terms:

Electrocardiograph* OR electrocardiogram* OR EKG OR ECG OR holter OR “mobile cardiac outpatient telemetry” OR patch monitor* OR “single lead” OR 12-lead AND screen*

Limit to Adult/Older Adult and latest update posted: 02/25/2020 – 10/06/2020

[underlined: Treatment]

Condition box:

“Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter”

Treatment box:

Anticoagulants OR Dabigatran OR Rivaroxaban OR Warfarin OR anticoagulant* OR apixaban OR Coumadin OR Dabigatran OR Edoxaban OR Eliquis OR NOAC* OR Pradaxa OR Rivaroxaban OR Savaysa OR “vitamin k agonist” OR “vitamin k agonists” OR VKA OR warfarin OR Xarelto OR “Factor Xa Inhibitors” OR “factor xa” OR Antithrombins OR antithrombin* OR thrombin inhibit* OR Aspirin OR clopidogrel OR Dipyridamole OR “acetylsalicylic acid” OR Aggrenox OR anti-platelet* OR antiplatelet* OR ASA OR aspirin OR Plavix

Limit to Adult/Older Adult and latest update posted: 02/25/2020 – 10/06/2020

Expert search statement:

AREA[ConditionSearch] (EXPAND[Concept] “Atrial Fibrillation” OR EXPAND[Concept] “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR EXPAND[Concept] “atrial flutter” OR EXPAND[Concept] “auricular flutter”) AND AREA[InterventionSearch] (Anticoagulants OR Dabigatran OR Rivaroxaban OR Warfarin OR anticoagulant* OR apixaban OR Coumadin OR Dabigatran OR Edoxaban OR Eliquis OR NOAC* OR Pradaxa OR Rivaroxaban OR Savaysa OR “vitamin k agonist” OR “vitamin k agonists” OR VKA OR warfarin OR Xarelto OR “Factor Xa Inhibitors” OR “factor xa” OR Antithrombins OR antithrombin* OR thrombin inhibit* OR Aspirin OR clopidogrel OR Dipyridamole OR “acetylsalicylic acid” OR Aggrenox OR anti-platelet* OR antiplatelet* OR ASA OR aspirin OR Plavix) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] (“Adult” OR “Older Adult”) AND AREA[LastUpdatePostDate] EXPAND[Term] RANGE[02/25/2020, 10/06/2020]

[underlined: Emerging Technologies]

Condition box:

(“Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter”)

Other Terms:

(“Fitness Trackers” OR “Mobile Applications” OR Photoplethysmography OR Smartphone OR Telemedicine OR “Wearable Electronic Devices” OR “1-lead” OR “single lead” OR “3-lead” OR “three lead” OR AliveCor OR app OR (apple AND watch*) OR “digital treatment” OR “Cardiio Rhythm” OR FibriCheck OR Fitbit* OR (fitness AND tracker*) OR “Galaxy Gear” OR “iRhythm Zio” OR KardiaMobile OR mHealth OR “mobile health” OR (mobile AND (app OR application* OR apps)) OR Photoplethysmography OR PPG OR “portable device” OR “portable devices” OR smartphone* OR (smart AND phone*) OR (smart AND watch*) OR smartwatch* OR telehealth OR telemedicine OR verily OR wearable* OR “wristband device” OR “wristband devices”)

Limit to Adult/Older Adult, Last update posted from 02/25/2020 to 10/06/2020

Expert search statement:

EXPAND[Concept] (“Fitness Trackers” OR “Mobile Applications” OR Photoplethysmography OR Smartphone OR Telemedicine OR “Wearable Electronic Devices” OR “1-lead” OR “single lead” OR “3-lead” OR “three lead” OR AliveCor OR app OR (apple AND watch*) OR “digital treatment” OR “Cardiio Rhythm” OR FibriCheck OR Fitbit* OR (fitness AND tracker*) OR “Galaxy Gear” OR “iRhythm Zio” OR KardiaMobile OR mHealth OR “mobile health” OR (mobile AND (app OR application* OR apps)) OR Photoplethysmography OR PPG OR “portable device” OR “portable devices” OR smartphone* OR (smart AND phone*) OR (smart AND watch*) OR smartwatch* OR telehealth OR telemedicine OR verily OR wearable* OR “wristband device” OR “wristband devices”) AND AREA[ConditionSearch] (“Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter”) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] (“Adult” OR “Older Adult”) AND AREA[LastUpdatePostDate] EXPAND[Term] RANGE[02/25/2020, 10/06/2020]

[underlined: Diagnostic Accuracy Gap Search] (shortened Other terms statement to remove duplicate terms and simplify logic)

Condition box:

“Atrial Fibrillation” OR “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR “atrial flutter” OR “auricular flutter”

Other terms box:

(“continuous ambulatory ECG” OR “continuous ambulatory EKG” OR electrocardiogram* OR electrocardiograph* OR electrocardiography OR EKG OR ECG OR “1-lead” OR “single lead” OR “3-lead” OR “three lead” OR “12-lead” OR “twelve lead” OR “event loop recorder” OR Holter OR “mobile cardiac telemetry” OR patch monitor* OR apple watch* OR “digital treatment” OR “Cardiio Rhythm” OR FibriCheck OR Fitbit* OR fitness tracker* OR “Galaxy Gear” OR “iRhythm Zio” OR KardiaMobile OR mHealth OR “mobile health” OR mobile app* OR Photoplethysmography OR PPG OR “portable device” OR “portable devices” OR smartphone* OR smart phone* OR smart watch* OR smartwatch* OR verily OR wearable* OR “wristband device” OR “wristband devices”) AND (“Sensitivity and Specificity” OR “Predictive Value of Tests” OR “ROC Curve” OR “Reproducibility of Results” OR pre-test probability OR pretest probability OR “predictive value” OR sensitivity OR specificity OR accuracy OR ROC OR “false positive” OR “false negative” OR “likelihood ratio” OR diagnos* or underdiagnose* or detect* or identif* or screen*)

Limit to Adult and Older Adult, Last update posted from 02/25/2020 to 10/06/2020

Expert search box:

(“continuous ambulatory ECG” OR “continuous ambulatory EKG” OR electrocardiogram* OR electrocardiograph* OR electrocardiography OR EKG OR ECG OR “1-lead” OR “single lead” OR “3-lead” OR “three lead” OR “12-lead” OR “twelve lead” OR “event loop recorder” OR Holter OR “mobile cardiac telemetry” OR patch monitor* OR apple watch* OR “digital treatment” OR “Cardiio Rhythm” OR FibriCheck OR Fitbit* OR fitness tracker* OR “Galaxy Gear” OR “iRhythm Zio” OR KardiaMobile OR mHealth OR “mobile health” OR mobile app* OR Photoplethysmography OR PPG OR “portable device” OR “portable devices” OR smartphone* OR smart phone* OR smart watch* OR smartwatch* OR verily OR wearable* OR “wristband device” OR “wristband devices”) AND (“Sensitivity and Specificity” OR “Predictive Value of Tests” OR “ROC Curve” OR “Reproducibility of Results” OR pre-test probability OR pretest probability OR “predictive value” OR sensitivity OR specificity OR accuracy OR ROC OR “false positive” OR “false negative” OR “likelihood ratio” OR diagnos* or underdiagnose* or detect* or identif* or screen*) AND AREA[ConditionSearch] (EXPAND[Concept] “Atrial Fibrillation” OR EXPAND[Concept] “Atrial Flutter” OR atrial fibril* OR atrium fibril* OR a-fib OR afib OR EXPAND[Concept] “atrial flutter” OR EXPAND[Concept] “auricular flutter”) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] (“Adult” OR “Older Adult”) AND AREA[LastUpdatePostDate] EXPAND[Term] RANGE[02/25/2020, 10/06/2020]

## Appendix C2 Detailed Eligibility Criteria

| Include | Exclude
Condition definition | AF (paroxysmal or persistent) | Other cardiac arrhythmias, non-arrhythmia–related cardiovascular disease (e.g., coronary heart disease, hypertension). Studies reporting atrial flutter will not be excluded as long as the focus is on AF.
Populations | KQs 1, 2, 4: Unselected or explicitly asymptomatic older adults (age ≥50 years) without known AF; older adults selected for increased risk of AF (e.g., those with obesity, smoking, alcohol use, hypertension); studies of mixed populations of asymptomatic and symptomatic persons are eligible if results are reported separately for asymptomatic persons or less than 10% of the sample is symptomatic.; KQ 3: Unselected or explicitly asymptomatic older adults without known AF; mixed populations of asymptomatic and symptomatic persons with and without AF or that include younger adults are eligible if results are reported separately for asymptomatic persons, those without known AF, or the older population, or less than 50% of the population is symptomatic, has known AF, or is younger than age 50 years.; KQs 5, 6: Older adults with AF. To approximate screen-detected persons with AF, we will aim to stratify analyses based on whether participants are asymptomatic/screen-detected vs. symptomatic (if possible); however, knowing that most studies enroll mixed populations or do not clearly enroll screen-detected or asymptomatic populations, we will not exclude studies based on whether participants were screen detected. To approximate “screening” vs. “disease management” populations, we will limit our analyses to studies of individuals not selected because of known heart disease, heart failure, and/or previous stroke or transient ischemic attack. | KQs 1–4: Symptomatic adults; adults with known AF; children, adolescents, and adults younger than age 50 years; adults at high(est) risk for AF (including but not limited to those with mitral valve disease or repair/replacement); and adults with history of stroke or transient ischemic attack; KQs 5, 6: Adults needing antiplatelet or anticoagulation medications for conditions other than AF; adults with AF and known heart disease, heart failure, and/or previous stroke or transient ischemic attack. Studies that exclusively enroll these populations will be excluded.
Screening test or intervention | KQs 1, 2, 4: Systematic screening using ECG or other technologic approach. Eligible approaches include:; One-time 12-lead or less than 12-lead ECG Intermittent or continuous ambulatory ECG such as Holter monitoring, event loop recorders, or patch monitors; One-time intermittent or continuous ambulatory photoplethysmography that includes an AF detection algorithm; One-time, intermittent, or continuous oscillometric blood pressure measurement devices that include an AF detection algorithm; Commercially available technologies directed to consumers (e.g., smartwatches, smartphone apps, heart rate or rhythm monitors); KQ 3: Eligible index tests include:; One-time 12-lead or less than 12-lead ECG interpreted by primary care provider, with or without ECG machine algorithm interpretation Intermittent ambulatory ECG such as event loop recorders or patch monitors; One-time or intermittent ambulatory photoplethysmography that includes an AF detection algorithm; One-time or ambulatory oscillometric blood pressure measurement devices with an AF detection algorithm Two-stage screening tests involving a single initial test followed by a second test; KQs 5, 6: Medical treatment with anticoagulants (e.g., apixaban, dabigatran, edoxaban, rivaroxaban, warfarin). Results will be stratified by type of medication. | KQs 1, 2, 4: Physical examination (including one-time in-office pulse palpation or heart auscultation); one-time in-office manual or automated pulse, blood pressure measurement, or pulse oximetry; two-stage approach in which a physical examination component or vital sign measurement is the initial test and only persons with irregular pulse or vital sign receive ECG; KQ 3: Same as excluded tests for KQs 1, 2, and 4 plus ECG (any number of leads) interpreted by a cardiologist^*^; continuous ambulatory ECG monitoring^*^; and cardiac monitoring with an implantable device^*^; KQs 5, 6: Nonpharmacologic treatment to prevent stroke (e.g., implantable devices), treatment or management of AF for reasons other than prevention of stroke (e.g., rate or rhythm control, cardioversion, ablation), antiplatelet therapy, and combinations of antiplatelet and anticoagulation treatment (e.g., aspirin plus warfarin)
Comparisons | KQs 1, 2, 4: No screening, nonsystematic screening, or usual care (which may include pulse palpation, single manual or automated blood pressure measurement, or cardiac auscultation during a physical examination); KQ 3: For persistent AF, single 12-lead ECG interpreted by one or more cardiologists; for paroxysmal AF, continuous ambulatory ECG monitoring interpreted by one or more cardiologists and implantable cardiac monitor interpreted by one or more cardiologists. Interpretation of ECG can be with or without a device-embedded AF detection algorithm.; KQs 5, 6: Placebo, no treatment | KQs 1, 2, 4: No comparison, nonconcordant historical control; KQ 3: No reference standard, reference standard other than 12-lead ECG, continuous ambulatory ECG monitoring, or implantable cardiac monitor all interpreted by one or more cardiologists with or without a device-embedded AF detection algorithm; KQs 5, 6: Active treatment (i.e., other anticoagulation medications or nonpharmacologic treatment)
Outcomes | KQ 1: All-cause mortality, stroke, stroke-related morbidity or mortality, and quality of life; KQ 2: Comparative diagnostic yield (i.e., number of persons diagnosed with AF in one group vs. another [unscreened/nonsystematically screened] group); KQ 3: Sensitivity, specificity, positive and negative predictive values, positive and negative likelihood ratios, true positives, true negatives, false positives, false negatives; KQ 4: Anxiety, labeling, harms of subsequent procedures or interventions initiated as a result of screening (e.g., subsequent ablation with complications), frequency of findings other than AF; KQ 5: All-cause mortality, cardioembolic stroke, cardioembolic stroke–related morbidity or mortality, and quality of life; KQ 6: Any harms requiring unexpected or unwanted medical attention (e.g., hemorrhagic stroke, major bleeding, allergic reaction) | KQs 4, 6: Nonserious events (e.g., bleeding not requiring or resulting in medical attention)
Study designs | KQ 1, 2, 4–6: RCTs and controlled clinical trials; KQ 3: Diagnostic test accuracy studies or systematic reviews of diagnostic test accuracy studies; KQ 4: Large prospective cohort studies are also eligible; KQ 5: Systematic reviews of relevant trials are also eligible; KQ 6: Systematic reviews of relevant trials and large prospective cohort studies are also eligible | All other designs, narrative reviews, case reports, case series, editorials, letters, cross-sectional studies, case-control studies, small prospective cohort studies, and retrospective cohort studies
Setting | KQs 1–4: Studies performed in primary care or primary care–referable settings, community settings; KQs 5, 6: Studies performed in primary care or specialty settings | KQs 1–4: Studies performed in specialty settings (including the emergency department), studies of patients undergoing preoperative evaluation, and inpatient settings; KQs 5, 6: Studies conducted primarily in inpatient settings
Country | Studies conducted in countries categorized as “Very High” on the 2018 Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries that are not categorized as “Very High” on the 2018 Human Development Index
Language | English | Non-English
Study quality | Good or fair | Poor (according to design-specific USPSTF criteria)

* 12-lead ECG and continuous ambulatory ECG interpreted by a cardiologist and implantable cardiac monitoring are excluded from KQ 3 (diagnostic accuracy) because these tests are considered the reference standard. Single-lead ECG interpreted by a cardiologist is not eligible because this review focuses on accuracy of conducting/interpreting tests in a primary care setting.

Abbreviations: AF=atrial fibrillation; ECG=electrocardiography; KQ=key question; RCT=randomized, controlled trial; USPSTF=U.S. Preventive Services Task Force.

## Appendix C3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of Ratings Based on Above Criteria

Good:: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.
Poor:: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Sources: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015^83^; Harris et al, 2001.^209^

### Systematic Reviews

#### Criteria

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

#### Definition of Ratings Based on Above Criteria

Good:: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions
Fair:: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies
Poor:: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

Sources: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015^83^; Harris et al, 2001.^209^