# Appendix B Contextual Questions

## CQ 1 What is the prevalence of previously unrecognized or undiagnosed AF in unselected or explicitly asymptomatic adults? Does the prevalence vary by age, primary care vs. community setting, method of diagnosis (e.g., single electrocardiogram vs. ambulatory electrocardiography monitoring), sex, or race/ethnicity?

The data provided in this contextual question (CQ) can be viewed as an estimate of the total burden of undiagnosed AF, whereas differences in detection of undiagnosed AF in the context of screening compared with no screening (or usual care) are addressed in KQ 2 of this report.

We identified 52 studies relevant to this CQ that were suitable for using to determine a pooled prevalence; 19 were included in the previous report^146^ and the rest are new to this update. These studies are summarized in Appendix B Table 1. We stratified this analysis by population-type (clinic based or community based) and screening approach using metaprop_one in Stata version 16 (StataCorp, LLC).^147^ Note, we did not conduct formal risk of bias assessment on studies included for this CQ.

In addition to the studies we included in the pooled estimates, we report the findings from the Apple Heart Study,^131^ a large uncontrolled pragmatic trial, findings from a long-term study using an implanted cardiac monitor,^56^ and findings from an individual patient data (IPD) meta-analysis published in 2019 reporting on the prevalence of screen-detected AF.^148^

### Characteristics of Studies Used in Pooled Estimates of Unknown AF Prevalence

Participants were recruited from population- or community-based samples in 25 studies used in our pooled estimates. The remaining 27 studies were performed among clinic-based samples. There were 29 uncontrolled trials, three parallel-assignment RCTs, nine cross-sectional studies, seven cohort studies, two diagnostic accuracy study, and two cluster RCTs. Sample sizes ranged from 75 participants^149^ to 644,124 participants.^150^ Most studies focused on older adults (age 65 years or older), although some studies included younger adults. Most studies excluded participants with known or diagnosed AF; for those studies that included such participants, we only used data from the proportion of participants without known AF. Some studies reported comorbidities of enrolled participants; in a few studies, participants with prior stroke or TIA were enrolled. Studies did not routinely assess whether enrolled participants had symptoms potentially attributed to AF. Thus, the prevalence estimates from these studies reflect prevalence among a population without known AF but some of whom may have risk factors that portend higher risk of AF or whom may have had unrecognized symptoms of AF.

A variety of methods were used for AF diagnosis. Most studies used devices based on standard electrocardiography (ECG) technology; two studies reported prevalence based on more than one approach. Eighteen studies used one-time, single-lead ECG (typically via handheld devices for 10 to 30 seconds) to identify new cases of AF; in more than half of studies, diagnosis was then confirmed with a 12-lead ECG. Twelve studies used a one-time, 12-lead ECG for AF diagnosis. Two studies used one-time ECG, although the number of leads was not reported, and one study used a three-lead ECG followed by confirmatory 12-lead ECG. Oscillometric blood pressure monitors and devices based on photoplethysmography with automated AF detection algorithms were used alone or in combination with single- or 12-lead ECG to detect new cases of undiagnosed AF in six studies. Various approaches combining a one-time single- or 12-lead ECG followed by 2 to 4 weeks of intermittent ambulatory ECG monitoring were used in seven studies. Continuous monitoring over 24 hours to 2 weeks was used in eight studies. Lastly, one study instructed participants on pulse palpation and asked them to conduct self-pulse palpation three times daily followed by a 30-second single-lead ECG.

### Pooled Prevalence of Unknown AF

Appendix B Figure 1 shows the pooled prevalence of previously undiagnosed AF in clinic and community-based samples based on the use of a test at one point in time. The pooled prevalence among clinic-based samples was 1.2 percent (95% CI, 0.9% to 1.5%; 20 studies; 58,213 participants) and was very similar among community-based samples (Appendix B Figure 2; pooled prevalence of 1.3% [95% CI, 1.0% to 1.6%]; 17 studies; 102,508 participants). Some heterogeneity in estimates exists but cannot be entirely explained by differences in study population or method of AF detection.

The prevalence of previously undiagnosed AF in clinic- and community-based samples based on intermittent or continuous monitoring varied more than the use of one-time tests (Appendix B Figure 3). The pooled prevalence among clinic-based samples was 3.2 percent (95% CI, 1.5% to 4.9%; 7 studies; 3,885 participants) and was 3.5 percent (95% CI, 2.0% to 5.1%; 8 studies; 662,443 participants) among community-based samples. The combined pooled prevalence for continuous or intermittent monitoring among clinic and community-based samples was 3.3 percent (95% CI, 2.3 to 4.3; 15 studies; 666,328 participants). Similar to one-time testing approaches, some heterogeneity exists, but cannot be entirely explained by differences in study population or method of AF detection.

When comparing one-time tests with intermittent or continuous monitoring, we observe that monitoring patients for longer periods of time yields higher detection rates of AF. This is likely due to increased detection of paroxysmal AF missed by one-time approaches to testing.

### Additional Information Regarding Prevalence of Unknown AF

We offer additional information related to studies and data not included in the pooled estimates of prevalence above.

The Apple Heart Study, published in 2019, was an uncontrolled, siteless, industry-funded pragmatic trial that used photoplethysmography, an optical sensor-based technology, embedded in the Apple Watch, synched to an Apple iPhone, with an algorithm to detect possible AF.^131^ The study recruited 419,093 participants age 22 years or older from among persons who downloaded the Apple Watch application from the Apple App Store, and 67,259 (16%) were age 55 years or older. Participants with previously known AF or who were current users of oral anticoagulants (OACs) were excluded. The study authors were clear that “notification based on an irregular pulse from a photoplethysmography signal should not be used for a definitive diagnosis of atrial fibrillation.”^131, p. 1916^ Notifications of abnormal rhythm were based on at least five out of six consecutive abnormal tachograms within a 48-hour period. This equates to more than 1 hour of abnormal rhythm before a notification is triggered. If a participant received a notification of possible AF, they were sent an ECG patch for 7 days of confirmatory monitoring and scheduled for a telemedicine visit. Among participants age 55 years or older, 1,331 (2.0%) received an irregular pulse notification. However, only 295 (22.2%) of those receiving a notification returned the confirmatory ECG patch monitor. Of those who returned the patch monitor, 110 (37.3%) were confirmed to have AF. Extrapolating the confirmation rate of 37 percent back to all participants age 55 years or older who received an irregular pulse notification suggests 492 cases of previously unknown AF for a prevalence of 0.7 percent. This prevalence is lower than what we calculated in our pooled estimates and may reflect a population with fewer AF risks than a general community or clinic-based population and also a longer threshold for abnormal rhythm for the initial notification.

Philippsen et al enrolled 82 participants age 65 years or older without known or suspected AF recruited from hospital outpatient diabetes and cardiology clinics into a long-term study with an implantable cardiac monitor.^56^ Patients with CIED, history of stroke, or history of TIAs were excluded. The mean age was 71, and 37 percent were female. Nearly three-quarters took medication for diabetes, the mean number of hypertensive agents was four, and the mean left ventricular ejection fraction was 60 percent. In this study, the mean duration of ICM use was 588 days, and 20.7 percent of participants had AF detected based on one or more episodes of AF rhythm for at least 2 minutes or longer. The much higher prevalence of AF in this study may reflect the much longer duration of monitoring and the identification of incident along with prevalent cases. In addition, the population enrolled may be considered higher risk than a general community or primary care clinic-based population. However, about a month after placement of the ICM, all participants also underwent a 2-channel, 72-hour Holter monitor, and the prevalence of AF detected by Holter monitoring was 2.4 percent (based on AF episodes at least 30 seconds or longer), consistent with pooled estimates we calculated in the previous section for continuous or intermittent monitoring. Thus, it is likely that the much higher prevalence observed from long-term continuous monitoring is because of the longer duration of monitoring and detection of incident cases, rather than population characteristics.

Lastly, Lowres et al conducted an IPD meta-analysis of 19 studies with at least 1,000 participants to report the prevalence of screen-detected AF.^148^ Two of the included studies used pulse palpation confirmed by a 12-lead ECG, and three of the included studies were conducted in countries that were not very highly developed per the United Nations Human Development Index. Nearly all included studies used one-time screening approaches. In this analysis, the age- and sex-adjusted AF detection rate in persons age 65 years or older was 1.4 percent (95% CI, 1.2% to 1.8%), consistent with the pooled estimates we calculated in the previous section for one-time screening tests.

#### Variation by Subgroup

With respect to variation in prevalence by subgroup, our data suggest that prevalence of AF increases as the age of participants increases. For example, in Appendix B Figure 1, the three studies reporting prevalence greater than 5 percent, for one-time and two-step tests, had mean age of 75 years or older.^151–153^ In the 2019 IPD, the age- and sex-adjusted detection rate in persons younger than 65 years was 0.41 percent (95% CI, 0.31% to 0.53%), lower than the 1.44 percent prevalence reported for persons older than 65 years.^148^

With respect to variation by sex, few studies report data stratified by sex. For example, in the actively monitored cohort of the mSToPS trial, 7 percent of males and 5 percent of females had a new AF diagnosis at 1 year.^109^ Data from Furberg et al^154^ indicated a higher prevalence in males than females, 1.9 percent vs. 1.2 percent, respectively. Of note, this study reported a strong association between advanced age in women and AF prevalence (p <0.0001), whereas this relationship was not significant in men.^154^ In the 2019 IPD meta-analysis, the proportion of screen-detected AF was higher among males than females across all age groups.^148^

## CQ 2 What is the stroke risk for the following populations?

### Asymptomatic Older Adults With Previously Unrecognized or Undiagnosed Atrial Fibrillation

We found no new evidence to directly address the question regarding the risk of stroke in asymptomatic older adults with previously unrecognized or undiagnosed AF. Therefore, we have included below the summary from the prior report unchanged.^146^

Limited evidence was found regarding the incidence of stroke in asymptomatic older adults with unrecognized or undiagnosed AF conducted among the general population. Martinez et al identified 5,555 persons with incidentally detected AF (and reportedly asymptomatic based on review of Read Medical Codes and ICD codes) through hospital and general practice databases.^189^ These were not screen detected as far as the article reports but rather seem to have been incidentally detected in the course of usual care. Just over half were treated with OAC therapy with or without antiplatelet therapy. The cohort included people with a history of coronary artery disease (CAD) without myocardial infarction (MI) (10.6%), MI (4.2%), and stroke or transient ischemic attack (TIA) (9.2%). Mean CHA_2_DS_2_-VASc score was 2.5 (standard deviation [SD], 1.5, and 73% had a score of 2 or greater) and mean CHADS_2_ score was 1.3 (1.1). Limitations of the study include that patients were not screen detected and that using Read Medical Codes and International Classification of Diseases (ICD) codes has limitations regarding the ability to identify asymptomatic people and to accurately identify previously undiagnosed AF. The study reported stroke incidence rates per 1,000 person-years over a maximum of 3 years by age group for those with incidentally detected AF as follows:

- Ages 18 to 49 years: 0 (95% CI, 0 to 6.5)
- Ages 50 to 64 years: 9.1 (95% CI, 5.9 to 13.4)
- Ages 65 to 74 years: 16.5 (95% CI, 13.1 to 20.6)
- Ages 75 to 84 years: 29.6 (95% CI, 25.1 to 34.7)

The study also provided data for a matched comparison group of people without AF (but not comparing asymptomatic vs. symptomatic people). Stroke incidence rates per 1,000 were 19.4 (95% CI, 17.1 to 21.9) for those with incidentally detected AF (all ages) and 8.4 (95% CI, 7.7 to 9.1) for the matched controls without AF.

#### Relative Risk of Stroke in Asymptomatic AF vs. Symptomatic AF

We identified five studies addressing this question; one (ORBIT-AF registry) is new to this update.^190^ In brief, there was no difference in stroke risk between patients with asymptomatic AF and symptomatic AF. However, results were somewhat imprecise, the risk of bias was high in these studies, and they may not be fully applicable to primary care patients. Study details, findings, and limitations of the five studies we identified are summarized in Appendix B Table 2.

These studies were conducted among different patient populations using different approaches to ascertain AF, and some reported a higher absolute incidence of stroke among persons with asymptomatic AF compared with persons with symptomatic AF. Adjusted analyses in three of the five studies showed no statistically significant difference between those with asymptomatic and symptomatic AF. Although some of the studies adjusted for known differences in baseline characteristics, the potential for residual confounding in these studies is high because asymptomatic and symptomatic persons differed on baseline characteristics across most studies for which this information was available. Some studies did not consider important risk factors for stroke in their adjusted analyses (e.g., CHA_2_DS_2_-VASc score or its components, smoking). Further, although some information about rates of anticoagulation treatment among persons with asymptomatic AF was provided, differences in treatment to prevent stroke between groups cannot be ruled out. The risk of selection bias in most of these studies is high, because many identified patients were from cardiology or AF registries and may not be representative of patients seen in primary care. Over 60 percent of participants in two of the studies had heart disease at baseline, and one study did not report baseline descriptive information (published as abstract only). Risk of ascertainment bias for determining symptom status (i.e., whether people were asymptomatic) is also a concern because the studies typically reported limited information about methods for ascertainment, and they relied on retrospective chart reviews or claims to determine whether patients were asymptomatic. Two studies clearly distinguished asymptomatic from symptomatic patients.^42,^ ^190^ Both studies reported no differences in outcomes for symptomatic vs. asymptomatic patients in adjusted analyses.

#### Predicted Stroke Risk Among Persons With Unrecognized AF

We identified 14 studies (13 primary research studies and 1 meta-analysis) providing data on the predicted risk of stroke among persons with previously unrecognized or undiagnosed AF; four are new to this update.^148,^ ^151,^ ^157,^ ^172^ In brief, mean stroke risk prediction scores of persons identified with AF who were asymptomatic and not known to previously have AF typically fall into ranges that would be associated with initiation of anticoagulation (in the absence of contraindications).

Findings from the 13 primary research studies (with a total of 734 people with previously undiagnosed AF) are summarized in Appendix B Table 3. Across these studies, the mean predicted stroke risk among studies using CHA_2_DS_2_-VASc ranged from 2.1 to 4.0. We determined that based on these studies the percentage of persons who would be eligible for anticoagulation (i.e., score ≥2 for males) ranges from 56 percent to 94 percent. Some studies in Appendix B Table 3 only reported mean CHADS_2_ scores, and we note these scores are not directly comparable to CHA_2_DS_2_-VASc scores, the latter of which 1) better identifies very low-risk patients, 2) classifies a lower proportion as moderate risk and more as high risk, and 3) includes additional AF risk factors, all of which were limitations of the original CHADS_2_ scoring system.^191^

In addition to the 13 primary research studies summarized above, Lowres et al conducted an individual patient-level (IPD) meta-analysis of more than 140,000 participants screened for AF in 19 studies across 14 countries (including 3 conducted in countries not very highly developed per the UN Human Development Index).^148^ Studies included had at least 1,000 participants, and participants were recruited from community populations (n=7), general practices (n=6), outpatient clinics (n=3), and pharmacies (n=3). Screening methods included pulse palpation (n=2), single-lead ECG (n=12), 12-lead ECG (n=4), and automated blood pressure machine (n=1). Across studies investigators identified 1,369 new AF cases and reported mean (95% CI) CHA_2_DS_2_-VASc scores in 5-year increments from ages 60 to 85 years (Appendix B Table 4). There was a consistent dose-response relationship between age and CHA_2_DS_2_-VASc score beginning at 1.1 (0.7 to 1.5) for participants younger than age 60 years and peaking at 3.9 (3.6 to 4.4) for those age 85 years or older. Although some of the increase in scores can be attributed to the anticipated age-related increases at 65 and 75 years—1 and 2 points, respectively—there still appears to be an increase in scores independent of the CHA_2_DS_2_-VASc age-based scoring item. Study authors also reported a country effect, with the highest CHA_2_DS_2_-VASc scores observed in Germany, Hong Kong, and the United States (mean score greater than 3.0) compared with the lowest in India (mean score less than 2.0); results were not affected by setting, method, urban/rural, era screened, or screen age eligibility. Although the authors do not comment further on this finding, it is possible the gradient could be due to country-based differences in access to care and availability of diagnostic services that are central to diagnosing conditions that are included in the CHA_2_DS_2_-VASc score (e.g., congestive heart failure, hypertension, diabetes, stroke or prior transient ischemic attack, vascular disease).

### Older Adults With Paroxysmal vs. Persistent AF

We identified three publications related to the stroke risk in older adults with paroxysmal vs. persistent or permanent AF. Findings are summarized in Appendix B Table 5. In general, the risk of stroke in older adults with paroxysmal AF is lower compared with older adults with nonparoxysmal AF, and there appears to be an increasing gradient for stroke risk based on AF type: paroxysmal, persistent, permanent.

Ganesan et al is a systematic review and meta-analysis of 10 RCTs and two prospective cohort studies including almost 100,000 patients with mean ages of 62 to 73 years.^44^ Followup ranged from 1 to 2.8 years. The pooled unadjusted risk ratio (RR) for stroke or systemic embolism in nonparoxysmal AF vs. paroxysmal AF was 1.4 (95% CI, 1.2 to 1.8, 12 studies), and the pooled adjusted HR was 1.4 (95% CI, 1.2 to 1.6; 12 studies). Unadjusted estimates for the annualized risk of thromboembolism in nonparoxysmal and paroxysmal AF were 2.2 percent (95% CI, 1.8 to 2.5) and 1.5 percent (95% CI, 1.2 to 1.8), respectively (7 studies, n=58,421). In univariate meta-regression analyses to explore the unadjusted increased thromboembolic risk, none of the study-level covariates (e.g., mean age, sex, hypertension, prior stroke, diabetes, heart failure) was a significant predictor, supporting AF type as an independent predictor of stroke. The study authors considered the overall individual study quality as strong based on the modified Newcastle-Ottawa scale.

Link et al conducted an RCT of edoxaban vs. warfarin (ENGAGE AF-TIMI 48) in over 21,000 patients with AF and a CHADS_2_ score of 2 or more.^43^ In a prespecified analysis, they reported the risk of the composite outcome of stroke or systemic embolic event in paroxysmal AF (1.5%/yr), persistent AF (1.8%/yr), and permanent AF (2.0%/yr). The adjusted HR (aHR) comparing paroxysmal to either persistent or permanent AF was 0.8 (95% CI, 0.7 to 0.9).

Boriani et al identified 2,119 consecutive inpatients and outpatients with incidentally detected AF (regardless of whether they were asymptomatic) who were enrolled in the EORP-AF Pilot General Registry study from 67 European hospitals and medical centers.^45^ All patients were screen detected using an ECG recording when they presented to a cardiologist and no later than 12 months before enrollment in the registry. Patients in the registry were followed for 3 years and had a mean age of 69 years. Authors reported the risk of stroke over 3 years: paroxysmal AF (1.4%), persistent AF (1.1%), and permanent AF (3.5%). At baseline entry into the registry, approximately 80 percent of patients were on OAC therapy.

### Older Adults With Paroxysmal AF Who Have a Lower vs. Higher AF Burden

In this section, we report concepts related to AF burden, summarize findings from systematic reviews and primary research studies concerning the risk of stroke and AF burden, summarize existing scientific statements and guidelines on this issue, and describe ongoing studies in this area. Overall, higher AF burden appears to be associated with a higher risk of stroke compared with lower AF burden, but no consensus exists regarding how to define AF burden, limiting its applicability for clinical decision making at the present. Additionally, with the exception of one study, Healey et. al,^193^ included in the Uittenbogaard meta-analysis,^48^ all included studies appeared to enroll patients with preexisting indications for CIEDs. As discussed in the previous section, the risk of stroke for patients with paroxysmal AF appears to be lower compared with those with nonparoxysmal AF. However, there may be a spectrum of stroke risk in paroxysmal AF that could warrant treatment for some paroxysmal AF patients but not others, but it remains unclear where to best draw the line between those who may and may not benefit from treatment.

Stroke risk stratification in AF has largely been approached based on patient characteristics (e.g., CHA_2_DS_2_-VASc) rather than AF type (i.e., paroxysmal vs. persistent). More recently the concept of AF burden, rather than AF type, has been introduced to quantify AF exposure, but no uniform definition of AF burden exists. For example, AF burden can refer to the duration of the longest AF episode, the number of AF episodes during a discrete monitoring period, or the proportion of time spent in AF during a monitored period.^7,^ ^125^ Additionally, the concept of AF density, which adds temporal dispersion of AF burden, has recently been introduced.^194^

In addition to AF burden, two additional concepts are important: atrial high-risk episodes (AHRE) and subclinical atrial fibrillation (SCAF). AHREs are episodes of atrial tachyarrhythmias (e.g., atrial tachycardia [AT], AF, atrial flutter) that are asymptomatic and detected via long-term continuous monitoring by a cardiac implantable electronic devices (CIED). SCAF is the subset of AHRE that excludes AT and atrial flutter. When SCAF is detected, a physician review of the device electrogram or a conventional 12-lead surface ECG with 30 seconds or more of AF rhythm may confirm clinical AF, regardless of whether symptoms are present or absent.^7,^ ^8,^ ^195^ AHRE and SCAF, which are detected by CIED, need to be differentiated from paroxysmal AF, which is most often diagnosed clinically through surface ECG but can be diagnosed based on good quality, saved intracardiac electrogram.^196,^ ^197,^ ^198^ Some studies have demonstrated that up to 80 percent of AHRE lasting longer than 5 minutes are AF.^199,^ ^200^ Importantly, implantable devices can lead to false-positive diagnoses of AF, especially within the first 3 months after implantation when transient AF is most likely to occur, which has led some researchers to define SCAF as episodes of AHRE of at least 5 minutes.^201^

Mahajan et al conducted a systematic review and meta-analysis of studies evaluating the association between SCAF and stroke risk in patients with CIEDs with implanted atrial leads.^46^ SCAF was defined as device-detected AHRE. Although the authors did not report on indications for CIED placement in the included studies, the baseline characteristics of patients included approximately 4% on anticoagulation, 60% with heart failure, and 35% with CAD. Mean study follow up ranged from 1 to 2.5 years. They identified seven studies (n=15,353 patients). Most studies were either retrospective or prospective cohort studies; the Atrial Fibrillation Reduction Atrial Pacing Trial (ASSERT) was an RCT, and the Stroke preventiOn Strategies based on Atrial Fibrillation Information from Implanted Devices (SOS AF) is a registry. Each study used a separate cut point to define SCAF based on duration of AHRE episodes ranging from at least 5 minutes to 24 hours; most studies, however, used cut points between 5 minutes and 5.5 hours. The annual stroke rate associated with SCAF was 1.89/100 person-years compared with 0.93/100 person-years for persons without SCAF (pooled OR, 2.4 [95% CI, 1.8 to 3.3]). The review authors rated all included studies as low risk of bias. Point estimates of all seven studies were similar with overlapping confidence intervals and low statistical heterogeneity. However, publication bias was not evaluated, and the range of cut points to define SCAF was large.

One of the studies included in the Mahajan et al meta-analysis, ASSERT, provides further breakdown of stroke risk by AF burden.^47^ In this study, 2,580 patients age 65 years or older with hypertension and no AF were enrolled after they had received a CIED for nodal dysfunction. Study participants were analyzed in three groups according to the longest episode of SCAF that occurred over a 3-month period: 6 minutes to 6 hours, 6 hours to 24 hours, and longer than 24 hours. Only participants with SCAF longer than 24 hours had increased risk of stroke (aHR, 3.2 [95% CI, 1.5 to 7.0]) compared with participants without SCAF. Participants with SCAF longer than 24 hours had an annual stroke risk of 5 percent, which is similar to the risk in patients with clinical AF. The major limitation of the study was that SCAF was assessed during the 3-month period after device implementation, which could have led to measurement error due to lead implantation causing transient SCAF.

Uittenbogaart et al conducted a systematic review and meta-analysis of observational studies evaluating thromboembolic events and AF burden.^48^ They identified seven studies (n=18,947), some of which were included in the Mahajan et al review. Only one study enrolled participants without medical indications for an implantable cardiac monitor.^193^ Most studies were rated as moderate risk of bias. All studies defined SCAF as AHRE lasting at least 5 to 14 minutes. Mean followup duration ranged from 1 to 7 years. AF burden was defined as either the duration of the longest episode, accumulated time per year, or maximum daily burden. Pooled analyses of two studies (n=12,734 participants) comparing participants with AHRE with participants with no AHRE demonstrated increased risk of thromboembolism for participants with AHRE longer than 6 minutes (HR, 1.8 [95% CI, 1.3 to 2.5]) and longer than 6 hours (HR, 1.8 [95% CI, 1.2 to 2.6]).^202,^ ^203^ A second pooled analysis (n=2,849 participants) comparing participants with AHRE to participants with no AHRE demonstrated increased risk of thromboembolism for AHRE greater than 24 hours (HR, 3.2 [95% CI, 1.8 to 5.9]) but no difference for AHRE less than 24 hours.^204,^ ^205^ Healey et al, the only included study to enroll participants without an indication for a CIED (n=256), recorded no thromboembolic events among participants with paroxysmal AF.^193^

The KP-RHYTHM Study is a retrospective cohort study that evaluated the risk of stroke in patients with paroxysmal AF detected by ambulatory ECG not on anticoagulation.^49^ Participants were members of the California Kaiser Permanente integrated healthcare system who were diagnosed with paroxysmal AF by 14-day Zio Patch monitoring (N=1,965) between 2011 and 2016. AF burden was defined as the proportion of time in AF during the monitoring period with a minimum episode duration of 30 seconds. Rate of thromboembolic events (i.e., stroke, TIA, systemic embolic event) was compared by AF burden in tertiles: less than 2 percent, 2 to 11 percent, and greater than 11 percent. Although rate of thromboembolic events rose by tertile (0.7, 1.0, and 2.9 per 100 person-years, respectively), 95 percent CIs were largely overlapping for all three groups. When compared with the combined first and second tertiles, the unadjusted HR for the third tertile was 3.2 (95% CI, 1.5 to 6.6). Adjusted and sensitivity analyses revealed similar conclusions to the primary analysis.

Both the American Heart Association (AHA) and the Canadian Cardiovascular Society (CCS) have issued statements on stroke prevention in SCAF as a result of the studies outlined above. The CCS guidelines recommend that patients with SCAF longer than 24 hours with at least one stroke risk factor should receive OAC.^74^ Additionally, patients with SCAF of shorter duration who are at high risk should also be considered for OAC. On the other hand, the AHA guidelines currently recommend mainly using vascular risk factors (e.g., CHA_2_DS_2_-VASc score) when deciding to use OAC for stroke prevention in AF.^125^ The AHA cited concerns that cutoffs for AF burden in all studies were arbitrary and not empirically derived; the effect of brief AF episodes is unknown; and some studies, including ASSERT, did not differentiate participants with AF vs. atrial flutter, which may have a different stroke risk. For patients with high AF burden (e.g., AHRE > 24 hrs) and high stroke risk (e.g., CHA_2_DS_2_-VASc ≥ 2 for men and ≥ 3 for women), the AHA considers anticoagulation a reasonable option.^125^ Although the European Society of Cardiology has recognized that AF burden may influence stroke risk, they conclude that the current evidence is insufficient to guide treatment and should not be a major factor in decision making related to stroke prevention treatment.^7^ However, they suggest modifiable stroke risk factors should be identified and managed. Lastly, they advise providers to consider OAC for selected patients with SCAF ≥ 24 hours and an estimated high stroke risk based on a validated tool such as the CHA_2_DS_2_-VASc.

Two trials comparing DOACs vs. aspirin are currently being conducted that will add information on the relationship between AF burden and stroke risk among people with indications for CIEDs: ARTESiA^206^ and NOAH-AFNET 6^207^ (Appendix H Table 1). ARTESiA is a multicenter, double-blind RCT of up to 4,000 patients age 55 years or older with SCAF (i.e., CIED-detected AF ≥ 6 minutes duration) and at least one stroke risk factor.^206^ Participants will be randomized to apixaban or aspirin with an anticipated mean followup of 36 months. The composite primary outcome is stroke, TIA, and systemic embolism, and the primary safety outcome is overt major bleeding. A planned subgroup analysis will compare participants with longest baseline SCAF greater than vs. less than the median study population value. NOAH-AFNET 6 is a pragmatic, multicenter, double-blind RCT of 3,400 participants with CIED-detected AHRE longer than 6 minutes, age 65 years or older, and at least one additional stroke risk factor.^207^ Participants are randomized to edoxaban or usual care (i.e., aspirin or placebo based on established indications) and followed for up to 3 years. The primary outcome is stroke, systemic embolism, or cardiovascular death, and a major bleeding event is a secondary outcome. Prespecified exploratory analyses will be conducted based on duration and pattern of AHRE. Results from both trials are expected in 2022. However, both trials are enrolling patients with indications for CIED, which may reduce the applicability of their results to asymptomatic, healthy adults.

Appendix B Table 1 Summary of Studies Published Since 2000 Reporting the Prevalence of Previously Undiagnosed Atrial Fibrillation Among Unselected or Asymptomatic Persons

Author, Year; Study Name; Registry No. | Study Design | Sample Size | Country | Study Population | Method of Detection | Previously Undiagnosed AF; Prevalence (95% CI)
Community-Based Samples
Bacchini et al, 2019^155^ | Uncontrolled trial | 3,071 | Italy | Participants age 50 years or older recruited from 74 community pharmacies; Mean age: NR; N (%) Female: NR | Oscillometric BP with automated AF detecton algorightm (MicrolifeAFIB) | 1.8% (NR)
Berge et al, 2018^156^; ACE; NCT01555411 | Cross-sectional study | 3,553 | Norway | Longitudinal, population-based cohort recruited from individuals born in 1950 from a single county; Mean age: 63.9 (0.7); N (%) Female: 1,807 (49) | 12-lead ECG | 0.3% (NR)
Busch et al, 2017^157^ | Cohort study | 1,678 | Germany | Participants age 20 to 79 recruited from population registries; Mean age:; No-AF: 51 (13); Tele-AF: 64 (14); ECG-AF: 69 (6); N (%) Female: 880 (52) | One-time 12-lead ECG followed by intermittent ambulatory single-lead ECG, two recordings of 30 s each daily over 4 weeks plus whenever symptoms (e.g., dizziness, chest pain) occur. Interpreted by trained personnel, with validation of abnormal rhythms by a second interpreter. | Single, 12-lead ECG: 1.3% (0.8% to 1.9%); Intermittent ECG:2.6% (1.9% to 3.4%); 21 new AF cases based on 12 lead; 43 new cases based on intermittent ECG (all were also detected by 12 lead)
Chan et al, 2016^158^ | Uncontrolled trial | 8,797 | Hong Kong | Population-based sample of adults age 18 years or older; Mean age 64.7 (SD 13.4); 71.5% men; 38.2% HTN; 14.8% DM; 0.7 % heart failure; 2.2 coronary heart disease; 2.7 cardiothoracic surgery | One-time single-lead ECG for 30-second interval using handheld device with smartphone application (AliveCor device). Detection based on presence of full 30-second interval of AF. | 1.1% (NR)
Chan et al, 2018^159^; AFINDER | Uncontrolled trial | 10,735 | Hong Kong | Community residents age 50 or older recruited through advertisements in media and community centers; Mean age: 78.6 (8.1); N (%) Female: 8,564 (79.8) | Single-lead handheld ECG (Kardia Mobile) for 30 seconds interpreted with algorithm | 0.69% (0.54% to 0.84%)
Claes et al, 2012^160^ | Uncontrolled trial | 10,758 | Belgium | Community-based sample of adults 40 years or older recruited through media advertisements; Mean age: 59 (SD, 11); 38% men | One-time single-lead ECG via a handheld device. Detection based on RR intervals, absence of p waves, and variable atrial cycle length. | 1.5% (NR)
Diouf et al, 2016^161^ | Cohort study | 8,273 | Australia | Partcipants age 35 years or older from the Australian Diabetes, Obesity and Lifestyle Study; Mean age: NR, all participants were age ≥35; N (%) Female: NR | 12-lead ECG | 1.1% (NR); Unclear whether sample included persons with known AF.
Doliwa et al, 2009^162^ | Test accuracy study | 606 | Sweden | Community-based sample of adults age 18 years or older.; 49% were age 60 or older; 64% men | One-time single-lead ECG via handheld device for 10-second interval. Detection criteria NR. | 1.0% (NR)
Engdahl et al, 2013^152^ | Uncontrolled trial | 767 | Sweden | Population-based sample of 75- and 76-year-old adults; Men: 43%; Heart failure: 4%; Hypertension: 53%; Diabetes: 11%; Stroke/TIA: 10% | Stepwise screening approach, initial 12-lead ECG, if normal and CHADS_2_ equal to 2 or more (i.e., 1 risk factor besides age) then intermittent single-lead ECG via handheld device twice daily for 2 weeks (55% of study population qualified for this second step). Detection based on 30-second interval of AF or two separate intervals at least 10 seconds. | 5.2% (3.8% to 7.7%); (40 cases total, 10 cases identified on initial 12-lead ECG, 30 cases identified on intermittent monitoring)
Frewen et al, 2013^163^; TILDA | Cohort study | 4,890 | Ireland | Population-based sample of community-dwelling adults age 50 years or older from a longitudinal study on aging; Mean age NR; 54% men | 12-lead ECG (lasting 10 minutes). Detection of AF by two independent clinicians according to European Society of Cardiology guidelines, with adjudication by a cardiologist. | 0.9% (NR)
Furberg et al, 1994^154^ | Cohort study | 5,151 | U.S. | Population recruited from Medicare eligibility lists of adults age 65 years or older from four U.S. communities.; Mean age 73 (NR); Men: 43%; White: 94.7% | One time, 12-lead ECG, interpreted centrally | 1.5% (NR)
Gudmundsdottir et al, 2020^164^ | Parallel-assignment RCT | 6315 | Sweden | Population-based sample of 75/76-year-olds randomized to control or invited to screening:; Congestive heart failure: 2.4%; Hypertension: 51.7%; Diabetes mellitus: 11.4%; Prior stroke or TIA: 8.1%; Vascular disease: 6.9%.; Mean age:; All participants were 75 or 76 years old at study entry; N (%) Female: 3,708 (54) | 30 second single-lead ECG with handheld device (Zenicor 2 device, Zenicor Medical Systems, Stockholm, Sweden). If sinus rhythm on index test, high-risk group offered two week intermittent ambulatory ECG with handheld device (Zenicor II) 4 × daily. | 2.6% (2.2% to 3.0%); All but 1 new case came from group of participants designated as high risk based on BNP levels recorded at baseline. Of the 165 new cases, 29 were made during initial one-time screen and 136 were diagnosed during extended ECG screening. Only high-risk participants were offered extended screening if initial one-time screening showed normal rhythm.
Kim et al, 2020^153^ | Uncontrolled trial | 5,366 | South Korea | Community-based sample of adults age 60 years or older recruited from community senior centers. In a preliminary study (2,422):; Hypertension: 50.9%; Diabetes: 24.2%; Dyslipidemia: 25.0%; Thyroid disease: 8.3%; Angina pectoris: 5.2%; Myocardial infarction: 2.6%; AF: 1.2%; Heart failure: 0.7%; Valvular heart disease: 0.3%; Transient ischemic accident: 0.5%; Cerebral infarction: 4.1%; Cerebral hemorrhage: 1.5%; Mean age: 75.5 (6.5); N (%) Female: 1,660 (69) | Automated single-lead ECG with Kardia Mobile (AliveCor, Mountain View, CA, USA). If positive for AF on first test, participants received confirmatory 12-lead ECG interpreted by cardiologist within 20 minutes. | 2.6% (2.2% to 3.1%)
Kropp et al, 2020^165^ | Uncontrolled trial | 250 | U.S. | Community sample of walk in customers at two rural pharmacies; Congestive heart failure: 3.2%,; Hypertension: 75.2%; Age greater than: 75, 21.6%; Diabetes mellitus: 29.6%; Previous stroke or transient ischemic attack: 7.6%; Peripheral vascular disease: 4.8%; Age 65 to 74: 25.6%; Obstructive sleep apnea: 24.8%; Obesity 65.2%.; Mean age: 61.7 (15.3); N (%) Female: 150 (60) | One-time single-lead, wireless, 30 second mobile-ECG (KardiaMobile by Alivecor) | 4.0% (NR); Prevalence was 3% after adjudication by 3 electrophysiologists.
Kvist et al, 2019^166^ | Cross-sectional study | 1,228 | Denmark | Men age 65 to 74 years enrolled in the DANCAVAS trial; recruited from the general population; Mean age: Median 69 (IQR 67.0 to 71.0); N (%) Female: 0 (0) | 12-lead ECG (recorded within 1 hour of single-lead ECG obtained during CT scan) interpreted by cardiologist | 0.7% (0.03% to 1.3%)
Lindberg et al, 2016^167^ | Uncontrolled trial | 200 | Sweden | Participants age 60 years or older in a single municipality who were participating in an ongoing national longitudinal study of aging; N (%) age groups:; Age 66-80: 125 (62.5%); Age >80: 75: (37.5%); N (%) Female: 112 (56) | 24-hour ambulatory ECG (ECG-BodyKom, Kiwodk Nordic AB) | 11% (NR)
Lowres et al, 2014^168^; SEARCH-AF | Uncontrolled trial | 1,000 | Australia | Community-based sample of adults age 65 years or older recruited from community pharmacies; Mean age: 76 (SD 7); Men: 44% | Pulse palpation and one-time single lead via handheld device connected to smartphone.; Criteria for detection NR. | 1.0% (95% CI, 0.5% to 1.8%); (Of the 10 cases of new AF, 2 had paroxysmal AF that reverted to sinus rhythm by the time of confirmation with 12-lead ECG)
Mandalenakis et al, 2018^169^ | Uncontrolled trial | 448 | Sweden | Population-based sample of 71-year-old men; Systolic blood pressure (mmHg): 147 ± 19; Diastolic blood pressure (mmHg): 86 ± 11; Hypertension: 56%; Previous myocardial infarction: 10%; Congestive heart failure: 3.5%; Previous stroke: 8.6%; Mean age: 71 (0); N (%) Female: 0 (0) | 12-lead ECG followed by thumb ECG (Zenicor) home recording twice daily for 30 seconds (one morning reading and one evening reading) for a 2-week period | 1.8% (NR)
Meschia et al, 2010^150^ | Cohort study | 29,861 | U.S. | Racially and ethnically diverse population-based sample of adults age 45 years or older; Median age: 74 (IQR 69 to 79); Men: 45%; Stroke: 11%; Hypertension: 59%; Diabetes: 221% | 12-lead ECG or 7-lead ECG obtained during in-home visit and interpreted centrally. Detection based on presence of AF on ECG | 0.6% (NR)
Omboni et al, 2016^170^ | Uncontrolled trial | 220 | Italy | Community-based sample of adults 18 years or older in two small villages. Screening performed in mobile units. History for cardiovascular disease: 11.4%.; Previous diagnosis of hypertension: 36.4%; Diabetes: 7.7%; Dyslipidemia: 27.3%; Obesity: 15.0%; Current smokers: 17.3%; Current drinkers: 43.2%.; Mean age: 57.5 (15.3); N (%) Female: 107 (49) | 3 back-to-back readings with oscillometric BP monitor (Microlife WatchBP Office AFIB, Microlife AG, Switzerland). Positive results followed by 30-second single-lead ECG with handheld ECG recorder (Cardio-A Palm ECG, Shenzhen Creative Industry Co. Ltd., China) | 1.8% (NR)
Schnabel et al, 2012^171^ | Cohort study | 5,000 | Germany | Population-based sample of adults between ages 35 and 74 years; Mean age 52: (SD 11); Men: 49.9%; Hypertension: 45.4%; Diabetes: 6.0%; Heart failure: 17.7%; Stroke: 1.5% | 12-lead ECG; detection based on confirmed AF by two independent cardiologists. | 0.5% (NR)
Svennberg et al, 2015^77^; STROKESTOP | Uncontrolled trial | 7,173 | Sweden | Population-based sample of 75- and 76-year-old adults; % men: NR; No clinical characteristics reported for the overall study population. | 12-lead ECG at index visit followed by intermittent single-lead ECG with handheld device twice daily and whenever palpitations occurred over 2 weeks. Detection based on AF or atrial flutter at index visit, during intermittent monitoring or in subsequent followup Holter monitoring or 12-lead ECGs. | 3.0% (95% CI, 2.7% to 3.5%); (218 cases total, 37 diagnosed at the index visit; 140 diagnosed with intermittent ECG, and 41 required Holter monitor or other repeat 12-lead ECG; 8 cases were atrial flutter)
Steinhubl et al, 2018^109^ | Parallel-assignment RCT | 1,738 (actively monitored) | U.S. | Recruitment from members of large health insurance plans recruited directly through email or direct mail.; Mean age: 73.5 (7.4); N (%) Female: 521 (38.1) | iRhythm Zio ECG patch for 14 days at baseline and again in 3 months; diagnoses by blinded to diagnosis of clinical events adjudication committee. Patch diagnosis based on 30 seconds or more of AF or atrial flutter detected by device and confirmed by investigator. | 6.2 (NR); This includes those diagnosed by patch, but also those who developed clinical symptoms and were diagnosed. 65 diagnoses based on patch, 44 were clinical diagnoses, before monitoring, after monitoring completed but without any findings of AF during monitoring.
Zaprutko et al, 2020^172^ | Uncontrolled trial | 490 | Poland | Community-based sample where every patient entering 10 pharmacies who looked to be >65 years was asked to join the study; Mean age: 73.7 (6.5); N (%) Female: 358 (68.2) | One-time single-lead ECG for 30-second interval using handheld device with smartphone application (Kardia mobile). Recordings sent to two cardiologists for final interpretation. | Algorithm interpretation: 3.5% (NR) (17 cases); Intepretation by cardiologist: 2.2% (12 cases), of these 7 (1.4%) were new diagnoses
Clinic-Based Samples
Bury et al, 2015^173^ | Uncontrolled trial | 566 | Ireland | Convenience sample of patients age 70 or older from 25 general practices; Mean age 78 (SD NR); Female: 60%; Hypertension: 48.2%; Diabetes: 10.6%; Coronary heart disease: 22.5%; Stroke: 2.6%; Other heart surgery or cardiac procedures: 3.1% | One-time 3-lead ECG using the ECG component of an automated external defibrillator followed by confirmatory 12-lead ECG. Criteria for detection NR but included both AF and atrial flutter. | 2.1% (NR); (2 of 12 cases were atrial flutter)
Chan et al, 2017^174^ | Cross-sectional study | 5,969 | Hong Kong | Patients ≥65 years of age recruited from primary healthcare setting; Mean age: 67.2 (11.0); N (%) Female: 3,217 (54) | Three BP measurements were taken using the automatic oscillometric BP monitor with AF detection algorithm. The “Afib” icon flashed when AF was detected. All diagnoses confirmed by standard 12-lead ECG. | 1.2% (NR); NR
Chan et al, 2017^175^ | Uncontrolled trial | 2,054 | Hong Kong | Patients ≥65 years of age with hypertension or diabetes mellitus, attending a genreal outpatient clinic; Mean age: 67.8 (10.6); N (%) Female: 1,112 (54) | One-time single-lead, mobile-ECG using AliveCor Heart Monitor AND automatic oscillometric BP monitor (the Microlife WatchBP Office AFIB) with AF detection algorithm, followed by 12-lead ECG for positive results. | 1.2% (NR)
Chan et al, 2016^176^ | Cross-sectional study | 990 | Hong Kong | Patients with a history of hypertension and/or diabetes mellitus or were ≥65 years of age recruited a general outpatient clinic; Mean age: 68.4 (12.2); N (%) Female: 539 (53) | 12-lead ECG confirmation by cardiologist after positive screen by either single-lead ECG for 30s with AliveCor heart monitor and 3 PPG waveforms acquired sequentially using Cardio Rhythm application | 5.1% (NR)
Clua-Espuny et al, 2013^177^ | Cross-sectional study | 1,043 | Spain | Patients recruited from primary care clinics; Mean age: 78.9 (SD 7.3); % men: NR | ECG in clinic setting, further details NR. Detection based on cardiologist confirmation of AF. | 2.2% (NR)
Deif et al, 2012^178^ | Uncontrolled trial | 2,802 | Australia | Ambulatory adults age 40 years or older undergoing preoperative evaluation for minor procedures or elective surgery; Mean age: 65 (SD 13); Men: 50% | “Routine” ECG; detection criteria NR. | All participants: 0.4% (NR); Participants age 65 years or older: 0.7% (NR)
Fitzmaurice et al, 2007^93^; SAFE | Cluster RCT | 9,137 | U.K. | Patients age 65 years or older from 50 general practices; Mean age: 75.3 (SD 7.2); Men: 42.8% | Practices were allocated to screening or control, and screening practices were subsequently allocated to systematic (invitation to attend screening clinic with 12-lead ECG) or opportunistic screening (pulse check at usual care visits with referral to screening clinic if abnormal).; Detection based on AF on 12-lead ECG. | Practices allocated to screening: 1.6%; Practices allocated to control: 1.0%
Ghazal et al, 2020^179^ | Test accuracy study | 1,010 | Sweden | Individuals age ≥ 65 years attending 1 of 4 primary care centers for routine care during study period;; Median age: 72; N (%) Female: 622 (61) | Instruction to patients for self pulse palpation 3 times daily followed by a 30-second ECG using handled device (Zenicor) over a 2-week period. Abnormal ECGs reviewed and confirmed by cardiologist; patch ECG used for 5 days in cases with unclear or uninterpretable findings. | 2.7% (1.8% to 3.9%)
Ghazal et al, 2019^180^ | Cross-sectional study | 290 | Sweden | Individuals registered with a single primary care center who visited the office for any reason during study period.; Mean age: All individuals were between 70 and 74 years; N (%) Female: NR, but likely at least half based on other data provided in the study. | 12-lead ECG plus 30 second single-lead ECG with handheld device (Zenicor) twice a day for at least 2 weeks, with subsequent confirmation and Holter monitoring if needed. | 5.5% (NR)
Grubb et al, 2019^151^ | Uncontrolled trial | 1,805 | United Kingdom | Patients 65 years or older from participating practices with at least 1 stroke risk factor including: heart failure, hypertension, diabetes mellitus, previous stroke or transient ischaemic attack, peripheral or carotid arterial disease; Mean age: 74.9 (7.1); N (%) Female: 703 (39) | Handheld, smartphone-based ECG recorder (AliveCor) for 30-second interval. | 5.1% (NR); Recordings interpreted by a cardiologist, not automated algorithm.
Hill et al, 1987^181^ | Uncontrolled trial | 819 | U.K. | Symptomless patients age 65 years or older from a single general practice; Mean age | Single 12-lead ECG in clinic setting. Detection based on interpretation by two clinicians. | 1.2% (NR)
Kaasenbrood et al, 2020^111^ | Cluster RCT | 17,107 | The Nether-lands | Clinic-based sample of 31 general practices. Baseline characteristics collected in a random sample of 10% of study participants.; 15 Intervention practices baseline characteristics:; Hypertension: 50.9%; Type 2 diabetes: 19.8%; COPD: 8.1%; Prior myocardial infarction: 6.8%; Ischemic stroke: 3.9%; TIA 4.6%. 16 control practices baseline characteristics:; Hypertension: 50.4%; Type 2 diabetes: 17.1%; COPD: 8.0%; Prior myocardial infarction: 6.7%; Ischemic stroke: 6.4%; TIA: 4.7%.; Mean age:; Intervention group: 74.3 (7.3).; Control arm: 74.5 (7.3); N (%) Female:; Intervention group: 4,680 (54.5).; Control arm: 4,610 (54.1) | One-time, single-lead ECG performed with handheld device (MyDiagnostic), interpreted by GP, followed by 12-lead ECG, interpreted by cardiologist | 1.4% (NR); Followup over 12 months.; Only 10.7% (919) of the population in the intervention practices were actually screened; the proportion with AF among this group was .030.
Kaasenbrood, 2016^182^ | Uncontrolled trial | 3,269 | The Nether-lands | Patients age 60 years or older recruited from 10 general practices at the time of yearly flu vaccination; Mean age: 69.4 (SD 8.9); Men: 49.0% | One-time single-lead ECG via handheld device for 60 seconds. Detection based on positive signal confirmed by cardiologist(s). | 1.1% (NR)
Kearley et al, 2014^113^ | Cross-sectional study | 890 | U.K. | Patients age ≥75 years recruited from six general practices; Mean age: 79.7 (NR); N (%) Female: 507 (50.7) | 12-lead ECG interpreted by cardiologist | 1.3% (NR)
Morgan et al, 2002^105^ | Parallel assignment RCT with two active comparators | 3,001 | U.K. | Patients ages 65 to 100 years from four general practices; Mean age: 75 (SD NR); Men: 41% | Systematic pulse and single-lead (II) ECG vs. opportunistic screening (reminder placed on patient chart to perform pulse screening). Detection based on AF on confirmatory ECG (in systematically screened arm). | Yield of new AF cases in systematically screened arm: 0.8% (NR) (systematically screened); 0.5% (NR) (opportunistically screened)
Orchard et al, 2016^183^; ACTRN12615000622505 | Uncontrolled trial | 972 | Australia | Participants age 65 years or older recruited from five general practices; Mean age: NR; N (%) Female: NR | Handheld, single lead ECG (AliveCor), if AF detected or ECG was not able to be classified, then 12-lead ECG used to confirm. | 0.8% (NR)
Orchard et al, 2019^184^; AF-SMART; ACTRN12616000850471 | Uncontrolled trial | 1,805 | Australia | Patients age 65 years or older seen within 8 general practices without known diagnosis of AF; Mean age: NR; N (%) Female: NR | One-time single lead ECG using AliveCor KardiaMobile smartphone ECG device; results confirmed with 12-lead ECG | 1.1% (NR)
Philippsen et al, 2017^56^ | Cross-sectional study | 82 | Denmark | Patients ≥ 65 years of age without known or suspected AF attending the diabetes and cardiology hospital outpatient clinics. Patients with known AF or CIED, history of stroke or TIA were excluded.; Mean age:; Median: 71.3 (IQR 67.4 to 75.1 years); N (%) Female: 30 (37); N (%) Insulin or oral anitdiabetics: 61 (74); Mean (SD) no. antihypertensives: 4 (0.9); Mean (SD) LVEF, %: 60 (7.0) | 2-channel 72-hour Holter monitoring analyzed by trained staff and adjudicated by 2 experienced cardiologists. AF defined as ≥>=1 episode of irregular rhythm without P waves lasting at least 30 seconds. | 2.4%
Quinn et al, 2018^185^ | Uncontrolled trial | 2,054 | Canada | Patients age 65 years or older who were attending routine appointments involving 22 primary care clinics; Mean age: 73.7 (6.9); N (%) Female: 1,096 (53.4) | Confirmation with 12-lead ECG or 24-hour Holter monitor after pulse check, single-lead ECG, and authomated oscillometric BP measurement with AF detection algorithm | 0.6% (NR)
Salvatori et al, 2015^186^ | Uncontrolled trial | 274 | Italy | Participants age 65 years or older with HTN without known AF or symptoms from 15 general practitioners were randomized to be recruited; Mean age: 70 (4); N (%) Female: 127 (46) | 48-hour Holter monitoring in participants | 2.6% (NR)
Tieleman et al, 2014^187^ | Uncontrolled trial | 632 | The Nether-lands | Patients undergoing influenza vaccination at a two general practice clinics; Mean age: 74 (7.1); N (%) Female: NR | One-time single-lead ECG for 60-second interval using handheld device, MyDiagnostick (MyDiagnostick Medical BV). Stored ECG results read by cardiologist for diagnosis. | 1.8% (NR)
Turakhia et al, 2015, STUDY-AF^149^ | Uncontrolled trial | 75 | U.S. | Single Veteran’s Health Administration clinic-based sample of adults age 55 years or older with 2 or more AF risk factors including CHD, heart failure, hypertension, diabetes, and sleep apnea; Mean age: 69 (SD 8.0); Men: 100%; With hypertension: 95%; With heart failure: 17%; With coronary artery disease: 77%; With diabetes: 56% | Continuous single-lead ECG via a wearable patch-based device for 2 weeks. AF based on presence of 30 seconds or more interval of AF. | 5.3% (NR)
Wheeldon et al, 1998^188^ | Uncontrolled trial | 1,207 | U.K. | Patients age 65 years or older from four general practices; Mean age: NR; % Men: NR | Single 12-lead ECG in clinic setting. Detection based on interpretation by cardiologist. | 0.4% (NR)

Abbreviations: ACE=Akershus Cardiac Examination; AF=atrial fibrillation; BNP=NT-proB type natriuretic peptide; BP=blood pressure; CA=California; CHADS_2_=Congestive heart failure, Hypertension, Age≥75 years, Diabetes mellitus, prior Stroke or TIA or thromboembolism; CHD=coronary heart disease; CHF=congestive heart failure; CI=confidence interval; CIED=cardiac implantable electronic devices; COPD=chronic obstructive pulmonary disease; DM=diabetes mellitus; ECG=electrocardiogram; GP=general practitioner; HTN=hypertension; ICM=insertable cardiac monitor; IQR=interquartile range; LVEF=left ventricular ejection fraction; MI=myocardial infarction; N=number of participants; NR=not reported; PPG=photoplethysmography; RCT=randomized, controlled trial; RR=risk ratio; SAFE=Screening for Atrial Fibrillation in the Elderly; SD=standard deviation; SEARCH-AF=Screening Education and Recognition in Community pHarmacies of Atrial Fibrillation; STUDY-AF=Screening Study for Undiagnosed Atrial Fibrillation; TIA=transient ischemic attack; TILDA=The Irish Longitudinal Study on Ageing; U.K.=United Kingdom; U.S.=United States.

Appendix B Figure 1 Prevalence of Undiagnosed Atrial Fibrillation Based on One-Time Tests in Clinic-Based Populations

* Confirmatory 12-lead ECG

Abbreviations: BPM=blood pressure monitor; CI=confidence interval; ECG=electrocardiography; NR=not reported; osc=oscillometric; PPG=photoplethysmography; UK=United Kingdom.

Appendix B Figure B1 is titled “Prevalence of Undiagnosed Atrial Fibrillation Based on One-Time Tests in Clinic-Based Populations.” This figure displays a forest plot reporting the pooled prevalence of previously undiagnosed atrial fibrillation for 20 studies in clinic-based samples based on the use of a test at one point in time. The overall pooled prevalence among clinic-based samples was 1.2 (95% CI, 0.9 to 1.5).

Appendix B Figure 2 Prevalence of Undiagnosed Atrial Fibrillation Based on One-Time Tests in Community-Based Populations

* Confirmatory 12-lead ECG

Abbreviations: BPM=blood pressure monitor; CI=confidence interval; ECG=electrocardiography; NR=not reported; osc=oscillometric; USA=United States of America.

Appendix B Figure B2 is titled “Prevalence of Undiagnosed Atrial Fibrillation Based on One-Time Tests in Community-Based Populations.” This figure displays a forest plot reporting the pooled prevalence of previously undiagnosed atrial fibrillation for 17 studies in community-based samples based on the use of a test at one point in time. The overall pooled prevalence among community-based samples was 1.3 (95% CI, 1.0 to 1.6).

Appendix B Figure 3 Prevalence of Undiagnosed Atrial Fibrillation Based on Continuous or Intermittent Monitoring Tests

* Confirmatory 12-Lead ECG

† Two rounds of 2-week continuous monitoring via ECG patch 3 months apart.

ǂ Only persons in the high-risk group as assessed via biomarker received intermittent monitoring.

Abbreviations: CI=confidence interval; ECG=electrocardiography; NR=not reported; osc=oscillometric; UK=United Kingdom; USA=United States of America.

Appendix B Figure B3 is titled “Prevalence of Undiagnosed Atrial Fibrillation Based on Continuous or Intermittent Monitoring Tests.” This figure displays a forest plot reporting the pooled prevalence of previously undiagnosed atrial fibrillation in clinic- and community-based sampled based on intermittent or continuous monitoring. The pooled prevalence among clinic-based samples was 3.2 percent (95% CI, 1.5 to 4.9; 7 studies; 3,885 participants) and was 3.5 percent (95% CI, 2.0 to 5.1; 8 studies; 662,443 participants) among community-based samples. The combined pooled prevalence for continuous or intermittent monitoring among clinic and community-based samples was 3.3 percent (95% CI, 2.3 to 4.3).

Appendix B Table 2 Stroke Incidence for People With Asymptomatic, Previously Unrecognized AF Compared With Stroke Incidence for People With Symptomatic AF Reported by Observational Studies

Author, Year; Country | Study Population and Setting | Stroke Incidence | Study Limitations
Thind et al, 2018^190^; U.S. | 176 sites enrolled 9319 participants with incident or prevalent AF between 2010 and 2011 from outpatient practices, diagnosed with ECG. Symptom status was assessed at baseline registry (ORBIT-AF) enrollment by clinician and symptom checklist. | Asymptomatic AF, 0.90 per 100 person-years vs. symptomatic AF 1.04 per 100 person-years for stroke or non-CNS embolism over mean followup of 2.6 years; Adjusted HR, 0.85 (95% CI, 0.63 to 1.16) comparing asymptomatic to symptomatic AF. Adjusted for a variety of clinical and demographic characteristics including age and use of oral anticoagulation | - High levels of comorbidities may limit applicability to general population (e.g., HTN 83%, DM 30%, CKD 34%, HF 32%, CAD 36%, CVA 15%); - Symptom status assessed at registry enrollment; symptom status at AF diagnosis unknown, which limits applicability to incident asymptomatic AF
Potpara, 2013^39^; Serbia | 146 asymptomatic patients with initial AF diagnosis between 1997 and 2007 diagnosed with 12-lead ECG during period medical exam based on registry of patients with AF. (Total cohort=1,100 individuals with AF); 47.9% were placed on aspirin and 40.4% were placed on oral anticoagulants after diagnosis | Asymptomatic AF, 14 (9.6%) vs. symptomatic AF, 44 (4.6%) with ischemic stroke during mean followup of 9.9 years; Adjusted HR, 1.8 (95% CI, 1.0 to 3.4, p=0.051) compared with individuals in cohort with symptomatic AF (adjustment for age, sex, and treatment at baseline) | - High potential for confounding (e.g., no adjustment for smoking status and other relevant imbalances between symptomatic and asymptomatic individuals at baseline); - Limited information regarding ascertainment of AF symptoms; - 60% had prior heart disease, so may not be applicable to general population
Tsang, 2011^40^; U.S. | 1,152 asymptomatic adults (mean age 74 years) with ECG-confirmed diagnosis of first AF between 1980 and 2000 in Olmsted County, Minnesota, based on medical record review; (Total cohort=4,618) | Number (%) of events NR for either group. Compared with persons with symptomatic AF, persons with asymptomatic AF were three times more likely to have sustained an ischemic stroke before their diagnosis after adjustment for age, sex, and other stroke risk factors (p<0.0001) | - Data published in abstract format only, limiting assessment of risk of bias; - No information to assess whether groups were similar at baseline or what specific stroke risk factors were included in analysis (it reported adjusting for age, sex, and “multiple other stroke risk factors”).; - Methods of ascertaining symptom status NR (other than stating that medical records were used)
Siontis, 2016^41^; U.S. | 161 asymptomatic adults (mean age 69.2) from among 1,000 randomly selected patients from a total cohort of 3,344 adults with incident AF between 2000 and 2010 in Olmsted County, Minnesota | Total of 59 strokes (among the 1,000).; Persons with asymptomatic AF had higher incidence of stroke over median followup of 5.6 years compared with persons with typical AF (adjusted HR, 2.6 [95% CI, 1.10 to 6.11]; adjusted for CHA_2_DS_2_-VASc score, age, BMI, smoking status, COPD, eGFR, dementia, malignancy, warfarin use and time in therapeutic range) | - Potential for residual confounding due to unmeasured differences in baseline characteristics among persons with typical, atypical, and asymptomatic AF as these groups were clearly different on numerous measured baseline characteristics; - Symptom status ascertained retrospectively by medical records review (by trained abstractors looking for information about palpitations, atypical symptoms, etc.)
Boriani, 2015^42^; Europe | 1,237 persons with asymptomatic AF (mean age 72; 520/1,237 with “fully asymptomatic” AF, indicating absence of current and previous symptoms) in an AF registry from those presenting to cardiology practices from 9 countries. Most asymptomatic patients had valvular heart disease (64.5%), chronic heart failure (44.3%), or CAD (40.1%).; (Total cohort=3,119 in the EORP-AF) | Mean followup about 1 year; Asymptomatic AF, 112/1064 (10.5%) vs. symptomatic AF, 80/1409 (5.7%) events for a composite incidence of stroke/TIA/peripheral embolism or death higher in asymptomatic AF compared with symptomatic AF at 1 year (p<0.0001) in unadjusted analyses. Multivariate analyses found no significant association with symptom status for mortality or for the composite of stroke/TIA/peripheral embolism or death^*^ | - High potential for residual confounding; asymptomatic patients were more likely to be older, male, and had a higher proportion of related comorbidities, including history of thromboembolic complications and stroke; - Analyses did not focus on the 520 “fully asymptomatic” persons for the comparisons reported; - Limited applicability to the key questions of this review because most participants had known heart disease

* Outcomes compared the 1,237 currently asymptomatic people (but not the fully asymptomatic) with symptomatic people.

Abbreviations: AF=atrial fibrillation; BMI=body mass index; CAD=coronary artery disease; CI=confidence interval; CKD=chronic kidney disease; CNS=central nervous system; COPD=chronic obstructive pulmonary disease; CVA= cerebrovascular accident; DM=diabetes mellitus; ECG=electrocardiogram; eGFR=estimated glomerular filtration rate; EORP=EurObservational Research Programme – Atrial Fibrillation; HR=hazard ratio; NR=not reported; ORBIT-AF=Outcomes Registry for Better Informed Treatment of Atrial Fibrillation; TIA=transient ischemic attack; U.S.=United States; vs=versus.

Appendix B Table 3 Predicted Stroke Risk Among Persons With Previously Unrecognized Atrial Fibrillation

Author, Year | n Previously Undiagnosed AF/N Total Study Sample (%) | Risk Instrument/Mean (SD) Predicted Stroke Risk
Bury et al (2015)^173^ | 12/566 (2.1) | CHA_2_DS_2_-VASc, median: 4
Chan et al (2016)^158^ | 101/8,797 (1.1) | CHA_2_DS_2_-VASc: 3.1 (1.3)
Deif et al (2012)^178^ | 10/1,459 (0.69) | Among persons age 65 or older; CHA_2_DS_2_-VASc: 3.8 (SD 2.0); CHADS_2_: 2.2 (1.5)
Grubb et al 2019^151^ | 92/1,805 (5.1) | CHA_2_DS_2_-VASc, median (range): 4.0 (2.0 to 7.0)
Kaasenbrood et al (2016)^182^ | 37/3,269 (1.1) | CHA_2_DS_2_-VASc: 3.4 (1.9)
Lowres et al (2014)^168^ | 15/1,000 (1.5) | CHA_2_DS_2_-VASc: 3.7 (1.1); CHADS_2_: 1.9 (1.1)
Orchard et al (2020)^192^ | 36/3,103 (1.2) | CHA_2_DS_2_-VASc: 3.2
Svennberg et al (2015)^77^ | 218/7,173 (3.0) | CHA_2_DS_2_-VASc: 3.5 (1.2)
Turakhia et al (2015)^149^ | 4/75 (5.3) | CHA_2_DS_2_-VASc ≥2 in all 4 participants
Zaprutko et al (2020)^172^ | 7/525 (1.3) | CHA_2_DS_2_-VASc: 2.1 (0.7)
Busch et al (2017)^157^ | 43/1,678 (2.6) | CHADS_2_: 2.4 (1.0)
Engdahl et al (2013)^152^ | 10/767 (1.3) | CHADS_2_: 1.8 (NR)
Fitzmaurice et al (2014)^92^ | 149/9137 (1.6) | CHADS_2_: 1.4 (1.1)

Abbreviations: AF=atrial fibrillation; CHADS_2_=Congestive heart failure, Hypertension, Age ≥75 years, Diabetes mellitus, prior Stroke or TIA or thromboembolism [doubled]; CHA_2_DS_2_-VASc=Congestive heart failure, Hypertension, Age ≥75 years [doubled], Diabetes mellitus, prior Stroke or TIA or thromboembolism [doubled], Vascular disease, Age 65-74 years, Sex category; n=number of patients; N/n=number of patients in sample; NR=not reported; SD=standard deviation.

Appendix B Table 4 Predicted Stroke Risk Profile of New AF Cases^148^

Age, years | n | Mean CHA_2_DS_2_-VASc (95% CI)
<60 | 251 | 1.1 (0.7-1.5)
60-64 | 125 | 1.4 (1.2-1.6)
65-69 | 223 | 2.5 (2.2-2.8)
70-74 | 240 | 2.7 (2.4-2.9)
75-79 | 228 | 3.8 (3.4-4.1)
80-84 | 151 | 3.8 (3.4-4.2)
85+ | 151 | 3.9 (3.6-4.4)

Abbreviations: AF=atrial fibrillation; CHA_2_DS_2_-VASc=Congestive heart failure, Hypertension, Age ≥75 years [doubled], Diabetes mellitus, prior Stroke or TIA or thromboembolism [doubled], Vascular disease, Age 65-74 years, Sex category; CI=confidence interval; n=number of patients.

Appendix B Table 5 Stroke Incidence and Predicted Stroke Risk for Older Adults With Paroxysmal AF Compared With Stroke Incidence for People With Persistent or Permanent AF

Author, Year; Country | Study Population and Setting | Stroke Incidence | Risk Instrument/Mean (SD) Predicted Stroke Risk | Study Limitations
Boriani et al, 2018^45^; 9 countries (Belgium, Denmark, Greece, Italy, Netherlands, Norway, Poland, Portugal, Romania); Prospective cohort study | Total: 2,119; Paroxysmal AF: 573; Persistent AF: 445; Long-standing persistent AF: 119; Permanent AF: 335 | Stroke, n (%) at 3 years followup; Paroxysmal AF: 7 (1.4); Persistent AF: 4 (1.1); Permanent AF: 10 (3.5); p=0.14; Calculated RD 0.32 (95% CI, −1.49 to 1.91) paroxysmal vs. persistent; Calculated RD −2.07 (95% CI, −4.95 to 0.07) paroxysmal vs. permanent | CHA_2_DS_2_-VASc: Low risk, n (%); Paroxysmal AF: 71 (12.4); Persistent AF: 28 (6.3); Long-standing persistent AF: 4 (3.4); Permanent AF: 11 (3.3); CHA_2_DS_2_-VASc: Moderate risk, n (%); Paroxysmal AF: 68 (11.9); Persistent AF: 55 (12.4); Long-standing persistent AF: 7 (5.9); Permanent AF: 16 (4.8); CHA_2_DS_2_-VASc: High risk, n (%); Paroxysmal AF: 434 (75.7); Persistent AF: 362 (81.3); Long-standing persistent AF: 108 (90.8); Permanent AF: 308 (91.9) | Only included patients presenting to a cardiologist.
Ganesan et al, 2016^44^; Systematic review/meta-analysis (n=12 included studies) | 99,996 patients from 12 studies (10 RCTs and 2 prospective cohort studies) | Stroke, %:; Nonparoxysmal AF: 2.2 (95% CI, 1.8 to 2.5); Paroxysmal AF: 1.5 (95% CI, 1.2 to 1.8); Adjusted^*^ RR of nonparoxysmal vs. paroxysmal AF: 1.4 (95% CI, 1.2 to 1.6), p<0.001, I^2^=28.8% | NR | Did not assess if increased thromboembolic risk for nonparoxysmal AF applies uniformly over all CHADS_2_/CHA_2_DS_2_-VASc scores.
Link et al, 2017^43^; Multiple countries (U.S. and non-U.S.); Prospective cohort study | Total N: 21,105; Paroxysmal AF: 5,366; Persistent AF: 4,868; Permanent AF: 10,865 | Stroke or SEE:; Paroxysmal AF: 1.5%/yr; Persistent AF: 1.8%/yr; Permanent AF: 2.0%/yr; Adjusted^†^ HR of paroxysmal vs. persistent AF: 0.8 (95% CI, 0.7 to 0.96), p=0.015; Adjusted^†^ HR of paroxysmal vs. permanent AF: 0.8 (95% CI, 0.7 to 0.9), p=0.004 | NR | Prespecified secondary analysis of clinical trial data.

* Adjusted for age, gender, hypertension, heart failure, previous thromboembolism, and diabetes mellitus.^44^

† Adjusted for age, sex, hypertension, congestive heart failure, prior stroke or TIA, diabetes mellitus, race, geographic region, BMI, smoking status, alcohol use, coronary artery disease, dyslipidemia, increased risk of falling, hepatic disease, neuropsychiatric disease, prior non-ICH bleed, use of antiplatelet agents at randomization, and creatinine clearance at randomization.^43^

Abbreviations: AF=atrial fibrillation; BMI=body mass index; CHADS_2_=Congestive heart failure, Hypertension, Age ≥75 years, Diabetes mellitus, prior Stroke or TIA or thromboembolism [doubled]; CHA_2_DS_2_-VASc=Congestive heart failure, Hypertension, Age ≥75 years [doubled], Diabetes mellitus, prior Stroke or TIA or thromboembolism [doubled], Vascular disease, Age 65-74 years, Sex category; CI=confidence interval; HR=hazard ratio; ICH=intracerebral hemorrhage; n/N=number of patients; NR=not reported; RCT=randomized, controlled trial; RD=risk difference; RR=risk ratio; SD=standard deviation; SEE=systemic embolic event; TIA=transient ischemic attack; U.S.=United States; vs=versus.