# Appendix A Additional Background

## Prevalence

Based on data from the Anticoagulation and Risk Factors in Atrial Fibrillation (ATRIA) study of 1.89 million adult California health plan members, in the 1990s the prevalence of diagnosed AF among the general population was 0.95 percent and was shown to increase dramatically with age (Appendix A Table 1).^26^

Appendix A Table 1 Prevalence of AF by Age and Sex in the ATRIA Study^26^

Age Band (Years) | Prevalence in Women (%) | Prevalence in Men (%)
<55 | 0.1 | 0.2
55-59 | 0.4 | 0.9
60-64 | 1.0 | 1.7
65-69 | 1.7 | 3.0
70-74 | 3.4 | 5.0
75-79 | 5.0 | 7.3
80-84 | 7.2 | 10.3
≥85 | 9.1 | 11.1

Abbreviations: AF=atrial fibrillation; ATRIA=Anticoagulation and Risk Factors in Atrial Fibrillation.

Appendix A Table 2 Validated Risk Prediction Tools for Stroke Risk

| Stroke Risk Tool
| CHA_2_DS_2_-VASc^134,^* | CHADS_2_^135^ | R_2_CHADS_2_^136^ | QStroke^137^ | ATRIA^138,†^
Risk Factor Category | Scoring/Points
Congestive Heart Failure | 1 (or LV dysfunction) | 1 (recent) | 1 (recent) | Y/N | 1
Hypertension | 1 | 1 (history of) | 1 (history of) | Continuous (SBP) | 1
Age (years) | 1 (65-74); 2 (75+) | 1 (75+) | 1 (75+) | Range, 25-84 | 6/9 (85+); 5/7 (75-84); 3/7 (65-74); 0/8 (<65)
Diabetes Mellitus | 1 | 1 | 1 | Y/N (T1DM, T2DM) | 1
Stroke/TIA/TE | 2 | 2 | 2
Renal Dysfunction | | | 2 (creatinine clearance < 60 mL/min) | | 1 (proteinuria); 1 (eGFR<45 mL/min/1.73 m^2^ or ESRD)
Sex | 1 (female) | | | Separate models for M/F | 1 (female)
Vascular Disease | 1 (prior MI, PAD, or aortic plaque)
Valvular Heart Disease | | | | Y/N
Family History CHD | | | | Y/N
TC:HDLC Ratio | | | | Continuous
Atrial Fibrillation | | | | Y/N
Rheumatoid Arthritis | | | | Y/N
BMI | | | | Continuous
Smoking Status | | | | 5 categories
Ethnicity | | | | 9 categories
Deprivation | | | | Continuous (TDI score)

* Addition of African American ethnicity to the CHA_2_DS_2_-VASc score (CHA_2_DS_2_-VASc-R) statistically significantly improves stroke prediction in AF patients >65 years of age by a small amount (HR, 1.24 vs. 1.25; C-statistic 0.60 vs. 0.61). NRI 7.6 percent (p<0.001)."

† Scored for age categories with/without prior stroke.

Abbreviations: AF=atrial fibrillation; ATRIA=AnTicoagulation and Risk Factors in Atrial Fibrillation; BMI=body mass index; CHADS_2_=Congestive heart failure, Hypertension, Age >=75 years, Diabetes mellitus, Prior stroke or TIA or thromboembolism; CHA_2_DS_2_-VASc=Congestive heart failure (or Left ventricular systolic dysfunction), Hypertension, Age >=75 years, Diabetes Mellitus, Prior stroke or TIA or thromboembolism, Vascular disease, Age 65-74 years, Sex category; CHD=coronary heart disease; eGFR=estimated glomerular filtration rate; ESRD=end stage renal disease; HDLC=high density lipoprotein cholesterol; HR=hazard ratio; LV=left ventricular; M/F=male/female; MI=myocardial infarction; NRI=Net Reclassification Improvement; PAD=peripheral artery disease; QStroke=risk prediction algorithm; R_2_CHADS_2_=Renal Dysfunction, Congestive Heart Failure, Hypertension, Age, Diabetes, Stroke/Transient Ischemic Attack; SBP=systolic blood pressure; T1DM=type 1 diabetes mellitus; T2DM=type 2 diabetes mellitus; TC=total cholesterol; TDI=Townsend Deprivation Index; TE=thromboembolism; TIA=transient ischemic attack; Y/N=yes/no.

Adapted from: Dzeshka, M. S., Lane, D. A., & Lip, G. Y. (2014). Stroke and bleeding risk in atrial fibrillation: navigating the alphabet soup of risk-score acronyms (CHADS_2_, CHA_2_DS_2_-VASC, R_2_CHADS_2_, HAS-BLED, ATRIA, and more). Clin Cardiol, 37(10), 634–644. doi: 10.1002/clc.22294 25168181

Appendix A Table 3 Examples of Validated Risk Prediction Tools for Bleeding

| Bleeding Risk Tool
| HAS-BLED^139^ | HEMORR_2_HAGES^140^ | ATRIA^141^
Risk Factor Category | Scoring/Points
Hypertension | 1 | 1 (uncontrolled) | 1
Age (years) | 1 (65+ or frail) | 1 (75+) | 2 (75+)
Stroke | 1 | 1
Hepatic and/or Renal Dysfunction | 1 or 2 | 1 | 3 (severe renal disease)
Ethanol Abuse | 1 | 1
Anemia | | 1 | 3
Bleeding-Associated Factors | 1 (bleeding tendency or predisposition) | 1 (reduced platelet count/function); 2 (rebleeding risk) | 1 (prior hemorrhage)
Malignancy | | 1
Genetic Factors (CYP2C9 SNP) | | 1
Excessive Fall Risk | | 1
Labile INRs (if on Warfarin) | 1
Drugs (e.g., antiplatelet or NSAIDs) | 1

Abbreviations: ATRIA=AnTicoagulation and Risk Factors in Atrial Fibrillation; CYP_2_C9 SNP=gene variant (single nucleotide polymorphism) affecting drug metabolism; HAS-BLED=Hypertension, Abnormal renal and liver function, Stroke, Bleeding, Labile international normalized ratios, Elderly, Drugs or alcohol; HEMORR2HAGES=Hepatic or renal disease, ethanol abuse, Malignancy, Older age, Reduced platelet count or function, Rebleeding risk, Hypertension, Anemia, Genetic factors, Excessive fall risk, Stroke; INR=International Normalized Ratio, assay used to determine clotting tendency; NSAID=nonsteroidal anti-inflammatory drug; SNP=single nucleotide polymorphisms.

Adapted from: Dzeshka, M. S., Lane, D. A., & Lip, G. Y. (2014). Stroke and bleeding risk in atrial fibrillation: navigating the alphabet soup of risk-score acronyms (CHADS_2_, CHA_2_DS_2_-VASC, R_2_CHADS_2_, HAS-BLED, ATRIA, and more). Clin Cardiol, 37(10), 634–644. doi: 10.1002/clc.22294 25168181

Appendix A Table 4 Recent Recommendations (2013 or Newer) on Primary Prevention of Stroke (Including Screening and/or Treatment) in Patients With Atrial Fibrillation

Society or Professional Organization, Year Scope | Screening | Anticoagulation^*^ | Antiplatelet^*^
ESC/EACTS/EHRA, 2020^7^; Management of AF | Age ≥65 years, opportunistic screening by pulse taking or ECG rhythm strip; systematic ECG screening should be considered in patients ≥75 years or those at high stroke risk | DOAC > VKA^‡^ | Not recommended
AHA/ACC/HRS, 2014-2019^3,^ ^4^; Management of AF | Not addressed | DOAC > VKA^†^ | Low stroke risk only^‡^
U.K. NSC, 2019^68^; Screening for AF | Age ≥65 years, screening with ECG not recommended; pulse palpation or modified blood pressure monitors (if available) administered by nurses in primary care settings considered appropriate screening tests (followed by a diagnostic 12-lead ECG interpreted by a trained general practitioner in those who screen positive, and referral to a cardiologist/specialist in cases in which the diagnosis is unclear) | Not addressed | Not addressed
ACCP, 2018^73^; Antithrombotic therapy for AF | Not addressed | DOAC > VKA^†^ | Not recommended
CCS, 2018^74^; Management of AF | Not addressed | DOAC > VKA^§^ | Low stroke risk only
NHFA CSANZ, 2018^70^; Screening for and management of AF | Age ≥65 years, case-finding with pulse palpation (and ECG when AF is suspected because of irregular pulse) or ECG rhythm strip in the clinic or community; devices that provide medical-quality ECG trace are the most preferred option for screening | DOAC > VKA^‡,^ ^ǁ^ | Not recommended
AF-SCREEN International Collaborative, 2017^66^; Screening for AF | Age >65 years, pulse then ECG, single-lead ECG, or patient-activated twice-daily intermittent screening for 2 weeks (for age ≥75 years or those at high stroke risk) | DOAC^‡^ | Not recommended
WHF, 2017^69^; Management of AF | Age ≥65 years, pulse palpation, with ECG as appropriate | VKA or DOAC^‡^ | Not recommended
EPCCS, 2016^67^; Prevention of stroke in AF | Age ≥65 years, case-finding with pulse palpation at least yearly, with ECG as appropriate (alternative approach could use modified sphygmomanometers or single-lead ECG devices if they have been subject to validation with 12-lead ECG) | VKA or DOAC^‡^ | Not recommended
NICE, 2014^142^; Management of AF | Screening asymptomatic persons not directly addressed; Age ≥ 18 years pulse palpation if symptoms and ECG when AF is suspected because of irregular pulse (symptomatic or not) | VKA or DOAC^‡^ | Not recommended
AHA/ASA 2014^71^; Prevention of stroke | Age ≥65 years, pulse with ECG as appropriate | VKA or DOAC^‡^; Note: the AHA published updated guidance in the 2019 AHA/ACC/HRS guideline. | Low stroke risk only^ǁ^
AAN, 2014^143^; Prevention of stroke in NVAF | Not addressed | VKA or DOAC^¶^ | Low stroke risk only^ǁ^
CADTH, 2013^144^; Antithrombotic agents in AF | Not addressed | VKA or DOAC^#^ | Not addressed
SIGN, 2013^145^; Antithrombotic indications | Not addressed | VKA or DOAC^§,^ ** | Limited to persons refusing VKA/DOAC

* All treatment recommendations are for patients found to be appropriate candidates for treatment based on risk stratification.

† Recommended for men with CHA_2_DS_2_-VASc score ≥2 and women with CHA_2_DS_2_-VASc score ≥3 (ACCP also recommends offering stroke prevention for patients with a single nonsex CHA_2_DS_2_-VASc risk factor).

‡ Recommended for patients with CHA_2_DS_2_-VASc score ≥2 in men and ≥3 in women and should be considered for score=1 in men or score=2 in women.

§ Recommended for patients ≥ age 65 or with CHADS_2_ score ≥1.

ǁ Consider for patients with CHA_2_DS_2_-VASc score=1.

¶ Recommended for elderly patients (older than 75 years of age) with no history of recent unprovoked bleeding, variable for patients with dementia or occasional falls.

# DOAC for patients with a CHADS_2_ score ≥1 who are unable to achieve adequate anticoagulation with warfarin.

** Recommended for patients with CHA_2_DS_2_-VASc score ≥1.

Abbreviations: AAN=American Academy of Neurology; ACC=American College of Cardiology; ACCP=American College of Chest Physicians; AF=atrial fibrillation; AF-SCREEN=acronym not defined; AHA=American Heart Association; ASA=American Stroke Association; CADTH=Canadian Agency for Drugs and Technologies in Health; CCS=Canadian Cardiovascular Society; CHADS_2_=Congestive heart failure, Hypertension, Age≥75 years, Diabetes mellitus, prior Stroke or TIA or thromboembolism; CHA_2_DS_2_-VASc=Congestive heart failure (or Left ventricular systolic dysfunction), Hypertension, Age >=75 years, Diabetes Mellitus, Prior stroke or TIA or thromboembolism, Vascular disease, Age 65-74 years, Sex category; DOAC=direct oral anticoagulants; ECG=electrocardiography; EACTS=European Association of Cardio-Thoracic Surgery; EHRA=European Heart Rhythm Association; EPCCS=European Primary Care Cardiovascular Society; ESC=European Society of Cardiology; HRS=Heart Rhythm Society; NHFA CSANZ=National Heart Foundation of Australia and the Cardiac Society of Australia and New Zealand; NICE=National Institute for Health and Care Excellence; NSC=National Screening Committee; NVAF=nonvalvular atrial fibrillation; SIGN=Scottish Intercollegiate Guidelines Network; U.K.=United Kingdom; VKA=vitamin K antagonist; WHF=World Heart Federation.