# References

1 American Diabetes Association. 2. Classification and diagnosis of diabetes: standards of medical care in diabetes-2018. Diabetes Care. 2018 Jan;41(Suppl 1):S13–S27. doi: 10.2337/dc18-S002. PMID: 29222373.29222373
2 American Diabetes Association. 2. Classification and diagnosis of diabetes: standards of medical care in diabetes-2019. Diabetes Care. 2019 Jan;42(Suppl 1):S13–S28. doi: 10.2337/dc19-S002. PMID: 30559228.30559228
3 Stumvoll M, Goldstein BJ, van Haeften TW. Type 2 diabetes: principles of pathogenesis and therapy. Lancet. 2005 Apr 9-15;365(9467):1333–46. doi: 10.1016/S0140-6736(05)61032-X. PMID: 15823385.15823385
4 Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998 Sep 12;352(9131):837–53. PMID: 9742976.9742976
5 Huang Y, Cai X, Mai W, . Association between prediabetes and risk of cardiovascular disease and all cause mortality: systematic review and meta-analysis. BMJ. 2016 Nov 23;355:i5953. doi: 10.1136/bmj.i5953. PMID: 27881363.27881363
6 Zheng Y, Ley SH, Hu FB. Global aetiology and epidemiology of type 2 diabetes mellitus and its complications. Nat Rev Endocrinol. 2018 Feb;14(2):88–98. doi: 10.1038/nrendo.2017.151. PMID: 29219149.29219149
7 Emerging Risk Factors C, Di Angelantonio E, Gao P, . Glycated hemoglobin measurement and prediction of cardiovascular disease. JAMA. 2014 Mar 26;311(12):1225–33. doi: 10.1001/jama.2014.1873. PMID: 24668104.24668104
8 Centers for Disease Control and Prevention. National diabetes statistics report, 2017. Centers for Disease Control and Prevention, U.S. Dept of Health and Human Services. Atlanta, GA: 2017.
9 Kuehn B. Diabetes incidence decreases. JAMA. 2019 Jul 9;322(2):108. doi: 10.1001/jama.2019.8668. PMID: 31287529.31287529
10 Heron M. Deaths: leading causes for 2015. Natl Vital Stat Rep. 2017 Nov;66(5):1–76. PMID: 29235984.29235984
11 National Center for Chronic Disease Prevention and Health Promotion (U.S.). Division of Diabetes Translation. National Diabetes Day fact sheet, 2011. Atlanta, GA: National Center for Chronic Disease Prevention and Health Promotion Division of Diabetes Translation; 2011.
12 U. S. Burden of Disease Collaborators, Mokdad AH, Ballestros K, . The state of US Health, 1990-2016: burden of diseases, injuries, and risk factors among US states. JAMA. 2018 Apr 10;319(14):1444–72. doi: 10.1001/jama.2018.0158. PMID: 29634829.29634829
13 Aschner P. New IDF clinical practice recommendations for managing type 2 diabetes in primary care. Diabetes Res Clin Pract. 2017 Oct;132:169–70. doi: 10.1016/j.diabres.2017.09.002. PMID: 28962686.28962686
14 Handelsman Y, Bloomgarden ZT, Grunberger G, . American Association of Clinical Endocrinologists and American College of Endocrinology - clinical practice guidelines for developing a diabetes mellitus comprehensive care plan - 2015. Endocr Pract. 2015 Apr;21 Suppl 1:1–87. doi: 10.4158/EP15672.GL. PMID: 25869408.25869408
15 American Diabetes Association. Diabetes risk. What causes diabetes? Find out and take control. Arlington, VA: American Diabetes Association; n.d. https://www.diabetes.org/diabetes-risk.
16 Government of Canada. Diabetes. Are you at risk? Canada: Government of Canada; 2017. https://www.healthycanadians.gc.ca/en/canrisk.
17 International Diabetes Federation. Test2Prevent. Brussels, Belgium: International Diabetes Federation; n.d. https://www.idf.org/type-2-diabetes-risk-assessment/.
18 Australian Government, Department of Health. Australian type 2 diabetes risk assessment tool (AUSDRISK). Canberra ACT Australian Government, Department of Health; 2016. https://www1.health.gov.au/internet/main/publishing.nsf/Content/chronic-diab-prev-aus. Accessed October 1, 2019.
19 Diabetes Canada Clinical Practice Guidelines Expert Committee, Prebtani APH, Bajaj HS, . Reducing the risk of developing diabetes. Can J Diabetes. 2018 Apr;42 Suppl 1:S20–S6. doi: 10.1016/j.jcjd.2017.10.033. PMID: 29650097.29650097
20 American Diabetes Association. 5. Prevention or delay of type 2 diabetes: standards of medical care in diabetes-2018. Diabetes Care. 2018 Jan;41(Suppl 1):S51–S4. doi: 10.2337/dc18-S005. PMID: 29222376.29222376
21 NICE. Type 2 diabetes: prevention in people at high risk. National Institute for Health and Care Excellence (NICE). Public health guideline [PH38]. 2012. https://www.nice.org.uk/guidance/ph38
22 American Diabetes Association. Standards of medical care in diabetes-2019 abridged for primary care providers. Clin Diabetes. 2019 Jan;37(1):11–34. doi: 10.2337/cd18-0105. PMID: 30705493.30705493
23 Garber AJ, Abrahamson MJ, Barzilay JI, . Consensus statement by the American Association of Clinical Endocrinologists and American College of Endocrinology on the comprehensive type 2 diabetes management algorithm - 2018 executive summary. Endocr Pract. 2018 Jan;24(1):91–120. doi: 10.4158/CS-2017-0153. PMID: 29368965.29368965
24 American Diabetes Association. 8. Pharmacologic approaches to glycemic treatment: standards of medical care in diabetes-2018. Diabetes Care. 2018 Jan;41(Suppl 1):S73–S85. doi: 10.2337/dc18-S008. PMID: 29222379.29222379
25 Qaseem A, Barry MJ, Humphrey LL, . Oral pharmacologic treatment of type 2 diabetes mellitus: a clinical practice guideline update from the American College of Physicians. Ann Intern Med. 2017 Feb 21;166(4):279–90. doi: 10.7326/m16-1860. PMID: 28055075.28055075
26 Pilla SJ, Segal JB, Maruthur NM. Primary care provides the majority of outpatient care for patients with diabetes in the US: NAMCS 2009-2015. J Gen Intern Med. 2019 Jul;34(7):1089–91. doi: 10.1007/s11606-019-04843-9. PMID: 30719646.30719646
27 Shealy KM, Wu J, Waites J, . Patterns of diabetes screening and prediabetes treatment during office visits in the US. J Am Board Fam Med. 2019 Mar-Apr;32(2):209–17. doi: 10.3122/jabfm.2019.02.180259. PMID: 30850457.30850457
28 Evron JM, Herman WH, McEwen LN. Changes in screening practices for prediabetes and diabetes since the recommendation for hemoglobin A1c testing. Diabetes Care. 2019 Apr;42(4):576–84. doi: 10.2337/dc17-1726. PMID: 30728220.30728220
29 U.S. Preventive Services Task Force. Procedure manual. Rockville, MD: U.S. Preventive Services Task Force,; 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.
30 West SL, Gartlehner G, Mansfield AJ, . Comparative effectiveness review methods: clinical heterogeneity. Rockville, MD; 2010.
31 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986 Sep;7(3):177–88. PMID: 3802833.3802833
32 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
33 Higgins JP, Thompson SG, Deeks JJ, . Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 6;327(7414):557–60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
34 Higgins JPT, Green S. Cochrane handbook for systematic reviews of interventions: John Wiley & Sons, Ltd; 2011.
35 Simmons RK, Echouffo-Tcheugui JB, Sharp SJ, . Screening for type 2 diabetes and population mortality over 10 years (ADDITION-Cambridge): a cluster-randomised controlled trial. Lancet. 2012 Nov 17;380(9855):1741–8. doi: 10.1016/S0140-6736(12)61422-6. PMID: 23040422.23040422
36 Echouffo-Tcheugui J, Simmons R, Prevost A, . Long-term effect of population screening for diabetes on cardiovascular morbidity, self-rated health, and health behavior. Ann Fam Med. 2015;13(2):149–57. doi: 10.1370/afm.1737. PMID: CN-01110231.25755036
37 Simmons RK, Rahman M, Jakes RW, . Effect of population screening for type 2 diabetes on mortality: long-term follow-up of the Ely cohort. Diabetologia. 2011 Feb;54(2):312–9. doi: 10.1007/s00125-010-1949-8. PMID: 20978739.20978739
38 Rahman M, Simmons RK, Hennings SH, . How much does screening bring forward the diagnosis of type 2 diabetes and reduce complications? Twelve year follow-up of the Ely cohort. Diabetologia. 2012 Jun;55(6):1651–9. doi: 10.1007/s00125-011-2441-9. PMID: 22237689.22237689
39 Rahman M, Simmons RK, Hennings SH, . Effect of screening for Type 2 diabetes on population-level self-rated health outcomes and measures of cardiovascular risk: 13-year follow-up of the Ely cohort. Diabet Med. 2012 Jul;29(7):886–92. doi: 10.1111/j.1464-5491.2012.03570.x. PMID: 22283392.22283392
40 Griffin SJ, Little PS, Hales CN, . Diabetes risk score: towards earlier detection of type 2 diabetes in general practice. Diabetes Metab Res Rev. 2000 May-Jun;16(3):164–71. PMID: 10867715.10867715
41 Park P, Simmons RK, Prevost AT, . Screening for type 2 diabetes is feasible, acceptable, but associated with increased short-term anxiety: a randomised controlled trial in British general practice. BMC Public Health. 2008 Oct 7;8:350. doi: 10.1186/1471-2458-8-350. PMID: 18840266.18840266
42 Eborall HC, Griffin SJ, Prevost AT, . Psychological impact of screening for type 2 diabetes: controlled trial and comparative study embedded in the ADDITION (Cambridge) randomised controlled trial. BMJ. 2007 Sep 8;335(7618):486. doi: 10.1136/bmj.39303.723449.55. PMID: 17761995.17761995
43 Paddison CA, Eborall HC, French DP, . Predictors of anxiety and depression among people attending diabetes screening: a prospective cohort study embedded in the ADDITION (Cambridge) randomized control trial. Br J Health Psychol. 2011 Feb;16(Pt 1):213–26. doi: 10.1348/135910710X495366. PMID: 21226792.21226792
44 Addolorato G, Ancona C, Capristo E, . State and trait anxiety in women affected by allergic and vasomotor rhinitis. J Psychosom Res. 1999 Mar;46(3):283–9. doi: 10.1016/s0022-3999(98)00109-3. PMID: 10193919.10193919
45 Knight RG, Waal-Manning HJ, Spears GF. Some norms and reliability data for the State-Trait Anxiety Inventory and the Zung Self-Rating Depression scale. Br J Clin Psychol. 1983;22(Pt 4):245–9.6640176
46 Kvaal K, Ulstein I, Nordhus IH, . The Spielberger State-Trait Anxiety Inventory (STAI): the state scale in detecting mental disorders in geriatric patients. Int J Geriatr Psychiatry. 2005 Jul;20(7):629–34. doi: 10.1002/gps.1330. PMID: 16021666.16021666
47 Uusitupa M, Peltonen M, Lindstrom J, . Ten-year mortality and cardiovascular morbidity in the Finnish Diabetes Prevention Study--secondary analysis of the randomized trial. PLoS One. 2009 May 21;4(5):e5656. doi: 10.1371/journal.pone.0005656. PMID: 19479072.19479072
48 Kulzer B, Hermanns N, Gorges D, . Prevention of Diabetes Self-Management Program (PREDIAS): effects on weight, metabolic risk factors, and behavioral outcomes. Diabetes Care. 2009 Jul;32(7):1143–6. doi: 10.2337/dc08-2141. PMID: 19509014.19509014
49 Morey MC, Pieper CF, Edelman DE, . Enhanced fitness: a randomized controlled trial of the effects of home-based physical activity counseling on glycemic control in older adults with prediabetes mellitus. J Am Geriatr Soc. 2012 Sep;60(9):1655–62. doi: 10.1111/j.1532-5415.2012.04119.x. PMID: 22985140.22985140
50 Florez H, Pan Q, Ackermann RT, . Impact of lifestyle intervention and metformin on health-related quality of life: the diabetes prevention program randomized trial. J Gen Intern Med. 2012 Dec;27(12):1594–601. doi: 10.1007/s11606-012-2122-5. PMID: 22692637.22692637
51 Davies MJ, Gray LJ, Troughton J, . A community based primary prevention programme for type 2 diabetes integrating identification and lifestyle intervention for prevention: the Let’s Prevent Diabetes cluster randomised controlled trial. Prev Med. 2016 Mar;84:48–56. doi: 10.1016/j.ypmed.2015.12.012. PMID: 26740346.26740346
52 le Roux CW, Astrup A, Fujioka K, . 3 years of liraglutide versus placebo for type 2 diabetes risk reduction and weight management in individuals with prediabetes: a randomised, double-blind trial. Lancet. 2017 Apr 8;389(10077):1399–409. doi: 10.1016/s0140-6736(17)30069-7. PMID: 28237263.28237263
53 Diabetes Prevention Program Research G. Long-term effects of lifestyle intervention or metformin on diabetes development and microvascular complications over 15-year follow-up: the Diabetes Prevention Program Outcomes Study. Lancet Diabetes Endocrinol. 2015 Nov;3(11):866–75. doi: 10.1016/s2213-8587(15)00291-0. PMID: 26377054.26377054
54 Janssen PG, Gorter KJ, Stolk RP, . Randomised controlled trial of intensive multifactorial treatment for cardiovascular risk in patients with screen-detected type 2 diabetes: 1-year data from the ADDITION Netherlands study. Br J Gen Pract. 2009 Jan;59(558):43–8. doi: 10.3399/bjgp09X394851. PMID: 19105915.19105915
55 van den Donk M, Gorter KJ, Rutten GE. No negative effects of a multi-factorial, intensified treatment on self-reported health status, treatment satisfaction, and diabetes-related distress in screen-detected type 2 diabetes patients. The ADDITION-Netherlands study. Qual Life Res. 2010 May;19(4):509–13. doi: 10.1007/s11136-010-9604-x. PMID: 20155327.20155327
56 Griffin SJ, Borch-Johnsen K, Davies MJ, . Effect of early intensive multifactorial therapy on 5-year cardiovascular outcomes in individuals with type 2 diabetes detected by screening (ADDITION-Europe): a cluster-randomised trial. Lancet. 2011 Jul 9;378(9786):156–67. doi: 10.1016/S0140-6736(11)60698-3. PMID: 21705063.21705063
57 Charles M, Ejskjaer N, Witte DR, . Prevalence of neuropathy and peripheral arterial disease and the impact of treatment in people with screen-detected type 2 diabetes: the ADDITION-Denmark study. Diabetes Care. 2011 Oct;34(10):2244–9. doi: 10.2337/dc11-0903. PMID: 21816977.21816977
58 Simmons RK, Sharp SJ, Sandbaek A, . Does early intensive multifactorial treatment reduce total cardiovascular burden in individuals with screen-detected diabetes? Findings from the ADDITION-Europe cluster-randomized trial. Diabet Med. 2012 Nov;29(11):e409–16. doi: 10.1111/j.1464-5491.2012.03759.x. PMID: 22823477.22823477
59 Van den Donk M, Griffin SJ, Stellato RK, . Effect of early intensive multifactorial therapy compared with routine care on self-reported health status, general well-being, diabetes-specific quality of life and treatment satisfaction in screen-detected type 2 diabetes mellitus patients (ADDITION-Europe): a cluster-randomised trial. Diabetologia. 2013 Aug 20doi: 10.1007/s00125-013-3011-0. PMID: 2395957123959571.
60 Simmons RK, Borch-Johnsen K, Lauritzen T, . A randomised trial of the effect and cost-effectiveness of early intensive multifactorial therapy on 5-year cardiovascular outcomes in individuals with screen-detected type 2 diabetes: the Anglo-Danish-Dutch Study of Intensive Treatment in People with Screen-Detected Diabetes in Primary Care (ADDITION-Europe) study. Health Technol Assess. 2016 Aug;20(64):1–86. doi: 10.3310/hta20640. PMID: 27583404.27583404
61 Griffin SJ, Rutten G, Khunti K, . Long-term effects of intensive multifactorial therapy in individuals with screen-detected type 2 diabetes in primary care: 10-year follow-up of the ADDITION-Europe cluster-randomised trial. Lancet Diabetes Endocrinol. 2019 Dec;7(12):925–37. doi: 10.1016/S2213-8587(19)30349-3. PMID: 31748169.31748169
62 Ackermann RT, Liss DT, Finch EA, . A randomized comparative effectiveness trial for preventing type 2 diabetes. Am J Public Health. 2015 Nov;105(11):2328–34. doi: 10.2105/ajph.2015.302641. PMID: 26378828.26378828
63 Bhopal RS, Douglas A, Wallia S, . Effect of a lifestyle intervention on weight change in south Asian individuals in the UK at high risk of type 2 diabetes: a family-cluster randomised controlled trial. Lancet Diabetes Endocrinol. 2014 Mar;2(3):218–27. doi: 10.1016/s2213-8587(13)70204-3. PMID: 24622752.24622752
64 Welsh P, Cezard G, Gill JM, . Associations between weight change and biomarkers of cardiometabolic risk in South Asians: secondary analyses of the PODOSA trial. Int J Obes (Lond). 2016 Jun;40(6):1005–11. doi: 10.1038/ijo.2016.35. PMID: 26927315.26927315
65 Block G, Azar K, Romanelli R, . Diabetes prevention and weight loss with a fully automated behavioral intervention by email, web, and mobile phone: a randomized controlled trial among persons with prediabetes. J Med Internet Res. 2015;17(10):e240. doi: 10.2196/jmir.4897. PMID: CN-01169265.26499966
66 Knowler WC, Barrett-Connor E, Fowler SE, . Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002 Feb 7;346(6):393–403. doi: 10.1056/NEJMoa012512. PMID: 11832527.11832527
67 Ratner R, Goldberg R, Haffner S, . Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the diabetes prevention program. Diabetes Care. 2005 Apr;28(4):888–94. PMID: 15793191.15793191
68 Diabetes Prevention Program Research Group, Knowler WC, Fowler SE, . 10-year follow-up of diabetes incidence and weight loss in the Diabetes Prevention Program Outcomes Study. Lancet. 2009 Nov 14;374(9702):1677–86. doi: 10.1016/S0140-6736(09)61457-4. PMID: 19878986.19878986
69 Diabetes Prevention Program Research G. Long-term safety, tolerability, and weight loss associated with metformin in the Diabetes Prevention Program Outcomes Study. Diabetes Care. 2012 Apr;35(4):731–7. doi: 10.2337/dc11-1299. PMID: 22442396.22442396
70 Apolzan JW, Venditti EM, Edelstein SL, . Long-term weight loss with metformin or lifestyle intervention in the Diabetes Prevention Program Outcomes Study. Ann Intern Med. 2019 Apr 23doi: 10.7326/M18-1605. PMID: 3100993931009939.
71 Juul L, Andersen VJ, Arnoldsen J, . Effectiveness of a brief theory-based health promotion intervention among adults at high risk of type 2 diabetes: one-year results from a randomised trial in a community setting. Prim Care Diabetes. 2016 Apr;10(2):111–20. doi: 10.1016/j.pcd.2015.07.002. PMID: 26259517.26259517
72 Katula JA, Vitolins MZ, Morgan TM, . The Healthy Living Partnerships to Prevent Diabetes study: 2-year outcomes of a randomized controlled trial. Am J Prev Med. 2013 Apr;44(4 Suppl 4):S324–32. doi: 10.1016/j.amepre.2012.12.015. PMID: 23498294.23498294
73 Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. 2005 Feb;67(2):152–62. doi: 10.1016/j.diabres.2004.06.010. PMID: 15649575.15649575
74 Hellgren MI, Petzold M, Beteus-Forslund H, . Feasibility of a randomized controlled intervention with physical activity in participants with impaired glucose tolerance recruited by FINDRISC: a pilot study. Scand J Public Health. 2014 Jul;42(5):463–70. doi: 10.1177/1403494814528290. PMID: 24867622.24867622
75 Hu Z, Qin L, Xu H. One-year results of a synthetic intervention model for the primary prevention of T2D among elderly individuals with prediabetes in rural China. Int J Environ Res Public Health. 2017 Apr 14;14(4)doi: 10.3390/ijerph14040417. PMID: 28420105.28420105
76 Lindahl B, Nilsson TK, Borch-Johnsen K, . A randomized lifestyle intervention with 5-year follow-up in subjects with impaired glucose tolerance: pronounced short-term impact but long-term adherence problems. Scand J Public Health. 2009 Jun;37(4):434–42. doi: 10.1177/1403494808101373. PMID: 19181821.19181821
77 O’Brien MJ, Perez A, Scanlan AB, . PREVENT-DM comparative effectiveness trial of lifestyle intervention and metformin. Am J Prev Med. 2017 Jun;52(6):788–97. doi: 10.1016/j.amepre.2017.01.008. PMID: 28237635.28237635
78 Oldroyd JC, Unwin NC, White M, . Randomised controlled trial evaluating the effectiveness of behavioural interventions to modify cardiovascular risk factors in men and women with impaired glucose tolerance: outcomes at 6 months. Diabetes Res Clin Pract. 2001 Apr;52(1):29–43. PMID: 11182214.11182214
79 Pan XR, Li GW, Hu YH, . Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance. The Da Qing IGT and Diabetes Study. Diabetes Care. 1997 Apr;20(4):537–44. PMID: 9096977.9096977
80 Li G, Zhang P, Wang J, . The long-term effect of lifestyle interventions to prevent diabetes in the China Da Qing Diabetes Prevention Study: a 20-year follow-up study. Lancet. 2008 May 24;371(9626):1783–9. doi: 10.1016/S0140-6736(08)60766-7. PMID: 18502303.18502303
81 Li G, Zhang P, Wang J, . Cardiovascular mortality, all-cause mortality, and diabetes incidence after lifestyle intervention for people with impaired glucose tolerance in the Da Qing Diabetes Prevention Study: a 23-year follow-up study. Lancet Diabetes Endocrinol. 2014 Jun;2(6):474–80. doi: 10.1016/s2213-8587(14)70057-9. PMID: 24731674.24731674
82 Penn L, White M, Oldroyd J, . Prevention of type 2 diabetes in adults with impaired glucose tolerance: the European Diabetes Prevention RCT in Newcastle upon Tyne, UK. BMC Public Health. 2009 Sep 16;9:342. doi: 10.1186/1471-2458-9-342. PMID: 19758428.19758428
83 Ramachandran A, Snehalatha C, Mary S, . The Indian Diabetes Prevention Programme shows that lifestyle modification and metformin prevent type 2 diabetes in Asian Indian subjects with impaired glucose tolerance (IDPP-1). Diabetologia. 2006 Feb;49(2):289–97. doi: 10.1007/s00125-005-0097-z. PMID: 16391903.16391903
84 Saito T, Watanabe M, Nishida J, . Lifestyle modification and prevention of type 2 diabetes in overweight Japanese with impaired fasting glucose levels: a randomized controlled trial. Arch Intern Med. 2011 Aug 8;171(15):1352–60. doi: 10.1001/archinternmed.2011.275. PMID: 21824948.21824948
85 Sakane N, Sato J, Tsushita K, . Prevention of type 2 diabetes in a primary healthcare setting: three-year results of lifestyle intervention in Japanese subjects with impaired glucose tolerance. BMC Public Health. 2011 Jan 17;11(1):40. doi: 10.1186/1471-2458-11-40. PMID: 21235825.21235825
86 Sakane N, Kotani K, Takahashi K, . Effects of telephone-delivered lifestyle support on the development of diabetes in participants at high risk of type 2 diabetes: J-DOIT1, a pragmatic cluster randomised trial. BMJ Open. 2015 Aug 19;5(8):e007316. doi: 10.1136/bmjopen-2014-007316. PMID: 26289448.26289448
87 Tuomilehto J, Lindstrom J, Eriksson JG, . Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001 May 3;344(18):1343–50. doi: 10.1056/NEJM200105033441801. PMID: 11333990.11333990
88 Van Name MA, Camp AW, Magenheimer EA, . Effective translation of an intensive lifestyle intervention for Hispanic women with prediabetes in a community health center setting. Diabetes Care. 2016 Apr;39(4):525–31. doi: 10.2337/dc15-1899. PMID: 26908915.26908915
89 Yates T, Davies M, Gorely T, . Effectiveness of a pragmatic education program designed to promote walking activity in individuals with impaired glucose tolerance: a randomized controlled trial. Diabetes Care. 2009 Aug;32(8):1404–10. doi: 10.2337/dc09-0130. PMID: 19602539.19602539
90 Chiasson JL, Josse RG, Gomis R, . Acarbose for prevention of type 2 diabetes mellitus: the STOP-NIDDM randomised trial. Lancet. 2002 Jun 15;359(9323):2072–7. doi: 10.1016/S0140-6736(02)08905-5. PMID: 12086760.12086760
91 Chiasson JL, Josse RG, Gomis R, . Acarbose treatment and the risk of cardiovascular disease and hypertension in patients with impaired glucose tolerance: the STOP-NIDDM trial. JAMA. 2003 Jul 23;290(4):486–94. doi: 10.1001/jama.290.4.486. PMID: 12876091.12876091
92 Espinoza SE, Wang CP, Tripathy D, . Pioglitazone is equally effective for diabetes prevention in older versus younger adults with impaired glucose tolerance. Age (Dordr). 2016 Dec;38(5–6):485–93. doi: 10.1007/s11357-016-9946-6. PMID: 27585671.27585671
93 DeFronzo RA, Tripathy D, Schwenke DC, . Pioglitazone for diabetes prevention in impaired glucose tolerance. N Engl J Med. 2011 Mar 24;364(12):1104–15. doi: 10.1056/NEJMoa1010949. PMID: 21428766.21428766
94 Dream Trial Investigators, Bosch J, Yusuf S, . Effect of ramipril on the incidence of diabetes. N Engl J Med. 2006 Oct 12;355(15):1551–62. doi: 10.1056/NEJMoa065061. PMID: 16980380.16980380
95 Dream Trial Investigators, Gerstein HC, Yusuf S, . Effect of rosiglitazone on the frequency of diabetes in patients with impaired glucose tolerance or impaired fasting glucose: a randomised controlled trial. Lancet. 2006 Sep 23;368(9541):1096–105. doi: 10.1016/S0140-6736(06)69420-8. PMID: 16997664.16997664
96 Dream Trial Investigators, Dagenais GR, Gerstein HC, . Effects of ramipril and rosiglitazone on cardiovascular and renal outcomes in people with impaired glucose tolerance or impaired fasting glucose: results of the Diabetes REduction Assessment with ramipril and rosiglitazone Medication (DREAM) trial. Diabetes Care. 2008 May;31(5):1007–14. doi: 10.2337/dc07-1868. PMID: 18268075.18268075
97 Kaku K, Kadowaki T, Terauchi Y, . Sitagliptin improves glycaemic excursion after a meal or after an oral glucose load in Japanese subjects with impaired glucose tolerance. Diabetes Obes Metab. 2015 Nov;17(11):1033–41. doi: 10.1111/dom.12507. PMID: 26094974.26094974
98 Kawamori R, Tajima N, Iwamoto Y, . Voglibose for prevention of type 2 diabetes mellitus: a randomised, double-blind trial in Japanese individuals with impaired glucose tolerance. Lancet. 2009 May 9;373(9675):1607–14. doi: 10.1016/S0140-6736(09)60222-1. PMID: 19395079.19395079
99 Lindblad U, Lindberg G, Mansson NO, . Can sulphonylurea addition to lifestyle changes help to delay diabetes development in subjects with impaired fasting glucose? The Nepi ANtidiabetes StudY (NANSY). Diabetes Obes Metab. 2011 Feb;13(2):185–8. doi: 10.1111/j.1463-1326.2010.01331.x. PMID: 21199271.21199271
100 Lu YH, Lu JM, Wang SY, . Outcome of intensive integrated intervention in participants with impaired glucose regulation in China. Adv Ther. 2011 Jun;28(6):511–9. doi: 10.1007/s12325-011-0022-4. PMID: 21533568.21533568
101 Navigator Study Group, Holman RR, Haffner SM, . Effect of nateglinide on the incidence of diabetes and cardiovascular events. N Engl J Med. 2010 Apr 22;362(16):1463–76. doi: 10.1056/NEJMoa1001122. PMID: 20228402.20228402
102 Navigator Study Group, McMurray JJ, Holman RR, . Effect of valsartan on the incidence of diabetes and cardiovascular events. N Engl J Med. 2010 Apr 22;362(16):1477–90. doi: 10.1056/NEJMoa1001121. PMID: 20228403.20228403
103 Currie G, Bethel MA, Holzhauer B, . Effect of valsartan on kidney outcomes in people with impaired glucose tolerance. Diabetes Obes Metab. 2017 Jun;19(6):791–9. doi: 10.1111/dom.12877. PMID: 28093841.28093841
104 Nijpels G, Boorsma W, Dekker JM, . A study of the effects of acarbose on glucose metabolism in patients predisposed to developing diabetes: the Dutch acarbose intervention study in persons with impaired glucose tolerance (DAISI). Diabetes Metab Res Rev. 2008 Nov-Dec;24(8):611–6. doi: 10.1002/dmrr.839. PMID: 18756586.18756586
105 Ramachandran A, Snehalatha C, Mary S, . Pioglitazone does not enhance the effectiveness of lifestyle modification in preventing conversion of impaired glucose tolerance to diabetes in Asian Indians: results of the Indian Diabetes Prevention Programme-2 (IDPP-2). Diabetologia. 2009 Jun;52(6):1019–26. doi: 10.1007/s00125-009-1315-x. PMID: 19277602.19277602
106 Weber MB, Ranjani H, Staimez LR, . The stepwise approach to diabetes prevention: results from the D-CLIP randomized controlled trial. Diabetes Care. 2016 Oct;39(10):1760–7. doi: 10.2337/dc16-1241. PMID: 27504014.27504014
107 Gokulakrishnan K, Ranjani H, Weber MB, . Effect of lifestyle improvement program on the biomarkers of adiposity, inflammation and gut hormones in overweight/obese Asian Indians with prediabetes. Acta Diabetol. 2017 Sep;54(9):843–52. doi: 10.1007/s00592-017-1015-9. PMID: 28620678.28620678
108 Zinman B, Harris SB, Neuman J, . Low-dose combination therapy with rosiglitazone and metformin to prevent type 2 diabetes mellitus (CANOE trial): a double-blind randomised controlled study. Lancet. 2010 Jul 10;376(9735):103–11. doi: 10.1016/S0140-6736(10)60746-5. PMID: 20605202.20605202
109 Pan CY, Gao Y, Chen JW, . Efficacy of acarbose in Chinese subjects with impaired glucose tolerance. Diabetes Res Clin Pract. 2003 Sep;61(3):183–90. PMID: 12965108.12965108
110 Gong Q, Zhang P, Wang J, . Morbidity and mortality after lifestyle intervention for people with impaired glucose tolerance: 30-year results of the Da Qing Diabetes Prevention Outcome Study. Lancet Diabetes Endocrinol. 2019 Jun;7(6):452–61. doi: 10.1016/S2213-8587(19)30093-2. PMID: 31036503.31036503
111 Alanne S, Roine RP, Rasanen P, . Estimating the minimum important change in the 15D scores. Qual Life Res. 2015 Mar;24(3):599–606. doi: 10.1007/s11136-014-0787-4. PMID: 25145637.25145637
112 Bjorner JB, Lyng Wolden M, Gundgaard J, . Benchmarks for interpretation of score differences on the SF-36 health survey for patients with diabetes. Value Health. 2013 Sep-Oct;16(6):993–1000. doi: 10.1016/j.jval.2013.06.022. PMID: 24041349.24041349
113 Davies MJ, Heller S, Skinner TC, . Effectiveness of the diabetes education and self management for ongoing and newly diagnosed (DESMOND) programme for people with newly diagnosed type 2 diabetes: cluster randomised controlled trial. BMJ. 2008 Mar 1;336(7642):491–5. doi: 10.1136/bmj.39474.922025.BE. PMID: 18276664.18276664
114 Holman RR, Paul SK, Bethel MA, . 10-year follow-up of intensive glucose control in type 2 diabetes. N Engl J Med. 2008 Oct 9;359(15):1577–89. doi: 10.1056/NEJMoa0806470. PMID: 18784090.18784090
115 Holman RR, Paul SK, Bethel MA, . Long-term follow-up after tight control of blood pressure in type 2 diabetes. N Engl J Med. 2008 Oct 9;359(15):1565–76. doi: 10.1056/NEJMoa0806359. PMID: 18784091.18784091
116 UK Prospective Diabetes Study Group. Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38. BMJ. 1998 Sep 12;317(7160):703–13. PMID: 9732337.9732337
117 Khunti K, Gray LJ, Skinner T, . Effectiveness of a diabetes education and self management programme (DESMOND) for people with newly diagnosed type 2 diabetes mellitus: three year follow-up of a cluster randomised controlled trial in primary care. BMJ. 2012 Apr 26;344:e2333. doi: 10.1136/bmj.e2333. PMID: 22539172.22539172
118 Yang Y, Yao JJ, Du JL, . Primary prevention of macroangiopathy in patients with short-duration type 2 diabetes by intensified multifactorial intervention: seven-year follow-up of diabetes complications in Chinese. Diabetes Care. 2013 Apr;36(4):978–84. doi: 10.2337/dc12-0227. PMID: 23230099.23230099
119 Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998 Sep 12;352(9131):854–65. PMID: 9742977.9742977
120 Kumar KJSTCK-M. Saxagliptin as initial therapy in treatment-naive Indian adults with type 2 diabetes mellitus inadequately controlled with diet and exercise alone: a randomized, double-blind, placebo-controlled, phase IIIb clinical study. Int J Diabetes Dev Ctries. 2014;34(4):201–9. PMID: CN-01092468.
121 Aekplakorn W, Tantayotai V, Numsangkul S, . Evaluation of a community-based diabetes prevention program in Thailand: a cluster randomized controlled trial. J Prim Care Community Health. 2019;10:2150132719847374. doi: 10.1177/2150132719847374. PMID: CN-01936412.31079517
122 Gray LJ, Yates T, Troughton J, . Engagement, retention, and progression to type 2 diabetes: a retrospective analysis of the cluster-randomised “Let’s Prevent Diabetes” trial. PLoS Med. 2016 Jul;13(7):e1002078. doi: 10.1371/journal.pmed.1002078. PMID: 27404094.27404094
123 Wong CK, Fung CS, Siu SC, . A short message service (SMS) intervention to prevent diabetes in Chinese professional drivers with pre-diabetes: a pilot single-blinded randomized controlled trial. Diabetes Res Clin Pract. 2013 Dec;102(3):158–66. doi: 10.1016/j.diabres.2013.10.002. PMID: 24466598.24466598
124 Wong CKH, Siu SC, Wong KW, . Five-year effectiveness of short messaging service (SMS) for pre-diabetes. BMC Res Notes. 2018 Oct 10;11(1):709. doi: 10.1186/s13104-018-3810-y. PMID: 30309382.30309382
125 Diabetes Prevention Program Research Group. Long-term effects of metformin on diabetes prevention: identification of subgroups that benefited most in the diabetes prevention program and diabetes prevention program outcomes study. Diabetes care. 2019;42(4):601–8. doi: 10.2337/dc18-1970. PMID: 30877090.30877090
126 Moungngern Y, Sanguanthammarong S, Teparak P, . Effects of a health promotion program conducted by nurses on stabilization of HBA1C in subjects at risk for diabetes: a phase III randomized controlled trial. Chotmaihet thangphaet [journal of the medical association of thailand]. 2018;101(10):1343–8. PMID: CN-01650364.
127 Kulkarni S, Xavier D, George B, . Effect of intensive lifestyle modification & metformin on cardiovascular risk in prediabetes: A pilot randomized control trial. Indian J Med Res. 2018 Dec;148(6):705–12. doi: 10.4103/ijmr.IJMR_1201_17. PMID: 30778004.30778004
128 Pedley CF, Case LD, Blackwell CS, . The 24-month metabolic benefits of the healthy living partnerships to prevent diabetes: A community-based translational study. Diabetes Metab Syndr. 2018 May;12(3):215–20. doi: 10.1016/j.dsx.2017.09.011. PMID: 28964720.28964720
129 Chobanian AV, Bakris GL, Black HR, . The seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003 May 21;289(19):2560–72. doi: 10.1001/jama.289.19.2560. PMID: 12748199.12748199
130 American Diabetes Association. 7. Obesity management for the treatment of type 2 diabetes: standards of medical care in diabetes-2018. Diabetes Care. 2018 Jan;41(Suppl 1):S65–S72. doi: 10.2337/dc18-S007. PMID: 29222378.29222378