# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Howard Tracer, MD, AHRQ Medical Officer; Tracy Wolff, MD, MPH, Scientific Director, USPSTF Division, AHRQ; current and former members of the USPSTF; expert reviewers Timothy J. Wilt, MD, MPH, Minneapolis VA Health Care System; William H. Herman, MD, MPH, University of Michigan; Justin B. Echouffo Tcheugui, MD, MPhil, PhD, Johns Hopkins Medicine; federal partners from the Centers for Disease Control and Prevention; Sharon Barrell, MA, editor, Loraine Monroe, publications specialist; and Carol Woodell, EPC Program Manager.