# Chapter 4 Discussion

## Summary of Evidence

Table 9 provides a summary of the main findings in this evidence review organized by KQ along with a description of consistency, precision, quality, limitations, strength of evidence, and applicability.

Table 9 Summary of Evidence on Screening for Abnormal Glucose and Diabetes

Key Question and Topic | No. of Studies (k), No. of Observations (n) | Summary of Findings | Consistency and Precision | Study Quality | Limitations (Including Reporting Bias) | Overall Strength of Evidence | Applicability
KQ 1. Benefits of screening | k=2 RCTs (5 publications), 25,120 participants | For invitations to screening with a stepwise approach (starting with random glucose) or OGTT every 5 years compared with controls, no significant difference between groups for all-cause or cause-specific mortality at 10 years, or self-reported CVD events or quality of life at 7-13 years. | Consistency unknown (the 2 trials evaluated different screening approaches); imprecise | 1 Good; 1 Fair | Duration of followup may be too short; for outcomes other than mortality, missing data from most participants; reporting bias not detected. | Low for no benefit for mortality.; Insufficient for all other outcomes. | Asymptomatic adults 40-69; trials evaluated invitations to screening for DM; neither assessed screening for prediabetes or focused on fasting glucose or A1c as the initial test; neither reported race/ethnicity; mean BMI was 30-31 (NR in 1 trial).
KQ 2. Harms of screening | k=3 RCTs (5 publications), 9,328 participants^*^ | No significant differences between screening and control groups for anxiety, depression, worry, or self-reported health. Possible short-term increases in anxiety (at 6 weeks) among persons screened and diagnosed with DM vs. those not diagnosed with DM (STAI scores: 46.7 vs. 37.0; p=0.031). No trials reported on labeling, harms from false-positive results, burden, inconvenience, or unnecessary testing and treatment. | Consistency unknown (no 2 studies used similar measures at similar timepoints); imprecise | Fair (at least medium risk of bias) | Missing data from many participants; heterogeneity of measures used and timing of assessments; reporting bias not detected. | Low for anxiety, depression, worry, or self-reported health.; Insufficient for other outcomes^†^ | Asymptomatic adults 40-69 at high risk of diabetes
KQ 3. Intervening at time of screen-detection vs. later | k=0, 0 | No eligible studies | NA | NA | NA | Insufficient | NA
KQ 4. Benefits of interventions for screen-detected DM | k=1 RCT (8 publications), 3,057 participants | ADDITION-Europe found no difference over 5 to 10 years between an intensive multifactorial intervention aimed at controlling glucose, blood pressure and cholesterol and routine care in the risk of all-cause mortality, cardiovascular-related mortality, cardiovascular events, quality of life, nephropathy, retinopathy, or neuropathy. | Consistency unknown (single study); imprecise | Fair | Followup may have been too short; decisions about medication choices were made by individual physicians and patients; reporting bias not detected | Low for no benefit | Adults age 40 to 69 years with screen-detected DM; mean baseline HbA1C 7.0% (median 6.5%); mean BMI 31.5; participants were predominantly white; screening risk questionnaire followed by random glucose or invitation to have OGTT.
KQ 4. Benefits of interventions for prediabetes | k=38 (56 publications), 36,393 participants | Most trials reported mortality or CVD events after ≤6 years and reported few events with no difference between groups. Two trials had ≥10 years of followup: Finnish DPP (n=505) found no statistically significant difference between groups for mortality or composite CVD events over 10 years^‡^ and Da Qing (n=576) found no statistically significant difference between lifestyle and control groups at 20 years,^§^ but rates were lower in the combined intervention groups at 23 years for all-cause mortality (28.1% vs. 38.4%; HR 0.71 [95% CI, 0.51 to 0.99]) and CVD-related mortality (11.9% vs. 19.6%; HR 0.59 [95% CI, 0.36 to 0.96]); rates remained lower at 30-year followup. For QOL, 5 trials suggested no clinically meaningful benefit. | Reasonably consistent for CVD events, mortality, and QOL; consistency unknown for aggregate microvascular outcome (single study); imprecise | Fair | Followup duration too short in most studies; at least medium risk of bias in the Da Qing trial,^‖^ and relatively few participants; heterogeneity of measures used to assess QOL; reporting bias not detected | Low for long-term mortality benefit after 20 years | Adults with prediabetes; the trial reporting reduction in CVD events associated with acarbose included a population at high risk of CVD; the Da Qing trial showing long-term mortality benefit associated with a lifestyle intervention was conducted in China and used a 6-year lifestyle intervention.
KQ 5. Benefits of interventions for recently diagnosed DM | k=5 RCTs^¶^ (8 publications), 5,138 participants | Intensive glucose control with sulfonylureas or insulin decreased the risk for all-cause mortality (RR, 0.87 [95% CI, 0.79 to 0.96]), diabetes-related mortality (RR, 0.83 [95% CI, 0.73 to 0.96]) and myocardial infarction (RR, 0.85 [95% CI, 0.74 to 0.97]) over 20 years (10-year post-trial assessment) but not at shorter followup. For overweight people, intensive glucose control with metformin decreased the risk for all-cause mortality (RR, 0.64 [95% CI, 0.45 to 0.91]), diabetes-related mortality [RR, 0.58 [95% CI, 0.37 to 0.91]) and myocardial infarction (RR, 0.61 [95% CI, 0.41 to 0.89]) at 10-year followup, and benefits were maintained longer term.^#^ | Consistency unknown;^**^ precise for mortality and CVD outcomes; imprecise for other outcomes | Good | The longer-term results presented were from 10-year post-trial monitoring. Only one lifestyle intervention was included with followup for only 3 years and few clinical events. Reporting bias was not detected. Duration of diabetes at baseline was NR in the UKPDS. | Moderate for improved long-term health outcomes | Most of the data is from UKPDS, conducted from 1977-1997; 4 of the included studies were from the U.K.; participants were predominantly white
KQ 6. Harms of interventions for diabetes | k=4 RCTs (6 publications), 5,402 participants | Overall, harms were generally sparsely reported, rare, and (when reported) not significantly different between groups. UKPDS reported major hypoglycemic events in 1%-1.8% of participants receiving sulfonylureas or insulin (vs. 0.7% in the conventional care group) | Unknown consistency; imprecise | Fair | Included studies all assessed different interventions; reporting bias not detected | Low | Screen-detected or newly diagnosed type 2 diabetes
KQ 6. Harms of interventions for prediabetes | k=21 RCTs (38 publications), 32,468 participants | Lifestyle interventions: 2 studies found no or few musculoskeletal adverse events; DPP found higher rates of musculoskeletal symptoms among the intensive lifestyle intervention group.; Medications: no increased risk of hypoglycemic events vs. placebo in 5 trials assessing 5 different medications (liraglutide, sitagliptin, metformin, nateglinide, and rosiglitazone+ metformin). Six pharmacologic trials found higher rates of GI adverse events vs. controls: metformin (k=3), and acarbose (k=2), and liraglutide (k=1). | Lifestyle interventions: inconsistent, imprecise; Pharmacologic interventions: reasonably consistent; imprecise | Fair | Sparse reporting of harms (of 38 studies of interventions for prediabetes, 21 reported on harms) | Low | Adults with screen-detected or newly diagnosed prediabetes; most studies reporting harms assessed pharmacologic interventions
KQ 7. Interventions for prediabetes to delay or prevent progression to diabetes | Lifestyle: k=23 RCTs (33 publications), 12,915 participants; Pharmacologic: k=15 RCTs (23 publications), 24,295 participants | Lifestyle interventions associated with reduction in diabetes (k=23, pooled RR, 0.78 [95% CI, 0.69 to 0.88]).^††^ Pooled RRs 0.63 (95% CI, 0.50 to 0.81) for followup <1 year, 0.58 (95% CI, 0.41 to 0.82) for followup 1-2 years, and 0.81 (95% CI, 0.73 to 0.89) for followup >2 years. For medications, metformin, TZDs, and AGIs were all associated with a reduction in diabetes (pooled RRs 0.73 [0.64, 0.83], 0.50 [0.28, 0.92], and 0.64 [0.43, 0.96], respectively.^‡‡^ | Reasonably consistent (except for TZDs and AGIs); precise for lifestyle interventions and metformin, imprecise for TZDs and AGIs | Good: 6; Fair: 30 | Heterogeneity in approaches to defining prediabetes; higher rates of dropout or nonadherence in studies of alpha glucosidase inhibitors; reporting bias not detected | High for lifestyle interventions and metformin (for benefit); Low for other medications^§§^ (for benefit) | Asymptomatic adults age 40s to 60s years; most trials evaluated high contact lifestyle interventions; mean baseline BMI ranged from 24 to 39 kg/m^2^
KQ 8. Change in health outcomes that results from reduction in DM incidence after interventions for prediabetes | k=8 (17 publications), 23,489 participants | Two trials had >5-year followup and 1 had >10-year followup. 1 trial (Da Qing, n=576) reported reduction in both diabetes incidence and long-term adverse health outcomes with more than 5 years followup, finding that a 6-year lifestyle intervention yielded an absolute decrease in diabetes incidence of 24% (over 6 years) and was associated with 10% fewer deaths and 8% fewer cardiovascular deaths over 30 years. | Consistency unknown (single study with adequate long-term followup); imprecise | Fair | Most trials had insufficient followup to assess long-term health outcomes; at least medium risk of bias in the Da Qing trial;^‖‖^ and relatively few participants | Low | Trials in U.S. and other highly developed countries had insufficient followup; Da Qing trial was conducted in China
KQ 9. Interventions for prediabetes and other intermediate outcomes | Lifestyle: k=28 (41 publications), 14,671 participants; Pharmacologic: k=13 (25 publications), 26,619 participants | Lifestyle interventions: associated with reduced SBP and DBP (pooled WMD −1.7 mmHg [95% CI, −2.6 to −0.8] and −1.2 mmHg [95% CI, −2.0 to −0.4], respectively), weight (pooled WMD −1.2 kg [95% CI, −1.6 to −0.7]), and BMI (pooled WMD −0.54 kg/m^2^ [95% CI, −0.76 to −0.33]).; Medications: most trials found no statistically significant association between hypoglycemic agents and changes in blood pressure or lipids,^¶¶^ but found reduction in weight and BMI^##^ (except TZDs were associated with weight gain: pooled WMD 1.9 kg [95% CI, 0.8 to 3.1]). | Lifestyle: reasonably consistent; precise; Hypoglycemic medications: inconsistent or consistency unknown (depending on the medication); imprecise | Good: 5; Fair: 33 | Outcomes were often among many secondary outcomes and not the primary focus of trials; Substantial or considerable statistical heterogeneity in some meta-analyses for weight, BMI, and lipids; reporting bias not detected | Lifestyle: High for benefit^***^; Medications: Low for no benefit for blood pressure and lipids; moderate for weight loss with metformin and weight gain with TZDs | Asymptomatic adults age 40s to 60s years; most trials evaluated high-contact lifestyle interventions; mean baseline BMI ranged from 24 to 39 kg/m^2^ (and was >30 in most)

* Comprising 7,380 participants surveyed from all 5 control practices and 10 intervention practices in ADDITION-Cambridge (although the number responding for any given timepoint and outcome measure ranged from 2,667 to 3,654), 1,594 from Ely (1442 without and 152 with diabetes), and 354 from the ADDITION-Cambridge pilot.

† Including labeling, harms from false-positive results, burden, inconvenience, or unnecessary testing and treatment.

‡ The Finnish DPP (n=505) found no statistically significant difference between groups for all-cause mortality (2.2 vs. 3.8 deaths per 1,000 person-years; HR, 0.57 [ 95% CI, 0.21 to 1.58]) or composite CVD events (incident fatal and nonfatal acute coronary events, coronary heart disease, stroke, and hypertensive disease) (22.9 vs. 22.0 events per 1,000 person-years; HR, 1.04 [95% CI, 0.72 to 1.51]) over 10 years of followup.^47^

§ Da Qing trial found no significant difference between lifestyle groups and control for all-cause mortality (25.0% vs. 29.3%; HR, 0.96 [95% CI, 0.65 to 1.41]) or CVD-related mortality (12% vs. 17%; HR, 0.83 [95% CI, 0.48 to 1.40]) at 20 years, but rates were significantly lower in the combined intervention group at 23 years for all-cause mortality (28.1% vs. 38.4%; HR, 0.71 [95% CI, 0.51 to 0.99]) and CVD-related mortality (11.9% vs. 19.6%; HR, 0.59 [95% CI, 0.36 to 0.96]).

‖ Unclear randomization and allocation concealment methods; baseline differences for smoking that bias results in favor of intervention.

¶ Three of the trials were related to the U.K. Prospective Diabetes Study (UKPDS), which was a randomized multicenter trial that ran for 20 years (from 1977 to 1997) in 23 sites across the United Kingdom.

# Tighter control of BP vs. less tight control (<150/85 vs. <180/105) decreased the risk of diabetes-related mortality (RR, 0.68 [95% CI, 0.49-0.94]) and stroke (RR, 0.56 [95% CI, 0.35–0.89]) at 9 years followup but the benefits were not maintained over longer term followup.

** Single study for each intervention and outcome, with most evidence of benefit coming from UKPDS trials.

†† Estimated number needed to treat (NNT) of 9 over 15 years.

‡‡ Estimated NNTs were 13 over 3 years and 8 over 15 years for metformin.

§§ Downgrading for imprecision and inconsistency for TZDs and alpha glucosidase inhibitors and for risk of bias for alpha glucosidase inhibitors.

‖‖ Unclear randomization and allocation concealment methods; baseline differences for smoking that bias results in favor of intervention.

¶¶ For some medications (rosiglitazone, acarbose) a single trial reported a statistically significant reduction in blood pressure, but the finding has not been replicated.

## Trials reporting reduction in weight or BMI assessed metformin, acarbose, or liraglutide.

*** Presence of dose response increased the strength of evidence for some outcomes (i.e., greater improvement with high contact interventions).

Abbreviations: ADDITION=Anglo-Danish-Dutch Study of Intensive Treatment In People with Screen Detected Diabetes in Primary Care; AGI=alpha glucosidase inhibitor; BMI=body mass index; BP=blood pressure; CI=confidence interval; CVD=cardiovascular disease; DBP=systolic blood pressure; DM=diabetes mellitus; G=group; HR=hazard ratio; k=number; KQ=key question; n=number; NA=not applicable; NNT=number needed to treat; NR=not reported; OGTT=oral glucose tolerance test; QOL=quality of life; RCT=randomized, controlled trial; RR=relative risk; SBP=systolic blood pressure; STAI=State-Trait Anxiety Inventory; TZD=thiazolidinedione; U.K.=United Kingdom; UKPDS=United Kingdom Prospective Diabetes Study; U.S.=United States; WMD=weighted mean difference.

### Evidence for Benefit and Harms of Screening

For benefits of screening, two trials (ADDITION-Cambridge and Ely; 25,120 total participants) evaluated invitations to screening for diabetes and found no significant difference between screening and control groups for all-cause or cause-specific mortality at 10 years or self-reported CVD events or quality of life at 7 through 13 years. The data for outcomes other than mortality were limited, because data were missing for most participants, and the duration of followup in both trials may have been too short to detect benefits for health outcomes. Neither trial assessed screening for prediabetes and neither assessed initial screening with A1c or fasting glucose. For harms of screening, no included studies reported on labeling, harms from false-positive results, burden, inconvenience, or unnecessary testing and treatment. The two included trials reported no significant differences between screening and control groups for anxiety, depression, worry, or self-reported health, but one reported short-term increases in anxiety (at 6 weeks) among persons screened and diagnosed with diabetes mellitus versus those not diagnosed with diabetes mellitus.

Compared with the prior evidence review for the USPSTF, one of the included articles is new in this update,^36^ and one included in the prior report for harms of screening has been added to KQ 1 in this update (because it reported some data on health outcomes).^39^ The former found no significant difference between screening and control groups in cardiovascular morbidity (the proportion reporting heart attack or stroke), self-rated functional status, quality of life, and a variety of health behaviors after 7 years in ADDITION-Cambridge.^36^ The latter found no significant difference between screening and control groups in self-reported myocardial infarction or stroke, symptoms of ischemic heart disease, or quality of life in the Ely study for the subgroup of participants not diagnosed with diabetes.^39^

### Benefits of Interventions for Screen-Detected or Recently Diagnosed Diabetes

For screen-detected diabetes, one trial (ADDITION-Europe, 3,057 participants) evaluated an intensive multifactorial intervention aimed at controlling glucose, blood pressure, and cholesterol and found no difference over 5 to 10 years in the risk of all-cause mortality, cardiovascular-related mortality, cardiovascular events, or other health outcomes between intervention and routine care groups. Followup may have been too short to detect benefits for health outcomes and results were imprecise. For recently diagnosed (not screen-detected) diabetes, the UKPDS found that long-term health outcomes (all-cause mortality, diabetes-related mortality, and myocardial infarction) were improved with intensive glucose control with sulfonylureas or insulin over 20 years (10-year post-trial assessment) but not at shorter followups. And, for overweight people, intensive glucose control with metformin decreased all-cause mortality, diabetes-related mortality, and myocardial infarction at the 10-year followup, and benefits were maintained longer term.

Regarding applicability, it is uncertain whether results from trials of people with recently diagnosed diabetes are applicable to those with screen-detected diabetes. Recently diagnosed diabetes was generally clinically detected (e.g., because of symptoms) and may represent a different subset of the diabetes spectrum, possibly with greater condition severity. Further, the evidence of benefits for people with recently diagnosed (not screen-detected) diabetes comes primarily from the UKPDS, conducted among predominantly white participants from 1977 through 1997 when routine care for cardiovascular disease prevention would not have included treatments now considered to be current standard medical therapy (e.g., statins, lower blood pressure targets). The comparison used in the hypertension in diabetes study embedded in UKPDS exemplifies differences from current standard therapy because it compared tighter control of blood pressure by targeting less than 150/85 versus less tight control targeting less than 180/105.

### Benefits of Interventions for Prediabetes

For prediabetes interventions, most trials had insufficient duration of followup for long-term health outcomes, reported few events, and found no differences between groups. One trial of a 6-year lifestyle intervention for people with IGT conducted in China (Da Qing, n=576) reported lower all-cause mortality and CVD-related mortality at 23 years and at 30 years but not at earlier followup. The trial was limited by at least medium risk of bias because of unclear randomization and allocation concealment methods and baseline differences likely to bias results in favor of the intervention. The sample size was relatively small, and the original trial was designed to assess diabetes incidence and not long-term health outcomes. Regarding applicability, the trial began in 1986 when (like UKPDS) routine care for cardiovascular disease prevention would not have included treatments now considered to be current standard medical therapy. Participants had IGT and mean baseline BMI was 25.7 kg/m^2^; applicability to other categories of prediabetes, U.S. populations, and those in different BMI categories is uncertain.

Meta-analyses found that lifestyle interventions for obese or overweight people with prediabetes were associated with a reduction in the incidence of diabetes in trials ranging from 1 year of followup to 30 years of followup (including 13 trials with at least 3 years of followup). Using the control group event rate from DPPOS, it was estimated that the number of obese or overweight people with prediabetes needed to treat to prevent one person from developing diabetes over 15 years was 9. Lifestyle interventions were also associated with reduced blood pressure (by about 1.7/1.2 mmHg), weight (by 1.2 kg), and BMI (by 0.54 kg/m^2^). The clinical significance of these small mean reductions is somewhat uncertain. For blood pressure, for example, some guidelines suggest that reductions of 2 to 3 mmHg could result in significant improvement in cardiovascular outcomes.^129^

Regarding applicability, the findings are applicable to overweight and obese adults, and most trials evaluated high-contact interventions (>360 minutes). For example, the intensive lifestyle modification program evaluated in the DPP comprised a 16-lesson curriculum covering diet, exercise, and behavior modification that was taught one-on-one by case managers. The goals of the lifestyle intervention were to achieve and maintain at least a 7 percent weight reduction through a low-calorie, low-fat diet, and moderate intensity physical activity for at least 150 minutes per week.

For medications, metformin, TZDs, and AGIs were associated with a reduction in diabetes incidence. Most trials of medications found no significant association between hypoglycemic agents and changes in blood pressure or lipids. The evidence for TZDs and AGIs was limited by imprecision, inconsistency, and risk of bias, but evidence for metformin was consistent, precise, and generally assessed as good quality. Nevertheless, head-to-head trial data demonstrate that lifestyle interventions are superior to metformin. The DPP compared an intensive lifestyle modification program with metformin and placebo, finding a greater reduction in diabetes incidence over about 3 years with a lifestyle program than with metformin, as compared with placebo (58% vs. 31% reduction in diabetes incidence).^66^ The authors estimated that about seven people would need to be treated with the lifestyle intervention or about 14 with metformin to prevent one case of diabetes over about 3 years.^66^ Longer followup over a mean of 15 years reported by the DPPOS also found greater reduction for the lifestyle program than for metformin, although it found a declining between-group difference (27% vs. 18% reduction in diabetes incidence).^53^

## Limitations

This review has limitations. The limitations of the included studies are discussed above in Results and Discussion. Here we focus on limitations of this review. We excluded non-English language articles. For studies of recently diagnosed diabetes, we excluded studies of persons who had diabetes for more than 1 year or with more advanced diabetes, aiming to identify the studies with good applicability to a screen-detected population. This review did not evaluate studies of weight loss medications or bariatric surgery to treat diabetes. FDA has approved one short-term (phentermine) and several long-term medications or medication combinations (orlistat, lorcaserin, phentermine/topiramate, naltrexone/bupropion, and liraglutide) for weight loss. Except for liraglutide, none of these medications is approved to treat diabetes. Instead, FDA has approved these weight-loss medications for individuals with a BMI greater than 27 kg/m^2^ with one or more obesity-related comorbid conditions, including type 2 diabetes, or those with a BMI greater than 30.^130^ NICE recommends orlistat, along with a low-fat diet, to prevent the onset of diabetes among individuals at high risk for developing diabetes who are unable to achieve weight loss through lifestyle changes.^21^

## Future Research Needs

Screening trials of sufficient duration and sample size that focus on health outcomes (e.g., mortality, CVD events) are needed, as are studies on potential harms of screening such as labeling, harms from false-positive results, burden, inconvenience, or unnecessary testing and treatment. Neither of the existing screening trials assessed screening for prediabetes, and neither assessed initial screening with A1c or fasting glucose, tests that might be more likely used in the United States if screening is performed. Longer followup of participants from trials is needed. For example, longer followup of participants with screen-detected diabetes from the ADDITION-Europe trial and followup for more than 20 years from trials evaluating lifestyle interventions for prediabetes (to replicate or refute the Da Qing results) would be helpful. Some of the key evidence has uncertain applicability to current U.S. adult populations (e.g., evidence from China or the United Kingdom from trials beginning 30 to 40 years ago), and trials conducted in the United States would be informative. For example, the prevalence of undiagnosed diabetes in U.S. adults might be higher (given the higher prevalence of obesity).

## Conclusion

Trials of screening for diabetes found no mortality benefit at 10 years but had insufficient data to assess other health outcomes. Evidence on harms of screening was scant. For people with screen-detected diabetes, one trial found no improvement in health outcomes over 5 to 10 years. For people with recently diagnosed (not screen-detected) diabetes, interventions improved health outcomes over 10 to 20 years. For obese or overweight people with prediabetes, interventions were associated with reduced incidence of diabetes and improvement in other intermediate outcomes, and limited evidence suggests that very high-contact lifestyle interventions improve health outcomes after more than 20 years.