# Chapter 3 Results

## Literature Search

We identified 9,349 unique records and assessed 2,997 full-text articles for eligibility (Figure 2). We excluded 2,908 studies for various reasons, detailed in Appendix C, and included 89 publications. Details of quality assessments of included studies and studies excluded because of poor quality are in Appendix D Tables 1 through 5.

Figure 2 Summary of Evidence Search and Selection

Note: The sum of the number of articles per KQ exceeds the total number of articles because some articles were applicable to multiple KQs.

Abbreviations: ICTRP=International Clinical Trials Registry Platform; KQ=key question; USPSTF=U.S. Preventive Services Task Force; WHO=World Health Organization.

Figure 2 is a flow diagram that documents the search and selection of articles. There were 9,214 unique records identified by searching PubMed (n=5,875), Cochrane Library (n=2,472), Clinicaltrials.gov (n=685), and WHO ICTRP (n=182). In addition, 135 records were identified from the 2015 USPSTF Screening for Abnormal Glucose and Type 2 Diabetes Mellitus Systematic Review (n=111), the 2014 Behavioral Counseling to Promote a Healthy Lifestyle for Cardiovascular Disease Prevention in Persons With Cardiovascular Risk Factors Systematic Review (n=5), and handsearching (n=19). In total, 9,349 titles and abstracts were screened for potential inclusion. Of these, 2,997 were deemed appropriate for full-text review to determine eligibility. After full-text review, 2,908 were excluded: 9 for wrong language/non-English; 1,005 for ineligible population; 3 for ineligible screening; 150 for ineligible treatment; 356 for ineligible comparison; 541 for ineligible outcome(s); 20 for ineligible setting; 738 for ineligible study design; 1 for ineligible country; 62 for being abstracts only; 22 for poor quality; and 1 for having redundant outcomes. Eighty-nine articles met inclusion criteria. Five articles were included for Key Question 1. Five articles were included for Key Question 2. Zero articles were included for Key Question 3. Sixty-four articles were included for Key Question 4. Eight articles were included for Key Question 5. Forty-four articles were included for Key Question 6. Fifty-six articles were included for Key Question 7. Seventeen articles were included for Key Question 8. Fifty-eight articles were included for Key Question 9.

## Results by Key Question

### KQ 1a Is There Direct Evidence That Screening for Type 2 Diabetes and Prediabetes in Asymptomatic Adults Improves Health Outcomes?

### KQ 1b Does the Effectiveness of Screening Differ for Subgroups Defined by Age, Sex, Race/Ethnicity, Socioeconomic Status, or BMI?

#### Characteristics of Included Trials

Two RCTs (described in 5 articles) conducted in the United Kingdom evaluated screening for type 2 diabetes: Anglo-Danish-Dutch Study of Intensive Treatment In People with Screen Detected Diabetes in Primary Care (ADDITION)-Cambridge (n=20,184 participants)^35,36^ and Ely (n=4,936 participants) (Table 3).^37–39^ This review found no trials that assessed screening for prediabetes or described identifying prediabetes, IGT, or IFG during screening. ADDITION-Cambridge was a cluster RCT of 33 general practices that evaluated a stepwise screening approach starting with the result of a random capillary blood glucose (if < 5.5 mmol/L [100 mg/dL] participants were determined to have no diabetes; if ≥5.5 mm/L, then additional tests were used to determine diabetes status), whereas the Ely study was a parallel group RCT at a single practice that evaluated screening every 5 years with an OGTT along with screening for CVD risk factors (cholesterol and blood pressure). Both trials relied on invitations to screening. ADDITION-Cambridge was a screening and intervention study that randomized practices 1:3:3 to no screening, screening invitations followed by intensive treatment of screen-detected diabetes (A1c target <7.0%, blood pressure target ≤135/85, and cholesterol targets, and low-dose aspirin use unless contraindicated), or screening followed by routine care of screen-detected diabetes; analyses combined the screening groups (comparing 5 control practices with 27 screening practices). The Ely study had no protocol for standard interventions for those with screen-detected diabetes (test results were provided to primary care providers to use as they deemed appropriate). The risk of bias for the Ely trial was rated as medium because of unclear methods of randomization, unclear allocation concealment, and baseline differences between groups.

Table 3 Characteristics of Included Trials Evaluating Screening for Type 2 Diabetes (KQ 1 and KQ 2)^*^

Author, Year; Trial Name | Design; Setting | Participants | Groups (No. Participants) | Followup | Age, Mean (SD or IQR), Years | No. (%) F | No. (%) Non-white | Diabetes Risk Score, Median (IQR) | BMI, Mean (kg/m^2^) | Prescribed Antihyper-tensive Medications, No. (%) | Quality
Eborall, 2007^42^; Paddison, 2011^43^; ADDITION-Cambridge | Substudy of an RCT involving 15 practices in the United Kingdom | Adults at high risk of having undiagnosed type 2 DM | G1: Invited for screening (6,416, 10 practices); G2: Non-Invited controls (964, 5 practices) | 12-15 months | G1: 57.6 (7.9); G2: 58.6 (7.8) | G1: 2,220 (34.6); G2: 343 (35.6) | NR | NR | G1: 30.5 (4.7); G2: 30.6 (4.9) | G1: 2,992 (46.6); G2: 472 (49.0) | Fair
Echouffo-Tcheugui, 2015^36^; ADDITION-Cambridge, 7 year followup | Cluster RCT; 33 practices in the United Kingdom | In trial and completed 7-year followup questionnaire | G1: Invited to stepwise screening and returned questionnaires at 7 year followup (27 practices; 1,373); G2: No screening and returned questionnaires at 7-year followup (5 practices; 572) | 7 years | Median; G1: 60 (54-65); G2: 60 (54-65) | G1: 534 (38.9); G2: 212 (37.1) | NR (1) | 0.36 (0.25-0.52) vs. 0.38 (0.25-0.56) | G1: 29.4 (27.7-32.3); G2: 29.6 (27.8-32.2) | 654 (47.6); 298 (52.1) | Fair
Rahman, 2012^38^,^†^; Ely | Subgroup analysis of an RCT; 1 general practice in the United Kingdom | Invited for screening in Phase 1 or Phase 2; diagnosed with DM | G1: Invited to screening in Phase 1 (1990-1999) and diagnosed with DM (116 invited; 92 attended health assessment); G2: Unscreened in Phase 1 and invited to screening in Phase 2 and diagnosed with DM (83 invited; 60 attended health assessment) | 12 years (Mean 11.6 years) | G1: 68.3 (7.0); G2: 66.4 (6.6) | G1: 31 (47.4); G2: 15 (45.8) | NR | NR | G1: 30.4 (SD 5.0); G2: 29.7 (SD 4.5) | G1: 46 (50.5); G2: 37 (59.7) | Fair
Rahman, 2012^39^,^‡^; Ely | Subgroup analysis of an RCT; 1 general practice in the United Kingdom | Invited for screening in Phase 1 or 2 and attended a health assessment; not diagnosed with DM | G1: Invited for screening in Phase 1 and not diagnosed with DM (1,696 invited; 731 attended health assessment); G2: Not initially invited to screening, but invited 10 years later, in Phase 2, and not diagnosed with DM (1,694 invited; 711 attended health assessment) | 13 years (mean 12.5 years) | G1: 63.5 (7.7); G2: 61.9 (7.0) | G1:423 (57.9); G2: 353 (49.6) | NR | NR | G1: 26.9 (SD 4.4); G2: 27.4 (SD 4.8) | G1: 230 (25.1); G2: 197 (25.1) | Fair
Simmons 2012^35^; ADDITION-Cambridge | Cluster RCT; 33 practices in the United Kingdom | High risk of diabetes (risk score ≥0.17) and without known DM | G1: Invited to screening with random capillary blood glucose and HbA1c^§^ (27 practices; 16,047 eligible, 15,089 invited); G1-a: Attended: 11,737, 78%; G1-b: Did not attend: 3,352, 22%; G2: No screening (5 practices; 4,137) | Median 9.6 years | G1: 58.2 (7.7); G2: 57.9 (7.8) | G1: 5,787 (36.1); G2: 1,496 (36.1) | NR (NR) | G1: 0.35 (0.24-0.52); G2: 0.34 (0.24-0.51) | G1: 30.5 (SD 4.6); G2: 30.6 (SD 4.6) | G1: 7,372 (45.9); G2: 1,853 (44.8) | Good
Simmons, 2011^37^; Ely | RCT; 1 general practice in the United Kingdom | Free of known diabetes | Phase 1 (1990-1999); G1: Invited to screening every 5 years with OGTT and for CVD risk (cholesterol, BP) (1,705); G1-a: Attended screening (1,157/1,705; 68%); G1-b: Did not attend (548/1,705; 32%); G2: No screening (3,231); Phase 2 (2000-2008) ^‖^; G1: Invited to screening; G1-a: Attended screening (714/1,577; 45%); G1-b: Did not attend (863/1,577; 55%); G2: No screening (1,425) | 10 years; 8 y | G1: 53 G2: 51 | G1: 936 (54.9); G2: 1,592 (49.3) | NR | NR | NR | NR | Fair
Park, 2008^41^; ADDITION pilot phase | RCT; 2 practices in the United Kingdom | Without known diabetes, high risk of having DM | G1: Invited to screening (116); G2: Not invited to screening (238) | Mean: 6 weeks | G1: 58.3 (7.3); G2: 58.9 (7.2) | G1: 40 (34.5); G2: 89 (37.4) | NR | NR | G1: 31.8 (4.5); G2: 31.3 (4.1) | G1: 42 (36.2); G2: 91 (38.2) | Fair

* None of the included studies reported baseline data for screened and unscreened groups for fasting plasma glucose, HbA1c, blood pressure, or smoking. The 12-year followup of the Ely study reported mean (SD) HbA1c for the subset of participants who were diagnosed with diabetes and attended a health assessment: for those invited to screening in Phase 1 versus those unscreened in Phase 1 and invited to screening in Phase 2 (7.0 [1.7] vs. 7.4 [1.6], p=0.22).^38^ The 13-year followup of the Ely study reported mean (SD) HbA1c for the subset of participants who were not diagnosed with diabetes and attended a health assessment between 2000-2003: for those invited to screening in Phase 1 versus those unscreened in Phase 1 and invited to screening in Phase 2 (5.4 [0.5] vs. 5.5 [0.7], p=0.002).^39^ It also reported mean (SD) systolic (132 [16] vs. 132 [17]) and diastolic (79 [10] vs. 79 [10]) blood pressure and the number (%) of current smokers at the 2000-2003 health assessment (97 [10.6] vs. 92 [11.7]).

† Data for participant characteristics (age, %F, etc.) are from the health assessment conducted in 2000-2003 (not from the time of enrollment/baseline of the trial).

‡ Data for participant characteristics (age, %F, etc.) are from the health assessment conducted in 2000-2003 (not from the time of enrollment/baseline of the trial).

§ After the random capillary blood glucose, participants were determined to have no diabetes if result was <5.5 mmol/L (100 mg/dL). If the random capillary blood glucose was 5.5 to 11.0 mmol/L (100 to 196 mg/dL), they went on to have a fasting capillary blood glucose test (if the result was <5.5 mmol/L they were determined to have no diabetes; if the fasting glucose was 5.5-6.0 [100-106 mg/dL] and capillary HbA1c of 6.1% or higher, they went on to have a standard 75 g OGTT; if the result was 6.1 [110 mg/dL] or higher, the went on to have a standard 75 g OGTT). If the initial random capillary blood glucose was 11.1 [200 mg/dL] or higher, participants went on to have a standard 75 g OGTT.

‖ Participants not invited to screening in Phase 1 were randomized to screening invitations vs. no invitations in Phase 2.

Abbreviations: ADDITION=Anglo-Danish-Dutch Study of Intensive Treatment In People with Screen Detected Diabetes in Primary Care; BMI=body mass index; BP=blood pressure; CVD=cardiovascular disease; DM=diabetes mellitus; F=female; G=group; IQR=interquartile range; HbA1c=hemoglobin A1c (or glycated hemoglobin); KQ=key question; No.=number; NR=not reported; OGTT=oral glucose tolerance test; RCT=randomized, controlled trial; SD=standard deviation; vs.=versus.

Participants in ADDITION-Cambridge were age 40 to 69 years without known diabetes and at high risk of diabetes (based on a risk score of ≥1.7 on a diabetes risk score that included age, gender, BMI, steroid and antihypertensive medication, family and smoking history),^40^ whereas those in the Ely study were age 40 to 65 years and required to be free from known diabetes (not selected based on risk). Mean age of participants ranged from 51 (Ely) to 58 (ADDITION-Cambridge), 36 percent (ADDITION-Cambridge) to 51 percent (Ely) were female, and neither study reported the percentage of nonwhite participants. Mean BMI was 30.5 in ADDITION-Cambridge and was not reported for the Ely study. The trials began screening in 1990 (Ely) and 2002 (ADDITION-Cambridge). Duration of followup ranged from 7 to 13 years for the outcomes reported.

In ADDITION-Cambridge, 78 percent of those invited were screened (11,737/15,089) and 466 of those (4% of those screened, 3% of those invited) were diagnosed with diabetes based on 1999 World Health Organization (WHO) criteria (number diagnosed with diabetes was not reported for the control group). In the initial 10-year phase of the Ely study, 68 percent of those invited were screened (1,157/1,705) and 116 of those (10% of those screened, 7% of those invited) were diagnosed with diabetes. Among a subset of participants who were diagnosed with diabetes and attended a health assessment after 12 years (n=152 persons), the Ely study reported that diabetes cases were identified 3.3 years earlier on average for those in the screening group (n=92) than in the control group (n=60).^38^

Both trials reported data on all-cause mortality, CVD mortality, other mortality, CVD events, and quality of life. For a subgroup of participants with diabetes, the Ely study reported some information related to nephropathy and peripheral neuropathy.^38^ Neither trial reported on amputations, skin ulcers, visual impairment, or periodontitis.

#### Mortality

Neither trial found a reduction in all-cause or type-specific mortality for screening compared with no screening over about 10 years of followup (all-cause mortality in ADDITION-Cambridge HR 1.06 [95% CI, 0.90 to 1.25]; in the Ely study unadjusted HR 0.96 [0.77 to 1.20] and adjusted HR 0.79 [0.63 to 1.00]) (Table 4).

Table 4 Main Results of Studies Evaluating Screening for Diabetes That Reported Health Outcomes (KQ 1)^*^

Author, Year; Trial Name; Diagnosis of DM, No. | Mortality; G1 vs. G2; HR (95% CI) | CVD Events; G1 vs. G2; OR, or RR, (95% CI) | Quality of Life; G1 vs. G2
Echouffo-Tcheugui, 2015^36^; ADDITION-Cambridge, 7-year followup; G1: 466; G2: NR | NR | 7 years; CVD events (MI or stroke), self-reported: 142 (12.4%) vs. 67 (13.5%), OR, 0.90 (0.71 to 1.15) | SF-8 physical health summary score,^†^ mean (SD): 47.8 (9.8) vs. 47.8 (10.3). Beta^‡^ −0.33 (95% CI, −1.80 to 1.14); SF-8 mental health summary score,^†^ mean (SD): 51.8 (8.6) vs. 52.2 (8.1). Beta^‡^ −0.38 (95% CI, −1.33 to 0.57); EQ-5D score,^†^ mean (SD): 0.87 (0.16) vs. 0.87 (0.15). Beta^‡^ 0.002 (95% CI, −0.02 to 0.02); EuroQol visual acuity score,^†^ mean (SD): 74.5 (16.5) vs. 73.7 (17.2). Beta^‡^ 0.80 (95% CI, −1.28 to 2.87)
Rahman, 2012^38^; Ely, diabetic subgroup; Total: 199; G1: 116 (108 screen detected); G2: 83 (26 screen detected). | G1: 0; G2: 0; Evaluation was limited to those diagnosed with diabetes who attended health assessment | Self-reported MI: 7/92 vs. 8/60, p=0.29; RR, 0.57 (0.22 to 1.49); Self-reported stroke: 3/92 vs. 5/60, p=0.19; RR, 0.39 (0.10 to 1.58); Clinical ischemic heart disease:^‖^ 18/92 vs. 8/60, p=0.32; ECG-confirmed ischemic heart disease:^¶^ 30/92 vs. 28/60, p=0.11; RR, 0.70 (0.47 to 1.04); Peripheral vascular disease:^#^ 5/92 vs. 2/60, p=0.55; RR, 1.63 (0.33 to 8.13) | Mean SF-36^§^ physical function score: 67.2 (SD, 29.4) vs. 69.6 (SD 30.7); p=0.64; Mean SF-36 mental health score: 77.8 (SD, 16.5) vs. 79.7 (SD, 16.1); p=0.47; Mean EQ-5D visual analog scale (95% CI): 78 (65 to 85) vs. 79.5 (60 to 88), p=0.68
Rahman, 2012^39^; Ely, nondiabetic subgroup; G1: 0; G2: 0 | G1: 0; G2: 0; Evaluation was limited to those not diagnosed with diabetes who attended health assessment | Self-reported MI: 28/731 vs. 29/711, p=0.9; Self-reported stroke: 13/731 vs. 12/711, p=0.7; Clinical ischemic heart disease:^‖^ 78/731 vs. 53/711, p=0.2 | Median (IQR) SF-36^**^ physical function score: 90 (75-95) vs. 90 (75-95); p=0.4; Median (IQR) SF-36 mental health score: 84 (68-92) vs. 84 (68-92); p=0.8; Mean EQ-5D visual analog scale (95% CI): 78.3 (77.2 to 79.4) vs. 77.7 (76.5 to 79.0), p=0.9
Simmons 2012^35^; ADDITION-Cambridge; G1: 466; G2: NR | 10 years; All-cause mortality: 1,532 vs. 377; 1.06 (0.90 to 1.25)^††^; Cardiovascular mortality: 482 vs. 124; 1.02 (0.75 to 1.38); Cancer mortality: 697 vs. 169; 1.08 (0.90 to 1.30); Other mortality: 353 vs. 84; 1.10 (0.87 to 1.39); Diabetes-related mortality: 75 vs. 16; 1.26 (0.75 to 2.10) | NR | NR
Simmons, 2011^37^; Ely; G1: 51, 26, and 31 in first, second, and third rounds of screening, respectively; G2: NR | Phase 1: 345 total deaths from 1991 to 1999, median 10-year followup (47,854 person-years); All-cause mortality: 116 vs. 229, 0.96 (0.77 to 1.20); adjusted^‡‡^ 0.79 (0.63 to 1.00)^§§^; Cancer-related mortality: 52 vs. 107; CVD mortality 41 vs. 74; other mortality 23 vs. 48; Phase 2: 291 total deaths from 2000 to 2008, median 8.1 y (23,144 person-years); All-cause mortality: 165 vs. 126, 1.20 (0.95 to 1.51); adjusted^‡‡^ 1.18 (0.93 to 1.51)^§§^; Cancer-related mortality 44 vs. 47; CVD mortality 68 vs. 43; other mortality 53 vs. 36 | NR | NR

* None of the included studies reported on amputations, skin ulcers, visual impairment, or periodontitis.

† SF-8 scale ranges from 0 to 100 for each summary score.

‡ Beta coefficients represent the mean difference between groups.

§ Medical Outcomes Study Short Form Health Survey, scale 0-100. Higher scores indicate better function.

‖ Based on Rose angina questionnaire score >3.

¶ Defined by Minnesota coding of ECG.

# Defined as ABPI <0.9, for which the article reports 90% sensitivity and specificity among in symptomatic disease. The article did not report whether any of these persons had symptoms of PVD.

** Medical Outcomes Study Short Form Health Survey, scale 0-100. Higher scores indicate better function.

†† Among G1 (the screening group), nonattenders had higher all-cause mortality than attenders: HR 2.01 (1.74 to 2.32) and were younger, more obese, more likely to be men, and less likely to be taking antihypertensive medications.

‡‡ Adjusted for age, sex, and deprivation (determined using the Townsend Index, which was calculated using postcodes to determine material deprivation based on four factors derived from the 1991 UK census: unemployment, overcrowding, car ownership, and home ownership).

§§ For phase 1, comparing those who attended screening vs. controls (G1-a vs. G2), the HR for all-cause mortality was 0.64 (0.47 to 0.86) and the adjusted HR was 0.54 (0.40 to 0.74). Comparing those who did not attend screening vs. controls (G1-b vs. G2), the HR for all-cause mortality was 1.68 (1.27 to 2.22) and the adjusted HR was 1.36 (1.01 to 1.82). For phase 2, comparing those who attended screening vs. controls (G1-a vs. G2), the HR for all-cause mortality was 0.46 (0.31 to 0.69) and the adjusted HR was 0.52 (0.35 to 0.78). Comparing those who did not attend screening vs. controls (G1-b vs. G2), the HR for all-cause mortality was 1.85 (1.45 to 2.36) and the adjusted HR 1.73 (1.34 to 2.24).

Abbreviations: ABPI=Ankle-brachial pressure index; ADDITION=Anglo-Danish-Dutch Study of Intensive Treatment In People with Screen Detected Diabetes in Primary Care; CI=confidence interval; CVD=cardiovascular disease; DM=diabetes mellitus; ECG=electrocardiogram; EQ-5D=EuroQol Research Foundation and LimeSurvey; G=group; HR=hazard ratio; IQR=interquartile range; KQ=key question; MI=myocardial infarction; No.=number; NR=not reported; OR=odds ratio; PVD=peripheral vascular disease; RR=relative risk; SD=standard deviation; SF-8=Short Form-8 questionnaire; SF-36=Short Form-36 questionnaire; U.K.=United Kingdom; vs.=versus.

#### Cardiovascular Events, Quality of Life, Nephropathy, and Neuropathy

Neither trial found statistically significant differences between screening and control groups for these outcomes, but data collection was limited to a minority of participants from the trials who completed followup surveys at 7 years (ADDITION-Cambridge) or attended a health assessment at 12 to 13 years (Ely), and results were imprecise (Table 4). A postal questionnaire sent to a random sample of participants in ADDITION-Cambridge (15% from the screening group and 40% from the control group) 7 years after randomization found no statistically significant differences between screening and control groups in the proportion reporting heart attack or stroke (OR 0.90 [95% CI, 0.71 to 1.15]), self-rated functional status, or quality of life (Table 4).^36^ Of 3,286 questionnaires mailed, 1,995 were returned (61% response rate; data provided for 10% of all ADDITION-Cambridge participants).^36^ For the Ely trial, two separate publications reported outcomes for those diagnosed with diabetes^38^ and those not diagnosed with diabetes^39^ who attended a health assessment. Together, the two publications provide results for less than a third of participants from the Ely trial. Neither publication reported any statistically significant differences between screening and control groups in self-reported heart attack or stroke, symptoms of ischemic heart disease, or quality of life (Table 4). Regarding nephropathy and neuropathy, for the subgroup of participants with diabetes who attended a health assessment at 12 years (n=152) one publication from the Ely trial reported no statistically significant difference between those in the screening and control groups for nephropathy (4/92 vs. 1/60, p=0.37) or peripheral neuropathy (39/92 vs. 32/60, p=0.47).^38^

### KQ 2a What Are the Harms of Screening for Type 2 Diabetes and Prediabetes in Asymptomatic Adults?

### KQ 2b Do the Harms of Screening Differ for Subgroups Defined by Age, Sex, Race/Ethnicity, Socioeconomic Status, or BMI?

#### Characteristics of Included Trials

Five articles that evaluated participants in the ADDITION-Cambridge pilot phase, ADDITION-Cambridge trial, or Ely trial were included (Table 3).^38,39,41–43^ The ADDITION-Cambridge and Ely trials were described in KQ 1. The ADDITION-Cambridge pilot (n=354 participants) was an RCT of two practices (that were not included in the subsequent ADDITION-Cambridge trial) in the United Kingdom to assess the feasibility of a diabetes screening program and the effects of invitation to diabetes screening on anxiety.^41^ Participants were randomized 2:1 to noninvited and invited groups. Those who attended screening underwent a stepwise screening process starting with a random capillary blood glucose. Participants were age 40 to 69 years without known diabetes and at high risk of diabetes (based on a risk score). Mean age was 59 years, 36 percent were female, and mean BMI was about 31 (all similar to the larger ADDITION-Cambridge trial). Duration of followup was 6 weeks. Of those invited, 82 percent were screened (95/116) and six of those were diagnosed with diabetes.

#### Results of Included Trials

All three trials reported some information on anxiety from screening, two reported on depression, two reported on self-reported health, and one reported on worry about diabetes (Table 5). No two studies used the same outcome measures at similar timepoints. None of the trials reported on labeling, harms from false-positive results, burden, inconvenience, or unnecessary testing and treatment. Overall, results of the three trials did not find clinically significant differences between the screening and control groups in measures of anxiety, depression, worry, or self-reported health, but the results suggest possible short-term increases in anxiety (at 6 weeks) among persons screened and diagnosed with diabetes compared with those screened and not diagnosed with diabetes.

Table 5 Results of Studies That Reported Harms of Screening for Diabetes (KQ 2)^*^

Author, Year; Trial Name | Anxiety | Depression | Other Adverse Events
Eborall, 2007; Paddison, 2011^42,43^; ADDITION-Cambridge substudy (15 practices) | Between group differences (95% CI) for G1 vs. G2; State Anxiety:^†^; Initial time point:^‡^ −0.53 (−2.60 to 1.54), p=0.62; 3-6 months: 1.51 (−0.17 to 3.20), p=0.10; 12-15 months: 0.57 (−1.11 to 2.24), p=0.52; HADS anxiety:^‖^; Initial time point: −0.46 (−0.99 to 0.07), p=0.12; 3-6 months: −0.12 (−0.55 to 0.32), p=0.61; 12-15 months: −0.01 (−0.47 to 0.45), p=0.98; G1 who screened positive for DM vs. G1 who screened negative; Met threshold for anxiety disorder (HADS anxiety score of 11 or higher) at 12-15 months:; 14.3% vs. 11.3%, p=NS^§^ | Between group differences (95% CI) for G1 vs. G2; HADS depression:^‖^; Initial time point: −0.37 (−0.93 to 0.18), p=0.21; 3-6 months: 0.01 (−0.51 to 0.54), p=0.96; 12-15 months: 0.22 (−0.31 to 0.74), p=0.44; G1 who screened positive for DM vs. G1 who screened negative; Met threshold for depressive disorder (HADS depression score of 11 or higher) at 12-15 months:; 6.4% vs. 5.5%, p=NS^§^ | Between group differences (95% CI) for G1 vs. G2; Self-reported health (scale range 1-5):; Initial time point: −0.02 (−0.18 to 0.14), p=0.81; 3-6 months: 0.02 (−0.13 to 0.18), p=0.78; 12-15 months: −0.03 (−0.20 to 0.13), p=0.70; Worry about diabetes:^¶^; Initial time point: 0.03 (−0.36 to 0.42), p=0.90; 3-6 months: −0.11 (−0.42 to 0.19), p=0.48; 12-15 months: −0.33 (−0.67 to 0.01), p=0.08
Park, 2008^41^; ADDITION-Cambridge (pilot phase) | STAI anxiety score (scale range 20-80; higher score indicates more anxiety), mean (SD); G1 vs. G2 after 6 weeks; 37.6 (12.2) vs. 34.1 (12.1); p=0.015; G1 diagnosed with DM (n=6) vs. G1 not diagnosed with DM: 46.7 vs. 37.0; p=0.031 | NR | Self-perceived health score (scale range 1-5; higher score indicates better perceived health), mean (SD), G1 vs. G2:; 2.97 (0.86) vs. 2.95 (0.87); p=0.82; Illness representation subscales: no between group difference for any measure
Rahman, 2012^38,39^; Ely | Prescribed anxiolytic drugs, n (%); Among those without DM, 13-year followup:; G1: 5 (0.5) vs. G2: 5 (0.6), p=0.8; Among those with DM, 12-year followup:; G1: 1 (1.1) vs. G2: 1 (1.6), p=0.78 | Prescribed antidepressants, n (%); Among those without DM, 13-year followup:; G1: 52 (5.7) vs. G2: 38 (4.8), p=0.4; Among those with DM, 12-year followup:; G1: 4 (4.4) vs. G2: 2 (3.2), p=0.71 | NR (self-reported MI, self-reported stroke, SF-36 and EQ-5D data are with the health outcomes, KQ 1)

* None of the included studies reported on harms from labeling, false-positive results, burden or inconvenience, or unnecessary testing or treatment.

† Scale range 20-80.

‡ Immediately after initial (random blood glucose) test for screening attenders, first contact for control participants.

§ Actual p value not reported but article noted that chi-square analysis showed no significant difference.

‖ Scale range 0-21.

¶ Scale range 6-24.

Abbreviations: ADDITION=Anglo-Danish-Dutch Study of Intensive Treatment In People with Screen Detected Diabetes in Primary Care; CI=confidence interval; DM=diabetes mellitus; EQ-5D=EuroQol Research Foundation and LimeSurvey; G=group; HADS=Hospital Anxiety and Depression Scale; KQ=key question; MI=myocardial infarction; n=number; NR=not reported; NS=not statistically significant; SD=standard deviation; SF-36=Short Form-36 questionnaire; STAI=Short-form Spielberger State Anxiety Inventory vs.=versus.

A substudy of the ADDITION-Cambridge trial surveyed participants from 10 of the screening practices and all five control practices (n=7,380) and found no differences between the screening and control groups in measures of anxiety, depression, worry about diabetes, or self-reported health immediately after screening, at 3 to 6 months, or at 12 to 15 months (Table 5). The study was limited by response rates on questionnaires, with missing data for many participants, especially among those invited to screening who did not attend screening. Specifically, response rates varied across timepoints and measures, from 37 percent to 54 percent for control group participants (n=964), from 34 percent to 81 percent for screening group participants who attended screening (n=4,370), and from 11 percent to 18 percent for those invited to screening who did not attend screening (n=2,046). The Ely trial found no differences between the screening and control groups in the proportion of participants taking antidepressant medications or taking anxiolytic medications, for both the subgroup of participants with diabetes (n=152) and the subgroup without diabetes (n=1442) at the 12- to 13-year followup (Table 5). Results from the Ely study, like those from ADDITION-Cambridge, were limited by missing data for many participants (e.g., of those without diabetes invited to attend a health assessment, 1442/3390 [43%] attended for outcome assessment). The ADDITION-Cambridge pilot (n=354) reported higher levels of anxiety at 6 weeks for those in the screening group than in the control group (mean State-Trait Anxiety Inventory [STAI] anxiety score 37.6 vs. 34.1; p=0.015). Although the difference between groups was statistically significant, the between-group difference of less than 4 (on STAI anxiety score) is of uncertain clinical significance (scale range 20 to 80, higher scores indicating more anxiety), and the total scores for both groups were below the suggested cut point for clinically significant symptoms (a cut point of 39 to 40 has been suggested for most persons, with some authors suggesting a higher cut point of 54 to 55 for older adults).^44–46^

Among persons screened in the ADDITION-Cambridge pilot, the six individuals diagnosed with diabetes after screening had higher levels of anxiety than those screened and not diagnosed with diabetes (STAI score: 46.7 vs. 37.0; p=0.031).

### KQ 3a Do Interventions for Screen-Detected Type 2 Diabetes and Prediabetes Provide an Incremental Benefit in Health Outcomes When Delivered at the Time of Detection Compared With Initiating Interventions Later, After Clinical Diagnosis?

### KQ 3b Does the Effectiveness of These Interventions Differ for Subgroups Defined by Age, Sex, Race/Ethnicity, Socioeconomic Status, or BMI?

We found no eligible studies that addressed this question.

### KQ 4a Do Interventions for Screen-Detected Type 2 Diabetes and Prediabetes Improve Health Outcomes Compared With No Intervention, Usual Care, or Interventions With Different Treatment Targets?

### KQ 4b Does the Effectiveness of These Interventions Differ for Subgroups Defined by Age, Sex, Race/Ethnicity, Socioeconomic Status, or BMI?

In summary, one cluster RCT (ADDITION-Europe, described in 8 articles) that evaluated interventions for individuals with screen-detected type 2 diabetes and 38 RCTs (described in 56 articles) that evaluated interventions for individuals with prediabetes were included. No new studies on interventions for screen-detected type 2 diabetes were identified that were published since the previous review for the USPSTF. Low strength of evidence from one cluster RCT (described in 8 articles) found no difference over about 5-years of followup between an intensive multifactorial intervention aimed at controlling glucose, blood pressure, and cholesterol and routine care in the risk of all-cause mortality, cardiovascular-related mortality, and the occurrence of a first cardiovascular event (myocardial infarction, stroke, revascularization or amputation) Differences remained non-significant at 10-years followup. There was also no difference between groups in the risk of outcomes related to chronic kidney disease, visual impairment, and neuropathy. All but one site (U.K.-Leicester) found no difference between groups across a range of quality of life outcomes.

For trials of interventions for people with prediabetes, the duration of followup in most trials was insufficient to assess for effects on mortality, CVD events, and other health outcomes. Most trials reporting mortality or CVD events over a followup duration of 6 years or less had few events with no difference between groups. In the two trials reporting outcomes beyond six years, one (the Finnish DPP) found no statistically significant difference for all-cause mortality (2.2 vs. 3.8 deaths per 1000 person years; HR, 0.57, 95% CI, 0.21 to 1.58) or composite CVD events (22.9 vs. 22.0 events per 1000 person years; HR, 1.04, 95% CI, 0.72 to 1.51) over 10 years of followup.^47^ The second trial (Da Qing) found lower all-cause mortality (28.1% vs. 38.4%; HR, 0.71 [95% CI, 0.51 to 0.99]) and CVD-related mortality (11.9% vs. 19.6%; HR, 0.59 [95% CI, 0.36 to 0.96]) for a 6-year combined lifestyle intervention group compared with controls at 23 years but not at earlier followups; 30-year followup was subsequently published and also reported lower mortality for those who received lifestyle intervention compared with controls. Five trials reporting quality of life found either no difference between groups,^48,49^ mixed results (improvements on some domains but not others),^50^ or small improvements in scores that are not likely clinically significant.^51,52^ The DPPOS study found no difference in an aggregate microvascular outcome (nephropathy, retinopathy, and neuropathy) at 15 years (placebo 12.4%, metformin 13.0%, intensive lifestyle 11.3%).^53^

#### Interventions for Screen-Detected Type 2 Diabetes

For screen-detected diabetes, the included publications all used data from the multicenter ADDITION-Europe that evaluated intensive multifactorial therapy for screen-detected type 2 diabetes compared with routine care (Table 6).^54–61^ Five publications (N=3,057) reported outcomes from across all three ADDITION-Europe countries (United Kingdom, Netherlands, and Denmark),^56,58–61^ two publications (N=498) reported outcomes for participants in the Netherlands (ADDITION-Netherlands),^54,55^ and one (N=1,161) reported outcomes for participants in Denmark (ADDITION-Denmark).^57^

Table 6 Characteristics of Included ADDITION-Europe Studies Evaluating Interventions for Screen-Detected Type 2 Diabetes (KQ 4)

Author, Year; Trial Name; Country | Group (No. Participants) | Duration of Followup, Years | Age, Mean (Range or SD), Years | No. (%) F | No. (%) Nonwhite | HbA1c; Mean (%)(SD)^*^ | BMI, Mean (kg/m^2^) | Mean (SD), SBP (mmHg); DBP (mmHg); No. (%) Smokers | Quality
Charles, 2011^57^; ADDITION-Denmark; Denmark | G1: Intensive multifactorial treatment using medication and promotion of healthy lifestyle^†^ (702); G2 Routine care: standard level of diabetes care according to Danish national recommendations (459) | Mean (SD); G1: 5.9 (1.6); G2: 5.8 (1.5) | G1: 59.6 (6.9); G2: 59.9 (6.8) | G1: 281 (40); G2: 190 (41) | NR | G1: 6.4 (6.0; 7.0); G2: 6.4 (6.0; 7.0) | G1: F: 31.5 (6.5); M: 30.4 (3.4); G2: F: 31.2 (6.0); M: 30.4 (4.4) | G1: 147.0 (19.1); G2: 149.8 (19.3); G1: 87.3 (10.6); G2: 88.3 (11.3); Daily; G1: 215 (31); G2: 134 (30); <Daily:; G1: 271 (39); G2: 169 (37) | Fair
Griffin, 2011^56^; Simmons, 2012^58^; van den Donk, 2013^59^; Simmons, 2016^60^; Griffin, 2019^61^; ADDITION-Europe; Denmark, U.K., the Netherlands | G1: Intensive multifactorial treatment with medications and healthy lifestyle education^†^ (1,678); G2: Routine care according to recommendations applicable to each center (1,379) | Mean followup 5.3 (±1.6) years in main trial; 9.6 (±2.99) in posttrial followup | G1: 60.3 (6.9); G2: 60.2 (6.8) | G1: 697 (41.5); G2: 589 (42.7) | G1: 68 (4.2); G2: 88 (6.6) | G1: 7.0 (1.6); G2: 7.0 (1.5) | G1: 31.6 (5.6); G2: 31.6 (5.6) | G1: 148.5 (22.1); G2: 149.8 (21.3); G1: 86.1 (11.1); G2: 86.5 (11.3); G1: 444 (27.0); G2: 375 (27.8) | Fair
van den Donk, 2010^55^; Janssen, 2009^54^; ADDITION-Netherlands; Netherlands | G1: 3-4 years of intensified multi-factorial treatment with medications and healthy lifestyle education^†^ (255); G2: routine care based on national guidelines (243) | 4.5 (3 for the SF-36 and the EQ-5D) | G1: 60.1 (5.4); G2: 59.9 (5.1) | G1:123 (48); G2:107 (44) | G1: 5 (2.0); G2: 3 (1.3) | G1: 7.3 (1.6); G2: 7.4 (1.7) | G1: 31.2 (5.1); G2: 30.4 (4.6) | G1: 166 (23); G2: 163 (23); G1: 90 (11); G2: 89 (10); G1: 67 (26.3); G2: 52 (21.4) | Fair

* Baseline fasting plasma glucose was not reported for ADDITION-Europe. It was only reported for ADDITION-Netherlands; for those participants, it was 8.0 Mmol/L (144 mg/dL).^54^

† Intensive Treatment Targets: HbA1c <7.0%; blood pressure ≤135/85 mmHg; total cholesterol <5.0 mmol/L (<193 mg/dL) in patients with no history of CVD; <4.5 mmol/L in patients with history of CVD.

Abbreviations: ADDITION=Anglo-Danish-Dutch Study of Intensive Treatment In People with Screen Detected Diabetes in Primary Care; BMI=body mass index; CVD=cardiovascular disease; DBP=diastolic blood pressure; EQ-5D=EuroQol-5D; F=female; G=group; HbA1c=hemoglobin A1c (or glycated hemoglobin); KQ=key question; M=male; No.=number; NR=not reported; SBP=systolic blood pressure; SD=standard deviation; SF-36=Short Form 36 questionnaire; U.K.=United Kingdom.

The intensive multifactorial intervention was guideline driven and included the use of medications and the promotion of healthy lifestyle to achieve the following targets: HbA1c ≤7.0 percent, blood pressure ≤135/85 mm Hg, cholesterol <5.0 mmol/L (<193 mg/dL) in patients with no history of CVD, and <4.5 mmol/L (<174 mg/dL) in patients with a history of CVD. Physicians and nurses received training in a stepwise treatment algorithm that included initiating insulin if HbA1c remained above 7.0 percent with oral medications, antihypertensives for blood pressure, 75 mg aspirin daily (unless contraindicated), and statins for cholesterol. Treatment targets were similar across centers and practices, but decisions related to choice of medications were made by the physicians and patients. Lifestyle education generally included small group or practice-based (one-on-one) educational meetings to discuss treatment targets, algorithms, and lifestyle advice. Participating practices were asked to provide the equivalent of up to three 10-minute consultations with a family physician and three 15-minute consultations with a nurse, per patient, per year for 3 years. Routine care was based on the national guidelines in each center. Population-based stepwise screening took place between April 2001 and December 2006 among individuals age 40 to 69 years (50 to 70 years in the Netherlands) without known diabetes. Screening programs varied by center and included a risk score assessment (the Cambridge diabetes risk score assessment, the Danish Diabetes Risk Score Questionnaire, and the Hoorn study Symptom Risk Questionnaire) followed by glucose testing or an invitation to attend an oral glucose tolerance test without prior risk assessment (Leicester U.K. center). Diabetes diagnosis was based on WHO’s 1999 criteria (FPG ≥7.0 mmol/L [≥126 mg/dL] 2-hour plasma glucose ≥11.1 mmol/L [≥200 mg/dL]) including the requirement for confirmatory followup testing. In ADDITION-Europe, the mean duration of followup was 5.3 years (range 4.5 to 6), mean age of participants was about 60 years, about 42 percent were female, participants were predominantly white (95%), mean baseline HbA1C was 7 percent (median 6.5), mean BMI was 31.5 kg/m^2^, and mean blood pressure was 148/86 mm Hg. One post hoc study reported results at the 10-year followup (5 years post-intervention).^61^

The primary outcome of ADDITION-Europe was a composite of first cardiovascular events, defined as cardiovascular death, myocardial infarction, stroke, revascularization, or amputation.^56^ ADDITION-Europe also reported on all-cause mortality, cardiovascular mortality, amputations, chronic kidney disease, retinopathy, neuropathy, and quality of life at 5 years;^56,58,60^ and a post hoc study reported on the primary outcomes at 10 years (mean followup duration of 9.61 years).^61^

For the subset of participants in ADDITION-Netherlands, quality of life outcomes at 1^54^ and 3 years were also reported.^55^ For the subset of participants in ADDITION-Denmark, neuropathy was also reported at 6 years.^57,60^ No study assessed skin ulcers or periodontitis.

##### Mortality and Cardiovascular Events

At a mean of 5.3 years of followup, ADDITION-Europe found no statistically significant difference in the risk of all-cause mortality (6.2% vs. 6.7%, HR, 0.91 [95% CI, 0.69 to 1.21]), cardiovascular mortality (1.5% vs. 1.6%, HR, 0.88 [95% CI, 0.51 to 1.51]), or first cardiovascular event (7.2% vs. 8.5%, respectively, HR, 0.83 [95% CI, 0.65 to 1.05]) between intensive multifactorial treatment (n=1,678) and routine care (n=1,377) (Table 7).^56^ A post hoc analysis at about the 10-year followup similarly found that differences remained nonsignificant for the primary composite outcome (HR, 0.87 [95% CI, 0.73 to 1.04]) and its components and for all-cause mortality (HR, 0.90 [95% CI, 0.76 to 1.07]).^61^ Results for all-cause mortality at a mean of 5.3 years varied across countries. In the United Kingdom, the risk of all-cause mortality was lower in the intensive treatment group than in the routine care group (HR, 0.59 [95% CI, 0.35 to 0.98], whereas there was no significant difference between groups in the Netherlands (HR, 0.85 [95% CI, 0.35 to 2.06] or in Denmark (HR, 1.15 [95% CI, 0.80 to 1.66]).

Table 7 Results for Mortality and Cardiovascular Events From Trials Evaluating Interventions for Screen-Detected Type 2 Diabetes (KQ 4)

First Author, Year; Trial Name | G1 (N); G2 (N) | Mortality; G1 vs. G2; HR (95% CI) | CVD Events; G1 vs. G2; HR (95% CI)
Griffin, 2011^56^; Simmons, 2012^58^; van den Donk, 2013^59^; Simmons, 2016^60^; Griffin, 2019^61^; ADDITION-Europe | G1: Intensive multifactorial treatment (1,678); G2: Routine care (1,379) | G1 vs. G2; Mean 5.3-year followup; All-cause mortality combined across countries; 104/1,678 (6.2%) vs. 92/1,377 (6.7%); HR (95% CI) 0.91 (0.69,1.21); All-cause mortality U.K.; HR (95% CI) 0.59 (0.35,0.98); All-cause mortality Denmark; HR (95% CI) 1.15 (0.80,1.66); All-cause mortality Netherlands; HR (95% CI) 0.85 (0.35,2.06); Cardiovascular-related death; 26/1,678 (1.5%) vs. 22/12,77 (1.6%); HR (95% CI) 0.88 (0.51,1.51); Cardiovascular-related death as first CV event; 26/121 (21%) vs. 22/117 (19%); HR (95% CI) 0.83 (0.64, 1.07); Cardiovascular-related death as second CV event; 5/33 (15%) vs. 3/38 (8%); HR (95% CI) 0.70 (0.43, 1.12); Mean 9.6-year followup; All-cause mortality combined across countries; 246/1,678 vs. 219/1,379; HR (95% CI) 0.90 (0.76, 1.07); Cardiovascular death; 60/1,678 (3.6%) vs. 47/1,379 (3.4%); HR (95% CI) 0.97 (0.69, 1.37) | G1 vs. G2; Mean 5.3-year followup; Composite of first cardiovascular event *; 121/1,678 (7.2%) vs. 117/1,377 (8.5%); HR (95% CI) 0.83 (0.65,1.05); P=0.12; Subgroups; Patients <60 years: HR (95% CI) 1.12 (0.70,1.79); Patients ≥60 years: HR (95% CI) 0.70 (0.52,0.95); P>0.1; Myocardial infarction; 29/1,678 (1.7%) vs. 32/1,377 (2.3%); HR (95% CI) 0.70 (0.41,1.21); Stroke; 22/1,678 (1.3%) vs. 19/1,377 (1.4%); HR (95% CI) 0.98 (0.57,1.71); Revascularization; 44/1,678 (2.6%) vs. 44/13,77 (3.2%); HR (95% CI) 0.79 (0.53,1.18); Risk of having one CV event per 1,000 person-years; HR (95% CI) 0.83 (0.64, 1.07); Risk of having two CV events per 1,000 person-years; HR (95% CI) 0.70 (0.43, 1.12); Risk of having any CVD event per 1,000 person-years; HR (95% CI) 0.77 (0.58, 1.02); Amputations with CV events; With 1^st^ CV event: G1 (0) G2 (0); with 2^nd^ CV event G1 (0) G2 (1); with 3^rd^ CV event G1 (1) G2 (0); Mean 9.6-year followup; Composite of first cardiovascular event *; 232/1,678 (13.8%) vs. 211/1,379 (15.3%); HR (95% CI) 0.87 (0.73, 1.04); p=0.14; Subgroups; Patients <60 years: HR (95% CI) 1.19 (0.86, 1.65); Patients ≥60 years: HR (95% CI) 0.74 (0.59, 0.93); p=0.046; Myocardial infarction; 48/1,678 (2.9%) vs. 48/1,379 (3.5%); HR (95% CI) 0.72 (0.48, 1.08); Stroke; 38/1,678 (2.3%) vs. 43/1,379 (3.1%); HR (95% CI) 0.74 (0.48, 1.16); Revascularization; 80/1,678 (4.8%) vs. 73/1,379 (5.3%); HR (95% CI) 0.87 (0.64, 1.17); Amputations; 6/1,678 (0.4%) vs. 0/1,379 (0%); HR (95% CI) NA

* Primary outcome: Any of cardiovascular death, myocardial Infarction, stroke, revascularization, and amputation.

Abbreviations: ADDITION=Anglo-Danish-Dutch Study of Intensive Treatment In People with Screen Detected Diabetes in Primary Care; CI=confidence interval; CV=cardiovascular; CVD=cardiovascular disease; G=group; HR=hazard ratio; KQ=key question; N=number; U.K.=United Kingdom.

##### Quality of Life, Nephropathy, Visual Impairment, and Neuropathy

Detailed description of the results for quality of life, nephropathy, retinopathy, and neuropathy are provided in Appendix E. In brief, ADDITION-Europe found no difference between groups in diabetes-specific or general quality of life measures, nephropathy (defined as microalbuminuria or macroalbuminuria), retinopathy (assessed using digital images), or peripheral neuropathy (Appendix E Tables 1, 2, and 3). For quality of life, one of the two U.K. sites (the U.K.-Leicester site) found improvement favoring the intensive treatment group (for the SF-36 physical component score, the EQ-VAS, and the ADDQoL) (Appendix E Table 2).^59^ None of the included publications reported on symptomatic chronic kidney disease, end-stage renal disease, requirement for dialysis, need for transplantation, vision changes, symptoms of retinopathy, or blindness.

##### Subgroups

In a predefined subgroup analysis, ADDITION-Europe reported a decreased risk of first composite cardiovascular event in people age 60 years or older (HR, 0.70 [95% CI, 0.52 to 0.95]) but not in people younger than 60 years (HR, 1.12 [95% CI, 0.70 to 1.79]), but the test for interaction between intervention and age was not statistically significant (p>0.1). A post hoc analysis found that the decreased risk of first composite cardiovascular event in people age 60 years or older was maintained at about the 10-year followup, and the test for interaction was statistically significant (p=0.046).^61^ It should be noted that following the initial 5-year intervention there were no attempts to maintain assigned study group treatments; therefore, observed differences at 10 years may reflect factors other than the study-group intervention. No effect of age or sex was found in outcomes related to the presence of albuminuria or retinopathy. The included studies did not provide subgroup results for race/ethnicity, socioeconomic status, or BMI.

#### Interventions for Prediabetes

Thirty-eight trials (described in 56 articles) assessing interventions for prediabetes reported on health outcomes (Appendix E Table 4).^47–53,62–110^ The majority (k=24) compared lifestyle interventions with controls (of these, three also included a separate pharmacologic intervention arm^68,77,83^) and 14 (described in 20 articles) compared a pharmacologic intervention with placebo.^52,90–95,97–109^ Thirty-seven studies were RCTs (4 of those were cluster RCTs^51,79,86,89^) and one was a non-randomized trial.^49^ Eight trials were set in the United States, and others (k=30) were set in various other countries, including Canada (k=1),^108^ the United Kingdom (k=5),^51,63,78,82,89^ other European countries (k=7, including Sweden,^74,76,99^ Denmark,^71^ Finland,^47^ the Netherlands,^104^ and Germany^48^), India (k=3),^83,105,106^ Japan (k=6),^73,84–86,97,98^ China (k=4),^75,79,100,109^ and multinational settings (k=4).^52,90,94,101^ Most studies enrolled populations with a mean or median age between 50 and 60 years; 6 studies enrolled younger populations (mean or median age ranging from 43 to 49 years),^52,77,83,86,88,105^ and 8 studies enrolled populations with a mean or median age ranging from 60 to 69 years.^49,51,74,75,89,97,100,101^ Two trials enrolled females only^77,88^ and four enrolled only males^73^ or less than 20 percent females.^49,86,105^ All other trials enrolled both males and females, and most enrolled an equal proportion of both. All studies enrolled adults with prediabetes; however, studies varied in terms of how prediabetes was defined and measured; five focusing on criteria for IFG only,^49,72,84,86,99^ 18 on IGT only,^73,74,76,78,79,82,83,85,87,89,90,93,97,98,104,105,108,109^ 10 on IFG and/or IGT,^48,51,63,66,75,88,94,100,101,106^ three on IFG and/or A1c,^65,71,77^ and two on IFG or IGT or A1c.^52,62^

Among studies assessing lifestyle interventions, most (19 of 24) included intervention components that focused on both diet/nutrition and physical activity,^48,51,62,63,65,66,72,73,75–78,82–88^ while three focused on physical activity alone^49,74,89^ and one compared three arms (diet, exercise, or diet plus exercise) with a control group.^79^ One RCT did not specify whether the focus of the intervention was diet, exercise, or both.^71^ In the 14 trials evaluating pharmacologic interventions, the following medications were compared with placebo or another control group, with or without a minimal intervention (e.g., written diabetes materials, general healthy lifestyle advice): metformin,^66,77,83,106^ pioglitazone,^93,105^ rosiglitazone,^95^ acarbose,^90,104^ voglibose,^98^ liraglutide,^52^ nateglinide,^101^ glimepiride,^100^ sitagliptin,^97^ a combination of metformin and rosiglitazone,^108^ and acarbose or metformin (depending on whether patients had IGT vs. IFG or IFG and IGT, respectively).^100^ Two studies also evaluated antihypertensives, including valsartan^102^ and ramipril.^94^

The primary outcome of most studies was to prevent the development of type 2 diabetes in participants with prediabetes. Eleven studies followed participants for 1 year or less;^48,49,62,65,71,74,75,77,78,89,97^ others usually had a followup duration ranging from 2 to 5 years for primary outcomes. Three included post-trial followup assessments that reported outcomes ranging from 10 to 30 years postrandomization. The DPP RCT enrolled participants in 1996 and compared an intensive lifestyle intervention or masked metformin with placebo over a mean followup duration of 3.2 years.^66^ All participants were invited to be followed in the DPPOS, and 88 percent (n=2,776) consented to enroll in DPPOS. Placebo was discontinued, and the metformin group received unmasked metformin; all groups were offered maintenance group lifestyle sessions to reinforce the basic lifestyle content. Participants who had originally been randomly assigned to the lifestyle intervention in DPP were offered supplementary group programs and individual lifestyle check-ins twice yearly.^53^ The DPPOS reported on incidence of microvascular outcomes and other risk factors for CVD but not all-cause mortality or CVD events. The Da Qing Diabetes Prevention Study randomized Chinese clinics in 1986 (33 primary care clinics, 577 participants) to a control or one of three lifestyle interventions (diet, exercise, or diet plus exercise).^79^ The active intervention occurred over 6 years; study participants were followed up to 23 years postrandomization to assess CVD events and mortality.^80,81^ In the 20-, 23-, and 30-year followup analyses, the three intervention groups were combined (n= 439) and compared with the control group (n=138). The Finnish Diabetes Prevention Study (DPS) (n=522) randomized participants enrolled from 1993 through 1998 into an intensive lifestyle intervention or control; the median intervention period was 4 years, and included followup 10 years postrandomization to assess mortality and CVD events.^47,87^

##### Mortality and Cardiovascular Events

Sixteen studies (described in 18 publications) reported on all-cause mortality (Appendix E Table 5);^47,49,52,67,71,74,80,81,83,84,94,98,99,101,104–106,110^ six of these also reported on CVD-related mortality^52,67,80,94,99,101^ and one reported on renal mortality.^101^ CVD events were reported in 16 studies (described in 18 publications) using heterogenous CVD outcome definitions (Appendix E Table 6).^47,49,52,62,67,78,80–83,86,91,93,94,101,105,108,110^ Few studies (k=6) reported on both mortality and CVD events,^47,49,67,80,83,105^ and only two (the Finnish DPS and Da Qing study) reported mortality and CVD events beyond 6 years of followup.^47,80^

Among studies reporting mortality and/or CVD events over a followup duration of 6 years or less, 14 reported on all cause-mortality; of these, 7 compared a lifestyle intervention to usual care and found no difference between groups (2 reported no deaths,^71,106^ 4 reported 2 or fewer deaths per arm,^49,74,83,84^ and 1 reported 0.10 to 0.20 deaths per 100 person-years across groups^67^), and 7 assessing pharmacologic interventions found low rates of all-cause mortality with no difference between groups.^52,94,98,99,101,104,105^ Five studies reported on disease-specific mortality over 3 to 3.7 years of followup, and all reported few CVD-related deaths with no differences between groups^52,67,94,99,101^ and one found no difference in renal mortality.^101^ Thirteen studies reporting on CVD events followed participants for 6 years or less, 12 found no difference between groups, and one trial (STOP-NIDDM) found benefit associated with acarbose.^90^ Most studies (k=11) reported few CVD events (0 to 5 events per group, or rates ranging from 0 to 2% per group) with no between-group differences.^49,52,62,78,82,83,86,93,96,105,108^ One trial (Nateglinide and Valsartan in Impaired Glucose Tolerance Outcomes Research [NAVIGATOR]) enrolled participants with prediabetes and established CVD and/or risk factors for CVD; over 6 years of followup, CVD event rates for some measures were relatively high in both groups (Appendix E Table 6), but there was no difference between groups for composite or individual CVD event rates.^101,102^ One study, STOP-NIDDM trial (n=1,429), found benefit in favor of acarbose among participants at relatively high risk of CVD.^90^ Eligibility criteria required participants to have prediabetes, high BMI (25 to 40), and no CVD events within 6 months of enrollment; however, 5 percent of enrolled participants had a history of CVD and 21 percent were taking a CVD-related medication (13% were current smokers, 51 percent had hypertension, and 58 percent has dyslipidemia).^90^ Over 3.3 years of followup, fewer participants in the acarbose group had any CVD event (composite outcome, including coronary heart disease, CVD death, congestive heart failure, cerebrovascular event, and peripheral vascular disease) than the placebo group (15 vs. 32 events, respectively; HR, 0.51[95% CI, 0.28 to 0.95]).^91^

Two studies reported on mortality and CVD events over a longer duration of followup (10 to 30 years). The Finnish DPS (n=505) found no statistically significant difference between groups for all-cause mortality (2.2 vs. 3.8 deaths per 1,000 person years; HR, 0.57 [95% CI, 0.21 to 1.58]) or composite CVD events (incident fatal and nonfatal acute coronary events, coronary heart disease, stroke, and hypertensive disease) (22.9 vs. 22.0 events per 1000 person years; HR, 1.04 [95% CI, 0.72 to 1.51]) over 10 years of followup.^47^ The Da Qing study found no significant difference between the combined intervention group and the control group for all-cause mortality (25.0% vs. 29.3%; HR, 0.96 [95% CI, 0.65 to 1.41]) or for CVD-related mortality (12% vs. 17%; HR, 0.83 [95% CI, 0.48 to 1.40]) at 20 years postrandomization.^80^ However, at 23 years, the combined intervention group was associated with a significantly lower all-cause mortality rate than the control group (28.1% vs. 38.4%; HR, 0.71 [95% CI, 0.51 to 0.99]) as well as lower CVD-related mortality (11.9% vs. 19.6%; HR, 0.59 [95% CI, 0.36 to 0.96]).^81^ Results at 30 years postrandomization were consistent with the 23-year results but were more precise, with a significantly lower all-cause mortality rate among the combined intervention group than the control group (45.7% vs. 56.3% [HR, 0.74 {95% CI, 0.61 to 0.89}]) as well as lower CVD-related mortality (29.6% vs. 22.0% [HR, 0.67 {95% CI, 0.48 to 0.94}]).^110^

##### Quality of Life

Five studies assessing interventions for prediabetes reported quality of life (Appendix E Table 7).^48–52^ Two found statistically significantly higher quality of life scores associated with the intervention group (but differences were below the minimal clinically important difference),^51,52^ one found mixed results (improvement on some quality of life domains but not others),^50^ and two found no difference between groups.^48,49^ In the three trials that found benefit, or mixed results, the difference in score changes between groups was small and below that considered to be a minimally important difference. The Let’s Prevent Diabetes trial (n=880) found a statistically significant greater change from baseline in the lifestyle intervention group (receiving a 6-hour structured group education session with 3-hour refresher sessions after 12 and 24 months) than the usual care group on the 15-dimensional quality of life scale at 3 years (+0.01; 95% CI, 0.001 to 0.02); the intervention group experienced a small improvement in scores, while the control group had a slight decline.^51^ The difference between groups (and change from baseline in the intervention group) is below the minimal clinically important change to determine improvement (+0.015) recommended by some.^111^ One trial assessing liraglutide (2,254 participants) found a significantly higher change from baseline score on the SF-36 physical component summary among the liraglutide group than placebo (+ 0.9; p=0.0156) and a similar difference between groups on the SF-36 mental component summary score that was not statistically significant (+0.8; p=0.08).^52^ The differences between groups was below the threshold considered to be a minimal clinically important difference by the DPP study authors (3% difference) and others.^112^ In the DPP study^50^ (n=3,234), summary scores worsened in all groups for the SF-6D and SF-36 PCS and MCS; the decline for SF-6D and PCS was lower in the intensive lifestyle intervention group than placebo or metformin groups but did not meet the minimally important difference of 3 percent (defined by authors based on the literature).^50^ For individual SF-36 domain scores, differences between the intensive lifestyle group and placebo reached the minimally important difference for general health (+3.2; p<0.01) and physical function (+3.6; p<0.01); there was no difference between metformin and placebo on any SF-36 component score.^50^ In the two trials that found no benefit, one found no difference between physical activity counseling and usual care groups in the change from baseline SF-36 general health domain score (p=0.92) or physical function score (p=0.09) at 1 year,^49^ and the other found no difference between lifestyle intervention (12 sessions on lifestyle modification) and control groups in the change from baseline score on the WHO-5 Well-being Index (1.4 vs. 0; p=0.101).^48^

##### Other Health Outcomes

Few studies reported other health outcomes associated with abnormal blood glucose (Appendix E Table 7). One study (the NAVIGATOR trial, n=9,306) randomized participants to valsartan (160 mg daily) or placebo and nateglinide (60 mg three times daily) and placebo.^103^ At 5 years, 0.1 percent (5 participants) in the valsartan and placebo groups developed end-stage renal disease (HR, 0.96 [95% CI, 0.28 to 3.31]), and few participants in any group (0.1% or less) experienced amputations with no differences between groups. No studies reported on visual impairment. In the open-label extension of the DPP trial (DPPOS 15-year followup), the prevalence of the aggregate microvascular outcome (nephropathy, retinopathy and neuropathy) was not significantly different between groups (placebo 12.4%, metformin 13.0%, intensive lifestyle 11.3%).^53^ Individual microvascular outcome rates were not reported separately by group. A post hoc analysis among participants whose most recent HbA1c was 6.5 percent or greater (n=607, approximately 26% of the DPPOS cohort) found lower rates of retinopathy (RR, 0.61 [95% CI, 0.37 to 1.01]) and neuropathy (RR, 0.38 [95% CI, 0.19 to 0.75]) for the intensive lifestyle group than placebo; there were no significant differences between the metformin and placebo groups.^53^

##### Subgroups

Two studies reporting health outcomes described results for eligible subgroups.^53,81^ In the Da Qing study, mortality rates were reported by sex at the 23- and 30-followup.^81,110^ Among women 23-years postrandomization, all-cause mortality (15% vs. 38.8% [HR 0.46 {95% CI, 0.24 to 0.87}]) and CVD mortality (6.0% vs. 17.0%; [HR 0.28 {95% CI, 0.11 vs. 0.71}]) were lower in the combined intervention group than in the control group. Among men, there was no significant difference between the combined intervention and control groups for all-cause mortality (39.6% vs. 45.6%[HR 0.97 {95% CI, 0.65 to 1.46}]) and for CVD mortality (17.0% vs. 21.5% [HR 0.91 {95% CI, 0.50 to 1.65}]). However, the test for interaction between sex and intervention was not statistically significant. At baseline, a higher proportion of men than women were smokers (61% vs. 16%). This pattern persisted at 30 years (for women, all-cause mortality in the intervention group compared with the control group: HR, 0.59 [95% CI, 0.38 to 0.91]; for men, HR, 0.85 [95% CI, 0.66 to 1.09]).^110^

In the DPPOS, rates of the aggregate microvascular outcome were reported for subgroups defined by age, sex, race, and ethnicity at 15 years postrandomization. There were no significant differences in treatment effects among subgroups defined by age at DPP enrollment. Sex-specific analyses found a significant interaction between sex and intervention, with benefit only in women. Among women (n=1,887), the lifestyle intervention was associated with a lower prevalence than the placebo group (8.7% vs. 11.0%; p<0.05) or the metformin group (8.7% vs. 11.2%; p<0.05); rates were similar among women in the metformin and placebo groups (11.2% vs. 11.0%).^53^ Among men, rates were similar for those in the placebo group (15.1%), metformin group (16.8%), and lifestyle intervention group (16.6%). No significant differences in treatment effects were found among groups defined by race or ethnicity. Among Hispanic Americans (n=426), the lifestyle intervention was associated with a lower prevalence than placebo (4.5% vs. 10.5%; p<0.05), and rates were similar among the metformin and placebo groups (10.7% vs. 10.5%), but the test for interaction between race or ethnicity and treatment was not significant.

### KQ 5a Do Interventions for Recently Diagnosed Type 2 Diabetes Improve Health Outcomes Compared With No Intervention, Usual Care, or Interventions With Different Treatment Targets?

### KQ 5b Does the Effectiveness of These Interventions Differ for Subgroups Defined by Age, Sex, Race/Ethnicity, Socioeconomic Status, or BMI?

In summary, moderate strength of evidence from five RCTs in people with recently diagnosed type 2 diabetes found no statistically significant difference in all-cause mortality, diabetes-related mortality, and cardiovascular outcomes between intensive glucose control with sulfonylureas or insulin and conventional care at 10 years or shorter followup. However, over longer-term followup (20 years after randomization) intensive glucose control with sulfonylureas or insulin decreased the risk for all-cause mortality, diabetes-related mortality, and myocardial infarction. Tighter control of blood pressure compared with less tight control (<150/85 vs. <180/105) resulted in a reduced risk of diabetes-related mortality and stroke after 9 years of followup, but there was no difference between groups at longer-term followup (10 years post-trial). Intensive glucose control with metformin compared with conventional care in overweight people reduced the risk of all-cause mortality, diabetes-related mortality, and myocardial infarction at both 10 and 20 years after randomization.

#### Characteristics of Included Trials

We included five RCTs (described in 8 articles) evaluating interventions for recently diagnosed type 2 diabetes (Table 8).^4,113–118^ Three were related to the UKPDS, which was a randomized multicenter trial that ran for 20 years (from 1977 to 1997) in 23 sites across the United Kingdom. The primary UKPDS (n=3,867) compared intensive blood-glucose control with sulphonylureas or insulin with conventional treatment in people with newly diagnosed type 2 diabetes.^4,114^ The hypertension in diabetes study embedded in the UKPDS (n=1,148) compared tight control of blood pressure with less tight control.^115,116^ The third included trial from the UKPDS (n=753) compared metformin in overweight individuals with conventional care.^119^ Another study, based in China (n=150), compared an intensive multifactorial intervention including the use of medications (metformin or glipizide followed by acarbose and insulin for glucose control, and the use of antihypertensives and statins) and healthy lifestyle advice (on diet, exercise, and smoking cessation) with conventional treatment.^118^ The fifth RCT (described in 2 articles) was conducted in the United Kingdom and examined the effectiveness of the Diabetes Education and Self Management for Ongoing and Newly Diagnosed (DESMOND) program for people with newly diagnosed type 2 diabetes (n=824).^113,117^

Table 8 Characteristics of Included Trials of Interventions for Individuals With Recently Diagnosed Type 2 Diabetes (KQ 5)

Author, Year; Trial Name; Country | Group (No. Participants) | Followup | Duration of Diabetes, Mean (Range or SD) | Age, Mean (Range or SD), Years | No. (%) F | No. (%) Nonwhite | HbA1C; Mean (%)(SD) | FPG Mean | BMI, Mean (kg/m^2^) | Mean (SD), SBP (mmHg); DBP (mmHg); No. (%) Smokers | Quality
Davies, 2008^113^; Khunti, 2012^117^; DESMOND; U.K. | G1: 6-hour group education session (delivered in 1-day or 2 half-days) focusing on lifestyle, food, physical activity and cardiovascular risk factors (437); G2: Usual care (including some form of access to diabetes education) (387) | 1 y | ≤12 weeks | G1: 59.0 (28-87); G2: 60.0 (29-87) | G1: 204 (47); G2: 168 (43) | G1: 39 (9); G2: 60 (15.5) | G1: 8.3 (2.2); G2: 7.9 (2.0) | NR | G1: 32.3 (6.1); G2: 32.4 (6.5) | G1: 141.1 (18.5); G2: 140.0 (16.6); G1: 82.4 (10.5); G2: 81.0 (10.5); G1: 57 (14); G2: 53 (16) | Fair
Yang, 2013^118^; China* | G1: Intensive multifactorial intervention including medications and healthy lifestyle, advice (n=75).; Targets: HbA1c <7%, FBG <7.0 mmol/L; BP 130/85; total cholesterol <4.66 mmol/L; G2: Conventional therapy (n=75) outpatient management without targets | 7 years | G1: 0.24 (.21) years; G2: 0.26 (0.22) years | G1: 49.5 (7.8); G2: 50.3 (7.2) | G1: 39 (52); G2: 35 (47) | NR | G1: 8.8 (1.6); G2: 8.6 (1.7) | Mmol/L; G1: 9.98 (2.81); G2: 9.95 (0.74) | G1: 24.8(2.1); G2: 23.3(1.9) | G1: 129.1(15.2); G2: 128.8 (11.3); G1: 79.8 (11.8); G2: 76.9 (6.4); G1: 24 (34); G2: 33 (48) | Fair
Holman, 2008^†^,^114^; UKPDS; U.K. | G1: Intensive therapy with sulfonylurea or insulin (2,729); G2: Intensive therapy with metformin (342); G3: Conventional therapy primarily with diet for normal weight (1,138); G4: Conventional therapy primarily with diet for overweight group (411) | 10-yr post-trial monitoring | Reported as newly diagnosed | G1: 63 (9); G2: 64 (9); G3 normal weight: 63 (9); G4 overweight: 64 (9) | G1: 870 (41.1); G2: 152 (54.5); G3 normal weight: 348 (39.5); G4 overweight: 167 (54.0) | G1: 401 (18.9); G2: 44 (15.8); G3 normal weight: 170 (19.3); G4 overweight: 47 (15.2) | Median (IQR); G1: 7.9 (6.8-9.2); G2: 8.4 (7.2-9.7); G3: 8.5 (7.3-9.7); G4 t: 8.9 (7.5-10.0); G1 V G3: p<0.001 | Mg/dl; G1: 161 (61); G2: 177 (64); G3: 178 (58); G4 : 182 (55); G1 vs. G3: p<0.001 | G1: 29.3 (5.5); G2: 31.7 (5.4); G3: 28.7 (5.6); G4: 32.2 (5.7); G1 vs. G3: p<0.005 | G1: 139 (20); G2: 141 (18); G3: 138 (21); G4 : 139 (22); G1: 77 (10); G2: 78 (10); G3: 77 (10); G4: 77 (10); NR | Good
Holman, 2008^115^; UKPDS, 2008^116^; Hypertension in diabetes Study, embedded in UKPDS^‡^ | G1: Tight BP control; BP target <150/85 mmHg, main treatment (758): ACE inhibitor, captopril (400); beta-blocker, atenolol (358); G2: Less-tight BP control, target <180/105 mmHg (without use of ACE inhibitors or beta-blockers) (390); 10-year, post-trial followup (n=884) | Median 8.4 | Mean years (IQR); G1: 2.7 (1.0-4.2); G2: 2.5 (1.0-4.4) | G1: 56.4 (8.1); G2: 56.5 (8.1) | G1: 348 (46); G2: 163 (42) | G1: 107 (14); G2: 46 (12) | G1: 6.9 (1.7); G2: 6.8 (1.5) | Median (IQR) mmol/L; G1: 7.4 (6.1-9.2); G2: 7.4 (6.2-9.8) | G1: 29.8 (5.5); G2: 29.3 (5.5) | G1: 159 (20); G2: 160 (22); G1: 94 (10); G2: 94 (9); Current smoker; G1: 171 (23); G2: 85 (22) | Good
UKPDS Group 1998^4^; UKPDS^†^; U.K. | G1: 23 centers: Intensive glucose control with sulphonylureas^§^ or insulin (2,729); G2: 1^st^ 15 centers: Intensive glucose control with chlorpropamide (100-500 mg/d) (619); G3: 1^st^ 15 centers: Intensive glucose control with glibenclamide (2.5-20 mg/d) (615); G4: 1^st^ 5 centers: Intensive blood glucose control with insulin (911); G5a: Conventional care vs. G1, diet alone (1,138); G5b: Conventional care vs. G2, G3, G4 diet alone (896) | Median 10 years | Reported as newly diagnosed | G1: 53.2 (8.6); G2: 54 (9); G3: 54 (8); G4: 54 (8); G5a: 53.4 (8.6); G5b: 54 (9) | G1: 1075 (39.3); G2: 260 (42.0); G3: 234 (38.0); G4: 346 (38.0); G5a: 433 (38.0); G5b: 341 (38.0) | G1: 519 (19); G2: 130 (21); G3: 98 (16); G4: 164 (18); G5a: 216 (19); G5b:152 (17) | G1: 7.09 (1.54); G2: 6.3 (1.4); G3: 6.3 (1.3); G4: 6.1 (1.1); G5a: 7.05 (1.42); G5b: 6.2 (1.2) | Mmol/L Median (IQR); G1: 8.1 (7.1-9.8); G2: 8.0 (7.1-9.7); G3: 8.0 (7.2-9.6); G4: 8.1 (7.1-9.9); G5a: 8.0 (7.1-9.6); G5b: 7.9 (7.1-9.4) | G1: 27.5 (5.1); G2: 27.0 (4.9); G3: 27.4 (5.0); G4: 27.0 (4.8); G5a: 27.8 (5.5); G5b: 27.5 (5.3) | G1: 135 (20); G2: 136 (19); G3: 136 (19); G4: 136 (20); G5a: 135 (19; G5b: 136 (19); G1: 83 (10); G2: 83 (10); G3: 83 (10); G4: 83 (11); G5a: 82 (10); G5b: 83 (10); Current; G1: 30%; G2: 31%; G2: 30%; G3: 30%; G5a: 31%; G5b: 32% | Good
UKPDS group, 1998^119^; UKPDS^†^ (Metformin for overweight substudy); U.K. | G1: Intensive blood glucose control with metformin (glucose target FPG <6 mmol/l) (342); G2: Conventional care with diet alone (411) | Median 10.7 years | Reported as newly diagnosed | G1: 53 (8); G2: 53 (9) | G1: 185 (54.1); G2: 218 (53.0) | G1: 51 (14.9); G2: 57 (13.9) | G1: 7.3 (1.5); G2: 7.1 (1.5) | G1: 8.1 (7.2-9.8); G2: 8.0 (7.1-9.3) | G1: 31.6 (4.8); G2: 31.8 (4.9) | G1: 140 (18); G2: 140 (18); G1: 85 (9); G2: 86 (10); Current; G1: 85 (25); G2: 103 (25) | Good

a Stepped approach to glucose medication treatment: metformin for patients with BMI≥24 kg/m^2^; glipizide for patients with BMI< BMI≥24 kg/m^2^ ; followed by a combination of these; followed by acarbose, followed by insulin. For BP control: Captopril followed by addition of calcium antagonist, followed by addition of diuretics or B-blockers Lipids: Statins or Chinese herb complex, aspirin.

† Unable to determine duration of diabetes for the UKPDS reported as all patients were newly diagnosed with type 2 diabetes.

‡ Included the hypertension in diabetes study (embedded in the UKPDS) because participants were newly diagnosed with diabetes at the time of entry into the UKPDS study (even though they had a mean duration of diabetes of 2.6 years at the time of randomization in the hypertension study).

§ Chlorpropamide, glibenclamide, or glipizide.

Abbreviations: ACE=angiotensin-converting enzyme; BMI=body mass index; BP=blood pressure; DBP=diastolic blood pressure; F=female; FBG=fasting blood glucose; FPG=fasting plasma glucose; G=group; HbA1c=hemoglobin A1c (or glycated hemoglobin); IQR=interquartile range; KQ=key question; No.=number; NR=not reported; SBP=systolic blood pressure; SD=standard deviation; U.K.=United Kingdom; UKPDS=United Kingdom Prospective Diabetes Study; vs.=versus.

The duration of interventions ranged from 6 hours to 10 years. The DESMOND program focused on lifestyle, food, physical activity, and cardiovascular risk factors with standard clinical management and was delivered over 6 hours (either in a 1-day single session or in 2 half-day sessions).^113,117^ Treatment duration in studies involving the use of medications ranged from 7 to 10 years. The intensive multifactorial treatment study based in China included 7 years of treatment.^118^ The UKPDS ran for 20 years with a median of 10 years of intensive treatment in the primary study,^4^ a median of 8.4 years in the hypertension for diabetes study (embedded in the UKPDS),^116^ and a median of 10.7 years in the UKPDS metformin substudy.^119^ Upon completion in 1997, all surviving individuals from the UKPDS (including patients from the hypertension and metformin studies) were entered into a 10-year post-trial monitoring study.^114,115^ For the intensive multifactorial treatment study conducted in China, lifestyle advice included guidance for proper diet (e.g., 60 to 70% of daily caloric intake from carbohydrates, grains, fruits, and vegetables together with monounsaturated fat), physical activity (e.g., ≥ three 30-minute sessions of light to moderate exercise per week), and reducing or quitting smoking.^118^ The glucose target for studies of intensive treatment was HbA1c <7%,^118^ fasting plasma glucose <7 mmol/l (126 mg/dL),^118^ or fasting plasma glucose <6 mmol/l (108 mg/dL).^4,119^ Blood pressure targets were 130/85 mmHg in the intensive multifactorial treatment study,^118^ <150/85 mmHg for more tightly controlled blood pressure, and <180/105 for less tightly controlled blood pressure in the hypertension for diabetes study,^116^ and the total cholesterol target in the intensive multifactorial study was <4.66 mmol/L (180 mg/dL).^118^ Conventional treatment was not regulated in the trial but involved no treatment targets and involved either ill-defined outpatient management,^118^ some form of access to diabetes education,^113,117^ or dietary advice every 3 months with the aim of maintaining near-normal bodyweight.^4,119^ Medications used varied across studies and often included a stepped approach to care with individuals progressing to additional treatments when targets were not met.

The mean age of participants ranged from 50 years to 60 years. From 39 to 53 percent of participants were female and participants were predominantly white (range 81% to 88%). Mean baseline HbA1c ranged from 6.6 percent to 8.7 percent, and fasting plasma glucose ranged from a median of 7.4 mmol/L (133 mg/dL) to a mean of 10 mmol/L (180 mg/dL). Mean baseline systolic/diastolic blood pressure ranged from 129/78 mm Hg to 160/94 mm Hg.

#### Mortality and Cardiovascular Events

Four studies (described in 7 articles) reported on all-cause mortality (Figure 3);^4,113–117,119^ three (described in 5 articles) reported on diabetes-related mortality (Figure 4),^4,114–116,119^ four (described in 6 articles) on myocardial infarction (Figure 5),^4,114–116,118,119^ and three (described in 5 articles) on stroke (Figure 5).^4,114–116,119^ Most studies found no statistically significant differences between intervention and control groups in all-cause mortality, diabetes-related mortality, myocardial infarction, and stroke over 1-, 3-, and 10-year followups (Figures 3, 4 and 5 and Appendix E Table 8). An exception to this were the 10-year followup results from the metformin for overweight individuals substudy of the UKPDS, which found a decreased risk of all-cause death (14.6% vs. 21.7%; RR, 0.64 [95% CI, 0.45 to 0.91]), diabetes-related death (8.2% vs. 13.4%; RR, 0.58 [95% CI, 0.37 to 0.91]), and myocardial infarction (11.4% vs. 17.8%; RR, 0.61 [95% CI, 0.41 to 0.89]) among overweight (>120% of ideal body weight) participants (n=342) receiving intensive blood glucose control with metformin compared with those receiving conventional treatment (n=411).^119^ Over the longer term (20 years followup), results from the 10-year post-trial monitoring of all surviving participants of the UKPDS trial (n=3,277 out of 4,209) found a decreased risk of all-cause mortality (43% vs. 47%; RR, 0.87 [95% CI, 0.79 to 0.96]), diabetes-related mortality (23% vs. 26%; RR, 0.83 [95% CI, 0.73 to 0.96]), and myocardial infarction (25% versus 28%; RR, 0.85 [95% CI, 0.74 to 0.97]) among those receiving intensive blood glucose control with sulphonylureas or insulin compared with those receiving conventional treatment (Figures 3, 4, and 5). For overweight (>120% of ideal body weight) participants (n=342) receiving intensive blood glucose control with metformin compared with those receiving conventional treatment (n=411), the decreased all-cause mortality risk observed at 10 years was maintained after a further 10-year post-trial monitoring period (44% vs. 53%; RR, 0.73 [95% CI, 0.59 to 0.89])^114^ (Figure 3). The longer-term benefits favoring intervention over control observed for mortality and myocardial infarction were not found for stroke (Figure 5).

Figure 3 All-Cause Mortality in Trials of Interventions for People With Recently Diagnosed Type 2 Diabetes (KQ 5)

* Group education in the DESMOND trial.

† BP control=Tighter blood pressure control (<150/85 vs. <180/105) in the hypertension in diabetes study embedded in UKPDS.

‡ Glucose control=Intensive therapy with sulfonylureas or insulin in UKPDS.

^§^ Weight control=Metformin for overweight substudy UKPDS group.

Abbreviations: BP=blood pressure; CI=confidence interval; DESMOND=Diabetes Education and Self Management for Ongoing and Newly Diagnosed; F/U=followup; KQ=key question; UKPDS=United Kingdom Prospective Diabetes Study; vs.=versus.

Figure 3 displays a forest plot reporting all-cause mortality in people with recently diagnosed Type 2 diabetes (KQ 5). Davies, 2003 reported 2 events in the group education intervention compared to 5 events in the control at 1-year followup (RR, 0.35 [95% CI 0.07 to 1.82]). Khunti, 2012 reported 15 deaths in the group education intervention compared to 11 events in the control at 3-year followup (RR, 1.21 [95% CI, 0.56 to 2.60]). Holman, 2008 reported 134 events in the BP control intervention compared to 83 events in the control at 9-year followup (RR, 0.82 [95% CI, 0.63 to 1.08]). UKPDS Group, 1998 reported 489 events in the Glucose control intervention compared to 213 events in the control at 10-year followup (RR, 0.94 [95% CI, 0.80 to 1.01]). UKPDS Group, 1998 reported 50 events in the weight control intervention compared to 89 events in the control at 10-year followup (RR, 0.64 [95% CI, 0.45 to 0.91]). Holman, 2008 reported 373 events in the BP control intervention compared to 211 events in the control at 10-year post-trial followup (RR, 0.89 [95% CI, 0.75 to 1.06]). Holman, 2008 reported 1,162 events in the glucose control intervention compared to 537 events in the control at 10-year post-trial followup (RR, 0.87 [95% CI, 0.79 to 0.96]). Holman, 2008 reported 152 events in the weight control intervention compared to 217 events in the control at 10-year post-trial followup (RR, 0.73 [95% CI, 0.59 to 0.89]).

Figure 4 Diabetes-Related Mortality in Trials of Interventions for People With Recently Diagnosed Type 2 Diabetes (KQ 5)

* BP control=Tighter blood pressure control (<150/85 vs. <180/105) in the hypertension in diabetes study embedded in UKPDS.

^†^ Glucose control=Intensive therapy with sulfonylureas or insulin in UKPDS.

^‡^ Weight control=Metformin for overweight substudy UKPDS group.

Abbreviations: BP=blood pressure; CI=confidence interval; F/U=followup; KQ=key question; UKPDS=United Kingdom Prospective Diabetes Study; vs.=versus.

Figure 4 displays a forest plot reporting diabetes-related mortality in people with recently diagnosed Type 2 diabetes (KQ 5). Holman, 2008 reported 82 events in the BP control intervention compared to 62 events in the control at 9-year followup (RR, 0.68 [95% CI, 0.49 to 0.94]). UKPDS Group, 1998 reported 285 events in the Glucose control intervention compared to 129 events in the control at 10-year followup (RR, 0.90 [95% CI, 0.73 to 1.11]). UKPDS Group, 1998 reported 28 events in the weight control intervention compared to 55 events in the control at 10-year followup (RR, 0.58 [95% CI, 0.37 to 0.91]). Holman, 2008 reported 203 events in the BP control intervention compared to 122 events in the control at 10-year post-trial follow up (RR, 0.84 [95% CI, 0.67 to 1.05]). Holman, 2008 reported 618 events in the glucose control intervention compared to 297 events in the control at 10-year post-trial followup (RR, 0.83 [95% CI, 0.73 to 0.96]). Holman, 2008 reported 81 events in the weight control intervention compared to 120 events in the control at 10-year post-trial followup (RR, 0.70 [95% CI, 0.53 to 0.92]).

Figure 5 Myocardial Infarction and Stroke Outcomes in Trials of Interventions for People With Recently Diagnosed Type 2 Diabetes (KQ 5)

* Multifactorial=Multifactorial intensive therapy.

^†^ BP control=Tighter blood pressure control (<150/85 vs. <180/105) in the hypertension in diabetes study embedded in UKPDS.

^‡^ Glucose control=Intensive therapy with sulfonylureas or insulin in UKPDS.

^§^ Weight control=Metformin for overweight substudy UKPDS group.

Abbreviations: BP=blood pressure; CI=confidence interval; F/U=followup; KQ=key question; UKPDS=United Kingdom Prospective Diabetes Study; vs.=versus.

Figure 5 displays a forest plot reporting myocardial infarction and stroke outcomes in people with recently diagnosed Type 2 diabetes (KQ 5). Yang, 2013 reported 1 myocardial infarction event in the multifactorial intervention compared to 1 myocardial infarction event in the control at 7-year followup (RR, 1.00 [95% CI 0.06 to 15.7]). Holman, 2008 reported 107 myocardial infarction events in the BP control intervention compared to 69 myocardial infarction events in the control at 9-year followup (RR, 0.79 [95% CI, 0.59 to 1.07]). UKPDS Group, 1998 reported 387 myocardial infarction events in the Glucose control intervention compared to 186 myocardial infarction events in the control at 10-year followup (RR, 0.84 [95% CI, 0.71 to 1.00]). UKPDS Group, 1998 reported 39 myocardial infarction events in the weight control intervention compared to 73 myocardial infarction events in the control at 10-year followup (RR, 0.61 [95% CI, 0.41 to 0.89]). Holman, 2008 reported 205 myocardial infarction events in the BP control intervention compared to 115 myocardial infarction events in the control at 10-year post-trial followup (RR, 0.90 [95% CI, 0.71 to 1.13]). Holman, 2008 reported 678 myocardial infarction events in the glucose control intervention compared to 319 myocardial infarction events in the control at 10-year post-trial followup (RR, 0.85 [95% CI, 0.74 to 0.97]). Holman, 2008 reported 81 myocardial infarction events in the weight control intervention compared to 126 myocardial infarction events in the control at 10-year post-trial followup (RR, 0.67 [95% CI, 0.51 to 0.89]). Holman, 2008 reported 38 stroke events in the BP control intervention compared to 34 stroke events in the control at 9-year followup (RR, 0.56 [95% CI, 0.35 to 0.89]). UKPDS Group, 1998 reported 148 stroke events in the Glucose control intervention compared to 55 stroke events in the control at 10-year followup (RR, 1.11 [95% CI, 0.81 to 1.51]). UKPDS Group, 1998 reported 12 stroke events in the weight control intervention compared to 23 stroke events in the control at 10-year followup (RR, 0.59 [95% CI, 0.29 to 1.18]). Holman, 2008 reported 90 stroke events in the BP control intervention compared to 58 stroke events in the control at 10-year post-trial followup (RR, 0.77 [95% CI, 0.55 to 1.07]). Holman, 2008 reported 260 stroke events in the glucose control intervention compared to 116 stroke events in the control at 10-year post-trial followup (RR, 0.91 [95% CI, 0.73 to 1.13]). Holman, 2008 reported 34 stroke events in the weight control intervention compared to 42 stroke events in the control at 10-year post-trial followup (RR, 0.80 [95% CI, 0.50 to 1.27]).

For blood pressure control, the hypertension for diabetes trial (embedded in the UKPDS study) found no statistically significant difference in the risk of all-cause mortality or myocardial infarction between participants receiving tighter blood pressure control (using mainly angiotensin-converting enzyme [ACE] inhibitors and beta blockers) (n=758) compared with those receiving less tight blood pressure control after 9 years of followup or at the post-trial followup (20 years after randomization) (Figures 3 and 5). However, the trial found a decreased risk of diabetes-related mortality (10.8% versus 15.9%; RR, 0.68 [95% CI, 0.49 to 0.94]) and stroke (5.0% vs. 8.7%; RR, 0.56 [95% CI, 0.35 to 0.89]) after 9 years of followup; differences between groups were not statistically significant at the 10-year post-trial followup for the 884 surviving participants (Figures 4 and 5).

One study reported on transient ischemic attack (Appendix E Table 8).^118^ At the 7-year followup, the small study conducted in China (n=150) found no difference in the risk of myocardial infarction (1.3% vs. 1.3%; RR, 1.0 [95% CI, 0.06 to 15.7]) or transient ischemic attack (RR, 2.0 [95% CI, 0.01 to 4.71]) among people with newly diagnosed type 2 diabetes receiving a multifactorial intensive intervention and those receiving conventional care.^118^

#### Quality of Life Outcomes

Only the DESMOND study (described in 2 articles) reported on quality of life outcomes.^113,117^ Measuring quality of life with the short version of the WHO’s quality of life instrument (WHOQOL-BREF) at 4, 8, and 12 months and at the 3-year followup, it found no differences between the intervention and control groups at any time point across six dimensions of quality of life (overall satisfaction, overall satisfaction with health, physical, psychological, social, and environmental) (Appendix E Table 9).

#### Chronic Kidney Disease

Two studies, both from the UKPDS, reported on outcomes related to chronic kidney disease, and neither found a statistically significant difference between intervention and control groups, although results were generally imprecise (Appendix E Table 10).^4,116^ At the 10-year followup, the UKPDS found no difference in the risk of renal failure (defined by dialysis or creatinine >250 μmol/L not related to any acute intercurrent illness) among people with newly diagnosed type 2 diabetes receiving intensive blood glucose control with sulfonylureas (chlorpropamide, glibenclamide, and glipizide) or with insulin (n=2,729) and those receiving conventional treatment (n=1,138) (0.6% vs. 0.8%; RR, 0.73 [95% CI, 0.25 to 2.14]).^4^ There was also no difference in the risk for renal failure for the comparison of each of the three medication groups (chlorpropamide, glibenclamide/glipizide, and insulin) with conventional care (Appendix E Table 10).^4^ After 9 years of followup, the hypertension for diabetes trial (embedded in the UKPDS) found no difference in the risk of renal failure among people with newly diagnosed type 2 diabetes receiving tight blood pressure control, using mainly ACE inhibitors and beta blockers (n=758) and those receiving less tight blood pressure control (n=390) (1.1% vs. 1.8%; RR, 0.53 [95% CI, 0.15 to 2.21]).^116^ The trial also found no statistically significant difference between groups in the risk of microalbuminuria (≥50 mg/l) (28.8% vs. 33.1%; RR, 0.77 [95% CI, 0.55 to 1.09]) or macroalbuminuria (≥300 mg/l) (3.2% vs. 5.7%; RR, 1.06 [95% CI, 0.42 to 2.67]).^116^

#### Visual Impairment

Three studies, all from the UKPDS, reported on a variety of clinical endpoints for visual impairment with mixed findings (Appendix E Table 10)^4,116,119^ At the 10-year followup, the UKPDS found a decreased risk of retinal photocoagulation among people with newly diagnosed type 2 diabetes receiving intensive blood glucose control with sulfonylureas (chlorpropamide, glibenclamide, and glipizide) or with insulin (n=2,729) and those receiving conventional treatment (n=1,138) (7.6% vs. 10.3%; RR, 0.71 [95% CI, 0.53 to 0.96]).^4^ There was no statistically significant difference in the risk for vitreous hemorrhage (0.7% vs. 0.88%; RR, 0.77 [95% CI, 0.28 to 2.11]), blindness in one eye (2.9% vs. 3.3%; RR, 0.84 [95% CI, 0.51 to 1.40]), or cataract extraction (5.5% vs. 7.0%, RR, 0.76 [95% CI, 0.53 to 1.08]) (Appendix E Table 10).^4^ At the 10-year followup, the metformin for overweight individuals substudy of the UKPDS found no difference in the risk of blindness in one eye among overweight (>120% of ideal body weight) participants (n=342) receiving intensive blood glucose control with metformin compared with those receiving conventional treatment (n=411) (3.5% vs. 3.2%; RR, 1.07 [95% CI, 0.38 to 2.99]). At a median of 7.5 years followup, the hypertension for diabetes trial (embedded in the UKPDS) found a decreased risk for progression to retinopathy (by ≥2 steps) among newly diagnosed type 2 diabetes patients receiving tight blood pressure control, using mainly ACE inhibitors and beta blockers (n=300) and those receiving less tight blood pressure control (n=152) (34.0% vs. 51.3%, respectively; RR, 0.66 [95% CI, 0.50 to 0.89]).^116^ The trial also found a decreased risk for deterioration in vision (defined as best vision in either eye deteriorating by three or more lines on an Early Detection of Diabetic Retinopathy Study chart) (10.2% vs. 19.4%; RR, 0.53 [95% CI, 0.30 to 0.93]).^116^

#### Amputations

Three studies, all from the UKPDS, reported on amputations (Appendix E Table 10) and found no statistically significant differences between the intervention and control groups, although results were generally imprecise.^4,116,119^ At the 10-year followup, the UKPDS found no difference in the risk of amputations among newly diagnosed type 2 diabetes patients receiving intensive blood glucose control with sulfonylureas (chlorpropamide, glibenclamide, and glipizide) or with insulin (n=2,729) and those receiving conventional treatment (n=1,138) (1.0% vs. 1.6%, respectively; RR, 0.61 [95% CI, 0.28 to 1.33]).^4^ At the 10-year followup, the metformin for overweight individuals substudy of the UKPDS found no difference in the risk of amputation among overweight (>120% of ideal body weight) participants (n=342) receiving intensive blood glucose control with metformin compared with those receiving conventional treatment (n=411) (1.8 % vs. 2.2%; RR, 0.74 [95% CI, 0.19 to 2.89]) Similarly, after 9 years of followup, the hypertension for diabetes trial (embedded in the UKPDS) found no difference in the risk of amputations among newly diagnosed type 2 diabetes patients receiving tight blood pressure control, using mainly ACE inhibitors and B-blockers (n=758) and those receiving less tight blood pressure control (n=390) (1.1% vs. 2.1%, respectively; RR, 0.51 [95% CI, 0.14 to 1.86]).^116^

#### Subgroups

The included studies did not provide results for subgroups defined by age, sex, race/ethnicity, or socioeconomic status. Results from the metformin for overweight people with newly diagnosed type 2 diabetes substudy of the UKPDS is described above. Overweight patients (n=753) were randomized to intensive glucose control with metformin or conventional care (i.e., care primarily with diet alone).^119^ Treatment began with 850 mg of metformin per day and was increased to a maximum dose of 2,550 mg per day with the aim of maintaining FPG below 6.0 mmol/L (108 mg/dL). Mean BMI was 31.5 kg/m^2^. Results were not stratified by BMI.

### KQ 6 What Are the Harms of Interventions for Prediabetes, Screen-Detected Type 2 Diabetes, or Recently Diagnosed Type 2 Diabetes?

#### Harms of Interventions for Screen-Detected or Recently Diagnosed Type 2 Diabetes

Overall, harms were sparsely reported, rare, and (when reported) not significantly different between intervention and control groups across trials. Four RCTs (described in 6 articles) reported on harms of interventions for screen-detected or recently diagnosed type 2 diabetes.^4,54,55,113,117,120^ None were specifically designed to investigate harms. Characteristics of three of the trials, already included in KQ 4 or KQ 5,^4,54,55,113,117^ are summarized in Tables 6 and 8. The fourth trial, not previously described, reported on harms related to saxagliptin (5 mg daily) as initial therapy in treatment-naïve adults with newly diagnosed type 2 diabetes.^120^ It was a 24-week double-blind placebo-controlled trial of 213 adults recruited from 12 centers across India. Of the four included RCTs, one (described in 2 articles), from the ADDITION-Netherlands trial (n=498), compared an intensive multifactorial intervention among screen-detected type 2 diabetes patients with usual care.^54,55^ The other three trials enrolled patients with recently diagnosed diabetes. One, the UKPDS trial (n=3,867), compared intensive blood-glucose control using sulphonylureas or insulin with conventional treatment,^4^ the DESMOND trial (n=824) compared a 6-hour structured group education program with usual care,^113,117^ and one RCT compared saxagliptin with placebo (n=213).^120^ Treatment duration ranged from 6 hours to 10 years. Three studies (5 articles) reported on withdrawals for any reason,^54,55,113,117,120^ two reported on treatment-related mortality,^4,120^ two on hypoglycemic events requiring medical attention,^4,120^ and one on general adverse events.^120^ Results are summarized in Appendix E Table 11.

##### Withdrawals

Across three trials (described in 5 articles) enrolling 1,535 participants^54,55,113,117,120^ there were a total of 51 withdrawals (for any reason) with no statistically significant differences between the intervention and control group in any trial (Appendix E Table 11).

##### Treatment-Related Mortality

Treatment-related mortality was rarely reported and very uncommon. The UKPDS trial (n=3,867) reported one patient out of 911 in the intervention group receiving insulin who died from hypoglycemia,^4^ and in the 24-week trial comparing saxagliptin with placebo (n=213) there were no reported treatment-related deaths.^120^

##### Hypoglycemic Events Requiring Medical Attention

Serious hypoglycemic events requiring medical attention were reported in two trials and were very rare (Appendix E Table 11). The UKPDS trial (n=3,867) compared each of three medication groups (chlorpropamide, glibenclamide, and insulin) with conventional care and found no statistically significant difference between each of the three medication groups and the usual care group. In the intention-to-treat analysis, major hypoglycemic events were reported in 1 percent (6/619) of participants receiving chlorpropamide, 1.4 percent (9/615) of participants receiving glibenclamide, 1.8 percent (16/911) of participants receiving insulin, and 0.7 percent (6/896) of participants in the conventional care group.^4^ The 24-week trial comparing saxagliptin as initial therapy with placebo (n=213) reported no hypoglycemic events requiring medical attention in either group.^120^

##### Serious and Treatment-Related Adverse Events

Only the 24-week trial comparing saxagliptin as initial therapy with placebo (n=213) reported serious and treatment-related adverse events.^120^ There was no statistically significant difference between the saxagliptin group and the placebo group in treatment-related adverse events (6 vs. 8; RR, 0.74 [95% CI, 0.27 to 2.07]), and there were no serious adverse events in either group.

#### Harms of Interventions for Prediabetes

In summary, 21 trials reported on harms associated with interventions for prediabetes (8 assessing a lifestyle intervention and 13 assessing a pharmacologic intervention). Categories and definitions used for adverse events were heterogenous across studies and few trials (k=3) reported adverse events beyond 5-years of followup.^69,80,101^ Five trials reported rates of hypoglycemia (using various definitions), each comparing a different medication with placebo (liraglutide, sitagliptin, metformin, nateglinide, and rosiglitazone +metformin); event rates were low, and no trial found no difference between groups over followup durations ranging from 8 weeks to 5 years.^52,69,97,101,108^ Twelve studies reported withdrawals due to adverse events associated with a pharmacotherapy intervention. Six trials (2 assessing metformin,^77,100^ and 1 each assessing sitagliptin,^97^ nateglinide,^101^ valsartan,^102^ acarbose,^109^ and rosiglitazone plus metformin,^108^) found no increased risk of withdrawals among the intervention group compared with placebo or control, and six found higher rates of withdrawals due to adverse effects associated the pharmacologic intervention than the placebo, including two studies of acarbose,^90,104^ and one study each assessing pioglitazone,^93^ ramipril,^94^ rosiglitazone,^95^ voglibose,^98^ and liraglutide.^52^ Nine studies of pharmacologic interventions reported on gastrointestinal adverse events; compared with placebo or control, higher rates were seen in studies assessing metformin (k=3),^66,77,108^ acarbose (k=2), and liraglutide (k=1),^52^ and rates were similar among groups in one study each assessing pioglitazone, sitagliptin, nateglinide, and valsartan.^93,97,101,102^ Seventeen studies reported other adverse events; types of events reported (and definitions) were heterogeneous and most found no difference between groups. Four studies of lifestyle interventions reported on musculoskeletal-related adverse events, two found no significant difference between groups,^62,86^ and one (the DPP) found higher rates of musculoskeletal symptoms per 100 person-years in the intensive lifestyle intervention group than control group (24.1 vs. 21.1 events per 100 person-years; p<0.017) at 2.3 years^66^ but no difference between groups for sprains or fractures needing medical attention at 15 years postrandomization.^53^

##### Study Characteristics

Study characteristics of interventions for prediabetes are described in detail in KQ 4. A subset of these studies (k=21) report on one or more harms, including eight studies (described in 12 publications) assessing a lifestyle intervention^53,62,63,66,68–71,77,79,84,86^ and 13 studies (described in 16 publications) assessing a pharmacotherapy intervention.^52,90,93–95,97,98,100–106,108,109^ Across all studies, adverse events were reported during followup durations that ranged from 8 weeks to 9 years; few studies (k=3) followed participants 5 years or longer.^69,80,101^

##### Hypoglycemia

Only one study reported rates of severe hypoglycemia requiring third-party assistance and found no events in participants randomized to liraglutide or placebo over 3.3 years.^52^ Four studies of pharmacotherapy interventions (sitagliptin, metformin, nateglinide, and rosiglitazone +metformin) reported on any hypoglycemia, or hypoglycemia defined as “non-serious versus serious,” “symptomatic,” or “mild versus moderate” and found no difference between interventions and placebo over 8 weeks to 5 years.^69,97,101,108^

##### Withdrawals Due to Adverse Events

Twelve studies reported withdrawals due to adverse events associated with a pharmacotherapy intervention. Six found no withdrawals due to adverse events associated with study treatments, or few withdrawals and no difference between groups over 8 weeks to 5 years among two studies assessing metformin,^77,100^ and one each assessing sitagliptin,^97^ nateglinide,^101^ valsartan,^102^ acarbose,^109^ and rosiglitazone plus metformin.^108^ Six other studies found higher rates of withdrawals due to adverse effects associated with a pharmacologic intervention than the placebo, including two studies of acarbose (STOP-NIDDM:^90^ 19% vs. 5% and the Dutch Acarbose Intervention Trial: 36.7% vs. 13.8%^104^), and one study each assessing pioglitazone (withdrawals due to weight gain, 3% vs. 1.0%),^93^ ramipril (medication withdrawals due to cough, 9.7 vs. 1.8%),^94^ rosiglitazone (withdrawals due to edema, 4.8% vs. 1.6%),^95^ voglibose (withdrawals attributed to study medication, 5% vs. 3%; p=0.01),^98^ and liraglutide (withdrawals due to any adverse event, 13% vs. 6%).^52^

##### Gastrointestinal Adverse Events

Nine studies reported on gastrointestinal adverse events (Appendix E Table 12). Three trials found higher rates of gastrointestinal adverse events associated with metformin.^66,77,108^ Of these, two found higher rates of any gastrointestinal symptoms in the metformin group than a standard lifestyle group, including the DPP (77.8% vs. 30.7%; p<0.017)^66^ and the PREVENT-DM trial (28% vs. 0%);^77^ one compared metformin plus rosiglitazone with placebo and found higher rates of any gastrointestinal events in the metformin plus rosiglitazone group (37% vs. 19%), as well as higher rates of diarrhea (16% vs. 6%).^108^ In the DPPOS, rates of gastrointestinal symptoms declined over time in all groups but continued to be significantly higher in the metformin group through 9 years of followup.^69^ Two trials found higher rates of gastrointestinal adverse events among the acarbose group than placebo; one reported higher rates of any gastrointestinal adverse events (85% vs. 60%; p<0.001)^90^ and one reported higher rates of specific gastrointestinal symptoms, including flatulence (15.9 vs. 6.1%), diarrhea (13.5% vs. 3.8%), and enlarged abdomen (13.5 vs. 3.8%).^109^ In one trial, participants randomized to liraglutide reported higher rates of nausea than placebo (41% vs. 17%) and higher rates of diarrhea (41% vs. 15%); the liraglutide group was associated with more cases of pancreatitis than placebo, although overall rates were low (10 vs. 2 cases; rates per group: 0.6% vs. 0.2%).^52^ One trial each assessed pioglitazone, sitagliptin, nateglinide, and valsartan and found similar rates of various gastrointestinal adverse events among medication and placebo groups (Appendix E Table 12).^93,97,101,102^

##### Other Adverse Events

Seventeen studies reported other adverse events; types of events reported (and definitions) were heterogeneous and most found no difference between groups or reported no adverse events were attributed to study interventions (Appendix E Table 12). Six studies of pharmacotherapy interventions reported rates of any adverse event per group; rates were generally higher among the pharmacotherapy intervention arm than placebo, including two trials of metformin^77,93^ and one trial each assessing rosiglitazone plus metformin (41% vs. 28%),^108^ sitagliptin,^97^ liraglutide,^52^ and acarbose.^109^

Four studies of lifestyle interventions reported on musculoskeletal events, one found no significant difference between groups for rates of joint sprains/strains or muscle or joint aches over one year,^62^ one found few cases of musculoskeletal problems^86^ (<1% per group, 6 vs. 3 cases in the intervention vs. control group, respectively), and one (the DPP) found higher rates of musculoskeletal symptoms per 100 person-years in the intensive lifestyle intervention group than control group (24.1 vs. 21.1 events per 100 person-years; p<0.017).^66^ In the DPPOS, rates of sprains or fractures needing medical attention were similar across groups at 15 years postrandomization (ranging from 3.7 to 4.3 events per 100 person-years).^53^

### KQ 7 Do Interventions for Prediabetes Delay or Prevent Progression to Type 2 Diabetes?

### KQ 7a Does the Effectiveness of These Interventions Differ for Subgroups Defined by Age, Sex, Race/Ethnicity, Socioeconomic Status, or BMI?

In summary, lifestyle interventions were associated with a reduction in the incidence of diabetes (pooled RR, 0.78 [95% CI, 0.69 to 0.88], 23 trials; 12,915 participants) (Figure 6). Most trials assessed high-contact lifestyle interventions. Pooled RRs were 0.63 (95% CI, 0.50 to 0.81) for followup less than 1 year, 0.58 (95% CI, 0.41 to 0.82) for followup 1 to 2 years, and 0.81 (95% CI, 0.73 to 0.89) for followup greater than 2 years. For medications, metformin, TZDs, and alpha glucosidase inhibitors were all associated with a reduction in diabetes (pooled RRs [95% CI] 0.73 [0.64, 0.83], 0.50 [0.28, 0.92], and 0.64 [0.43, 0.96], respectively) (Figure 6), although results for TZDs and alpha glucosidase inhibitors were limited by imprecision, inconsistency, and risk of bias (for trials of alpha glucosidase inhibitors).

Figure 6 Delaying or Preventing Progression to Diabetes: Results of Meta-Analyses of Trials Evaluating Interventions for People With Prediabetes (KQ 7)

Abbreviations: BMI=body mass index; CI=confidence interval; f/u=followup; K=number of studies; KQ=key question; N=number; RR=relative risk.

Figure 6 displays the pooled estimates from multiple meta-analyses reporting the risk ratio (RR) of delaying or preventing progression to diabetes, intervention vs. control (KQ7). Using longest available followup, lifestyle interventions were associated with a reduction in progression to diabetes (pooled RR, 0.78 [95% CI, 0.69 to 0.88]; I2 = 46.76; 23 studies). Four trials of followups less than 12 months yielded a pooled RR of 0.63 (95% CI, 0.50 to 0.81; I2 = 0.00). Fifteen trials of followups between 12 to 24 months yielded a pooled RR 0.58 (95% CI, 0.41 to 0.82; I2 = 55.70). Thirteen trials of followups greater than 24 months yielded a pooled RR of 0.81 (95% CI, 0.73 to 0.89; I2 = 40.56). Five trials of medium contact lifestyle interventions yielded a pooled RR of 0.67 (95% CI, 0.37 to 1.22; I2 = 70.70). Eighteen trials of high contact lifestyle interventions yielded a pooled RR of 0.79 (95% CI, 0.71 to 0.89; I2 = 36.62). Four trials with a baseline mean or median BMI less than 25 kg/m2 yielded a pooled RR of 0.46 (95% CI, 0.21 to 1.02; I2 = 82.92). Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled RR of 0.86 (95% CI, 0.71 to 1.05; I2 = 44.21). Thirteen trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled RR of 0.77 (95% CI, 0.65 to 0.91, I2 = 20.13). Three trials of metformin yielded a pooled RR of 0.73 (95% CI, 0.64 to 0.83; I2 = 0.00). Three trials of acarbose or voglibose yielded a pooled RR of 0.64 (95% CI, 0.43 to 0.96, I2 = 76.27). Three trials of pioglitazone or rosiglitazone yielded a pooled RR of 0.50 (95% CI, 0.28 to 0.92; I2 = 91.86).

#### Lifestyle Interventions: Study Characteristics

Twenty-three trials (described in 33 articles) compared lifestyle interventions with controls for delaying or preventing the onset of type 2 diabetes (Appendix E Table 4).^47,49,51,53,62,63,66–69,71–77,79–89,110,121–124^ This current report includes data from 16 additional articles assessing lifestyle interventions that were not in the 2015 review for the USPSTF,^49,51,62,63,71,74,75,77,86,88,89,110,121–124^ including an update to the DPPOS trial,^53^ which extended followup time to 15 years.

Trial start dates ranged from 1986^79^ to 2015.^75^ No trials had less than 12 months of followup, ten had 12 months to 24 months followup,^49,62,71,72,74,75,77,88,89,121^ and 13 had greater than 24 months of followup.^51,53,63,73,76,80–87,110,123,124^ Six trials were conducted in the United States,^49,62,66,72,77,88^ four in the United Kingdom,^51,63,82,89^ four in Japan,^73,84–86^ three in China,^75,79–81,110,123,124^ two in Sweden,^74,76^ and one each in Denmark,^71^ Finland,^47,87^,India,^83^ and Thailand.^121^ Sample sizes ranged from 52^74^ to 3,284.^66^ Three trials had a sample size less than 100,^74,77,89^ 11 had a sample sizes between 100 and 500,^49,63,71–73,75,76,82,85,88,123,124^ and nine had sample sizes greater than 500.^51,62,66,79,83,84,86,87,121^

Regarding prediabetes ascertainment, studies used a variety of approaches to define participant eligibility, with three focusing on criteria for IFG,^72,84,86^ nine on IGT,^49,73,74,76,79,82,85,87,89^ eight on IFG and/or IGT,^51,63,66,75,83,88,121,123,124^ two on IFG and/or A1c,^71,77^ and one on IFG or IGT or A1c.^62^

In most trials (18 of the 23), the lifestyle interventions focused on both diet/nutrition and physical activity.^51,62,63,66,72,73,75–77,82–88,121,123,124^ In three of the 23 RCTs, the lifestyle interventions were focused on physical activity only.^49,74,89^In one of the 23 trials, participants were randomized to one of three treatment groups: diet, exercise, or diet plus exercise,^79^ and one RCT did not specify whether the focus of the intervention was diet, exercise, or both.^71^

Most studies (k=18) delivered high-contact (i.e., dose) lifestyle interventions.^51,62,63,66,71–73,76,77,79–85,87,88,121^ Five studies evaluated medium-dose interventions,^49,75,86,89^ and two evaluated a low-dose intervention.^74^ Lifestyle interventions were administered in a group setting in six trials,^51,62,74,77,89,121^ individually in eight trials,^49,66,71,73,75,84,87,88^ within individual and group sessions in four trials,^72,79,82,85^ by telephone and/or email in two trials,^65,86^, by text messages in one trial,^123,124^ and in sessions that included family members in two trials.^63,88^ Two trials did not specify whether interventions were delivered in individual or group settings.^76,83^ Intervention delivery personnel varied and included physicians, nurse practitioners, dieticians, nurses, community health workers, trained educators, physiotherapists, behavioral medicine clinic staff, public health professionals, case managers, dieticians, and nutritionists. All control groups received a variation of standard care that was minimal and included advice on healthy lifestyle, diabetes, and its management.

Among trials that reported mean or median baseline A1c values, most were less than 6 percent,^49,65,74,75,77^ but some were greater than 6 percent.^51,62,66^ Mean baseline fasting glucose levels among the trials ranged from 98 to 113 mg/dL. Baseline mean or median ages of participants ranged from 43^88^ to 67.^49^ Mean or median ages were in the 40s in six trials,^77,79,81,82,83,86,88^ in the 50s in eleven trials,^62,66,72,73,76,84,85,87,121,123,124^ and in the 60s in six trials.^49,51,71,74,75,89^ Two trials enrolled females only^77,88^ and four enrolled no females^73^ or less than 20 percent females.^49,86,123,124^ Among the other trials, the proportion of female participants ranged from 34 percent^89^ to 71 percent.^62^ Eleven trials did not report information on race/ethnicity.^71,73–76,79,82,84–87^ The proportion of nonwhite participants ranged from 25 percent to 100 percent in trials reporting the information.^49,51,62,63,66,72,77,83,88,89^ Seven trials enrolled a majority of nonwhite participants.^62,63,77,83,88,121,123,124^ Mean baseline BMI ranged from 24 kg/m^273^ to 37 kg/m^2^.^62^ Baseline mean or median BMIs were below 25 for four trials,^73,75,85,86^ in the overweight range (>25 kg/m^2^ and <30 kg/m^2^) for seven trials,^75,79,83,84,89,121,123,124^ and in the obesity range (≥30 kg/m^2^) for 13 studies.^49,51,62,63,66,71,72,74,76,77,82,87,88^ Among the trials that reported mean or median systolic blood pressures, they ranged from 123^66^ to 148.^51^

#### Lifestyle Interventions: Results for Delay or Prevention of Progression to Diabetes

Figure 6 provides the pooled estimates from multiple meta-analyses; Appendix F includes the complete forest plot for each meta-analysis as well as additional figures showing trial data that were not pooled. Meta-analysis of 23 trials (using the longest available followup from each) found that lifestyle interventions were associated with a reduction in progression to diabetes (pooled RR, 0.78 [95% CI, 0.69-0.88]; 12,915 participants; I^2^=47%). Based on this pooled risk, nine people with prediabetes would need to be treated to prevent one case of diabetes after 15 years. For the 18 high-contact interventions, the pooled estimate was nearly the same as for all interventions (pooled RR, 0.79 [95% CI, 0.71 to 0.889]), whereas the meta-analysis for medium contact interventions yielded a very imprecise result and considerable statistical heterogeneity (pooled RR, 0.67 [95% CI, 0.37 to 1.22]; I^2^=71%). When stratifying by followup time, the pooled risk ratios were 0.81 (95% CI, 0.73 to 0.89) for followup greater than 2 years, 0.58 (95% CI, 0.41 to 0.82) for followup 1 to 2 years, and 0.63 (95% CI, 0.50 to 0.81) for followup less than 1 year (Figure 6). When stratifying by baseline BMI, the four trials with baseline mean or median BMI less than 25 kg/m^2^ yielded a pooled RR of 0.46 (95% CI, 0.21 to 1.01), the six with baseline BMI in the overweight range (>25 kg/m^2^ and < 30 kg/m^2^) yielded a pooled RR of 0.86 (95% CI, 0.71 to 1.05), and the 13 with baseline BMI in the obese range (>30 kg/m2) yielded a pooled RR of 0.77 (95% CI, 0.65 to 0.91) (Figure 6).

#### Lifestyle Interventions: Subgroups

The DPP, the DPPOS, and the Da Qing study reported eligible subgroup analyses. While these studies were not designed or powered to detect differences in intervention effects for subgroups, a statistically significant benefit favoring lifestyle intervention over control was found for nearly all subgroups. The DPP investigators reported that the lifestyle intervention was effective in all subgroups and treatment effects did not differ by age (25-44, 45-59, ≥60), sex, race or ethnicity (White, African American, Hispanic, American Indian, Asian), or BMI (22 to <30, 30 to <35, ≥35 kg/m^2^) after three years of followup, acknowledging that subgroup analyses were post-hoc. The Da Qing study reported subgroup results by baseline BMI after six years of followup, finding that the relative decrease in diabetes incidence was similar for lean (<25 kg/m^2^) and overweight (BMI ≥25 kg/m^2^) participants. In post-hoc secondary analysis after 23 years, the Da Qing study reported a similar decrease in diabetes incidence for women and men after 23 years (adjusted HR, 0.55 [95% CI, 0.35 to 0.87] vs. 0.56 [95% CI, 0.39 to 0.81], respectively) and after 30 years (adjusted HR, 0.62 [95% CI, 0.42 to 0.92] vs. 0.61 [95% CI, 0.44 to 0.83], respectively).

#### Pharmacologic Interventions: Study Characteristics

Fifteen trials (reported in 23 articles) evaluated pharmacologic interventions to delay or prevent diabetes.^52,53,66–68,70,77,83,90,92–95,98,100–102,104–106,108,125^ Diabetic medications evaluated in the trials included the biguanide metformin,^66,77,83,106^ thiazolidinediones,^93,95,105^ alpha glucosidase inhibitors,^90,98,104^ liraglutide,^52^ nateglinide,^101^ a sulfonylurea,^100^ a combination of metformin and the thiazolidinedione rosiglitazone,^108^ and acarbose or metformin.^100^ Two studies also evaluated antihypertensives: valsartan^102^ or ramipril.^94^ This current report includes data from four additional articles assessing medications that were not in the 2015 USPSTF report.^52,53,77,106^

Trial start dates ranged from 1996^66^ to 2013.^77^ Followup was 3 years or longer for all but three trials.^77,93,98^ Four trials were conducted in multiple countries,^52,90,94,101^ three in the United States,^66,77,93^ three in India,^83,105,106^ and one trial each in Japan,^98^ Sweden,^100^ and the Netherlands.^104^ Sample sizes ranged from 92^77^ to 9306.^101^ Five trials had a sample size less than 500,^77,100,104,105,108^ three had a sample size between 500 and 1000,^83,93,106^ and six had a sample size greater than 1,000.^52,66,90,94,98,101^ Studies used a variety of approaches to define participant eligibility, with two focusing on IFG;^83,99^ three on IFG and IGT;^90,101,108^ four on IGT;^66,93,100,105^ two on IFG and/or IGT;^94,106^ three on A1c, IFG, and IGT;^52,98,104^ and one on IFG and/or A1c.^77^

Trials that evaluated metformin used doses of 500 mg twice daily^83,106^ or 850 mg twice daily.^66,77^ The three trials evaluating alpha glucosidase inhibitors examined acarbose 50 mg three times daily,^104^ acarbose 100 mg three times daily,^90^ and voglibose 0.2 mg three times daily.^98^ The TZD trials evaluated pioglitazone 30 mg daily,^105^ pioglitazone 45 mg daily,^93^ and rosiglitazone 80 mg daily.^95^ One study each examined the glucagon-like peptide 1 receptor agonist liraglutide at 3.0 mg daily,^52^ the meglitinide nateglinide 60 mg three times daily,^101^ the sulfonylurea glimepiride 1 mg daily,^100^ a combination of metformin 500 mg and rosiglitazone 2 mg twice daily,^108^ and acarbose 50 mg three times daily or metformin 250 mg three times daily.^100^

Control groups received placebo and variations of usual care or minimal intervention including written materials. Usual care or minimal intervention varied and consisted of standard care, diabetes prevention materials, general healthy lifestyle advice, lifestyle counseling focused on diabetes prevention, diabetic education, and sometimes no counseling or educational materials. Four trials did not have a placebo in their control group.^77,83,100,106^

Baseline mean ages of participants ranged from 45 to 64. The percentage of females enrolled ranged from 13 percent^105^ to 100 percent,^77^ and the percentage of nonwhite participants ranged from 0^77,83,105,106^ to 97.^90^ Baseline BMIs ranged from 26 kg/m^283,98^ to 39 kg/m^2^.^52^ Baseline mean or median systolic blood pressure readings were between 118^105^ and 142.^99^

#### Pharmacologic Interventions: Results for Delay or Prevention of Progression to Diabetes

Figure 6 provides the pooled estimates from multiple meta-analyses; Appendix F includes the complete forest plot for each meta-analysis as well as additional figures showing trial data that were not pooled. For metformin, meta-analysis of three trials, including 3-year followup data for the DPP, found that it was associated with a reduction in the incidence of diabetes (pooled RR, 0.73 [95% CI, 0.64 to 0.83]) (Figure 6); using 15-year followup data from DPPOS (instead of the 3-year DPP data) in the meta-analysis also found that metformin was associated with a reduction in the incidence of diabetes (pooled RR, 0.87 [95% CI, 0.77 to 0.98]). For both TZDs and alpha glucosidase inhibitors, meta-analysis of three trials each found associations with a reduction in the incidence of diabetes (Figure 6), but the results were limited by imprecision and inconsistency across trials (Appendix F).

#### Pharmacologic Interventions: Subgroups

With the caveat that their subgroup analyses were post-hoc and underpowered, the DPP authors noted that after 3 years of followup, the effect of metformin compared with placebo was not statistically significantly different for subgroups defined by age, sex, or race and ethnicity. However, they reported statistically significant effect modification by BMI (p<0.05), with greater effect on diabetes incidence for those with higher BMIs (e.g., reduction in diabetes incidence 53% [95% CI, 36% to 65%] for BMI ≥35 kg/m^2^ vs. 3% [95% CI, −36% to 30%] for BMI 22 to <30 kg/m^2^). After 15 years of followup within DPPOS, the effect of metformin compared with control was not significantly different (i.e., there was no effect modification) between males and females or for those in different categories defined by BMI, age, or race/ethnicity.^125^ The Indian Diabetes Prevention Program (IDPP) investigators found that age, sex, and BMI did not independently influence the development of diabetes for the control group compared with any of its three treatment groups, including the metformin only group.

#### Mixed Interventions and Stepwise Strategies

The CANOE trial^108^ randomly assigned participants to receive a combination pill of rosiglitazone and metformin or matching placebo with a median followup of 3.9 years. Participants in both groups also received five 30-minute individually delivered lifestyle intervention sessions during the first year. The incidence of diabetes in the combination pill group was 14% compared with 39% in the placebo group (RR, 0.42 [95% CI, 0.24 to 0.74]; 207 total participants).

Two trials used impaired fasting glucose and impaired glucose tolerance to guide pharmacologic treatment for their intervention groups.^100,106^ One trial was performed in China^100^ (n=210) and randomized participants to receive medication with a lifestyle intervention or routine care for 2 years. The group receiving medication with a lifestyle intervention received acarbose if they had isolated impaired fasting glucose and metformin if they had both impaired fasting glucose and impaired glucose tolerance. After 2 years, no subjects in the intervention group and six subjects in the control group developed diabetes based on a per-protocol analysis. The Diabetes Community Lifestyle Improvement Program (D-CLIP)^106^ intervention was performed in India and randomized participants to receive a DPP-based lifestyle intervention and then metformin if (after at least 4 months) they had IFG and IGT or IFG and an A1c was at least 5.7 percent. After a followup of 3 years, 26 percent in the intervention group and 35 percent in the control group developed diabetes (RR, 0.79 [95% CI, 0.60 to 1.32]; 578 total participants).

### KQ 8 After Interventions for Prediabetes Are Provided, What Is the Magnitude of Change in Health Outcomes That Results From the Reduction in Type 2 Diabetes Incidence?

In summary, most studies had insufficient followup duration to assess long-term health outcomes. Just two trials had longer than 5 years followup, and just one trial (Da Qing) reported a decrease in diabetes incidence. It found an absolute decrease in diabetes incidence of about 24 percent over 6 years (43.6% vs. 67.7% of participants after a 6-year lifestyle intervention vs. control) was associated with 10 percent fewer deaths (46% vs. 56%) and 8 percent fewer cardiovascular deaths (22% vs. 30%) over 30 years.^110^ However, the trial was assessed as having at least medium risk of bias (e.g., for unclear methods of randomization and allocation concealment and baseline differences between groups in smoking status) and results were imprecise.^81^

Eight RCTs (described in 17 articles) were eligible.^50–53,67,79–81,90–93,95,96,101,110,122^ Sample sizes ranged from 576^79–81^ to 9,306.^101^ Other than prediabetes, participants were not required to have additional cardiovascular risk factors in three studies (reported in 8 articles).^51,79–81,95,96,110,122^ Participants had elevated BMI in four studies (reported in 8 articles).^50,52,53,67,90–93^ In one study participants had at least one cardiovascular risk factor or CVD.^101^ Three studies (reported in 9 articles) investigated lifestyle interventions^50,51,53,67,79–81,110,122^ and one study investigated each of the following medications: metformin,^50,53,67^ acarbose,^90,91^ pioglitazone,^92,93^ rosiglitazone,^94–96^ liraglutide,^52^ and nateglinide.^101^ Total length of followup ranged from 2.2 years^92,93^ to 30 years.^110^ Only two included studies (Da Qing and NAVIGATOR)^79–81,101,110^ had greater than 5 years followup. Six studies analyzed diabetes incidence over the same time period as the health outcome.^50–53,67,90–93,95,96,122^ One study (Da Qing) analyzed diabetes incidence at 6, 23, and 30 years, and health outcomes at 20, 23, and 30 years,^79–81,110^ and another (NAVIGATOR) analyzed diabetes incidence at 5 years and health outcomes at 6.5 years.^101^

Two studies (described in 5 articles) were conducted in the United States,^50,53,67,92,93^ one (described in 2 articles) was conducted in the United Kingdom,^51,122^ one (described in 4 articles) was conducted in China,^79–81,110^ and four (described in 6 articles) were conducted across multiple countries.^52,90,91,95,96,101^ Three studies (reported in 7 articles) reported all-cause mortality and cardiovascular mortality.^79–81,95,96,101,110^ Seven studies (reported in 15 articles) reported cardiovascular events (either individually or as composites).^50,52,53,67,79–81,90–93,95,96,101,110^ Three studies (reported in 6 articles) reported quality of life outcomes.^50–53,67,122^ One study^110^ reported retinopathy, nephropathy, and neuropathy outcomes and a composite of these.

Main results are summarized in Figure 7. Because most of the trials had insufficient duration of followup to adequately assess for long-term benefits for health outcomes after a reduction in diabetes incidence, the text here focuses on the two trials with more than 5 years followup as well as the DPP because of its particular applicability to the U.S. populations. Additional detailed results for the other included trials are provided in Appendix E.

Figure 7 Main Results of Studies Reporting Both Diabetes Incidence and Health Outcomes After Interventions for Prediabetes (KQ 8)

* Calculated RR and 95% CI from number of events; study did not report HR.

Abbreviations: CDQDPOS=China Da Qing Diabetes Prevention Outcomes Study; CI=confidence interval; CV=cardiovascular; DPP=Diabetes Prevention Program; F/U=followup; HR=hazard ratio; KQ=key question; NAVIGATOR=Nateglinide and Valsartan in Impaired Glucose Tolerance Outcomes Research; RR=relative risk; STOP-NIDDM=Study TO Prevent Noninsulin-Dependent Diabetes Mellitus; T2DM=type 2 diabetes mellitus; y=years.

Figure 7 displays a forest plot reporting the hazard ratio (RR) of studies reporting both diabetes incidence and health outcomes after intervention for prediabetes (KQ8). CDQDPOS, reported 173 events of T2DM incidence in the combination intervention group compared to 90 events in the control group at 6-year followup (HR, 0.49 [95% CI, 0.33 to 0.73]). CDQDPOS, reported 312 events of T2DM incidence in the combination intervention group compared to 124 events in the control group at 23-year followup (HR, 0.55 [95% CI, 0.40 to 0.76]). CDQDPOS, reported 121 all-cause mortalities in the combination intervention group compared to 53 events in the control group at 23-year followup (HR, 0.71 [95% CI, 0.51 to 0.99]). CDQDPOS, reported 51 CV mortalities in the combination intervention group compared to 27 events in the control group at 23-year followup (HR, 0.59 [95% CI, 0.36 to 0.96]). The NAVIGATOR trial reported 1,674 events of T2DM incidence in the nateglinide intervention group compared to 1,580 events in the control group at 5-year followup (HR, 1.07 [95% CI, 1.00 to 1.15]). The NAVIGATOR trial reported 310 all-cause mortalities in the nateglinide intervention group compared to 312 events in the control group at 6.5-year followup (HR, 1.00 [95% CI, 0.85 to 1.17]). The NAVIGATOR trial reported 126 CV mortalities in the nateglinide intervention group compared to 118 events in the control group at 6.5-year followup (HR, 1.07 [95% CI, 0.83 to 1.38]). The NAVIGATOR trial reported 135 MI in the nateglinide intervention group compared to 143 events in the control group at 6.4-year followup (HR, 0.95 [95% CI, 0.75 to 1.20]). The NAVIGATOR trial reported 111 stroke events in the nateglinide intervention group compared to 126 events in the control group at 6.4-year followup (HR, 0.89 [95% CI, 0.69 to 1.15]). The NAVIGATOR trial reported 332 revascularization events in the nateglinide intervention group compared to 315 events in the control group at 6.3-year followup (HR, 1.06 [95% CI, 0.91 to 1.24]). The DPP reported 132 events of T2DM incidence in the lifestyle intervention group compared to 278 events in the control group at 3-year followup (HR, 0.49, 95% CI, 0.40 to 0.58). The DPP reported 26 CV events in the lifestyle intervention group compared to 22 events in the control group at 3-year followup (HR, 1.17 [95% CI, 0.67 to 2.06]). The DPP reported 199 events of T2DM incidence in the metformin intervention group compared to 278 events in the control group at 3-year followup (HR, 0.72 [95% CI, 0.62 to 0.85]). The DPP reported 17 CV events in the metformin intervention group compared to 22 events in the control group at 3-year followup (HR, 0.78 [95% CI, 0.42 to 1.46]). The DREAM trial reported 280 events of T2DM incidence in the rosiglitazone intervention group compared to 658 events in the control group at 3-year followup (HR, 0.38 [95% CI, 0.33 to 0.44]). The DREAM trial reported 30 all-cause mortalities in the rosiglitazone intervention group compared to 33 events in the control group at 3-year followup (HR, 0.91 [95% CI, 0.56 to 1.49]). The DREAM trial reported 12 CV mortalities in the rosiglitazone intervention group compared to 10 events in the control group at 3-year followup (HR, 1.20 [95% CI, 0.52 to 2.77). The DREAM trial reported 77 CV event 1 in the rosiglitazone intervention group compared to 56 events in the control group at 3-year followup (HR, 1.38 [95% CI, 0.98 to 1.95). The DREAM trial reported 33 CV event 2 in the rosiglitazone intervention group compared to 23 events in the control group at 3-year followup (HR, 1.43 [95% CI, 0.84 to 2.44). The DREAM trial reported 16 MI events in the rosiglitazone intervention group compared to 9 events in the control group at 3-year followup (HR, 1.78 [95% CI, 0.79 to 4.03). The DREAM trial reported 37 revascularization events in the rosiglitazone intervention group compared to 29 events in the control group at 3-year followup (HR, 1.27 [95% CI, 0.78 to 2.07). The DREAM trial reported a HR of 1.20 (95% CI, 0.66 to 2.17) for new angina. The STOP-NIDDM trial reported 221 events of T2DM incidence in the acarbose intervention group compared to 285 events in the control group at 3.3-year followup (HR, 0.75 [95% CI, 0.63 to 0.90]). The STOP-NIDDM trial reported 15 major CV events in the acarbose intervention group compared to 32 events in the control group at 3.3-year followup (HR, 0.51 [95% CI, 0.28 to 0.95]). The ACT NOW trial reported 15 events of T2DM incidence in the pioglitazone intervention group compared to 50 events in the control group at 2.2-year followup (HR, 0.30 [95% CI, 0.17 to 0.52]). The ACT NOW trial reported 26 CV events in the pioglitazone intervention group compared to 23 events in the control group at 2.2-year followup (HR, 1.1 [95% CI, 0.65 to 1.91]). The SCALE trial reported 26 events of T2DM incidence in the liraglutide intervention group compared to 46 events in the control group at 3.1-year followup (HR, 0.28 [95% CI, 0.18 to 0.45]). The SCALE trial reported 242 CV events in the liraglutide intervention group compared to 142 events in the control group at 3.1-year followup (HR, 0.84 [95% CI, 0.70 to 1.02]).

The China Da Qing Diabetes Prevention Outcomes Study (CDQDPOS) evaluated a lifestyle intervention with 30 years of followup in China, among people with prediabetes without requiring additional risk factors for diabetes or mortality.^79–81,110^ The Da Qing results indicate that an absolute decrease in diabetes incidence of about 24 percent over 6 years (43.6% vs. 67.7%) of participants for lifestyle intervention vs. control)^79–81^ was associated with 10 percent fewer deaths (46% vs. 56%), 8 percent fewer cardiovascular deaths (22% vs. 30%), 11 percent fewer cardiovascular events (48% vs. 59%), and 5 percent fewer microvascular events (19% vs. 24%) over 30 years.^110^ Other outcomes are reported in Appendix E. However, the risk of bias was at least medium, in part because of unclear randomization and a baseline imbalance in smoking status. Differences in diabetes incidence developed over the first 6 years, then decreased slightly over the 30 years of followup because the majority of participants developed diabetes.^81^ At the 20-year followup, differences in all-cause mortality, cardiovascular mortality, and cardiovascular events were not statistically significant.^80^

The NAVIGATOR trial recruited participants with both prediabetes and either cardiovascular risk factors or CVD from multiple countries, with 6.5 years of followup.^101^ Nateglinide did not significantly reduce diabetes incidence or improve health outcomes (Figure 7).^101^

The DPP evaluated a lifestyle intervention and metformin in people with prediabetes and BMI of 24 or higher in non-Asians and 22 or higher in Asians.^50,53,67^ The DPP results found an absolute decrease in diabetes incidence of about 15 percent with lifestyle interventions (14.4% vs. 29.7% for lifestyle intervention vs. control) and an absolute decrease in diabetes incidence of about 8 percent with metformin (21.5% vs. 29.7% for metformin vs. control) over about 3 years^53^ and no statistically significant change in incidence of composite cardiovascular events (including cardiovascular death, coronary revascularization, artery disease, stroke, cardiac arrhythmia, congestive heart failure, and unstable angina) over the same time period (2.4% lifestyle vs. 1.6% metformin vs. 2.0% control) (Figure 7).^67^

### KQ 9 Do Interventions for Prediabetes Improve Other Intermediate Outcomes (Blood Pressure, Lipid Levels, BMI, Weight, and Calculated 10-Year Cardiovascular Disease Risk)?

In summary, 38 RCTs (described in 58 articles) were included (Appendix E Table 4).^47–53,62–80,82,84–96,100–108,110,121–124,126–128^ Of those, 28 trials (described in 41 articles) evaluated lifestyle interventions and 13 (described in 25 articles) evaluated pharmacotherapy. Figures 8 through 10 provide the pooled estimates from multiple meta-analyses; Appendix F includes the complete forest plot for each meta-analysis as well as additional figures showing trial data that were not pooled. Lifestyle interventions were associated with reduced systolic and diastolic blood pressure (pooled WMD, −1.7 mm hg [95% CI, −2.6 to −0.8] and −1.2 mm hg [95% CI, −2.0 to −0.4], respectively), weight (pooled WMD, −1.15 kg [95% CI, −1.56 to −0.74]), and BMI (pooled WMD, −0.54 kg/m^2^ [95% CI, −0.76 to −0.33]) (Figures 8 and 10). Most trials evaluating hypoglycemic agents found no statistically significant association with changes in blood pressure or lipids. Trials of some hypoglycemic agents (metformin, acarbose, or liraglutide) reported reductions in weight and BMI, whereas meta-analysis of trials evaluating TZDs found an association with weight gain (pooled WMD, 1.9 kg [95% CI, 0.8 to 3.1]).

Figure 8 Blood Pressure: Results of Meta-Analyses of Trials Evaluating Lifestyle Interventions for People With Prediabetes (KQ 9)

Abbreviations: BMI=body mass index; CI=confidence interval; DBP=diastolic blood pressure; f/u=followup; KQ=key question; K=number of studies; N=number; SBP=systolic blood pressure; WMD=weighted mean difference.

Figure 8 displays the pooled estimates from multiple meta-analyses reporting the weighted mean difference (WMD) comparing intervention to control on blood pressure (KQ9). Using longest available followup, lifestyle interventions were associated with a reduction in systolic blood pressure (pooled WMD, −1.68 [95% CI, −2.57 to −0.79]; I2 = 11.43; 18 studies). Five trials of followups less than 12 months yielded a pooled WMD of −0.15 (95% CI, −2.31 to 2.01; I2 = 33.17) for systolic blood pressure. Fourteen trials of followups between 12 to 24 months yielded a pooled WMD of −1.39 (95% CI, −2.60 to −0.17; I2 = 64.56) for systolic blood pressure. Six trials of followups greater than 24 months yielded a pooled WMD of −1.44 (95% CI, −3.08 to 0.21; I2 = 25.97) for systolic blood pressure. Five trials of medium contact lifestyle interventions yielded a pooled WMD of −0.60 (95% CI, −2.86 to 1.67; I2 = 24.30) for systolic blood pressure. Thirteen trials of high contact lifestyle interventions yielded a pooled WMD of −2.11 (95% CI, −3.01 to −1.21; I2 = 1.53) for systolic blood pressure. Five trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of −0.24 (95% CI, −1.84 to 1.36; I2 = 0.00) for systolic blood pressure. Thirteen trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of −2.23 (95% CI, −3.11 to −1.36, I2 = 0.00) for systolic blood pressure. Using longest available followup, lifestyle interventions were associated with a reduction in diastolic blood pressure (pooled WMD, −1.22 [95% CI, −2.02 to −0.42]; I2 = 31.62; 15 studies). Three trials of followups less than 12 months yielded a pooled WMD of −0.44 (95% CI, −3.36 to 2.48; I2 = 67.18) for diastolic blood pressure. Twelve trials of followups between 12 to 24 months yielded a pooled WMD of −1.51 (95% CI, −2.52 to −0.49; I2 = 63.22) for diastolic blood pressure. Six trials of followups greater than 24 months yielded a pooled WMD of −0.55 (95% CI, −1.86 to 0.76; I2 = 51.82) for diastolic blood pressure. Twelve trials of high contact lifestyle interventions yielded a pooled WMD of −1.35 (95% CI, −2.17 to −0.54; I2 = 25.84) in diastolic blood pressure. Three trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of 1.01 (95% CI, −2.26 to 4.29; I2 = 52.75) in diastolic blood pressure. Twelve trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of −1.52 (95% CI, −2.27 to −0.76, I2 = 18.12) in diastolic blood pressure.

Figure 9 Lipids: Summary of Meta-Analysis Results for Trials Evaluating Lifestyle Interventions for People With Prediabetes (KQ 9)

Abbreviations: BMI=body mass index; CI=confidence interval; HDL=high density lipoprotein; f/u=followup; KQ=key question; K=number of studies; LDL= low density lipoprotein; N=number; WMD=weighted mean difference.

Figure 9 displays the pooled estimates from multiple meta-analyses reporting the weighted mean difference (WMD) in lipids comparing lifestyle intervention to control (KQ9). Using longest available followup, 19 trials yielded a pooled WMD, −0.69 (95% CI, −2.23 to −0.86; I2 = 83.17) in total cholesterol. Four trials of followups less than 12 months yielded a pooled WMD of −3.03 (95% CI, −6.62 to 0.57; I2 = 0.00) in total cholesterol. Fourteen trials of followups between 12 to 24 months yielded a pooled WMD of −0.27 (95% CI, −0.60 to 0.06; I2 = 16.11) in total cholesterol. Six trials of followups greater than 24 months yielded a pooled WMD of 0.66 (95% CI, −5.57 to 6.90; I2 = 84.76) in total cholesterol. Seven trials of medium contact lifestyle interventions yielded a pooled WMD of −4.10 (95% CI, −6.43 to −1.77; I2 = 0.00) in total cholesterol. Twelve trials of high contact lifestyle interventions yielded a pooled WMD of −0.07 (95% CI, −2.84 to 2.70; I2 = 88.60) in total cholesterol. Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of −3.98 (95% CI, −6.60 to −1.36; I2 = 0.00) in total cholesterol. Twelve trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of 0.56 (95% CI, −1.21 to 2.32, I2 = 87.97) in total cholesterol. Using longest available followup, 21 trials yielded a pooled WMD, 0.00 (95% CI, 0.00 to 0.00; I2 = 0.00) in high density lipoprotein. Five trials of followups less than 12 months yielded a pooled WMD of 0.00 (95% CI, 0.00 to 0.00; I2 = 0.00) in high density lipoprotein. Fifteen trials of followups between 12 to 24 months yielded a pooled WMD of 0.00 (95% CI, −0.01 to 0.01; I2 = 34.16) in high density lipoprotein. Seven trials of followups greater than 24 months yielded a pooled WMD of 2.25 (95% CI, 0.74 to 3.77; I2 = 57.96) in high density lipoprotein. Seven trials of medium contact lifestyle interventions yielded a pooled WMD of 0.00 (95% CI, 0.00 to 0.00; I2 = 0.00) in high density lipoprotein. Fourteen trials of high contact lifestyle interventions yielded a pooled WMD of 0.00 (95% CI, −0.01 to 0.01; I2 = 72.80) in high density lipoprotein. Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of 0.00 (95% CI, 0.00 to 0.00; I2 = 59.16) in high density lipoprotein. Fourteen trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of 0.30 (95% CI, 0.05 to 0.55, I2 = 63.20) in high density lipoprotein. Using longest available followup, 12 trials yielded a pooled WMD, −0.18 (95% CI, −0.52 to 0.17; I2 = 4.94) in low density lipoprotein. Three trials of followups less than 12 months yielded a pooled WMD of −1.58 (95% CI, −8.22 to 5.06; I2 = 37.31) in low density lipoprotein. Eight trials of followups between 12 to 24 months yielded a pooled WMD of −0.25 (95% CI, −0.66 to 0.16; I2 = 12.98) in low density lipoprotein. Five trials of followups greater than 24 months yielded a pooled WMD of 0.10 (95% CI, −3.97 to 4.16; I2 = 52.58) in low density lipoprotein. Four trials of medium contact lifestyle interventions yielded a pooled WMD of 0.98 (95% CI, −7.22 to 9.18; I2 = 0.00) in low density lipoprotein. Eight trials of high contact lifestyle interventions yielded a pooled WMD of 0.01 (95% CI, −1.72 to 1.74; I2 = 27.74) in low density lipoprotein. Using longest available followup, 19 trials yielded a pooled WMD, −0.21 (95% CI, −0.71 to 0.28; I2 = 61.95) in triglycerides. Five trials of followups less than 12 months yielded a pooled WMD of 4.06 (95% CI, −11.54 to 19.66; I2 = 47.19) in triglycerides. Thirteen trials of followups between 12 to 24 months yielded a pooled WMD of −0.41 (95% CI, −1.34 to 0.52; I2 = 59.54) in triglycerides. Seven trials of followups greater than 24 months yielded a pooled WMD of −6.13 (95% CI, −12.73 to 0.47; I2 = 67.87) in triglycerides. Seven trials of medium contact lifestyle interventions yielded a pooled WMD of −1.42 (95% CI, −9.13 to 6.29; I2 = 30.53) in triglycerides. Twelve trials of high contact lifestyle interventions yielded a pooled WMD of −0.33 (95% CI, −1.12 to 0.47; I2 = 71.85) in triglycerides. Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of 0.42 (95% CI, −5.84 to 6.68; I2 = 26.90) in triglycerides. Twelve trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of −0.77 (95% CI, −1.89 to 0.34, I2 = 71.39) in triglycerides.

Figure 10 BMI and Weight: Results of Meta-Analyses of Trials Evaluating Lifestyle Interventions for People With Prediabetes (KQ 9)

Abbreviations: BMI=body mass index; CI=confidence interval; f/u=followup; KQ=key question; K=number of studies; N=number; WMD=weighted mean difference.

Figure 10 displays the pooled estimates from multiple meta-analyses reporting the weighted mean difference (WMD) in weight and BMI comparing lifestyle intervention to control (KQ9). Using longest available followup, 27 trials yielded a pooled WMD, −1.15 (95% CI, −1.56 to −0.74; I2 = 80.84) in weight. Seven trials of followups less than 12 months yielded a pooled WMD of −0.59 (95% CI, −1.20 to 0.01; I2 = 70.44) in weight. Eighteen trials of followups between 12 to 24 months yielded a pooled WMD of −1.35 (95% CI, −2.05 to −0.65; I2 = 89.56) in weight. Twelve trials of followups greater than 24 months yielded a pooled WMD of −0.85 (95% CI, −1.34 to −0.36; I2= 82.05) in weight. Seven trials of medium contact lifestyle interventions yielded a pooled WMD of −0.75 (95% CI, −1.42 to −0.08; I2 = 85.26) in weight. Twenty trials of high contact lifestyle interventions yielded a pooled WMD of −1.37 (95% CI, −1.91 to −0.84; I2 = 77.12) in weight. Four trials with a baseline mean or median BMI less than 25 kg/m2 yielded a pooled WMD of −1.09 (95% CI, −1.93 to −0.24; I2 = 79.00) in weight. Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of −0.36 (95% CI, −1.02 to 0.30; I2 = 78.34) in weight. Sixteen trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of −1.79 (95% CI, −2.48 to −1.11, I2 = 76.53) in weight. Using longest available followup, 19 trials yielded a pooled WMD, −0.54 (95% CI, −0.76 to −0.33; I2 = 70.50) in BMI. Six trials of followups less than 12 months yielded a pooled WMD of −0.36 (95% CI, −0.64 to −0.07; I2 = 63.57) in BMI. Twelve trials of followups between 12 to 24 months yielded a pooled WMD of −0.54 (95% CI, −0.80 to −0.28; I2 = 74.69) in BMI. Eight trials of followups greater than 24 months yielded a pooled WMD of −0.41 (95% CI, −0.67 to −0.16; I2= 63.13) in BMI. Eight trials of medium contact lifestyle interventions yielded a pooled WMD of −0.43 (95% CI, −0.72 to −0.14; I2 = 66.96) in BMI. Twelve trials of high contact lifestyle interventions yielded a pooled WMD of −0.65 (95% CI, −0.99 to −0.31; I2 = 72.53) in BMI. Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of −0.34 (95% CI, −0.58 to −0.10; I2 = 47.91) in BMI. Eleven trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of −0.64 (95% CI, −0.97 to −0.32, I2 = 73.64) in BMI.

#### Lifestyle Interventions: Study Characteristics

Twenty-eight RCTs (described in 41 articles) evaluated lifestyle interventions.^47–49,51,53,62–68,70–80,82,84–89,110,121–124,126–128^ Trials were conducted between 1986 and 2017 and had a mean duration of followup ranging from 6 months to 30 years. Followup duration was less than 12 months in four trials,^65,78,126,127^ 12 to 24 months in 13,^48,49,62,71,72,74,75,77,86,88,89,121,128^ and more than 24 months in 12.^47,51,53,63,64,66–68,70,73,76,79,80,82,84,85,87,110,123,124^ Eight trials were conducted in the United States;^49,53,62,65–70,72,77,88,128^ five in the United Kingdom;^51,63,64,78,82,89^ four in Japan;^73,84–86^ three in China;^75,79,80,110,123,124^ two each in Sweden^74,76^ and Thailand;^121,126^ and one each in Denmark,^71^ Finland,^47,87^ Germany,^48^ and India.^127^ Sample sizes ranged from 52 to 3,234. In six studies, sample sizes were fewer than 100,^63,64,74,77,78,89,127^ in 13 they were 100 to 499,^48,49,65,71–73,75,76,82,85,88,123,124,126,128^ in five they were 500 to 1,000,^47,51,62,79,80,84,87,110^ and four studies had sample sizes greater than 1,000.^53,66–68,70,86,121^

Studies used a variety of approaches to define prediabetes. In six trials, prediabetes was determined by the results of either the fasting glucose or glucose tolerance test.^48,51,63,64,85,88,123,124^ Three studies used A1c results as criteria for prediabetes, with or without results from other tests,^62,65,77^ two focused on fasting glucose,^72,86,128^ three focused on OGTT results,^76,78,82^ and 14 focused on a combination of test results.^47,49,53,66–71,73–75,79,80,84,87,89,110,121,126,127^ Overweight or obesity, as defined by BMI measures, was included as an eligibility criterion in 15 trials, though none required subjects to be obese (BMI >30 kg/m^2^).^47–49,53,62,65–68,70,72,76,82,84,87,89,121,126^

The mean age of participants ranged from 44 to 70 years. Two studies enrolled women only,^77,88^ and another only men;^73^ among the others, the proportion of female participants ranged from 3 percent (in a veteran population^49^) to 80 percent. The proportion of nonwhite participants ranged from 10 percent to 100 percent in trials reporting the information. Twenty-one trials did not report information on race/ethnicity. Participants’ mean fasting plasma glucose levels at baseline ranged from 96 mg/dL to 112 mg/dL (reported in all but 3 studies). In the 15 trials that reported mean baseline hemoglobin A1c, levels ranged from 5.4 percent to 6.2 percent. Mean baseline BMI ranged from 24 kg/m^2^ to 37 kg/m^2^, and values were 30 or above (indicating obesity) in 17 studies.^47–49,51,53,62–72,74,76–78,82,87,88,128^

In 23 of the trials, the lifestyle intervention focused on diet/nutrition and physical activity,^47,48,51,53,62–68,70–73,75–78,82,84–88,121,123,124,126–128^ while three had physical activity-related interventions only.^49,74,89^ In one trial, participants were randomized to diet-only, exercise-only, or diet-and-exercise interventions (or to the control group).^79,80,110^ The specific content of the theory-based health behavior promotion in one study was not described.^71^ Most interventions also included material on health behavior topics such as goal setting, self-monitoring/regulation, problem solving, stress management, or relapse prevention. In 14 of the included trials, the lifestyle intervention was administered in small groups,^48,51,62,71,72,74–77,85,88,89,121,126,128^ in nine trials during individual visits/sessions,^47,49,53,66–68,70,73,78,82,84,87,127^ one of which also provided weekly reminders via standardized short message service (SMS) and monthly phone calls.^127^ In one trial, the intervention was delivered in both individual and group sessions.^79,80,110^ Sessions included family members in one trial.^63,64^ Two trials evaluated the effects of telephone- and/or email-delivered lifestyle interventions,^65,86^ and in another the intervention was provided via SMS messages alone.^123,124^ In trials with multiple group sessions, the number of meetings ranged from 3 to 24 during the intervention period; the number of individual intervention visits ranged from 6 to 34, and the family-centered intervention took place during 15 visits. We identified high-contact interventions (>360 minutes) in 21 studies^47,48,51,53,62–68,70–74,76,77,79,80,82,84,85,87,88,110,121,126,128^ and medium (31 to 360 minutes) in seven.^49,75,78,86,89,123,124,127^ One of the studies that evaluated a high-contact intervention had three groups and also evaluated a low-contact intervention.^74^ Intervention delivery personnel varied widely and included instructors hired and trained for the trial, health care staff, case managers, public health professionals, and community health care workers. Control groups received some variation of standard care, usually including, on a less intensive basis than the intervention, written and/or verbal information and advice on diabetes and its management.

Effects on systolic blood pressure were assessed in 18 trials.^47,48,51,62–64,67,71,74,76–78,80,84,87–89,110,123,124,127,128^ Of those, all but three also reported on diastolic blood pressure.^62,89,127^ Effects on total cholesterol and HDL levels were assessed in 19 trials^47–49,62,64,67,71,74–78,84,87–89,121,123,124,127^ and one on total cholesterol alone;^80,110^ 12 assessed effects on low density lipoprotein (LDL) levels.^49,51,64,67,71,74,76–78,121,123,124,127^ Nineteen assessed effects on triglycerides;^47–49,51,64,67,74–78,84,87–89,121–124,126–128^ two of these also reported HDL outcomes.^126,128^ Twenty-seven trials evaluated effects of lifestyle interventions on continuous measures of weight;^47–49,51,53,62–66,68,71–77,80,82,84–89,121,123,124,126,127^ 10 evaluated binary measures of weight change (e.g., less than vs. more than 5% of baseline body weight,^62,63,65,70–72,82,84,87,121^) and 20 reported on BMI.^48,49,51,53,63,65,72,74–80,84,85,88,110,121,123,124,126,127^

#### Lifestyle Interventions: Results for Blood Pressure

Lifestyle interventions were associated with a reduction in both systolic and diastolic blood pressure (pooled WMD, −1.7 [95% CI, −2.57 to −0.79] and pooled WMD, −1.2 [95% CI, −2.02 to −0.42], respectively) (Figure 8). Analyses stratified by duration of followup (i.e., timing of outcome assessment) found similar associations with blood pressure reduction at 12 to 24 months but no association with blood pressure reduction at followups greater than 24 months or followups shorter than 12 months (Figure 8). Analyses stratified by contact (i.e., dose) and by BMI found an association with reduction in blood pressure for trials evaluating high-contact interventions (but not lower contact) and for studies of participants with baseline BMI of 30 kg/m^2^ or higher (but not lower BMI), which represents the vast majority of included trials (Figure 8).

#### Lifestyle Interventions: Results for Lipid Levels

Meta-analyses of all eligible trials (regardless of contact dose, followup, or baseline BMI) found that lifestyle interventions were not associated with improvements in total cholesterol, HDL, LDL, or triglycerides (Figure 9). However, analyses stratified by duration of followup found associations with increased HDL at followups greater than 24 months (Figure 9). Analyses stratified by contact and BMI found associations with reduced total cholesterol for medium contact interventions and for trials of participants with baseline BMI of 25 to 29.9 kg/m^2^. Analyses stratified by BMI found an association with improvement in HDL for trials of participants with baseline BMI of 30 kg/m^2^ or higher (but not lower BMI), which represents the vast majority of included trials.

#### Lifestyle Interventions: Results for Weight and BMI

Lifestyle interventions were associated with a reduction in weight and BMI (pooled WMD, −1.2 kg [95% CI, −1.6 to −0.74] and pooled WMD, −0.54 kg/m^2^ [95% CI, −0.76 to −0.33], respectively) (Figure 10). Analyses stratified by duration of followup (i.e., timing of outcome assessment) found similar associations with reduction in weight and BMI. The associations remained significant for trials of medium dose and high-contact lifestyle interventions when stratifying by contact dose (Figure 10), but one trial of a low-contact lifestyle intervention found no significant association.^74^

Ten studies reported on weight as a binary outcome between 6 months and 15 years (Appendix F Figures 81 through 84).^47,53,62,63,65,68,70–72,82,84,87,121^ Nine reported on the proportion achieving some weight loss threshold,^47,53,62,63,65,68,70–72,84,87,121^ one on weight gain,^63^ and one reported on beneficial changes in weight.^82^ Lifestyle interventions were associated with a greater proportion of participants achieving at least 5 percent weight loss compared with controls over 6 months to 3 years (pooled RR, 3.3 [95% CI, 2.6 to 4.2]; I^2^ = 61%; 9 trials; 6,658 participants) (Appendix F Figure 82). The association remained significant in analyses stratified by medium or high-contact (no low-contact studies were found), duration of followup, and baseline BMI (for 7 trials with baseline BMI ≥30 and 2 with baseline 25 to 29.9; none had baseline BMI <25) (Appendix F Figures 83 through 84).

#### Lifestyle Interventions: Results for 10-Year CVD Risk

One trial (Let’s Prevent Diabetes) reported on 10-year CVD risk.^51^ The trial (N= 880) found no statistically significant association between the intervention and improvements in CVD risk scores at 6, 12, 24, and 36 months (Appendix F Figure 95).

#### Pharmacological Interventions: Study Characteristics

Thirteen trials (described in 25 articles) evaluated pharmacological interventions.^52,53,66–70,77,90–96,100–108^ All of these trials were included in KQ 7 also and have been previously described. Briefly, duration of followup ranged from 1 year to 3.9 years. Followup duration was 12 to 24 months in two studies^77,100^ and more than 24 months in 11.^52,53,66–70,90–95,101–105,107,108^ Sample sizes ranged from 62 to 9,306. In one study, sample sizes were fewer than 100,^77^ in three they were 100 to 499,^100,104,105^ in two they were 500 to 1,000,^92,93,107^ and six had sample sizes greater than 1,000.^52,53,66–70,90,91,94,95,101–103^

Trials used a variety of approaches to define prediabetes. In two trials, prediabetes was determined by the results of either the fasting glucose or glucose tolerance test.^94,95,107^ Two studies used A1c results as criteria for prediabetes, with or without results from other tests,^52,77^ one focused on fasting glucose,^101–103^ one focused on OGTT results,^100^ and seven focused on combinations of test results.^53,66–70,90–93,104,105,108^ Overweight or obesity, as defined by BMI measures, was part of the eligibility criteria in seven trials,^53,66–70,90–93,100,107,108^ and one required subjects to be obese (BMI ≥30 kg/m).^52^ Participants’ mean fasting plasma glucose levels at baseline ranged from 96 mg/dL to 118 mg/dL. Baseline measures for hemoglobin A1c, when reported, ranged from 5.5 percent to 6.0 percent. Mean baseline BMI ranged from 26 to 39 kg/m^2^, and values were 30 or above (indicating obesity) in nine studies.^52,53,66–70,77,90–95,101–103,108^

Medications evaluated were metformin (4 trials, including 1 using a stepwise strategy with some participants receiving metformin after 4 months),^53,66–70,77,107^ liraglutide,^52^ pioglitazone (2 trials),^93,105^ acarbose (2 trials),^90,91,104^ combination therapy with metformin plus rosiglitazone,^108^ rosiglitazone,^95^ nateglinide,^101^ and acarbose 50 mg three times daily or metformin 250 mg three times daily.^100^ In the trial that evaluated acarbose or metformin, participants were stratified into three groups (isolated IGT [I-IGT], isolated IFG [I-IFG], and IFG+IGT) before randomization. Subjects with I-IGT received 50 mg acarbose 3 times daily plus lifestyle intervention; those with I-IFG or IFG-IGT received 250 mg metformin three times daily plus lifestyle intervention.^100^

#### Pharmacological Interventions: Results for Blood Pressure

Ten trials evaluated the effects of pharmacological interventions on blood pressure (Appendix F Figures 82 and 83).^52,66,67,77,90–94,100–103,105,107^ Overall, most trials did not find a statistically significant association between hypoglycemic agents and blood pressure reduction (Appendix F Figures 82 and 83). For some medications (rosiglitazone, acarbose),^90,91,94,95^ a single trial reported a statistically significant reduction in blood pressure, but the finding has not been replicated (there was not another eligible trial evaluating the medication and reporting on blood pressure). For metformin, two trials (PREVENT-DM and DPP) evaluated 850 mg twice daily and reported no significant difference in blood pressure measures between those receiving metformin and those receiving standard care^77^ or placebo^67^ over 1 to 3 years.

Two trials using a stepwise design initially focusing on lifestyle interventions that incorporated subsequent medications both reported greater reductions in blood pressure for the intervention groups compared with controls after 1 to 2 years.^100,106,107^ The D-CLIP trial evaluated 4 months of lifestyle intervention followed by the addition of metformin in very high-risk participants compared with standard care and found greater reduction in blood pressure for the intervention group (mean difference for systolic blood pressure −1.2 mm hg [95% CI, −2.4 to −0.01] for the 150 participants with blood pressure data). In Lu et al., all participants initially entered the study and received lifestyle and health education for 1 year followed by randomization to a control group or intensive intervention with either acarbose or metformin. Results showed a reduction in systolic blood pressure for individuals in the intensive intervention particularly compared with the control group (mean difference for systolic blood pressure −17.3 mm hg [95% CI, −25.8 to −8.7], 210 participants).^100^

#### Pharmacological Interventions: Results for Lipid Levels

Ten trials reported on lipid outcomes (Appendix F Figures 84 through 87).^52,67,77,90,91,93,100,104,105,107,108^ Of these, seven reported total cholesterol levels,^52,66,67,77,100,104,105,107,108^ seven reported HDL,^52,66,67,77,93,100,107,108^ seven reported LDL,^52,66,67,77,92,93,100,107,108^ and 10 reported triglycerides.^52,66,67,77,90,91,93,100,104,105,107,108^ Overall, most trials did not find a statistically significant association between hypoglycemic agents and change in lipid levels (Appendix F Figures 84 through 87). For some medications (metformin, pioglitazone, acarbose, liraglutide),^90,91,94,95^ a single trial reported a statistically significant improvement in one or two lipid categories, but the findings have not been replicated (either there was not another eligible trial evaluating the medication and reporting on lipids, or a second trial had a null finding). For metformin, the DPP (n=2,155) reported a greater increase in HDL for those receiving metformin compared with those receiving placebo after 3 years (difference between groups 0.40 [95% CI, 0.15 to 0.65]) but no difference between groups for other lipids,^67^ whereas the PREVENT-DM study (n=92) found no statistically significant difference between metformin and controls at 1 year.^77^

#### Pharmacological Interventions: Results for Weight and BMI

Effects of pharmacological interventions on weight or BMI were assessed in 13 trials.^52,53,66–70,77,83,90–95,100–103,105,107,108^ All of these reported on continuous measures of weight, many also reported on BMI,^52,53,68–70,77,90–95,100–103,105,107,108^ and three assessed binary measures of weight change (e.g., achieving weight loss of 5% of body weight).^52,53,68–70,108^

Seven trials reported on the association between change in weight or BMI and monotherapy with metformin (2 trials),^50,66,67,77^ acarbose,^90,91^ liraglutide,^52^ pioglitazone (2 trials),^93,105^ or rosiglitazone.^95^ Overall, trials of metformin, acarbose, and liraglutide generally reported reductions in weight and BMI with medications, whereas meta-analysis of three trials^93,95,105^ of TZDs (pioglitazone and rosiglitazone) found that they were associated with an increase in weight compared with controls (pooled WMD for TZDs, 1.9 kg [95% CI, 0.8 to 3.1]; 6,278 participants) (Appendix F Figures 88 through 92). For metformin, the DPP (n=2,155) reported greater decreases in weight for those receiving metformin compared with those receiving placebo (−2.0 kg [95% CI, −3.2 to −0.8]);^66^ in DPPOS, higher percentages of participants in the metformin group achieving 5 percent weight loss (at 1 year, 29% vs. 13%, p<0.001; at 2 years, 26% vs. 14%, p<0.001),^70^ and higher percentages of participants in the metformin group achieving 10 percent weight loss (1 year, 8% vs. 4%, p<0.001; 2 years, 10% vs. 5%, p<0.001). The PREVENT-DM trial of metformin also found that participants in the intervention group had greater decreases in weight and BMI, but the differences between groups were not statistically significant and results were imprecise (−1.7 kg [95% CI, −4.7 to 1.3] and −0.7 kg/m^2^ [95% CI, −1.9 to 0.5]).^77^

Two trials using a stepwise design initially focusing on lifestyle interventions that incorporated subsequent medications both reported greater reductions in weight or BMI for the intervention groups compared with controls after 1 to 2 years.^100,106,107^ Among a subgroup of 150 overweight/obese participants from the D-CLIP trial,^107^ investigators evaluated 4 months of lifestyle intervention followed by the addition of metformin in very high-risk participants and reported that the intervention of adapted DPP lifestyle classes plus metformin was associated with decreases in weight (−0.60 kg [95% CI, −1.94 to 0.74] and BMI compared with control at 12 months (−0.50 kg/m^2^ [95% CI, −0.996 to −0.004]). In an RCT (n=210) of an intensive integrated intervention (lifestyle and health education for 1 year followed by either acarbose or metformin),^100^ participants in the intervention group had a decrease in weight (mean difference, −1.43 [95% CI, −2.549 to −0.311]) and BMI (mean difference, −0.58 [95% CI, −1.149 to −0.011] compared with control at 2 years.^100^

#### Pharmacological Interventions: Results for 10-Year Cardiovascular Disease Risk

No eligible studies reported this outcome.