# Chapter 2 Methods

## Key Questions and Analytic Framework

The scope and key questions (KQs) were developed by the Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers. The analytic framework and KQs that guided the review are shown in Figure 1. Nine KQs were developed for this review:

1. a. Is there direct evidence that screening for type 2 diabetes and prediabetes in asymptomatic adults improves health outcomes?
  b. Does the effectiveness of screening differ for subgroups defined by age, sex, race/ethnicity, socioeconomic status, or BMI?
2. a. What are the harms of screening for type 2 diabetes and prediabetes in asymptomatic adults?
  b. Do the harms of screening differ for subgroups defined by age, sex, race/ethnicity, socioeconomic status, or BMI?
3. a. Do interventions for screen-detected type 2 diabetes and prediabetes provide an incremental benefit in health outcomes when delivered at the time of detection compared with initiating interventions later, after clinical diagnosis?
  b. Does the effectiveness of these interventions differ for subgroups defined by age, sex, race/ethnicity, socioeconomic status, or BMI?
4. a. Do interventions for screen-detected type 2 diabetes and prediabetes improve health outcomes compared with no intervention, usual care, or interventions with different treatment targets?
  b. Does the effectiveness of these interventions differ for subgroups defined by age, sex, race/ethnicity, socioeconomic status, or BMI?
5. a. Do interventions for recently diagnosed type 2 diabetes improve health outcomes compared with no intervention, usual care, or interventions with different treatment targets?
  b. Does the effectiveness of these interventions differ for subgroups defined by age, sex, race/ethnicity, socioeconomic status, or BMI?
6. What are the harms of interventions for prediabetes, screen-detected type 2 diabetes, or recently diagnosed type 2 diabetes?
7. a. Do interventions for prediabetes delay or prevent progression to type 2 diabetes?
  b. Does the effectiveness of these interventions differ for subgroups defined by age, sex, race/ethnicity, socioeconomic status, or BMI?
8. After interventions for prediabetes are provided, what is the magnitude of change in health outcomes that results from the reduction in type 2 diabetes incidence?
9. Do interventions for prediabetes improve other intermediate outcomes (blood pressure, lipid levels, BMI, weight, and calculated 10-year cardiovascular disease risk)?

Figure 1 Analytic Framework

* Eligible interventions include pharmacotherapy and primary care–relevant behavioral counseling focused on healthy diet and nutrition, physical activity, or both.

† Other intermediate outcomes include blood pressure, lipid levels, BMI, weight, and calculated 10-year cardiovascular disease risk.

Abbreviations: BMI=body mass index.

Figure 1 depicts the key questions within the context of the eligible populations, screenings/interventions, comparisons, outcomes, and settings. On the left, the population of interest is non-pregnant adults without symptoms or a diagnosis of diabetes. Moving from left to right, the figure illustrates the overarching question: Is there direct evidence that screening for type 2 diabetes and prediabetes in asymptomatic adults improves health outcomes (KQ1)? Screening may result in harms (KQ2). After diagnosis of type 2 diabetes or prediabetes, the figure illustrates the following questions: Do interventions provide an incremental benefit in health outcomes when delivered at the time of detection compared with initiating interventions later, after clinical diagnosis (KQ3) and do interventions improve health outcomes compared with no interventions, usual care, or different treatment targets (KQ4)? For recently diagnosed type 2 diabetes, the figure illustrates the question: Do interventions improve health outcomes compared with no interventions, usual care, or different treatment targets (KQ5)? Interventions may result in harms (KQ6). For prediabetes, the figure depicts the questions: Do interventions delay or prevent progression to type 2 diabetes (KQ7) and after intervention, what is the magnitude of change in health outcomes that results from a specified change in type 2 diabetes incidence (KQ8)? The figure also depicts the question: Do interventions for prediabetes improve other intermediate outcomes (blood pressure, lipids, BMI, weight, and calculated 10-year cardiovascular disease risk) (KQ9)?

In addition to addressing the KQs, this review also looked for evidence related to five contextual questions (CQs) that focused on risk assessment tools, agreement among screening tests, screening tests’ prediction of future adverse health outcomes, yield of rescreening at different intervals in adults with an initial normal screening test, and recently published modeling studies that assess screening (vs. no screening) and examine health outcomes. These CQs were not a part of this systematic review. They are intended to provide additional background information. Literature addressing the contextual questions is summarized in Appendix A. This review also included nine supplemental questions that were added during the USPSTF deliberation process. The supplemental questions focused on the use of metformin for prediabetes, the natural history of prediabetes, overdiagnosis and overtreatment, disutilities, patient-reported health status measures, uptake, and adherence. Literature addressing the supplemental questions is summarized in Appendix B.

## Data Sources and Searches

PubMed/MEDLINE and the Cochrane Library were searched for English-language articles published from January 1, 2014, through September 10, 2019. Medical Subject Headings were used as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, tests, interventions, outcomes, and study designs. The search relied primarily on the previous systematic review for the USPSTF to identify potentially relevant studies published before 2014 (we reassessed all articles included in that systematic review using the eligibility criteria). Complete search terms and limits are listed in Appendix B. Targeted searches for unpublished literature were conducted by searching ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry Platform. To supplement electronic searches, the reference lists of pertinent review articles and studies that met the inclusion criteria were reviewed. Studies suggested by peer reviewers or public comment respondents were reviewed and, if appropriate, incorporated into the final review. Since September 10, 2019, ongoing surveillance was conducted through article alerts and targeted searches of journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on May 21, 2021, and did not identify any additional studies that would affect the conclusions. All literature search results were managed using EndNote™ version 9.2 (Thomson Reuters, New York, NY).

## Study Selection

Inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs were developed with input from the USPSTF (Appendix B). English-language studies of asymptomatic, nonpregnant adults age 18 years or older conducted in countries categorized as medium or higher on the 2016 Human Development Index were included. For all KQs, controlled clinical trials were eligible. Controlled prospective cohort studies were also eligible for KQs on harms of screening and treatment (KQs 2 and 6) and the change in health outcomes after reduction in type 2 DM incidence (KQ 8); case-control studies were eligible for KQs on harms (KQs 2 and 6).

For KQs 1 and 2 (direct evidence of benefits and harms of screening), studies that compared screening with A1c, fasting glucose, or OGTT with no screening or alternative screening strategies were eligible. KQs 3 through 6 (benefits and harms of interventions for health outcomes among people with prediabetes and DM) evaluated primary care–relevant behavioral counseling interventions or pharmacologic interventions for prediabetes and type 2 DM but differed in eligible populations, comparisons, or outcomes. KQs 3 and 4 required participants to have screen-detected DM or prediabetes but differed in their comparison (with KQ 3 comparing sooner vs. later intervention and KQ 4 comparing interventions vs. no intervention, placebo, usual care, etc.), whereas KQ 5 assessed studies of people with recently diagnosed DM (but not required to be screen detected). For KQ 6 (harms of interventions), all populations and comparisons eligible for KQs 3 through 5 (on benefits of interventions) that reported on harms were eligible. For KQs 7 and 9, studies of interventions for people with prediabetes that reported on incidence of diabetes (KQ 7) or other intermediate outcomes (blood pressure, lipids, BMI, weight, or calculated 10-year ASCVD risk) were eligible. For KQ8, we included studies of interventions for prediabetes that reported both the change in incidence of diabetes and health outcomes (from KQs 4 and 7). Studies with too few events to adequately address KQ 8 (<20 people with the relevant events) were not included, nor were studies that only reported composite outcomes that included intermediate outcomes if they did not report the health outcome components of the composite separately. For KQ 8, studies of interventions that do not address glycemic status were not included (e.g., blood pressure medications). We used the adjusted hazard ratios reported by study authors, when available, and calculated relative risks and 95% confidence intervals when only numbers of events were reported.

Titles and abstracts were independently reviewed by two investigators; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. The full texts were then independently reviewed by two investigators to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus.

## Quality Assessment and Data Abstraction

We assessed the quality of studies as good, fair, or poor, using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B). Two independent investigators assigned quality ratings for each study. Disagreements were resolved by discussion. Only studies rated as having good or fair quality were included.

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. All data extractions were checked by a second investigator for completeness and accuracy.

## Data Synthesis and Analysis

Findings for each KQ were summarized in tabular and narrative format. The overall strength of the evidence for each KQ was assessed as high, moderate, low, or insufficient based on the overall quality of the studies, consistency of results between studies, precision of findings, risk of reporting bias, and limitations of the body of evidence, using methods developed for the USPSTF (and the EPC program).^29^ Additionally, the applicability of the findings to U.S. primary care populations and settings was assessed. Discrepancies were resolved through consensus discussion.

To determine whether meta-analyses were appropriate, the clinical and methodological heterogeneity of the studies was assessed according to established guidance.^30^ The populations, tests, treatments, comparators, outcomes, and study designs were assessed qualitatively, looking for similarities and differences. For KQs 7 and 9, when at least three similar studies were available, quantitative synthesis was conducted with random-effects models using the inverse-variance weighted method (DerSimonian and Laird) to estimate pooled effects.^31^ For binary outcomes (e.g., progression to type 2 diabetes) relative risks and 95 percent CIs were calculated. Statistical significance was assumed when 95 percent CIs of pooled results did not cross the null. All testing was two sided. For continuous outcomes (e.g., blood pressure), we calculated the weighted mean difference (WMD) between intervention and control. Whenever possible, we used the number of all randomized patients as the denominator to reflect a true intention-to-treat analysis. For all quantitative syntheses, the I^2^ statistic was calculated to assess statistical heterogeneity in effects between studies.^32,33^ An I^2^ from 0 to 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, 50 to 90 percent may represent substantial heterogeneity, and 75 percent or greater represents considerable heterogeneity.^34^ We conducted additional analyses to explore heterogeneity or robustness of findings, stratifying by duration of followup (i.e., timing of outcome assessment), lifestyle intervention contact time (i.e., dose), and baseline BMI of study participants. We estimated the total hours of interventionist contact time (i.e., dose) based on the planned number and length of contacts. If a study did not report the length of sessions, we estimated session length as follows: a session described as brief was assumed to last 15 minutes if it was a face-to-face individual contact and 5 minutes if it was a phone session; for sessions that were not described as brief, individual face-to-face or interactive web-based sessions were assumed to last 30 minutes and group sessions were assumed to last for 60 minutes. We categorized an intervention as low dose if the number of minutes was estimated to be 30 or less, medium if the number of minutes was 31 to 360, and high if the number of minutes was greater than 360. Interventions that consisted of only print materials were categorized as low dose. Mailings and print materials were not included in the estimated of number of sessions or session length. For KQ 7, we calculated the number needed to treat to prevent one person from developing diabetes for interventions with moderate or high strength of evidence (for benefit), using our pooled RRs and the control group event rate from the Diabetes Prevention Program (DPP) (over 3 years) and the DPP Outcomes Study (DPPOS) (over 15 years). When studies reported raw numbers of events but did not report hazard ratios, RRs, or ORs, we calculated RRs. Quantitative analyses were conducted using Comprehensive Meta-Analysis version 3.3 (Biostat, Inc., Englewood, NJ) and Stata version 14 (Stata Corp).

## Expert Review and Public Comment

A draft Research Plan for this topic was posted on the USPSTF Web site for public comment from July 5, 2018 to August 1, 2018. In response to comments, we made the following changes: 1) added a KQ about other intermediate outcomes after interventions for prediabetes (KQ 9), 2) clarified the types of eligible interventions, 3) added socioeconomic status to the subgroups listed in the KQs, 4) revised the terminology used to describe counseling interventions (including revisions for consistency with other topics in the USPSTF portfolio), 5) expanded the list of eligible outcomes, and 6) clarified that eligible study settings include those in which screening and interventions could feasibly be implemented in or referred from primary care. The final version of the research plan was posted on the USPSTF Web site on November 15, 2018. A draft report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and addressed in revisions of this report when appropriate. Revisions included clarifications to the introduction, addition of longer-term followup publications from included studies (those studies were also identified in the literature surveillance), and edits to clarify wording and interpretation of the results of included studies. The draft report was posted for public comment from March 16, 2021, to April 12, 2021, and no substantive changes were made based on public comments.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and members of the USPSTF participated in developing the scope of work and reviewed draft reports, but the authors are solely responsible for the content.