# Chapter 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to inform an update of its recommendation on screening asymptomatic adults for abnormal blood glucose and type 2 diabetes mellitus (DM). In 2015, the USPSTF recommended screening for abnormal blood glucose as part of cardiovascular risk assessment in adults ages 40 to 70 years who are overweight or obese. In addition, it recommended that clinicians offer or refer patients with abnormal blood glucose to intensive behavioral counseling interventions to promote a healthful diet and physical activity (B recommendation). Screening for gestational DM and screening of children are not addressed in this review.

## Condition Definition

DM refers to a range of metabolic disorders characterized by hyperglycemia. Table 1 shows general categories and definitions of DM used by the American Diabetes Association (ADA).^1^ The 2019 ADA guidelines emphasize that type 1 and type 2 DM are heterogeneous diseases in which clinical presentation and disease progression may vary considerably and that both may occur in adults or children.^2^ Type 2 DM is characterized by insulin resistance and relative insulin deficiency.

Table 1 Classification of Diabetes^*^

Category | Definition/Etiology
Type 1 diabetes | Diabetes due to autoimmune β-cell destruction, usually leading to absolute insulin deficiency
Type 2 diabetes | Diabetes due to a progressive loss of β-cell insulin secretion frequently on the background of insulin resistance
Gestational diabetes mellitus | Diabetes diagnosed in the second or third trimester of pregnancy that was not clearly overt diabetes prior to gestation
Diabetes due to other causes | Includes specific types of diabetes attributable to the following: monogenic diabetes syndromes (e.g., maturity-onset diabetes of the young), diseases of the exocrine pancreas (e.g., pancreatitis), and drug- or chemical-induced diabetes (e.g., glucocorticoid use, in the treatment of HIV/AIDS, or after organ transplantation)

* Adapted from 2018 American Diabetes Association guidelines^1^

Abbreviation: HIV/AIDS=human immunodeficiency virus/acquired immunodeficiency syndrome.

The ADA criteria identify three tests that can be used to identify type 2 diabetes or prediabetes: A1c, fasting plasma glucose, or oral glucose tolerance test (OGTT) (Table 2). The ADA guidelines note that a second test is required for confirmation unless there is a clear clinical diagnosis (e.g., patient in hyperglycemic crisis). Prediabetes is the term used for individuals potentially at increased risk for diabetes whose glucose levels are considered higher than normal but do not meet criteria for diabetes.^1^ Prediabetes includes individuals who meet criteria for impaired fasting glucose (IFG), impaired glucose tolerance (IGT), and those with a glycated hemoglobin (A1c) from 5.7 to 6.4 percent.

Table 2 Criteria for the Diagnosis of Type 2 Diabetes and Prediabetes^*^

Diagnosis | A1c^†^ | Fasting^‡^ Plasma Glucose | OGTT^†,§^ | Other
Type 2 diabetes | ≥6.5%; (48 mmol/mol)^§^ | ≥126 mg/dL; (7.0 mmol/L) | ≥200 mg/dL; (11.1 mmol/L) | Random plasma glucose ≥200 mg/dL (11.1 mmol/L) in a patient with classic symptoms of hyperglycemia or hyperglycemia crisis
Prediabetes^‖^ | 5.7 to 6.4%; (39-47 mmol/mol) | IFG: 100 to 125 mg/dL; (5.6-6.9 mmol/L) | IGT: 140 to 199 mg/dL (7.8-11.0 mmol/L) | NA

* Adapted from 2018 American Diabetes Association guidelines.^1^

† The ADA guidelines note this test should be performed in a laboratory using a method that is NGSP certified and standardized to the DCCT assay.

‡ Fasting is defined as no caloric intake for at least 8 hours.

§ Refers to values measured 2 hours post-load on the 75 g OGTT. Per the ADA recommendations, the test should be performed as described by the World Health Organization, using a glucose load containing the equivalent of 75-gram anhydrous glucose dissolved in water.

‖ ADA guidelines note that for all three tests the risk is continuous, extending below the lower limit of the range and becoming disproportionately greater at higher ends of the range.

Abbreviations: A1c=glycated hemoglobin; ADA=American Diabetes Association; DCCT=Diabetes Control and Complications Trial; IFG=impaired fasting glucose; IGT=impaired glucose tolerance; NA=not applicable; NGSP=National Glycohemoglobin Standardization Program; OGTT=oral glucose tolerance test.

## Etiology and Natural History

DM is caused by a combination of insulin resistance and relative insulin deficiency.^3^ The development of DM has been attributed to a complex interaction between genetic susceptibility and environmental factors (including diet and obesity).^3^ Resulting hyperglycemia may be symptomatic or asymptomatic. Classic symptoms of hyperglycemia include polyuria, polydipsia, polyphagia, blurred vision, and unintentional weight loss. Left untreated, hyperglycemia can lead to acute and chronic morbidity and mortality. The natural history of asymptomatic screen-detected type 2 diabetes is unclear. In the United Kingdom Prospective Diabetes Study (UKPDS, N=3,867), adults with clinically detected diabetes based on mean fasting plasma glucose (FPG) levels of 6.1 to 15.0 mmol/L (110 to 270 mg/dL) without symptoms of hyperglycemia were randomized to intensive treatment (with a sulphonylurea or insulin) compared with conventional care (diet alone, drugs were only added if there were hyperglycemic symptoms or FPG > 15 mmol/L [270 mg/dL]).^4^ In the conventional care group, incident outcomes of multiple diabetes-related microvascular and macrovascular outcomes were measured over 10 years of followup (Appendix A Table 1). The estimates reflect the natural history of diabetes detected early (prior to developing symptoms of hyperglycemia); estimates for the 10-year risk of outcomes among populations identified with prediabetes or screen-detected diabetes would be lower. In addition, the UKPDS was started in 1977; usual care for comorbid conditions (e.g., use of statins, hypertension treatment) has changed over time, likely reducing the risk of adverse health outcomes (compared with those reported in the study).

Evidence from observational studies suggests that glucose levels in the prediabetes range are associated with increased risk of cardiovascular disease (CVD). A meta-analysis of prospective cohort studies (k=53) found that having IFG, IGT, or A1c levels between 5.7 and 6.4 percent was associated with a significantly higher risk of CVD (relative risk [RR], 1.13 to 1.30) and coronary heart disease (RR, 1.10 to 1.20) than normoglycemia.^5^ IFG and IGT (but not A1c levels in the prediabetes range) were also associated with increased risk of stroke (RR, 1.06 to 1.20) and overall mortality (RR, 1.13 to 1.32) compared with normoglycemia.^5^ The Supplemental Questions in Appendix B have additional information about the natural history of prediabetes.

## Risk Factors

Many risk factors are associated with development of DM in adults, including older age, family history, overweight and obesity, dietary and lifestyle factors, environmental exposures, and others.^6^ Contextual Question 1 in Appendix A provides additional information about risk assessment tools for predicting the risk of prediabetes or type 2 DM.

Individuals with prediabetes are thought to be at highest risk of developing incident DM. As noted above, observational studies have shown an association between prediabetes and CVD. Despite this evidence, adding A1c to CVD risk assessment for individuals without known CVD or diabetes has not shown incremental benefit for prediction of CVD risk.^7^ In an analysis of individual-participant data from 73 prospective studies (294,998 individuals) without known DM or CVD, adding information on levels of A1c to conventional CVD risk factors was associated with only slight improvement in risk discrimination and was not associated with significant improvement in reclassification of participants across clinical risk categories recommended to inform decisions about preventive treatment.^7^

## Prevalence and Burden

According to the Centers for Disease Control and Prevention’s 2017 National Diabetes Statistics Report, an estimated 12.2 percent of all U.S. adults (≥18 years) had diabetes in 2015.^8^ Of those with diabetes, 23.8 percent were not aware of or did not report having diabetes. The estimated percentages of people with diabetes and prediabetes were derived from the National Health and Nutrition Examination Survey, National Health Interview Survey (NHIS), and other sources. Diagnosed diabetes was determined by self-report among survey respondents and by diagnostic codes; both fasting glucose and A1c levels were used to derive estimates for undiagnosed diabetes and prediabetes (most estimates do not differentiate between type 1 and type 2 diabetes).^8^ Prevalence increases with age; it was lowest in younger adults (4.0% in adults ages 18 to 44 years) and highest in those age 65 years or older (25.2%). Prevalence was similar in women and men (11.7% and 12.7%, respectively). Age-adjusted estimates from the same data source for 2013-2015 showed a higher prevalence of diabetes among American Indians/Alaska Natives (15.1%), non-Hispanic blacks (12.7%), and people of Hispanic ethnicity (12.1%) than non-Hispanic whites (7.4%) and Asians (8.0%). Prevalence of diagnosed diabetes also varied by education level; higher rates were reported by those with less than a high school education (12.6%) than those with a high school education (9.5%) or more than a high school education (7.2%).^8^ Counties in the southern and Appalachian regions of the United States tended to have the highest prevalence of diagnosed diabetes.

A more recent report from CDC scientists found that the number of people newly diagnosed with diabetes decreased from 2009 to 2017 (from about 1.7 million cases per year to about 1.3 million cases per year in 2017), after having increased from 1990 to 2009.^9^ The data (self-reported data from NHIS) do not distinguish between type 1 and type 2 diabetes, but over 90% of people with diabetes in the United States have type 2 diabetes.

According to CDC’s 2017 report, an estimated 33.9 percent of U.S. adults met criteria for prediabetes in 2015 based on their fasting glucose or A1c level.^8^ Similar to diabetes prevalence, estimates of prediabetes were higher in older adults. Nearly half (48.3%) of adults age 65 years or older met criteria for prediabetes in 2015. Across all age categories, 11.6 percent of adults who met criteria for prediabetes had been told by a health professional that they had prediabetes.^8^

In terms of burden of disease, diabetes was estimated to be the seventh leading cause of death in the United States in 2015 based on the Underlying Cause of Death database.^10^ Approximately 3 percent of deaths (79,535 of 2,712,630 total deaths) were attributed to diabetes based on death certifications for U.S. residents. Cause of death was based on ICD-10 codes, and estimates do not differentiate between type of diabetes. Morbidity from type 2 diabetes is due to macrovascular disease (atherosclerosis), microvascular disease (retinopathy, nephropathy, and neuropathy), and acute complications (of hyperglycemia or hypoglycemia). Diabetes is the leading cause of kidney failure, lower-limb amputations other than those caused by injury, and new cases of blindness among adults in the United States.^11^ Estimates based on results of the Global Burden of Disease Study indicate that diabetes was the third leading cause of years lived with disability in 2016, which is an approximate 30 percent increase from 1990 (when it ranked 8^th^).^12^ In terms of causes of disability-adjusted life-years in the United States, diabetes ranked 4^th^ in 2016, an increase from the 6^th^ leading cause in 1990 (an approximate 11% increase).^12^

## Rationale for Screening and Screening Strategies

Screening asymptomatic adults for type 2 diabetes may allow earlier detection, diagnosis, and treatment, with the ultimate goal of improving health outcomes. Earlier detection of prediabetes may allow for interventions to prevent progression to diabetes and a shorter exposure to the hyperglycemic states associated with adverse outcomes. When screening results in a diagnosis of diabetes, treatment to prevent or reduce the risk of diabetic complications can be initiated.^1,13,14^

Screening tests and thresholds for a positive test are summarized in Table 2. Strategies for screening for prediabetes and type 2 diabetes are the same and include screening individuals of prespecified age groups or targeted screening based on the presence of risk factors assessed either without or with formal risk assessment instruments.^1,13,14^ If not using a formal instrument, assessing for diabetes risk factors (e.g., age, overweight, history of gestational diabetes, identifying as a member of a race or ethnicity with a higher risk of diabetes, hyperlipidemia) is followed by fasting glucose, hemoglobin A1c, or oral glucose tolerance testing for those at increased risk. Examples of formal risk assessment tools include the ADA risk test,^15^ Canadian Diabetes Risk Assessment Questionnaire (CANRISK),^16^ Finnish Diabetes Risk Score (FINDRISC),^17^ and Australian Type 2 Diabetes Risk Assessment Tool (AUSDRISK).^18^

## Treatment Approaches

### For Reducing Progression From Prediabetes to Diabetes

Intensive lifestyle interventions to achieve weight loss and increase physical activity are the first-line therapies for preventing progression of prediabetes to diabetes. The U.S. Food and Drug Administration (FDA) has not approved any medications specifically to prevent progression of prediabetes to diabetes, nor has the Canadian Medicare System.^19,20^ The National Institute for Clinical Excellence (NICE), in contrast, has approved the use of metformin among prediabetic individuals with worsening glucose control despite lifestyle changes or inability to participate in lifestyle change.^21^ For people with prediabetes, the ADA recommends that metformin should be considered for prevention of diabetes, especially for those with BMI 35 or greater, those under 60 years of age, and women with prior gestational DM.^22^

### Hypoglycemic Agents

Lifestyle interventions are the first-line therapies for patients diagnosed with diabetes. Recommendations and formal programs to improve diet and increase exercise are often accompanied or followed by pharmacotherapy. Pharmacotherapy includes the biguanide metformin, sulfonylureas (e.g., glipizide, glyburide, glimepiride), GLP-1 receptor agonists (liraglutide, exenatide, lixisenatide, dulaglutide, semaglutide), sodium glucose cotransporter 2 (SGLT-2) inhibitors (empagliflozin, canaglifozin, dapaglifozin, ertugliflozin), dipeptidyl peptidase 4 inhibitors (saxagliptin, sitagliptin, alogliptin, linagliptin), thiazolidinediones (pioglitazone, rosiglitazone), alpha glucosidase inhibitors (acarbose, miglitol, voglibose), and insulin.^23,24^ The ADA recommends monotherapy with metformin along with lifestyle modification as initial therapy.^22^ The intensity of recommended pharmacotherapy regimens depends on A1c level. The ADA also recommends considering insulin for those with evidence of ongoing weight loss and symptoms of hyperglycemia when A1c or blood glucose levels are very high (>10% or ≥300 mg/dL, respectively) and initiating dual therapy for those who have A1c 1.5% or more above their glycemic target (which could range from <6.5% to <8%, depending on their individualized goal).^22^ The American College of Physicians (ACP) also suggests metformin as the first-line pharmacotherapy for diabetes with the addition of other agents (e.g., sulfonylureas, thiazolidinedione, SGLT-2 inhibitors or dipeptidyl peptidase-4 [DPP-4] inhibitor) as needed.^25^ Appendix A provides additional information on treatments for people with diabetes aiming to reduce CVD risk and microvascular complications (e.g., hypertension treatment).

## Clinical Practice in the United States

The majority of outpatient care for people with diabetes in the United States is provided by primary care.^26^ Analysis of data from the 2009 through 2015 National Ambulatory Medical Care Survey (NAMCS) found that the mean number of total yearly visits for people with diabetes was much higher for primary care offices than for specialist offices, hospital outpatient departments, and hospital emergency departments (61.4 million vs. 32.0, 11.1, and 12.1 million, respectively).^26^ Similarly, the mean number of total yearly visits for which diabetes was a reason for the visit was much higher for primary care offices than for specialist offices, hospital outpatient departments, and hospital emergency departments (14.4 million vs. 4.9, 2.4, and 0.3, respectively).^26^

Recent studies have described the uptake of screening for diabetes in the United States. One study using NAMCS data reported a low rate of annual screening for people meeting ADA criteria (age 45 years or older and those <45 years of age with BMI ≥25 and an additional risk factor) of less than 15 percent in each year from 2012 to 2015 (covering a total of 105,721 office visits), although screening increased from 2012 to 2015 from 10 percent to 13.4 percent.^27^ The study also reported the prevalence of and treatment patterns for prediabetes (identified by fasting blood glucose, A1c, or ICD-9 codes). Of those screened, 16.7 percent had prediabetes. Of all visits for people with prediabetes (5,406 visits), lifestyle management was provided at 21.3 percent, and antihyperglycemic medications were prescribed at 2.9 percent. Metformin was by far the most commonly prescribed medication in visits for prediabetes (accounting for 76.1% of antihyperglycemic medications).

An evaluation of 12,772 people without diabetes who were at least 45 years of age reported high rates of screening, with 78 percent being screened at least once over 3 years from 2010 through 2013.^28^ Subjects were members of a health maintenance organization assigned to primary care providers in a large academic health system. Screening was defined as the first OGTT, A1c, or any glucose test performed. Glucose was (by far) the most common test, accounting for 86 percent of the initial screening tests versus 14 percent for A1c (OGTT accounted for <1%). It is uncertain whether many of the glucose tests should truly be considered screening tests because they were not required to be fasting tests for the main analysis. When limiting the screening definition for the analysis to glucose tests specifically marked as fasting tests (and still including OGTT and A1c), they reported a much lower rate of screening, at 20 percent of participants. Of the participants screened with A1c, 63 percent met criteria for prediabetes or diabetes.

## Recommendations of Other Organizations

All current clinical practice guidelines (CPGs) recommend screening high-risk groups for diabetes (Appendix A Table 2) but with some variation in how high risk is defined, including the number of risk factors necessary before screening. When screening tests are normal, repeat screening is generally recommended every 3 years. Annual screening is typically recommended for those with prediabetes. Most guidelines recommend using either validated diabetes risk assessment tools/calculators or a set of criteria for increased risk (e.g., BMI, family history, hypertension) to determine whether to screen. In the United Kingdom for example, the assessment of diabetes risk has two stages; the first step recommends using a validated risk tool (or in the absence of an available validated tool a diabetes risk filter) to identify people at risk before performing the second step, a blood test to confirm whether an individual has or is at risk of type 2 diabetes. The Canadian Task Force on Preventive Health Care recommends the use of a validated diabetes risk assessment tool (FINDRISC) to determine who should be screened using HbA1c testing. In Australia, diabetes risk assessment is recommended every 3 years from age 40 with blood test screening for those identified as high risk (using the risk calculator) or with other known risk factors.

Clinical practice guidelines vary with respect to recommending universal blood test screening for type 2 diabetes (Appendix A Table 2). Most organizations recommend against universal blood test screening without the presence of risk factors. The ADA along with the American Association of Clinical Endocrinologists and American College of Endocrinology recommend screening all adults, using a plasma glucose test or HbA1c, beginning at age 45 regardless of risk factors (the ADA also recommends screening overweight or obese adults of any age with at least one risk factor). The Canadian Diabetes Association and the Singapore Ministry of Health recommend blood sugar screening for all adults beginning at age 40.