# Appendix F Additional Figures

Appendix F Figure 1 Lifestyle vs. Control: Progression to T2DM

Appendix Figure 1 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with lifestyle intervention vs. control for all available followups. RRs ranged between 0.14 (95% CI, 0.02 to 1.15) to 1.52 (95% CI, 0.93 to 2.48).

Appendix F Figure 2 Lifestyle vs. Control: Progression to T2DM (Endpoint)

Appendix Figure 2 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with lifestyle intervention vs. control. Using the longest available followup, lifestyle interventions were associated with a reduction in progression to diabetes (pooled RR, 0.78 [95% CI, 0.70 to 0.88]; I2 = 46.76; 23 studies).

Appendix F Figure 3 Lifestyle vs. Control: Progression to T2DM (>24 Months)

Appendix Figure 3 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with lifestyle intervention vs. control at followups greater than 24 months. Thirteen trials of followups greater than 24 months yielded a pooled RR of 0.81 (95% CI, 0.73 to 0.89; I2 = 40.56).

Appendix F Figure 4 Lifestyle vs. Control: Progression to T2DM (12-24 Months)

Appendix Figure 4 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with lifestyle intervention vs. control at followups between 12 to 24 months. Fifteen trials of followups between 12 to 24 months yielded a pooled RR 0.58 (95% CI, 0.41 to 0.82; I2 = 55.70).

Appendix F Figure 5 Lifestyle vs. Control: Progression to T2DM (<12 Months)

Appendix Figure 5 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with lifestyle intervention vs. control at followups of less than 12 months. Four trials of followups less than 12 months yielded a pooled RR of 0.63 (95% CI, 0.50 to 0.81; I2 = 0.00).

Appendix F Figure 6 High Contact Lifestyle vs. Control: Progression to T2DM

Appendix Figure 6 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with high contact lifestyle intervention vs. control. Eighteen trials of high contact lifestyle interventions yielded a pooled RR of 0.79 (95% CI, 0.71 to 0.89; I2 = 36.62).

Appendix F Figure 7 Medium Contact Lifestyle vs. Control: Progression to T2DM

Appendix Figure 7 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with medium contact lifestyle intervention vs. control. Five trials of medium contact lifestyle interventions yielded a pooled RR of 0.67 (95% CI, 0.37 to 1.22; I2 = 70.70).

Appendix F Figure 8 Lifestyle vs. Control: Progression to T2DM (Baseline BMI >30)

Appendix Figure 8 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with lifestyle intervention vs. control in studies with a baseline mean or median BMI greater than 30 kg/m2. Twelve trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled RR of 0.77 (95% CI, 0.65 to 0.91, I2 = 20.13).

Appendix F Figure 9 Lifestyle vs. Control: Progression to T2DM (Baseline BMI 25-29.9)

Appendix Figure 9 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with lifestyle intervention vs. control in studies with a baseline mean or median BMI between 25 to 29.9 kg/m2. Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled RR of 0.86 (95% CI, 0.71 to 1.05; I2 = 44.21).

Appendix F Figure 10 Lifestyle vs. Control: Progression to T2DM (Baseline BMI <25)

Appendix Figure 10 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with lifestyle intervention vs. control in studies with a baseline mean or median BMI less than 25 kg/m2. Three trials with a baseline mean or median BMI less than 25 kg/m2 yielded a pooled RR of 0.46 (95% CI, 0.21 to 1.02; I2 = 82.92).

Appendix F Figure 11 Pharmacological vs. Control: Progression to T2DM (All)

Appendix Figure 11 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with pharmacological interventions vs. control for all available followups. RRs ranged between 0.28 (95% CI, 0.18 to 0.45) to 1.06 (95% CI, 1.01 to 1.12).

Appendix F Figure 12 Metformin vs. Control: Progression to T2DM (With DPP)

Appendix Figure 12 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with metformin vs. control with the DPP. Metformin yielded a pooled RR of 0.73 (95% CI, 0.64 to 0.83; I2 = 0.00; 3 trials).

Appendix F Figure 13 Metformin vs. Control: Progression to T2DM (With DPPOS)

Appendix Figure 13 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with metformin vs. control with the DPPOS. Metformin yielded a pooled RR of 0.87 (95% CI, 0.77 to 0.98; I2 = 11.68; 3 trials).

Appendix F Figure 14 Thiazolidinediones vs. Control: Progression to T2DM

Appendix Figure 14 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with thiazolidinediones vs. control. Three trials of pioglitazone or rosiglitazone yielded a pooled RR of 0.50 (95% CI, 0.28 to 0.92; I2 = 91.86).

Appendix F Figure 15 Alpha Glucosidase Inhibitor vs. Control: Progression to T2DM

Appendix Figure 15 displays a forest plot reporting the risk ratio (RR) of delaying or preventing progression to diabetes with alpha glucosidase vs. control. Three trials of acarbose or voglibose yielded a pooled RR of 0.64 (95% CI, 0.43 to 0.96, I2 = 76.27).

Appendix F Figure 16 Lifestyle vs. Control: Systolic Blood Pressure (All)

Appendix Figure 16 displays a forest plot reporting the difference in means for systolic blood pressure, lifestyle interventions vs. control for all available followups. WMDs ranged between −7.90 (95% CI, −12.52 to −3.27) to 5.70 (95% CI, −5.07 to 16.47).

Appendix F Figure 17 Lifestyle vs. Control: Systolic Blood Pressure (Endpoint)

Appendix Figure 17 displays a forest plot reporting the difference in means for systolic blood pressure, lifestyle intervention vs. control. Using longest available followup, lifestyle interventions were associated with a reduction in systolic blood pressure (pooled WMD, −1.68 [95% CI, −2.57 to −0.79]; I2 = 11.43; 18 studies).

Appendix F Figure 18 Lifestyle vs. Control: Systolic Blood Pressure (>24 Months)

Appendix Figure 18 displays a forest plot reporting the difference in means for systolic blood pressure, lifestyle intervention vs. control at followups greater than 24 months. Six trials of followups greater than 24 months yielded a pooled WMD of −1.44 (95% CI, −3.08 to 0.21; I2 = 25.97) for systolic blood pressure.

Appendix F Figure 19 Lifestyle vs. Control: Systolic Blood Pressure (12-24 Months)

Appendix Figure 19 displays a forest plot reporting the difference in means for systolic blood pressure, lifestyle intervention vs. control at followups between 12 to 24 months. Fourteen trials of followups between 12 to 24 months yielded a pooled WMD of −1.39 (95% CI, −2.60 to −0.17; I2 = 64.56) for systolic blood pressure.

Appendix F Figure 20 Lifestyle vs. Control: Systolic Blood Pressure (<12 Months)

Appendix Figure 20 displays a forest plot reporting the difference in means for systolic blood pressure, lifestyle intervention vs. control at followups less than 12 months. Five trials of followups less than 12 months yielded a pooled WMD of −0.15 (95% CI, −2.31 to 2.01; I2 = 33.17) for systolic blood pressure.

Appendix F Figure 21 High Contact Lifestyle vs. Control: Systolic Blood Pressure

Appendix Figure 21 displays a forest plot reporting the difference in means for systolic blood pressure, high contact lifestyle intervention vs. control. Thirteen trials of high contact lifestyle interventions yielded a pooled WMD of −2.11 (95% CI, −3.01 to −1.21; I2 = 1.53) for systolic blood pressure.

Appendix F Figure 22 Medium Contact Lifestyle vs. Control: Systolic Blood Pressure

Appendix Figure 22 displays a forest plot reporting the difference in means for systolic blood pressure, medium contact lifestyle intervention vs. control. Five trials of medium contact lifestyle interventions yielded a pooled WMD of −0.60 (95% CI, −2.86 to 1.67; I2 = 24.30) for systolic blood pressure.

Appendix F Figure 23 Lifestyle vs. Control: Systolic Blood Pressure (BMI >30)

Appendix Figure 23 displays a forest plot reporting the difference in means for systolic blood pressure, lifestyle intervention vs. control in studies with a with a baseline mean or median BMI greater than 30 kg/m2. Thirteen trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of −2.23 (95% CI, −3.11 to −1.36, I2 = 0.00) for systolic blood pressure.

Appendix F Figure 24 Lifestyle vs. Control: Systolic Blood Pressure (BMI 25-29.9)

Appendix Figure 24 displays a forest plot reporting the difference in means for systolic blood pressure, lifestyle intervention vs. control in studies with a baseline mean or median BMI between 25 to 29.5 kg/m2. Five trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of −0.24 (95% CI, −1.84 to 1.36; I2 = 0.00) for systolic blood pressure.

Appendix F Figure 25 Lifestyle vs. Control: Diastolic Blood Pressure (All)

Appendix Figure 25 displays a forest plot reporting the difference in means for diastolic blood pressure, lifestyle interventions vs. control for all available followups. WMDs ranged between −4.90 (95% CI, −9.69 to −0.11) to 5.70 (95% CI, −1.52 to 12.92).

Appendix F Figure 26 Lifestyle vs. Control: Diastolic Blood Pressure (Endpoint)

Appendix Figure 26 displays a forest plot reporting the difference in means for diastolic blood pressure, lifestyle intervention vs. control. Using longest available followup, lifestyle interventions were associated with a reduction in diastolic blood pressure (pooled WMD, −1.22 [95% CI, −2.02 to −0.42]; I2 = 31.62; 15 studies).

Appendix F Figure 27 Lifestyle vs. Control: Diastolic Blood Pressure (>24 Months)

Appendix Figure 27 displays a forest plot reporting the difference in means for diastolic blood pressure, lifestyle intervention vs. control at followups greater than 24 months. Six trials of followups greater than 24 months yielded a pooled WMD of −0.55 (95% CI, −1.86 to 0.76; I2 = 51.82) for diastolic blood pressure.

Appendix F Figure 28 Lifestyle vs. Control: Diastolic Blood Pressure (12-24 Months)

Appendix Figure 28 displays a forest plot reporting the difference in means for diastolic blood pressure, lifestyle intervention vs. control at followups between 12 to 24 months. Twelve trials of followups between 12 to 24 months yielded a pooled WMD of −1.51 (95% CI, −2.52 to −0.49; I2 = 63.22) for diastolic blood pressure.

Appendix F Figure 29 Lifestyle vs. Control: Diastolic Blood Pressure (<12 months)

Appendix Figure 29 displays a forest plot reporting the difference in means for diastolic blood pressure, lifestyle intervention vs. control at followups less than 12 months. Three trials of followups less than 12 months yielded a pooled WMD of −0.44 (95% CI, −3.36 to 2.48; I2 = 67.18) for diastolic blood pressure.

Appendix F Figure 30 High Contact Lifestyle vs. Control: Diastolic Blood Pressure

Appendix Figure 30 displays a forest plot reporting the difference in means for diastolic blood pressure, high contact lifestyle intervention vs. control. Twelve trials of high contact lifestyle interventions yielded a pooled WMD of −1.35 (95% CI, −2.17 to −0.54; I2 = 25.84) in diastolic blood pressure.

Appendix F Figure 31 Medium Contact Lifestyle vs. Control: Diastolic Blood Pressure

Appendix Figure 31 displays a forest plot reporting the difference in means for diastolic blood pressure, medium contact lifestyle intervention vs. control. Two trials of medium contact lifestyle interventions yielded WMDs ranging between −1.00 (95% CI, −2.93 to 0.93) to 2.9 (95% CI, −0.98 to 6.70) in diastolic blood pressure.

Appendix F Figure 32 Lifestyle vs. Control: Diastolic Blood Pressure (BMI >30)

Appendix Figure 32 displays a forest plot reporting the difference in means for diastolic blood pressure, lifestyle intervention vs. control in studies with a baseline mean or median BMI greater than or equal to 30 kg/m2. Twelve trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of −1.52 (95% CI, −2.27 to −0.76, I2 = 18.12) in diastolic blood pressure.

Appendix F Figure 33 Lifestyle vs. Control: Diastolic Blood Pressure (BMI 25-29.9)

Appendix Figure 33 displays a forest plot reporting the difference in means for diastolic blood pressure, lifestyle intervention vs. control in studies with a baseline mean or median BMI between 25 to 29.5 kg/m2. Three trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of 1.01 (95% CI, −2.26 to 4.29; I2 = 52.75) in diastolic blood pressure.

Appendix F Figure 34 Lifestyle vs. Control: Total Cholesterol (All)

Appendix Figure 34 displays a forest plot reporting the difference in means for total cholesterol, lifestyle interventions vs. control for all available followups. WMDs ranged between −11.99 (95% CI, −25.02 to 1.04) to 10.06 (95% CI, 8.80 to 11.32).

Appendix F Figure 35 Lifestyle vs. Control: Total Cholesterol (Endpoint)

Appendix Figure 35 displays a forest plot reporting the difference in means for total cholesterol, lifestyle intervention vs. control. Using longest available followup, 19 trials yielded a pooled WMD, −0.69 (95% CI, −2.23 to −0.86; I2 = 83.17) in total cholesterol.

Appendix F Figure 36 Lifestyle vs. Control: Total Cholesterol (>24 Months)

Appendix Figure 36 displays a forest plot reporting the difference in means for total cholesterol, lifestyle intervention vs. control at followups greater than 24 months. Six trials of followups greater than 24 months yielded a pooled WMD of 0.66 (95% CI, −5.57 to 6.90; I2 = 84.76) in total cholesterol.

Appendix F Figure 37 Lifestyle vs. Control: Total Cholesterol (12-24 Months)

Appendix Figure 37 displays a forest plot reporting the difference in means for total cholesterol, lifestyle intervention vs. control at followups between 12 to 24 months. Fourteen trials of followups between 12 to 24 months yielded a pooled WMD of −0.27 (95% CI, −0.60 to 0.06; I2 = 16.11) in total cholesterol.

Appendix F Figure 38 Lifestyle vs. Control: Total Cholesterol (<12 Months)

Appendix Figure 38 displays a forest plot reporting the difference in means for total cholesterol, lifestyle intervention vs. control at followups less than 12 months. Four trials of followups less than 12 months yielded a pooled WMD of −3.03 (95% CI, −6.62 to 0.57; I2 = 0.00) in total cholesterol.

Appendix F Figure 39 High Contact Lifestyle vs. Control: Total Cholesterol

Appendix Figure 39 displays a forest plot reporting the difference in means for total cholesterol, high contact lifestyle intervention vs. control. Twelve trials of high contact lifestyle interventions yielded a pooled WMD of −0.07 (95% CI, −2.84 to 2.70; I2 = 88.60) in total cholesterol.

Appendix F Figure 40 Medium Contact Lifestyle vs. Control: Total Cholesterol

Appendix Figure 40 displays a forest plot reporting the difference in means for total cholesterol, medium contact lifestyle intervention vs. control. Seven trials of medium contact lifestyle interventions yielded a pooled WMD of −4.10 (95% CI, −6.43 to −1.77; I2 = 0.00) in total cholesterol.

Appendix F Figure 41 Lifestyle vs. Control: Total Cholesterol (BMI >30)

Appendix Figure 41 displays a forest plot reporting the difference in means for total cholesterol, lifestyle intervention vs. control in studies with a baseline mean or median BMI greater than or equal to 30 kg/m2. Twelve trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of 0.56 (95% CI, −1.21 to 2.32, I2 = 87.97) in total cholesterol.

Appendix F Figure 42 Lifestyle vs. Control: Total Cholesterol (BMI 25-29.9)

Appendix Figure 42 displays a forest plot reporting the difference in means for total cholesterol, lifestyle intervention vs. control in studies with a baseline mean or median BMI between 25 to 29.5 kg/m2. Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of −3.98 (95% CI, −6.60 to −1.36; I2 = 0.00) in total cholesterol.

Appendix F Figure 43 Lifestyle vs. Control: Total Cholesterol (BMI <25)

Appendix Figure 43 displays a forest plot reporting the difference in means for total cholesterol, lifestyle intervention vs. control in studies with a baseline mean or median BMI less than 25 kg/m2. One trial with a baseline mean or median BMI less than 25 kg/m2 yielded a WMD of −4.5 (95% CI, −8.08 to −0.92; I2 = N/A) in total cholesterol.

Appendix F Figure 44 Lifestyle vs. Control: High Density Lipoprotein (All)

Appendix Figure 44 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle interventions vs. control for all available followups. WMDs ranged between −2.70 (95% CI, −8.13 to 2.73) to 6.70 (95% CI, 0.89 to 13.31).

Appendix F Figure 45 Lifestyle vs. Control: High Density Lipoprotein (Endpoint)

Appendix Figure 45 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle intervention vs. control. Using longest available followup, 21 trials yielded a pooled WMD, 0.00 (95% CI, 0.00 to 0.00; I2 = 58.80) in high density lipoprotein.

Appendix F Figure 46 Lifestyle vs. Control: High Density Lipoprotein (Endpoint) Sensitivity Analysis

Note: This sensitivity analysis removed one study from Figure 45 (Moungngern, 2018), a study that found no difference between groups, had just 125 participants, and was potentially overweighted in the meta-analysis.

Appendix Figure 46 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle intervention vs. control, sensitivity analyses. The sensitivity analysis removed Moungngern (2018), a study that found no difference between groups, had just 125 participants, and was potentially overweighted in the meta-analysis. Using longest available followup, 20 trials yielded a pooled WMD, 0.00 (95% CI, −0.01 to 0.01; I2 = 60.67) in high density lipoprotein.

Appendix F Figure 47 Lifestyle vs. Control: High Density Lipoprotein (>24 Months)

Appendix Figure 47 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle intervention vs. control at followups greater than 24 months. Seven trials of followups greater than 24 months yielded a pooled WMD of 2.25 (95% CI, 0.74 to 3.77; I2 = 57.96) in high density lipoprotein.

Appendix F Figure 48 Lifestyle vs. Control: High Density Lipoprotein (12-24 Months)

Appendix Figure 48 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle intervention vs. control at followups between 12 to 24 months. Fifteen trials of followups between 12 to 24 months yielded a pooled WMD of 0.00 (95% CI, −0.01 to 0.01; I2 = 34.16) in high density lipoprotein.

Appendix F Figure 49 Lifestyle vs. Control: High Density Lipoprotein (<12 Months)

Appendix Figure 49 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle intervention vs. control at followups less than 12 months. Five trials of followups less than 12 months yielded a pooled WMD of 0.00 (95% CI, 0.00 to 0.00; I2 = 0.00) in high density lipoprotein.

Appendix F Figure 50 Lifestyle vs. Control: High Density Lipoprotein (<12 Months) Sensitivity Analysis

Note: This sensitivity analysis removed one study from Figure 49 (Moungngern, 2018), a study that found no difference between groups, had just 125 participants, and was potentially overweighted in the meta-analysis.

Appendix Figure 50 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle intervention vs. control at followups less than 12 months, sensitivity analyses (removing Moungngern (2018)). Four trials of followups less than 12 months yielded a pooled WMD of 0.17 (95% CI, −0.16 to 0.50; I2 = 0.00) in high density lipoprotein.

Appendix F Figure 51 High Contact Lifestyle vs. Control: High Density Lipoprotein

Appendix Figure 51 displays a forest plot reporting the difference in means for high density lipoprotein, high contact lifestyle intervention vs. control. Fourteen trials of high contact lifestyle interventions yielded a pooled WMD of 0.00 (95% CI, −0.01 to 0.01; I2 = 72.80) in high density lipoprotein.

Appendix F Figure 52 High Contact Lifestyle vs. Control: High Density Lipoprotein Sensitivity Analysis

Note: This sensitivity analysis removed one study from Figure 51 (Moungngern, 2018), a study that found no difference between groups, had just 125 participants, and was potentially overweighted in the meta-analysis.

Appendix Figure 52 displays a forest plot reporting the difference in means for high density lipoprotein, high contact lifestyle intervention vs. control, sensitivity analyses (removing Moungngern (2018)). Thirteen trials of high contact lifestyle interventions yielded a pooled WMD of 1.10 (95% CI, 0.36 to 1.84; I2 = 74.89) in high density lipoprotein.

Appendix F Figure 53 High Contact Lifestyle vs. Control: High Density Lipoprotein Sensitivity Analysis

Note: This sensitivity analysis removed three studies from Figure 51 (Hellgren, 2014; Juul, 2016; and Moungngern, 2018) that found no difference between groups and were potentially overweighted in the meta-analysis.

Appendix Figure 53 displays a forest plot reporting the difference in means for high density lipoprotein, high contact lifestyle intervention vs. control, sensitivity analyses (removing 3 studies that found no differences between groups and that were potentially overweighted in the meta-analysis). Eleven trials of high contact lifestyle interventions yielded a pooled WMD of 1.35 (95% CI, 0.56 to 2.14; I2 = 52.22) in high density lipoprotein.

Appendix F Figure 54 Medium Contact Lifestyle vs. Control: High Density Lipoprotein

Appendix Figure 54 displays a forest plot reporting the difference in means for high density lipoprotein, medium contact lifestyle intervention vs. control. Seven trials of medium contact lifestyle interventions yielded a pooled WMD of 0.00 (95% CI, −0.00 to 0.00; I2 = 0.00) in high density lipoprotein.

Appendix F Figure 55 Lifestyle vs. Control: High Density Lipoprotein (BMI >30)

Appendix Figure 55 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle intervention vs. control in studies with a baseline mean or median BMI greater than or equal to 30 kg/m2. Fourteen trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of 0.30 (95% CI, 0.05 to 0.55, I2 = 63.20) in high density lipoprotein.

Appendix F Figure 56 Lifestyle vs. Control: High Density Lipoprotein (BMI 25-29.9)

Appendix Figure 56 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle intervention vs. control in studies with a baseline mean or median BMI between 25 to 29.5 kg/m2. Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of 0.00 (95% CI, −0.00 to 0.00; I2 = 59.16) in high density lipoprotein.

Appendix F Figure 57 Lifestyle vs. Control: High Density Lipoprotein (BMI 25-29.9) Sensitivity Analysis

Note: This sensitivity analysis removed one study from Figure 56 (Moungngern, 2018), a study that found no difference between groups, had just 125 participants, and was potentially overweighted in the meta-analysis.

Appendix Figure 57 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle intervention vs. control in studies with a baseline mean or median BMI between 25 to 29.5 kg/m2, sensitivity analysis (removing Moungngern (2018)). Five trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of 0.28 (95% CI, −0.22 to 0.78; I2 = 65.96) in high density lipoprotein.

Appendix F Figure 58 Lifestyle vs. Control: High Density Lipoprotein (BMI 25-29.9) Sensitivity Analysis

Note: This sensitivity analysis removed two studies from Figure 56 (Moungngern, 2018; Yates, 2009 [PREPARE with pedometer]) that found no difference between groups and were potentially overweighted in the meta-analysis.

Appendix Figure 58 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle intervention vs. control in studies with a baseline mean or median BMI between 25 to 29.5 kg/m2, sensitivity analysis (removing two studies that found no differences between groups and that were potentially overweighted in the meta-analysis). Five trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of 1.78 (95% CI, −0.44 to 2.79; I2 = 66.09) in high density lipoprotein.

Appendix F Figure 59 Lifestyle vs. Control: High Density Lipoprotein (BMI <25)

Appendix Figure 59 displays a forest plot reporting the difference in means for high density lipoprotein, lifestyle intervention vs. control in studies with a baseline mean or median BMI less than 25 kg/m2. One trial with a baseline mean or median BMI less than 25 kg/m2 yielded a WMD of 1.00 (95% CI, −1.40 to 3.40; I2 = N/A) in high density lipoprotein.

Appendix F Figure 60 Lifestyle vs. Control: Low Density Lipoprotein (All)

Appendix Figure 60 displays a forest plot reporting the difference in means for low density lipoprotein, lifestyle interventions vs. control for all available followups. WMDs ranged between −16.30 (95% CI, −38.24 to 5.635) to 5.81 (95% CI, 0.65 to 10.97).

Appendix F Figure 61 Lifestyle vs. Control: Low Density Lipoprotein (Endpoint)

Appendix Figure 61 displays a forest plot reporting the difference in means for low density lipoprotein, lifestyle intervention vs. control. Using longest available followup, 12 trials yielded a pooled WMD, −0.18 (95% CI, −0.52 to 0.17; I2 = 4.94) in low density lipoprotein.

Appendix F Figure 62 Lifestyle vs. Control: Low Density Lipoprotein (>24 Months)

Appendix Figure 62 displays a forest plot reporting the difference in means for low density lipoprotein, lifestyle intervention vs. control at followups greater than 24 months. Five trials of followups greater than 24 months yielded a pooled WMD of 0.10 (95% CI, −3.97 to 4.16; I2 = 52.58) in low density lipoprotein.

Appendix F Figure 63 Lifestyle vs. Control: Low Density Lipoprotein (12-24 Months)

Appendix Figure 63 displays a forest plot reporting the difference in means for low density lipoprotein, lifestyle intervention vs. control at followups 12 to 24 months. Eight trials of followups between 12 to 24 months yielded a pooled WMD of −0.25 (95% CI, −0.66 to 0.16; I2 = 12.98) in low density lipoprotein.

Appendix F Figure 64 Lifestyle vs. Control: Low Density Lipoprotein (<12 Months)

Appendix Figure 64 displays a forest plot reporting the difference in means for low density lipoprotein, lifestyle intervention vs. control at followups less than 12 months. Three trials of followups less than 12 months yielded a pooled WMD of −1.58 (95% CI, −8.22 to 5.06; I2 = 37.31) in low density lipoprotein.

Appendix F Figure 65 High Contact Lifestyle vs. Control: Low Density Lipoprotein

Appendix Figure 65 displays a forest plot reporting the difference in means for low density lipoprotein, high contact lifestyle intervention vs. control. Eight trials of high contact lifestyle interventions yielded a pooled WMD of 0.01 (95% CI, −1.72 to 1.74; I2 = 27.4) in low density lipoprotein.

Appendix F Figure 66 Medium Contact Lifestyle vs. Control: Low Density Lipoprotein

Appendix Figure 66 displays a forest plot reporting the difference in means for low density lipoprotein, medium contact lifestyle intervention vs. control. Four trials of medium contact lifestyle interventions yielded a pooled WMD of 0.98 (95% CI, −7.22 to 9.18; I2 = 0.00) in low density lipoprotein.

Appendix F Figure 67 Lifestyle vs. Control: Triglycerides (All)

Appendix Figure 67 displays a forest plot reporting the difference in means for triglycerides, lifestyle interventions vs. control for all available followups. WMDs ranged between −49.400 (95% CI, −90.16 to −8.64) to 53.20 (95% CI, 9.47 to 96.93).

Appendix F Figure 68 Lifestyle vs. Control: Triglycerides (Endpoint)

Appendix Figure 68 displays a forest plot reporting the difference in means for triglycerides, lifestyle intervention vs. control. Using longest available followup, 19 trials yielded a pooled WMD, −0.21 (95% CI, −0.71 to 0.28; I2 = 61.95) in triglycerides.

Appendix F Figure 69 Lifestyle vs. Control: Triglycerides (Endpoint) Sensitivity Analysis

Note: This sensitivity analysis removed one study from Figure 68 (Aekplakorn, 2019), a study that found no difference between groups and was potentially overweighted in the meta-analysis.

Appendix Figure 69 displays a forest plot reporting the difference in means for triglycerides, lifestyle intervention vs. control, sensitivity analysis (removing Aekplakorn (2019)). Using longest available followup, 18 trials yielded a pooled WMD, −0.93 (95% CI, −2.05 to 0.19; I2 = 63.26) in triglycerides.

Appendix F Figure 70 Lifestyle vs. Control: Triglycerides (>24 Months)

Appendix Figure 70 displays a forest plot reporting the difference in means for triglycerides, lifestyle intervention vs. control at followups greater than 24 months. Seven trials of followups greater than 24 months yielded a pooled WMD of −6.13 (95% CI, −12.73 to 0.47; I2 = 67.87) in triglycerides.

Appendix F Figure 71 Lifestyle vs. Control: Triglycerides (>24 Months) Sensitivity Analysis

Note: This sensitivity analysis removed one study from Figure 70 (Aekplakorn, 2019), a study that found no difference between groups and was potentially overweighted in the meta-analysis.

Appendix Figure 71 displays a forest plot reporting the difference in means for triglycerides, lifestyle intervention vs. control at followups greater than 24 months, sensitivity analysis (removing Aekplakorn (2019)). Six trials of followups greater than 24 months yielded a pooled WMD of −9.28 (95% CI, −14.45 to −4.11; I2 = 3.87) in triglycerides.

Appendix F Figure 72 Lifestyle vs. Control: Triglycerides (12-24 Months)

Appendix Figure 72 displays a forest plot reporting the difference in means for triglycerides, lifestyle intervention vs. control at followups between 12 to 24 months. Thirteen trials of followups between 12 to 24 months yielded a pooled WMD of −0.41 (95% CI, −1.34 to 0.52; I2 = 59.54) in triglycerides.

Appendix F Figure 73 Lifestyle vs. Control: Triglycerides (<12 Months)

Appendix Figure73 displays a forest plot reporting the difference in means for triglycerides, lifestyle intervention vs. control at followups less than 12 months. Five trials of followups less than 12 months yielded a pooled WMD of 4.06 (95% CI, −11.54 to 19.66; I2 = 47.19) in triglycerides.

Appendix F Figure 74 High Contact Lifestyle vs. Control: Triglycerides

Appendix Figure 74 displays a forest plot reporting the difference in means for triglycerides, high contact lifestyle intervention vs. control. Twelve trials of high contact lifestyle interventions yielded a pooled WMD of −0.33 (95% CI, −1.12 to 0.47; I2 = 71.85) in triglycerides.

Appendix F Figure 75 High Contact Lifestyle vs. Control: Triglycerides Sensitivity Analysis

Note: This sensitivity analysis removed one study from Figure 74 (Aekplakorn, 2019), a study that found no difference between groups and was potentially overweighted in the meta-analysis.

Appendix Figure 75 displays a forest plot reporting the difference in means for triglycerides, high contact lifestyle intervention vs. control, sensitivity analysis (removing Aekplakorn (2019)). Eleven trials of high contact lifestyle interventions yielded a pooled WMD of −8.24 (95% CI, −15.11 to −1.36; I2 = 74.40) in triglycerides.

Appendix F Figure 76 Medium Contact Lifestyle vs. Control: Triglycerides

Appendix Figure 76 displays a forest plot reporting the difference in means for triglycerides, medium contact lifestyle intervention vs. control. Seven trials of medium contact lifestyle interventions yielded a pooled WMD of −1.42 (95% CI, −9.13 to −6.29; I2 = 30.53) in triglycerides.

Appendix F Figure 77 Lifestyle vs. Control: Triglycerides (BMI >30)

Appendix Figure 77 displays a forest plot reporting the difference in means for triglycerides, lifestyle intervention vs. control in studies with a baseline mean or median BMI greater than or equal to 30 kg/m2. Twelve trials with a baseline mean or median BMI greater than or equal to 30 kg/m2 yielded a pooled WMD of −0.77 (95% CI, −1.89 to 0.34, I2 = 71.39) in triglycerides.

Appendix F Figure 78 Lifestyle vs. Control: Triglycerides (BMI 25-29.9)

Appendix Figure 78 displays a forest plot reporting the difference in means for triglycerides, lifestyle intervention vs. control in studies with a baseline mean or median BMI between 25 to 29.5 kg/m2. Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of 0.42 (95% CI, −5.84 to 6.68; I2 = 26.90) in triglycerides.

Appendix F Figure 79 Lifestyle vs. Control: Triglycerides (BMI 25-29.9) Sensitivity Analysis

Note: This sensitivity analysis removed one study from Figure 78 (Aekplakorn, 2019), a study that found no difference between groups and was potentially overweighted in the meta-analysis.

Appendix Figure 79 displays a forest plot reporting the difference in means for triglycerides, lifestyle intervention vs. control in studies with a baseline mean or median BMI between 25 to 29.5 kg/m2, sensitivity analysis. Five trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of 4.50 (95% CI, −9.24 to 18.24; I2 = 38.86) in triglycerides.

Appendix F Figure 80 Lifestyle vs. Control: Triglycerides (BMI <25)

Appendix Figure 80 displays a forest plot reporting the difference in means for triglycerides, lifestyle intervention vs. control in studies with a baseline mean or median BMI less than 25 kg/m2. One trial with a baseline mean or median BMI less than 25 kg/m2 yielded a WMD of −3.50 (95% CI, −8.83 to 1.83; I2 = N/A) in triglycerides.

Appendix F Figure 81 Lifestyle vs. Control: Weight Continuous (All)

Appendix Figure 81 displays a forest plot reporting the difference in means for weight, lifestyle interventions vs. control for all available followups. WMDs ranged between −5.20 (95% CI, −8.23 to −2.17 to 2.30 (95% CI, −0.76 to 5.36).

Appendix F Figure 82 Lifestyle vs. Control: Weight Continuous (Endpoint)

Appendix Figure 82 displays a forest plot reporting the difference in means for weight, lifestyle intervention vs. control. Using longest available followup, 27 trials yielded a pooled WMD, −1.15 (95% CI, −1.56 to −0.74; I2 = 80.84) in weight.

Appendix F Figure 83 Lifestyle vs. Control: Weight Continuous (>24 Months)

Appendix Figure 83 displays a forest plot reporting the difference in means for weight, lifestyle intervention vs. control at followups greater than 24 months. Twelve trials of followups greater than 24 months yielded a pooled WMD of −0.85 (95% CI, −1.34 to −0.36; I2 = 82.05) in weight.

Appendix F Figure 84 Lifestyle vs. Control: Weight Continuous (12-24 Months)

Appendix Figure 84 displays a forest plot reporting the difference in means for weight, lifestyle intervention vs. control at followups between 12 to 24 months. Eighteen trials of followups between 12 to 24 months yielded a pooled WMD of −1.35 (95% CI, −2.05 to −0.65; I2 = 89.56) in weight.

Appendix F Figure 85 Lifestyle vs. Control: Weight Continuous (<12 Months)

Appendix Figure 85 displays a forest plot reporting the difference in means for weight, lifestyle intervention vs. control at followups less than 12 months. Seven trials of followups less than 12 months yielded a pooled WMD of −0.59 (95% CI, −1.20 to 0.01; I2 = 70.44) in weight.

Appendix F Figure 86 High Contact Lifestyle vs. Control: Weight Continuous

Appendix Figure 86 displays a forest plot reporting the difference in means for weight, high contact lifestyle intervention vs. control. Twenty trials of high contact lifestyle interventions yielded a pooled WMD of −1.37 (95% CI, −1.91 to −0.84; I2 = 77.12) in weight.

Appendix F Figure 87 Medium Contact Lifestyle vs. Control: Weight Continuous

Appendix Figure 87 displays a forest plot reporting the difference in means for weight, medium contact lifestyle intervention vs. control. Seven trials of medium contact lifestyle interventions yielded a pooled WMD of −0.75 (95% CI, −1.42 to −0.08; I2 = 85.26) in weight.

Appendix F Figure 88 Lifestyle vs. Control: Weight Continuous (BMI >30)

Appendix Figure 88 displays a forest plot reporting the difference in means for weight, lifestyle intervention vs. control in studies with a baseline mean or median BMI greater than or equal to 30 kg/m2. Sixteen trials with a baseline mean or median BMI greater or equal to 30 kg/m2 yielded a pooled WMD of −1.79 (95% CI, −2.48 to −1.11, I2 = 76.53) in weight.

Appendix F Figure 89 Lifestyle vs. Control: Weight Continuous (BMI 25-29.9)

Appendix Figure 89 displays a forest plot reporting the difference in means for weight, lifestyle intervention vs. control in studies with a baseline mean or median BMI between 25 to 29.5 kg/m2. Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of −0.36 (95% CI, −1.02 to 0.30; I2 = 78.34) in weight.

Appendix F Figure 90 Lifestyle vs. Control: Weight Continuous (<BMI 25)

Appendix Figure 90 displays a forest plot reporting the difference in means for weight, lifestyle intervention vs. control in studies with a baseline mean or median BMI less than 25 kg/m2. Four trials with a baseline mean or median BMI less than 25 kg/m2 yielded a pooled WMD of −1.09 (95% CI, −1.93 to −0.24; I2 = 79.00) in weight.

Appendix F Figure 91 Lifestyle vs. Control: Weight Binary

Appendix Figure 91 displays a forest plot reporting the risk ratio (RR) of weight loss using binary measures for all available followups. RRs ranged between 0.85 (95% CI, 0.71 to 1.03) to 20.96 (95% CI, 5.17 to 84.92).

Appendix F Figure 92 Lifestyle vs. Control: Weight Binary (Endpoint)

Appendix Figure 92 displays a forest plot reporting the risk ratio (RR) of weight loss (greater than 5%) using binary measures, lifestyle intervention vs. control. Using the longest available followup, lifestyle interventions were associated with increased weight loss (pooled RR, 3.33 [95% CI, 2.65 to 4.18]; I2 = 61.29; 9 studies).

Appendix F Figure 93 Lifestyle vs. Control: 5% Weight Loss (12-24 Months)

Appendix Figure 93 displays a forest plot reporting the risk ratio (RR) of weight loss (greater than 5%) at followups between 12 to 24 months, lifestyle intervention vs. control. At followups between 12 to 24 months, lifestyle interventions were associated with increased weight loss (pooled RR, 3.03 [95% CI, 2.24 to 4.12]; I2 = 74.36; 6 studies).

Appendix F Figure 94 High Contact Lifestyle vs. Control: Weight Loss Binary

Appendix Figure 94 displays a forest plot reporting the risk ratio (RR) of weight loss (greater than 5%), high contact lifestyle intervention vs. control. High contact lifestyle interventions were associated with increased weight loss (pooled RR, 3.52 [95% CI, 2.82 to 4.40]; I2 = 57.94; 8 studies).

Appendix F Figure 95 Lifestyle vs. Control: BMI (All)

Appendix Figure 95 displays a forest plot reporting the difference in means for BMI, lifestyle interventions vs. control for all available followups. WMDs ranged between −4.00 (95% CI, −6.37 to −1.63) to 2.30 (95% CI, −2.05 to 6.65).

Appendix F Figure 96 Lifestyle vs. Control: BMI (Endpoint)

Appendix Figure 96 displays a forest plot reporting the difference in means for BMI, lifestyle intervention vs. control. Using longest available followup, 19 trials yielded a pooled WMD, −0.54 (95% CI, −0.76 to −0.33; I2 = 70.50) in BMI.

Appendix F Figure 97 Lifestyle vs. Control: BMI (>24 Months)

Appendix Figure 97 displays a forest plot reporting the difference in means for BMI, lifestyle intervention vs. control at followups greater than 24 months. Eight trials of followups greater than 24 months yielded a pooled WMD of −0.41 (95% CI, −0.67 to −0.16; I2= 63.13) in BMI.

Appendix F Figure 98 Lifestyle vs. Control: BMI (12-24 Months)

Appendix Figure 98 displays a forest plot reporting the difference in means for BMI, lifestyle intervention vs. control at followups between 12 to 24 months. Twelve trials of followups between 12 to 24 months yielded a pooled WMD of −0.54 (95% CI, −0.80 to −0.28; I2 = 74.69) in BMI.

Appendix F Figure 99 Lifestyle vs. Control: BMI (<12 Months)

Appendix Figure 99 displays a forest plot reporting the difference in means for BMI, lifestyle intervention vs. control at followups less than 12 months. Six trials of followups less than 12 months yielded a pooled WMD of −0.36 (95% CI, −0.64 to −0.07; I2 = 63.57) in BMI.

Appendix F Figure 100 Lifestyle vs. Control: BMI (BMI >30)

Appendix Figure 100 displays a forest plot reporting the difference in means for BMI, lifestyle intervention vs. control in studies with a baseline mean or median BMI greater than or equal to 30 kg/m2. Eleven trials with a baseline mean or median BMI greater or equal to 30 kg/m2 yielded a pooled WMD of −0.64 (95% CI, −0.97 to −0.32, I2 = 73.64) in BMI.

Appendix F Figure 101 Lifestyle vs. Control: BMI (BMI 25-29.9)

Appendix Figure 101 displays a forest plot reporting the difference in means for BMI, lifestyle intervention vs. control in studies with a baseline mean or median BMI between 25 to 29.5 kg/m2. Six trials with a baseline mean or median BMI between 25 to 29.5 kg/m2 yielded a pooled WMD of −0.34 (95% CI, −0.58 to −0.10; I2 = 47.91) in BMI.

Appendix F Figure 102 Lifestyle vs. Control: BMI (BMI <25)

Appendix Figure 102 displays a forest plot reporting the difference in means for weight, lifestyle intervention vs. control in studies with a baseline mean or median BMI less than 25 kg/m2. Two trials with a baseline mean or median BMI less than 25 kg/m2 yielded WMDs ranging between of −0.40 (95% CI, −0.80 to 0.00) to −4.00 (95% CI, −6.37 to −1.63) in BMI.

Appendix F Figure 103 High Contact Lifestyle vs. Control: BMI

Appendix Figure 103 displays a forest plot reporting the difference in means for BMI, high contact lifestyle intervention vs. control. Twelve trials of high contact lifestyle interventions yielded a pooled WMD of −0.65 (95% CI, −0.99 to −0.31; I2 = 72.53) in BMI.

Appendix F Figure 104 Medium Contact Lifestyle vs. Control: BMI

Appendix Figure 104 displays a forest plot reporting the difference in means for BMI, medium contact lifestyle intervention vs. control. Eight trials of medium contact lifestyle interventions yielded a pooled WMD of −0.43 (95% CI, −0.72 to −0.14; I2 = 66.96) in BMI.

Appendix F Figure 105 Lifestyle vs. Control: 10-Year CVD Risk

Appendix Figure 105 displays a forest plot reporting the difference in means for 10-year CVD risk for one trial at 6 months, 12 months, 24 months, and 36 months of followup. The trial yielded WMDs between −0.74 (95% CI, −1.62 to 0.14) to 0.28 (95% CI, −0.80 to 1.36).

Appendix F Figure 106 Pharmacological or Combo vs. Control: Systolic Blood Pressure

Appendix Figure 106 displays a forest plot reporting the difference in means for systolic blood pressure, pharmacological intervention or combination vs. control for all available followups. WMDs ranged between −17.26 (95% CI, −25.79 to −8.73) to 0.28 (95% CI, −1.11 to 1.67).

Appendix F Figure 107 Pharmacological or Combo vs. Control: Diastolic Blood Pressure

Appendix Figure 107 displays a forest plot reporting the difference in means for diastolic blood pressure, pharmacological intervention or combination vs. control for all available followups. WMDs ranged between −6.44 (95% CI, −9.62 to −3.26) to 0.28 (95% CI, −0.54 to 1.12).

Appendix F Figure 108 Pharmacological or Combo vs. Control: Total Cholesterol

Appendix Figure 108 displays a forest plot reporting the difference in means for total cholesterol, pharmacological intervention or combination vs. control for all available followups. WMDs ranged between −77.34 (95% CI, −146.02 to −8.66) to 15.46 (95% CI, 6.47 to 24.45).

Appendix F Figure 109 Pharmacological or Combo vs. Control: High Density Lipoprotein

Appendix Figure 109 displays a forest plot reporting the difference in means for high density lipoprotein, pharmacological intervention or combination vs. control. WMDs ranged between −2.90 (95% CI, −6.63 to 0.83) to 34.80 (95% CI, −22.01 to 91.61).

Appendix F Figure 110 Pharmacological or Combo vs. Control: Low Density Lipoprotein

Appendix Figure 110 displays a forest plot reporting the difference in means for low density lipoprotein, pharmacological intervention or combination vs. control. WMDs ranged between −77.34 (95% CI, −169.46 to 14.78) to −0.39 (95% CI, −7.15 to 6.37).

Appendix F Figure 111 Pharmacological or Combo vs. Control: Triglycerides

Appendix Figure 111 displays a forest plot reporting the difference in means for triglycerides, pharmacological intervention or combination vs. control. WMDs ranged between −531.42 (95% CI, −819.07 to −243.77) to 51.37 (95% CI, 0.54 to 102.20).

Appendix F Figure 112 Pharmacological or Combo vs. Control: Weight Continuous (All)

Appendix Figure 112 displays a forest plot reporting the difference in means for weight, pharmacological intervention or combination vs. control. WMDs ranged between −3.50 (95% CI, −5.26 to −1.74) to 3.20 (95% CI, 1.30 to 5.10).

Appendix F Figure 113 Thiazolidinedione vs. Control: Weight Continuous

Appendix Figure 113 displays a forest plot reporting the difference in means for weight, thiazolidinedione vs. control. Three trials of thiazolidinedione vs. control yielded a pooled WMD of 1.91 (95% CI, 0.75 to 3.08; I2 = 70.91) in weight.

Appendix F Figure 114 Hypertension Treatment vs. Control: Weight Continuous

Appendix Figure 114 displays a forest plot reporting the difference in means for weight, hypertension treatment vs. control. Two trials of hypertension treatments yielded WMDs between −0.14 (95% CI, −0.29 to 0.011) to 0.28 (95% CI, 0.11 to 0.45).

Appendix F Figure 115 Rosiglitazone Plus Metformin vs. Control: Weight Loss or Weight Gain Binary

Appendix Figure 115 displays a forest plot reporting the risk ratio (RR) of weight loss (greater than 2 kg and greater than 3 kg) and weight gain (greater than 2 kg and greater than 3 kg), rosiglitazone plus metformin vs. control in one trial. The trial yielded a RR of 0.86 (95% CI, 0.56 to 1.31) for weight gain greater than 2kg and a RR of 1.01 (95% CI, 0.60 to 1.71) for weight gain greater than 3 kg. The trial yielded a RR of 0.70 (95% CI, 0.46 to 1.05) for weight loss greater than 2 kg and a RR of 0.68 (95% CI, 0.42 to 1.11) for weight loss greater than 3 kg.

Appendix F Figure 116 Pharmacological or Combo vs. Control: BMI

Appendix Figure 116 displays a forest plot reporting the difference in means for BMI, pharmacological or combination intervention vs. control. Nine trials yielded WMDs between −1.70 (95% CI, −2.55 to −0.84) to 1.20 (95% CI, 0.49 to 1.91) for BMI.

## Appendix References

1 Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998 Sep 12;352(9131):837–53. PMID: 9742976.9742976
2 American Diabetes Association. 2. Classification and diagnosis of diabetes: standards of medical care in diabetes-2018. Diabetes Care. 2018 Jan;41(Suppl 1):S13–S27. doi: 10.2337/dc18-S002. PMID: 29222373.29222373
3 International Diabetes Federation. IDF clinical practice recommendations for managing type 2 diabetes in primary care. Brussels Belgium: International Diabetes Foundation; 2017. https://www.idf.org/e-library/guidelines/128-idf-clinical-practice-recommendations-for-managing-type-2-diabetes-in-primary-care.html
4 The Royal Australian College of General Practitioners. General practice management of type 2 diabetes: 2016–18. RACGP. East Melbourne, Vic: 2016. https://www.racgp.org.au/download/Documents/Guidelines/Diabetes/2015diabetesmanagement.pdf
5 Handelsman Y, Bloomgarden ZT, Grunberger G, . American Association of Clinical Endocrinologists and American College of Endocrinology - clinical practice guidelines for developing a diabetes mellitus comprehensive care plan - 2015. Endocr Pract. 2015 Apr;21 Suppl 1:1–87. doi: 10.4158/EP15672.GL. PMID: 25869408.25869408
6 Redmon B, Caccamo D, Flavin P, . Diagnosis and management of type 2 diabetes mellitus in adults. Institute for Clinical Systems Improvement (ICSI). Bloomington, MN: 2014.
7 Canadian Diabetes Association Clinical Practice Guidelines Expert C, Ekoe JM, Punthakee Z, . Screening for type 1 and type 2 diabetes. Can J Diabetes. 2013 Apr;37 Suppl 1:S12–5. doi: 10.1016/j.jcjd.2013.01.012. PMID: 24070932.24070932
8 Authors/Task Force M, Ryden L, Grant PJ, . ESC Guidelines on diabetes, pre-diabetes, and cardiovascular diseases developed in collaboration with the EASD: the Task Force on diabetes, pre-diabetes, and cardiovascular diseases of the European Society of Cardiology (ESC) and developed in collaboration with the European Association for the Study of Diabetes (EASD). Eur Heart J. 2013 Oct;34(39):3035–87. doi: 10.1093/eurheartj/eht108. PMID: 23996285.23996285
9 Pottie K, Jaramillo A, Lewin G, . Recommendations on screening for type 2 diabetes in adults. CMAJ. 2012 Oct 16;184(15):1687–96. doi: 10.1503/cmaj.120732. PMID: 23073674.23073674
10 NICE. Type 2 diabetes: prevention in people at high risk. National Institute for Health and Care Excellence (NICE). Public health guideline [PH38]. 2012. https://www.nice.org.uk/guidance/ph38
11 Waugh NR, Shyangdan D, Taylor-Phillips S, . Screening for type 2 diabetes: a short report for the National Screening Committee. Health Technol Assess. 2013 Aug;17(35):1–90. doi: 10.3310/hta17350. PMID: 23972041.23972041
12 American Diabetes Association. 9. Cardiovascular disease and risk management: standards of medical care in diabetes-2018. Diabetes Care. 2018 Jan;41(Suppl 1):S86–S104. doi: 10.2337/dc18-S009. PMID: 29222380.29222380
13 American Diabetes Association. Standards of medical care in diabetes-2019 abridged for primary care providers. Clin Diabetes. 2019 Jan;37(1):11–34. doi: 10.2337/cd18-0105. PMID: 30705493.30705493
14 American Academy of Family Physicians. Aspirin use to prevent cardiovascular disease and colorectal cancer- clinical preventive service recommendation. Leawood, KS: American Academy of Family Physicians; 2016. https://www.aafp.org/patient-care/clinical-recommendations/all/aspirin-use-prevention.html.
15 Carey RM, Whelton PK, ACC AHA Hypertension Guideline Writing Committee. Prevention, detection, evaluation, and management of high blood pressure in adults: synopsis of the 2017 American College of Cardiology/American Heart Association Hypertension Guideline. Ann Intern Med. 2018 Mar 6;168(5):351–8. doi: 10.7326/M17-3203. PMID: 29357392.29357392
16 Qaseem A, Wilt TJ, Rich R, . Pharmacologic treatment of hypertension in adults aged 60 years or older to higher versus lower blood pressure targets: a clinical practice guideline from the American College of Physicians and the American Academy of Family Physicians. Ann Intern Med. 2017 Mar 21;166(6):430–7. doi: 10.7326/M16-1785. PMID: 28135725.28135725
17 Wilt TJ, Kansagara D, Qaseem A, . Hypertension limbo: balancing benefits, harms, and patient preferences before we lower the bar on blood pressure. Ann Intern Med. 2018 Mar 6;168(5):369–70. doi: 10.7326/M17-3293. PMID: 29357397.29357397
18 Barber S, Davies M, Khunti K, . Risk assessment tools for detecting those with pre-diabetes: a systematic review (Provisional abstract). Database of Abstracts of Reviews of Effects; 2014. p. 1–13.
19 Abbasi A, Peelen LM, Corpeleijn E, . Prediction models for risk of developing type 2 diabetes: systematic literature search and independent external validation study. BMJ. 2012 Sep 18;345:e5900. doi: 10.1136/bmj.e5900. PMID: 22990994.22990994
20 Noble D, Mathur R, Dent T, . Risk models and scores for type 2 diabetes: systematic review. BMJ. 2011 Nov 28;343:d7163. doi: 10.1136/bmj.d7163. PMID: 22123912.22123912
21 Buijsse B, Simmons RK, Griffin SJ, . Risk assessment tools for identifying individuals at risk of developing type 2 diabetes. Epidemiol Rev. 2011;33:46–62. doi: 10.1093/epirev/mxq019. PMID: 21622851.21622851
22 Wilson PW, Meigs JB, Sullivan L, . Prediction of incident diabetes mellitus in middle-aged adults: the Framingham Offspring Study. Arch Intern Med. 2007 May 28;167(10):1068–74. doi: 10.1001/archinte.167.10.1068. PMID: 17533210.17533210
23 Yoshizawa S, Kodama S, Fujihara K, . Utility of nonblood-based risk assessment for predicting type 2 diabetes mellitus: A meta-analysis. Prev Med. 2016 Oct;91:180–7. doi: 10.1016/j.ypmed.2016.07.026. PMID: 27473666.27473666
24 Balkau B, Lange C, Fezeu L, . Predicting diabetes: clinical, biological, and genetic approaches: data from the Epidemiological Study on the Insulin Resistance Syndrome (DESIR). Diabetes Care. 2008 Oct;31(10):2056–61. doi: 10.2337/dc08-0368. PMID: 18689695.18689695
25 American Diabetes Association. 16. Diabetes advocacy: standards of medical care in diabetes-2019. Diabetes Care. 2019 Jan;42(Suppl 1):S182–S3. doi: 10.2337/dc19-S016. PMID: 3055924230559242
26 Bang H, Edwards AM, Bomback AS, . Development and validation of a patient self-assessment score for diabetes risk. Ann Intern Med. 2009 Dec 1;151(11):775–83. doi: 10.7326/0003-4819-151-11-200912010-00005. PMID: 19949143.19949143
27 Alberti KG, Zimmet PZ. Definition, diagnosis and classification of diabetes mellitus and its complications. Part 1: diagnosis and classification of diabetes mellitus provisional report of a WHO consultation. Diabet Med. 1998 Jul;15(7):539–53. doi: 10.1002/(SICI)1096-9136(199807)15:7<539::AID-DIA668>3.0.CO;2-S. PMID: 9686693.9686693
28 Hawa MI, Buchan AP, Ola T, . LADA and CARDS: a prospective study of clinical outcome in established adult-onset autoimmune diabetes. Diabetes Care. 2014 Jun;37(6):1643–9. doi: 10.2337/dc13-2383. PMID: 24722498.24722498
29 Kuznetsov L, Long GH, Griffin SJ, . Are changes in glycaemic control associated with diabetes-specific quality of life and health status in screen-detected type 2 diabetes patients? Four-year follow up of the ADDITION-Cambridge cohort. Diabetes Metab Res Rev. 2015 Jan;31(1):69–75. doi: 10.1002/dmrr.2559. PMID: 24817063.24817063
30 Stoop CH, Nefs G, Pop VJ, . Diabetes-specific emotional distress in people with Type 2 diabetes: a comparison between primary and secondary care. Diabet Med. 2014 Oct;31(10):1252–9. doi: 10.1111/dme.12472. PMID: 24766062.24766062
31 Griffin SJ, Simmons RK, Prevost AT, . Multiple behaviour change intervention and outcomes in recently diagnosed type 2 diabetes: the ADDITION-Plus randomised controlled trial. Diabetologia. 2014 Jul;57(7):1308–19. doi: 10.1007/s00125-014-3236-6. PMID: 24759957.24759957
32 Black JA, Sharp SJ, Wareham NJ, . Change in cardiovascular risk factors following early diagnosis of type 2 diabetes: a cohort analysis of a cluster-randomised trial. Br J Gen Pract. 2014 Apr;64(621):e208–16. doi: 10.3399/bjgp14X677833. PMID: 24686885.24686885
33 Hannon TS, Kirkman MS, Patel YR, . Profound defects in beta-cell function in screen-detected type 2 diabetes are not improved with glucose-lowering treatment in the Early Diabetes Intervention Program (EDIP). Diabetes Metab Res Rev. 2014 Nov;30(8):767–76. doi: 10.1002/dmrr.2553. PMID: 24819707.24819707
34 Larsen JR, Vedtofte L, Holst JJ, . Does a GLP-1 receptor agonist change glucose tolerance in patients treated with antipsychotic medications? Design of a randomised, double-blinded, placebo-controlled clinical trial. BMJ Open. 2014 Mar 25;4(3):e004227. doi: 10.1136/bmjopen-2013-004227. PMID: 24667381.24667381
35 Kuznetsov L, Griffin SJ, Davies MJ, . Diabetes-specific quality of life but not health status is independently associated with glycaemic control among patients with type 2 diabetes: a cross-sectional analysis of the ADDITION-Europe trial cohort. Diabetes Res Clin Pract. 2014 May;104(2):281–7. doi: 10.1016/j.diabres.2013.12.029. PMID: 24636627.24636627
36 Bhopal RS, Douglas A, Wallia S, . Effect of a lifestyle intervention on weight change in south Asian individuals in the UK at high risk of type 2 diabetes: a family-cluster randomised controlled trial. Lancet Diabetes Endocrinol. 2014 Mar;2(3):218–27. doi: 10.1016/s2213-8587(13)70204-3. PMID: 24622752.24622752
37 Dalsgaard EM, Vestergaard M, Skriver MV, . Socioeconomic position and cardiovascular risk factors among people with screen-detected Type 2 DM: six-year follow-up of the ADDITION-Denmark trial. Prim Care Diabetes. 2014 Dec;8(4):322–9. doi: 10.1016/j.pcd.2014.01.006. PMID: 24613817.24613817
38 Sheppler CR, Lambert WE, Gardiner SK, . Predicting adherence to diabetic eye examinations: development of the compliance withAnnual Diabetic Eye Exams Survey. Ophthalmology. 2014 Jun;121(6):1212–9. doi: 10.1016/j.ophtha.2013.12.016. PMID: 24518614.24518614
39 Kopf S, Oikonomou D, von Eynatten M, . Urinary excretion of high molecular weight adiponectin is an independent predictor of decline of renal function in type 2 diabetes. Acta Diabetol. 2014;51(3):479–89. doi: 10.1007/s00592-013-0542-2. PMID: 24366425.24366425
40 DuBose KD, Cummings DM, Imai S, . Development and validation of a tool for assessing glucose impairment in adolescents. Prev Chronic Dis. 2012;9:E104. PMID: 22632741.22632741
41 Heikes KE, Eddy DM, Arondekar B, . Diabetes Risk Calculator: a simple tool for detecting undiagnosed diabetes and pre-diabetes. Diabetes Care. 2008 May;31(5):1040–5. doi: 10.2337/dc07-1150. PMID: 18070993.18070993
42 Koopman RJ, Mainous AG, 3rd, Everett CJ, . Tool to assess likelihood of fasting glucose impairment (TAG-IT). Ann Fam Med. 2008 Nov–Dec;6(6):555–61. doi: 10.1370/afm.913. PMID: 19001309.19001309
43 Yu W, Liu T, Valdez R, . Application of support vector machine modeling for prediction of common diseases: the case of diabetes and pre-diabetes. BMC Med Inform Decis Mak. 2010 Mar 22;10:16. doi: 10.1186/1472-6947-10-16. PMID: 20307319.20307319
44 Schmidt MI, Duncan BB, Bang H, . Identifying individuals at high risk for diabetes: The Atherosclerosis Risk in Communities study. Diabetes Care. 2005 Aug;28(8):2013–8. doi: 10.2337/diacare.28.8.2013. PMID: 16043747.16043747
45 Stern MP, Williams K, Haffner SM. Identification of persons at high risk for type 2 diabetes mellitus: do we need the oral glucose tolerance test? Ann Intern Med. 2002;136:575–81.11955025
46 Mann DM, Bertoni AG, Shimbo D, . Comparative validity of 3 diabetes mellitus risk prediction scoring models in a multiethnic US cohort: the Multi-Ethnic Study of Atherosclerosis. Am J Epidemiol. 2010 May 1;171(9):980–8. doi: 10.1093/aje/kwq030. PMID: 20375194.20375194
47 Kanaya AM, Wassel Fyr CL, de Rekeneire N, . Predicting the development of diabetes in older adults: the derivation and validation of a prediction rule. Diabetes Care. 2005 Feb;28(2):404–8. doi: 10.2337/diacare.28.2.404. PMID: 15677800.15677800
48 Kahn HS, Cheng YJ, Thompson TJ, . Two risk-scoring systems for predicting incident diabetes mellitus in U.S. adults age 45 to 64 years. Ann Intern Med. 2009 Jun 2;150(11):741–51. doi: 10.7326/0003-4819-150-11-200906020-00002. PMID: 19487709.19487709
49 Barry E, Roberts S, Oke J, . Efficacy and effectiveness of screen and treat policies in prevention of type 2 diabetes: systematic review and meta-analysis of screening tests and interventions. BMJ. 2017 Jan 4;356:i6538. doi: 10.1136/bmj.i6538. PMID: 28052845.28052845
50 American Diabetes Association (ADA). 2. Classification and diagnosis of diabetes: standards of medical care in diabetes - 2018 Diabetes Care. 2018;41:S13–S27.29222373
51 World Health Organization. Use of glycated haemoglobin (HbA1c) in the diagnosis of diabetes mellitus: abbreviated report of a WHO consultation. WHO Press; 2011.
52 World Health Organization. HbA1c in the diagnosis of type 2 diabetes: a systematic review. Geneva, Switzerland: World Health Organization; 2011. https://www.who.int/diabetes/publications/sys_rev_hba1c_web.pdf.
53 Diabetes Canada Clinical Practice Guidelines Expert Committee, Ekoe JM, Goldenberg R, . Screening for diabetes in adults. Can J Diabetes. 2018 Apr;42 Suppl 1:S16–S9. doi: 10.1016/j.jcjd.2017.10.004. PMID: 29650090.29650090
54 Stinton C, Fraser H, Geppert J, . Screening for type 2 diabetes in adults: external review against programme appraisal criteria for the UK national screening committee version: 3 – consultation document. England: Crown Copyright; 2019. https://legacyscreening.phe.org.uk/diabetes.
55 Kowall B, Rathmann W, Heier M, . Categories of glucose tolerance and continuous glycemic measures and mortality. Eur J Epidemiol. 2011 Aug;26(8):637–45. doi: 10.1007/s10654-011-9609-y. PMID: 21785986.21785986
56 Barr EL, Boyko EJ, Zimmet PZ, . Continuous relationships between non-diabetic hyperglycaemia and both cardiovascular disease and all-cause mortality: the Australian Diabetes, Obesity, and Lifestyle (AusDiab) study. Diabetologia. 2009 Mar;52(3):415–24. doi: 10.1007/s00125-008-1246-y. PMID: 19130039.19130039
57 Massin P, Lange C, Tichet J, . Hemoglobin A1c and fasting plasma glucose levels as predictors of retinopathy at 10 years: the French DESIR Study HbA1c, fasting glucose, and 10-year retinopathy. JAMA Ophthalmology. 2011;129(2):188–95. doi: 10.1001/archophthalmol.2010.353 %J JAMA Ophthalmology.
58 Tapp RJ, Tikellis G, Wong TY, . Longitudinal association of glucose metabolism with retinopathy: results from the Australian Diabetes Obesity and Lifestyle (AusDiab) study. Diabetes Care. 2008 Jul;31(7):1349–54. doi: 10.2337/dc07-1707. PMID: 18411241.18411241
59 van Leiden HA, Dekker JM, Moll AC, . Risk factors for incident retinopathy in a diabetic and nondiabetic population: the Hoorn Study. JAMA Ophthalmology. 2003;121(2):245–51. doi: 10.1001/archopht.121.2.245 %J JAMA Ophthalmology.
60 McCance DR, Hanson RL, Charles MA, . Comparison of tests for glycated haemoglobin and fasting and two hour plasma glucose concentrations as diagnostic methods for diabetes.[Erratum appears in BMJ 1994 Oct;309(6958):841]. BMJ. 1994 May 21;308(6940):1323–8. PMID: 8019217.8019217
61 Martínez-Vizcaíno V, Cavero-Redondo I, Álvarez-Bueno C, . The accuracy of diagnostic methods for diabetic retinopathy: a systematic review and meta-analysis. PloS one. 2016;11(4):e0154411–e. doi: 10.1371/journal.pone.0154411. PMID: 27123641.27123641
62 American Diabetes Association. 2. Classification and diagnosis of diabetes: standards of medical care in diabetes-2019. Diabetes Care. 2019 Jan;42(Suppl 1):S13–S28. doi: 10.2337/dc19-S002. PMID: 30559228.30559228
63 de Vegt F, Dekker JM, Ruhe HG, . Hyperglycaemia is associated with all-cause and cardiovascular mortality in the Hoorn population: the Hoorn Study. Diabetologia. 1999 Aug;42(8):926–31. doi: 10.1007/s001250051249. PMID: 10491751.10491751
64 Metcalf PA, Kyle C, Kenealy T, . HbA_1c_ in relation to incident diabetes and diabetes-related complications in non-diabetic adults at baseline. J Diabetes Complications. 2017 May;31(5):814–23. doi: 10.1016/j.jdiacomp.2017.02.007. PMID: 28319002.28319002
65 Cederberg H, Saukkonen T, Laakso M, . Postchallenge glucose, A1C, and fasting glucose as predictors of type 2 diabetes and cardiovascular disease: a 10-year prospective cohort study. Diabetes Care. 2010 Sep;33(9):2077–83. doi: 10.2337/dc10-0262. PMID: 20573752.20573752
66 Kalogeropoulos A, Georgiopoulou V, Harris TB, . Glycemic status and incident heart failure in elderly without history of diabetes mellitus: the health, aging, and body composition study. J Card Fail. 2009 Sep;15(7):593–9. doi: 10.1016/j.cardfail.2009.03.001. PMID: 19700136.19700136
67 Brateanu A, Barwacz T, Kou L, . Determining the optimal screening interval for type 2 diabetes mellitus using a risk prediction model. PLoS One. 2017;12(11):e0187695. doi: 10.1371/journal.pone.0187695. PMID: 29135987.29135987
68 Lindeman RD, Yau CL, Baumgartner RN, . Longitudinal study of fasting serum glucose concentrations in healthy elderly. The New Mexico Aging Process Study. J Nutr Health Aging. 2003;7(3):172–7. PMID: 1276679512766795
69 Takahashi O, Farmer AJ, Shimbo T, . A1C to detect diabetes in healthy adults: when should we recheck? Diabetes Care. 2010 Sep;33(9):2016–7. doi: 10.2337/dc10-0588. PMID: 20566678.20566678
70 Selph S, Dana T, Blazina I, . Screening for type 2 diabetes mellitus: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2015 Jun 2;162(11):765–76. doi: 10.7326/m14-2221. PMID: 25867111.25867111
71 Kahn R, Alperin P, Eddy D, . Age at initiation and frequency of screening to detect type 2 diabetes: a cost-effectiveness analysis. Lancet. 2010 Apr 17;375(9723):1365–74. doi: 10.1016/S0140-6736(09)62162-0. PMID: 20356621.20356621
72 Gillies CL, Lambert PC, Abrams KR, . Different strategies for screening and prevention of type 2 diabetes in adults: cost effectiveness analysis. BMJ. 2008 May 24;336(7654):1180–5. doi: 10.1136/bmj.39545.585289.25. PMID: 18426840.18426840
73 Mortaz S, Wessman C, Duncan R, . Impact of screening and early detection of impaired fasting glucose tolerance and type 2 diabetes in Canada: a Markov model simulation. Clinicoecon Outcomes Res. 2012;4:91–7. doi: 10.2147/CEOR.S30547. PMID: 22553425.22553425
74 Hoerger TJ, Hicks KA, Sorensen SW, . Cost-effectiveness of screening for pre-diabetes among overweight and obese U.S. adults. Diabetes Care. 2007 Nov;30(11):2874–9. doi: 10.2337/dc07-0885. PMID: 17698614.17698614
75 Herman WH, Ye W, Griffin SJ, . Early detection and treatment of type 2 diabetes reduce cardiovascular morbidity and mortality: a simulation of the results of the Anglo-Danish-Dutch Study of Intensive Treatment in People With Screen-Detected Diabetes in Primary Care (ADDITION-Europe). Diabetes Care. 2015 Aug;38(8):1449–55. doi: 10.2337/dc14-2459. PMID: 25986661.25986661
76 Simmons RK, Borch-Johnsen K, Lauritzen T, . A randomised trial of the effect and cost-effectiveness of early intensive multifactorial therapy on 5-year cardiovascular outcomes in individuals with screen-detected type 2 diabetes: the Anglo-Danish-Dutch Study of Intensive Treatment in People with Screen-Detected Diabetes in Primary Care (ADDITION-Europe) study. Health Technol Assess. 2016 Aug;20(64):1–86. doi: 10.3310/hta20640. PMID: 27583404.27583404
77 Laxy M, Wilson ECF, Boothby CE, . Incremental costs and cost effectiveness of intensive treatment in individuals with type 2 diabetes detected by screening in the ADDITION-UK Trial: an update with empirical trial-based cost data. Value Health. 2017 Dec;20(10):1288–98. doi: 10.1016/j.jval.2017.05.018. PMID: 29241888.29241888
78 U.S. Preventive Services Task Force. Procedure manual. Rockville, MD: U.S. Preventive Services Task Force,; 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.
79 Diabetes Prevention Program Research G. Long-term effects of lifestyle intervention or metformin on diabetes development and microvascular complications over 15-year follow-up: the Diabetes Prevention Program Outcomes Study. Lancet Diabetes Endocrinol. 2015 Nov;3(11):866–75. doi: 10.1016/s2213-8587(15)00291-0. PMID: 26377054.26377054
80 Knowler WC, Barrett-Connor E, Fowler SE, . Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002 Feb 7;346(6):393–403. doi: 10.1056/NEJMoa012512. PMID: 11832527.11832527
81 Diabetes Prevention Program Research Group. Long-term effects of metformin on diabetes prevention: identification of subgroups that benefited most in the diabetes prevention program and diabetes prevention program outcomes study. Diabetes care. 2019;42(4):601–8. doi: 10.2337/dc18-1970. PMID: 30877090.30877090
82 Glauber H, Vollmer WM, Nichols GA. A simple model for predicting two-year risk of diabetes development in individuals with prediabetes. Perm J. 2018;22:17–050. doi: 10.7812/TPP/17-050. PMID: 29309270.29309270
83 Vijayakumar P, Nelson RG, Hanson RL, . HbA1c and the prediction of type 2 diabetes in children and adults. Diabetes Care. 2017 Jan;40(1):16–21. doi: 10.2337/dc16-1358. PMID: 27810987.27810987
84 Kim YA, Ku EJ, Khang AR, . Role of various indices derived from an oral glucose tolerance test in the prediction of conversion from prediabetes to type 2 diabetes. Diabetes Res Clin Pract. 2014 Nov;106(2):351–9. doi: 10.1016/j.diabres.2014.08.014. PMID: 25245975.25245975
85 Selvin E, Steffes MW, Zhu H, . Glycated hemoglobin, diabetes, and cardiovascular risk in nondiabetic adults. N Engl J Med. 2010 Mar 4;362(9):800–11. doi: 10.1056/NEJMoa0908359. PMID: 20200384.20200384
86 Davies MJ, Gray LJ, Troughton J, . A community based primary prevention programme for type 2 diabetes integrating identification and lifestyle intervention for prevention: the Let’s Prevent Diabetes cluster randomised controlled trial. Prev Med. 2016 Mar;84:48–56. doi: 10.1016/j.ypmed.2015.12.012. PMID: 26740346.26740346
87 Saito T, Watanabe M, Nishida J, . Lifestyle modification and prevention of type 2 diabetes in overweight Japanese with impaired fasting glucose levels: a randomized controlled trial. Arch Intern Med. 2011 Aug 8;171(15):1352–60. doi: 10.1001/archinternmed.2011.275. PMID: 21824948.21824948
88 Bancks MP, Odegaard AO, Koh WP, . Glycated hemoglobin and incident type 2 diabetes in singaporean chinese adults: the Singapore Chinese health study. PLoS One. 2015;10(3):e0119884. doi: 10.1371/journal.pone.0119884. PMID: 25775375.25775375
89 Robinson TE, Kenealy T, Garrett M, . Ethnicity and risk of lower limb amputation in people with Type 2 diabetes: a prospective cohort study. Diabet Med. 2016 Jan;33(1):55–61. doi: 10.1111/dme.12807. PMID: 25982171.25982171
90 Liu G, Li Y, Hu Y, . Influence of lifestyle on incident cardiovascular disease and mortality in patients with diabetes mellitus. J Am Coll Cardiol. 2018 Jun 26;71(25):2867–76. doi: 10.1016/j.jacc.2018.04.027. PMID: 29929608.29929608
91 Herman WH, Hoerger TJ, Brandle M, . The cost-effectiveness of lifestyle modification or metformin in preventing type 2 diabetes in adults with impaired glucose tolerance. Ann Intern Med. 2005 Mar 1;142(5):323–32. doi: 10.7326/0003-4819-142-5-200503010-00007. PMID: 15738451.15738451
92 Holman RR, Paul SK, Bethel MA, . Long-term follow-up after tight control of blood pressure in type 2 diabetes. N Engl J Med. 2008 Oct 9;359(15):1565–76. doi: 10.1056/NEJMoa0806359. PMID: 18784091.18784091
93 Davies MJ, Heller S, Skinner TC, . Effectiveness of the diabetes education and self management for ongoing and newly diagnosed (DESMOND) programme for people with newly diagnosed type 2 diabetes: cluster randomised controlled trial. BMJ. 2008 Mar 1;336(7642):491–5. doi: 10.1136/bmj.39474.922025.BE. PMID: 18276664.18276664
94 Khunti K, Gray LJ, Skinner T, . Effectiveness of a diabetes education and self management programme (DESMOND) for people with newly diagnosed type 2 diabetes mellitus: three year follow-up of a cluster randomised controlled trial in primary care. BMJ. 2012 Apr 26;344:e2333. doi: 10.1136/bmj.e2333. PMID: 22539172.22539172
95 van den Donk M, Gorter KJ, Rutten GE. No negative effects of a multi-factorial, intensified treatment on self-reported health status, treatment satisfaction, and diabetes-related distress in screen-detected type 2 diabetes patients. The ADDITION-Netherlands study. Qual Life Res. 2010 May;19(4):509–13. doi: 10.1007/s11136-010-9604-x. PMID: 20155327.20155327
96 Diabetes Prevention Program Research G. The 10-year cost-effectiveness of lifestyle intervention or metformin for diabetes prevention: an intent-to-treat analysis of the DPP/DPPOS. Diabetes Care. 2012 Apr;35(4):723–30. doi: 10.2337/dc11-1468. PMID: 22442395.22442395
97 Florez H, Pan Q, Ackermann RT, . Impact of lifestyle intervention and metformin on health-related quality of life: the diabetes prevention program randomized trial. J Gen Intern Med. 2012 Dec;27(12):1594–601. doi: 10.1007/s11606-012-2122-5. PMID: 22692637.22692637
98 Maindal HT, Carlsen AH, Lauritzen T, . Effect of a participant-driven health education programme in primary care for people with hyperglycaemia detected by screening: 3-year results from the Ready to Act randomized controlled trial (nested within the ADDITION-Denmark study). Diabet Med. 2014 Aug;31(8):976–86. doi: 10.1111/dme.12440. PMID: 24646371.24646371
99 Marrero D, Pan Q, Barrett-Connor E, . Impact of diagnosis of diabetes on health-related quality of life among high risk individuals: the Diabetes Prevention Program outcomes study. Qual Life Res. 2014 Feb;23(1):75–88. doi: 10.1007/s11136-013-0436-3. PMID: 23709097.23709097
100 Neumann A, Schoffer O, Norstrom F, . Health-related quality of life for pre-diabetic states and type 2 diabetes mellitus: a cross-sectional study in Vasterbotten Sweden. Health Qual Life Outcomes. 2014 Oct 24;12:150. doi: 10.1186/s12955-014-0150-z. PMID: 25342083.25342083
101 Vaatainen S, Keinanen-Kiukaanniemi S, Saramies J, . Quality of life along the diabetes continuum: a cross-sectional view of health-related quality of life and general health status in middle-aged and older Finns. Qual Life Res. 2014 Sep;23(7):1935–44. doi: 10.1007/s11136-014-0638-3. PMID: 24510623.24510623
102 Black JA, Long GH, Sharp SJ, . Change in cardio-protective medication and health-related quality of life after diagnosis of screen-detected diabetes: results from the ADDITION-Cambridge cohort. Diabetes Res Clin Pract. 2015 Jul;109(1):170–7. doi: 10.1016/j.diabres.2015.04.013. PMID: 25937542.25937542
103 DiBonaventura M, Lay AL, Kumar M, . The association between body mass index and health and economic outcomes in the United States. J Occup Environ Med. 2015 Oct;57(10):1047–54. doi: 10.1097/jom.0000000000000539. PMID: 26461859.26461859
104 Leal J, Ahrabian D, Davies MJ, . Cost-effectiveness of a pragmatic structured education intervention for the prevention of type 2 diabetes: economic evaluation of data from the Let’s Prevent Diabetes cluster-randomised controlled trial. BMJ Open. 2017 Jan 9;7(1):e013592. doi: 10.1136/bmjopen-2016-013592. PMID: 28069625.28069625
105 Makrilakis K, Liatis S, Tsiakou A, . Comparison of health-related quality of Life (HRQOL) among patients with pre-diabetes, diabetes and normal glucose tolerance, using the 15D-HRQOL questionnaire in Greece: the DEPLAN study. BMC Endocr Disord. 2018 May 29;18(1):32. doi: 10.1186/s12902-018-0261-3. PMID: 29843700.29843700
106 Coons SJ, Rao S, Keininger DL, . A comparative review of generic quality-of-life instruments. Pharmacoeconomics. 2000 Jan;17(1):13–35. doi: 10.2165/00019053-200017010-00002. PMID: 10747763.10747763
107 Wiebe S, Guyatt G, Weaver B, . Comparative responsiveness of generic and specific quality-of-life instruments. J Clin Epidemiol. 2003 Jan;56(1):52–60. doi: 10.1016/s0895-4356(02)00537-1. PMID: 12589870.12589870
108 Ara R, Wailoo A. Using health state utility values in models exploring the cost-effectiveness of health technologies. Value Health. 2012 Sep–Oct;15(6):971–4. doi: 10.1016/j.jval.2012.05.003. PMID: 22999149.22999149
109 Kempf K, Kruse J, Martin S. ROSSO-in-praxi follow-up: long-term effects of self-monitoring of blood glucose on weight, hemoglobin A1c, and quality of life in patients with type 2 diabetes mellitus. Diabetes Technol Ther. 2012 Jan;14(1):59–64. doi: 10.1089/dia.2011.0116. PMID: 21988274.21988274
110 Seppala T, Saxen U, Kautiainen H, . Impaired glucose metabolism and health related quality of life. Prim Care Diabetes. 2013 Oct;7(3):223–7. doi: 10.1016/j.pcd.2013.03.001. PMID: 23639608.23639608
111 Hunger M, Holle R, Meisinger C, . Longitudinal changes in health-related quality of life in normal glucose tolerance, prediabetes and type 2 diabetes: results from the KORA S4/F4 cohort study. Qual Life Res. 2014 Nov;23(9):2515–20. doi: 10.1007/s11136-014-0689-5. PMID: 24729056.24729056
112 Kulzer B, Hermanns N, Gorges D, . Prevention of Diabetes Self-Management Program (PREDIAS): effects on weight, metabolic risk factors, and behavioral outcomes. Diabetes Care. 2009 Jul;32(7):1143–6. doi: 10.2337/dc08-2141. PMID: 19509014.19509014
113 Taylor LM, Spence JC, Raine K, . Physical activity and health-related quality of life in individuals with prediabetes. Diabetes Res Clin Pract. 2010 Oct;90(1):15–21. doi: 10.1016/j.diabres.2010.04.011. PMID: 20727611.20727611
114 Ibrahim N, Moy FM, Awalludin IA, . The health-related quality of life among pre-diabetics and its association with body mass index and physical activity in a semi-urban community in Malaysia--a cross sectional study. BMC Public Health. 2014 Apr 1;14:298. doi: 10.1186/1471-2458-14-298. PMID: 24684809.24684809
115 le Roux CW, Astrup A, Fujioka K, . 3 years of liraglutide versus placebo for type 2 diabetes risk reduction and weight management in individuals with prediabetes: a randomised, double-blind trial. Lancet. 2017 Apr 8;389(10077):1399–409. doi: 10.1016/s0140-6736(17)30069-7. PMID: 28237263.28237263
116 Rabijewski M, Papierska L, Maksym R, . The relationship between health-related quality of life and anabolic hormone levels in middle-aged and elderly men with prediabetes: a cross-sectional study. Am J Mens Health. 2018 Sep;12(5):1593–603. doi: 10.1177/1557988318777926. PMID: 29882445.29882445
117 Janssen PG, Gorter KJ, Stolk RP, . Randomised controlled trial of intensive multifactorial treatment for cardiovascular risk in patients with screen-detected type 2 diabetes: 1-year data from the ADDITION Netherlands study. Br J Gen Pract. 2009 Jan;59(558):43–8. doi: 10.3399/bjgp09X394851. PMID: 19105915.19105915
118 Gray LJ, Yates T, Troughton J, . Engagement, retention, and progression to type 2 diabetes: a retrospective analysis of the cluster-randomised “Let’s Prevent Diabetes” trial. PLoS Med. 2016 Jul;13(7):e1002078. doi: 10.1371/journal.pmed.1002078. PMID: 27404094.27404094
119 Ratner R, Goldberg R, Haffner S, . Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the diabetes prevention program. Diabetes Care. 2005 Apr;28(4):888–94. PMID: 15793191.15793191
120 Morey MC, Pieper CF, Edelman DE, . Enhanced fitness: a randomized controlled trial of the effects of home-based physical activity counseling on glycemic control in older adults with prediabetes mellitus. J Am Geriatr Soc. 2012 Sep;60(9):1655–62. doi: 10.1111/j.1532-5415.2012.04119.x. PMID: 22985140.22985140
121 Cai X, Zhang Y, Li M, . Association between prediabetes and risk of all cause mortality and cardiovascular disease: updated meta-analysis. BMJ. 2020 Jul 15;370:m2297. doi: 10.1136/bmj.m2297. PMID: 32669282.32669282
122 Fuller JH, Shipley MJ, Rose G, . Coronary-heart-disease risk and impaired glucose tolerance. The Whitehall study. Lancet. 1980 Jun 28;1(8183):1373–6. doi: 10.1016/s0140-6736(80)92651-3. PMID: 6104171.6104171
123 Fuller JH, Shipley MJ, Rose G, . Mortality from coronary heart disease and stroke in relation to degree of glycaemia: the Whitehall study. Br Med J (Clin Res Ed). 1983 Sep 24;287(6396):867–70. doi: 10.1136/bmj.287.6396.867. PMID: 6412862.6412862
124 Eschwege E, Richard JL, Thibult N, . Coronary heart disease mortality in relation with diabetes, blood glucose and plasma insulin levels. The Paris Prospective Study, ten years later. Horm Metab Res Suppl. 1985;15:41–6. PMID: 3908280.3908280
125 Knowler WC, Sartor G, Melander A, . Glucose tolerance and mortality, including a substudy of tolbutamide treatment. Diabetologia. 1997 Jun;40(6):680–6. doi: 10.1007/s001250050734. PMID: 9222648.9222648
126 Asymptomatic hyperglycemia and coronary heart disease. A series of papers by the International Collaborative Group, based on studies in fifteen populations. Introduction. J Chronic Dis. 1979;32(11–12):683–91. doi: 10.1016/0021-9681(79)90047-x. PMID: 315952.315952
127 Joint discussion: the International Collaborative Group. J Chronic Dis. 1979;32(11–12):829–37. PMID: 511969.511969
128 Stamler R, Stamler J, Lindberg HA, . Asymptomatic hyperglycemia and coronary heart disease in middle-aged men in two employed populations in Chicago. J Chronic Dis. 1979;32(11–12):805–15. doi: 10.1016/0021-9681(79)90060-2. PMID: 315962.315962
129 Pyorala K, Savolainen E, Lehtovirta E, . Glucose tolerance and coronary heart disease: Helsinki policemen study. J Chronic Dis. 1979;32(11–12):729–45. doi: 10.1016/0021-9681(79)90052-3. PMID: 315955.315955
130 Ducimetiere P, Eschwege E, Richard J, . Relationship of glucose tolerance to prevalence of ECG abnormalities and to annual mortality from cardiovascular disease: results of the Paris Prospective Study. J Chronic Dis. 1979;32(11–12):759–66. doi: 10.1016/0021-9681(79)90054-7. PMID: 315957.315957
131 Hansen LJ, Olivarius Nde F, Siersma V. 16-year excess all-cause mortality of newly diagnosed type 2 diabetic patients: a cohort study. BMC Public Health. 2009 Oct 31;9:400. doi: 10.1186/1471-2458-9-400. PMID: 19878574.19878574
132 Olivarius NF, Beck-Nielsen H, Andreasen AH, . Randomised controlled trial of structured personal care of type 2 diabetes mellitus. BMJ. 2001 Oct 27;323(7319):970–5. doi: 10.1136/bmj.323.7319.970. PMID: 11679387.11679387
133 Wright AK, Kontopantelis E, Emsley R, . Life expectancy and cause-specific mortality in type 2 diabetes: a population-based cohort study quantifying relationships in ethnic subgroups. Diabetes Care. 2017 Mar;40(3):338–45. doi: 10.2337/dc16-1616. PMID: 27998911.27998911
134 Stuart EA, Bradshaw CP, Leaf PJ. Assessing the generalizability of randomized trial results to target populations. Prev Sci. 2015 Apr;16(3):475–85. doi: 10.1007/s11121-014-0513-z. PMID: 25307417.25307417
135 Altman DG, Schulz KF, Moher D, . The revised CONSORT statement for reporting randomized trials: explanation and elaboration. Ann Intern Med. 2001 Apr 17;134(8):663–94. doi: 10.7326/0003-4819-134-8-200104170-00012. PMID: 11304107.11304107
136 Jordan S, Watkins A, Storey M, . Volunteer bias in recruitment, retention, and blood sample donation in a randomised controlled trial involving mothers and their children at six months and two years: a longitudinal analysis. PLoS One. 2013;8(7):e67912. doi: 10.1371/journal.pone.0067912. PMID: 23874465.23874465
137 Lindahl B, Nilsson TK, Borch-Johnsen K, . A randomized lifestyle intervention with 5-year follow-up in subjects with impaired glucose tolerance: pronounced short-term impact but long-term adherence problems. Scand J Public Health. 2009 Jun;37(4):434–42. doi: 10.1177/1403494808101373. PMID: 19181821.19181821
138 Yates T, Davies M, Gorely T, . Effectiveness of a pragmatic education program designed to promote walking activity in individuals with impaired glucose tolerance: a randomized controlled trial. Diabetes Care. 2009 Aug;32(8):1404–10. doi: 10.2337/dc09-0130. PMID: 19602539.19602539
139 Ackermann RT, Liss DT, Finch EA, . A randomized comparative effectiveness trial for preventing type 2 diabetes. Am J Public Health. 2015 Nov;105(11):2328–34. doi: 10.2105/ajph.2015.302641. PMID: 26378828.26378828
140 Sakane N, Kotani K, Takahashi K, . Effects of telephone-delivered lifestyle support on the development of diabetes in participants at high risk of type 2 diabetes: J-DOIT1, a pragmatic cluster randomised trial. BMJ Open. 2015 Aug 19;5(8):e007316. doi: 10.1136/bmjopen-2014-007316. PMID: 26289448.26289448
141 Van Name MA, Camp AW, Magenheimer EA, . Effective translation of an intensive lifestyle intervention for Hispanic women with prediabetes in a community health center setting. Diabetes Care. 2016 Apr;39(4):525–31. doi: 10.2337/dc15-1899. PMID: 26908915.26908915
142 O’Brien MJ, Perez A, Scanlan AB, . PREVENT-DM comparative effectiveness trial of lifestyle intervention and metformin. Am J Prev Med. 2017 Jun;52(6):788–97. doi: 10.1016/j.amepre.2017.01.008. PMID: 28237635.28237635
143 Hellgren MI, Petzold M, Beteus-Forslund H, . Feasibility of a randomized controlled intervention with physical activity in participants with impaired glucose tolerance recruited by FINDRISC: a pilot study. Scand J Public Health. 2014 Jul;42(5):463–70. doi: 10.1177/1403494814528290. PMID: 24867622.24867622
144 Katula JA, Vitolins MZ, Morgan TM, . The Healthy Living Partnerships to Prevent Diabetes study: 2-year outcomes of a randomized controlled trial. Am J Prev Med. 2013 Apr;44(4 Suppl 4):S324–32. doi: 10.1016/j.amepre.2012.12.015. PMID: 23498294.23498294
145 Juul L, Andersen VJ, Arnoldsen J, . Effectiveness of a brief theory-based health promotion intervention among adults at high risk of type 2 diabetes: one-year results from a randomised trial in a community setting. Prim Care Diabetes. 2016 Apr;10(2):111–20. doi: 10.1016/j.pcd.2015.07.002. PMID: 26259517.26259517
146 Diabetes Prevention Program Research Group, Knowler WC, Fowler SE, . 10-year follow-up of diabetes incidence and weight loss in the Diabetes Prevention Program Outcomes Study. Lancet. 2009 Nov 14;374(9702):1677–86. doi: 10.1016/S0140-6736(09)61457-4. PMID: 19878986.19878986
147 Walker EA, Molitch M, Kramer MK, . Adherence to preventive medications: predictors and outcomes in the Diabetes Prevention Program. Diabetes Care. 2006 Sep;29(9):1997–2002. doi: 10.2337/dc06-0454. PMID: 16936143.16936143
148 Moin T, Duru OK, Turk N, . Effectiveness of shared decision-making for diabetes prevention: 12-month results from the Prediabetes Informed Decision and Education (PRIDE) Trial. J Gen Intern Med. 2019 Nov;34(11):2652–9. doi: 10.1007/s11606-019-05238-6. PMID: 31471729.31471729
149 Zigmont VA, Shoben AB, Kaye GL, . An evaluation of reach for a work site implementation of the National Diabetes Prevention Program focusing on diet and exercise. Am J Health Promot. 2018 Jul;32(6):1417–24. doi: 10.1177/0890117117733348. PMID: 28990395.28990395
150 Davy BM, Winett RA, Savla J, . Resist diabetes: a randomized clinical trial for resistance training maintenance in adults with prediabetes. PLoS One. 2017;12(2):e0172610. doi: 10.1371/journal.pone.0172610. PMID: 28231265.28231265
151 Sepah SC, Jiang L, Peters AL. Translating the Diabetes Prevention Program into an online social network: validation against CDC standards. Diabetes Educ. 2014 Jul;40(4):435–43. doi: 10.1177/0145721714531339. PMID: 24723130.24723130
152 Wardian JL, True MW, Sauerwein TJ, . Evaluation of the group lifestyle balance program in a military setting: an investment worth expanding. Mil Med. 2018 Jan 1;183(1–2):e138–e43. doi: 10.1093/milmed/usx058. PMID: 29401348.29401348
153 Vojta D, Koehler TB, Longjohn M, . A coordinated national model for diabetes prevention: linking health systems to an evidence-based community program. Am J Prev Med. 2013 Apr;44(4 Suppl 4):S301–6. doi: 10.1016/j.amepre.2012.12.018. PMID: 23498291.23498291
154 Healthwise. Decision aid summary. Prediabetes: which treatment should I use to prevent type 2 diabetes? Ottawa: Ottawa Hospital Research Institute; 2019. https://decisionaid.ohri.ca/Azsumm.php?ID=1654.
155 O’Brien MJ, Cameron KA, Vargas MC, . Evaluation of a prediabetes decision aid on patient-reported outcomes in primary care: a pilot study. J Gen Intern Med. 2020 Jun 15doi: 10.1007/s11606-020-05936-6. PMID: 32542497.32542497
156 O’Brien MJ, Moran MR, Tang JW, . Patient perceptions about prediabetes and preferences for diabetes prevention. Diabetes Educ. 2016 Dec;42(6):667–77. doi: 10.1177/0145721716666678. PMID: 27621093.27621093
157 Valabhji J, Barron E, Bradley D, . Early outcomes from the English National Health Service Diabetes Prevention Programme. Diabetes Care. 2020 Jan;43(1):152–60. doi: 10.2337/dc19-1425. PMID: 31719054.31719054
158 DeBoer MD, Filipp SL, Gurka MJ. Use of a Metabolic Syndrome Severity Z Score to track risk during treatment of prediabetes: an analysis of the Diabetes Prevention Program. Diabetes Care. 2018 Nov;41(11):2421–30. doi: 10.2337/dc18-1079. PMID: 30275282.30275282
159 Metcalf PA, Kyle C, Kenealy T, . HbA1c in relation to incident diabetes and diabetes-related complications in non-diabetic adults at baseline. J Diabetes Complications. 2017 May;31(5):814–23. doi: 10.1016/j.jdiacomp.2017.02.007. PMID: 28319002.28319002
160 Nichols GA, Arondekar B, Herman WH. Complications of dysglycemia and medical costs associated with nondiabetic hyperglycemia. Am J Manag Care. 2008 Dec;14(12):791–8. PMID: 19067496.19067496
161 Colagiuri S, Cull CA, Holman RR, . Are lower fasting plasma glucose levels at diagnosis of type 2 diabetes associated with improved outcomes?: U.K. prospective diabetes study 61. Diabetes Care. 2002 Aug;25(8):1410–7. doi: 10.2337/diacare.25.8.1410. PMID: 12145243.12145243
162 Vistisen D, Witte DR, Brunner EJ, . Risk of cardiovascular disease and death in individuals with prediabetes defined by different criteria: the Whitehall II Study. Diabetes Care. 2018 04;41(4):899–906. doi: 10.2337/dc17-2530. PMID: 29453200.29453200
163 McCoy RG, Zhang Y, Herrin J, . Changing trends in type 2 diabetes mellitus treatment intensification, 2002-2010. Am J Manag Care. 2015 May 1;21(5):e288–96. PMID: 26167776.26167776
164 Jannoo Z, Yap BW, Khan NM, . Assessing diabetes distress among type 2 diabetes mellitus in Malaysia using the problem areas in diabetes scale. Value Health Reg Issues. 2019 May;18:159–64. doi: 10.1016/j.vhri.2019.03.004. PMID: 31082796.31082796
165 Al Sayah F, Yeung RO, Johnson JA. Association of depressive symptoms and diabetes distress with severe hypoglycemia in adults with type 2 diabetes. Can J Diabetes. 2019 Jul;43(5):316–21. doi: 10.1016/j.jcjd.2018.11.002. PMID: 30578165.30578165
166 Kane NS, Hoogendoorn CJ, Tanenbaum ML, . Physical symptom complaints, cognitive emotion regulation strategies, self-compassion and diabetes distress among adults with Type 2 diabetes. Diabet Med. 2018 Dec;35(12):1671–7. doi: 10.1111/dme.13830. PMID: 30264898.30264898
167 Hayashino Y, Tsujii S, Ishii H. Association of diabetes therapy-related quality of life and physical activity levels in patients with type 2 diabetes receiving medication therapy: the Diabetes Distress and Care Registry at Tenri (DDCRT 17). Acta Diabetol. 2018 Feb;55(2):165–73. doi: 10.1007/s00592-017-1080-0. PMID: 29188385.29188385
168 Yu CH, Parsons JA, Mamdani M, . A web-based intervention to support self-management of patients with type 2 diabetes mellitus: effect on self-efficacy, self-care and diabetes distress. BMC Med Inform Decis Mak. 2014 Dec 14;14:117. doi: 10.1186/s12911-014-0117-3. PMID: 25495847.25495847
169 Gahlan D, Rajput R, Gehlawat P, . Prevalence and determinants of diabetes distress in patients of diabetes mellitus in a tertiary care centre. Diabetes Metab Syndr. 2018 May;12(3):333–6. doi: 10.1016/j.dsx.2017.12.024. PMID: 29301728.29301728
170 Stamler R, Stamler J, Schoenberger JA, . Relationship of glucose tolerance to prevalence of ECG abnormalities and to 5-year mortality from cardiovascular disease: findings of the Chicago Heart Association Detection Project in Industry. J Chronic Dis. 1979;32(11–12):817–28. doi: 10.1016/0021-9681(79)90061-4. PMID: 315963.315963
171 Stenhouse NS, Murphy BP, Welborn TA. Busselton population study: risk associated with asymptomatic hyperglycemia. J Chronic Dis. 1979;32(11–12):693–8. doi: 10.1016/0021-9681(79)90048-1. PMID: 511966.511966
172 Reunanen A, Pyorala K, Aromaa A, . Glucose tolerance and coronary heart disease in middle-aged Finnish men: Social Insurance Institution’s Coronary Heart Disease Study. J Chronic Dis. 1979;32(11–12):747–58. doi: 10.1016/0021-9681(79)90053-5. PMID: 315956.315956
173 Da Silva A, Widmer LK, Ziegler HW, . The Basle longitudinal study: report on the relation of initial glucose level to baseline ECG abnormalities, peripheral artery disease, and subsequent mortality. J Chronic Dis. 1979;32(11–12):797–803. doi: 10.1016/0021-9681(79)90059-6. PMID: 511968.511968
174 Fuller JH, McCartney P, Jarrett RJ, . Hyperglycaemia and coronary heart disease: the Whitehall study. J Chronic Dis. 1979;32(11–12):721–8. doi: 10.1016/0021-9681(79)90051-1. PMID: 511967.511967
175 Schroll M, Hagerup L. Relationship of fasting blood glucose to prevalence of ECG abnormalities and 10 yr risk of mortality from cardiovascular diseases in men born in 1914: from the Glostrup population studies. J Chronic Dis. 1979;32(11–12):699–707. doi: 10.1016/0021-9681(79)90049-3. PMID: 315953.315953
176 Hawthorne VM, Gilmour WH. Relationship of glucose to prevalence of ECG abnormalities at baseline and to 6-yr mortality in Scottish males aged 45-64 yr. J Chronic Dis. 1979;32(11–12):787–96. doi: 10.1016/0021-9681(79)90058-4. PMID: 315961.315961
177 EuroQol. EQ-5D User Guides. Rotterdam, The Netherlands: EuroQol Office; n.d. https://euroqol.org/publications/user-guides/.
178 Xie F, Pullenayegum E, Gaebel K, . A time trade-off-derived value set of the EQ-5D-5L for Canada. Med Care. 2016 Jan;54(1):98–105. doi: 10.1097/MLR.0000000000000447. PMID: 26492214.26492214
179 Devlin NJ, Shah KK, Feng Y, . Valuing health-related quality of life: an EQ-5D-5L value set for England. Health Econ. 2018 Jan;27(1):7–22. doi: 10.1002/hec.3564. PMID: 28833869.28833869
180 Pickard AS, Law EH, Jiang R, . United States faluation of EQ-5D-5L health states using an international protocol. Value Health. 2019 Aug;22(8):931–41. doi: 10.1016/j.jval.2019.02.009. PMID: 31426935.31426935
181 Sintonen H. The 15-D measure of health related quality of life. II Feasibility, reliability and validity of its valuation system. Centre for Health Program Evaluation. 1995. https://citeseerx.ist.psu.edu/viewdoc/download?doi=10.1.1.203.951&rep=rep1&type=pdf
182 Sieber W, Groessl E, Ph D, . Quality of well being self-administered (QWB-SA) scale. 2008 01/01.
183 Ware J, Kosinski M, Keller S. SF-36 physical and mental health summary scales: a user’s manual. Health Assessment Lab. Boston, MA: 1994.
184 Ware J, Kosinski M, Keller S. SF-12: how to score the SF-12 physical and mental health summary scales. The Health Institute, New England Medical Center. Boston, MA: 1995.
185 Hanmer J. Predicting an SF-6D preference-based score using MCS and PCS scores from the SF-12 or SF-36. Value Health. 2009 Sep;12(6):958–66. doi: 10.1111/j.1524-4733.2009.00535.x. PMID: 19490549.19490549
186 Brazier J, Roberts J, Deverill M. The estimation of a preference-based measure of health from the SF-36. J Health Econ. 2002 Mar;21(2):271–92. doi: 10.1016/s0167-6296(01)00130-8. PMID: 11939242.11939242
187 Johnson JA, Maddigan SL. Performance of the RAND-12 and SF-12 summary scores in type 2 diabetes. Qual Life Res. 2004 Mar;13(2):449–56. doi: 10.1023/B:QURE.0000018494.72748.cf. PMID: 15085917.15085917
188 Kaplan RM. The minimally clinically important difference in generic utility-based measures. COPD. 2005 Mar;2(1):91–7. doi: 10.1081/copd-200052090. PMID: 17136968.17136968
189 Fryback DG, Dunham NC, Palta M, . US norms for six generic health-related quality-of-life indexes from the National Health Measurement study. Med Care. 2007 Dec;45(12):1162–70. doi: 10.1097/MLR.0b013e31814848f1. PMID: 18007166.18007166
190 Luo N, Johnson J, Coons SJ. Using instrument-defined health state transitions to estimate minimally important differences for four preference-based health-related quality of life instruments. Med Care. 2010 Apr;48(4):365–71. doi: 10.1097/mlr.0b013e3181c162a2. PMID: 20355266.20355266
191 Kind P, Hardman G, Macran S. UK population norms for EQ-5D. Centre for Health Economics, University of York. 1999. https://www.york.ac.uk/media/che/documents/papers/discussionpapers/CHE%20Discussion%20Paper%20172.pdf
192 Janssen MF, Szende A, Cabases J, . Population norms for the EQ-5D-3L: a cross-country analysis of population surveys for 20 countries. Eur J Health Econ. 2019 Mar;20(2):205–16. doi: 10.1007/s10198-018-0955-5. PMID: 29445941.29445941
193 Walters SJ, Brazier JE. Comparison of the minimally important difference for two health state utility measures: EQ-5D and SF-6D. Qual Life Res. 2005 Aug;14(6):1523–32. doi: 10.1007/s11136-004-7713-0. PMID: 16110932.16110932
194 Alanne S, Roine RP, Rasanen P, . Estimating the minimum important change in the 15D scores. Qual Life Res. 2015 Mar;24(3):599–606. doi: 10.1007/s11136-014-0787-4. PMID: 25145637.25145637
195 Sintonen H. The 15-D measure of health related quality of life: reliability, validity and sensitivity of its health state descriptive system. Centre for Health Program Evaluation. Australia: 1994. https://business.monash.edu/__data/assets/pdf_file/0009/391374/wp41-1.pdf
196 Haapaniemi TH, Sotaniemi KA, Sintonen H, . The generic 15D instrument is valid and feasible for measuring health related quality of life in Parkinson’s disease. J Neurol Neurosurg Psychiatry. 2004 Jul;75(7):976–83. doi: 10.1136/jnnp.2003.015693. PMID: 15201353.15201353
197 Ware JE. User’s manual for the SF-36v2 health survey. London: Quality Metric; 2007.
198 Pickard AS, Neary MP, Cella D. Estimation of minimally important differences in EQ-5D utility and VAS scores in cancer. Health Qual Life Outcomes. 2007 Dec 21;5:70. doi: 10.1186/1477-7525-5-70. PMID: 18154669.18154669
199 Zanini A, Aiello M, Adamo D, . Estimation of minimal clinically important difference in EQ-5D visual analog scale score after pulmonary rehabilitation in subjects with COPD. Respir Care. 2015 Jan;60(1):88–95. doi: 10.4187/respcare.03272. PMID: 25336531.25336531
200 National Libary of Medicine. Self-reported population health: an international perspective based on EQ-5D. Dordrecht: Springer; 2014.
201 Feeny D, Furlong W, Torrance GW, . Multiattribute and single-attribute utility functions for the health utilities index mark 3 system. Med Care. 2002 Feb;40(2):113–28. doi: 10.1097/00005650-200202000-00006. PMID: 11802084.11802084
202 Hays RD, Morales LS. The RAND-36 measure of health-related quality of life. Ann Med. 2001 Jul;33(5):350–7. doi: 10.3109/07853890109002089. PMID: 11491194.11491194
203 Topp CW, Ostergaard SD, Sondergaard S, . The WHO-5 Well-Being Index: a systematic review of the literature. Psychother Psychosom. 2015;84(3):167–76. doi: 10.1159/000376585. PMID: 25831962.25831962
204 Wu W, Li Y, Chen X, . Effect of linagliptin on glycemic control in chinese patients with newly-diagnosed, drug-naive type 2 diabetes mellitus: a randomized controlled trial. Med Sci Monit. 2015 Sep 9;21:2678–84. doi: 10.12659/msm.894026. PMID: 26350766.26350766
205 Block G, Azar K, Romanelli R, . Diabetes prevention and weight loss with a fully automated behavioral intervention by email, web, and mobile phone: a randomized controlled trial among persons with prediabetes. J Med Internet Res. 2015;17(10):e240. doi: 10.2196/jmir.4897. PMID: CN-01169265.26499966
206 Bulatova N, Kasabri V, Qotineh A, . Effect of metformin combined with lifestyle modification versus lifestyle modification alone on proinflammatory-oxidative status in drug-naive pre-diabetic and diabetic patients: a randomized controlled study. Diabetes and metabolic syndrome: clinical research and reviews. 2017;(no pagination)doi: 10.1016/j.dsx.2017.11.003. PMID: CN-01442803.
207 Alfawaz H, Wani K, Alnaami A, . Effects of different dietary and lifestyle modification therapies on metabolic syndrome in prediabetic Arab patients: a 12-month longitudinal study. Nutrients. 2018;10(3) (no pagination)doi: 10.3390/nu10030383. PMID: CN-01464865.
208 Kumar KJSTCK-M. Saxagliptin as initial therapy in treatment-naive Indian adults with type 2 diabetes mellitus inadequately controlled with diet and exercise alone: a randomized, double-blind, placebo-controlled, phase IIIb clinical study. Int J Diabetes Dev Ctries. 2014;34(4):201–9. PMID: CN-01092468.
209 Hesselink AE, Rutten GE, Slootmaker SM, . Effects of a lifestyle program in subjects with Impaired Fasting Glucose, a pragmatic cluster-randomized controlled trial. BMC Fam Pract. 2015 Dec 22;16:183. doi: 10.1186/s12875-015-0394-7. PMID: 26695176.26695176
210 Echouffo-Tcheugui J, Simmons R, Prevost A, . Long-term effect of population screening for diabetes on cardiovascular morbidity, self-rated health, and health behavior. Ann Fam Med. 2015;13(2):149–57. doi: 10.1370/afm.1737. PMID: CN-01110231.25755036
211 Moore SM, Hardie EA, Hackworth NJ, . Can the onset of type 2 diabetes be delayed by a group-based lifestyle intervention? A randomised control trial. Psychol Health. 2011 Apr;26(4):485–99. doi: 10.1080/08870440903548749. PMID: 20945253.20945253
212 Oldroyd JC, Unwin NC, White M, . Randomised controlled trial evaluating the effectiveness of behavioural interventions to modify cardiovascular risk factors in men and women with impaired glucose tolerance: outcomes at 6 months. Diabetes Res Clin Pract. 2001 Apr;52(1):29–43. PMID: 11182214.11182214
213 Wang Z, Xu D, Huang L, . Effects of saxagliptin on glucose homeostasis and body composition of obese patients with newly diagnosed pre-diabetes. Diabetes Res Clin Pract. 2017 Aug;130:77–85. doi: 10.1016/j.diabres.2017.05.012. PMID: 28575729.28575729
214 Duijzer G, Haveman-Nies A, Jansen SC, . Effect and maintenance of the SLIMMER diabetes prevention lifestyle intervention in Dutch primary healthcare: a randomised controlled trial. Nutr Diabetes. 2017 May 8;7(5):e268. doi: 10.1038/nutd.2017.21. PMID: 28481335.28481335
215 Hu Z, Qin L, Xu H. One-year results of a synthetic intervention model for the primary prevention of T2D among elderly individuals with prediabetes in rural China. Int J Environ Res Public Health. 2017 Apr 14;14(4)doi: 10.3390/ijerph14040417. PMID: 28420105.28420105
216 Cezaretto A, Barros CR, Almeida-Pititto B, . Lifestyle intervention using the psychoeducational approach is associated with greater cardiometabolic benefits and retention of individuals with worse health status. Arch Endocrinol Metab. 2017 Jan–Feb;61(1):36–44. doi: 10.1590/2359-3997000000185. PMID: 28273202.28273202
217 Yeh MC, Heo M, Suchday S, . Translation of the Diabetes Prevention Program for diabetes risk reduction in Chinese immigrants in New York City. Diabet Med. 2016 Apr;33(4):547–51. doi: 10.1111/dme.12848. PMID: 26179569.26179569
218 Kaku K, Kadowaki T, Terauchi Y, . Sitagliptin improves glycaemic excursion after a meal or after an oral glucose load in Japanese subjects with impaired glucose tolerance. Diabetes Obes Metab. 2015 Nov;17(11):1033–41. doi: 10.1111/dom.12507. PMID: 26094974.26094974
219 Dawes D, Ashe M, Campbell K, . Preventing diabetes in primary care: a feasibility cluster randomized trial. Can J Diabetes. 2015 Apr;39(2):111–6. doi: 10.1016/j.jcjd.2014.08.004. PMID: 25439501.25439501
220 Welsh P, Cezard G, Gill JM, . Associations between weight change and biomarkers of cardiometabolic risk in South Asians: secondary analyses of the PODOSA trial. Int J Obes (Lond). 2016 Jun;40(6):1005–11. doi: 10.1038/ijo.2016.35. PMID: 26927315.26927315
221 Mann D, Palmisano J, Lin J. A pilot randomized trial of technology-assisted goal setting to improve physical activity among primary care patients with prediabetes. Preventive medicine reports. 2016;4:107–12. doi: 10.1016/j.pmedr.2016.05.012. PMID: CN-01165746.27413670
222 Weber MB, Ranjani H, Staimez LR, . The stepwise approach to diabetes prevention: results from the D-CLIP randomized controlled trial. Diabetes Care. 2016 Oct;39(10):1760–7. doi: 10.2337/dc16-1241. PMID: 27504014.27504014
223 Gokulakrishnan K, Ranjani H, Weber MB, . Effect of lifestyle improvement program on the biomarkers of adiposity, inflammation and gut hormones in overweight/obese Asian Indians with prediabetes. Acta Diabetol. 2017 Sep;54(9):843–52. doi: 10.1007/s00592-017-1015-9. PMID: 28620678.28620678
224 Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. 2005 Feb;67(2):152–62. doi: 10.1016/j.diabres.2004.06.010. PMID: 15649575.15649575
225 Pan XR, Li GW, Hu YH, . Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance. The Da Qing IGT and Diabetes Study. Diabetes Care. 1997 Apr;20(4):537–44. PMID: 9096977.9096977
226 Li G, Zhang P, Wang J, . The long-term effect of lifestyle interventions to prevent diabetes in the China Da Qing Diabetes Prevention Study: a 20-year follow-up study. Lancet. 2008 May 24;371(9626):1783–9. doi: 10.1016/S0140-6736(08)60766-7. PMID: 18502303.18502303
227 Li G, Zhang P, Wang J, . Cardiovascular mortality, all-cause mortality, and diabetes incidence after lifestyle intervention for people with impaired glucose tolerance in the Da Qing Diabetes Prevention Study: a 23-year follow-up study. Lancet Diabetes Endocrinol. 2014 Jun;2(6):474–80. doi: 10.1016/s2213-8587(14)70057-9. PMID: 24731674.24731674
228 Gong Q, Zhang P, Wang J, . Morbidity and mortality after lifestyle intervention for people with impaired glucose tolerance: 30-year results of the Da Qing Diabetes Prevention Outcome Study. Lancet Diabetes Endocrinol. 2019 Jun;7(6):452–61. doi: 10.1016/S2213-8587(19)30093-2. PMID: 31036503.31036503
229 Dyson PA, Hammersley MS, Morris RJ, . The Fasting Hyperglycaemia Study: II. Randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism. 1997 Dec;46(12 Suppl 1):50–5. PMID: 9439560.9439560
230 Eborall HC, Griffin SJ, Prevost AT, . Psychological impact of screening for type 2 diabetes: controlled trial and comparative study embedded in the ADDITION (Cambridge) randomised controlled trial. BMJ. 2007 Sep 8;335(7618):486. doi: 10.1136/bmj.39303.723449.55. PMID: 17761995.17761995
231 Paddison CA, Eborall HC, French DP, . Predictors of anxiety and depression among people attending diabetes screening: a prospective cohort study embedded in the ADDITION (Cambridge) randomized control trial. Br J Health Psychol. 2011 Feb;16(Pt 1):213–26. doi: 10.1348/135910710X495366. PMID: 21226792.21226792
232 Tuomilehto J, Lindstrom J, Eriksson JG, . Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001 May 3;344(18):1343–50. doi: 10.1056/NEJM200105033441801. PMID: 11333990.11333990
233 Uusitupa M, Peltonen M, Lindstrom J, . Ten-year mortality and cardiovascular morbidity in the Finnish Diabetes Prevention Study--secondary analysis of the randomized trial. PLoS One. 2009 May 21;4(5):e5656. doi: 10.1371/journal.pone.0005656. PMID: 19479072.19479072
234 Ramachandran A, Snehalatha C, Mary S, . The Indian Diabetes Prevention Programme shows that lifestyle modification and metformin prevent type 2 diabetes in Asian Indian subjects with impaired glucose tolerance (IDPP-1). Diabetologia. 2006 Feb;49(2):289–97. doi: 10.1007/s00125-005-0097-z. PMID: 16391903.16391903
235 Chiasson JL, Josse RG, Gomis R, . Acarbose for prevention of type 2 diabetes mellitus: the STOP-NIDDM randomised trial. Lancet. 2002 Jun 15;359(9323):2072–7. doi: 10.1016/S0140-6736(02)08905-5. PMID: 12086760.12086760
236 Chiasson JL, Josse RG, Gomis R, . Acarbose treatment and the risk of cardiovascular disease and hypertension in patients with impaired glucose tolerance: the STOP-NIDDM trial. JAMA. 2003 Jul 23;290(4):486–94. doi: 10.1001/jama.290.4.486. PMID: 12876091.12876091
237 Diabetes Prevention Program Research G. Long-term safety, tolerability, and weight loss associated with metformin in the Diabetes Prevention Program Outcomes Study. Diabetes Care. 2012 Apr;35(4):731–7. doi: 10.2337/dc11-1299. PMID: 22442396.22442396
238 Apolzan JW, Venditti EM, Edelstein SL, . Long-term weight loss with metformin or lifestyle intervention in the Diabetes Prevention Program Outcomes Study. Ann Intern Med. 2019 Apr 23doi: 10.7326/M18-1605. PMID: 31009939.31009939
239 Aroda VR, Edelstein SL, Goldberg RB, . Long-term metformin use and vitamin B12 deficiency in the Diabetes Prevention Program Outcomes Study. J Clin Endocrinol Metab. 2016 Apr;101(4):1754–61. doi: 10.1210/jc.2015-3754. PMID: 26900641.26900641
240 Aroda VR, Christophi CA, Edelstein SL, . The effect of lifestyle intervention and metformin on preventing or delaying diabetes among women with and without gestational diabetes: the Diabetes Prevention Program outcomes study 10-year follow-up. J Clin Endocrinol Metab. 2015 Apr;100(4):1646–53. doi: 10.1210/jc.2014-3761. PMID: 25706240.25706240
241 Griffin SJ, Borch-Johnsen K, Davies MJ, . Effect of early intensive multifactorial therapy on 5-year cardiovascular outcomes in individuals with type 2 diabetes detected by screening (ADDITION-Europe): a cluster-randomised trial. Lancet. 2011 Jul 9;378(9786):156–67. doi: 10.1016/S0140-6736(11)60698-3. PMID: 21705063.21705063
242 Simmons RK, Sharp SJ, Sandbaek A, . Does early intensive multifactorial treatment reduce total cardiovascular burden in individuals with screen-detected diabetes? Findings from the ADDITION-Europe cluster-randomized trial. Diabet Med. 2012 Nov;29(11):e409–16. doi: 10.1111/j.1464-5491.2012.03759.x. PMID: 22823477.22823477
243 Van den Donk M, Griffin SJ, Stellato RK, . Effect of early intensive multifactorial therapy compared with routine care on self-reported health status, general well-being, diabetes-specific quality of life and treatment satisfaction in screen-detected type 2 diabetes mellitus patients (ADDITION-Europe): a cluster-randomised trial. Diabetologia. 2013 Aug 20doi: 10.1007/s00125-013-3011-0. PMID: 23959571.23959571
244 Griffin SJ, Rutten G, Khunti K, . Long-term effects of intensive multifactorial therapy in individuals with screen-detected type 2 diabetes in primary care: 10-year follow-up of the ADDITION-Europe cluster-randomised trial. Lancet Diabetes Endocrinol. 2019 Dec;7(12):925–37. doi: 10.1016/S2213-8587(19)30349-3. PMID: 31748169.31748169
245 Charles M, Ejskjaer N, Witte DR, . Prevalence of neuropathy and peripheral arterial disease and the impact of treatment in people with screen-detected type 2 diabetes: the ADDITION-Denmark study. Diabetes Care. 2011 Oct;34(10):2244–9. doi: 10.2337/dc11-0903. PMID: 21816977.21816977
246 Pan CY, Gao Y, Chen JW, . Efficacy of acarbose in Chinese subjects with impaired glucose tolerance. Diabetes Res Clin Pract. 2003 Sep;61(3):183–90. PMID: 12965108.12965108
247 Park P, Simmons RK, Prevost AT, . Screening for type 2 diabetes is feasible, acceptable, but associated with increased short-term anxiety: a randomised controlled trial in British general practice. BMC Public Health. 2008 Oct 7;8:350. doi: 10.1186/1471-2458-8-350. PMID: 18840266.18840266
248 Simmons RK, Echouffo-Tcheugui JB, Sharp SJ, . Screening for type 2 diabetes and population mortality over 10 years (ADDITION-Cambridge): a cluster-randomised controlled trial. Lancet. 2012 Nov 17;380(9855):1741–8. doi: 10.1016/S0140-6736(12)61422-6. PMID: 23040422.23040422
249 Simmons RK, Rahman M, Jakes RW, . Effect of population screening for type 2 diabetes on mortality: long-term follow-up of the Ely cohort. Diabetologia. 2011 Feb;54(2):312–9. doi: 10.1007/s00125-010-1949-8. PMID: 20978739.20978739
250 Rahman M, Simmons RK, Hennings SH, . How much does screening bring forward the diagnosis of type 2 diabetes and reduce complications? Twelve year follow-up of the Ely cohort. Diabetologia. 2012 Jun;55(6):1651–9. doi: 10.1007/s00125-011-2441-9. PMID: 22237689.22237689
251 DeFronzo RA, Tripathy D, Schwenke DC, . Pioglitazone for diabetes prevention in impaired glucose tolerance. N Engl J Med. 2011 Mar 24;364(12):1104–15. doi: 10.1056/NEJMoa1010949. PMID: 21428766.21428766
252 Espinoza SE, Wang CP, Tripathy D, . Pioglitazone is equally effective for diabetes prevention in older versus younger adults with impaired glucose tolerance. Age (Dordr). 2016 Dec;38(5–6):485–93. doi: 10.1007/s11357-016-9946-6. PMID: 27585671.27585671
253 Dream Trial Investigators, Bosch J, Yusuf S, . Effect of ramipril on the incidence of diabetes. N Engl J Med. 2006 Oct 12;355(15):1551–62. doi: 10.1056/NEJMoa065061. PMID: 16980380.16980380
254 Dream Trial Investigators, Gerstein HC, Yusuf S, . Effect of rosiglitazone on the frequency of diabetes in patients with impaired glucose tolerance or impaired fasting glucose: a randomised controlled trial. Lancet. 2006 Sep 23;368(9541):1096–105. doi: 10.1016/S0140-6736(06)69420-8. PMID: 16997664.16997664
255 Dream Trial Investigators, Dagenais GR, Gerstein HC, . Effects of ramipril and rosiglitazone on cardiovascular and renal outcomes in people with impaired glucose tolerance or impaired fasting glucose: results of the Diabetes REduction Assessment with ramipril and rosiglitazone Medication (DREAM) trial. Diabetes Care. 2008 May;31(5):1007–14. doi: 10.2337/dc07-1868. PMID: 18268075.18268075
256 Kawamori R, Tajima N, Iwamoto Y, . Voglibose for prevention of type 2 diabetes mellitus: a randomised, double-blind trial in Japanese individuals with impaired glucose tolerance. Lancet. 2009 May 9;373(9675):1607–14. doi: 10.1016/S0140-6736(09)60222-1. PMID: 19395079.19395079
257 Pedley CF, Case LD, Blackwell CS, . The 24-month metabolic benefits of the healthy living partnerships to prevent diabetes: A community-based translational study. Diabetes Metab Syndr. 2018 May;12(3):215–20. doi: 10.1016/j.dsx.2017.09.011. PMID: 28964720.28964720
258 Lindblad U, Lindberg G, Mansson NO, . Can sulphonylurea addition to lifestyle changes help to delay diabetes development in subjects with impaired fasting glucose? The Nepi ANtidiabetes StudY (NANSY). Diabetes Obes Metab. 2011 Feb;13(2):185–8. doi: 10.1111/j.1463-1326.2010.01331.x. PMID: 21199271.21199271
259 Lu YH, Lu JM, Wang SY, . Outcome of intensive integrated intervention in participants with impaired glucose regulation in China. Adv Ther. 2011 Jun;28(6):511–9. doi: 10.1007/s12325-011-0022-4. PMID: 21533568.21533568
260 Navigator Study Group, Holman RR, Haffner SM, . Effect of nateglinide on the incidence of diabetes and cardiovascular events. N Engl J Med. 2010 Apr 22;362(16):1463–76. doi: 10.1056/NEJMoa1001122. PMID: 20228402.20228402
261 Navigator Study Group, McMurray JJ, Holman RR, . Effect of valsartan on the incidence of diabetes and cardiovascular events. N Engl J Med. 2010 Apr 22;362(16):1477–90. doi: 10.1056/NEJMoa1001121. PMID: 20228403.20228403
262 Currie G, Bethel MA, Holzhauer B, . Effect of valsartan on kidney outcomes in people with impaired glucose tolerance. Diabetes Obes Metab. 2017 Jun;19(6):791–9. doi: 10.1111/dom.12877. PMID: 28093841.28093841
263 Nijpels G, Boorsma W, Dekker JM, . A study of the effects of acarbose on glucose metabolism in patients predisposed to developing diabetes: the Dutch acarbose intervention study in persons with impaired glucose tolerance (DAISI). Diabetes Metab Res Rev. 2008 Nov–Dec;24(8):611–6. doi: 10.1002/dmrr.839. PMID: 18756586.18756586
264 Penn L, White M, Oldroyd J, . Prevention of type 2 diabetes in adults with impaired glucose tolerance: the European Diabetes Prevention RCT in Newcastle upon Tyne, UK. BMC Public Health. 2009 Sep 16;9:342. doi: 10.1186/1471-2458-9-342. PMID: 19758428.19758428
265 Ramachandran A, Snehalatha C, Mary S, . Pioglitazone does not enhance the effectiveness of lifestyle modification in preventing conversion of impaired glucose tolerance to diabetes in Asian Indians: results of the Indian Diabetes Prevention Programme-2 (IDPP-2). Diabetologia. 2009 Jun;52(6):1019–26. doi: 10.1007/s00125-009-1315-x. PMID: 19277602.19277602
266 Sakane N, Sato J, Tsushita K, . Prevention of type 2 diabetes in a primary healthcare setting: three-year results of lifestyle intervention in Japanese subjects with impaired glucose tolerance. BMC Public Health. 2011 Jan 17;11(1):40. doi: 10.1186/1471-2458-11-40. PMID: 21235825.21235825
267 Zinman B, Harris SB, Neuman J, . Low-dose combination therapy with rosiglitazone and metformin to prevent type 2 diabetes mellitus (CANOE trial): a double-blind randomised controlled study. Lancet. 2010 Jul 10;376(9735):103–11. doi: 10.1016/S0140-6736(10)60746-5. PMID: 20605202.20605202
268 Aekplakorn W, Tantayotai V, Numsangkul S, . Evaluation of a community-based diabetes prevention program in Thailand: a cluster randomized controlled trial. J Prim Care Community Health. 2019;10:2150132719847374. doi: 10.1177/2150132719847374. PMID: CN-01936412.31079517
269 Barengo NC, Acosta T, Arrieta A, . Early lifestyle interventions in people with impaired glucose tolerance in northern Colombia: the DEMOJUAN project. Int J Environ Res Public Health. 2019;16(8)doi: 10.3390/ijerph16081403. PMID: CN-01936821.
270 Moungngern Y, Sanguanthammarong S, Teparak P, . Effects of a health promotion program conducted by nurses on stabilization of HBA1C in subjects at risk for diabetes: a phase III randomized controlled trial. Chotmaihet thangphaet [journal of the medical association of thailand]. 2018;101(10):1343–8. PMID: CN-01650364.
271 Kramer MK, Vanderwood KK, Arena VC, . Evaluation of a diabetes prevention program lifestyle intervention in older adults: a randomized controlled study in three senior/community centers of varying socioeconomic status. Diabetes Educ. 2018 Apr;44(2):118–29. doi: 10.1177/0145721718759982. PMID: 29514568.29514568
272 Kulkarni S, Xavier D, George B, . Effect of intensive lifestyle modification & metformin on cardiovascular risk in prediabetes: A pilot randomized control trial. Indian J Med Res. 2018 Dec;148(6):705–12. doi: 10.4103/ijmr.IJMR_1201_17. PMID: 30778004.30778004
273 Wong CK, Fung CS, Siu SC, . A short message service (SMS) intervention to prevent diabetes in Chinese professional drivers with pre-diabetes: a pilot single-blinded randomized controlled trial. Diabetes Res Clin Pract. 2013 Dec;102(3):158–66. doi: 10.1016/j.diabres.2013.10.002. PMID: 24466598.24466598
274 Wong CKH, Siu SC, Wong KW, . Five-year effectiveness of short messaging service (SMS) for pre-diabetes. BMC Res Notes. 2018 Oct 10;11(1):709. doi: 10.1186/s13104-018-3810-y. PMID: 30309382.30309382
275 Lai YJ, Hu HY, Chen HH, . Dipeptidyl peptidase-4 inhibitors and the risk of acute pancreatitis in patients with type 2 diabetes in Taiwan: a population-based cohort study. Medicine (Baltimore). 2015 Oct;94(43):e1906. doi: 10.1097/md.0000000000001906. PMID: 26512613.26512613
276 Yang Y, Yao JJ, Du JL, . Primary prevention of macroangiopathy in patients with short-duration type 2 diabetes by intensified multifactorial intervention: seven-year follow-up of diabetes complications in Chinese. Diabetes Care. 2013 Apr;36(4):978–84. doi: 10.2337/dc12-0227. PMID: 23230099.23230099
277 Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998 Sep 12;352(9131):854–65. PMID: 9742977.9742977
278 Holman RR, Paul SK, Bethel MA, . 10-year follow-up of intensive glucose control in type 2 diabetes. N Engl J Med. 2008 Oct 9;359(15):1577–89. doi: 10.1056/NEJMoa0806470. PMID: 18784090.18784090
279 UK Prospective Diabetes Study Group. Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38. BMJ. 1998 Sep 12;317(7160):703–13. PMID: 9732337.9732337