# Appendix D Quality Assessments

Appendix D Table 1 Quality Assessment of Controlled Trials (All KQs)

First Author, Year; Trial Name | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | What was the reported adherence to the intervention? | Did the study have cross-overs or contamination raising concern for bias? | What was the overall attrition? Enter values for both loss to f/u (missing data) and non-completers | What was the differential attrition? | Did the study have high differential attrition (>10% but think about how it might bias) or overall high attrition (depends on duration and outcome; generally 20%) raising concern for bias?
Wu, 2015^204^ | Yes | Yes | Yes | NR | No | 4% | 2% | No
Block, 2015^205^; Alive-PD | Yes | Unclear | No | NR | No | 11% (3 m); 14% (6 m) | 5% (6 m) | No
Bulatova, 2017^206^ | Unclear | Unclear | No | NR | No | 42% | 7% | Yes
Alfawaz, 2018^207^ | Yes | Yes | Yes | NR | No | 26% | 13-27% across arms | Yes
Kumar, 2014^208^ | Yes | Unclear | Yes | Unclear (n=7/242 excluded during run-in for “severe noncompliance”; n=2 excluded during study period for poor compliance) | No | 1% | 0% | No
Hesselink, 2015^209^ | Yes | Unclear | No | During year 1, 48% of intervention group received fewer than the 5 recommended visits in study protocol | 66% of control group received more than the single visit prescribed for IFG by U.K. guidelines | Sites: 15%; Individuals:; 19% (12 m); 22% (24 m) | Sites: 13%; Individuals:; 11% (12 m); 6% (24 m) | Yes
Echouffo-Tcheugui, 2015^210^ | Yes | Yes | Unclear | Not reported | Unclear | 59% | 9.8% | Unclear
Maindal, 2014^98^ | Yes | Yes | Unclear | 38% received the intervention (attended >3 meetings) | Unclear | 58% (141/242) based on heart score for diabetic group | Not reported | Yes
Kulzer, 2009^112^; Prevention of Diabetes Self-Management Program (PREDIAS) | Yes | Yes | Yes | NR | Unclear | 17/182 participants=9.3% dropout | Attrition not reported for control and intervention groups separately (only provide overall dropout rate) | No
Moore, 2011^211^ | Unclear | No | Unclear | NR | Unclear | Attrition: 11% (33/307) overall for non- completers overall but varied significantly across measured variables (e.g., 35% for BP, from 0-23% for primary variables-NR) | 4% [(25/208)-(8/99)] | Unclear
Morey, 2012^120^; The Enhancing Fitness in Older Overweight Veterans with Impaired Glucose Tolerance (Enhanced Fitness) Trial | Unclear | Yes | No | NR | NR | 13.2% | 3.7% | No
Oldroyd, 2001^212^ | Yes | Yes | No | 24/39 attended all 6 f/u appointments (62%) | NR | Noncompleters (at 6-months f/u) 14% (67/78) | 8% [(7/39)-4/39)] | No
Yates, 2009^138^; The Prediabetes Risk Education and Physical Activity Recommendation and Encouragement (PREPARE) | Yes | Yes | Yes | NR | NR | Noncompleters: 15% (83/98); Missing data: 11% (87/98) | Non-completers (control vs. combined intervention) 13%; Missing data (control vs. combined intervention) 6% | Yes
Sakane, 2015^140^; The Japan Diabetes Outcome Intervention Trial-1 (J-DOIT1) | Yes | No | Unclear | Proportion with good adherence (>80%) was 91.4%, 82.7%, and 81.1% in centers A, B, and C, respectively | No | Confirm that we need one number here; Overall attrition: (217+288)/2,607=19.3% | 3.4% (20.9-17.5) | No
Wang, 2017^213^ | Unclear | Unclear | Yes | NR | NR | No attrition | No attrition | No
Duijzer, 2017^214^ | Unclear | Yes | Unclear | NR | NR | Attrition at 12 months: 13% (41/316); Attrition at 18 months: 24% (76/316) | At 12 months: 5% [(16/155)- (25/161)]; At 18 months: 0% [(37/155)-(39/161)] | No problems with diff attrition at 12 months or 18 months; however, high overall attrition at 18 months.
Hu, 2017^215^ | Yes | Yes | Yes | At 12 months, dietary 80.2%, physical activity 50.8%; Attended education curriculum=85.7%; SMBG=56.7%; Lifestyle behavior changes=ranged from 27-83% across behaviors | NR | Total dropout was 32/434 at 6 months (7.4%); 57/434 at 12 months (13.1%) | At 12 months: 1.9% | No
Cezaretto, 2017^216^ | Unclear | Unclear | Yes | Although compliance was defined as 70%, attendance to the interdisciplinary group sessions, compliance (AKA adherence) not reported | NR | 25% overall (22+24=46) (47/183) taking into account those who either dropped out or died).; (22+1+4+24+3)/183=29.5% taking into account those who dropped out, diet, or had onset of T2DM. | Intervention group=27/97=27.8%; Control group=27/59=45.8% | Yes
O’Brien, 2017^142^; The Promotora Effectiveness Versus Metformin Trial (PREVENT-DM) | Yes | Yes | Yes | ILI group: 70% attended 9/24 sessions; Met group: 66% adherence | NR | Total attrition (7/92=7.6%) | 2% | No
Van Name, 2016^141^ | Unclear | Unclear | No | 68% attended (42 subjects) attended at least 14 classes in the ILI group, 7% (4 subjects) attended 0-2 classes | NR | 6% (8/130) | 0% | No
Ackermann, 2015^139^; Reaching Out to Prevent Increases in Diabetes (RAPID) | Yes | Yes | Yes | 62.6% of the YDPP group went to at least 1 lesson. 40.0% went to 9 or more intervention lessons | Suggest unclear | Missing wt data:15.5% at 12 months | 3.3 | No
Juul, 2016^145^ | Yes | Yes | Unclear | Attendance rates for the 6 sessions for the intervention group was 95%, 88%, 87%, 73%, 67%, 51%, respectively | Unclear | 15% noncompleters for clinical measurements | 5% [(11/63)-(8/64)] | No
Yeh, 2016^217^ | NR | NR | Unclear | 89.2% for core intervention session. 55.8% at 6 monthly post-core sessions | NR | 3.3% | 6.67% | No
Kaku, 2015^218^ | Unclear | Unclear | Yes | NR | NR | 3.3% | Suggest NR | No
Dawes, 2015^219^ | Unclear (cluster randomized) | Unclear | No | NR | Unclear | 5% (of those who responded to the recruitment letter); 33% of participants recruited agreed to participate | 1.5% | No
Hellgren, 2014^143^ | Unclear | Unclear | Yes | NR | Unclear | 13% | 0-21% (across 3 groups) | Unclear
Davies, 2016^86^; Gray, 2016^118^; Let’s Prevent Diabetes | Unclear | Unclear | No | 23% of participants in intervention group did not attend initial education session | Unclear | 24% | 3% | Unclear
Bhopal, 2014^36^; Welsh, 2016^220^; The Prevention of Diabetes and Obesity in South Asians (PODOSA) study | Yes | Yes | No | Varied by year and group; nearly all of individual group participants and family members attended scheduled visits (>94%) | Unclear | Individuals: 2%; Families: 1% | Individuals: 2%; Families: 1% | No
Mann, 2016^221^ | Yes (PCPs randomized) | Unclear | Unclear for PCPs; participants mostly similar | NR | Unclear | 9% | 11% | Yes
Weber, 2016^222^; Gokulakrishnan, 2017^223^; Diabetes Community Lifestyle Improvement Program (D-CLIP) | Yes | Yes | Yes | Intervention group attended an average of 12 classes (out of 16); 22% attended all 15, and 70% attended 12 or more | Unclear | 5% | 0% | No
le Roux, 2017^115^ SCALE Obesity and Prediabetes Trial | Yes | Yes | Yes | NR | No | 3% (analyzed sample at 3 years); 50% (completed treatment at 3 years) | 0.5% (analyzed sample at 3 years); 8% (completed treatment at 3 years, higher in liraglutide arm) | Unclear
Kosaka, 2005^224^ | Unclear | Unclear | Yes | NR | No | See comments; 8.5% loss to followup over years 1-4 | See comments; 2.1% loss to followup over years 1-4 | Unclear
Pan, 1997^225^; Li, 2008^226^; Li, 2014^227^; Gong, 2019^228^; China Da Qing Diabetes Prevention Outcomes Study (CDQDPOS) | Unclear; cluster randomization | Unclear | Unclear | NR | Unclear | 8% at 6 years; 6% at 20, 23, and 30 years | NR at 6 years; 5% at 20, 23, and 30 years | No
Dyson, 1997^229^ | Unclear | Unclear | Unclear | NR | No | 11% | 7% | Unclear
Eborall, 2007^230^; Paddison, 2011^231^; ADDITION-Cambridge | Yes | Yes | Yes | Screening group: 32% invited did not attend | Unclear | Response rates; Control (not invited to screen):; Initial: 54%; 3-6 months: 43%; 12-15 months: 37%; Screening attenders:; Initial: 74%^*^; 3-6 months: 66%; 12-15 months: 67%; Screening nonattenders:; Initial: N/A; 3-6 months: 50%; 12-15 months: 43% | Varies by group and comparison. Higher among screening group attenders than control group and screening nonattenders at all time points. | Yes
Tuomilehto, 2001^232^; Uusitupa, 2009^233^; Finnish Diabetes Prevention Study (FDPS) | Yes | Yes | Yes | NR | Yes | 3% | 0% | No
Ramachandran, 2006^234^ Indian Diabetes Prevention Programme | Unclear | Unclear | No (see comments) | At study end:^†^; Lifestyle alone: 82% diet, 59% activity; Lifestyle plus metformin: 82% diet, 63% activity, 91% metformin 91%; Metformin alone: 95% metformin | Unclear | 5% | 0-4% across groups | No
Chiasson, 2002^235^; Chiasson, 2003^236^; STOP-NIDDM | Yes | Yes | Yes | 29% in acarbose arm and 19% in placebo arm discontinued early; higher % in acarbose arm discontinued due to GI adverse events than placebo arm (19% vs. 5%) | No | 4% (loss to followup); 24% discontinued early but were included in analysis | 0% (loss to followup); 12% more in acarbose group discontinued early | Unclear
Diabetes Prevention Program Research Group, 2002^80^; Diabetes Prevention Program Research Group, 2005^119^; Diabetes Prevention Program Research Group, 2012^97^; DPP | Yes | Yes | Yes | Lifestyle intervention: 74% met goal of 150 min of physical activity per week, 58% at most recent visit at trial closure; % who took ≥80% of prescribed medication:; Placebo: 77%; Metformin: 72% | No | 0% (all participants included in analyses); at close of study, 7.5% had not attended a scheduled visit within the previous 5 m | 0% | No
Diabetes Prevention Program Research Group, 2012^237^ Diabetes Prevention Program Research Group, 2009^146^; Diabetes Prevention Program Research Group, 2015^79^; Apolzan, 2019^238^; Diabetes Prevention Program Research Group, 2019^81^; DPPOS | Yes | Yes | No (for characteristics at DPPOS enrollment); Yes, for original DPP arms | 12% of DPP participants did not continue into DPPOS (censored from adherence outcomes after DPP); Average metformin adherence: (adherent defined as taking ≥80% of prescribed medication): DPP: 72% DPPOS: 49% | Yes; after DPP, all groups were offered a 15-session lifestyle intervention. % of randomized groups attending at least some sessions during open-label extension:; Placebo: 57%; Metformin: 58%; Lifestyle: 40% | 12% of DPP participants chose not to continue into DPPOS; an additional 15% did not have microvascular outcome data | 0% (similar number in each group participated in DPPOS and had microvascular outcomes) | Unclear
Aroda, 2016^239^ | Yes | Yes | No; analysis limited to DPP participants with B12 measure at DPPOS year 1 or year 9. Higher % in placebo group with diabetes, anemia, and using acid-suppression medication at DPPOS year 1 | Average metformin adherence: (adherent defined as taking ≥80% of prescribed medication): DPP: 72% DPPOS: 49% | Yes, at DPPOS year 9, 11.4% of metformin group and 10.1% of placebo group used acid suppression medication; no information about use of B12 or other supplements | Of those randomized, 21% not included at DPPOS year 1 and 30% at DPPOS year 9 | 0% (similar number in each group met inclusion criteria) | Yes
Aroda, 2015^240^ | Yes | Yes | No, analysis limited to parous women with ≥ live birth; characteristics by treatment arm NR. Women with GDM history were younger than those with no GDM (mean 43 vs. 51 years). Potential misclassification of GDM status due to recall bias, lack of verification, differences in screening practices over time | Unclear | Unclear; women reporting GDM were younger than those with no past GDM. Potential contamination due to differences in GDM screening and treatment among older vs. younger women | 13% of DPP participants chose not to continue in DPPOS; Men and non-parous women were excluded from GDM subgroup analysis (45%) | 3% (difference in DPPOS participation among parous by GDM status) | Yes
Griffin, 2011^241^; Simmons, 2012^242^; Van den Donk, 2013^243^; Simmons, 2016^76^; Griffin, 2019^244^; ADDITION-Europe | Yes | NA (cluster randomized | No; slightly lower % in the routine care vs. intensive therapy group reported using antihyperten-sives (43.7 vs. 46.7), cholesterol lowering medications (15.4 vs. 17), and aspirin (12.6 vs. 15.5); characteristics of practices randomized not provided | NR | Unclear; screening programs and intervention delivery varied by study center. Authors note that trial was undertaken at the same time as other improvements in diabetes care delivery and changes in T2DM treatment guidelines | CVD outcomes: Practices: 7%; Participants: 0%; For QoL, 27% had missing data (all but 4% were included in multiple imputation analysis) | CVD outcomes: Practices: 7% (11% routine care vs. 4% intensive treatment sites); Participants: 0%; For QoL, 4% | No for CVD outcomes; unclear for QoL
Charles, 2011^245^; ADDITION-Denmark | Yes | NA (cluster randomized) | No; slightly fewer participants in the routine care group were on antihyperten-sives (76% vs. 80%), lipid lowering drugs (75% vs. 81%) and anti-glycemics (52 vs. 63%) drugs than the intensive treatment arm. More patients were identified in intensive treatment practices than control practices via screening (number of practices randomized were equal) | NR | Unclear; screening programs and intervention delivery varied by study center | Practices: 5%; Participants: 24% (29% for neuropathy outcome) | Practices: 3%; Participants: 3% | Yes
Van den Donk, 2010^95^; Janssen, 2009^117^; ADDITION-Netherlands | Yes | NA (cluster randomized) | Yes (participants mostly similar); higher % of treatment practices in urban centers than routine care (30% vs. 52%) | NR | Unclear; Dutch guidelines for T2DM updated during study period, authors note that some routine care providers may have offered more intensive treatment of CVD risk factors | 12 months:; Practices: 0%; Participants: 1.4%; 3 and 4.5 years (QoL): Varies by measure, up to 28% to 40% did not respond | 12 months:; Practices: 0%; Participants: 1%; 3 and 4.5 years (QoL): Authors report no differential missing data | No (12 months); Yes (QoL at 3.5-4 years)
UKPDS, 1998^1^; UKPDS | Yes | Yes | Yes | Unclear | Unclear | 2-3% (varies by outcome and comparison) | 0% | No
Pan, 2003^246^ | Unclear | Unclear | No | Medication compliance (for N analyzed):; Acarbose: 98%; Placebo: 96% | No | 4% | 2% | No
Park, 2008^247^; ADDITION-Cambridge (pilot study) | Yes | Unclear | Yes | 82% of intervention group attended screening | No | 31% | 5% | No
Simmons, 2012^248^; ADDITION-Cambridge | Yes | Yes | Yes | 78% of intervention group attended screening | No | Unclear | Unclear | Unclear
Simmons, 2011^249^; Rahman, 2012^250^; Ely | Unclear | Unclear | No; differences in gender; age and deprivation; adjusted for in analysis | Phase I: 68% of intervention group attended screening; Phase II: 45% of intervention group attended screening | No | Unclear | Unclear | Unclear
Davies, 2008^93^; Khunti, 2012^94^; DESMOND | Yes | Yes | No; not HbA1c, sex, or use of oral hypoglycemic agents | NR | No | 4 months: 1.4%; 8 months: 4.25; 12 months: 6.1% | 4 months: 1.18%; 8 months: 1.2%; 12 months: 1.9% | No
DeFronzo, 2011^251^; Espinoza, 2016^252^; Actos Now for Prevention of Diabetes Trial (ACT NOW) | Unclear; likely yes (block randomization based on a “randomization code”) | Unclear | Yes | Adherence to the study regimen by pill count was greater than 80% in both groups | No | 27.6% | 7.1% | No
DREAM Trial Investigators, 2006^253^; DREAM Trial Investigators, 2006^254^; DREAM Trial Investigators, 2008^255^; Diabetes Reduction Assessment with ramipril and rosiglitazone Medication (DREAM) Trial | Yes | Yes | Yes | At least 80% adherence; G1: 75.1%, G2: 71.1% | No | 1.9% | .49% | No
Kawamori, 2009^256^ | Yes | Yes | Yes | Compliance with treatment was similarly high in the two treatment; those who did not take their medication were excluded groups | No | 15% | 2.12% | No
Katula, 2013^144^; Pedley, 2018^257^; Healthy Living Partnership (HELP PD) | Unclear | Unclear | Yes | Sessions attendance of Intervention group; Phase 1: 72.2% (15.5% makeup by phone); Phase 2: 40.4 (22.9% makeup by phone); Across 24 months: 58.6%(18.7% by phone) | No | 6 months: 6.97%; 12 months: 9.30%; 18 months: 14.62%; 24 months: 13.29% | 6 months: 8.57%; 12 months: 2.6%; 18 months: 5.21%; 24 months: 5.22% | No
Lindahl, 2009^137^ | Yes | Yes | Yes | Unclear, reported that adherence was low | No | 13.4% | 7.4% | No
Lindblad, 2011^258^; The Nepi ANtidiabetes StudY (NANSY) | Unclear | Unclear | Yes | Unclear | No | 25.9% | Unclear | Unclear
Lu, 2011^259^ | Unclear | Unclear | Yes | Unclear, broken down by each component, significant differences between groups except for agents for dyslipidemia | No | 11.9% | 5% | No
The NAVIGATOR Study Group, 2010^260^; The NAVIGATOR Study Group, 2010^261^; Currie, 2017^262^; Nateglinide and Valsartan in Impaired Glucose Tolerance Outcomes Research (NAVIGATOR) Trial | Yes | Yes | Yes | Those taking medication 6 months: 92 vs. 94.2; 1 year: 79.8% vs. 80.8; 3 years: 74.7 vs. 75.9; 5 years 69.9 vs. 71.0 | No | 19.7% | 0.17% | No
Nijpels, 2008^263^; DAISI | Yes | Yes | No;; not HbA1c | 95% compliance (6 reported noncompliance) | No | 44.07% | 12.07% | No
Penn, 2009^264^ | Yes | Yes | Yes | Unclear | No | Year 1:18.62%; Year 2: 23.53%; Year 3: 28.43%; Year 4: 32.35% | Year 1: 5.88%; Year 2: 3.92%; Year 3: 7.84%; Year 4: 5.88% | No
Ramachandran, 2009^265^; IDPP-2 | Yes | No, sequential | Yes | >80% adherence; G1: 61.3 vs. G2: 60.2 | No | 9.83% | 3.72% | No
Saito, 2011^87^; ZPLS | Yes | Yes | Yes | Unclear | No | 12.3% | 3.54% | No
Sakane, 2011^266^ | Unclear | Unclear | Yes | Unclear, only reported nurses training attendance | No | 28.04% | 2.78% | No
Zinman, 2010^267^; CAnadian Normoglycemia Outcomes Evaluation trial (CANOE) | Yes | Yes | Yes | At least 80%, G1: 78%, G2: 81% | No | 13.05% | 3.06% | No
Aekplakorn, 2019^268^ | Yes | NR | No, differences between groups for weight/BMI | NR | NR | 146 (16.7%) of control group; 111 (10.8%) of the intervention group; Overall attrition was 13.5%. | 5.9% | No
Barengo, 2019^269^ | Yes | NR | No, there were differences in the percentage of subjects in each of the 3 BMI categories and percentage with a previous increased glucose in blood; for the study participants who were included in the analysis, the percentages of individuals with normoglycemia, isolated IFG, isolated IGT, and IFG and IGT were different | 100% of the nutrition and physical activity groups attended at least one group and one individual session | NR | Half of the study participants were lost to followup of at least 18 months; 122/246 (50%) of control group, 136/261 in the nutritional intervention group (52%), and 132/265 in the physical activity intervention group (50%) remained for the data analysis process | <3% | Yes. Overall attrition was 49.5%
Moungngern, 2018^270^ | Yes | Unclear | Yes | NR | No | Attrition for completers: 11.2% | 3.7% | No
Kramer, 2018^271^ | Yes | Yes | Yes | 75% of all participants attended at least 12 of 16 core sessions with median attendance 14 of 16 initial sessions and 4 of 6 post-core sessions | Unclear | 7.5% | 1.5% | No
Kulkarni, 2017^272^ | Yes | Yes | Unclear | 85% +/- 6.5% | No | 14.6% | 5.3% and 11% | Unclear
Wong, 2013^273^; Wong, 2018^274^ | Yes | Yes | No, differences between groups for BMI, occupational profile, frequency of eating out, family history of T2DM, and hypertension | NR | No | At 24 months, 32% attrition; At 60 months, 45/54 in the intervention group and 41/50 remained; 17% overall attrition | At 24 months. 41/54 in intervention and 29/50 of the control group remained. 24% differential attrition | Yes, high overall and differential attrition at some timepoints but not all

* Response rates were similar among those who screened positive and negative (82% and 81%, respectively). However, 310 questionnaires from screen-positive patients that were completed or returned after the date of the second test were excluded, reducing response rate among screen positive individuals to 65% and 74% overall. Similarly, to ensure analyses captured effect of screening results, questionnaires received from attenders before they had their results at 3-6 months (N=10) and 12-15 months (n=4) were excluded.

† Metformin adherence was defined as taking ≥50% of pills and assessed by tablet count once every 3 months.

Abbreviations: ACT NOW=Actos Now for Prevention of Diabetes; ADDITION=Anglo-Dutch-Danish Study of Intensive Treatment in People with Screen Detected Diabetes in Primary Care; AKA=also known as; BMI=body mass index; CANOE=CAnadian Normoglycemia Outcomes Evaluation trial; CDQDPOS=China Da Qing Diabetes Prevention Outcomes Study; CVD=cardiovascular disease; D-CLIP=Diabetes Community Lifestyle Improvement Program; DAISI=Dutch acarbose intervention study in persons with impaired glucose tolerance; DESMOND=Diabetes education and self management for ongoing and newly diagnosed programme; DM=diabetes mellitus; DPP=Diabetes Prevention Program; DPPOS=Diabetes Prevention Program Outcomes Study; DREAM=Diabetes Reduction Assessment with ramipril and rosiglitazone Medication; FDPS=Finnish Diabetes Prevention Study; GDM=gestational diabetes mellitus; HbA1c/HBA1c=hemoglobin A1c; IDPP-2=Indian Diabetes Prevention Programme-2; IFG=impaired fasting glucose; IGT=impaired glucose tolerance; J-DOIT1=The Japan Diabetes Outcome Intervention Trial-1; KQ=key question; NA=not applicable; NANSY=The Nepi ANtidiabetes StudY; NAVIGATOR=Nateglinide and Valsartan in Impaired Glucose Tolerance Outcomes Research; NR=not reported; PCP=primary care physician; PODOSA=The Prevention of Diabetes and Obesity in South Asians; PREDIAS=Prevention of Diabetes Self-Management Program; PREPARE=The Prediabetes Risk Education and Physical Activity Recommendation and Encouragement; PREVENT-DM=The Promotora Effectiveness Versus Metformin Trial; QoL=quality of life; RAPID=Reaching Out to Prevent Increases in Diabetes; SCALE=Satiety and Clinical Adiposity–Liraglutide Evidence; STOP-NIDDM=Study TO Prevent Noninsulin-Dependent Diabetes Mellitus; T2DM=type 2 diabetes mellitus; UKPDS=United Kingdom Prospective Diabetes Study; vs.=versus; wt=weight; ZPLS=Zensharen Study for Prevention of Lifestyle Diseases.

Appendix D Table 2 Quality Assessment of Controlled Trials (All KQs)

First Author, Year; Trial Name | Were outcome measurements equal, valid and reliable? | Were patients masked? | Were providers masked? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | What was the method used to handle missing data? | Did they use an ITT analysis? (i.e., Analyze People in the Groups They Were Randomized to) | Quality Rating (for Benefits) | Comments
Wu, 2015^204^ | Yes | Yes | Yes | Yes | Unclear | Non-completers excluded from analysis | No | Fair | Potential for selection bias; 22% of participants enrolled in placebo run-in excluded (16/73) for unclear reasons. Adherence not reported. Duration of followup on adequate to assess long-term harms.
Block, 2015^205^; Alive-PD | Yes | No | Yes | Yes | | Imputation (Heckman selection model) | Yes | Fair | More Asian participants (25.2 vs. 16.5) and fewer Hispanic participants (4.3 vs. 8.0) in intervention group than control group. Six months may not be adequate to assess benefit of this behavioral intervention for preventing diabetes.
Bulatova, 2017^206^ | Yes | No | Unclear | Unclear | Yes | Excluded from analysis | No | Poor | Fewer males, diabetics (vs. prediabetics) and patients with metabolic syndrome in control vs. intervention group. Authors note lack of adherence as a limitation, but do not provide rates of adherence. High overall attrition (42%); analysis includes completers only.
Alfawaz, 2018^207^ | Yes | No | Unclear | Unclear | Yes | Excluded those lost to followup at 6 m and 12 m; LOCF for those with some missing data (<5% of total data points on a variable) | No | Poor | Unclear masking of provides/outcome assessors. No description of compliance. High overall and differential attrition (greater in arm assigned metformin than lifestyle intervention). Excluded participants from analysis who did not complete 6- or 12-month followup.
Kumar, 2014^208^ | Yes | Yes | Unclear | Unclear | Yes | LOCF | No | Fair
Hesselink, 2015^209^ | Yes | No | No | No | Yes | Excluded from analysis | | Poor | Cluster-randomized trial; methods for recruiting participants differed across sites (opportunistic screening/referral, vs. using pre-specified criteria). Participants in intervention group were younger (62 vs. 65 years) and more likely to report being motivated to change their lifestyle (46% vs. 30%) than control group. No description of practice-level characteristics. More practices and participants in control group were lost to followup than intervention group. Potential contamination (more visits for IFG in control group than planned).
Echouffo-Tcheugui, 2015^210^ | No | No | No | Unclear | Yes | NA | Yes | Fair
Maindal, 2014^98^ | No | No | No | Yes | Yes | Not reported | Unclear | Poor | High risk of selection bias and underpowered for differences for subgroup of interest.
Kulzer, 2009^112^; Prevention of Diabetes Self-Management Program (PREDIAS) | Unclear | No | Unclear | Yes | Yes | Last value moved forward | Yes | Fair
Moore, 2011^211^ | Yes | No | No | Unclear | Yes | Missing data was excluded | No | Poor | Very high rates of diff attrition and/or overall attrition for all eligible outcomes: BMI, weight, HDL, LDL, BP
Morey, 2012^120^; The Enhancing Fitness in Older Overweight Veterans with Impaired Glucose Tolerance (Enhanced Fitness) Trial | Yes | No | Unclear | Yes | Yes | Mixed models | Yes | Fair
Oldroyd, 2001^212^ | Yes | No | No | NR | Yes | None | No | Fair
Yates, 2009^138^ | Yes | No | No | NR | Yes | LOCF and NOCB | No | Fair
Sakane, 2015^140^; The Japan Diabetes Outcome Intervention Trial-1 (J-DOIT1) | No | No | No | No | Yes | LOCF | Yes | Fair
Wang, 2017^213^ | Yes | NR | Unclear | Unclear | Yes | NA | NR | Poor | High risk of selection bias, poor reporting, underpowered
Duijzer, 2017^214^ | Yes | No | No | NR | Yes | Per protocol analysis, missing data were excluded | No | Fair
Hu, 2017^215^ | Yes | No | No | NR | Yes | Missing data were excluded | Yes | Fair
Cezaretto, 2017^216^ | Yes | Unclear | Unclear | Unclear | Yes | Used generalized linear mixed models considering an unstructured covariance matrix, which takes into account missing data | No | Poor | High rate of overall attrition and high rate of differential attribution
O’Brien, 2017^142^ | Yes | No | No | Unclear | Yes | Modified intention to treat (excluded those who were in baseline groups who became pregnant) | Yes | Fair
Van Name, 2016^141^ | Yes | No | No | NR | Yes | Per protocol analysis, missing data not included | No | Fair
Ackermann, 2015^139^; Reaching Out to Prevent Increases in Diabetes (RAPID) | Yes for wt as primary outcome; No for A1c and lipids | Yes | Yes | Yes | Yes | Multiple imputation | Yes | Good
Juul, 2016^145^ | Yes | No | No | No | Yes | No imputation, intention to treat | Yes | Fair
Yeh, 2016^217^ | Yes | No | No | NR | Yes | None | No | Poor | Pilot study, very small, poor reporting. High risk of selection bias and perhaps contamination due to lack of blinding, per protocol analyses
Kaku, 2015^218^ | Yes | Yes | NR | Yes | Yes | Excluded missing data | Yes | NA
Dawes, 2015^219^ | Yes | No | No | Unclear | Yes | None (excluded) | No | Poor | Cluster-randomized study with N=6 practice sites randomized. Characteristics of sites not provided; Intervention group included a higher % of males (57% vs. 42%) and Asian participants (46% vs. 4%). Despite cluster design, study was analyzed at individual participant level and analyses were not adjusted for ICC.
Hellgren, 2014^143^ | Yes | No | Unclear | Unclear | Yes | None (excluded) | No | Fair | Unclear reporting of randomization; 13% attrition (differential attrition varied 0-21% across groups). Participants lost to followup were excluded from analysis.
Davies, 2016^86^; Gray, 2016^118^; Let’s Prevent Diabetes | Yes | No | No | Unclear | Yes | LOCF | Yes (modified ITT) | Fair | Cluster-randomized trial. At baseline, intervention group had higher rates of smoking and more lived in socially deprived locations than usual-care group; weight, BMI, and weight circumference were significantly higher in standard-care group than intervention group.
Bhopal, 2014^36^; Welsh, 2016^220^; The Prevention of Diabetes and Obesity in South Asians (PODOSA) study | Yes | No | No | Unclear | Yes | Excluded those who died or were lost to followup (LOCF for missing data at followup visits) | Modified ITT | Fair | Characteristics of individuals in intervention and control groups mostly similar except for more physical activity in intervention group, and less cholesterol medication in intervention group than control. Low attrition, analysis included nearly all randomized except for 1-2 participants in each group who died or were lost to followup.
Mann, 2016^221^ | Yes | No | No | Unclear | Unclear | None (excluded) | No | Poor | Randomized at provider level; 20 providers (from 2 practices) randomized. Characteristics of providers/practices NR. Intervention is an EMR-based tool to facilitate goal setting. Risk of contamination (providers at same practice randomized to intervention and control). Results analyzed at individual level. Differential attrition (11%, higher in intervention group).
Weber, 2016^222^; Gokulakrishnan, 2017^223^; Diabetes Community Lifestyle Improvement Program (D-CLIP) | Yes | No | No | Unclear | Unclear | Excluded those who moved or were lost to followup | No | Fair | Excluded participants who moved or were lost to followup; however, attrition was low (and no differential attrition).
le Roux, 2017^115^; SCALE Obesity and Prediabetes Trial | Yes | Yes | Yes | Unclear | Yes | LOCF for post-baseline measurements | No | Fair | High rate of attrition/withdrawal at 3 years (50% overall), although analysis accounted for missing data.
Kosaka, 2005^224^ | Yes | No | No | Unclear | Yes | Unclear | No | Fair | Risk of selection bias; selection method for eligible participants from larger cohort not described. N randomized NR; after 1 year of observation, 5.6% in control and 4.7% in intervention group initially randomized dropped out, and 8.5% of those who continued did not attend the final outcome assessment. Handling of missing data unclear.
Pan, 1997^225^; Li, 2008^226^; Li, 2014^227^; Gong, 2019^228^; China Da Qing Diabetes Prevention Outcomes Study (CDQDPOS) | Yes; unclear for 10-year CVD (some cases based on ECG results only, not patient history or symptoms) | No | No | Unclear for 6, 23, and 30-year followup; adjudicators for mortality and CVD outcomes at 20-year blinded to intervention status | Yes | None (excluded) | No | Fair | Cluster randomization at clinic level); characteristics of clinics NR. Unclear whether individuals recruited before or after clinics randomized. At 23 and 30 years followup, an imbalance in smoking status (50% control vs. 38% intervention) was reported and adjusted for in a post hoc analysis. Not reported in previous papers. Unclear validity of CVD outcomes at 10 years and later (some cases based on ECG results alone).
Dyson, 1997^229^ | Yes | No | No | Unclear | Yes | None (excluded) | No | Poor | Table of baseline characteristics not provided; groups were similar in a range of metabolic measures at baseline, aside from triglyceride levels (slightly higher among intervention group vs. control group). Overall attrition 11% (7% differential attrition); analyses did not address missing data.
Eborall, 2007^230^; Paddison, 2011^231^; ADDITION-Cambridge | Yes | No | No | Unclear | Yes | None (excluded) | No | Fair | Nonrandomized substudy of ADDITION trial. Baseline characteristics similar, but no baseline measures of psychological distress/ anxiety reported. Low response rate among screening group nonattenders; reasons for nonresponse in this group may be associated with outcome (worry about diabetes, distress associated with screening).
Tuomilehto, 2001^232^; Uusitupa, 2009^233^; Finnish Diabetes Prevention Study (FDPS) | Yes | No | No | Yes | Yes | None (excluded) | No | Fair | No ITT analysis; however, attrition was low. Control group reported improved diet/exercise habits (varied by goal, 40% decreased sugar intake, 15 increased exercise) raising concern for contamination.
Ramachandran, 2006^234^ Indian Diabetes Prevention Programme | Yes | No | No | Unclear | Yes | None (excluded) | No | Fair | Groups mostly similar at baseline except for higher % w/family history of diabetes in control group (59%) than metformin (41%) and LSM+MET group (47%). No ITT analysis; however, overall attrition was low (5%).
Chiasson, 2002^235^; Chiasson, 2003^236^; STOP-NIDDM | Yes | Yes | Yes | Yes | Yes | Excluded; authors report inclusion of 3% of patients without followup measure did not affect results (provide p-value only) | No | Fair | High rate of early discontinuation (24% overall), more participants in acarbose group withdrew early due to GI adverse effects than control group. Nearly all participants included in 3-year analysis
Diabetes Prevention Program Research Group, 2002^80^; Diabetes Prevention Program Research Group, 2005^119^; Diabetes Prevention Program Research Group, 2012^97^; DPP | Yes | No for lifestyle vs. medication (participants masked to placebo vs. metformin) | Yes for metformin and placebo groups | Yes | Yes | LOCF | Yes | Good
Diabetes Prevention Program Research Group, 2012^237^; Diabetes Prevention Program Research Group, 2009^146^; Diabetes Prevention Program Research Group, 2015^79^; Apolzan, 2019^238^; Diabetes Prevention Program Research Group, 2019^81^; DPPOS | Yes | For study period only, not open-label extension | For study period only, not open-label extension | Unclear | Yes | LOCF (for DPP and those who chose to participate in DPPOS) | No (12% did not participate in open-label phase) | Fair | Analyses combine outcomes from DPP and DPPOS; 12% chose not to participate in DPPOS (plus missing data because of loss to followup in DPPOS). Characteristics differed between those who enrolled vs. not (e.g., higher in those who had developed DM, lower in women with history of GDM). Both groups offered DPP lifestyle intervention prior to DPPOS.
Aroda, 2016^239^ | No; B12 not measured at DPP baseline. After DPPOS year 1, anemia was only assessed in metformin group participants who were actively taking drug | For study period only, not open-label extension | For study period only, not open label extension | Unclear | Unclear | Excluded | No | Poor | Only DPP participants enrolled in DPPOS and had B12 measured during DPPOS were analyzed (missing 20-30% of those randomized); risk of measurement bias (no baseline B12 from DPP, and only those using metformin after DPPOS year 1 had B12 measure). Risk of contamination from use of acid medications; no assessment of whether participants used B12 oral supplements
Aroda, 2015^240^ | Yes | For study period only, not open-label extension | For study period only, not open-label extension | Unclear | Yes | LOCF (but limited to those who chose to participate in DPPOS and met post hoc subgroup analysis criteria) | No | Poor | Risk of selection bias; women w/GDM were younger than those with no GDM (by mean 8.5 years), and characteristics by treatment arm not described for analyzed sample. Potential for misclassification of GDM status due to no verification of diagnosis, and potential recall bias.
Griffin, 2011^241^; Simmons, 2012^242^; Van den Donk, 2013^243^; Simmons, 2016^76^; Griffin, 2019^244^; ADDITION-Europe | Yes | No | No | Yes | Unclear; 5 years likely not sufficient for some CVD outcomes | Varies by outcome; LOCF for most; others (QoL) excluded from analysis | Yes (modified ITT) | Fair | Risk of selection bias (fewer participants in routine care arm were taking antihypertensives, cholesterol medication, and aspirin at baseline. Risk of contamination due to other QI efforts and changes in guidelines for T2DM care. Five-year followup may not be sufficient for CVD outcomes.
Charles, 2011^245^; ADDITION-Denmark | Unclear; variation outcome measures and procedures varied across sites | No | No | Yes | Unclear; 6 years may not be sufficient for PAD and neuropathy outcomes | Excluded from analysis | No | Fair | Risk of selection bias; more patients with diabetes found in practices randomized to intensive treatment than control (training of staff may have affected participant selection). At baseline, fewer participants in routine-care arm were on medications that may affect outcomes (e.g., antihypertensives). Analysis is limited to participants who had had assessments for PAD and neuropathy (20% overall attrition). Testing for neuropathy differed across centers.
Van den Donk, 2010^95^; Janssen, 2009^117^; ADDITION-Netherlands | Yes | No | No | Yes | Yes for most outcomes; unclear for QoL at 1 yr | LOCF for 1 yr outcomes; participants with missing QoL measures at 3.5-4 yrs excluded | Yes (12 months); no for QoL at 3.5-4 yrs | Fair | Risk of selection bias; baseline practice characteristics differed, but participant characteristics were similar, and analyses adjusted for clustering. Potential contamination due to change in national guidelines for T2DM. High attrition at 3.5-4 years for QoL (28-50% missing data) and no ITT.
UKPDS, 1998^1^; UKPDS | Yes | No | No | Yes | Yes | LOCF | Yes | Good
Pan, 2003^246^ | Yes | Yes | Yes | Unclear | Unclear (conversion to type 2 DM); yes for others | Unclear | Yes (modified ITT) | Fair | Intervention group was younger than control group (53.4 vs. 55.6, p=0.034), other characteristics similar. Difference in age unlikely to be clinically important. Duration (4 months) may not be sufficient to assess conversion to type 2 DM.
Park, 2008^247^; ADDITION-Cambridge (pilot study) | Yes | Unclear | Unclear | Unclear | Yes | Completers only analysis | No | Fair | Completers analysis; masking and concealment unclear
Simmons, 2012^248^; ADDITION-Cambridge | Yes | No | No | Unclear | Yes | Unclear | Yes | Good
Simmons, 2011^249^; Rahman, 2012^250^; Ely | Yes | No | No | Unclear | Yes | Imputation | Yes | Fair
Davies, 2008^93^; Khunti, 2012^94^; DESMOND | Yes | Yes | No | No | Yes | Unclear | Yes | Fair
DeFronzo, 2011^251^; Espinoza, 2016^252^; Actos Now for Prevention of Diabetes Trial (ACT NOW) | Yes | Unclear | Unclear; likely yes | Unclear; likely yes | Yes | NA | No | Fair | Primary and secondary analyses were performed without data imputation since no statistically significance bias was found based on missing data; overall attrition high
DREAM Trial Investigators, 2006^253^; DREAM Trial Investigators, 2006^254^; DREAM Trial Investigators, 2008^255^; Diabetes Reduction Assessment with ramipril and rosiglitazone Medication (DREAM) Trial | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Good
Kawamori, 2009^256^ | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Good
Katula, 2013^144^; Pedley, 2018^257^; Healthy Living Partnership (HELP PD) | Yes | No | No | Yes | Yes | Unclear | Yes | Fair
Lindahl, 2009^137^ | Yes | No | No | Unclear | Yes | Imputation | Yes | Fair
Lindblad, 2011^258^; The Nepi ANtidiabetes StudY (NANSY) | Yes | Yes | Unclear | Unclear | Yes | Unclear, used ITT but noted when data were missing | Yes | Fair
Lu, 2011^259^ | Yes | No | No | Unclear | Yes | Unclear | Unclear | Fair
The NAVIGATOR Study Group, 2010^260^; The NAVIGATOR Study Group, 2010^261^; Currie, 2017^262^; Nateglinide and Valsartan in Impaired Glucose Tolerance Outcomes Research (NAVIGATOR) Trial | Yes | Yes | Unclear | Yes | Yes | Unclear | Yes | Good
Nijpels, 2008^263^; DAISI | Yes | Unclear | Yes | Yes | Yes | ITT and per-protocol, removed for per-protocol analysis | Yes | Fair
Penn, 2009^264^ | Yes | No | No | Yes | | | | Fair
Ramachandran, 2009^265^; IDPP-2 | Yes | Yes | Unclear | Yes | Yes | Unclear | Yes | Fair
Sakane, 2011^266^ | Yes | No | No | No | Yes | Unclear, used ITT | Yes | Fair
Saito, 2011^87^; ZPLS | Yes | No | No | No | Yes | Unclear, noted when it was missing | Yes | Fair
Zinman, 2010^267^; CAnadian Normoglycemia Outcomes Evaluation trial (CANOE) | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Good
Aekplakorn, 2019^268^ | Yes | No | NR | NR | Yes | ITT for diabetes incidence; NR for all other outcomes | ITT for diabetes incidence; NR for all other outcomes | Fair
Barengo, 2019^269^ | Yes | No | No | Yes | Yes | Per-protocol | No | Poor | High risk of bias due to very high overall attrition
Moungngern, 2018^270^ | Yes | No | No | Unclear | Yes | Excluded from analysis | No | Fair
Kramer, 2018^271^ | Yes | No | No | Yes | Yes | Excluded | No | Poor | In addition to no ITT analysis, participants could choose whether to receive the intervention face-to-face or by DVD and it is unclear what effect this may have had on contamination and outcomes.
Kulkarni, 2017^272^ | Yes | No | No | Unclear | Yes | Excluded | Yes | Fair
Wong, 2013^273^; Wong, 2018^274^ | Yes, they were valid and reliable; they were equal across groups, but not over time (ascertainment methods changed over time: electronic medical records were retrieved to obtain the diagnosis of event, anthropometric and blood measurements for those who had clinical reading and detailed events recorded within 1-year of assessment. For those recorded at the time beyond 1 year of assessment, the research team arranged health examinations to obtain anthropometric and blood measurements) | No | Unclear | No | Yes | Last value carried forward | Yes. Also had a per-protocol analysis | Fair

Abbreviations: A1c=glycated hemoglobin; ADDITION=Anglo-Dutch-Danish Study of Intensive Treatment in People with Screen Detected Diabetes in Primary Care; BMI=body mass index; BP=blood pressure; CANOE=CAnadian Normoglycemia Outcomes Evaluation trial; CDQDPOS=China Da Qing Diabetes Prevention Outcomes Study; CVD=cardiovascular disease; D-CLIP=Diabetes Community Lifestyle Improvement Program; DAISI=Dutch acarbose intervention study in persons with impaired glucose tolerance; DESMOND=Diabetes education and self management for ongoing and newly diagnosed programme; DM=diabetes mellitus; DPP=Diabetes Prevention Program; DPPOS=Diabetes Prevention Program; DREAM=Diabetes Reduction Assessment with ramipril and rosiglitazone Medication; ECG=electrocardiogram; EMR=electronic medical record; FDPS=Finnish Diabetes Prevention Study; GDM=gestational diabetes mellitus; HDL=high-density lipoproteins; hx=history; IDPP-2=Indian Diabetes Prevention Programme-2; ITT=intention-to-treat; KQ=key question; LDL=low-density lipoproteins; LOCF=last observation carried forward; LSM=lifestyle modification; MET=metformin; NA=not applicable; NANSY=The Nepi ANtidiabetes StudY; NAVIGATOR=Nateglinide and Valsartan in Impaired Glucose Tolerance Outcomes Research; NOCB=next observation carried backward; NR=not reported; PAD=peripheral arterial disease; PODOSA=The Prevention of Diabetes and Obesity in South Asians; QoL=quality of life; RAPID=Reaching Out to Prevent Increases in Diabetes; SCALE=Satiety and Clinical Adiposity–Liraglutide Evidence; STOP-NIDDM=Study TO Prevent Noninsulin-Dependent Diabetes Mellitus; T2DM=type 2 diabetes mellitus; ZPLS=Zensharen Study for Prevention of Lifestyle Diseases.

Appendix D Table 3 Quality Assessment of Controlled Trials: Additional Questions for Studies Reporting Harms (KQs 2 and 6 Only)

First Author, Year; Trial Name | Were harms prespecified and defined? | Were ascertainment techniques for harms adequately described? | Were ascertainment techniques for harms equal, valid, and reliable? | Was duration of followup adequate for harms assessment? | Quality Rating (for Harms) | Comments
Wu, 2015^204^ | Unclear | No | Unclear | Unclear | Poor | Duration of followup may not be adequate to assess long-term harms. No description of whether harms were prespecified or how they were ascertained.
Block, 2015^205^; Alive-PD | Unclear | Unclear | Unclear | Unclear | Poor | No description of whether harms were prespecified/defined or how they were ascertained; authors report harms do not differ by group but do not provide data on harms.
Kumar, 2014^208^ | Yes | Yes | Yes | Unclear | Fair | Some harms (hypoglycemia) appear to have been prespecified. Not clear whether others were prespecified or how they were defined
Wang, 2017^213^ | No | Yes | Yes | No | Poor | Study too small to adequately compare harms across the groups
Ackermann, 2015^139^; Reaching Out to Prevent Increases in Diabetes (RAPID) | No | Yes | Yes | Yes | Fair
Kaku, 2015^218^ | Yes | Yes | Yes | No | Fair
Weber, 2016^222^; Gokulakrishnan, 2017^223^; Diabetes Community Lifestyle Improvement Program (D-CLIP) | Unclear | No | Yes | Yes | Fair | Unclear whether harms prespecified or clearly defined. Authors describe planned ascertainment during followup visits.
le Roux, 2017^115^ SCALE Obesity and Prediabetes Trial | Yes | Yes | Unclear | Yes | Fair | High rate of attrition/withdrawal at 3 years (50% overall), although analysis accounted for missing data.
Eborall, 2007^230^; Paddison, 2011^231^; ADDITION-Cambridge | Yes | Yes | Yes | Yes | Fair | Nonrandomized substudy of ADDITION trial. Baseline characteristics were similar, but no baseline measures of psychological distress/anxiety were reported. Low response rate among screening group nonattenders; reasons for nonresponse in this group may be associated with outcome (worry about diabetes, distress associated with screening)
Ramachandran, 2006^234^ Indian Diabetes Prevention Programme | Unclear | No | Unclear | Yes | Fair | Harms (and ascertainment technique) not described in detail. Study notes that a safety committee monitored the adverse events.
Chiasson, 2002^235^; Chiasson, 2003^236^; STOP-NIDDM | Unclear | No | Unclear | Yes | Fair | No description of whether harms were prespecified or how they were ascertained. Safety committee member conducted interim analysis at 1 year to ascertain adverse effects.
Pan, 2003^246^ | Unclear | Yes | Yes | Unclear | Fair | Length of followup (4 months) may not be sufficient to detect all important adverse events.
Diabetes Prevention Program Research Group, 2002^80^; Diabetes Prevention Program Research Group, 2005^119^; Diabetes Prevention Program Research Group, 2012^97^; DPP | Yes | Unclear | Unclear | Yes | Fair | Protocol describes question for eliciting side effects but does not clearly state whether harms were prespecified.
Diabetes Prevention Program Research Group, 2012^237^; Diabetes Prevention Program Research Group, 2009^146^; Diabetes Prevention Program Research Group, 2015^79^; Apolzan, 2019^238^; Diabetes Prevention Program Research Group, 2019^81^; DPPOS | Yes | Yes | No | Yes | Fair | Analysis combines data from RCT and 7- to 8-year open-label phase; 12% chose not to participate in open-label extension. Unclear whether reasons for not participating are related to adverse effects.
Aroda, 2016^239^ | No | Yes | No | Unclear | Poor | Post hoc assessment of B12 deficiency from participants in DPP who continued in DPPOS and had a B12 measure. No baseline B12 at enrollment; outcome was not prespecified and measured equally across groups.
Van den Donk, 2010^95^; Janssen, 2009^117^; ADDITION-Netherlands | Unclear | Yes | Yes | Yes | Good
Park, 2008^247^; ADDITION-Cambridge (pilot study) | Yes | Yes | Yes | Yes | Fair
Davies, 2008^93^; Khunti, 2012^94^; DESMOND | Unclear | Unclear | Unclear | Unclear | Poor | No description of whether harms were prespecified/defined or how they were ascertained; only provides those who withdrew not specific to those who withdrew due to adverse events.
DeFronzo, 2011^251^; Espinoza, 2016^252^; Actos Now for Prevention of Diabetes Trial (ACT NOW) | Yes | Yes | Yes | Unclear | Fair
DREAM Trial Investigators, 2006^253^; DREAM Trial Investigators, 2006^254^; DREAM Trial Investigators, 2008^255^; Diabetes Reduction Assessment with ramipril and rosiglitazone Medication (DREAM) Trial | Unclear | Unclear | Unclear | Unclear | Good
Lu, 2011^259^ | Unclear | Unclear | Unclear | Unclear | Poor
The NAVIGATOR Study Group, 2010^260^; The NAVIGATOR Study Group, 2010^261^; Currie, 2017^262^; Nateglinide and Valsartan in Impaired Glucose Tolerance Outcomes Research (NAVIGATOR) Trial | Yes | Yes | Yes | Unclear | Good
Nijpels, 2008^263^; DAISI | Yes | Yes | Yes | Unclear | Fair
Ramachandran, 2009^265^; IDPP-2 | Unclear | Unclear | Unclear | Unclear | Fair
Saito, 2011^87^; ZPLS | Unclear | Unclear | Unclear | Unclear | Poor | No description of whether harms were prespecified/defined or how they were ascertained; authors report harms do not differ by group but do not provide data on harms.
Zinman, 2010^267^; CAnadian Normoglycemia Outcomes Evaluation trial (CANOE) | Yes | Yes | Yes | Unclear | Fair

Abbreviations: ACT NOW=Actos Now for Prevention of Diabetes; ADDITION=Anglo-Dutch-Danish Study of Intensive Treatment in People with Screen Detected Diabetes in Primary Care; CANOE=CAnadian Normoglycemia Outcomes Evaluation trial; D-CLIP=Diabetes Community Lifestyle Improvement Program; DESMOND=Diabetes education and self management for ongoing and newly diagnosed programme; DPP=Diabetes Prevention Program; DPPOS=Diabetes Prevention Program; DREAM=Diabetes Reduction Assessment with ramipril and rosiglitazone Medication; IDPP-2=Indian Diabetes Prevention Programme-2; KQ=key question; NAVIGATOR=Nateglinide and Valsartan in Impaired Glucose Tolerance Outcomes Research; RAPID=Reaching Out to Prevent Increases in Diabetes; RCT=randomized, controlled trial; SCALE=Satiety and Clinical Adiposity–Liraglutide Evidence; STOP-NIDDM=Study TO Prevent Noninsulin-Dependent Diabetes Mellitus.

Appendix D Table 4 Quality Assessment of Cohort Studies (KQs 2, 6, 8)

First Author, Year | Were eligibility criteria clearly described? | Were groups similar at baseline? | What was the reported adherence to the intervention? | Did the study have cross-overs or contamination raising concern for bias? | What was the overall attrition? Enter values for both loss to f/u and non-completers | What was the differential attrition? | Did the study have high differential attrition (>10% but think about how it might bias) or overall high attrition (depends on duration and outcome; generally 20%) raising concern for bias?
Lai, 2015^275^ | Yes | No | NR | Unclear | NR | NR | Unclear

Abbreviations: KQ=key question; NR=not reported.

Appendix D Table 5 Quality Assessment of Cohort Studies (KQs 2, 6, 8)

First Author, Year | Was assessment of the drug or other intervention exposure (dose and duration) valid and reliable? | Were outcome measurements equal, valid and reliable? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | What was the method used to handle missing data? | Did the analysis adjust for potential confounders? (or are confounders addressed via restriction, matching, or stratification) | Quality Rating | Comments
Lai, 2015^275^ | Yes | Yes | No | No | Unclear | Yes | Poor | Age imbalance at baseline. Drug users younger with higher diabetes complications severity index. They adjust for confounders, which results in no significant relationship between drug use and pancreatitis.; Lack of detail of loss to followup suggests that it was unmeasured.; 2008 to 2011 may be insufficient followup to pancreatitis.

For RCTs and cohorts, definition of ratings based on above criteria:

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.

Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.