# Appendix C Excluded Studies

## Appendix References

X1 Non-English
X2 Ineligible Population
X3 Ineligible Screening
X4 Ineligible Treatment
X5 Ineligible Comparison
X6 Ineligible Outcome
X7 Ineligible Setting
X8 Ineligible Study Design
X9 Ineligible Country
X10 Abstract Only
X11 Poor Quality
X12 Redundant Outcomes

1 A 6-year lifestyle intervention can prevent or delay diabetes for decades. Nature clinical practice endocrinology and metabolism. 2008;4(9):477-. doi: 10.1038/ncpendmet0911. PMID: CN-01729518. Exclusion Code: X8.
2 Adherence to predefined dietary patterns and incident type 2 diabetes in European populations: EPIC-InterAct Study. Diabetologia. 2014 Feb;57(2):321–33. doi: 10.1007/s00125-013-3092-9. PMID: 24196190. Exclusion Code: X8.24196190
3 Effect of a long-term behavioural weight loss intervention on nephropathy in overweight or obese adults with type 2 diabetes: a secondary analysis of the Look AHEAD randomised clinical trial. Lancet Diabetes Endocrinol. 2014 Oct;2(10):801–9. doi: 10.1016/s2213-8587(14)70156-1. PMID: 25127483. Exclusion Code: X2.25127483
4 Eight-year weight losses with an intensive lifestyle intervention: the look AHEAD study. Obesity (Silver Spring). 2014 Jan;22(1):5–13. doi: 10.1002/oby.20662. PMID: 24307184. Exclusion Code: X2.24307184
5 Restoring Insulin Secretion (RISE): design of studies of beta-cell preservation in prediabetes and early type 2 diabetes across the life span. Diabetes Care. 2014;37(3):780–8. doi: 10.2337/dc13-1879. PMID: 24194506. Exclusion Code: X6.24194506
6 Alogliptin/metformin (Vipdomet®) (Structured abstract). Health Technology Assessment Database. 2014(4)PMID: HTA-32014001454. Exclusion Code: X8.
7 Influence of baseline glycemia on outcomes with insulin glargine use in patients uncontrolled on oral agents. Postgraduate medicine. 126 (3) (pp 111-125), 2014. Date of publication: 01 jan 2014. 2014doi: 10.3810/pgm.2014.05.2761. PMID: CN-01265348. Exclusion Code: X8.
8 Effect of renal impairment on the pharmacokinetics, efficacy, and safety of albiglutide. Postgraduate medicine. 126 (3) (pp 35-46), 2014. Date of publication: 01 jan 2014. 2014doi: 10.3810/pgm.2014.05.2754. PMID: CN-01265349. Exclusion Code: X2.
9 Dietary fibre and incidence of type 2 diabetes in eight European countries: the EPIC-InterAct Study and a meta-analysis of prospective studies. Diabetologia. 2015 Jul;58(7):1394–408. doi: 10.1007/s00125-015-3585-9. PMID: 26021487. Exclusion Code: X8.26021487
10 Predictors of nonsevere and severe hypoglycemia during glucose-lowering treatment with insulin glargine or standard drugs in the ORIGIN trial. Diabetes Care. 2015 Jan;38(1):22–8. doi: 10.2337/dc14-1329. PMID: 25352653. Exclusion Code: X2.25352653
11 HbA1c as a predictor of diabetes and as an outcome in the diabetes prevention program: a randomized clinical trial. Diabetes Care. 2015 Jan;38(1):51–8. doi: 10.2337/dc14-0886. PMID: 25336746. Exclusion Code: X6.25336746
12 Insulin degludec/liraglutide (Xultophy®) (Structured abstract). Health Technology Assessment Database. 2015(4)PMID: HTA-32015001184. Exclusion Code: X8.
13 Metabolic effects of exercise training among fitness- nonresponsive patients with type 2 diabetes: the HART-D study. Diabetes care. 38 (8) (pp 1494-1501), 2015. Date of publication: august 2015. 2015doi: 10.2337/dc14-2378. PMID: CN-01265814. Exclusion Code: X2.
14 Persistent effects of intensive glycemic control on retinopathy in type 2 diabetes in the action to control cardiovascular risk in diabetes (ACCORD) follow-on study. Diabetes Care. 2016 Jul;39(7):1089–100. doi: 10.2337/dc16-0024. PMID: 27289122. Exclusion Code: X2.27289122
15 Cardiovascular and other outcomes postintervention with insulin glargine and omega-3 fatty acids (ORIGINALE). Diabetes Care. 2016 May;39(5):709–16. doi: 10.2337/dc15-1676. PMID: 26681720. Exclusion Code: X2.26681720
16 Prospective association of GLUL rs10911021 with cardiovascular morbidity and mortality among individuals with type 2 diabetes: The Look AHEAD Study. Diabetes. 2016 Jan;65(1):297–302. doi: 10.2337/db15-0890. PMID: 26395743. Exclusion Code: X6.26395743
17 Comparison of active treatments for impaired glucose regulation: a Salford Royal Foundation Trust and Hitachi collaboration (CATFISH): study protocol for a randomized controlled trial. Trials. 17 (1) (no pagination), 2016. Article number: 424. Date of publication: 26 aug 2016. 2016doi: 10.1186/s13063-016-1519-6. PMID: CN-01193394. Exclusion Code: X6.
18 Does exercise training impact clock genes in patients with coronary artery disease and type 2 diabetes mellitus? European journal of preventive cardiology. 23 (13) (pp 1375-1382), 2016. Date of publication: 01 sep 2016. 2016doi: 10.1177/2047487316639682. PMID: CN-01195924. Exclusion Code: X2.
19 Rosuvastatin dose-dependently improves flow-mediated dilation, but reduces adiponectin levels and insulin sensitivity in hypercholesterolemic patients. International journal of cardiology. 223 (pp 488-493), 2016. Date of publication: 15 nov 2016. 2016doi: 10.1016/j.ijcard.2016.08.051. PMID: CN-01194068. Exclusion Code: X2.
20 Effects of a long-term lifestyle modification programme on peripheral neuropathy in overweight or obese adults with type 2 diabetes: the Look AHEAD study. Diabetologia. 2017 Jun;60(6):980–8. doi: 10.1007/s00125-017-4253-z. PMID: 28349174. Exclusion Code: X2.28349174
21 Compare the efficacy and safety of dipeptidyl peptidase-4 inhibitors with other oral hypoglycemic agents in type 2 diabetes mellitus patients. International journal of pharmaceutical sciences and research. 2018;9(11):4963–7. doi: 10.13040/IJPSR.0975-8232.9%2811%29.4963-67. PMID: CN-01923031. Exclusion Code: X5.
22 Effects of a combination therapy with atorvastatin and metformin on the glycemic control and adiposity indices in newly diagnosed overweight patients with type 2 diabetes mellitus: a pilot study. Asian journal of pharmaceutical and clinical research. 2018;11(12):209–13. doi: 10.22159/ajpcr.2018.v11i12.28309. PMID: CN-01932324. Exclusion Code: X5.
23 Evaluation of fractures, bone mineral density (BMD), and bone biomarkers in patients with type 2 diabetes mellitus (T2DM) receiving ertugliflozin. Diabetes. 2018;Conference: 78th Scientific Sessions of the American Diabetes Association, ADA 2018. United States. 67(Supplement 1):A307. PMID: CN-01921432. Exclusion Code: X2.
24 Evaluation of osmotic diuresis and volume depletion events in patients with type 2 diabetes mellitus (T2DM) receiving ertugliflozin. Diabetes. 2018;Conference: 78th Scientific Sessions of the American Diabetes Association, ADA 2018. United States. 67(Supplement 1):A313. PMID: CN-01921472. Exclusion Code: X2.
25 The ENCOURAGE healthy families study: a comparative effectiveness trial to reduce risk for type 2 diabetes in mothers and children. Pediatr Diabetes. 2018;19(6):1041–9. doi: 10.1111/pedi.12692. PMID: CN-01921093. Exclusion Code: X5.
26 The effectiveness of text message support for weight loss to reduce diabetes risk. Diabetes. 2018;Conference: 78th Scientific Sessions of the American Diabetes Association, ADA 2018. United States. 67(Supplement 1):A343. PMID: CN-01921457. Exclusion Code: X10.
27 Response to Pioglitazone in Patients With Nonalcoholic Steatohepatitis With vs Without Type 2 Diabetes. Clin Gastroenterol Hepatol. 2018;16(4):558–66.e2. doi: 10.1016/j.cgh.2017.12.001. PMID: CN-01656871. Exclusion Code: X5.29223443
28 Age no impediment to effective weight loss with liraglutide 3.0 mg: data from two randomized trials. Italian journal of medicine. 2018;Conference: 23. Congresso Nazionale della Societa Scientifica FADOI. Italy. 12(2 Supplement 1):36. doi: 10.4081/itjm.2018.s2. PMID: CN-01628793. Exclusion Code: X8.
29 Impact of gastric banding versus metformin on B-cell function in adults with impaired glucose tolerance or mild type 2 diabetes. Diabetes care. 2018;41(12):2544–51. doi: 10.2337/dc18-1662. PMID: CN-01926015. Exclusion Code: X5.30282699
30 The rationale and design of the personal diet study, a randomized clinical trial evaluating a personalized approach to weight loss in individuals with pre-diabetes and early-stage type 2 diabetes. Contemp Clin Trials. 2019;79:80–8. doi: 10.1016/j.cct.2019.03.001. PMID: CN-01967052. Exclusion Code: X5.30844471
31 An Educational Intervention Using Steno Balance Cards to Improve Glycemic Control in Patients With Poorly Controlled Type 2 Diabetes Mellitus. Journal of nursing research. 2019;27(1):1–7. doi: 10.1097/jnr.0000000000000275. PMID: CN-01932641. Exclusion Code: X2.
32 Impact of pharmacist-directed counseling and message reminder services on medication adherence and clinical outcomes in type 2 diabetes mellitus. J Pharm Bioallied Sci. 2019;11(1):77–82. doi: 10.4103/JPBS.JPBS_211_18. PMID: CN-01926071. Exclusion Code: X2.30906143
33 Lack of Durable Improvements in β-Cell Function Following Withdrawal of Pharmacological Interventions in Adults With Impaired Glucose Tolerance or Recently Diagnosed Type 2 Diabetes. Diabetes care. 2019doi: 10.2337/dc19-0556. PMID: CN-01958655. Exclusion Code: X6.
34 Aaboe K, Akram S, Deacon CF, . Restoration of the insulinotropic effect of glucose-dependent insulinotropic polypeptide contributes to the antidiabetic effect of dipeptidyl peptidase-4 inhibitors. Diabetes Obes Metab. 2015 Jan;17(1):74–81. doi: 10.1111/dom.12395. PMID: 25243647. Exclusion Code: X6.25243647
35 Abbas AS, Dehbi HM, Ray KK. Cardiovascular and non-cardiovascular safety of dipeptidyl peptidase-4 inhibition: a meta-analysis of randomized controlled cardiovascular outcome trials. Diabetes Obes Metab. 2016 Mar;18(3):295–9. doi: 10.1111/dom.12595. PMID: 26510994. Exclusion Code: X8.26510994
36 Abbott KA, Veysey M, Lucock M, . Sex-dependent association between erythrocyte n-3 PUFA and type 2 diabetes in older overweight people. Br J Nutr. 2016 Apr;115(8):1379–86. doi: 10.1017/s0007114516000258. PMID: 26887798. Exclusion Code: X8.26887798
37 Abd E-KS, Al-Jiffri O, Al-Shreef F. Aerobic exercises alleviate symptoms of fatigue related to inflammatory cytokines in obese patients with type 2 diabetes. African historical studies. 2015;15(4):1142–8. doi: 10.4314/ahs.v15i4.13. PMID: CN-01198736. Exclusion Code: X2.
38 Abd El-Kader SM, Al-Jiffri OH. Impact of weight reduction on insulin resistance, adhesive molecules and adipokines dysregulation among obese type 2 diabetic patients. Afr Health Sci. 2018 Dec;18(4):873–83. doi: 10.4314/ahs.v18i4.5. PMID: 30766550. Exclusion Code: X6.30766550
39 Abdelmoneim AS, Eurich DT, Gamble JM, . Risk of acute coronary events associated with glyburide compared with gliclazide use in patients with type 2 diabetes: a nested case-control study. Diabetes Obes Metab. 2014 Jan;16(1):22–9. doi: 10.1111/dom.12173. PMID: 23802997. Exclusion Code: X2.23802997
40 Abdul-Ghani MA, Puckett C, Triplitt C, . Initial combination therapy with metformin, pioglitazone and exenatide is more effective than sequential add-on therapy in subjects with new-onset diabetes. Results from the Efficacy and Durability of Initial Combination Therapy for Type 2 Diabetes (EDICT): a randomized trial. Diabetes Obes Metab. 2015 Mar;17(3):268–75. doi: 10.1111/dom.12417. PMID: 25425451. Exclusion Code: X5.25425451
41 Abe M, Higuchi T, Moriuchi M, . Efficacy and safety of saxagliptin, a dipeptidyl peptidase-4 inhibitor, in hemodialysis patients with diabetic nephropathy: A randomized open-label prospective trial. Diabetes Res Clin Pract. 2016 Jun;116:244–52. doi: 10.1016/j.diabres.2016.04.034. PMID: 27321342. Exclusion Code: X2.27321342
42 Aberle J, Wehrhahn T, Van Gaal L, . Effects of treatment with liraglutide 3.0 mg in subjects with BMI < 35 and BMI ≥35 kg/m2: subgroup analysis of the SCALE Obesity and Prediabetes 56-week trial. Diabetologie und stoffwechsel. 2016;11doi: 10.1055/s-0036-1580948. PMID: CN-01753280. Exclusion Code: X10.
43 Abrahami D, Douros A, Yin H, . Dipeptidyl peptidase-4 inhibitors and incidence of inflammatory bowel disease among patients with type 2 diabetes: population based cohort study. Bmj. 2018 Mar 21;360:k872. doi: 10.1136/bmj.k872. PMID: 29563098. Exclusion Code: X2.29563098
44 Acar S, Malkoc M, Calan M, . The effect of multimodal exercise training program in subject with type 2 diabetes mellitus. Turkish journal of endocrinology and metabolism. 2014;18(3):67–74. doi: 10.4274/tjem.2576. PMID: CN-01037079. Exclusion Code: X6.
45 Ackermann RT, Finch EA, Schmidt KK, . Rationale, design, and baseline characteristics of a community-based comparative effectiveness trial to prevent type 2 diabetes in economically disadvantaged adults: the RAPID Study. Contemp Clin Trials. 2014 Jan;37(1):1–9. doi: 10.1016/j.cct.2013.10.003. PMID: 24177413. Exclusion Code: X6.24177413
46 Action to Control Cardiovascular Risk in Diabetes Study G, Gerstein HC, Miller ME, . Effects of intensive glucose lowering in type 2 diabetes. N Engl J Med. 2008 Jun 12;358(24):2545–59. doi: 10.1056/NEJMoa0802743. PMID: 18539917. Exclusion Code: X2.18539917
47 Actrn. Efficacy of health promotion interventions in adults with lifestyle and health risk factors for dementia. Http://www.anzctr.org.au/actrn12616000868482.aspx. 2016 PMID: CN-01308100. Exclusion Code: X2.
48 Adachi H, Katsuyama H, Yanai H. The low dose (7.5mg/day) pioglitazone is beneficial to the improvement in metabolic parameters without weight gain and an increase of risk for heart failure. Int J Cardiol. 2017 Jan 15;227:247–8. doi: 10.1016/j.ijcard.2016.11.126. PMID: 27838132. Exclusion Code: X8.27838132
49 Adachi M, Yamaoka K, Watanabe M, . Does the behavioural type-specific approach for type 2 diabetes promote changes in lifestyle? Protocol of a cluster randomised trial in Japan. BMJ Open. 2017 Oct 24;7(10):e017838. doi: 10.1136/bmjopen-2017-017838. PMID: 29070640. Exclusion Code: X6.29070640
50 Adam L, O’Connor C, Garcia A. Evaluating the impact of diabetes self-management education methods on knowledge, attitudes and behaviours of adult patients with type 2 diabetes mellitus. Canadian journal of diabetes. 2018;(no pagination)doi: 10.1016/j.jcjd.2017.11.003. PMID: CN-01460056. Exclusion Code: X5.
51 Adams SP, Alaeiilkhchi N, Wright JM. Pitavastatin for lowering lipids. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
52 Adams SP, Sekhon SS, Tsang M, . Fluvastatin for lowering lipids. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2018. Exclusion Code: X8.
53 Adams SP, Sekhon SS, Wright JM. Rosuvastatin for lowering lipids. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
54 Adams SP, Tiellet N, Wright JM. Cerivastatin for lowering lipids. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
55 Adams SP, Tsang M, Wright JM. Atorvastatin for lowering lipids. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
56 Addy C, Tatosian D, Glasgow XS, . Pharmacokinetic and pharmacodynamic effects of multiple-dose administration of omarigliptin, a once-weekly dipeptidyl peptidase-4 inhibitor, in obese participants with and without type 2 diabetes mellitus. Clin Ther. 2016 Mar;38(3):516–30. doi: 10.1016/j.clinthera.2015.12.020. PMID: 26869191. Exclusion Code: X2.26869191
57 Addy C, Tatosian DA, Glasgow XS, . Effects of age, sex, and obesity on the single-dose pharmacokinetics of omarigliptin in healthy subjects. Clin Pharmacol Drug Dev. 2016 Sep;5(5):374–82. doi: 10.1002/cpdd.255. PMID: 27627193. Exclusion Code: X2.27627193
58 Ae YS, Han B, Kim S, . Efficacy and safety of gemigliptin in type 2 diabetes patients with moderate to severe renal impairment. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A314–a5. doi: 10.2337/db16-861-1374. PMID: CN-01449946. Exclusion Code: X2.
59 Agarwal G, Angeles RN, Dolovich L, . The Community Health Assessment Program in the Philippines (CHAP-P) diabetes health promotion program for low- to middle-income countries: study protocol for a cluster randomized controlled trial. BMC Public Health. 2019 Jun 3;19(1):682. doi: 10.1186/s12889-019-6974-z. PMID: 31159778. Exclusion Code: X2.31159778
60 Agboola S, Jethwani K, Lopez L, . Text to move: A randomized controlled trial of a text-messaging program to improve physical activity behaviors in patients with type 2 diabetes mellitus. J Med Internet Res. 2016 Nov 18;18(11):e307. doi: 10.2196/jmir.6439. PMID: 27864165. Exclusion Code: X6.27864165
61 Aguiar EJ, Morgan PJ, Collins CE, . The PULSE (Prevention Using LifeStyle Education) trial protocol: a randomised controlled trial of a type 2 diabetes prevention programme for men. Contemp Clin Trials. 2014 Sep;39(1):132–44. doi: 10.1016/j.cct.2014.07.008. PMID: 25092484. Exclusion Code: X6.25092484
62 Aguiar EJ, Morgan PJ, Collins CE, . Efficacy of the type 2 diabetes prevention using lifestyle education program RCT. Am J Prev Med. 2016 Mar;50(3):353–64. doi: 10.1016/j.amepre.2015.08.020. PMID: 26526160. Exclusion Code: X2.26526160
63 Agyemang C, Beune E, Meeks K, . Rationale and cross-sectional study design of the research on obesity and type 2 diabetes among African migrants: the RODAM study. BMJ Open. 2014 Mar 21;4(3):e004877. doi: 10.1136/bmjopen-2014-004877. PMID: 24657884. Exclusion Code: X8.24657884
64 Aharaz A, Pottegard A, Henriksen DP, . Risk of lactic acidosis in type 2 diabetes patients using metformin: A case control study. PLoS One. 2018;13(5):e0196122. doi: 10.1371/journal.pone.0196122. PMID: 29738540. Exclusion Code: X2.29738540
65 Ahmad J, Zubair M, Malik N, . Glycemic and non-glycemic targets in younger and older North Indian subjects with type 2 diabetes in a tertiary care hospital: A 10 year’s retrospective data analysis. Diabetes Metab Syndr. 2016 Jan-Mar;10(1 Suppl 1):S130–4. doi: 10.1016/j.dsx.2015.10.010. PMID: 26564028. Exclusion Code: X8.26564028
66 Ahmad MA, Kapur P, Khanam R, . Comparative effect of antihypertensive therapy on blood glucose level in hypertensive patients in an Indian population. Drug Res (Stuttg). 2014 May;64(5):276–80. doi: 10.1055/s-0033-1357202. PMID: 24132701. Exclusion Code: X5.24132701
67 Ahmadi Z, Sadeghi T, Loripoor M. The outcomes of peer-led diabetes education in comparison to education delivered by health professionals in Iranian patients. Health Educ Res. 2018 Feb 1;33(1):64–72. doi: 10.1093/her/cyx068. PMID: 29088414. Exclusion Code: X6.29088414
68 Ahmann A, Rodbard HW, Rosenstock J, . Efficacy and safety of liraglutide versus placebo added to basal insulin analogues (with or without metformin) in patients with type 2 diabetes: a randomized, placebo-controlled trial. Diabetes Obes Metab. 2015 Nov;17(11):1056–64. doi: 10.1111/dom.12539. PMID: 26179619. Exclusion Code: X2.26179619
69 Ahmed MA, Muntingh G, Rheeder P. Vitamin B12 deficiency in metformin-treated type-2 diabetes patients, prevalence and association with peripheral neuropathy. BMC Pharmacol Toxicol. 2016 Oct 7;17(1):44. doi: 10.1186/s40360-016-0088-3. PMID: 27716423. Exclusion Code: X8.27716423
70 Ahmed RH, Huri HZ, Al-Hamodi Z, . Serum levels of soluble CD26/dipeptidyl peptidase-IV in type 2 diabetes mellitus and its association with metabolic syndrome and therapy with antidiabetic agents in Malaysian subjects. PLoS One. 2015;10(10):e0140618. doi: 10.1371/journal.pone.0140618. PMID: 26474470. Exclusion Code: X8.26474470
71 Ahn CH, Han KA, Yu JM, . Efficacy and safety of gemigliptin, a dipeptidyl peptidase-4 inhibitor, in patients with type 2 diabetes mellitus inadequately controlled with combination treatment of metformin and sulphonylurea: a 24-week, multicentre, randomized, double-blind, placebo-controlled study (TROICA study). Diabetes Obes Metab. 2017 May;19(5):635–43. doi: 10.1111/dom.12866. PMID: 28026912. Exclusion Code: X2.28026912
72 Ahn CH, Kim EK, Min SH, . Effects of gemigliptin, a dipeptidyl peptidase-4 inhibitor, on lipid metabolism and endotoxemia after a high-fat meal in patients with type 2 diabetes. Diabetes Obes Metab. 2017 Mar;19(3):457–62. doi: 10.1111/dom.12831. PMID: 27868366. Exclusion Code: X2.27868366
73 Ahn S, Lee J, Bartlett-Prescott J, . Evaluation of a Behavioral Intervention With Multiple Components Among Low-Income and Uninsured Adults With Obesity and Diabetes. Am J Health Promot. 2018 Feb;32(2):409–22. doi: 10.1177/0890117117696250. PMID: 28279084. Exclusion Code: X8.28279084
74 Ahren B, Atkin SL, Charpentier G, . Semaglutide induces weight loss in subjects with type 2 diabetes regardless of baseline BMI or gastrointestinal adverse events in the SUSTAIN 1 to 5 trials. Diabetes Obes Metab. 2018 Sep;20(9):2210–9. doi: 10.1111/dom.13353. PMID: 29766634. Exclusion Code: X2.29766634
75 Ahren B, Carr MC, Murphy K, . Albiglutide for the treatment of type 2 diabetes mellitus: an integrated safety analysis of the HARMONY phase 3 trials. Diabetes Res Clin Pract. 2017 Apr;126:230–9. doi: 10.1016/j.diabres.2017.02.017. PMID: 28284167. Exclusion Code: X8.28284167
76 Ahren B, Galstyan G, Gautier J-F, . Postprandial glucagon reductions correlate to reductions in postprandial glucose and glycated hemoglobin with lixisenatide treatment in type 2 diabetes mellitus: A post hoc analysis. Diabetes therapy. 2016;7(3):583–90. doi: 10.1007/s13300-016-0179-6. PMID: CN-01210587. Exclusion Code: X2.27319011
77 Ahren B, Johnson SL, Stewart M, . HARMONY 3: 104-week randomized, double-blind, placebo- and active-controlled trial assessing the efficacy and safety of albiglutide compared with placebo, sitagliptin, and glimepiride in patients with type 2 diabetes taking metformin. Diabetes Care. 2014 Aug;37(8):2141–8. doi: 10.2337/dc14-0024. PMID: 24898304. Exclusion Code: X2.24898304
78 Ahsan S, Ahmed S, Ahmed SD, . Status of serum adiponectin related to insulin resistance in prediabetics. J Pak Med Assoc. 2014 Feb;64(2):184–8. PMID: 24640810. Exclusion Code: X8.24640810
79 Ahsan S, Ahmed SD, Jamali SN, . Frequency and risk of metabolic syndrome in prediabetics versus normal glucose tolerant subjects -- a comparative study. J Pak Med Assoc. 2015 May;65(5):496–500. PMID: 26028383. Exclusion Code: X8.26028383
80 Airhart S, Cade W, Jiang H, . A diet rich in medium-chain fatty acids improves systolic function and alters the lipidomic profile in patients with type 2 diabetes: A pilot study. Journal of clinical endocrinology and metabolism. 2016;101(2):504–12. doi: 10.1210/jc.2015-3292. PMID: CN-01137618. Exclusion Code: X6.26652763
81 Ajdi F, Khabbal Y, Safi S. ADR of oral antidiabetic. Drug Saf. 2009;32(10):949–50. doi: 10.2165/11316660-000000000-00000. PMID: CN-01760775. Exclusion Code: X8.
82 Akerblom A, Oldgren J, Latva-Rasku A, . Effects of DAPAgliflozin on CARDiac substrate uptake, myocardial efficiency, and myocardial contractile work in type 2 diabetes patients-a description of the DAPACARD study. Ups J Med Sci. 2019;124(1):59–64. doi: 10.1080/03009734.2018.1515281. PMID: CN-01915581. Exclusion Code: X6.30618324
83 Akilen R, Pimlott Z, Tsiami A, . Effect of short-term administration of cinnamon on blood pressure in patients with prediabetes and type 2 diabetes (Provisional abstract). Nutrition. 2013;29(10):1192–6. PMID: DARE-12013042187. Exclusion Code: X8.23867208
84 Akturan S, Kaya CA, Unalan PC, . The effect of the BATHE interview technique on the empowerment of diabetic patients in primary care: a cluster randomised controlled study. Prim Care Diabetes. 2017 Apr;11(2):154–61. doi: 10.1016/j.pcd.2016.12.003. PMID: 28122690. Exclusion Code: X6.28122690
85 Al HA, Abu-Raghif A, Al GM. Effects of metformin alone and in combination with sitagliptin on oxidative stress and proinflammatory markers in patients with diabetes mellitus type-2. International journal of pharmaceutical sciences review and research. 2017;42(1):185–90. PMID: CN-01330293. Exclusion Code: X6.
86 Al Tunaiji H, Davis JC, Mackey DC, . Population attributable fraction of type 2 diabetes due to physical inactivity in adults: a systematic review. BMC Public Health. 2014 May 18;14:469. doi: 10.1186/1471-2458-14-469. PMID: 24885278. Exclusion Code: X8.24885278
87 Alanzi T, Bah S, Alzahrani S, . Evaluation of a mobile social networking application for improving diabetes Type 2 knowledge: an intervention study using WhatsApp. J Comp Eff Res. 2018 Sep;7(9):891–9. doi: 10.2217/cer-2018-0028. PMID: 29943647. Exclusion Code: X6.29943647
88 Albert Perez E, Mateu Olivares V, Martinez-Espinosa RM, . New Insights about How to Make an Intervention in Children and Adolescents with Metabolic Syndrome: Diet, Exercise vs. Changes in Body Composition. A Systematic Review of RCT. Nutrients. 2018 Jul 6;10(7)doi: 10.3390/nu10070878. PMID: 29986479. Exclusion Code: X8.29986479
89 Aldekhail NM, Logue J, McLoone P, . Effect of orlistat on glycaemic control in overweight and obese patients with type 2 diabetes mellitus: a systematic review and meta-analysis of randomized controlled trials. Obes Rev. 2015 Dec;16(12):1071–80. doi: 10.1111/obr.12318. PMID: 26345590. Exclusion Code: X8.26345590
90 Alemayehu B, Liu J, Rajpathak S, . Healthcare resource use and associated costs of hypoglycemia in patients with type 2 diabetes prescribed sulfonylureas. J Diabetes Complications. 2017 Nov;31(11):1620–3. doi: 10.1016/j.jdiacomp.2017.07.012. PMID: 28844830. Exclusion Code: X8.28844830
91 Alemi H, Khaloo P, Mansournia MA, . Pulse pressure and diabetes treatments: blood pressure and pulse pressure difference among glucose lowering modality groups in type 2 diabetes. Medicine (Baltimore). 2018 Feb;97(6):e9791. doi: 10.1097/md.0000000000009791. PMID: 29419672. Exclusion Code: X8.29419672
92 Alfawaz H, Wani K, Alnaami A, . Effects of different dietary and lifestyle modification therapies on metabolic syndrome in prediabetic Arab patients: a 12-month longitudinal study. Nutrients. 2018;10(3) (no pagination)doi: 10.3390/nu10030383. PMID: CN-01464865. Exclusion Code: X11.
93 Alfredsson J, Green JB, Stevens SR, . Sex differences in management and outcomes of patients with type 2 diabetes and cardiovascular disease: A report from TECOS. Diabetes Obes Metab. 2018 Oct;20(10):2379–88. doi: 10.1111/dom.13377. PMID: 29923323. Exclusion Code: X2.29923323
94 Alghafri TS, Alharthi SM, Al-Farsi YM, . Study protocol for “MOVEdiabetes”: a trial to promote physical activity for adults with type 2 diabetes in primary health care in Oman. BMC Public Health. 2017 Jan 6;17(1):28. doi: 10.1186/s12889-016-3990-0. PMID: 28056933. Exclusion Code: X6.28056933
95 Alhalel N, Schueller S, O’Brien M. Association of changes in mental health with weight loss during intensive lifestyle intervention: does the timing matter? Obesity science and practice. 2018;(no pagination)doi: 10.1002/osp4.157. PMID: CN-01464110. Exclusion Code: X5.
96 Ali M, Echouffo-Tcheugui J, Williamson D. How effective were lifestyle interventions in real-world settings that were modeled on the Diabetes Prevention Program? (Structured abstract). Health Affairs; 2012. p. 67–75. Exclusion Code: X8.
97 Ali Z, Daniyal M, S II, . Evaluation, efficacy and tolerability of GlucoNovax tablet in type 2 diabetic patients. Pak J Pharm Sci. 2016 Jul;29(4 Suppl):1443–9. PMID: 27592478. Exclusion Code: X5.27592478
98 Al-Khudairy L, Loveman E, Colquitt JL, . Diet, physical activity and behavioural interventions for the treatment of overweight or obese adolescents aged 12 to 17 years. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
99 Al-Mallah M, Khawaja O, Sinno M, . Do angiotensin converting enzyme inhibitors or angiotensin receptor blockers prevent diabetes mellitus? A meta-analysis (Structured abstract). Cardiol J; 2010. p. 448–56. Exclusion Code: X8.
100 Almeida F, Pardo K, Seidel R, . Design and methods of “diaBEAT-it!”: a hybrid preference/randomized control trial design using the RE-AIM framework. Contemp Clin Trials. 2014;38(2):383–96. doi: 10.1016/j.cct.2014.06.010. PMID: CN-00994992. Exclusion Code: X6.24956325
101 Alonso A, Bahnson JL, Gaussoin SA, . Effect of an intensive lifestyle intervention on atrial fibrillation risk in individuals with type 2 diabetes: the Look AHEAD randomized trial. Am Heart J. 2015 Oct;170(4):770–7.e5. doi: 10.1016/j.ahj.2015.07.026. PMID: 26386801. Exclusion Code: X6.26386801
102 Alonso-Dominguez R, Garcia-Ortiz L, Patino-Alonso MC, . Effectiveness of A Multifactorial Intervention in Increasing Adherence to the Mediterranean Diet among Patients with Diabetes Mellitus Type 2: A Controlled and Randomized Study (EMID Study). Nutrients. 2019 Jan 14;11(1)doi: 10.3390/nu11010162. PMID: 30646500. Exclusion Code: X2.30646500
103 Alonso-Dominguez R, Gomez-Marcos MA, Patino-Alonso MC, . Effectiveness of a multifactorial intervention based on an application for smartphones, heart-healthy walks and a nutritional workshop in patients with type 2 diabetes mellitus in primary care (EMID): study protocol for a randomised controlled trial. BMJ Open. 2017 Sep 14;7(9):e016191. doi: 10.1136/bmjopen-2017-016191. PMID: 28912193. Exclusion Code: X6.28912193
104 Alonso-Dominguez R, Patino-Alonso MC, Sanchez-Aguadero N, . Effect of a multifactorial intervention on the increase in physical activity in subjects with type 2 diabetes mellitus: a randomized clinical trial (EMID Study). Eur J Cardiovasc Nurs. 2019doi: 10.1177/1474515119835048. PMID: CN-01915610. Exclusion Code: X6.
105 Alothman S, Yahya A, Rucker J, . Effectiveness of interventions for promoting objectively measured physical activity of adults with type 2 diabetes: A systematic review. J Phys Act Health. 2017 May;14(5):408–15. doi: 10.1123/jpah.2016-0528. PMID: 28169570. Exclusion Code: X8.28169570
106 Al-Ozairi E, Ridge K, Taghadom E, . Diabetes and TelecommunicationS (DATES) study to support self-management for people with type 2 diabetes: a randomized controlled trial. BMC Public Health. 2018 Nov 12;18(1):1249. doi: 10.1186/s12889-018-6136-8. PMID: 30419893. Exclusion Code: X6.30419893
107 Alqudah A, McKinley MC, McNally R, . Risk of pre-eclampsia in women taking metformin: a systematic review and meta-analysis. Diabet Med. 2018 Feb;35(2):160–72. doi: 10.1111/dme.13523. PMID: 29044702. Exclusion Code: X8.29044702
108 Al-Shreef F, Al-Jiffri O, Abd E-KS. Bone metabolism and hand grip strength response to aerobic versus resistance exercise training in non-insulin dependent diabetic patients. African historical studies. 2015;15(3):896–901. doi: 10.4314/ahs.v15i3.25. PMID: CN-01264189. Exclusion Code: X6.
109 Alvarez C, Ramirez-Campillo R, Lucia A, . Concurrent exercise training on hyperglycemia and comorbidities associated: non-responders using clinical cutoff points. Scandinavian journal of medicine & science in sports. 2019doi: 10.1111/sms.13413. PMID: CN-01936585. Exclusion Code: X6.
110 Alvarez C, Ramirez-Campillo R, Martinez-Salazar C, . Low-volume high-intensity interval training as a therapy for type 2 diabetes. Int J Sports Med. 2016 Aug;37(9):723–9. doi: 10.1055/s-0042-104935. PMID: 27259099. Exclusion Code: X2.27259099
111 Álvarez-Pérez J, Sánchez-Villegas A, Díaz-Benítez E, . Influence of a Mediterranean dietary pattern on body fat distribution: results of the PREDIMED-Canarias intervention randomized trial. J Am Coll Nutr. 2016;35(6):568–80. doi: 10.1080/07315724.2015.1102102. PMID: CN-01307309. Exclusion Code: X6.27314172
112 Ambery P, Parker VE, Stumvoll M, . MEDI0382, a GLP-1 and glucagon receptor dual agonist, in obese or overweight patients with type 2 diabetes: a randomised, controlled, double-blind, ascending dose and phase 2a study. Lancet. 2018 Jun 30;391(10140):2607–18. doi: 10.1016/s0140-6736(18)30726-8. PMID: 29945727. Exclusion Code: X2.29945727
113 Ambery P, Stylianou A, Atkinson G, . Open-label randomized non-inferiority trial of a fixed-dose combination of glimepiride and atorvastatin for the treatment of people whose Type 2 diabetes is uncontrolled on metformin. Diabet Med. 2016 Aug;33(8):1084–93. doi: 10.1111/dme.13003. PMID: 26484794. Exclusion Code: X5.26484794
114 Amblee A, Lious D, Fogelfeld L. Combination of saxagliptin and metformin is effective as initial therapy in new-onset type 2 diabetes mellitus with severe hyperglycemia. J Clin Endocrinol Metab. 2016 Jun;101(6):2528–35. doi: 10.1210/jc.2015-4097. PMID: 27144930. Exclusion Code: X5.27144930
115 Amendezo E, Walker Timothy D, Karamuka V, . Effects of a lifestyle education program on glycemic control among patients with diabetes at Kigali University Hospital, Rwanda: A randomized controlled trial. Diabetes Res Clin Pract. 2017 Apr;126:129–37. doi: 10.1016/j.diabres.2017.02.001. PMID: 28237859. Exclusion Code: X6.28237859
116 Amin NB, Aggarwal N, Pall D, . Two dose-ranging studies with PF-04937319, a systemic partial activator of glucokinase, as add-on therapy to metformin in adults with type 2 diabetes. Diabetes Obes Metab. 2015 Aug;17(8):751–9. doi: 10.1111/dom.12474. PMID: 25885172. Exclusion Code: X2.25885172
117 Amirehsani KA, Hu J, Wallace DC, . Hispanic Families’ Action Plans for a Healthier Lifestyle for Diabetes Management. Diabetes Educ. 2019 Feb;45(1):87–95. doi: 10.1177/0145721718812478. PMID: 30466357. Exclusion Code: X8.30466357
118 Amosova MV, Gurova OY, Fadeev VV. Predictors of glucose-lowering response to treatment with glucagonlike peptide-1 receptor agonists in patients with diabetes and obesity. Diabetologia. 2018;61:S361-. doi: 10.1007/s00125-018-4693-0. PMID: CN-01647035. Exclusion Code: X2.
119 An R. Diabetes diagnosis and nutrition facts label use among US adults, 2005-2010. Public Health Nutr. 2016 Aug;19(12):2149–56. doi: 10.1017/s1368980015003079. PMID: 26483168. Exclusion Code: X6.26483168
120 An Y, Zhang P, Wang J, . Differences in efficacy of diet and/or exercise interventions in preventing diabetes in normal and overweight/obese people with IGT: results from the 20-year follow-up of daqing diabetes prevention study. Diabetes. 2017;66:A420-. PMID: CN-01771874. Exclusion Code: X10.
121 Andersen ES, Lund A, Bagger JI, . Is glucagon-like peptide-1 fully protected by the dipeptidyl peptidase 4 inhibitor sitagliptin when administered to patients with type 2 diabetes? Diabetes Obes Metab. 2018 Aug;20(8):1937–43. doi: 10.1111/dom.13321. PMID: 29654643. Exclusion Code: X2.29654643
122 Anderson LM, Adeney KL, Shinn C, . Community coalition-driven interventions to reduce health disparities among racial and ethnic minority populations. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
123 Anderson RT, Narayan KM, Feeney P, . Effect of intensive glycemic lowering on health-related quality of life in type 2 diabetes: ACCORD trial. Diabetes Care. 2011 Apr;34(4):807–12. doi: 10.2337/dc10-1926. PMID: 21346183. Exclusion Code: X2.21346183
124 Anderson SG, Hutchings DC, Woodward M, . Phosphodiesterase type-5 inhibitor use in type 2 diabetes is associated with a reduction in all-cause mortality. Heart. 2016 Nov 1;102(21):1750–6. doi: 10.1136/heartjnl-2015-309223. PMID: 27465053. Exclusion Code: X4.27465053
125 Andreadis P, Karagiannis T, Malandris K, . Semaglutide for type 2 diabetes mellitus: A systematic review and meta-analysis. Diabetes Obes Metab. 2018 Sep;20(9):2255–63. doi: 10.1111/dom.13361. PMID: 29756388. Exclusion Code: X8.29756388
126 Andrews RC, Cooper AR, Montgomery AA, . Diet or diet plus physical activity versus usual care in patients with newly diagnosed type 2 diabetes: the Early ACTID randomised controlled trial. Lancet. 2011 Jul 9;378(9786):129–39. doi: 10.1016/S0140-6736(11)60442-X. PMID: 21705068. Exclusion Code: X6.21705068
127 Anholm C, Kumarathurai P, Pedersen LR, . Liraglutide effects on beta-cell, insulin sensitivity and glucose effectiveness in patients with stable coronary artery disease and newly diagnosed type 2 diabetes. Diabetes Obes Metab. 2017 Jun;19(6):850–7. doi: 10.1111/dom.12891. PMID: 28124822. Exclusion Code: X2.28124822
128 Antithrombotic Trialists C. Collaborative meta-analysis of randomised trials of antiplatelet therapy for prevention of death, myocardial infarction, and stroke in high risk patients. BMJ. 2002 Jan 12;324(7329):71–86. PMID: 11786451. Exclusion Code: X8.11786451
129 Anyanwagu U, Mamza J, Donnelly R, . Effects of background statin therapy on glycemic response and cardiovascular events following initiation of insulin therapy in type 2 diabetes: a large UK cohort study. Cardiovasc Diabetol. 2017 Aug 22;16(1):107. doi: 10.1186/s12933-017-0587-6. PMID: 28830436. Exclusion Code: X8.28830436
130 Anzaldo-Campos MC, Contreras S, Vargas-Ojeda A, . Dulce wireless Tijuana: A randomized control trial evaluating the impact of Project Dulce and short-term mobile technology on glycemic control in a family medicine clinic in Northern Mexico. Diabetes Technol Ther. 2016 Apr;18(4):240–51. doi: 10.1089/dia.2015.0283. PMID: 26914371. Exclusion Code: X2.26914371
131 Aponte J, Jackson TD, Wyka K, . Health effectiveness of community health workers as a diabetes self-management intervention. Diab Vasc Dis Res. 2017 Jul;14(4):316–26. doi: 10.1177/1479164117696229. PMID: 28330385. Exclusion Code: X6.28330385
132 Apovian C, Palmer K, Fain R, . Effects of lorcaserin on fat and lean mass loss in obese and overweight patients without and with type 2 diabetes mellitus: the BLOSSOM and BLOOM-DM studies. Diabetes, obesity & metabolism. 2016;18(9):945–8. doi: 10.1111/dom.12690. PMID: CN-01266203. Exclusion Code: X2.
133 Apovian CM. Naltrexone/bupropion for the treatment of obesity and obesity with Type 2 diabetes. Future Cardiol. 2016 Mar;12(2):129–38. doi: 10.2217/fca.15.79. PMID: 26679384. Exclusion Code: X8.26679384
134 Araki A, Iimuro S, Sakurai T, . Long-term multiple risk factor interventions in Japanese elderly diabetic patients: the Japanese Elderly Diabetes Intervention Trial--study design, baseline characteristics and effects of intervention. Geriatr Gerontol Int. 2012 Apr;12 Suppl 1:7–17. doi: 10.1111/j.1447-0594.2011.00808.x. PMID: 22435936. Exclusion Code: X2.22435936
135 Araki E, Inagaki N, Tanizawa Y, . Efficacy and safety of once-weekly dulaglutide in combination with sulphonylurea and/or biguanide compared with once-daily insulin glargine in Japanese patients with type 2 diabetes: a randomized, open-label, phase III, non-inferiority study. Diabetes Obes Metab. 2015 Oct;17(10):994–1002. doi: 10.1111/dom.12540. PMID: 26179754. Exclusion Code: X5.26179754
136 Araki E, Tanizawa Y, Tanaka Y, . Long-term treatment with empagliflozin as add-on to oral antidiabetes therapy in Japanese patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2015 Jul;17(7):665–74. doi: 10.1111/dom.12464. PMID: 25772548. Exclusion Code: X2.25772548
137 Araki E, Yamashita S, Arai H, . Effects of K-877, a novel selective PPARalpha modulator (SPPARMalpha), on lipid and glucose metabolism in fasting and postprandial states in type 2 diabetic patients with dyslipidaemia. Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S531. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212854. Exclusion Code: X6.
138 Arambepola C, Ricci-Cabello I, Manikavasagam P, . The impact of automated brief messages promoting lifestyle changes delivered via mobile devices to people with type 2 diabetes: A systematic literature review and meta-analysis of controlled trials. J Med Internet Res. 2016 Apr 19;18(4):e86. doi: 10.2196/jmir.5425. PMID: 27095386. Exclusion Code: X8.27095386
139 Ard J, Cannon A, Lewis CE, . Efficacy and safety of liraglutide 3.0 mg for weight management are similar across races: subgroup analysis across the SCALE and phase II randomized trials. Diabetes Obes Metab. 2016 Apr;18(4):430–5. doi: 10.1111/dom.12632. PMID: 26744025. Exclusion Code: X8.26744025
140 Ardigo D, Vaccaro O, Cavalot F, . Effectiveness of treat-to-target strategy for LDL-cholesterol control in type 2 diabetes: post-hoc analysis of data from the MIND.IT study. Eur J Prev Cardiol. 2014 Apr;21(4):456–63. doi: 10.1177/2047487312467746. PMID: 23147277. Exclusion Code: X5.23147277
141 Aregbesola A, de Mello VDF, Lindstrom J, . Serum adiponectin/Ferritin ratio in relation to the risk of type 2 diabetes and insulin sensitivity. Diabetes Res Clin Pract. 2018;141:264–74. doi: 10.1016/j.diabres.2018.05.012. PMID: CN-01610774. Exclusion Code: X5.29777745
142 Arens JH, Hauth W, Weissmann J. Novel App- and Web-Supported Diabetes Prevention Program to Promote Weight Reduction, Physical Activity, and a Healthier Lifestyle: Observation of the Clinical Application. J Diabetes Sci Technol. 2018 Jul;12(4):831–8. doi: 10.1177/1932296818768621. PMID: 29584454. Exclusion Code: X8.29584454
143 Areosa SA, Vernooij RW, González-Colaço HM, . Effect of the treatment of Type 2 diabetes mellitus on the development of cognitive impairment and dementia. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
144 Ariel D, Kim SH, Abbasi F, . Effect of liraglutide administration and a calorie-restricted diet on lipoprotein profile in overweight/obese persons with prediabetes. Nutr Metab Cardiovasc Dis. 2014 Dec;24(12):1317–22. doi: 10.1016/j.numecd.2014.06.010. PMID: 25280957. Exclusion Code: X6.25280957
145 Arima R, Hautakoski A, Marttila M, . Cause-specific mortality in endometrioid endometrial cancer patients with type 2 diabetes using metformin or other types of antidiabetic medication. Gynecol Oncol. 2017 Dec;147(3):678–83. doi: 10.1016/j.ygyno.2017.10.014. PMID: 29054569. Exclusion Code: X2.29054569
146 Arima R, Marttila M, Hautakoski A, . Antidiabetic medication, statins and the risk of endometrioid endometrial cancer in patients with type 2 diabetes. Gynecol Oncol. 2017 Sep;146(3):636–41. doi: 10.1016/j.ygyno.2017.06.011. PMID: 28645427. Exclusion Code: X8.28645427
147 Arima R, Marttila M, Hautakoski A, . Antidiabetic Medication, Statins and the Risk and Prognosis of Non-endometrioid Endometrial Cancer in Women with Type 2 Diabetes. Anticancer Res. 2018 Jul;38(7):4169–78. doi: 10.21873/anticanres.12710. PMID: 29970546. Exclusion Code: X8.29970546
148 Arling V, Huth F, Slavchova V, . Supporting Patients with Diabetes mellitus type 2 and Obesity in Transfer of Medically Indicated Lifestyle Changes into Everyday Life by a Planning Competence Training in a Randomized Controlled Trial. Die Rehabilitation. 2019doi: 10.1055/a-0891-3505. PMID: CN-01956563. Exclusion Code: X1.
149 Armato J, DeFronzo RA, Abdul-Ghani M, . Successful treatment of prediabetes in clinical practice: targeting insulin resistance and beta-cell dysfunction. Endocr Pract. 2012 May-Jun;18(3):342–50. doi: 10.4158/EP11194.OR. PMID: 22068250. Exclusion Code: X8.22068250
150 Arnetz L, Hage C, Brismar K, . Copeptin, insulin-like growth factor binding protein-1 and sitagliptin: a report from the BEta-cell function in Glucose abnormalities and Acute Myocardial Infarction study. Diab Vasc Dis Res. 2016 Jul;13(4):307–11. doi: 10.1177/1479164116635997. PMID: 27190088. Exclusion Code: X2.27190088
151 Aroda VR, Bailey TS, Cariou B, . Effect of adding insulin degludec to treatment in patients with type 2 diabetes inadequately controlled with metformin and liraglutide: a double-blind randomized controlled trial (BEGIN: ADD TO GLP-1 Study). Diabetes Obes Metab. 2016 Jul;18(7):663–70. doi: 10.1111/dom.12661. PMID: 26990378. Exclusion Code: X2.26990378
152 Aroda VR, Christophi CA, Edelstein SL, . The effect of lifestyle intervention and metformin on preventing or delaying diabetes among women with and without gestational diabetes: the Diabetes Prevention Program outcomes study 10-year follow-up. J Clin Endocrinol Metab. 2015 Apr;100(4):1646–53. doi: 10.1210/jc.2014-3761. PMID: 25706240. Exclusion Code: X11.25706240
153 Aroda VR, Edelstein SL, Goldberg RB, . Long-term metformin use and vitamin B12 deficiency in the Diabetes Prevention Program Outcomes Study. J Clin Endocrinol Metab. 2016 Apr;101(4):1754–61. doi: 10.1210/jc.2015-3754. PMID: 26900641. Exclusion Code: X11.26900641
154 Aronne L, Shanahan W, Fain R, . Safety and efficacy of lorcaserin: a combined analysis of the BLOOM and BLOSSOM trials. Postgrad Med. 2014 Oct;126(6):7–18. doi: 10.3810/pgm.2014.10.2817. PMID: 25414931. Exclusion Code: X2.25414931
155 Aronson R, Frias J, Goldman A, . Long-term efficacy and safety of ertugliflozin monotherapy in patients with inadequately controlled T2DM despite diet and exercise: VERTIS MONO extension study. Diabetes Obes Metab. 2018 Jun;20(6):1453–60. doi: 10.1111/dom.13251. PMID: 29419917. Exclusion Code: X2.29419917
156 Arora S, Peters A, Burner E, . Trial to examine text message-based mHealth in emergency department patients with diabetes (TExT-MED): a randomized controlled trial. Annals of emergency medicine. 2014;63(6):745–54.e6. doi: 10.1016/j.annemergmed.2013.10.012. PMID: CN-01120365. Exclusion Code: X7.24225332
157 Aschner P, Sethi B, Gomez-Peralta F, . Insulin glargine compared with premixed insulin for management of insulin-naive type 2 diabetes patients uncontrolled on oral antidiabetic drugs: the open-label, randomized GALAPAGOS study. J Diabetes Complications. 2015 Aug;29(6):838–45. doi: 10.1016/j.jdiacomp.2015.04.003. PMID: 25981123. Exclusion Code: X5.25981123
158 Aso Y, Jojima T, Iijima T, . Sitagliptin, a dipeptidyl peptidase-4 inhibitor, increases the number of circulating CD34(+)CXCR4(+) cells in patients with type 2 diabetes. Endocrine. 2015 Dec;50(3):659–64. doi: 10.1007/s12020-015-0688-5. PMID: 26209038. Exclusion Code: X5.26209038
159 Astrup A, Fujioka K, Violante OR, . Efficacy and safety of liraglutide 3.0 Mg in adult overweight and obese weight loss responders without diabetes: results of the 56-week randomised, controlled, scale obesity and prediabetes trial. Obesity facts. 2015;8:42. doi: 10.1159/000382140. PMID: CN-01100860. Exclusion Code: X10.
160 Astrup A, Greenway F, Krempf M, . Weight loss and improvements in cardiometabolic risk factors with liraglutide 3.0 mg: the SCALE obesity and prediabetes randomized, double-blind, placebo-controlled 3-year trial. Obesity reviews. Conference: 13th international congress on obesity, ICO 2016. Vancouver, BC canada. 2016;17(Suppl 2):71. doi: 10.1111/obr.12401. PMID: CN-01659381. Exclusion Code: X10.
161 Astrup A, Greenway F, Krempf M, . Weight loss and associated improvements in cardiometabolic risk factors with liraglutide 3.0 mg in the SCALE Obesity and Prediabetes randomised, double-blind, placebo-controlled 3-year trial. Obesity facts. Conference: european obesity summit (EOS): 1st joint congress of EASO and IFSO-EC. Gothenburg sweden. Conference start: 20160601. Conference end: 20160604. Conference publication: (var.pagings). 2016;9:182. doi: 10.1159/000446744. PMID: CN-01266566. Exclusion Code: X10.
162 Astrup A, Hjorth MF, Ritz C, . Pretreatment fasting plasma glucose and insulin as determinants of weight loss success: the new nordic diet study. Diabetes. 2017;66:A205-. PMID: CN-01772035. Exclusion Code: X2.
163 Astrup A, Rice Bradley BH, Brenna JT, . Regular-fat dairy and human health: A synopsis of symposia presented in Europe and North America (2014-2015). Nutrients. 2016 Jul 29;8(8)doi: 10.3390/nu8080463. PMID: 27483308. Exclusion Code: X8.27483308
164 Atkins ER, Hirakawa Y, Salam A, . Side effects and tolerability of combination blood pressure lowering according to blood pressure levels: an analysis of the PROGRESS and ADVANCE trials. J Hypertens. 2017 Jun;35(6):1318–25. doi: 10.1097/hjh.0000000000001287. PMID: 28169881. Exclusion Code: X8.28169881
165 Attridge M, Creamer J, Ramsden M, . Culturally appropriate health education for people in ethnic minority groups with type 2 diabetes mellitus. Cochrane Database Syst Rev. 2014 Sep 4(9):Cd006424. doi: 10.1002/14651858.CD006424.pub3. PMID: 2518821025188210. Exclusion Code: X8.
166 Aulinger BA, Bedorf A, Kutscherauer G, . Defining the role of GLP-1 in the enteroinsulinar axis in type 2 diabetes using DPP-4 inhibition and GLP-1 receptor blockade. Diabetes. 2014 Mar;63(3):1079–92. doi: 10.2337/db13-1455. PMID: 24296715. Exclusion Code: X4.24296715
167 Avenell A, Mak JC, O’Connell D. Vitamin D and vitamin D analogues for preventing fractures in post-menopausal women and older men. Cochrane Database of Systematic Reviews. 2014(4)doi: 10.1002/14651858.CD000227.pub4. PMID: CD000227. Exclusion Code: X8.
168 Avery L, Charman SJ, Taylor L, . Systematic development of a theory-informed multifaceted behavioural intervention to increase physical activity of adults with type 2 diabetes in routine primary care: Movement as Medicine for Type 2 Diabetes. Implement Sci. 2016 Jul 19;11:99. doi: 10.1186/s13012-016-0459-6. PMID: 27430648. Exclusion Code: X8.27430648
169 Avery L, Flynn D, Dombrowski SU, . Successful behavioural strategies to increase physical activity and improve glucose control in adults with Type 2 diabetes. Diabet Med. 2015 Aug;32(8):1058–62. doi: 10.1111/dme.12738. PMID: 25764343. Exclusion Code: X8.25764343
170 Avery L, Sniehotta F, Denton S, . Movement as medicine for type 2 diabetes: protocol for an open pilot study and external pilot clustered randomised controlled trial to assess acceptability, feasibility and fidelity of a multifaceted behavioural intervention targeting physical activity in primary care. Trials. 2014;15:46. doi: 10.1186/1745-6215-15-46. PMID: CN-01037963. Exclusion Code: X6.24491134
171 Awodele O, Osuolale JA. Medication adherence in type 2 diabetes patients: study of patients in Alimosho General Hospital, Igando, Lagos, Nigeria. Afr Health Sci. 2015 Jun;15(2):513–22. doi: 10.4314/ahs.v15i2.26. PMID: 26124798. Exclusion Code: X8.26124798
172 Ayers D, Kanters S, Goldgrub R, . Network meta-analysis of liraglutide versus dipeptidyl peptidase-4 inhibitors for the treatment of type 2 diabetes in Japanese patients. Curr Med Res Opin. 2017 Sep;33(9):1653–61. doi: 10.1080/03007995.2017.1345730. PMID: 28635331. Exclusion Code: X8.28635331
173 Azami G, Soh KL, Sazlina SG, . Effect of a Nurse-Led Diabetes Self-Management Education Program on Glycosylated Hemoglobin among Adults with Type 2 Diabetes. J Diabetes Res. 2018;2018:4930157. doi: 10.1155/2018/4930157. PMID: 30225268. Exclusion Code: X2.30225268
174 Azar K, Koliwad S, Poon T, . Electronic cardiometabolic program (ECMP): a randomized controlled trial. Diabetes. 2015;64:A226. . PMID: CN-01086614. Exclusion Code: X10.
175 Azar KM, Chung S, Wang EJ, . Impact of education on weight in newly diagnosed type 2 diabetes: Every little bit helps. PLoS One. 2015;10(6):e0129348. doi: 10.1371/journal.pone.0129348. PMID: 26052698. Exclusion Code: X8.26052698
176 Azar KM, Koliwad S, Poon T, . The Electronic CardioMetabolic Program (eCMP) for patients with cardiometabolic risk: A randomized controlled trial. J Med Internet Res. 2016 May 27;18(5):e134. doi: 10.2196/jmir.5143. PMID: 27234480. Exclusion Code: X2.27234480
177 Aziz Z, Mathews E, Absetz P, . A group-based lifestyle intervention for diabetes prevention in low- and middle-income country: implementation evaluation of the Kerala Diabetes Prevention Program. Implement Sci. 2018 Jul 18;13(1):97. doi: 10.1186/s13012-018-0791-0. PMID: 30021592. Exclusion Code: X6.30021592
178 Azoulay L, Filion KB, Platt RW, . Association between incretin-based drugs and the risk of acute pancreatitis. JAMA Intern Med. 2016 Oct 1;176(10):1464–73. doi: 10.1001/jamainternmed.2016.1522. PMID: 27479930. Exclusion Code: X5.27479930
179 Azoulay L, Filion KB, Platt RW, . Incretin based drugs and the risk of pancreatic cancer: international multicentre cohort study. Bmj. 2016 Feb 17;352:i581. doi: 10.1136/bmj.i581. PMID: 26888382. Exclusion Code: X5.26888382
180 Ba J, Han P, Yuan G, . Randomized trial assessing the safety and efficacy of sitagliptin in Chinese patients with type 2 diabetes mellitus inadequately controlled on sulfonylurea alone or combined with metformin. J Diabetes. 2017 Jul;9(7):667–76. doi: 10.1111/1753-0407.12456. PMID: 27502307. Exclusion Code: X2.27502307
181 Badeau RM, Honka MJ, Lautamaki R, . Systemic metabolic markers and myocardial glucose uptake in type 2 diabetic and coronary artery disease patients treated for 16 weeks with rosiglitazone, a PPARgamma agonist. Ann Med. 2014 Feb;46(1):18–23. doi: 10.3109/07853890.2013.853369. PMID: 24266715. Exclusion Code: X2.24266715
182 Bae J, Min K, Kim Y, . Efficacy and safety of fixed-dose combination therapy of gemigliptin/ rosuvastatin compared to each mono therapy in type 2 diabetes patients with dyslipidaemia: BALANCE study. Diabetologia. Conference: 53rd annual meeting of the european association for the study of diabetes, EASD 2017. Portugal. 2017;60(1 Supplement 1):S366–s7. doi: 10.1007/s00125-017-4350-z. PMID: CN-01418944. Exclusion Code: X2.
183 Baek JH, Jin SM, Kaku K, . Efficacy of mitiglinide and sitagliptin, alone or in combination, on postprandial excursion and glycemic variability assessed by continuous glucose monitoring: a post hoc analysis with single-day treatment. Expert Opin Pharmacother. 2015 Jun;16(8):1127–36. doi: 10.1517/14656566.2015.1035646. PMID: 25881690. Exclusion Code: X5.25881690
184 Bagnasco A, Di Giacomo P, Da Rin Della Mora R, . Factors influencing self-management in patients with type 2 diabetes: a quantitative systematic review protocol. J Adv Nurs. 2014 Jan;70(1):187–200. doi: 10.1111/jan.12178. PMID: 23763567. Exclusion Code: X8.23763567
185 Bailey CJ, Morales Villegas EC, Woo V, . Efficacy and safety of dapagliflozin monotherapy in people with Type 2 diabetes: a randomized double-blind placebo-controlled 102-week trial. Diabet Med. 2015 Apr;32(4):531–41. doi: 10.1111/dme.12624. PMID: 25381876. Exclusion Code: X2.25381876
186 Bailey KJ, Little JP, Jung ME. Self-monitoring using continuous glucose monitors with real-time feedback improves exercise adherence in individuals with impaired blood glucose: A pilot study. Diabetes Technol Ther. 2016 Mar;18(3):185–93. doi: 10.1089/dia.2015.0285. PMID: 26885934. Exclusion Code: X2.26885934
187 Bailey RA, Vijapurkar U, Meininger G, . Diabetes-related composite quality end point attainment: Canagliflozin versus sitagliptin based on a pooled analysis of 2 clinical trials. Clin Ther. 2015 May 1;37(5):1045–54. doi: 10.1016/j.clinthera.2015.02.020. PMID: 25795432. Exclusion Code: X8.25795432
188 Bain S, O’Neil P, Fujioka K, . Efficacy and safety of liraglutide 3.0 mg in adult overweight and obese weight loss responders without diabetes: results of the randomised, double-blind, placebocontrolled 56 week SCALE Obesity and Prediabetes trial. Diabetic medicine. Conference: diabetes UK professional conference 2016. Glasgow united kingdom. 2016;33(Suppl 1):64. doi: 10.1111/dme.17_13048. PMID: CN-01471025. Exclusion Code: X10.
189 Bainbridge V, Ahren B, Jones-Leone A, . Effects of mild to moderate renal impairment on albiglutide (ALBI) in type 2 diabetes. Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S359. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212893. Exclusion Code: X8.
190 Bajaj H, Venn K, Ye C, . Randomized trial of long-acting insulin glargine titration web tool (LTHome) versus enhanced usual therapy of glargine titration (INNOVATE Trial). Diabetes Technol Ther. 2016;18(10):610–5. doi: 10.1089/dia.2016.0182. PMID: CN-01424770. Exclusion Code: X2.27652718
191 Bajpeyi S, Pasarica M, Conley KE, . Pioglitazone-induced improvements in insulin sensitivity occur without concomitant changes in muscle mitochondrial function. Metabolism. 2017 Apr;69:24–32. doi: 10.1016/j.metabol.2016.11.016. PMID: 28285649. Exclusion Code: X6.28285649
192 Baker L, Hansen A, Cholerton B, . Effects of aerobic exercise on cognition and biomarkers in adults with a double-hit risk for dementia: mild cognitive impairment and prediabetes. Alzheimer’s and dementia. 2014;10:P125. PMID: CN-01056791. Exclusion Code: X10.
193 Baker L, Skinner J, Craft S, . Aerobic exercise reduces phosphorylated tau protein in cerebrospinal fluid in older adults with mild cognitive impairment. Alzheimer’s and dementia. 2015;11(7 suppl. 1):P324. PMID: CN-01163343. Exclusion Code: X6.
194 Baker PR, Francis DP, Soares J, . Community wide interventions for increasing physical activity. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
195 Baksi A, Kraydashenko O, Zalevkaya A, . A phase II, randomized, placebo-controlled, double-blind, multi-dose study of SRT2104, a SIRT1 activator, in subjects with type 2 diabetes. Br J Clin Pharmacol. 2014 Jul;78(1):69–77. doi: 10.1111/bcp.12327. PMID: 24446723. Exclusion Code: X2.24446723
196 Balducci S, D’Errico V, Haxhi J, . Effect of a Behavioral Intervention Strategy on Sustained Change in Physical Activity and Sedentary Behavior in Patients With Type 2 Diabetes: The IDES_2 Randomized Clinical Trial. Jama. 2019 Mar 5;321(9):880–90. doi: 10.1001/jama.2019.0922. PMID: 30835309. Exclusion Code: X2.30835309
197 Balducci S, D’Errico V, Haxhi J, . Effect of a behavioral intervention strategy for adoption and maintenance of a physically active lifestyle: The Italian Diabetes and Exercise Study 2 (IDES_2): a randomized controlled trial. Diabetes Care. 2017 Nov;40(11):1444–52. doi: 10.2337/dc17-0594. PMID: 28821576. Exclusion Code: X2.28821576
198 Balducci S, Sacchetti M, Haxhi J, . The Italian Diabetes and Exercise Study 2 (IDES-2): a long-term behavioral intervention for adoption and maintenance of a physically active lifestyle. Trials. 2015;16(1) (no pagination)doi: 10.1186/s13063-015-1088-0. PMID: CN-01128421. Exclusion Code: X2.
199 Balducci S, Vulpiani M, Pugliese L, . Effect of supervised exercise training on musculoskeletal symptoms and function in patients with type 2 diabetes: the Italian Diabetes Exercise Study (IDES). Acta Diabetol. 2014;51(4):647–54. doi: 10.1007/s00592-014-0571-5. PMID: CN-01002868. Exclusion Code: X2.24566991
200 Baltzis D, Dushay JR, Loader J, . Effect of linagliptin on vascular function: A randomized, placebo-controlled study. J Clin Endocrinol Metab. 2016 Nov;101(11):4205–13. doi: 10.1210/jc.2016-2655. PMID: 27583476. Exclusion Code: X2.27583476
201 Bangalore S, Kumar S, Lobach I, . Blood pressure targets in subjects with type 2 diabetes mellitus/impaired fasting glucose: observations from traditional and bayesian random-effects meta-analyses of randomized trials. Circulation. 2011 Jun 21;123(24):2799–810, 9 p following 810. doi: 10.1161/CIRCULATIONAHA.110.016337. PMID: 21632497. Exclusion Code: X8.21632497
202 Bansal D, Gudala K, Undela K. Statins for preventing colorectal adenoma and carcinoma. Cochrane Database of Systematic Reviews. 2014(5)doi: 10.1002/14651858.CD011137. PMID: CD011137. Exclusion Code: X8.
203 Baptista LC, Dias G, Souza NR, . Effects of long-term multicomponent exercise on health-related quality of life in older adults with type 2 diabetes: evidence from a cohort study. Qual Life Res. 2017 Aug;26(8):2117–27. doi: 10.1007/s11136-017-1543-3. PMID: 28303367. Exclusion Code: X4.28303367
204 Baptista LC, Machado-Rodrigues AM, Martins RA. Exercise but not metformin improves health-related quality of life and mood states in older adults with type 2 diabetes. Eur J Sport Sci. 2017 Jul;17(6):794–804. doi: 10.1080/17461391.2017.1310933. PMID: 28394739. Exclusion Code: X5.28394739
205 Bar D, Lavie O, Stein N, . The effect of metabolic comorbidities and commonly used drugs on the prognosis of patients with ovarian cancer. Eur J Obstet Gynecol Reprod Biol. 2016 Dec;207:227–31. doi: 10.1016/j.ejogrb.2016.09.005. PMID: 27890326. Exclusion Code: X2.27890326
206 Baranov O, Kahle M, Deacon CF, . Feedback suppression of meal-induced glucagon-like peptide-1 (GLP-1) secretion mediated through elevations in intact GLP-1 caused by dipeptidyl peptidase-4 inhibition: a randomized, prospective comparison of sitagliptin and vildagliptin treatment. Diabetes Obes Metab. 2016 Nov;18(11):1100–9. doi: 10.1111/dom.12706. PMID: 27300579. Exclusion Code: X2.27300579
207 Barber S, Davies M, Khunti K, . Risk assessment tools for detecting those with pre-diabetes: a systematic review (Provisional abstract). Database of Abstracts of Reviews of Effects; 2014. p. 1–13. Exclusion Code: X8.
208 Bardini G, Giannini S, Rotella CM, . Lower and higher-potency statins on glycemic control in type 2 diabetes: A retrospective cohort study. Diabetes Res Clin Pract. 2016 Oct;120:104–10. doi: 10.1016/j.diabres.2016.07.015. PMID: 27525366. Exclusion Code: X8.27525366
209 Barengo NC, Acosta T, Arrieta A, . Early lifestyle interventions in people with impaired glucose tolerance in northern Colombia: the DEMOJUAN project. Int J Environ Res Public Health. 2019;16(8)doi: 10.3390/ijerph16081403. PMID: CN-01936821. Exclusion Code: X11.
210 Barkas F, Elisaf M, Liberopoulos E, . Statin therapy with or without ezetimibe and the progression to diabetes. J Clin Lipidol. 2016 Mar-Apr;10(2):306–13. doi: 10.1016/j.jacl.2015.11.015. PMID: 27055961. Exclusion Code: X8.27055961
211 Barr P, Patel B. Evaluation of new onset diabetes in pre-diabetic patients taking statin medication. Value in health. Conference: ISPOR 22nd annual international meeting. United states. 2017;20(5):A176. PMID: CN-01407834. Exclusion Code: X8.
212 Barr P, Patel B. Assessment of new onset diabetes and statin medication utilization. Value in health. Conference: ISPOR 22nd annual international meeting. United states. 2017;20(5):A176. PMID: CN-01407837. Exclusion Code: X8.
213 Barrera M, Jr., Toobert DJ, Strycker LA. Relative contributions of naturalistic and constructed support: two studies of women with type 2 diabetes. J Behav Med. 2014 Feb;37(1):59–69. doi: 10.1007/s10865-012-9465-6. PMID: 23109138. Exclusion Code: X4.23109138
214 Bartlett DB, Slentz CA, Connelly MA, . Association of the composite inflammatory biomarker GlycA, with exercise-induced changes in body habitus in men and women with prediabetes. Oxid Med Cell Longev. 2017;2017:5608287. doi: 10.1155/2017/5608287. PMID: 28642810. Exclusion Code: X5.28642810
215 Basak Cinar A, Schou L. Health promotion for patients with diabetes: health coaching or formal health education? Int Dent J. 2014 Feb;64(1):20–8. doi: 10.1111/idj.12058. PMID: 24117102. Exclusion Code: X4.24117102
216 Bateman M, McCarthy C, Simmons D, . Evaluation of patient health questionnaire (PHQ-9) score and hemoglobin A1C (Hba1C) in patients with type 2 diabetes mellitus. Journal of pharmacy practice. Conference: 19th annual meeting of the college of psychiatric and neurologic pharmacists, CPNP. United states. 2016;29(3):305. doi: 10.1177/0897190016645328. PMID: CN-01362011. Exclusion Code: X6.
217 Bauman V, Ariel-Donges AH, Gordon EL, . Effect of dose of behavioral weight loss treatment on glycemic control in adults with prediabetes. BMJ open diabetes research and care. 2019;7(1)doi: 10.1136/bmjdrc-2019-000653. PMID: CN-01956865. Exclusion Code: X5.
218 Bays H, Pi-Sunyer X, Hemmingsson JU, . Liraglutide 3.0 mg for weight management: weight-loss dependent and independent effects. Curr Med Res Opin. 2017 Feb;33(2):225–9. doi: 10.1080/03007995.2016.1251892. PMID: 27817208. Exclusion Code: X8.27817208
219 Bays HE, Brinton EA, Triscari J, . Extended-release niacin/laropiprant significantly improves lipid levels in type 2 diabetes mellitus irrespective of baseline glycemic control. Vasc Health Risk Manag. 2015;11:165–72. doi: 10.2147/vhrm.s70907. PMID: 25750540. Exclusion Code: X6.25750540
220 Beaudoin N, Bouvet G, Coriati A, . Combined exercise training improves glycemic control in adult with cystic fibrosis. Med Sci Sports Exerc. 2017;49(2):231–7. doi: 10.1249/MSS.0000000000001104. PMID: CN-01199954. Exclusion Code: X2.27669451
221 Beavers KM, Case LD, Blackwell CS, . Effects of weight regain following intentional weight loss on glucoregulatory function in overweight and obese adults with pre-diabetes. Obes Res Clin Pract. 2015 May-Jun;9(3):266–73. doi: 10.1016/j.orcp.2014.09.003. PMID: 25293586. Exclusion Code: X6.25293586
222 Becker RH, Stechl J, Msihid J, . Lixisenatide resensitizes the insulin-secretory response to intravenous glucose challenge in people with type 2 diabetes--a study in both people with type 2 diabetes and healthy subjects. Diabetes Obes Metab. 2014 Sep;16(9):793–800. doi: 10.1111/dom.12278. PMID: 24521245. Exclusion Code: X6.24521245
223 Becker RH, Stechl J, Steinstraesser A, . Lixisenatide reduces postprandial hyperglycaemia via gastrostatic and insulinotropic effects. Diabetes Metab Res Rev. 2015 Sep;31(6):610–8. doi: 10.1002/dmrr.2647. PMID: 25773712. Exclusion Code: X2.25773712
224 Becquemont L, Bauduceau B, Benattar-Zibi L, . Association between cardiovascular drugs and chronic kidney disease in non-institutionalized elderly patients. Basic Clin Pharmacol Toxicol. 2015 Aug;117(2):137–43. doi: 10.1111/bcpt.12376. PMID: 25594245. Exclusion Code: X2.25594245
225 Belalcazar LM, Anderson AM, Lang W, . Fiber intake and plasminogen activator inhibitor-1 in type 2 diabetes: Look AHEAD (Action for Health in Diabetes) trial findings at baseline and year 1. J Acad Nutr Diet. 2014 Nov;114(11):1800–10.e2. doi: 10.1016/j.jand.2014.06.357. PMID: 25131348. Exclusion Code: X6.25131348
226 Belalcazar LM, Lang W, Haffner SM, . Improving adiponectin levels in individuals with diabetes and obesity: insights from look AHEAD. Diabetes Care. 2015 Aug;38(8):1544–50. doi: 10.2337/dc14-2775. PMID: 25972574. Exclusion Code: X6.25972574
227 Belalcazar LM, Papandonatos GD, Erar B, . Lifestyle intervention for weight loss and cardiometabolic changes in the setting of glucokinase regulatory protein inhibition: glucokinase regulatory Protein-Leu446Pro variant in Look AHEAD. Circ Cardiovasc Genet. 2016 Feb;9(1):71–8. doi: 10.1161/circgenetics.115.001192. PMID: 26578543. Exclusion Code: X4.26578543
228 Belalcazar LM, Papandonatos GD, McCaffery JM, . A common variant in the CLDN7/ELP5 locus predicts adiponectin change with lifestyle intervention and improved fitness in obese individuals with diabetes. Physiol Genomics. 2015 Jun;47(6):215–24. doi: 10.1152/physiolgenomics.00109.2014. PMID: 25759378. Exclusion Code: X6.25759378
229 Bell S, Farran B, McGurnaghan S, . Risk of acute kidney injury and survival in patients treated with metformin: an observational cohort study. BMC Nephrol. 2017 May 19;18(1):163. doi: 10.1186/s12882-017-0579-5. PMID: 28526011. Exclusion Code: X8.28526011
230 Bellavere F, Cacciatori V, Bacchi E, . Effects of aerobic or resistance exercise training on cardiovascular autonomic function of subjects with type 2 diabetes: a pilot study. Nutrition, metabolism, and cardiovascular diseases : NMCD. 2018;28(3):226–33. doi: 10.1016/j.numecd.2017.12.008. PMID: CN-01460663. Exclusion Code: X2.
231 Bentley C, Otesile O, Bacigalupo R, . Feasibility study of portable technology for weight loss and HbA1c control in type 2 diabetes. BMC Med Inform Decis Mak. 2016;16:92. doi: 10.1186/s12911-016-0331-2. PMID: CN-01414064. Exclusion Code: X6.27418275
232 Bentley-Lewis R, Aguilar D, Riddle MC, . Rationale, design, and baseline characteristics in evaluation of LIXisenatide in Acute Coronary Syndrome, a long-term cardiovascular end point trial of lixisenatide versus placebo. Am Heart J. 2015 May;169(5):631–8.e7. doi: 10.1016/j.ahj.2015.02.002. PMID: 25965710. Exclusion Code: X6.25965710
233 Benzaquen M, Borradori L, Berbis P, . Dipeptidyl peptidase IV inhibitors, a risk factor for bullous pemphigoid: Retrospective multicenter case-control study from France and Switzerland. J Am Acad Dermatol. 2018 Jun;78(6):1090–6. doi: 10.1016/j.jaad.2017.12.038. PMID: 29274348. Exclusion Code: X2.29274348
234 Bergman A, Tan B, Somayaji VR, . A 4-week study assessing the pharmacokinetics, pharmacodynamics, safety, and tolerability of the glucagon receptor antagonist PF-06291874 administered as monotherapy in subjects with type 2 diabetes mellitus. Diabetes Res Clin Pract. 2017 Apr;126:95–104. doi: 10.1016/j.diabres.2017.01.019. PMID: 28237861. Exclusion Code: X2.28237861
235 Bergman M, Chetrit A, Roth J, . One-hour post-load plasma glucose level during the OGTT predicts dysglycemia: observations from the 24year follow-up of the Israel Study of Glucose Intolerance, Obesity and Hypertension. Diabetes Res Clin Pract. 2016 Oct;120:221–8. doi: 10.1016/j.diabres.2016.08.013. PMID: 27596059. Exclusion Code: X4.27596059
236 Bergman M, Manco M, Sesti G, . Petition to replace current OGTT criteria for diagnosing prediabetes with the 1-hour post-load plasma glucose>/=155mg/dl (8.6mmol/L). Diabetes Res Clin Pract. 2018 Dec;146:18–33. doi: 10.1016/j.diabres.2018.09.017. PMID: 30273707. Exclusion Code: X8.30273707
237 Bergmark BA, Bhatt DL, Braunwald E, . Risk Assessment in Patients With Diabetes With the TIMI Risk Score for Atherothrombotic Disease. Diabetes Care. 2018 Mar;41(3):577–85. doi: 10.2337/dc17-1736. PMID: 29196298. Exclusion Code: X2.29196298
238 Berk KA, Buijks HIM, Verhoeven AJM, . Group cognitive behavioural therapy and weight regain after diet in type 2 diabetes: results from the randomised controlled POWER trial. Diabetologia. 2018;61(4):790–9. doi: 10.1007/s00125-017-4531-9. PMID: CN-01704040. Exclusion Code: X2.29318342
239 Berkowitz SA, Hulberg AC, Standish S, . Addressing unmet basic resource needs as part of chronic cardiometabolic disease management. JAMA Intern Med. 2017 Feb 1;177(2):244–52. doi: 10.1001/jamainternmed.2016.7691. PMID: 27942709. Exclusion Code: X6.27942709
240 Bernstein AM, Gendy G, Rudd N, . Management of prediabetes through lifestyle modification in overweight and obese African-American women: the Fitness, Relaxation, and Eating to Stay Healthy (FRESH) randomized controlled trial. Public Health. 2014 Jul;128(7):674–7. doi: 10.1016/j.puhe.2014.04.005. PMID: 24996961. Exclusion Code: X6.24996961
241 Best C, Struthers H, Laciny E, . Sitagliptin reduces markers of inflammation and chronic immune cell activation in hiv+ adults with glucose intolerance. Endocrine reviews. Conference: 97th annual meeting and expo of the endocrine society, ENDO 2015. United states. Conference start: 20150305. Conference end: 20150308. 2015;36(no pagination)PMID: CN-01293804. Exclusion Code: X6.
242 Best C, Struthers H, Laciny E, . Sitagliptin reduces inflammation and chronic immune cell activation in HIV+ adults with impaired glucose tolerance. J Clin Endocrinol Metab. 2015 Jul;100(7):2621–9. doi: 10.1210/jc.2015-1531. PMID: 25938633. Exclusion Code: X6.25938633
243 Bethel MA, Engel SS, Green JB, . Assessing the safety of sitagliptin in older participants in the Trial Evaluating Cardiovascular Outcomes with Sitagliptin (TECOS). Diabetes Care. 2017 Apr;40(4):494–501. doi: 10.2337/dc16-1135. PMID: 28057693. Exclusion Code: X2.28057693
244 Betsch D, Gao Z, Mugford G, . Optimizing Glycemic Control in Adults With Type 1 or Type 2 Diabetes Attending a Multidisciplinary Foot Clinic. Can J Diabetes. 2018 Aug;42(4):437–41. doi: 10.1016/j.jcjd.2017.10.058. PMID: 29284562. Exclusion Code: X2.29284562
245 Beulens JW, Hart HE, Kuijs R, . Influence of duration and dose of metformin on cobalamin deficiency in type 2 diabetes patients using metformin. Acta Diabetol. 2015 Feb;52(1):47–53. doi: 10.1007/s00592-014-0597-8. PMID: 24908579. Exclusion Code: X2.24908579
246 Beulens JW, Patel A, Vingerling JR, . Effects of blood pressure lowering and intensive glucose control on the incidence and progression of retinopathy in patients with type 2 diabetes mellitus: a randomised controlled trial. Diabetologia. 2009 Oct;52(10):2027–36. doi: 10.1007/s00125-009-1457-x. PMID: 19633827. Exclusion Code: X2.19633827
247 Bhanpuri NH, Hallberg SJ, Williams PT, . Cardiovascular disease risk factor responses to a type 2 diabetes care model including nutritional ketosis induced by sustained carbohydrate restriction at 1 year: an open label, non-randomized, controlled study. Cardiovasc Diabetol. 2018;17(1):56. doi: 10.1186/s12933-018-0698-8. PMID: CN-01703637. Exclusion Code: X6.29712560
248 Bi Y, Lu J, Wang W, . Cohort profile: risk evaluation of cancers in Chinese diabetic individuals: a longitudinal (REACTION) study. J Diabetes. 2014 Mar;6(2):147–57. doi: 10.1111/1753-0407.12108. PMID: 24237858. Exclusion Code: X5.24237858
249 Biadgo B, Melak T, Ambachew S, . The Prevalence of Metabolic Syndrome and Its Components among Type 2 Diabetes Mellitus Patients at a Tertiary Hospital, Northwest Ethiopia. Ethiop J Health Sci. 2018 Sep;28(5):645–54. doi: 10.4314/ejhs.v28i5.16. PMID: 30607080. Exclusion Code: X8.30607080
250 Biddle GJH, Edwardson CL, Henson J, . Associations of Physical Behaviours and Behavioural Reallocations with Markers of Metabolic Health: A Compositional Data Analysis. Int J Environ Res Public Health. 2018 Oct 17;15(10)doi: 10.3390/ijerph15102280. PMID: 30336601. Exclusion Code: X5.30336601
251 Biddle GJH, Edwardson CL, Rowlands AV, . Differences in objectively measured physical activity and sedentary behaviour between white Europeans and south Asians recruited from primary care: cross-sectional analysis of the PROPELS trial. BMC Public Health. 2019 Jan 21;19(1):95. doi: 10.1186/s12889-018-6341-5. PMID: 30665392. Exclusion Code: X8.30665392
252 Bidonde J, Busch AJ, van dSI, . Whole body vibration exercise training for fibromyalgia. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
253 Biessels GJ, Janssen J, van den Berg E, . Rationale and design of the CAROLINA(R) - cognition substudy: a randomised controlled trial on cognitive outcomes of linagliptin versus glimepiride in patients with type 2 diabetes mellitus. BMC Neurol. 2018 Jan 15;18(1):7. doi: 10.1186/s12883-018-1014-7. PMID: 29334906. Exclusion Code: X5.29334906
254 Biesty LM, Egan AM, Dunne F, . Planned birth at or near term for improving health outcomes for pregnant women with gestational diabetes and their infants. Cochrane Database of Systematic Reviews. 2018(1)doi: 10.1002/14651858.CD012910. PMID: CD012910. Exclusion Code: X8.
255 Bieszk N, Reynolds SL, Wei W, . “Act on threes” paradigm for treatment intensification of type 2 diabetes in managed care: results of a randomized controlled study with an educational intervention targeting improved glycemic control. J Manag Care Spec Pharm. 2016 Sep;22(9):1028–38. doi: 10.18553/jmcp.2016.22.9.1028. PMID: 27579824. Exclusion Code: X2.27579824
256 Billington EO, Grey A, Bolland MJ. The effect of thiazolidinediones on bone mineral density and bone turnover: systematic review and meta-analysis. Diabetologia. 2015 Oct;58(10):2238–46. doi: 10.1007/s00125-015-3660-2. PMID: 26109213. Exclusion Code: X8.26109213
257 Biondi-Zoccai G, Pinto A, Versaci F, . Comparative impact of hypoglycemic agents on severity and extent of myocardial ischemia in patients with type 2 diabetes mellitus undergoing myocardial perfusion scintigraphy. J Cardiovasc Pharmacol. 2016 Aug;68(2):162–70. doi: 10.1097/fjc.0000000000000399. PMID: 27074768. Exclusion Code: X2.27074768
258 Biswas A, Oh PI, Faulkner GE, . Sedentary time and its association with risk for disease incidence, mortality, and hospitalization in adults: a systematic review and meta-analysis. Ann Intern Med. 2015 Jan 20;162(2):123–32. doi: 10.7326/m14-1651. PMID: 25599350. Exclusion Code: X8.25599350
259 Bizino MB, Jazet IM, Westenberg JJM, . Effect of liraglutide on cardiac function in patients with type 2 diabetes mellitus: randomized placebo-controlled trial. Cardiovasc Diabetol. 2019;18(1)doi: 10.1186/s12933-019-0857-6. PMID: CN-01936998. Exclusion Code: X2.
260 Bjorner J, Brett J, Meincke H, . The effect of liraglutide 3.0 mg for weight management on HRQoL, as measured by SF-36: 3-year data. Diabetologia. Conference: 52nd annual meeting of the european association for the study of diabetes, EASD 2016. Germany. Conference start: 20160912. Conference end: 20160916. 2016;59(1 Supplement 1):S330. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212739. Exclusion Code: X10.
261 Black JA, Sharp SJ, Wareham NJ, . Change in cardiovascular risk factors following early diagnosis of type 2 diabetes: a cohort analysis of a cluster-randomised trial. Br J Gen Pract. 2014 Apr;64(621):e208–16. doi: 10.3399/bjgp14X677833. PMID: 24686885. Exclusion Code: X5.24686885
262 Blackberry ID, Furler JS, Ginnivan LE, . An exploratory trial of insulin initiation and titration among patients with type 2 diabetes in the primary care setting with retrospective continuous glucose monitoring as an adjunct: INITIATION study protocol. BMC Fam Pract. 2014 May 3;15:82. doi: 10.1186/1471-2296-15-82. PMID: 24886287. Exclusion Code: X6.24886287
263 Blackford K, Jancey J, Lee AH, . A randomised controlled trial of a physical activity and nutrition program targeting middle-aged adults at risk of metabolic syndrome in a disadvantaged rural community. BMC Public Health. 2015 Mar 25;15:284. doi: 10.1186/s12889-015-1613-9. PMID: 25885657. Exclusion Code: X6.25885657
264 Blackford K, Jancey J, Lee AH, . Home-based lifestyle intervention for rural adults improves metabolic syndrome parameters and cardiovascular risk factors: A randomised controlled trial. Prev Med. 2016 Aug;89:15–22. doi: 10.1016/j.ypmed.2016.05.012. PMID: 27196148. Exclusion Code: X2.27196148
265 Block G, Azar K, Block T, . Development and clinical trial of an eHealth program for pre-diabetics. FASEB journal. 2014;28(1 suppl. 1)PMID: CN-01060740. Exclusion Code: X6.
266 Block G, Azar KM, Romanelli RJ, . Improving diet, activity and wellness in adults at risk of diabetes: randomized controlled trial. Nutr Diabetes. 2016 Sep 19;6(9):e231. doi: 10.1038/nutd.2016.42. PMID: 27643726. Exclusion Code: X6.27643726
267 Blom DJ, Koren MJ, Roth E, . Evaluation of the efficacy, safety and glycaemic effects of evolocumab (AMG 145) in hypercholesterolaemic patients stratified by glycaemic status and metabolic syndrome. Diabetes Obes Metab. 2017 Jan;19(1):98–107. doi: 10.1111/dom.12788. PMID: 27619750. Exclusion Code: X4.27619750
268 Blomster JI, Zoungas S, Woodward M, . The impact of level of education on vascular events and mortality in patients with type 2 diabetes mellitus: Results from the ADVANCE study. Diabetes Res Clin Pract. 2017 May;127:212–7. doi: 10.1016/j.diabres.2017.03.015. PMID: 28395214. Exclusion Code: X2.28395214
269 Blonde L, Baron MA, Zhou R, . Efficacy and risk of hypoglycemia with use of insulin glargine or comparators in patients with cardiovascular risk factors. Postgrad Med. 2014 May;126(3):172–89. doi: 10.3810/pgm.2014.05.2766. PMID: 24918802. Exclusion Code: X8.24918802
270 Blonde L, Chava P, Dex T, . Predictors of outcomes in patients with type 2 diabetes in the lixisenatide GetGoal clinical trials. Diabetes Obes Metab. 2017 Feb;19(2):275–83. doi: 10.1111/dom.12815. PMID: 27767249. Exclusion Code: X2.27767249
271 Blonde L, Jendle J, Gross J, . Once-weekly dulaglutide versus bedtime insulin glargine, both in combination with prandial insulin lispro, in patients with type 2 diabetes (AWARD-4): a randomised, open-label, phase 3, non-inferiority study. Lancet. 2015 May 23;385(9982):2057–66. doi: 10.1016/s0140-6736(15)60936-9. PMID: 26009229. Exclusion Code: X5.26009229
272 Blonde L, Stenlof K, Fung A, . Effects of canagliflozin on body weight and body composition in patients with type 2 diabetes over 104 weeks. Postgrad Med. 2016;128(4):371–80. doi: 10.1080/00325481.2016.1169894. PMID: CN-01177673. Exclusion Code: X2.27002421
273 Blueher M, Wehrhahn T, Hermansen K, . Early weight loss with liraglutide 3.0 mg is a good predictor of clinically meaningful weight loss after 56 weeks. Diabetologie und stoffwechsel. 2016;11doi: 10.1055/s-0036-1580953. PMID: CN-01753320. Exclusion Code: X6.
274 Bluher M, Greenway F, Le Rouge CW, . 3-year efficacy and safety for liraglutide 3.0 mg in adults with obesity/overweight, prediabetes and baseline BMI < 35 vs. ≥35 kg/m2 in the SCALE Obesity and Prediabetes, double-blind, placebo-controlled trial. Diabetologie und stoffwechsel. 2017;12doi: 10.1055/s-0037-1601675. PMID: CN-01727789. Exclusion Code: X10.
275 Bluher M, Hermansen K, Greenway F, . Early weight loss with liraglutide 3.0 mg is good predictor of clinically meaningful weight loss after 56 weeks. Diabetologia. 2015;58(1 suppl. 1):S310. doi: 10.1007/s00125-015-3687-4. PMID: CN-01136820. Exclusion Code: X10.
276 Bluher M, Schweizer A, Bader G, . Changes in body weight after 24 weeks of vildagliptin therapy as a function of fasting glucose levels in patients with type 2 diabetes. Vasc Health Risk Manag. 2014;10:661–4. doi: 10.2147/vhrm.s73608. PMID: 25429228. Exclusion Code: X8.25429228
277 Bo A, Thomsen RW, Nielsen JS, . Early-onset type 2 diabetes: Age gradient in clinical and behavioural risk factors in 5115 persons with newly diagnosed type 2 diabetes-Results from the DD2 study. Diabetes Metab Res Rev. 2018 Mar;34(3)doi: 10.1002/dmrr.2968. PMID: 29172021. Exclusion Code: X8.29172021
278 Bo S, Ponzo V, Evangelista A, . Effects of 6 months of resveratrol versus placebo on pentraxin 3 in patients with type 2 diabetes mellitus: a double-blind randomized controlled trial. Acta Diabetol. 2017 May;54(5):499–507. doi: 10.1007/s00592-017-0977-y. PMID: 28238190. Exclusion Code: X2.28238190
279 Bock BC, Thind H, Fava JL, . Feasibility of yoga as a complementary therapy for patients with type 2 diabetes: The Healthy Active and in Control (HA1C) study. Complement Ther Med. 2019 Feb;42:125–31. doi: 10.1016/j.ctim.2018.09.019. PMID: 30670230. Exclusion Code: X4.30670230
280 Bode B, DeFronzo R, Bergenstal R, . Effect of liraglutide 3.0/1.8 mg on body weight and cardiometabolic risk factors in overweight/obese adults with type 2 diabetes: SCALE diabetes randomised, double-blind, 56-week trial. Diabetologia. 2014;57(1 suppl. 1):S83. doi: 10.1007/s00125-014-3355-0. PMID: CN-01059211. Exclusion Code: X2.
281 Bode B, Stenlof K, Harris S, . Long-term efficacy and safety of canagliflozin over 104 weeks in patients aged 55-80 years with type 2 diabetes. Diabetes Obes Metab. 2015 Mar;17(3):294–303. doi: 10.1111/dom.12428. PMID: 25495720. Exclusion Code: X2.25495720
282 Bodicoat DH, Khunti K, Srinivasan BT, . Incident Type 2 diabetes and the effect of early regression to normoglycaemia in a population with impaired glucose regulation. Diabet Med. 2017 Mar;34(3):396–404. doi: 10.1111/dme.13091. PMID: 26871995. Exclusion Code: X5.26871995
283 Bohula EA, Scirica BM, Inzucchi SE, . Effect of lorcaserin on prevention and remission of type 2 diabetes in overweight and obese patients (CAMELLIA-TIMI 61): a randomised, placebo-controlled trial. Lancet. 2018 Nov 24;392(10161):2269–79. doi: 10.1016/s0140-6736(18)32328-6. PMID: 30293771. Exclusion Code: X4.30293771
284 Bokvist K, Ding Y, Landschulz WH, . Gastrin analogue administration adds no significant glycaemic benefit to a glucagon-like peptide-1 receptor agonist acutely or after washout of both analogues. Diabetes, obesity & metabolism. 2019doi: 10.1111/dom.13695. PMID: CN-01937042. Exclusion Code: X2.
285 Bolinder J, Ljunggren Ö, Johansson L, . Dapagliflozin maintains glycaemic control while reducing weight and body fat mass over 2 years in patients with type 2 diabetes mellitus inadequately controlled on metformin. Diabetes, obesity & metabolism. 2014;16(2):159–69. doi: 10.1111/dom.12189. PMID: CN-00959256. Exclusion Code: X2.
286 Bolli GB, Munteanu M, Dotsenko S, . Efficacy and safety of lixisenatide once daily vs. placebo in people with Type 2 diabetes insufficiently controlled on metformin (GetGoal-F1). Diabet Med. 2014 Feb;31(2):176–84. doi: 10.1111/dme.12328. PMID: 24117597. Exclusion Code: X2.24117597
287 Bollyky JB, Bravata D, Yang J, . Remote Lifestyle Coaching Plus a Connected Glucose Meter with Certified Diabetes Educator Support Improves Glucose and Weight Loss for People with Type 2 Diabetes. J Diabetes Res. 2018;2018:3961730. doi: 10.1155/2018/3961730. PMID: 29888288. Exclusion Code: X5.29888288
288 Bonadonna RC, Blonde L, Antsiferov M, . Lixisenatide as add-on treatment among patients with different beta-cell function levels as assessed by HOMA-beta index. Diabetes Metab Res Rev. 2017 Sep;33(6)doi: 10.1002/dmrr.2897. PMID: 28303626. Exclusion Code: X8.28303626
289 Boncelj Svetek M, Erzen B, Kanc K, . Impaired endothelial function and arterial stiffness in patients with type 2 diabetes - the effect of a very low-dose combination of fluvastatin and valsartan. J Diabetes Complications. 2017 Mar;31(3):544–50. doi: 10.1016/j.jdiacomp.2016.12.002. PMID: 28012835. Exclusion Code: X2.28012835
290 Bond-Smith G, Belgaumkar AP, Davidson BR, . Enhanced recovery protocols for major upper gastrointestinal, liver and pancreatic surgery. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
291 Bonn SE, Alexandrou C, Hjorleifsdottir Steiner K, . App-technology to increase physical activity among patients with diabetes type 2 - the DiaCert-study, a randomized controlled trial. BMC Public Health. 2018 Jan 10;18(1):119. doi: 10.1186/s12889-018-5026-4. PMID: 29316905. Exclusion Code: X6.29316905
292 Bonora E, Bryzinski B, Hirshberg B, . A post hoc analysis of saxagliptin efficacy and safety in patients with type 2 diabetes stratified by UKPDS 10-year cardiovascular risk score. Nutr Metab Cardiovasc Dis. 2016 May;26(5):374–9. doi: 10.1016/j.numecd.2015.11.004. PMID: 27033025. Exclusion Code: X8.27033025
293 Booth AO, Lowis C, Hunter SJ, . Development and evaluation of a computer-based, self-management tool for people recently diagnosed with type 2 diabetes. J Diabetes Res. 2016;2016:3192673. doi: 10.1155/2016/3192673. PMID: 27446961. Exclusion Code: X6.27446961
294 Bordeleau L, Yakubovich N, Dagenais GR, . The association of basal insulin glargine and/or n-3 fatty acids with incident cancers in patients with dysglycemia. Diabetes Care. 2014;37(5):1360–6. doi: 10.2337/dc13-1468. PMID: 24574355. Exclusion Code: X2.24574355
295 Borelli MR, Riden HE, Bang H, . Protocol for a cluster randomized controlled trial to study the effectiveness of an obesity and diabetes intervention (PASOS) in an immigrant farmworker population. BMC Public Health. 2018 Jul 9;18(1):849. doi: 10.1186/s12889-018-5560-0. PMID: 29986676. Exclusion Code: X2.29986676
296 Borowska M, Dworacka M, Weso?owska A, . The impact of pharmacotherapy of type 2 diabetes mellitus on IL-1?, IL-6 and IL-10 secretion. Pharmacology. 2016;97(3–4):189–94. doi: 10.1159/000443897. PMID: CN-01259783. Exclusion Code: X2.26854669
297 Borowska M, Dworacka M, Wesolowska A, . The impact of pharmacotherapy of type 2 diabetes mellitus on IL-1beta, IL-6 and IL-10 secretion. Pharmacology. 2016;97(3–4):189–94. doi: 10.1159/000443897. PMID: 26854669. Exclusion Code: X2.26854669
298 Borzouei S, Soltanian AR. Application of an artificial neural network model for diagnosing type 2 diabetes mellitus and determining the relative importance of risk factors. Epidemiol Health. 2018;40:e2018007. doi: 10.4178/epih.e2018007. PMID: 29529860. Exclusion Code: X5.29529860
299 Boucaud-Maitre D, Ropers J, Porokhov B, . Lactic acidosis: relationship between metformin levels, lactate concentration and mortality. Diabet Med. 2016 Nov;33(11):1536–43. doi: 10.1111/dme.13098. PMID: 26882092. Exclusion Code: X6.26882092
300 Bouchi R, Fukuda T, Takeuchi T, . Dipeptidyl peptidase 4 inhibitors attenuates the decline of skeletal muscle mass in patients with type 2 diabetes. Diabetes Metab Res Rev. 2018 Feb;34(2)doi: 10.1002/dmrr.2957. PMID: 29054111. Exclusion Code: X2.29054111
301 Bouldin ED, Trivedi RB, Reiber GE, . Associations between having an informal caregiver, social support, and self-care among low-income adults with poorly controlled diabetes. Chronic illness. 2017;13(4):239–50. doi: 10.1177/1742395317690032. PMID: CN-01615080. Exclusion Code: X4.29119864
302 Boussageon R, Bejan-Angoulvant T, Saadatian-Elahi M, . Effect of intensive glucose lowering treatment on all cause mortality, cardiovascular death, and microvascular events in type 2 diabetes: meta-analysis of randomised controlled trials. BMJ. 2011 Jul 26;343:d4169. doi: 10.1136/bmj.d4169. PMID: 21791495. Exclusion Code: X8.21791495
303 Boustani MA, Pittman It, Yu M, . Similar efficacy and safety of once-weekly dulaglutide in patients with type 2 diabetes aged >/=65 and <65 years. Diabetes Obes Metab. 2016 Aug;18(8):820–8. doi: 10.1111/dom.12687. PMID: 27161178. Exclusion Code: X5.27161178
304 Bowen ME, Cavanaugh KL, Wolff K, . The diabetes nutrition education study randomized controlled trial: a comparative effectiveness study of approaches to nutrition in diabetes self-management education. Patient Educ Couns. 2016 Aug;99(8):1368–76. doi: 10.1016/j.pec.2016.03.017. PMID: 27026388. Exclusion Code: X2.27026388
305 Bozack A, Millstein S, Garcel JM, . Implementation and outcomes of the New York State YMCA diabetes prevention program: a multisite community-based translation, 2010-2012. Prev Chronic Dis. 2014 Jul 10;11:E115. doi: 10.5888/pcd11.140006. PMID: 25010997. Exclusion Code: X8.25010997
306 Bozzetto L, Annuzzi G, Costabile G, . A CHO/fibre diet reduces and a MUFA diet increases postprandial lipaemia in type 2 diabetes: no supplementary effects of low-volume physical training. Acta Diabetol. 2014;51(3):385–93. doi: 10.1007/s00592-013-0522-6. PMID: 24132660. Exclusion Code: X6.24132660
307 Bozzetto L, Costabile G, Luongo D, . Reduction in liver fat by dietary MUFA in type 2 diabetes is helped by enhanced hepatic fat oxidation. Diabetologia. 2016 Dec;59(12):2697–701. doi: 10.1007/s00125-016-4110-5. PMID: 27650287. Exclusion Code: X6.27650287
308 Braithwaite T, Sharma A, Bartholomew D, . Population-based self-reported prevalence and management of Type 2 diabetes, hypertension and dyslipidaemia. West Indian Med J. 2016;65:54-. PMID: CN-01787387. Exclusion Code: X6.
309 Brath H, Bialek C, Gingl E, . Efficacy and tolerability of vildagliptin-based versus comparative dual therapy in type 2 diabetes : results of the Austrian subpopulation of the EDGE study. Wien Klin Wochenschr. 2015 Apr;127(7–8):250–5. doi: 10.1007/s00508-014-0646-x. PMID: 25576329. Exclusion Code: X2.25576329
310 Bratseth V, Byrkjeland R, Njerve I, . Procoagulant activity in patients with combined type 2 diabetes and coronary artery disease: no effects of long-term exercise training. Diab Vasc Dis Res. 2017;14(2):144–51. doi: 10.1177/1479164116679080. PMID: CN-01338813. Exclusion Code: X2.28111966
311 Breyer BN, Phelan S, Hogan PE, . Intensive lifestyle intervention reduces urinary incontinence in overweight/obese men with type 2 diabetes: results from the Look AHEAD trial. J Urol. 2014 Jul;192(1):144–9. doi: 10.1016/j.juro.2014.02.036. PMID: 24533998. Exclusion Code: X6.24533998
312 Briggs AH, Bhatt DL, Scirica BM, . Health-related quality-of-life implications of cardiovascular events in individuals with type 2 diabetes mellitus: a subanalysis from the Saxagliptin Assessment of Vascular Outcomes Recorded in Patients with Diabetes Mellitus (SAVOR)-TIMI 53 trial. Diabetes Res Clin Pract. 2017 Aug;130:24–33. doi: 10.1016/j.diabres.2016.12.019. PMID: 28554140. Exclusion Code: X2.28554140
313 Bril F, Portillo Sanchez P, Lomonaco R, . Liver safety of statins in prediabetes or T2DM and nonalcoholic steatohepatitis: post hoc analysis of a randomized trial. J Clin Endocrinol Metab. 2017 Aug 1;102(8):2950–61. doi: 10.1210/jc.2017-00867. PMID: 28575232. Exclusion Code: X2.28575232
314 Brinkworth GD, Luscombe-Marsh ND, Thompson CH, . Long-term effects of very low-carbohydrate and high-carbohydrate weight-loss diets on psychological health in obese adults with type 2 diabetes: randomized controlled trial. J Intern Med. 2016 Oct;280(4):388–97. doi: 10.1111/joim.12501. PMID: 27010424. Exclusion Code: X2.27010424
315 Brinton EA, Ballantyne CM, Guyton JR, . Lipid Effects of Icosapent Ethyl in Women with Diabetes Mellitus and Persistent High Triglycerides on Statin Treatment: ANCHOR Trial Subanalysis. J Womens Health (Larchmt). 2018 Sep;27(9):1170–6. doi: 10.1089/jwh.2017.6757. PMID: 29583081. Exclusion Code: X5.29583081
316 Broglio F, Mannucci E, Napoli R, . Beneficial effect of lixisenatide after 76 weeks of treatment in patients with type 2 diabetes mellitus: a meta-analysis from the GetGoal programme. Diabetes Obes Metab. 2017 Feb;19(2):248–56. doi: 10.1111/dom.12810. PMID: 27762096. Exclusion Code: X8.27762096
317 Brokaw SM, Carpenedo D, Campbell P, . Effectiveness of an adapted diabetes prevention program lifestyle intervention in older and younger adults. J Am Geriatr Soc. 2015 Jun;63(6):1067–74. doi: 10.1111/jgs.13428. PMID: 26031428. Exclusion Code: X2.26031428
318 Bron M, Wilson C, Fleck P. A post hoc analysis of HbA1c, hypoglycemia, and weight change outcomes with alogliptin vs glipizide in older patients with type 2 diabetes. Diabetes therapy. 2014;5(2):521–34. doi: 10.1007/s13300-014-0088-5. PMID: CN-01040685. Exclusion Code: X5.25424968
319 Bronden A, Alber A, Rohde U, . Single-dose metformin enhances bile acid-induced glucagon-like peptide-1 secretion in patients with type 2 diabetes. J Clin Endocrinol Metab. 2017 Nov 1;102(11):4153–62. doi: 10.1210/jc.2017-01091. PMID: 28938439. Exclusion Code: X6.28938439
320 Brouwer TF, Vehmeijer JT, Kalkman DN, . Intensive Blood Pressure Lowering in Patients With and Patients Without Type 2 Diabetes: A Pooled Analysis From Two Randomized Trials. Diabetes Care. 2018 Jun;41(6):1142–8. doi: 10.2337/dc17-1722. PMID: 29212825. Exclusion Code: X8.29212825
321 Brown J, Alwan NA, West J, . Lifestyle interventions for the treatment of women with gestational diabetes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
322 Brown J, Ceysens G, Boulvain M. Exercise for pregnant women with pre-existing diabetes for improving maternal and fetal outcomes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
323 Brown J, Ceysens G, Boulvain M. Exercise for pregnant women with gestational diabetes for improving maternal and fetal outcomes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
324 Brown J, Crawford TJ, Alsweiler J, . Dietary supplementation with myo-inositol in women during pregnancy for treating gestational diabetes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
325 Brown J, Grzeskowiak L, Williamson K, . Insulin for the treatment of women with gestational diabetes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
326 Brown J, Martis R, Hughes B, . Oral anti-diabetic pharmacological therapies for the treatment of women with gestational diabetes. Cochrane Database of Systematic Reviews. 2017(1)doi: 10.1002/14651858.CD011967.pub2. PMID: CD011967. Exclusion Code: X8.
327 Brown SD, Fotuhi O, Grijalva CS, . A Randomized Study of Values Affirmation to Promote Interest in Diabetes Prevention Among Women With a History of Gestational Diabetes. Med Care. 2019;57(7):528–35. doi: 10.1097/MLR.0000000000001133. PMID: CN-01958913. Exclusion Code: X6.31107396
328 Browning C, Chapman A, Yang H, . Management of type 2 diabetes in China: the Happy Life Club, a pragmatic cluster randomised controlled trial using health coaches. BMJ Open. 2016 Mar 4;6(3):e009319. doi: 10.1136/bmjopen-2015-009319. PMID: 26944692. Exclusion Code: X2.26944692
329 Bruderer SG, Bodmer M, Jick SS, . Incidence of and risk factors for severe hypoglycaemia in treated type 2 diabetes mellitus patients in the UK--a nested case-control analysis. Diabetes Obes Metab. 2014 Sep;16(9):801–11. doi: 10.1111/dom.12282. PMID: 24612200. Exclusion Code: X5.24612200
330 Brunisholz KD, Joy EA, Hashibe M, . Stepping back to move forward: evaluating the effectiveness of a diabetes prevention program within a large integrated healthcare delivery system. J Healthc Qual. 2017 Sep/Oct;39(5):278–93. doi: 10.1097/jhq.0000000000000103. PMID: 28858965. Exclusion Code: X8.28858965
331 Bryson A, Jennings PE, Deak L, . The efficacy and safety of teneligliptin added to ongoing metformin monotherapy in patients with type 2 diabetes: a randomized study with open label extension. Expert Opin Pharmacother. 2016 Jul;17(10):1309–16. doi: 10.1080/14656566.2016.1190334. PMID: 27181910. Exclusion Code: X2.27181910
332 Bryzinski B, Allen E, Cook W, . Saxagliptin efficacy and safety in patients with type 2 diabetes receiving concomitant statin therapy. J Diabetes Complications. 2014 Nov-Dec;28(6):887–93. doi: 10.1016/j.jdiacomp.2014.07.006. PMID: 25168266. Exclusion Code: X8.25168266
333 Buckley LF, Dixon DL, Wohlford GFt, . Intensive Versus Standard Blood Pressure Control in SPRINT-Eligible Participants of ACCORD-BP. Diabetes Care. 2017 Dec;40(12):1733–8. doi: 10.2337/dc17-1366. PMID: 28947569. Exclusion Code: X2.28947569
334 Buckley LF, Dixon DL, Wohlford GFt, . Effect of intensive blood pressure control in patients with type 2 diabetes mellitus over 9 years of follow-up: A subgroup analysis of high-risk ACCORDION trial participants. Diabetes Obes Metab. 2018 Jun;20(6):1499–502. doi: 10.1111/dom.13248. PMID: 29424469. Exclusion Code: X2.29424469
335 Buehler AM, Cavalcanti AB, Berwanger O, . Effect of tight blood glucose control versus conventional control in patients with type 2 diabetes mellitus: a systematic review with meta-analysis of randomized controlled trials. Cardiovasc Ther. 2013 Jun;31(3):147–60. doi: 10.1111/j.1755-5922.2011.00308.x. PMID: 22212499. Exclusion Code: X8.22212499
336 Buhse S, Muhlhauser I, Heller T, . Informed shared decision-making programme on the prevention of myocardial infarction in type 2 diabetes: a randomised controlled trial. BMJ Open. 2015 Nov 13;5(11):e009116. doi: 10.1136/bmjopen-2015-009116. PMID: 26567256. Exclusion Code: X4.26567256
337 Buijsse B, Boeing H, Drogan D, . Consumption of fatty foods and incident type 2 diabetes in populations from eight European countries. Eur J Clin Nutr. 2015 Apr;69(4):455–61. doi: 10.1038/ejcn.2014.249. PMID: 25424603. Exclusion Code: X8.25424603
338 Bukhsh A, Nawaz M, Ahmed H, . A randomized controlled study to evaluate the effect of pharmacist-led educational intervention on glycemic control, self-care activities and disease knowledge among type 2 diabetes patients: a consort compliant study protocol. Medicine. 2018;97(12):e9847. doi: 10.1097/MD.0000000000009847. PMID: CN-01599566. Exclusion Code: X6.29561461
339 Bukman AJ, Duijzer G, Haveman-Nies A, . Is the success of the SLIMMER diabetes prevention intervention modified by socioeconomic status? A randomised controlled trial. Diabetes Res Clin Pract. 2017 Jul;129:160–8. doi: 10.1016/j.diabres.2017.05.002. PMID: 28528077. Exclusion Code: X2.28528077
340 Bulatova N, Kasabri V, Qotineh A, . Effect of metformin combined with lifestyle modification versus lifestyle modification alone on proinflammatory-oxidative status in drug-naïve pre-diabetic and diabetic patients: a randomized controlled study. Diabetes Metab Syndr. 2018;12(3):257–67. doi: 10.1016/j.dsx.2017.11.003. PMID: CN-01643201. Exclusion Code: X5.29221717
341 Bulatova N, Kasabri V, Qotineh A, . Effect of metformin combined with lifestyle modification versus lifestyle modification alone on proinflammatory-oxidative status in drug-naive pre-diabetic and diabetic patients: a randomized controlled study. Diabetes and metabolic syndrome: clinical research and reviews. 2017;(no pagination)doi: 10.1016/j.dsx.2017.11.003. PMID: CN-01442803. Exclusion Code: X11.
342 Burton JH, Johnson M, Johnson J, . Addition of a gastrointestinal microbiome modulator to metformin improves metformin tolerance and fasting glucose levels. J Diabetes Sci Technol. 2015 Jul;9(4):808–14. doi: 10.1177/1932296815577425. PMID: 25802471. Exclusion Code: X4.25802471
343 Busch RS, Kane MP. Combination SGLT2 inhibitor and GLP-1 receptor agonist therapy: a complementary approach to the treatment of type 2 diabetes. Postgrad Med. 2017 Sep;129(7):686–97. doi: 10.1080/00325481.2017.1342509. PMID: 28657399. Exclusion Code: X8.28657399
344 Buse JB, Bethel MA, Green JB, . Pancreatic safety of sitagliptin in the TECOS Study. Diabetes Care. 2017 Feb;40(2):164–70. doi: 10.2337/dc15-2780. PMID: 27630212. Exclusion Code: X8.27630212
345 Buse JB, DeFronzo RA, Rosenstock J, . The primary glucose-lowering effect of metformin resides in the gut, not the circulation: results from short-term pharmacokinetic and 12-week dose-ranging studies. Diabetes Care. 2016 Feb;39(2):198–205. doi: 10.2337/dc15-0488. PMID: 26285584. Exclusion Code: X8.26285584
346 Buse JB, Han J, Miller S, . Addition of exenatide BID to insulin glargine: a post-hoc analysis of the effect on glycemia and weight across a range of insulin titration. Curr Med Res Opin. 2014 Jul;30(7):1209–18. doi: 10.1185/03007995.2014.896329. PMID: 24621255. Exclusion Code: X2.24621255
347 Buse JB, Vilsboll T, Thurman J, . Contribution of liraglutide in the fixed-ratio combination of insulin degludec and liraglutide (IDegLira). Diabetes Care. 2014 Nov;37(11):2926–33. doi: 10.2337/dc14-0785. PMID: 25114296. Exclusion Code: X5.25114296
348 But A, Wang H, Mannisto S, . Assessing the effect of treatment duration on the association between anti-diabetic medication and cancer risk. PLoS One. 2014;9(11):e113162. doi: 10.1371/journal.pone.0113162. PMID: 25419576. Exclusion Code: X2.25419576
349 Butalia S, Gutierrez L, Lodha A, . Short- and long-term outcomes of metformin compared with insulin alone in pregnancy: a systematic review and meta-analysis. Diabet Med. 2017 Jan;34(1):27–36. doi: 10.1111/dme.13150. PMID: 27150509. Exclusion Code: X8.27150509
350 Butt M, Mhd AA, Bakry M, . Impact of a pharmacist led diabetes mellitus intervention on HbA1c, medication adherence and quality of life: a randomised controlled study. Saudi pharmaceutical journal. 2016;24(1):40–8. doi: 10.1016/j.jsps.2015.02.023. PMID: CN-01177833. Exclusion Code: X2.26903767
351 Buysman EK, Chow W, Henk HJ, . Characteristics and outcomes of patients with type 2 diabetes mellitus treated with canagliflozin: a real-world analysis. BMC Endocr Disord. 2015 Nov 2;15:67. doi: 10.1186/s12902-015-0064-8. PMID: 26527413. Exclusion Code: X6.26527413
352 Buysman EK, Liu F, Hammer M, . Impact of medication adherence and persistence on clinical and economic outcomes in patients with type 2 diabetes treated with liraglutide: a retrospective cohort study. Adv Ther. 2015 Apr;32(4):341–55. doi: 10.1007/s12325-015-0199-z. PMID: 25832470. Exclusion Code: X8.25832470
353 Caballero AE, Nikonova E, Zhou S, . Efficacy of lorcaserin by race: a post-hoc analysis of phase 3 studies in adults with overweight or obesity with and without type 2 diabetes mellitus (T2DM). Diabetes. 2017;66:A688-. PMID: CN-01755827. Exclusion Code: X5.
354 Caetano I, Santiago LM, Marques M. Impact of written information on control and adherence in type 2 diabetes. Rev Assoc Med Bras (1992). 2018 Feb;64(2):140–7. doi: 10.1590/1806-9282.64.02.140. PMID: 29641669. Exclusion Code: X6.29641669
355 Cahill LE, Pan A, Chiuve SE, . Fried-food consumption and risk of type 2 diabetes and coronary artery disease: a prospective study in 2 cohorts of US women and men. Am J Clin Nutr. 2014 Aug;100(2):667–75. doi: 10.3945/ajcn.114.084129. PMID: 24944061. Exclusion Code: X8.24944061
356 Cahn A, Mosenzon O, Bhatt DL, . Hypoglycaemia manifestations and recurrent events: lessons from the SAVOR-TIMI 53 outcome study. Diabetes Obes Metab. 2017 Jul;19(7):1045–50. doi: 10.1111/dom.12903. PMID: 28181728. Exclusion Code: X2.28181728
357 Cahn A, Raz I, Mosenzon O, . Predisposing factors for any and major hypoglycemia with saxagliptin versus placebo and overall: analysis from the SAVOR-TIMI 53 Trial. Diabetes Care. 2016 Aug;39(8):1329–37. doi: 10.2337/dc15-2763. PMID: 27222508. Exclusion Code: X2.27222508
358 Cai C, Hu J. Effectiveness of a family-based diabetes self-management educational intervention for Chinese adults with type 2 diabetes in Wuhan, China. Diabetes Educ. 2016 Dec;42(6):697–711. doi: 10.1177/0145721716674325. PMID: 27831523. Exclusion Code: X2.27831523
359 Cai J, Delahanty LM, Akapame S, . Impact of Canagliflozin Treatment on Health-Related Quality of Life among People with Type 2 Diabetes Mellitus: A Pooled Analysis of Patient-Reported Outcomes from Randomized Controlled Trials. Patient. 2018 Jun;11(3):341–52. doi: 10.1007/s40271-017-0290-4. PMID: 29313267. Exclusion Code: X8.29313267
360 Cai X, Shi L, Yang W, . Cost-effectiveness analysis of dapagliflozin treatment versus metformin treatment in Chinese population with type 2 diabetes. J Med Econ. 2019 Apr;22(4):336–43. doi: 10.1080/13696998.2019.1570220. PMID: 30663458. Exclusion Code: X8.30663458
361 Cai XL, Chen YL, Zhao JJ, . Efficacy and safety of avandamet or uptitrated metformin treatment in patients with type 2 diabetes inadequately controlled with metformin alone: a multicenter, randomized, controlled trial. Chin Med J (Engl). 2015 May 20;128(10):1279–87. doi: 10.4103/0366-6999.156735. PMID: 25963345. Exclusion Code: X2.25963345
362 Cakirca M, Karatoprak C, Zorlu M, . Effect of vildagliptin add-on treatment to metformin on plasma asymmetric dimethylarginine in type 2 diabetes mellitus patients. Drug Des Devel Ther. 2014;8:239–43. doi: 10.2147/dddt.s52545. PMID: 24627624. Exclusion Code: X2.24627624
363 Calles-Escandon J, Lovato LC, Simons-Morton DG, . Effect of intensive compared with standard glycemia treatment strategies on mortality by baseline subgroup characteristics: the Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial. Diabetes Care. 2010 Apr;33(4):721–7. doi: 10.2337/dc09-1471. PMID: 20103550. Exclusion Code: X2.20103550
364 Callisaya M, Daly R, Sharman J, . Feasibility of a multi-modal exercise program on cognition in older adults with type 2 diabetes - a pilot randomised controlled trial. BMC Geriatr. 2017;17(1):237. doi: 10.1186/s12877-017-0635-9. PMID: CN-01569752. Exclusion Code: X2.29037162
365 Camargo A, Rangel-Zúñiga O, Alcalá-Díaz J, . Dietary fat may modulate adipose tissue homeostasis through the processes of autophagy and apoptosis. Eur J Nutr. 2017;56(4):1621–8. doi: 10.1007/s00394-016-1208-y. PMID: CN-01600960. Exclusion Code: X6.27029919
366 Cameron AJ, Zimmet PZ. What will it take to curb the rise in obesity? Med J Aust. 2014 Jul 7;201(1):25–6. PMID: 24999882. Exclusion Code: X8.24999882
367 Campbell T, Dunt D, Fitzgerald JL, . The impact of patient narratives on self-efficacy and self-care in Australians with type 2 diabetes: stage 1 results of a randomized trial. Health Promot Int. 2015 Sep;30(3):438–48. doi: 10.1093/heapro/dat058. PMID: 23985247. Exclusion Code: X5.23985247
368 Cannon CP, McGuire DK, Pratley R, . Design and baseline characteristics of the eValuation of ERTugliflozin effIcacy and Safety CardioVascular outcomes trial (VERTIS-CV). Am Heart J. 2018 Dec;206:11–23. doi: 10.1016/j.ahj.2018.08.016. PMID: 30290289. Exclusion Code: X2.30290289
369 Cao L, Sun H, Wu H, . Pioglitazone for adults with high risk of developing type 2 diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
370 Cao YX, Liu HH, Dong QT, . Effect of proprotein convertase subtilisin/kexin type 9 (PCSK9) monoclonal antibodies on new-onset diabetes mellitus and glucose metabolism: A systematic review and meta-analysis. Diabetes Obes Metab. 2018 Jun;20(6):1391–8. doi: 10.1111/dom.13235. PMID: 29377473. Exclusion Code: X8.29377473
371 Cardoso C, Leite N, Carlos F, . Efficacy and safety of diacerein in patients with inadequately controlled type 2 diabetes: a randomized controlled trial. Diabetes care. 2017;40(10):1356–63. doi: 10.2337/dc17-0374. PMID: CN-01442169. Exclusion Code: X2.28818994
372 Carey ME, Mandalia PK, Daly H, . Increasing capacity to deliver diabetes self-management education: results of the DESMOND lay educator non-randomized controlled equivalence trial. Diabet Med. 2014 Nov;31(11):1431–8. doi: 10.1111/dme.12483. PMID: 24798205. Exclusion Code: X6.24798205
373 Carlson N, Hommel K, Olesen JB, . Metformin-associated risk of acute dialysis in patients with type 2 diabetes: a nationwide cohort study. Diabetes Obes Metab. 2016 Dec;18(12):1283–7. doi: 10.1111/dom.12764. PMID: 27534835. Exclusion Code: X5.27534835
374 Carmichael OT, Neiberg RH, Dutton G, . ASSOCIATIONS BETWEEN TEN-YEAR CHANGE IN DIABETES MARKERS AND COGNITIVE PERFORMANCE IN TYPE 2 DIABETES. Alzheimer’s & dementia. 2018;14(7):P1415–P6. doi: 10.1016/j.jalz.2018.06.2944. PMID: CN-01654443. Exclusion Code: X6.
375 Caro-Bautista J, Martin-Santos FJ, Morales-Asencio JM. Systematic review of the psychometric properties and theoretical grounding of instruments evaluating self-care in people with type 2 diabetes mellitus. J Adv Nurs. 2014 Jun;70(6):1209–27. doi: 10.1111/jan.12298. PMID: 24237156. Exclusion Code: X8.24237156
376 Carrasquillo O, Patberg E, Alonzo Y, . Rationale and design of the Miami Healthy Heart Initiative: a randomized controlled study of a community health worker intervention among Latino patients with poorly controlled diabetes. International journal of general medicine. 2014;7:115–25. doi: 10.2147/IJGM.S56250. PMID: CN-00981318. Exclusion Code: X2.24600243
377 Carrington MJ, Zimmet P. Nurse health and lifestyle modification versus standard care in 40 to 70 year old regional adults: study protocol of the Management to Optimise Diabetes and mEtabolic syndrome Risk reduction via Nurse-led intervention (MODERN) randomized controlled trial. BMC Health Serv Res. 2017;17(1):813. doi: 10.1186/s12913-017-2769-z. PMID: CN-01614875. Exclusion Code: X6.29212477
378 Carter P, Achana F, Troughton J, . A Mediterranean diet improves HbA1c but not fasting blood glucose compared to alternative dietary strategies: a network meta-analysis. J Hum Nutr Diet. 2014 Jun;27(3):280–97. doi: 10.1111/jhn.12138. PMID: 23790149. Exclusion Code: X8.23790149
379 Carter P, Bodicoat DH, Davies MJ, . A retrospective evaluation of the NHS Health Check Programme in a multi-ethnic population. J Public Health (Oxf). 2016 Sep;38(3):534–42. doi: 10.1093/pubmed/fdv115. PMID: 26315996. Exclusion Code: X4.26315996
380 Carter S, Clifton PM, Keogh JB. The effect of intermittent compared with continuous energy restriction on glycaemic control in patients with type 2 diabetes: 24-month follow-up of a randomised noninferiority trial. Diabetes Res Clin Pract. 2019;151:11–9. doi: 10.1016/j.diabres.2019.03.022. PMID: CN-01954874. Exclusion Code: X2.30902672
381 Carter S, Keogh J, Clifton P. The effects of intermittent compared with continuous energy restriction on glycaemic control in type 2 diabetes: a pilot trial. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A195. doi: 10.2337/db16-652-860. PMID: CN-01449935. Exclusion Code: X2.
382 Cassidy S, Thoma C, Hallsworth K, . High intensity intermittent exercise improves cardiac structure and function and reduces liver fat in patients with type 2 diabetes: a randomised controlled trial. Diabetologia. 2016 Jan;59(1):56–66. doi: 10.1007/s00125-015-3741-2. PMID: 26350611. Exclusion Code: X6.26350611
383 Castagno D, Baird-Gunning J, Jhund PS, . Intensive glycemic control has no impact on the risk of heart failure in type 2 diabetic patients: evidence from a 37,229 patient meta-analysis. Am Heart J. 2011 Nov;162(5):938–48 e2. doi: 10.1016/j.ahj.2011.07.030. PMID: 22093212. Exclusion Code: X8.22093212
384 Castro-Cornejo ML, Rico-Herrera L, Padilla-Raygoza N. Effect of educational support on treatment adherence in patients with type 2 diabetes: an experimental study. Enfermeria clinica. 2014;24(3):162–7. doi: 10.1016/j.enfcli.2013.11.004. PMID: CN-01118402. Exclusion Code: X1.24530350
385 Cavender MA, Scirica BM, Raz I, . Cardiovascular outcomes of patients in SAVOR-TIMI 53 by baseline hemoglobin A1c. Am J Med. 2016 Mar;129(3):340.e1–8. doi: 10.1016/j.amjmed.2015.09.022. PMID: 26524706. Exclusion Code: X2.26524706
386 Cavender MA, White WB, Jarolim P, . Serial measurement of high-sensitivity troponin i and cardiovascular outcomes in patients with type 2 diabetes mellitus in the EXAMINE Trial (Examination of Cardiovascular Outcomes With Alogliptin Versus Standard of Care). Circulation. 2017 May 16;135(20):1911–21. doi: 10.1161/circulationaha.116.024632. PMID: 28246236. Exclusion Code: X2.28246236
387 Cavero-Redondo I, Peleteiro B, Alvarez-Bueno C, . The Effect of Physical Activity Interventions on Glycosylated Haemoglobin (HbA1c) in Non-diabetic Populations: A Systematic Review and Meta-analysis. Sports Med. 2018 May;48(5):1151–64. doi: 10.1007/s40279-018-0861-0. PMID: 29453742. Exclusion Code: X8.29453742
388 Cederberg H, Stancakova A, Yaluri N, . Increased risk of diabetes with statin treatment is associated with impaired insulin sensitivity and insulin secretion: a 6 year follow-up study of the METSIM cohort. Diabetologia. 2015 May;58(5):1109–17. doi: 10.1007/s00125-015-3528-5. PMID: 25754552. Exclusion Code: X4.25754552
389 Cefalu WT, Bell-Farrow A, Wang ZQ, . Effect of glipizide GITS on insulin sensitivity, glycemic indices, and abdominal fat composition in NIDDM. Drug development research. 1998;44(1):1–7. doi: 10.1002/(SICI)1098-2299(199805)44:1<1::AID-DDR1>3.0.CO. PMID: CN-01767801. Exclusion Code: X6.
390 Ceriello A, Esposito K, Sala L, . The protective effect of the Mediterranean diet on endothelial resistance to GLP-1 in type 2 diabetes: a preliminary report. Cardiovasc Diabetol. 2014;13:140. doi: 10.1186/s12933-014-0140-9. PMID: CN-01089862. Exclusion Code: X2.25407792
391 Cezaretto A, Barros CR, Almeida-Pititto B, . Lifestyle intervention using the psychoeducational approach is associated with greater cardiometabolic benefits and retention of individuals with worse health status. Arch Endocrinol Metab. 2017 Jan-Feb;61(1):36–44. doi: 10.1590/2359-3997000000185. PMID: 28273202. Exclusion Code: X11.28273202
392 Cezaretto A, Ferreira SR, Sharma S, . Impact of lifestyle interventions on depressive symptoms in individuals at-risk of, or with, type 2 diabetes mellitus: A systematic review and meta-analysis of randomized controlled trials. Nutr Metab Cardiovasc Dis. 2016 Aug;26(8):649–62. doi: 10.1016/j.numecd.2016.04.009. PMID: 27266986. Exclusion Code: X8.27266986
393 Cezaretto A, Pakseresht M, Sharma S, . Influence of depression on cardiometabolic responses to a lifestyle intervention in at-risk individuals. J Affect Disord. 2015 Mar 15;174:516–21. doi: 10.1016/j.jad.2014.12.037. PMID: 25554997. Exclusion Code: X5.25554997
394 Cha SA, Lim SY, Kim KR, . Community-based randomized controlled trial of diabetes prevention study for high-risk individuals of type 2 diabetes: lifestyle intervention using web-based system. BMC Public Health. 2017 May 5;17(1):387. doi: 10.1186/s12889-017-4283-y. PMID: 28476101. Exclusion Code: X6.28476101
395 Chai S, Yao B, Xu L, . The effect of diabetes self-management education on psychological status and blood glucose in newly diagnosed patients with diabetes type 2. Patient Educ Couns. 2018 Aug;101(8):1427–32. doi: 10.1016/j.pec.2018.03.020. PMID: 29622281. Exclusion Code: X5.29622281
396 Chalermsri C, Paisansudhi S, Kantachuvesiri P, . The effectiveness of holistic diabetic management between Siriraj Continuity of Care clinic and medical out-patient department. J Med Assoc Thai. 2014 Mar;97 Suppl 3:S197–205. PMID: 24772599. Exclusion Code: X8.24772599
397 Chalmers J, Arima H, Woodward M, . Effects of combination of perindopril, indapamide, and calcium channel blockers in patients with type 2 diabetes mellitus: results from the Action In Diabetes and Vascular Disease: Preterax and Diamicron Controlled Evaluation (ADVANCE) trial. Hypertension. 2014 Feb;63(2):259–64. doi: 10.1161/hypertensionaha.113.02252. PMID: 24324048. Exclusion Code: X2.24324048
398 Chamany S, Walker EA, Schechter CB, . Telephone intervention to improve diabetes control: a randomized trial in the New York City A1c Registry. Am J Prev Med. 2015 Dec;49(6):832–41. doi: 10.1016/j.amepre.2015.04.016. PMID: 26232903. Exclusion Code: X2.26232903
399 Chamarthi B, Ezrokhi M, Rutty D, . Impact of bromocriptine-QR therapy on cardiovascular outcomes in type 2 diabetes mellitus subjects on metformin. Postgrad Med. 2016 Nov;128(8):761–9. doi: 10.1080/00325481.2016.1243003. PMID: 27687032. Exclusion Code: X2.27687032
400 Chamberlain C, O’Mara-Eves A, Porter J, . Psychosocial interventions for supporting women to stop smoking in pregnancy. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
401 Chamukuttan S, Ram J, Nanditha A, . Baseline level of 30-min plasma glucose is an independent predictor of incident diabetes among Asian Indians: analysis of two diabetes prevention programmes. Diabetes Metab Res Rev. 2016;32(7):762–7. doi: 10.1002/dmrr.2799. PMID: CN-01414360. Exclusion Code: X8.26991329
402 Chan J, Sui Y, Oldenburg B, . Effects of telephone-based peer support in patients with type 2 diabetes mellitus receiving integrated care: a randomized clinical trial. JAMA internal medicine. 2014;174(6):972–81. doi: 10.1001/jamainternmed.2014.655. PMID: CN-00996305. Exclusion Code: X2.24781960
403 Chan SP, Colagiuri S. Systematic review and meta-analysis of the efficacy and hypoglycemic safety of gliclazide versus other insulinotropic agents. Diabetes Res Clin Pract. 2015 Oct;110(1):75–81. doi: 10.1016/j.diabres.2015.07.002. PMID: 26361859. Exclusion Code: X8.26361859
404 Chang CC, Chen YT, Hsu CY, . Dipeptidyl peptidase-4 inhibitors, peripheral arterial disease, and lower extremity amputation risk in diabetic patients. Am J Med. 2017 Mar;130(3):348–55. doi: 10.1016/j.amjmed.2016.10.016. PMID: 27884648. Exclusion Code: X2.27884648
405 Chang CH, Chang YC, Lin JW, . Cardiovascular risk associated with acarbose versus metformin as the first-line treatment in patients with type 2 diabetes: a nationwide cohort study. J Clin Endocrinol Metab. 2015 Mar;100(3):1121–9. doi: 10.1210/jc.2014-2443. PMID: 25555040. Exclusion Code: X5.25555040
406 Chang CH, Lin JW, Chen ST, . Dipeptidyl peptidase-4 inhibitor use is not associated with acute pancreatitis in high-risk type 2 diabetic patients: a nationwide cohort study. Medicine (Baltimore). 2016 Feb;95(7):e2603. doi: 10.1097/md.0000000000002603. PMID: 26886601. Exclusion Code: X2.26886601
407 Chang CH, Sakaguchi M, Dolin P. Epidemiology of lactic acidosis in type 2 diabetes patients with metformin in Japan. Pharmacoepidemiol Drug Saf. 2016 Oct;25(10):1196–203. doi: 10.1002/pds.4030. PMID: 27221971. Exclusion Code: X5.27221971
408 Chang HY, Hsieh CF, Singh S, . Anti-diabetic therapies and the risk of acute pancreatitis: a nationwide retrospective cohort study from Taiwan. Pharmacoepidemiol Drug Saf. 2015 Jun;24(6):567–75. doi: 10.1002/pds.3770. PMID: 25851403. Exclusion Code: X8.25851403
409 Chang HY, Wahlqvist ML, Liu WL, . Management trajectories in the type 2 diabetes integrated delivery system project in Taiwan: accounting for behavioral therapy, nutrition education and therapeutics. Asia Pac J Clin Nutr. 2014;23(4):592–606. doi: 10.6133/apjcn.2014.23.4.06. PMID: 25516317. Exclusion Code: X2.25516317
410 Chang PY, Chien LN, Lin YF, . Nonadherence of oral antihyperglycemic medication will increase risk of end-stage renal disease. Medicine (Baltimore). 2015 Nov;94(47):e2051. doi: 10.1097/md.0000000000002051. PMID: 26632708. Exclusion Code: X4.26632708
411 Chang SH, Wu LS, Lee CH, . Simvastatin-ezetimibe combination therapy is associated with a lower rate of major adverse cardiac events in type 2 diabetics than high potency statins alone: A population-based dynamic cohort study. Int J Cardiol. 2015;190:20–5. doi: 10.1016/j.ijcard.2015.04.121. PMID: 25912112. Exclusion Code: X8.25912112
412 Chang YC, Chuang LM, Lin JW, . Cardiovascular risks associated with second-line oral antidiabetic agents added to metformin in patients with Type 2 diabetes: a nationwide cohort study. Diabet Med. 2015 Nov;32(11):1460–9. doi: 10.1111/dme.12800. PMID: 25970814. Exclusion Code: X5.25970814
413 Chao J, Yang L, Xu H, . The effect of integrated health management model on the health of older adults with diabetes in a randomized controlled trial. Arch Gerontol Geriatr. 2015 Jan-Feb;60(1):82–8. doi: 10.1016/j.archger.2014.10.006. PMID: 25456892. Exclusion Code: X2.25456892
414 Chao YH, Usher K, Buettner PG, . Cluster randomised controlled trial: educational self-care intervention with older Taiwanese patients with type 2 diabetes mellitus--impact on blood glucose levels and diabetic complications. Collegian. 2014;21(1):43–51. PMID: 24772989. Exclusion Code: X6.24772989
415 Chapman LE, Darling AL, Brown JE. Association between metformin and vitamin B12 deficiency in patients with type 2 diabetes: a systematic review and meta-analysis. Diabetes Metab. 2016 Nov;42(5):316–27. doi: 10.1016/j.diabet.2016.03.008. PMID: 27130885. Exclusion Code: X8.27130885
416 Charbonnel B, Bertolini M, Tinahones FJ, . Lixisenatide plus basal insulin in patients with type 2 diabetes mellitus: a meta-analysis. J Diabetes Complications. 2014 Nov-Dec;28(6):880–6. doi: 10.1016/j.jdiacomp.2014.07.007. PMID: 25130920. Exclusion Code: X8.25130920
417 Chaudhari P, Zhou Z, Yang H, . Real-world treatment for diabetic nephropathy (DN) in patients with type 2 diabetes mellitus (T2DM). Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A603. doi: 10.2337/db16-2367-2454. PMID: CN-01449824. Exclusion Code: X5.
418 Chen CB, Eurich DT, Majumdar SR, . Metformin and the risk of prostate cancer across racial/ethnic groups: a population-based cohort study. Prostate Cancer Prostatic Dis. 2017 Mar;20(1):122–6. doi: 10.1038/pcan.2016.65. PMID: 28071672. Exclusion Code: X8.28071672
419 Chen DY, Wang SH, Mao CT, . Sitagliptin after ischemic stroke in type 2 diabetic patients: A nationwide cohort study. Medicine (Baltimore). 2015 Jul;94(28):e1128. doi: 10.1097/md.0000000000001128. PMID: 26181549. Exclusion Code: X2.26181549
420 Chen HH, Horng MH, Yeh SY, . Glycemic control with thiazolidinedione is associated with fracture of T2DM patients. PLoS One. 2015;10(8):e0135530. doi: 10.1371/journal.pone.0135530. PMID: 26317995. Exclusion Code: X2.26317995
421 Chen HH, Lin CL, Yeh SY, . Short-term dipeptidyl peptidase-4 inhibitor use increases the risk of herpes zoster infection in Asian patients with diabetes. Qjm. 2016 Feb;109(2):91–5. doi: 10.1093/qjmed/hcv096. PMID: 25991869. Exclusion Code: X5.25991869
422 Chen HH, Lin MC, Muo CH, . Combination therapy of metformin and statin may decrease hepatocellular carcinoma among diabetic patients in Asia. Medicine (Baltimore). 2015 Jun;94(24):e1013. doi: 10.1097/md.0000000000001013. PMID: 26091447. Exclusion Code: X8.26091447
423 Chen HY, Yang FY, Jong GP, . Antihyperglycemic drugs use and new-onset atrial fibrillation in elderly patients. Eur J Clin Invest. 2017 May;47(5):388–93. doi: 10.1111/eci.12754. PMID: 28369870. Exclusion Code: X2.28369870
424 Chen JH, Ou HT, Lin TC, . Pharmaceutical care of elderly patients with poorly controlled type 2 diabetes mellitus: a randomized controlled trial. Int J Clin Pharm. 2016 Feb;38(1):88–95. doi: 10.1007/s11096-015-0210-4. PMID: 26499503. Exclusion Code: X4.26499503
425 Chen JM, Chang CW, Chang TH, . Effects of statins on incident dementia in patients with type 2 DM: a population-based retrospective cohort study in Taiwan. PLoS One. 2014;9(2):e88434. doi: 10.1371/journal.pone.0088434. PMID: 24520388. Exclusion Code: X8.24520388
426 Chen K, Kang D, Yu M, . Direct head-to-head comparison of glycaemic durability of dipeptidyl peptidase-4 inhibitors and sulphonylureas in patients with type 2 diabetes mellitus: A meta-analysis of long-term randomized controlled trials. Diabetes Obes Metab. 2018 Apr;20(4):1029–33. doi: 10.1111/dom.13147. PMID: 29095568. Exclusion Code: X8.29095568
427 Chen L, Chubak J, Boudreau DM, . Diabetes treatments and risks of adverse breast cancer outcomes among early-stage breast cancer patients: a SEER-Medicare analysis. Cancer Res. 2017 Nov 1;77(21):6033–41. doi: 10.1158/0008-5472.can-17-0687. PMID: 28935814. Exclusion Code: X2.28935814
428 Chen LY, Bigger JT, Hickey KT, . Effect of Intensive Blood Pressure Lowering on Incident Atrial Fibrillation and P-Wave Indices in the ACCORD Blood Pressure Trial. Am J Hypertens. 2016;29(11):1276–82. doi: 10.1093/ajh/hpv172. PMID: CN-01914312. Exclusion Code: X2.26476086
429 Chen M, Sun Q, Giovannucci E, . Dairy consumption and risk of type 2 diabetes: 3 cohorts of US adults and an updated meta-analysis. BMC Med. 2014 Nov 25;12:215. doi: 10.1186/s12916-014-0215-1. PMID: 25420418. Exclusion Code: X8.25420418
430 Chen M, Xie CG, Gao H, . Comparative effectiveness of sodium-glucose co-transporter 2 inhibitors for controlling hyperglycaemia in patients with type 2 diabetes: protocol for a systematic review and network meta-analysis. BMJ Open. 2016 Jan 29;6(1):e010252. doi: 10.1136/bmjopen-2015-010252. PMID: 26826156. Exclusion Code: X8.26826156
431 Chen M, Zhao X, Zhang Q, . Effects of different metformin treatment dose for 6 months on rectal aberrant crypt foci in patients with newly diagnosed type 2 diabetes. Diabetes/metabolism research and reviews. Conference: 21st scientific meeting of the chinese diabetes society. China. 2017;33(Supplement 1) (no pagination)doi: 10.1002/dmrr.2948. PMID: CN-01431760. Exclusion Code: X6.
432 Chen MF, Hung SL, Chen SL. Empowerment program for people with prediabetes: a randomized controlled trial. J Nurs Res. 2017 Apr;25(2):99–111. doi: 10.1097/jnr.0000000000000193. PMID: 28277390. Exclusion Code: X5.28277390
433 Chen MJ, Tsan YT, Liou JM, . Statins and the risk of pancreatic cancer in Type 2 diabetic patients--a population-based cohort study. Int J Cancer. 2016 Feb 1;138(3):594–603. doi: 10.1002/ijc.29813. PMID: 26296262. Exclusion Code: X2.26296262
434 Chen X, Lv X, Yang G, . Polyethylene glycol loxenatide injections added to metformin effectively improve glycemic control and exhibit favorable safety in type 2 diabetic patients. J Diabetes. 2017 Feb;9(2):158–67. doi: 10.1111/1753-0407.12397. PMID: 26989888. Exclusion Code: X2.26989888
435 Chen Y, Ning G, Wang C, . Efficacy and safety of linagliptin monotherapy in Asian patients with inadequately controlled type 2 diabetes mellitus: a multinational, 24-week, randomized, clinical trial. Journal of diabetes investigation. 2015;6(6):692–8. doi: 10.1111/jdi.12346. PMID: CN-01105613. Exclusion Code: X2.26543544
436 Chen YH, Du L, Geng XY, . Effects of sulfonylureas on lipids in type 2 diabetes mellitus: a meta-analysis of randomized controlled trials. J Evid Based Med. 2015 Aug;8(3):134–48. doi: 10.1111/jebm.12157. PMID: 26066789. Exclusion Code: X8.26066789
437 Chen YJ, Li LJ, Tang WL, . First-line drugs inhibiting the renin angiotensin system versus other first-line antihypertensive drug classes for hypertension. Cochrane Database of Systematic Reviews. 2018(11)doi: 10.1002/14651858.CD008170.pub3. PMID: CD008170. Exclusion Code: X8.
438 Cheng Q, Yang S, Zhao C, . Efficacy of metformin-based oral antidiabetic drugs is not inferior to insulin glargine in newly diagnosed type 2 diabetic patients with severe hyperglycemia after short-term intensive insulin therapy. J Diabetes. 2015 Mar;7(2):182–91. doi: 10.1111/1753-0407.12167. PMID: 24823280. Exclusion Code: X5.24823280
439 Cheng S, Ge J, Zhao C, . Effects of aerobic exercise and diet intervention on glycaemic control and liver fat content in men and women aged 50-65 years with prediabetes and non-alcoholic fatty liver disease: a multicentre, randomised controlled trial. The lancet diabetes and endocrinology. Conference: 2016 chinese diabetes society meeting. China. 2016;4(Spec. issue 3):S7. doi: 10.1016/S2213-8587%2816%2930362-X. PMID: CN-01421516. Exclusion Code: X6.
440 Cheng YY, Leu HB, Chen TJ, . Metformin-inclusive therapy reduces the risk of stroke in patients with diabetes: a 4-year follow-up study. J Stroke Cerebrovasc Dis. 2014 Feb;23(2):e99–105. doi: 10.1016/j.jstrokecerebrovasdis.2013.09.001. PMID: 24119365. Exclusion Code: X8.24119365
441 Cherrington AL, Agne AA, Lampkin Y, . Diabetes Connect: developing a mobile health intervention to link diabetes community health workers with primary care. J Ambul Care Manage. 2015 Oct-Dec;38(4):333–45. doi: 10.1097/jac.0000000000000110. PMID: 26353025. Exclusion Code: X6.26353025
442 Chew EY, Davis MD, Danis RP, . The effects of medical management on the progression of diabetic retinopathy in persons with type 2 diabetes: the Action to Control Cardiovascular Risk in Diabetes (ACCORD) Eye Study. Ophthalmology. 2014 Dec;121(12):2443–51. doi: 10.1016/j.ophtha.2014.07.019. PMID: 25172198. Exclusion Code: X2.25172198
443 Chiang JI, Furler J, Mair FS, . Impact of multimorbidity count on all-cause mortality and glycaemic outcomes in people with type 2 diabetes: a systematic review protocol. BMJ Open. 2018 Apr 5;8(4):e021100. doi: 10.1136/bmjopen-2017-021100. PMID: 29626050. Exclusion Code: X8.29626050
444 Chin HJ, Nam JH, Lee EK, . Comparative safety for cardiovascular outcomes of DPP-4 inhibitors versus glimepiride in patients with type 2 diabetes: A retrospective cohort study. Medicine (Baltimore). 2017 Jun;96(25):e7213. doi: 10.1097/md.0000000000007213. PMID: 28640111. Exclusion Code: X8.28640111
445 Cho YK, Kim YJ, Kang YM, . Comparison between sodium-glucose cotransporter 2 inhibitors and pioglitazone as additions to insulin therapy in type 2 diabetes patients: A systematic review with an indirect comparison meta-analysis. J Diabetes Investig. 2018 Jul;9(4):882–92. doi: 10.1111/jdi.12787. PMID: 29215196. Exclusion Code: X8.29215196
446 Choi HJ, Park C, Lee YK, . Risk of fractures and diabetes medications: a nationwide cohort study. Osteoporos Int. 2016 Sep;27(9):2709–15. doi: 10.1007/s00198-016-3595-6. PMID: 27080708. Exclusion Code: X8.27080708
447 Choi SH, Lim S, Hong ES, . PROPIT: A PROspective comparative clinical study evaluating the efficacy and safety of PITavastatin in patients with metabolic syndrome. Clin Endocrinol (Oxf). 2015 May;82(5):670–7. doi: 10.1111/cen.12580. PMID: 25109606. Exclusion Code: X2.25109606
448 Chon S, Rhee S, Ahn K, . Long-term effects on glycaemic control and beta-cell preservation of early intensive treatment in patients with newly diagnosed type 2 diabetes: a multicentre randomized trial. Diabetes, obesity & metabolism. 2018;(no pagination)doi: 10.1111/dom.13196. PMID: CN-01449523. Exclusion Code: X5.
449 Chon S, Rhee SY, Ahn KJ, . Long-term effects on glycaemic control and β-cell preservation of early intensive treatment in patients with newly diagnosed type 2 diabetes: a multicentre randomized trial. Diabetes, obesity & metabolism. 2018;20(5):1121–30. doi: 10.1111/dom.13196. PMID: CN-01704096. Exclusion Code: X5.
450 Chou HC, Chen WW, Hsiao FY. Acute pancreatitis in patients with type 2 diabetes mellitus treated with dipeptidyl peptidase-4 inhibitors: a population-based nested case-control study. Drug Saf. 2014 Jul;37(7):521–8. doi: 10.1007/s40264-014-0171-x. PMID: 24859164. Exclusion Code: X2.24859164
451 Chou PS, Ho BL, Yang YH. Effects of pioglitazone on the incidence of dementia in patients with diabetes. J Diabetes Complications. 2017 Jun;31(6):1053–7. doi: 10.1016/j.jdiacomp.2017.01.006. PMID: 28254448. Exclusion Code: X8.28254448
452 Chow E, Hassali M, Saleem F, . Effects of pharmacist-led patient education on diabetes-related knowledge and medication adherence: a home-based study. Health education journal. 2015;75(4):421–33. doi: 10.1177/0017896915597021. PMID: CN-01167380. Exclusion Code: X2.
453 Chow W, Buysman E, Rupnow MF, . Canagliflozin treatment of Hispanic and non-Hispanic patients with type 2 diabetes in a US managed care setting. Curr Med Res Opin. 2016;32(1):13–22. doi: 10.1185/03007995.2015.1100598. PMID: 26414434. Exclusion Code: X6.26414434
454 Christensen P, Meinert Larsen T, Westerterp-Plantenga M, . Men and women respond differently to rapid weight loss: Metabolic outcomes of a multi-centre intervention study after a low-energy diet in 2500 overweight, individuals with pre-diabetes (PREVIEW). Diabetes Obes Metab. 2018 Dec;20(12):2840–51. doi: 10.1111/dom.13466. PMID: 30088336. Exclusion Code: X4.30088336
455 Chrvala CA, Sherr D, Lipman RD. Diabetes self-management education for adults with type 2 diabetes mellitus: a systematic review of the effect on glycemic control. Patient Educ Couns. 2016 Jun;99(6):926–43. doi: 10.1016/j.pec.2015.11.003. PMID: 26658704. Exclusion Code: X8.26658704
456 Chuang LH, Verheggen BG, Charokopou M, . Cost-effectiveness analysis of exenatide once-weekly versus dulaglutide, liraglutide, and lixisenatide for the treatment of type 2 diabetes mellitus: an analysis from the UK NHS perspective. J Med Econ. 2016 Dec;19(12):1127–34. doi: 10.1080/13696998.2016.1203329. PMID: 27310712. Exclusion Code: X8.27310712
457 Chung C, Bryant A, Brown PD. Interventions for the treatment of brain radionecrosis after radiotherapy or radiosurgery. Cochrane Database of Systematic Reviews. 2018(7)doi: 10.1002/14651858.CD011492.pub2. PMID: CD011492. Exclusion Code: X8.
458 Chung W, Chua S, Lai P, . Effects of a pharmaceutical care model on medication adherence and glycemic control of people with type 2 diabetes. Patient preference and adherence. 2014;8:1185–94. doi: 10.2147/PPA.S66619. PMID: CN-01103196. Exclusion Code: X2.25214772
459 Chung YR, Park SW, Choi SY, . Association of statin use and hypertriglyceridemia with diabetic macular edema in patients with type 2 diabetes and diabetic retinopathy. Cardiovasc Diabetol. 2017 Jan 7;16(1):4. doi: 10.1186/s12933-016-0486-2. PMID: 28061854. Exclusion Code: X2.28061854
460 Chung YR, Park SW, Kim JW, . Protective effects of dipeptidyl peptidase-4 inhibitors on progression of diabetic retinopathy in patients with type 2 diabetes. Retina. 2016 Dec;36(12):2357–63. doi: 10.1097/iae.0000000000001098. PMID: 27285457. Exclusion Code: X8.27285457
461 Cichosz SL, Johansen MD, Knudsen ST, . A classification model for predicting eye disease in newly diagnosed people with type 2 diabetes. Diabetes Res Clin Pract. 2015 May;108(2):210–5. doi: 10.1016/j.diabres.2015.02.020. PMID: 25765665. Exclusion Code: X8.25765665
462 Cigrovski Berkovic M, Herman Mahecic D, Gradiser M, . Impact of health policy and practice on finding the best fit for patients with type 2 diabetes after metformin failure: Croatian pilot study. Prim Care Diabetes. 2017 Jun;11(3):265–72. doi: 10.1016/j.pcd.2017.02.004. PMID: 28314484. Exclusion Code: X5.28314484
463 Cinar AB, Oktay I, Schou L. “Smile healthy to your diabetes”: health coaching-based intervention for oral health and diabetes management. Clin Oral Investig. 2014 Sep;18(7):1793–801. doi: 10.1007/s00784-013-1165-2. PMID: 24362589. Exclusion Code: X5.24362589
464 Cinar AB, Schou L. Impact of empowerment on toothbrushing and diabetes management. Oral Health Prev Dent. 2014;12(4):337–44. doi: 10.3290/j.ohpd.a32130. PMID: 24914427. Exclusion Code: X4.24914427
465 Cinar AB, Schou L. The role of self-efficacy in health coaching and health education for patients with type 2 diabetes. Int Dent J. 2014 Jun;64(3):155–63. doi: 10.1111/idj.12093. PMID: 24571189. Exclusion Code: X6.24571189
466 Cioffi CE, Ranjani H, Staimez LR, . Self-efficacy and diabetes prevention in overweight South Asians with pre-diabetes. BMJ open diabetes research and care. 2018;6(1) (no pagination)doi: 10.1136/bmjdrc-2018-000561. PMID: CN-01649732. Exclusion Code: X6.
467 Clar C, Al-Khudairy L, Loveman E, . Low glycaemic index diets for the prevention of cardiovascular disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
468 Claussen A, Moller JB, Kristensen NR, . Impact of demographics and disease progression on the relationship between glucose and HbA1c. Eur J Pharm Sci. 2017 Jun 15;104:417–23. doi: 10.1016/j.ejps.2017.04.006. PMID: 28412484. Exclusion Code: X8.28412484
469 Clegg LE, Heerspink HJL, Penland RC, . Reduction of Cardiovascular Risk and Improved Estimated Glomerular Filtration Rate by SGLT2 Inhibitors, Including Dapagliflozin, Is Consistent Across the Class: An Analysis of the Placebo Arm of EXSCEL. Diabetes Care. 2019 Feb;42(2):318–26. doi: 10.2337/dc18-1871. PMID: 30523029. Exclusion Code: X8.30523029
470 Clemens KK, McArthur E, Dixon SN, . The hypoglycemic risk of glyburide (glibenclamide) compared with modified-release gliclazide. Can J Diabetes. 2015 Aug;39(4):308–16. doi: 10.1016/j.jcjd.2015.01.001. PMID: 25840942. Exclusion Code: X5.25840942
471 Cloostermans L, Wendel-Vos W, Doornbos G, . Independent and combined effects of physical activity and body mass index on the development of Type 2 Diabetes - a meta-analysis of 9 prospective cohort studies. Int J Behav Nutr Phys Act. 2015 Dec 1;12:147. doi: 10.1186/s12966-015-0304-3. PMID: 26619831. Exclusion Code: X8.26619831
472 Cobitz A, Zambanini A, Sowell M, . A retrospective evaluation of congestive heart failure and myocardial ischemia events in 14237 patients with type 2 diabetes mellitus enrolled in 42 short-term, double-blind, randomized clinical studies with rosiglitazone. Pharmacoepidemiol Drug Saf. 2008;17(8):769–81. doi: 10.1002/pds.1615. PMID: CN-01786791. Exclusion Code: X8.18613278
473 Coca SG, Ismail-Beigi F, Haq N, . Role of intensive glucose control in development of renal end points in type 2 diabetes mellitus: systematic review and meta-analysis intensive glucose control in type 2 diabetes. Arch Intern Med. 2012 May 28;172(10):761–9. doi: 10.1001/archinternmed.2011.2230. PMID: 22636820. Exclusion Code: X8.22636820
474 Coleman T, Chamberlain C, Davey M-A, . Pharmacological interventions for promoting smoking cessation during pregnancy. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
475 Coles LT, Fletcher EA, Galbraith CE, . Patient freedom to choose a weight loss diet in the treatment of overweight and obesity: a randomized dietary intervention in type 2 diabetes and pre-diabetes. Int J Behav Nutr Phys Act. 2014 May 16;11:64. doi: 10.1186/1479-5868-11-64. PMID: 24886191. Exclusion Code: X6.24886191
476 Colhoun H, Ginsberg H, Robinson J, . No effect of PCSK9 inhibitor alirocumab on the incidence of diabetes in a pooled analysis from 10 ODYSSEY Phase 3 studies. Eur Heart J. 2016;37(39):2981–9. doi: 10.1093/eurheartj/ehw292. PMID: CN-01243782. Exclusion Code: X8.27460890
477 Collard D, Brouwer TF, Peters RJG, . Creatinine Rise During Blood Pressure Therapy and the Risk of Adverse Clinical Outcomes in Patients With Type 2 Diabetes Mellitus. Hypertension. 2018 Dec;72(6):1337–44. doi: 10.1161/hypertensionaha.118.11944. PMID: 30571235. Exclusion Code: X2.30571235
478 Collins J, Ryan L, Truby H. A systematic review of the factors associated with interest in predictive genetic testing for obesity, type II diabetes and heart disease. J Hum Nutr Diet. 2014 Oct;27(5):479–88. doi: 10.1111/jhn.12179. PMID: 24236642. Exclusion Code: X8.24236642
479 Colunga-Lozano LE, Gonzalez Torres FJ, Delgado-Figueroa N, . Sliding scale insulin for non-critically ill hospitalised adults with diabetes mellitus. Cochrane Database Syst Rev. 2018 Nov 29;11:Cd011296. doi: 10.1002/14651858.CD011296.pub2. PMID: 30488948. Exclusion Code: X8.30488948
480 Colunga-Lozano LE, Gonzalez Torres FJ, Delgado-Figueroa N, . Sliding scale insulin for non-critically ill hospitalised adults with diabetes mellitus. Cochrane Database of Systematic Reviews. 2018(11)doi: 10.1002/14651858.CD011296.pub2. PMID: CD011296. Exclusion Code: X8.
481 Connelly PJ, Lonergan M, Soto-Pedre E, . Acute kidney injury, plasma lactate concentrations and lactic acidosis in metformin users: A GoDarts study. Diabetes Obes Metab. 2017 Nov;19(11):1579–86. doi: 10.1111/dom.12978. PMID: 28432751. Exclusion Code: X2.28432751
482 Cook W, Minervini G, Bryzinski B, . Saxagliptin efficacy and safety in patients with type 2 diabetes mellitus stratified by cardiovascular disease history and cardiovascular risk factors: analysis of 3 clinical trials. Postgrad Med. 2014 Oct;126(6):19–32. doi: 10.3810/pgm.2014.10.2818. PMID: 25414932. Exclusion Code: X8.25414932
483 Cooper AJ, Westgate K, Brage S, . Sleep duration and cardiometabolic risk factors among individuals with type 2 diabetes. Sleep Med. 2015 Jan;16(1):119–25. doi: 10.1016/j.sleep.2014.10.006. PMID: 25439076. Exclusion Code: X5.25439076
484 Cooper LB, Mi X, Mentz RJ, . Management of newly treated diabetes in Medicare beneficiaries with and without heart failure. Clin Cardiol. 2017 Jan;40(1):38–45. doi: 10.1002/clc.22603. PMID: 27783884. Exclusion Code: X5.27783884
485 Cooper ME, Perkovic V, McGill JB, . Kidney disease end points in a pooled analysis of individual patient-level data from a large clinical trials program of the dipeptidyl peptidase 4 inhibitor linagliptin in type 2 diabetes. Am J Kidney Dis. 2015 Sep;66(3):441–9. doi: 10.1053/j.ajkd.2015.03.024. PMID: 25960304. Exclusion Code: X8.25960304
486 Coppell KJ, Abel SL, Freer T, . The effectiveness of a primary care nursing-led dietary intervention for prediabetes: a mixed methods pilot study. BMC Fam Pract. 2017;18(1):106. doi: 10.1186/s12875-017-0671-8. PMID: CN-01621604. Exclusion Code: X8.29268719
487 Coppolino G, Pisano A, Rivoli L, . Renal denervation for resistant hypertension. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
488 Corley B, Carroll R, Hall R, . Intermittent fasting in Type 2 diabetes mellitus and the risk of hypoglycaemia: a randomized controlled trial. Diabetic medicine. 2018;35(5):588–94. doi: 10.1111/dme.13595. PMID: CN-01568708. Exclusion Code: X2.29405359
489 Cornel JH, Bakris GL, Stevens SR, . Effect of sitagliptin on kidney function and respective cardiovascular outcomes in type 2 diabetes: outcomes from TECOS. Diabetes Care. 2016 Dec;39(12):2304–10. doi: 10.2337/dc16-1415. PMID: 27742728. Exclusion Code: X2.27742728
490 Cornelis MC, Chiuve SE, Glymour MM, . Bachelors, divorcees, and widowers: does marriage protect men from type 2 diabetes? PLoS One. 2014;9(9):e106720. doi: 10.1371/journal.pone.0106720. PMID: 25229473. Exclusion Code: X4.25229473
491 Cornell S. Review of empagliflozin monotherapy for previously untreated patients with type 2 diabetes mellitus: comparison with sitagliptin. Postgrad Med. 2015 Apr;127(3):277–81. doi: 10.1080/00325481.2015.1018798. PMID: 25724655. Exclusion Code: X8.25724655
492 Corrao G, Monzio Compagnoni M, Rea F, . Clinical significance of diabetes likely induced by statins: evidence from a large population-based cohort. Diabetes Res Clin Pract. 2017 Nov;133:60–8. doi: 10.1016/j.diabres.2017.08.008. PMID: 28892732. Exclusion Code: X8.28892732
493 Cortez DN, Macedo MM, Souza DA, . Evaluating the effectiveness of an empowerment program for self-care in type 2 diabetes: a cluster randomized trial. BMC Public Health. 2017 Jan 6;17(1):41. doi: 10.1186/s12889-016-3937-5. PMID: 28061840. Exclusion Code: X6.28061840
494 Cotter AP, Durant N, Agne AA, . Internet interventions to support lifestyle modification for diabetes management: a systematic review of the evidence. J Diabetes Complications. 2014 Mar-Apr;28(2):243–51. doi: 10.1016/j.jdiacomp.2013.07.003. PMID: 24332469. Exclusion Code: X8.24332469
495 Cox DJ, Taylor AG, Singh H, . Glycemic load, exercise, and monitoring blood glucose (GEM): a paradigm shift in the treatment of type 2 diabetes mellitus. Diabetes Res Clin Pract. 2016 Jan;111:28–35. doi: 10.1016/j.diabres.2015.10.021. PMID: 26556234. Exclusion Code: X2.26556234
496 Cradock KA, G OL, Finucane FM, . Behaviour change techniques targeting both diet and physical activity in type 2 diabetes: a systematic review and meta-analysis. Int J Behav Nutr Phys Act. 2017 Feb 8;14(1):18. doi: 10.1186/s12966-016-0436-0. PMID: 28178985. Exclusion Code: X8.28178985
497 Crandall J, Mather K, Rajpathak S, . Statin use and risk of developing diabetes: results from the diabetes prevention program. BMJ open diabetes research and care. 2017;5(1) (no pagination)doi: 10.1136/bmjdrc-2017-000438. PMID: CN-01420976. Exclusion Code: X5.
498 Crawford TJ, Crowther CA, Alsweiler J, . Antenatal dietary supplementation with myo-inositol in women during pregnancy for preventing gestational diabetes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
499 Cuevas HE, Brown SA, Garcia AA, . Blood glucose self-monitoring patterns in Mexican Americans: further lessons from the Starr County Border Health Initiative. Diabetes Technol Ther. 2015 Feb;17(2):105–11. doi: 10.1089/dia.2014.0147. PMID: 25291318. Exclusion Code: X6.25291318
500 Cuevas-Ramos D, Almeda-Valdés P, Meza-Arana CE, . Sitaglitpin phosphate treatment in patients with reactive hypoglycemia secondary to dysinsulinism. Controlled, randomized, double-blind study. Gac Med Mex. 2017;153(Supl. 2):S51–S9. doi: 10.24875/GMM.M17000007. PMID: CN-01704246. Exclusion Code: X1.29099829
501 Cui JY, Zhou RR, Han S, . Statin therapy on glycemic control in type 2 diabetic patients: A network meta-analysis. J Clin Pharm Ther. 2018 Aug;43(4):556–70. doi: 10.1111/jcpt.12690. PMID: 29733433. Exclusion Code: X8.29733433
502 Cummings DM, Lutes LD, Littlewood K, . EMPOWER: a randomized trial using community health workers to deliver a lifestyle intervention program in African American women with Type 2 diabetes: design, rationale, and baseline characteristics. Contemp Clin Trials. 2013;36(1):147–53. doi: 10.1016/j.cct.2013.06.006. PMID: CN-01705587. Exclusion Code: X2.23792133
503 Cummings DM, Lutes LD, Littlewood K, . Impact of Distress Reduction on Behavioral Correlates and A1C in African American Women with Uncontrolled Type 2 Diabetes: results from EMPOWER. Ethnicity & disease. 2017;27(2):155–60. doi: 10.18865/ed.27.2.155. PMID: CN-01955681. Exclusion Code: X2.28439186
504 Cunningham AT, Crittendon DR, White N, . The effect of diabetes self-management education on HbA1c and quality of life in African-Americans: a systematic review and meta-analysis. BMC Health Serv Res. 2018 May 16;18(1):367. doi: 10.1186/s12913-018-3186-7. PMID: 29769078. Exclusion Code: X8.29769078
505 Curioni C, André C. Rimonabant for overweight or obesity. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2006. Exclusion Code: X8.
506 Currie CJ, Holden SE, Jenkins-Jones S, . Impact of differing glucose-lowering regimens on the pattern of association between glucose control and survival. Diabetes Obes Metab. 2018 Apr;20(4):821–30. doi: 10.1111/dom.13155. PMID: 29119713. Exclusion Code: X5.29119713
507 Cusi K, Orsak B, Bril F, . Long-term pioglitazone treatment for patients with nonalcoholic steatohepatitis and prediabetes or type 2 diabetes mellitus: a randomized trial. Ann Intern Med. 2016 Sep 6;165(5):305–15. doi: 10.7326/m15-1774. PMID: 27322798. Exclusion Code: X2.27322798
508 Cusi K, Sanyal AJ, Zhang S, . Different effects of basal insulin peglispro and insulin glargine on liver enzymes and liver fat content in patients with type 1 and type 2 diabetes. Diabetes Obes Metab. 2016 Oct;18 Suppl 2:50–8. doi: 10.1111/dom.12751. PMID: 27723227. Exclusion Code: X2.27723227
509 Cusi K, Sattar N, Garcia-Perez LE, . Dulaglutide decreases plasma aminotransferases in people with Type 2 diabetes in a pattern consistent with liver fat reduction: a post hoc analysis of the AWARD programme. Diabet Med. 2018 Oct;35(10):1434–9. doi: 10.1111/dme.13697. PMID: 29869810. Exclusion Code: X6.29869810
510 Czech M, Rdzanek E, Paweska J, . Drug-related risk of severe hypoglycaemia in observational studies: a systematic review and meta-analysis. BMC Endocr Disord. 2015 Oct 12;15:57. doi: 10.1186/s12902-015-0052-z. PMID: 26458540. Exclusion Code: X8.26458540
511 Dabrowski M, Szymanska-Garbacz E, Miszczyszyn Z, . Risk factors for cancer development in type 2 diabetes: a retrospective case-control study. BMC Cancer. 2016 Oct 10;16(1):785. doi: 10.1186/s12885-016-2836-6. PMID: 27724912. Exclusion Code: X2.27724912
512 Dadgostar H, Firouzinezhad S, Ansari M, . Supervised group-exercise therapy versus home-based exercise therapy: their effects on quality of life and cardiovascular risk factors in women with type 2 diabetes. Diabetes Metab Syndr. 2016;10(2 Suppl 1):S30–6. doi: 10.1016/j.dsx.2016.01.016. PMID: CN-01264379. Exclusion Code: X2.
513 Dafoulas G, Mavrodi A, Gkiata P, . Long-term tele-monitoring of patients with type 2 diabetes mellitus: results of the Greek pilot of the renewing health multicentre randomised control trial. Diabetologia. 2014;57(1 suppl. 1):S405–s6. doi: 10.1007/s00125-014-3355-0. PMID: CN-01059121. Exclusion Code: X10.
514 Daido H, Horikawa Y, Takeda J. The effects of pitavastatin on glucose metabolism in patients with type 2 diabetes with hypercholesterolemia. Diabetes Res Clin Pract. 2014 Dec;106(3):531–7. doi: 10.1016/j.diabres.2014.09.048. PMID: 25458331. Exclusion Code: X6.25458331
515 Dallosso HM, Bodicoat DH, Campbell M, . Self-monitoring of blood glucose versus self-monitoring of urine glucose in adults with newly diagnosed Type 2 diabetes receiving structured education: a cluster randomized controlled trial. Diabet Med. 2015 Mar;32(3):414–22. doi: 10.1111/dme.12598. PMID: 25308625. Exclusion Code: X4.25308625
516 Dalsgaard EM, Vestergaard M, Skriver MV, . Socioeconomic position and cardiovascular risk factors among people with screen-detected Type 2 DM: six-year follow-up of the ADDITION-Denmark trial. Prim Care Diabetes. 2014 Dec;8(4):322–9. doi: 10.1016/j.pcd.2014.01.006. PMID: 24613817. Exclusion Code: X8.24613817
517 Dalsgaard EM, Vestergaard M, Skriver MV, . Psychological distress, cardiovascular complications and mortality among people with screen-detected type 2 diabetes: follow-up of the ADDITION-Denmark trial. Diabetologia. 2014 Apr;57(4):710–7. doi: 10.1007/s00125-014-3165-4. PMID: 24442448. Exclusion Code: X8.24442448
518 Dambha-Miller H, Cooper AJ, Simmons RK, . Patient-centred care, health behaviours and cardiovascular risk factor levels in people with recently diagnosed type 2 diabetes: 5-year follow-up of the ADDITION-Plus trial cohort. BMJ Open. 2016 Jan 6;6(1):e008931. doi: 10.1136/bmjopen-2015-008931. PMID: 26739725. Exclusion Code: X5.26739725
519 Dang S, Oropesa L, Byrne M, . Race/ethnic disparities in weight and glycemia in older adults receiving lifestyle interventions via peer-leaders with or without mobile enhancement for diabetes prevention and management. Journal of the american geriatrics society. 2014;62:S216. doi: 10.1111/jgs.12870. PMID: CN-01063945. Exclusion Code: X6.
520 Dasgupta K, Rosenberg E, Daskalopoulou S. Step Monitoring to improve ARTERial health (SMARTER) through step count prescription in type 2 diabetes and hypertension: trial design and methods. Cardiovasc Diabetol. 2014;13:7. doi: 10.1186/1475-2840-13-7. PMID: CN-00921778. Exclusion Code: X6.24393423
521 Dasgupta K, Rosenberg E, Joseph L, . Physician step prescription and monitoring to improve ARTERial health (SMARTER): a randomized controlled trial in patients with type 2 diabetes and hypertension. Diabetes Obes Metab. 2017 May;19(5):695–704. doi: 10.1111/dom.12874. PMID: 28074635. Exclusion Code: X6.28074635
522 Dauriz M, Targher G, Temporelli PL, . Prognostic impact of diabetes and prediabetes on survival outcomes in patients with chronic heart failure: a post-hoc analysis of the GISSI-HF (Gruppo Italiano per lo Studio della Sopravvivenza nella Insufficienza Cardiaca-Heart Failure) trial. J Am Heart Assoc. 2017 Jul 5;6(7)doi: 10.1161/jaha.116.005156. PMID: 28679559. Exclusion Code: X2.28679559
523 Davenport C, Mahmood WA, Forde H, . The effects of insulin and liraglutide on osteoprotegerin and vascular calcification in vitro and in patients with type 2 diabetes. Eur J Endocrinol. 2015 Jul;173(1):53–61. doi: 10.1530/eje-14-1137. PMID: 26036811. Exclusion Code: X5.26036811
524 Davidson JA, Jones-Leone A, Wilson TH, . Albiglutide efficacy and safety in the Latino/Hispanic subpopulation for the integrated phase III program. Postgrad Med. 2017 Nov;129(8):849–57. doi: 10.1080/00325481.2017.1387473. PMID: 29083275. Exclusion Code: X8.29083275
525 Davidson JA, Manghi FP, Yu M, . Efficacy and safety of dulaglutide in Hispanic/Latino patients with type 2 diabetes in the award clinical program. Endocr Pract. 2016 Dec;22(12):1406–14. doi: 10.4158/ep161337.or. PMID: 27540883. Exclusion Code: X2.27540883
526 Davies AK, McGale N, Humphries SE, . Effectiveness of a self-management intervention with personalised genetic and lifestyle-related risk information on coronary heart disease and diabetes-related risk in type 2 diabetes (CoRDia): study protocol for a randomised controlled trial. Trials. 2015 Dec 2;16:547. doi: 10.1186/s13063-015-1073-7. PMID: 26631181. Exclusion Code: X6.26631181
527 Davies M, Pieber TR, Hartoft-Nielsen ML, . Effect of oral semaglutide compared with placebo and subcutaneous semaglutide on glycemic control in patients with type 2 diabetes: a randomized clinical trial. Jama. 2017 Oct 17;318(15):1460–70. doi: 10.1001/jama.2017.14752. PMID: 29049653. Exclusion Code: X6.29049653
528 Davies MJ, Bain SC, Atkin SL, . Efficacy and safety of liraglutide versus placebo as add-on to glucose-lowering therapy in patients with type 2 diabetes and moderate renal impairment (LIRA-RENAL): a randomized clinical trial. Diabetes Care. 2016 Feb;39(2):222–30. doi: 10.2337/dc14-2883. PMID: 26681713. Exclusion Code: X2.26681713
529 Davies MJ, Bergenstal R, Bode B, . Efficacy of liraglutide for weight loss among patients with type 2 diabetes: The SCALE Diabetes Randomized Clinical Trial. Jama. 2015 Aug 18;314(7):687–99. doi: 10.1001/jama.2015.9676. PMID: 26284720. Exclusion Code: X2.26284720
530 Davis P, Yokoyama W. Cinnamon intake lowers fasting blood glucose: meta-analysis (Provisional abstract). Journal of Medicinal Food; 2011. p. 884–9. Exclusion Code: X8.
531 Davy BM, Winett RA, Savla J, . Resist diabetes: a randomized clinical trial for resistance training maintenance in adults with prediabetes. PLoS One. 2017;12(2):e0172610. doi: 10.1371/journal.pone.0172610. PMID: 28231265. Exclusion Code: X4.28231265
532 Dawes D, Ashe M, Campbell K, . Preventing diabetes in primary care: a feasibility cluster randomized trial. Canadian journal of diabetes. 2014;38:S59. PMID: CN-01098577. Exclusion Code: X10.
533 Dawes D, Ashe M, Campbell K, . Preventing diabetes in primary care: a feasibility cluster randomized trial. Can J Diabetes. 2015 Apr;39(2):111–6. doi: 10.1016/j.jcjd.2014.08.004. PMID: 25439501. Exclusion Code: X11.25439501
534 De Berardis G, Sacco M, Strippoli GF, . Aspirin for primary prevention of cardiovascular events in people with diabetes: meta-analysis of randomised controlled trials. BMJ. 2009 Nov 6;339:b4531. doi: 10.1136/bmj.b4531. PMID: 19897665. Exclusion Code: X8.19897665
535 de Boer SA, Heerspink HJL, Juarez Orozco LE, . Effect of linagliptin on pulse wave velocity in early type 2 diabetes: a randomized, double-blind, controlled 26-week trial (RELEASE). Diabetes Obes Metab. 2017 Aug;19(8):1147–54. doi: 10.1111/dom.12925. PMID: 28244635. Exclusion Code: X6.28244635
536 de Galan BE, Perkovic V, Ninomiya T, . Lowering blood pressure reduces renal events in type 2 diabetes. J Am Soc Nephrol. 2009 Apr;20(4):883–92. doi: 10.1681/ASN.2008070667. PMID: 19225038. Exclusion Code: X2.19225038
537 de Groot M, Marrero D, Mele L, . Depressive Symptoms, Antidepressant Medication Use, and Inflammatory Markers in the Diabetes Prevention Program. Psychosom Med. 2018 Feb/Mar;80(2):167–73. doi: 10.1097/psy.0000000000000535. PMID: 29016549. Exclusion Code: X6.29016549
538 de Jong RG, Burden AM, de Kort S, . No decreased risk of gastrointestinal cancers in users of metformin in The Netherlands; a time-varying analysis of metformin exposure. Cancer Prev Res (Phila). 2017 May;10(5):290–7. doi: 10.1158/1940-6207.capr-16-0277. PMID: 28274936. Exclusion Code: X5.28274936
539 de Kort S, Simons CC, van den Brandt PA, . Diabetes mellitus type 2 and subsite-specific colorectal cancer risk in men and women: results from the Netherlands Cohort Study on diet and cancer. Eur J Gastroenterol Hepatol. 2016 Aug;28(8):896–903. doi: 10.1097/meg.0000000000000626. PMID: 27097356. Exclusion Code: X2.27097356
540 de Kreutzenberg SV, Ceolotto G, Cattelan A, . Metformin improves putative longevity effectors in peripheral mononuclear cells from subjects with prediabetes. A randomized controlled trial. Nutr Metab Cardiovasc Dis. 2015 Jul;25(7):686–93. doi: 10.1016/j.numecd.2015.03.007. PMID: 25921843. Exclusion Code: X6.25921843
541 de Las Heras Gala T, Herder C, Rutters F, . Association of changes in inflammation with variation in glycaemia, insulin resistance and secretion based on the KORA study. Diabetes Metab Res Rev. 2018 Nov;34(8):e3063. doi: 10.1002/dmrr.3063. PMID: 30114727. Exclusion Code: X4.30114727
542 de Mello VD, Lindstrom J, Eriksson JG, . Markers of cholesterol metabolism as biomarkers in predicting diabetes in the Finnish Diabetes Prevention Study. Nutr Metab Cardiovasc Dis. 2015 Jul;25(7):635–42. doi: 10.1016/j.numecd.2015.03.012. PMID: 25921846. Exclusion Code: X3.25921846
543 de Ranitz-Greven WL, Beulens JW, Hoeks LB, . Patients with type 2 diabetes mellitus failing on oral agents and starting once daily insulin regimen; a small randomized study investigating effects of adding vildagliptin. BMC Res Notes. 2014 Aug 29;7:579. doi: 10.1186/1756-0500-7-579. PMID: 25175981. Exclusion Code: X2.25175981
544 de Simone G, Olsen MH, Wachtell K, . Clusters of metabolic risk factors predict cardiovascular events in hypertension with target-organ damage: the LIFE study. J Hum Hypertens. 2007;21(8):625–32. doi: 10.1038/sj.jhh.1002203. PMID: CN-01715606. Exclusion Code: X2.17476291
545 de Sousa Almeida M, de Araujo Goncalves P, Branco P, . Impact of renal sympathetic denervation on left ventricular structure and function at 1-year follow-up. PLoS One. 2016;11(3):e0149855. doi: 10.1371/journal.pone.0149855. PMID: 26934735. Exclusion Code: X4.26934735
546 de Sousa MV, Fukui R, Krustrup P, . Positive effects of football on fitness, lipid profile, and insulin resistance in Brazilian patients with type 2 diabetes. Scand J Med Sci Sports. 2014 Aug;24 Suppl 1:57–65. doi: 10.1111/sms.12258. PMID: 24944132. Exclusion Code: X2.24944132
547 de Souza CF, Dalzochio MB, Zucatti ATN, . Efficacy of an education course delivered to community health workers in diabetes control: a randomized clinical trial. Endocrine. 2017 Aug;57(2):280–6. doi: 10.1007/s12020-017-1352-z. PMID: 28646377. Exclusion Code: X6.28646377
548 de Vries FM, Denig P, Vegter S, . Does a cardiovascular event change adherence to statin treatment in patients with type 2 diabetes? A matched cohort design. Curr Med Res Opin. 2015 Apr;31(4):595–602. doi: 10.1185/03007995.2015.1011780. PMID: 25629791. Exclusion Code: X6.25629791
549 de Vries FM, Voorham J, Hak E, . Prescribing patterns, adherence and LDL-cholesterol response of type 2 diabetes patients initiating statin on low-dose versus standard-dose treatment: a descriptive study. Int J Clin Pract. 2016 Jun;70(6):482–92. doi: 10.1111/ijcp.12806. PMID: 27125890. Exclusion Code: X6.27125890
550 de Wit HM, Vervoort GM, Jansen HJ, . Durable efficacy of liraglutide in patients with type 2 diabetes and pronounced insulin-associated weight gain: 52-week results from the Effect of Liraglutide on insulin-associated wEight GAiN in patients with Type 2 diabetes’ (ELEGANT) randomized controlled trial. J Intern Med. 2016 Mar;279(3):283–92. doi: 10.1111/joim.12447. PMID: 26553486. Exclusion Code: X2.26553486
551 de Wit HM, Vervoort GM, Jansen HJ, . Liraglutide reverses pronounced insulin-associated weight gain, improves glycaemic control and decreases insulin dose in patients with type 2 diabetes: a 26 week, randomised clinical trial (ELEGANT). Diabetologia. 2014 Sep;57(9):1812–9. doi: 10.1007/s00125-014-3302-0. PMID: 24947583. Exclusion Code: X2.24947583
552 de Zeeuw D, Bekker P, Henkel E, . The effect of CCR2 inhibitor CCX140-B on residual albuminuria in patients with type 2 diabetes and nephropathy: a randomised trial. Lancet Diabetes Endocrinol. 2015 Sep;3(9):687–96. doi: 10.1016/s2213-8587(15)00261-2. PMID: 26268910. Exclusion Code: X2.26268910
553 de Zeeuw D, Coll B, Andress D, . The endothelin antagonist atrasentan lowers residual albuminuria in patients with type 2 diabetic nephropathy. J Am Soc Nephrol. 2014 May;25(5):1083–93. doi: 10.1681/asn.2013080830. PMID: 24722445. Exclusion Code: X2.24722445
554 Debussche X, Besancon S, Balcou-Debussche M, . Structured peer-led diabetes self-management and support in a low-income country: the ST2EP randomised controlled trial in Mali. PLoS One. 2018;13(1):e0191262. doi: 10.1371/journal.pone.0191262. PMID: 29357380. Exclusion Code: X6.29357380
555 Dede N, Ipekci S, Kebapcilar L, . Influence of exercise on leptin, adiponectin and quality of life in type 2 diabetics. Turkish journal of endocrinology and metabolism. 2015;19(1):7–13. doi: 10.4274/tjem.2564. PMID: CN-01069460. Exclusion Code: X2.
556 DeFronzo RA, Lewin A, Patel S, . Combination of empagliflozin and linagliptin as second-line therapy in subjects with type 2 diabetes inadequately controlled on metformin. Diabetes Care. 2015 Mar;38(3):384–93. doi: 10.2337/dc14-2364. PMID: 25583754. Exclusion Code: X2.25583754
557 DeFronzo RA, Tripathy D, Abdul-Ghani M, . The disposition index does not reflect beta-cell function in IGT subjects treated with pioglitazone. J Clin Endocrinol Metab. 2014 Oct;99(10):3774–81. doi: 10.1210/jc.2014-1515. PMID: 24937535. Exclusion Code: X6.24937535
558 Del Prato S, Foley JE, Kothny W, . Study to determine the durability of glycaemic control with early treatment with a vildagliptin-metformin combination regimen vs. standard-of-care metformin monotherapy-the VERIFY trial: a randomized double-blind trial. Diabet Med. 2014 Oct;31(10):1178–84. doi: 10.1111/dme.12508. PMID: 24863949. Exclusion Code: X6.24863949
559 Del Prato S, Nauck M, Duran-Garcia S, . Long-term glycaemic response and tolerability of dapagliflozin versus a sulphonylurea as add-on therapy to metformin in patients with type 2 diabetes: 4-year data. Diabetes Obes Metab. 2015 Jun;17(6):581–90. doi: 10.1111/dom.12459. PMID: 25735400. Exclusion Code: X5.25735400
560 Del Prato S, Patel S, Crowe S, . Efficacy and safety of linagliptin according to patient baseline characteristics: a pooled analysis of three phase 3 trials. Nutr Metab Cardiovasc Dis. 2016 Oct;26(10):886–92. doi: 10.1016/j.numecd.2016.06.015. PMID: 27484756. Exclusion Code: X8.27484756
561 Delahanty LM, Dalton KM, Porneala B, . Improving diabetes outcomes through lifestyle change--a randomized controlled trial. Obesity (Silver Spring). 2015 Sep;23(9):1792–9. doi: 10.1002/oby.21172. PMID: 26260043. Exclusion Code: X2.26260043
562 Delevatti R, Kanitz A, Alberton C, . Glucose control can be similarly improved after aquatic or dry-land aerobic training in patients with type 2 diabetes: a randomized clinical trial. Journal of science and medicine in sport. 2016;19(8):688–93. doi: 10.1016/j.jsams.2015.10.008. PMID: CN-01166516. Exclusion Code: X5.26777722
563 Dell’Oro R, Maloberti A, Nicoli F, . Long-term saxagliptin treatment improves endothelial function but not pulse wave velocity and intima-media thickness in type 2 diabetic patients. High Blood Press Cardiovasc Prev. 2017 Dec;24(4):393–400. doi: 10.1007/s40292-017-0215-2. PMID: 28608024. Exclusion Code: X6.28608024
564 d’Emden MC, Jenkins AJ, Li L, . Favourable effects of fenofibrate on lipids and cardiovascular disease in women with type 2 diabetes: results from the Fenofibrate Intervention and Event Lowering in Diabetes (FIELD) study. Diabetologia. 2014 Nov;57(11):2296–303. doi: 10.1007/s00125-014-3344-3. PMID: 25149070. Exclusion Code: X2.25149070
565 Dempsey PC, Larsen RN, Sethi P, . Benefits for type 2 diabetes of interrupting prolonged sitting with brief bouts of light walking or simple resistance activities. Diabetes Care. 2016 Jun;39(6):964–72. doi: 10.2337/dc15-2336. PMID: 27208318. Exclusion Code: X6.27208318
566 Dempsey PC, Larsen RN, Winkler EAH, . Prolonged uninterrupted sitting elevates postprandial hyperglycaemia proportional to degree of insulin resistance. Diabetes Obes Metab. 2018 Jun;20(6):1526–30. doi: 10.1111/dom.13254. PMID: 29431272. Exclusion Code: X4.29431272
567 den Braver NR, Lakerveld J, Rutters F, . Built environmental characteristics and diabetes: a systematic review and meta-analysis. BMC Med. 2018 Jan 31;16(1):12. doi: 10.1186/s12916-017-0997-z. PMID: 29382337. Exclusion Code: X8.29382337
568 den Hertog HM, Vermeer SE, Zandbergen AA, . Safety and feasibility of metformin in patients with Impaired glucose tolerance and a recent TIA or minor ischemic stroke (LIMIT) trial - a multicenter, randomized, open-label phase II trial. Int J Stroke. 2015 Jan;10(1):105–9. doi: 10.1111/ijs.12023. PMID: 23489282. Exclusion Code: X2.23489282
569 den Ouden H, Berends J, Stellato RK, . Effect of six years intensified multifactorial treatment on levels of hs-CRP and adiponectin in patients with screen detected type 2 diabetes: the ADDITION-Netherlands randomized trial. Diabetes Metab Res Rev. 2015 Oct;31(7):758–66. doi: 10.1002/dmrr.2669. PMID: 26109470. Exclusion Code: X6.26109470
570 Deng D, Yang Y, Tang X, . Association between metformin therapy and incidence, recurrence and mortality of prostate cancer: evidence from a meta-analysis. Diabetes Metab Res Rev. 2015 Sep;31(6):595–602. doi: 10.1002/dmrr.2645. PMID: 25708557. Exclusion Code: X8.25708557
571 Deng FE, Shivappa N, Tang Y, . Association between diet-related inflammation, all-cause, all-cancer, and cardiovascular disease mortality, with special focus on prediabetics: findings from NHANES III. Eur J Nutr. 2017 Apr;56(3):1085–93. doi: 10.1007/s00394-016-1158-4. PMID: 26825592. Exclusion Code: X4.26825592
572 Deng K, Ren Y, Luo Z, . Peer support training improved the glycemic control, insulin management, and diabetic behaviors of patients with type 2 diabetes in rural communities of Central China: a randomized controlled trial. Medical science monitor. 2016;22:267–75. PMID: CN-01133668. Exclusion Code: X2.26808489
573 Deng XL, Ma R, Zhu HX, . Short article: a randomized-controlled study of sitagliptin for treating diabetes mellitus complicated by nonalcoholic fatty liver disease. Eur J Gastroenterol Hepatol. 2017 Mar;29(3):297–301. doi: 10.1097/meg.0000000000000780. PMID: 27832040. Exclusion Code: X6.27832040
574 Denney WS, Denham DS, Riggs MR, . Glycemic effect and safety of a systemic, partial glucokinase activator, PF-04937319, in patients with type 2 diabetes mellitus inadequately controlled on metformin-a randomized, crossover, active-controlled study. Clin Pharmacol Drug Dev. 2016 Nov;5(6):517–27. doi: 10.1002/cpdd.261. PMID: 27870481. Exclusion Code: X2.27870481
575 Dennis JM, Henley WE, Weedon MN, . Sex and BMI Alter the Benefits and Risks of Sulfonylureas and Thiazolidinediones in Type 2 Diabetes: A Framework for Evaluating Stratification Using Routine Clinical and Individual Trial Data. Diabetes Care. 2018 Sep;41(9):1844–53. doi: 10.2337/dc18-0344. PMID: 30072404. Exclusion Code: X8.30072404
576 DePaoli A, Higgins L, Henry R, . Can a selective PPAR? modulator improve glycemic control in patients with type 2 diabetes with fewer side effects compared with pioglitazone? Diabetes care. 2014;37(7):1918–23. doi: 10.2337/dc13-2480. PMID: CN-01117206. Exclusion Code: X2.24722496
577 DePaoli AM, Higgins LS, Henry RR, . Can a selective PPARgamma modulator improve glycemic control in patients with type 2 diabetes with fewer side effects compared with pioglitazone? Diabetes Care. 2014 Jul;37(7):1918–23. doi: 10.2337/dc13-2480. PMID: 24722496. Exclusion Code: X2.24722496
578 Derosa G, Mugellini A, Pesce RM, . A study about the relevance of adding acetylsalicylic acid in primary prevention in subjects with type 2 diabetes mellitus: effects on some new emerging biomarkers of cardiovascular risk. Cardiovasc Diabetol. 2015 Jul 30;14:95. doi: 10.1186/s12933-015-0254-8. PMID: 26223257. Exclusion Code: X6.26223257
579 Derosa G, Ragonesi P, Fogari E, . Sitagliptin added to previously taken antidiabetic agents on insulin resistance and lipid profile: a 2-year study evaluation. Fundamental & clinical pharmacology. 2014;28(2):221–9. doi: 10.1111/fcp.12001. PMID: CN-00981584. Exclusion Code: X2.23039403
580 Desai J, Taylor G, Benitez G, . Can financial incentives prevent diabetes in a low-income population? Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A71. doi: 10.2337/db16-1-381. PMID: CN-01449781. Exclusion Code: X4.
581 Desai J, Taylor G, Vazquez-Benitez G, . Financial incentives for diabetes prevention in a Medicaid population: study design and baseline characteristics. Contemp Clin Trials. 2017 Feb;53:1–10. doi: 10.1016/j.cct.2016.11.007. PMID: 27890521. Exclusion Code: X6.27890521
582 Desai M, Yavin Y, Balis D, . Renal safety of canagliflozin, a sodium glucose co-transporter 2 inhibitor, in patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2017 Jun;19(6):897–900. doi: 10.1111/dom.12876. PMID: 28083972. Exclusion Code: X5.28083972
583 Desroches S, Lapointe A, Ratté S, . Interventions to enhance adherence to dietary advice for preventing and managing chronic diseases in adults. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2013. Exclusion Code: X8.
584 Desveaux L, Agarwal P, Shaw J, . A randomized wait-list control trial to evaluate the impact of a mobile application to improve self-management of individuals with type 2 diabetes: a study protocol. BMC Med Inform Decis Mak. 2016;16(1):144. doi: 10.1186/s12911-016-0381-5. PMID: CN-01413689. Exclusion Code: X6.27842539
585 Detournay B, Halimi S, Robert J, . Hypoglycemia hospitalization frequency in patients with type 2 diabetes mellitus: a comparison of dipeptidyl peptidase 4 inhibitors and insulin secretagogues using the French health insurance database. Vasc Health Risk Manag. 2015;11:417–25. doi: 10.2147/vhrm.s84507. PMID: 26229480. Exclusion Code: X5.26229480
586 Devineni D, Manitpisitkul P, Murphy J, . Effect of canagliflozin on the pharmacokinetics of glyburide, metformin, and simvastatin in healthy participants. Clin Pharmacol Drug Dev. 2015 May-Jun;4(3):226–36. doi: 10.1002/cpdd.166. PMID: 27140803. Exclusion Code: X2.27140803
587 DeVries JH, Desouza C, Bellary S, . Achieving glycaemic control without weight gain, hypoglycaemia, or gastrointestinal adverse events in type 2 diabetes in the SUSTAIN clinical trial programme. Diabetes Obes Metab. 2018 Oct;20(10):2426–34. doi: 10.1111/dom.13396. PMID: 29862621. Exclusion Code: X2.29862621
588 Dhatariya K, Bain SC, Buse JB, . The Impact of Liraglutide on Diabetes-Related Foot Ulceration and Associated Complications in Patients With Type 2 Diabetes at High Risk for Cardiovascular Events: Results From the LEADER Trial. Diabetes Care. 2018 Oct;41(10):2229–35. doi: 10.2337/dc18-1094. PMID: 30072400. Exclusion Code: X2.30072400
589 Di Pino A, Currenti W, Urbano F, . Low advanced glycation end product diet improves the lipid and inflammatory profiles of prediabetic subjects. J Clin Lipidol. 2016 Sep-Oct;10(5):1098–108. doi: 10.1016/j.jacl.2016.07.001. PMID: 27678426. Exclusion Code: X4.27678426
590 Di Prospero NA, Artis E, Andrade-Gordon P, . CCR2 antagonism in patients with type 2 diabetes mellitus: a randomized, placebo-controlled study. Diabetes Obes Metab. 2014 Nov;16(11):1055–64. doi: 10.1111/dom.12309. PMID: 24798870. Exclusion Code: X2.24798870
591 Díaz-López A, Babio N, Martínez-González M, . Mediterranean diet, retinopathy, nephropathy, and microvascular diabetes complications: a post hoc analysis of a randomized trial. Diabetes care. 2015;38(11):2134–41. doi: 10.2337/dc15-1117. PMID: CN-01140898. Exclusion Code: X2.26370380
592 Dicks L, Kirch N, Gronwald D, . Regular Intake of a Usual Serving Size of Flavanol-Rich Cocoa Powder Does Not Affect Cardiometabolic Parameters in Stably Treated Patients with Type 2 Diabetes and Hypertension-A Double-Blinded, Randomized, Placebo-Controlled Trial. Nutrients. 2018 Oct 5;10(10)doi: 10.3390/nu10101435. PMID: 30301127. Exclusion Code: X4.30301127
593 Digenio A, Dunbar RL, Alexander VJ, . Antisense-mediated lowering of plasma apolipoprotein C-III by volanesorsen improves dyslipidemia and insulin sensitivity in type 2 diabetes. Diabetes Care. 2016 Aug;39(8):1408–15. doi: 10.2337/dc16-0126. PMID: 27271183. Exclusion Code: X2.27271183
594 Dimitriu-Leen AC, Scholte AJ, van Rosendael AR, . Value of coronary computed tomography angiography in tailoring aspirin therapy for primary prevention of atherosclerotic events in patients at high risk with diabetes mellitus. Am J Cardiol. 2016 Mar 15;117(6):887–93. doi: 10.1016/j.amjcard.2015.12.023. PMID: 26803383. Exclusion Code: X8.26803383
595 Dimova ED, Mohan ARM, Swanson V, . Interventions for prevention of type 2 diabetes in relatives: a systematic review. Prim Care Diabetes. 2017 Aug;11(4):313–26. doi: 10.1016/j.pcd.2017.04.003. PMID: 28511962. Exclusion Code: X8.28511962
596 Ding D, Chong S, Jalaludin B, . Risk factors of incident type 2-diabetes mellitus over a 3-year follow-up: results from a large Australian sample. Diabetes Res Clin Pract. 2015 May;108(2):306–15. doi: 10.1016/j.diabres.2015.02.002. PMID: 25737033. Exclusion Code: X4.25737033
597 Distiller LA, Polakow ES, Joffe BI. Type 2 diabetes mellitus and hypothyroidism: the possible influence of metformin therapy. Diabet Med. 2014 Feb;31(2):172–5. doi: 10.1111/dme.12342. PMID: 24151823. Exclusion Code: X6.24151823
598 Do DV, Wang X, Vedula SS, . Blood pressure control for diabetic retinopathy. Cochrane Database of Systematic Reviews. 2015(1)doi: 10.1002/14651858.CD006127.pub2. PMID: CD006127. Exclusion Code: X8.
599 do Rosário Pinto M, Parreira P, Basto ML, . Impact of a structured multicomponent educational intervention program on metabolic control of patients with type 2 diabetes. BMC Endocr Disord. 2017;17(1):77. doi: 10.1186/s12902-017-0222-2. PMID: CN-01621646. Exclusion Code: X6.29246139
600 do Valle Nascimento TM, Resnicow K, Nery M, . A pilot study of a Community Health Agent-led type 2 diabetes self-management program using Motivational Interviewing-based approaches in a public primary care center in Sao Paulo, Brazil. BMC Health Serv Res. 2017 Jan 13;17(1):32. doi: 10.1186/s12913-016-1968-3. PMID: 28086870. Exclusion Code: X6.28086870
601 Dobbins R, Byerly R, Gaddy R, . GSK256073 acutely regulates NEFA levels via HCA2 agonism but does not achieve durable glycaemic control in type 2 diabetes. A randomised trial. Eur J Pharmacol. 2015 May 15;755:95–101. doi: 10.1016/j.ejphar.2015.03.005. PMID: 25773496. Exclusion Code: X4.25773496
602 Dobler A, Herbeck Belnap B, Pollmann H, . Telephone-delivered lifestyle support with action planning and motivational interviewing techniques to improve rehabilitation outcomes. Rehabil Psychol. 2018 May;63(2):170–81. doi: 10.1037/rep0000224. PMID: 29878825. Exclusion Code: X2.29878825
603 Dobson R, Whittaker R, Jiang Y, . Effectiveness of text message based, diabetes self management support programme (SMS4BG): two arm, parallel randomised controlled trial. Bmj. 2018 May 17;361:k1959. doi: 10.1136/bmj.k1959. PMID: 29773539. Exclusion Code: X2.29773539
604 Dobson R, Whittaker R, Jiang Y, . Text message-based diabetes self-management support (SMS4BG): study protocol for a randomised controlled trial. Trials. 2016;17:179. doi: 10.1186/s13063-016-1305-5. PMID: CN-01307511. Exclusion Code: X6.27039300
605 Dodd JM, Grivell RM, Deussen AR, . Metformin for women who are overweight or obese during pregnancy for improving maternal and infant outcomes. Cochrane Database of Systematic Reviews. 2018(7)doi: 10.1002/14651858.CD010564.pub2. PMID: CD010564. Exclusion Code: X8.
606 Dodevska MS, Sobajic SS, Djordjevic PB, . Effects of total fibre or resistant starch-rich diets within lifestyle intervention in obese prediabetic adults. Eur J Nutr. 2016 Feb;55(1):127–37. doi: 10.1007/s00394-015-0831-3. PMID: 25588971. Exclusion Code: X5.25588971
607 Dogru A, Ovayolu N, Ovayolu O. The effect of motivational interview persons with diabetes on self-management and metabolic variables. J Pak Med Assoc. 2019 Mar;69(3):294–300. PMID: 30890817. Exclusion Code: X6.30890817
608 Domínguez CS, Carrillo FL, Gobierno HJ, . Effectiveness of a low-fructose and/or low-sucrose diet in decreasing insulin resistance (DISFRUTE study): study protocol for a randomized controlled trial. Trials. 2017;18(1):369. doi: 10.1186/s13063-017-2043-z. PMID: CN-01599958. Exclusion Code: X6.28784181
609 Donazar-Ezcurra M, Lopez-Del Burgo C, Bes-Rastrollo M. Primary prevention of gestational diabetes mellitus through nutritional factors: a systematic review. BMC Pregnancy Childbirth. 2017 Jan 13;17(1):30. doi: 10.1186/s12884-016-1205-4. PMID: 28086820. Exclusion Code: X8.28086820
610 Dong JQ, Rossulek M, Somayaji VR, . Pharmacokinetics and pharmacodynamics of PF-05231023, a novel long-acting FGF21 mimetic, in a first-in-human study. Br J Clin Pharmacol. 2015 Nov;80(5):1051–63. doi: 10.1111/bcp.12676. PMID: 25940675. Exclusion Code: X4.25940675
611 Dong K, Xue X. Study on the effect of single exercise intervention on students with impaired glucose tolerance. Basic and clinical pharmacology and toxicology. Conference: 2017 international conference on human health and medical engineering, HHME 2017. China. 2018;122(Supplement 2):17. doi: 10.1111/bcpt.12968. PMID: CN-01570710. Exclusion Code: X5.
612 Dong Y, Wang P, Dai Z, . Increased self-care activities and glycemic control rate in relation to health education via Wechat among diabetes patients: A randomized clinical trial. Medicine (Baltimore). 2018 Dec;97(50):e13632. doi: 10.1097/md.0000000000013632. PMID: 30558051. Exclusion Code: X2.30558051
613 Dorresteijn JA, Kriegsman DM, Assendelft WJ, . Patient education for preventing diabetic foot ulceration. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
614 Dou J, Ma J, Liu J, . Efficacy and safety of saxagliptin in combination with metformin as initial therapy in Chinese patients with type 2 diabetes: Results from the START study, a multicentre, randomized, double-blind, active-controlled, phase 3 trial. Diabetes Obes Metab. 2018 Mar;20(3):590–8. doi: 10.1111/dom.13117. PMID: 28926170. Exclusion Code: X5.28926170
615 Douros A, Dell’Aniello S, Yu OHY, . Sulfonylureas as second line drugs in type 2 diabetes and the risk of cardiovascular and hypoglycaemic events: population based cohort study. Bmj. 2018 Jul 18;362:k2693. doi: 10.1136/bmj.k2693. PMID: 30021781. Exclusion Code: X5.30021781
616 Douros A, Yin H, Yu OHY, . Pharmacologic differences of sulfonylureas and the risk of adverse cardiovascular and hypoglycemic events. Diabetes Care. 2017 Nov;40(11):1506–13. doi: 10.2337/dc17-0595. PMID: 28864502. Exclusion Code: X5.28864502
617 Drake I, Wallstrom P, Hindy G, . TCF7L2 type 2 diabetes risk variant, lifestyle factors, and incidence of prostate cancer. Prostate. 2014 Sep;74(12):1161–70. doi: 10.1002/pros.22832. PMID: 24961829. Exclusion Code: X4.24961829
618 Driessen JH, Henry RM, van Onzenoort HA, . Bone fracture risk is not associated with the use of glucagon-like peptide-1 receptor agonists: a population-based cohort analysis. Calcif Tissue Int. 2015 Aug;97(2):104–12. doi: 10.1007/s00223-015-9993-5. PMID: 25894068. Exclusion Code: X5.25894068
619 Driessen JH, van den Bergh JP, van Onzenoort HA, . Long-term use of dipeptidyl peptidase-4 inhibitors and risk of fracture: a retrospective population-based cohort study. Diabetes Obes Metab. 2017 Mar;19(3):421–8. doi: 10.1111/dom.12843. PMID: 27943565. Exclusion Code: X5.27943565
620 Driessen JH, van Onzenoort HA, Henry RM, . Use of dipeptidyl peptidase-4 inhibitors for type 2 diabetes mellitus and risk of fracture. Bone. 2014 Nov;68:124–30. doi: 10.1016/j.bone.2014.07.030. PMID: 25093264. Exclusion Code: X5.25093264
621 Driessen JH, van Onzenoort HA, Starup-Linde J, . Use of glucagon-like-peptide 1 receptor agonists and risk of fracture as compared to use of other anti-hyperglycemic drugs. Calcif Tissue Int. 2015 Nov;97(5):506–15. doi: 10.1007/s00223-015-0037-y. PMID: 26184119. Exclusion Code: X5.26184119
622 Driessen JH, van Onzenoort HA, Starup-Linde J, . Use of dipeptidyl peptidase 4 inhibitors and fracture risk compared to use of other anti-hyperglycemic drugs. Pharmacoepidemiol Drug Saf. 2015 Oct;24(10):1017–25. doi: 10.1002/pds.3837. PMID: 26183226. Exclusion Code: X5.26183226
623 Drignath S, Winkley K, Wijesuriya M, . Pragmatic lifestyle modification programme reduces depression and perceived stress in south Asian adults with pre-diabetes: a randomised controlled trial. Diabetologia. 2018;61:S128–S9. doi: 10.1007/s00125-018-4693-0. PMID: CN-01647133. Exclusion Code: X6.
624 Drummen M, Dorenbos E, Vreugdenhil ACE, . Associations of Brain Reactivity to Food Cues with Weight Loss, Protein Intake and Dietary Restraint during the PREVIEW Intervention. Nutrients. 2018 Nov 15;10(11)doi: 10.3390/nu10111771. PMID: 30445718. Exclusion Code: X4.30445718
625 Du J, Liang L, Fang H, . Efficacy and safety of saxagliptin add-on to metformin compared with acarbose add-on to metformin in patients with type 2 diabetes mellitus (T2DM) inadequately controlled with metformin monotherapy. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A293. doi: 10.2337/db16-861-1374. PMID: CN-01449885. Exclusion Code: X5.
626 Duckworth W, Abraira C, Moritz T, . Glucose control and vascular complications in veterans with type 2 diabetes. N Engl J Med. 2009 Jan 8;360(2):129–39. doi: 10.1056/NEJMoa0808431. PMID: 19092145. Exclusion Code: X2.19092145
627 Duggan C, Carosso E, Mariscal N, . Diabetes prevention in Hispanics: report from a randomized controlled trial. Prev Chronic Dis. 2014 Feb 27;11:E28. doi: 10.5888/pcd11.130119. PMID: 24576395. Exclusion Code: X6.24576395
628 Duijzer G, Haveman-Nies A, Jansen SC, . Effect and maintenance of the SLIMMER diabetes prevention lifestyle intervention in Dutch primary healthcare: a randomised controlled trial. Nutr Diabetes. 2017 May 8;7(5):e268. doi: 10.1038/nutd.2017.21. PMID: 28481335. Exclusion Code: X11.28481335
629 Duijzer G, Haveman-Nies A, Jansen SC, . SLIMMER: a randomised controlled trial of diabetes prevention in Dutch primary health care: design and methods for process, effect, and economic evaluation. BMC Public Health. 2014 Jun 14;14:602. doi: 10.1186/1471-2458-14-602. PMID: 24928217. Exclusion Code: X6.24928217
630 Dujic T, Zhou K, Yee SW, . Variants in pharmacokinetic transporters and glycemic response to metformin: a metgen meta-analysis. Clin Pharmacol Ther. 2017 Jun;101(6):763–72. doi: 10.1002/cpt.567. PMID: 27859023. Exclusion Code: X8.27859023
631 Dungan KM, Raz I, Skrivanek Z, . Achieving the composite endpoint of glycated haemoglobin <7.0%, no weight gain and no hypoglycaemia in the once-weekly dulaglutide AWARD programme. Diabetes Obes Metab. 2016 Jan;18(1):49–55. doi: 10.1111/dom.12575. PMID: 26362460. Exclusion Code: X8.26362460
632 Dungan KM, Weitgasser R, Perez Manghi F, . A 24-week study to evaluate the efficacy and safety of once-weekly dulaglutide added on to glimepiride in type 2 diabetes (AWARD-8). Diabetes Obes Metab. 2016 May;18(5):475–82. doi: 10.1111/dom.12634. PMID: 26799540. Exclusion Code: X2.26799540
633 Dunkler D, Kohl M, Heinze G, . Modifiable lifestyle and social factors affect chronic kidney disease in high-risk individuals with type 2 diabetes mellitus. Kidney Int. 2015 Apr;87(4):784–91. doi: 10.1038/ki.2014.370. PMID: 25493953. Exclusion Code: X8.25493953
634 Duran-Garcia S, Lee J, Yki-Jarvinen H, . Efficacy and safety of linagliptin as add-on therapy to basal insulin and metformin in people with Type 2 diabetes. Diabet Med. 2016 Jul;33(7):926–33. doi: 10.1111/dme.13041. PMID: 26605991. Exclusion Code: X2.26605991
635 Duru OK, Turk N, Ettner SL, . Adherence to metformin, statins, and ACE/ARBs within the Diabetes Health Plan (DHP). J Gen Intern Med. 2015 Nov;30(11):1645–50. doi: 10.1007/s11606-015-3284-8. PMID: 25944019. Exclusion Code: X6.25944019
636 Dushay JR, Tecilazich F, Kafanas A, . Aliskiren improves vascular smooth muscle function in the skin microcirculation of type 2 diabetic patients with normal renal function. J Renin Angiotensin Aldosterone Syst. 2015 Jun;16(2):344–52. doi: 10.1177/1470320313489060. PMID: 23670354. Exclusion Code: X2.23670354
637 Dutour A, Abdesselam I, Ancel P, . Exenatide decreases liver fat content and epicardial adipose tissue in patients with obesity and type 2 diabetes: a prospective randomized clinical trial using magnetic resonance imaging and spectroscopy. Diabetes Obes Metab. 2016 Sep;18(9):882–91. doi: 10.1111/dom.12680. PMID: 27106272. Exclusion Code: X2.27106272
638 Duvivier BM, Schaper NC, Hesselink MK, . Breaking sitting with light activities vs structured exercise: a randomised crossover study demonstrating benefits for glycaemic control and insulin sensitivity in type 2 diabetes. Diabetologia. 2017 Mar;60(3):490–8. doi: 10.1007/s00125-016-4161-7. PMID: 27904925. Exclusion Code: X2.27904925
639 Dworacka M, Krzyzagorska E, Wesolowska A, . Statins in low doses reduce VEGF and bFGF serum levels in patients with type 2 diabetes mellitus. Pharmacology. 2014;93(1–2):32–8. doi: 10.1159/000357476. PMID: 24434301. Exclusion Code: X6.24434301
640 Dworacka M, Krzyzagorska E, Wesolowska A, . Circulating monocyte chemotactic protein 1 (MCP-1), vascular cell adhesion molecule 1 (VCAM-1) and angiogenin in type 2 diabetic patients treated with statins in low doses. Eur J Pharmacol. 2014 Oct 5;740:474–9. doi: 10.1016/j.ejphar.2014.06.041. PMID: 24991787. Exclusion Code: X6.24991787
641 Dwyer JP, Greco BA, Umanath K, . Pyridoxamine dihydrochloride in diabetic nephropathy (PIONEER-CSG-17): lessons learned from a pilot study. Nephron. 2015;129(1):22–8. doi: 10.1159/000369310. PMID: 25532068. Exclusion Code: X2.25532068
642 Dyson PA, Hammersley MS, Morris RJ, . The Fasting Hyperglycaemia Study: II. Randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism. 1997 Dec;46(12 Suppl 1):50–5. PMID: 9439560. Exclusion Code: X11.9439560
643 Eades CE, France EF, Evans JM. Prevalence of impaired glucose regulation in Europe: a meta-analysis. Eur J Public Health. 2016 Aug;26(4):699–706. doi: 10.1093/eurpub/ckw085. PMID: 27423001. Exclusion Code: X8.27423001
644 Eaglehouse YL, Kramer MK, Rockette-Wagner B, . Evaluation of physical activity reporting in community Diabetes Prevention Program lifestyle intervention efforts: a systematic review. Prev Med. 2015 Aug;77:191–9. doi: 10.1016/j.ypmed.2015.05.023. PMID: 26051204. Exclusion Code: X8.26051204
645 Eaglehouse YL, Schafer GL, Arena VC, . Impact of a community-based lifestyle intervention program on health-related quality of life. Qual Life Res. 2016 Aug;25(8):1903–12. doi: 10.1007/s11136-016-1240-7. PMID: 26896960. Exclusion Code: X7.26896960
646 Eaglehouse YL, Venditti EM, Kramer MK, . Factors related to lifestyle goal achievement in a diabetes prevention program dissemination study. Transl Behav Med. 2017 Dec;7(4):873–80. doi: 10.1007/s13142-017-0494-0. PMID: 28397158. Exclusion Code: X7.28397158
647 Eakin EG, Winkler EA, Dunstan DW, . Living well with diabetes: 24-month outcomes from a randomized trial of telephone-delivered weight loss and physical activity intervention to improve glycemic control. Diabetes Care. 2014 Aug;37(8):2177–85. doi: 10.2337/dc13-2427. PMID: 24658390. Exclusion Code: X6.24658390
648 Earnest C, Johannsen N, Swift D, . Aerobic and strength training in concomitant metabolic syndrome and type 2 diabetes. Med Sci Sports Exerc. 2014;46(7):1293–301. doi: 10.1249/MSS.0000000000000242. PMID: CN-01046923. Exclusion Code: X2.24389523
649 Eastwood SV, Tillin T, Mayet J, . Ethnic differences in cross-sectional associations between impaired glucose regulation, identified by oral glucose tolerance test or HbA1c values, and cardiovascular disease in a cohort of European and South Asian origin. Diabet Med. 2016 Mar;33(3):340–7. doi: 10.1111/dme.12895. PMID: 26314829. Exclusion Code: X8.26314829
650 Ebert DD, Nobis S, Lehr D, . The 6-month effectiveness of Internet-based guided self-help for depression in adults with type 1 and 2 diabetes mellitus. Diabet Med. 2017 Jan;34(1):99–107. doi: 10.1111/dme.13173. PMID: 27334444. Exclusion Code: X2.27334444
651 Ebrahimi H, Ashrafi Z, Rudsari DM, . Effect of Family-Based Education on the Quality of Life of Persons With Type 2 Diabetes: A Randomized Clinical Trial. J Nurs Res. 2018 Apr;26(2):97–103. doi: 10.1097/jnr.0000000000000212. PMID: 28858971. Exclusion Code: X2.28858971
652 Ebrahimi H, Sadeghi M, Amanpour F, . Evaluation of empowerment model on indicators of metabolic control in patients with type 2 diabetes, a randomized clinical trial study. Prim Care Diabetes. 2016 Apr;10(2):129–35. doi: 10.1016/j.pcd.2015.09.003. PMID: 26795772. Exclusion Code: X2.26795772
653 Eccleston C, Fisher E, Craig L, . Psychological therapies (Internet-delivered) for the management of chronic pain in adults. Cochrane Database of Systematic Reviews. 2014(2)doi: 10.1002/14651858.CD010152.pub2. PMID: CD010152. Exclusion Code: X8.
654 Echouffo-Tcheugui JB, Narayan KM, Weisman D, . Association between prediabetes and risk of chronic kidney disease: a systematic review and meta-analysis. Diabet Med. 2016 Dec;33(12):1615–24. doi: 10.1111/dme.13113. PMID: 26997583. Exclusion Code: X8.26997583
655 Eckel RH, Henry RR, Yue P, . Effect of ranolazine monotherapy on glycemic control in subjects with type 2 diabetes. Diabetes Care. 2015 Jul;38(7):1189–96. doi: 10.2337/dc14-2629. PMID: 26049552. Exclusion Code: X2.26049552
656 Edelman D, Dolor R, Coffman C, . Nurse-led behavioral management of diabetes and hypertension in community practices: a randomized trial. J Gen Intern Med. 2015;30(5):626–33. doi: 10.1007/s11606-014-3154-9. PMID: CN-01043634. Exclusion Code: X2.25567758
657 Edwards MK, Addoh O, Sng E, . Physical activity, body mass index and waist circumference change, and normal-range glycated hemoglobin on incident diabetes: Jackson Heart Study. Postgrad Med. 2017 Nov;129(8):842–8. doi: 10.1080/00325481.2017.1358065. PMID: 28730854. Exclusion Code: X6.28730854
658 Egede LE, Walker RJ, Payne EH, . Effect of psychotherapy for depression via home telehealth on glycemic control in adults with type 2 diabetes: subgroup analysis of a randomized clinical trial. J Telemed Telecare. 2018;24(9):596–602. doi: 10.1177/1357633X17730419. PMID: CN-01665682. Exclusion Code: X5.28945160
659 Egede LE, Williams JS, Voronca DC, . Telephone-delivered behavioral skills intervention for African American adults with type 2 diabetes: a randomized controlled trial. J Gen Intern Med. 2017 Jul;32(7):775–82. doi: 10.1007/s11606-017-4023-0. PMID: 28337686. Exclusion Code: X6.28337686
660 Eichner NZM, Gaitan JM, Gilbertson NM, . Postprandial augmentation index is reduced in adults with prediabetes following continuous and interval exercise training. Exp Physiol. 2019 Feb;104(2):264–71. doi: 10.1113/ep087305. PMID: 30537411. Exclusion Code: X5.30537411
661 Ekholm E, Hansen L, Johnsson E, . Combined treatment with saxagliptin plus dapagliflozin reduces insulin levels by increased insulin clearance and improves beta-cell function. Endocr Pract. 2017 Mar;23(3):258–65. doi: 10.4158/ep161323.or. PMID: 27849380. Exclusion Code: X2.27849380
662 Ekstrom N, Svensson AM, Miftaraj M, . Cardiovascular safety of glucose-lowering agents as add-on medication to metformin treatment in type 2 diabetes: report from the Swedish National Diabetes Register. Diabetes Obes Metab. 2016 Oct;18(10):990–8. doi: 10.1111/dom.12704. PMID: 27282621. Exclusion Code: X2.27282621
663 El DR, Gameiro OL, Ogata MS, . Zinc supplementation for the prevention of type 2 diabetes mellitus in adults with insulin resistance. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
664 El Messaoudi S, Schreuder TH, Kengen RD, . Impact of metformin on endothelial ischemia-reperfusion injury in humans in vivo: a prospective randomized open, blinded-endpoint study. PLoS One. 2014;9(4):e96062. doi: 10.1371/journal.pone.0096062. PMID: 24755906. Exclusion Code: X2.24755906
665 El Toony LF, Hamad DA, Omar OM. Outcome of focused pre-Ramadan education on metabolic and glycaemic parameters in patients with type 2 diabetes mellitus. Diabetes Metab Syndr. 2018 Sep;12(5):761–7. doi: 10.1016/j.dsx.2018.04.036. PMID: 29729978. Exclusion Code: X2.29729978
666 El-Benhawy SA, El-Sheredy HG. Metformin and survival in diabetic patients with breast cancer. J Egypt Public Health Assoc. 2014 Dec;89(3):148–53. doi: 10.1097/01.EPX.0000456620.00173.c0. PMID: 25534180. Exclusion Code: X2.25534180
667 Elgart JF, Gonzalez L, Prestes M, . Frequency of self-monitoring blood glucose and attainment of HbA1c target values. Acta Diabetol. 2016 Feb;53(1):57–62. doi: 10.1007/s00592-015-0745-9. PMID: 25841589. Exclusion Code: X5.25841589
668 Eliraqi GM, Vistisen D, Lauritzen T, . Intensive multifactorial treatment modifies the effect of family history of diabetes on glycaemic control in people with Type 2 diabetes: a post hoc analysis of the ADDITION-Denmark randomized controlled trial. Diabet Med. 2015 Aug;32(8):1085–9. doi: 10.1111/dme.12764. PMID: 25819139. Exclusion Code: X6.25819139
669 Elkind-Hirsch K, Paterson M, Seidemann E, . Short-term therapy with combination DPP-4 inhibitor saxagliptin/ metformin XR is superior to saxagliptin or metformin XR monotherapy in women with polycystic ovary syndrome (PCOS) and impaired glucose regulation. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A7. doi: 10.2337/db16-1-381. PMID: CN-01449810. Exclusion Code: X5.
670 Elkind-Hirsch K, Paterson M, Shaler D, . Short-term sitagliptin-metformin therapy is more effective than metformin or placebo in prior gestational diabetic women with impaired glucose regulation. Diabetes. 2017;66:A390-. PMID: CN-01709032. Exclusion Code: X6.
671 Elkind-Hirsch KE, Paterson MS, Seidemann EL, . Short-term therapy with combination dipeptidyl peptidase-4 inhibitor saxagliptin/metformin extended release (XR) is superior to saxagliptin or metformin XR monotherapy in prediabetic women with polycystic ovary syndrome: a single-blind, randomized, pilot study. Fertil Steril. 2017 Jan;107(1):253–60.e1. doi: 10.1016/j.fertnstert.2016.09.023. PMID: 28228317. Exclusion Code: X5.28228317
672 Elkind-Hirsch KE, Paterson MS, Shaler D, . Short-term sitagliptin-metformin therapy is more effective than metformin or placebo in prior gestational diabetic women with impaired glucose regulation. Endocr Pract. 2018 Apr;24(4):361–8. doi: 10.4158/ep-2017-0251. PMID: 29561188. Exclusion Code: X2.29561188
673 Ells LJ, Mead E, Atkinson G, . Surgery for the treatment of obesity in children and adolescents. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
674 Elsner B, Kugler J, Pohl M, . Transcranial direct current stimulation (tDCS) for improving aphasia in adults with aphasia after stroke. Cochrane Database of Systematic Reviews. 2019(5)doi: 10.1002/14651858.CD009760.pub4. PMID: CD009760. Exclusion Code: X8.
675 Emoto M, Oura T, Matsui A, . Pancreatic safety in Japanese patients with type 2 diabetes treated with once weekly dulaglutide 0.75 mg up to 52 weeks in phase 3 clinical trials. Endocr J. 2017 Feb 27;64(2):191–206. doi: 10.1507/endocrj.EJ16-0365. PMID: 27853058. Exclusion Code: X2.27853058
676 Emoto M, Terauchi Y, Ozeki A, . A 1-year safety study of dulaglutide in Japanese patients with type 2 diabetes on a single oral hypoglycemic agent: an open-label, nonrandomized, phase 3 trial. Endocr J. 2015;62(12):1101–14. doi: 10.1507/endocrj.EJ15-0401. PMID: 26477324. Exclusion Code: X2.26477324
677 Endevelt R, Peled R, Azrad A, . Diabetes prevention program in a Mediterranean environment: individual or group therapy? An effectiveness evaluation. Prim Care Diabetes. 2015;9(2):89–95. doi: 10.1016/j.pcd.2014.07.005. PMID: CN-01087663. Exclusion Code: X5.25151065
678 Eng M, Gibbs B, Tudorascu D, . PCP weight loss assistance in a primary care population: lessons learned from participants with recent intentional weight loss in the maintain-PC study. Journal of general internal medicine. 2016;31(2 suppl. 1):S332–s3. PMID: CN-01160477. Exclusion Code: X2.
679 Engeda JC, Stackhouse A, White M, . Evidence of heterogeneity in statin-associated type 2 diabetes mellitus risk: A meta-analysis of randomized controlled trials and observational studies. Diabetes Res Clin Pract. 2019 May;151:96–105. doi: 10.1016/j.diabres.2019.04.005. PMID: 30954511. Exclusion Code: X8.30954511
680 Engel SS, Suryawanshi S, Stevens SR, . Safety of sitagliptin in patients with type 2 diabetes and chronic kidney disease: outcomes from TECOS. Diabetes Obes Metab. 2017 Nov;19(11):1587–93. doi: 10.1111/dom.12983. PMID: 28432745. Exclusion Code: X5.28432745
681 England C, Andrews R, Jago R, . Changes in reported food intake in adults with type 2 diabetes in response to a nonprescriptive dietary intervention. Journal of human nutrition and dietetics. 2014;27(4):311–21. doi: 10.1111/jhn.12154. PMID: CN-01121810. Exclusion Code: X6.23980910
682 England C, Thompson J, Jago R, . Dietary changes and associations with metabolic improvements in adults with type 2 diabetes during a patient-centred dietary intervention: an exploratory analysis. BMJ open. 2014;4(6):e004953. doi: 10.1136/bmjopen-2014-004953. PMID: CN-01161089. Exclusion Code: X5.
683 Erdmann E, Harding S, Lam H, . Ten-year observational follow-up of PROactive: a randomized cardiovascular outcomes trial evaluating pioglitazone in type 2 diabetes. Diabetes Obes Metab. 2016 Mar;18(3):266–73. doi: 10.1111/dom.12608. PMID: 26592506. Exclusion Code: X2.26592506
684 Erdmann E, Song E, Spanheimer R, . Observational follow-up of the PROactive study: a 6-year update. Diabetes Obes Metab. 2014 Jan;16(1):63–74. doi: 10.1111/dom.12180. PMID: 23859428. Exclusion Code: X2.23859428
685 Erickson M, Braun K, List R, . Evaluation of US Veterans nutrition education for diabetes prevention. J Nutr Educ Behav. 2016 Sep;48(8):538–43.e1. doi: 10.1016/j.jneb.2016.06.007. PMID: 27614279. Exclusion Code: X8.27614279
686 Eriksson J, Lundkvist P, Sjostrom C, . One year of treatment with dapagliflozin QD + exenatide QW in obese adults without diabetes: results of an open-label extension study. Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S332–s3. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212718. Exclusion Code: X2.
687 Eriksson JW, Bodegard J, Nathanson D, . Sulphonylurea compared to DPP-4 inhibitors in combination with metformin carries increased risk of severe hypoglycemia, cardiovascular events, and all-cause mortality. Diabetes Res Clin Pract. 2016 Jul;117:39–47. doi: 10.1016/j.diabres.2016.04.055. PMID: 27329021. Exclusion Code: X5.27329021
688 Erlandson KM, Jiang Y, Debanne SM, . Rosuvastatin worsens insulin resistance in HIV-infected adults on antiretroviral therapy. Clin Infect Dis. 2015 Nov 15;61(10):1566–72. doi: 10.1093/cid/civ554. PMID: 26157049. Exclusion Code: X2.26157049
689 Errazuriz I, Dube S, Slama M, . Randomized controlled trial of a MUFA or fiber-rich diet on hepatic fat in prediabetes. Journal of clinical endocrinology and metabolism. 2017;102(5):1765–74. doi: 10.1210/jc.2016-3722. PMID: CN-01373290. Exclusion Code: X6.28323952
690 Espeland M, Luchsinger J, Neiberg R, . Long term effect of intensive lifestyle intervention on cerebral blood flow. J Am Geriatr Soc. 2017;(no pagination)doi: 10.1111/jgs.15159. PMID: CN-01430811. Exclusion Code: X6.
691 Espeland MA, Erickson K, Neiberg RH, . Brain and white matter hyperintensity volumes after 10 years of random assignment to lifestyle intervention. Diabetes Care. 2016 May;39(5):764–71. doi: 10.2337/dc15-2230. PMID: 27208378. Exclusion Code: X2.27208378
692 Espeland MA, Glick HA, Bertoni A, . Impact of an intensive lifestyle intervention on use and cost of medical services among overweight and obese adults with type 2 diabetes: the action for health in diabetes. Diabetes Care. 2014 Sep;37(9):2548–56. doi: 10.2337/dc14-0093. PMID: 25147253. Exclusion Code: X6.25147253
693 Espeland MA, Lewis CE, Bahnson J, . Impact of weight loss on ankle-brachial index and interartery blood pressures. Obesity (Silver Spring). 2014 Apr;22(4):1032–41. doi: 10.1002/oby.20658. PMID: 24174392. Exclusion Code: X6.24174392
694 Espeland MA, Lipska K, Miller ME, . Effects of physical activity intervention on physical and cognitive function in sedentary adults with and without diabetes. J Gerontol A Biol Sci Med Sci. 2017 Jun 1;72(6):861–6. doi: 10.1093/gerona/glw179. PMID: 27590629. Exclusion Code: X6.27590629
695 Espeland MA, Luchsinger JA, Baker LD, . Effect of a long-term intensive lifestyle intervention on prevalence of cognitive impairment. Neurology. 2017 May 23;88(21):2026–35. doi: 10.1212/wnl.0000000000003955. PMID: 28446656. Exclusion Code: X2.28446656
696 Espeland MA, Probstfield J, Hire D, . Systolic blood pressure control among individuals with type 2 diabetes: a comparative effectiveness analysis of three interventions. Am J Hypertens. 2015 Aug;28(8):995–1009. doi: 10.1093/ajh/hpu292. PMID: 25666468. Exclusion Code: X2.25666468
697 Espeland MA, Rapp SR, Bray GA, . Long-term impact of behavioral weight loss intervention on cognitive function. J Gerontol A Biol Sci Med Sci. 2014 Sep;69(9):1101–8. doi: 10.1093/gerona/glu031. PMID: 24619151. Exclusion Code: X2.24619151
698 Espinoza S, Wang C, Reaven P, . Pioglitazone is equally effective for preventing diabetes in older compared to younger pre-diabetic adults. Journal of the american geriatrics society. 2015;63:S100. doi: 10.1111/jgs.13439. PMID: CN-01080950. Exclusion Code: X10.
699 Espinoza S, Wang C-P, Clement S, . Pioglitazone is equally effective for diabetes prevention in older compared with younger prediabetic adults. Diabetes. 2015;64:A308–a9. doi: 10.2337/db159321471. PMID: CN-01103727. Exclusion Code: X10.
700 Espinoza SE, Musi N, Wang CP, . Rationale and Study Design of a Randomized Clinical Trial of Metformin to Prevent Frailty in Older Adults with Pre-Diabetes. Journals of gerontology. Series A, Biological sciences and medical sciences. 2019doi: 10.1093/gerona/glz078. PMID: CN-01916206. Exclusion Code: X4.
701 Esposito K, Chiodini P, Capuano A, . Baseline glycemic parameters predict the hemoglobin A1c response to DPP-4 inhibitors : meta-regression analysis of 78 randomized controlled trials with 20,053 patients. Endocrine. 2014 May;46(1):43–51. doi: 10.1007/s12020-013-0090-0. PMID: 24248503. Exclusion Code: X8.24248503
702 Esposito K, Chiodini P, Maiorino MI, . Glycaemic durability with dipeptidyl peptidase-4 inhibitors in type 2 diabetes: a systematic review and meta-analysis of long-term randomised controlled trials. BMJ Open. 2014 Jun 10;4(6):e005442. doi: 10.1136/bmjopen-2014-005442. PMID: 24916090. Exclusion Code: X8.24916090
703 Esposito K, Maiorino M, Petrizzo M, . The effects of a Mediterranean diet on the need for diabetes drugs and remission of newly diagnosed type 2 diabetes: follow-up of a randomized trial. Diabetes care. 2014;37(7):1824–30. doi: 10.2337/dc13-2899. PMID: CN-01041243. Exclusion Code: X5.24722497
704 Essien O, Otu A, Umoh V, . Intensive patient education improves glycaemic control in diabetes compared to conventional education: a randomised controlled trial in a Nigerian tertiary care hospital. PLoS One. 2017;12(1):e0168835. doi: 10.1371/journal.pone.0168835. PMID: 28045979. Exclusion Code: X9.28045979
705 Estacio RO, Jeffers BW, Hiatt WR, . The effect of nisoldipine as compared with enalapril on cardiovascular outcomes in patients with non-insulin-dependent diabetes and hypertension. N Engl J Med. 1998 Mar 5;338(10):645–52. doi: 10.1056/NEJM199803053381003. PMID: 9486993. Exclusion Code: X2.9486993
706 Eurich DT, Weir DL, Simpson SH, . Risk of new-onset heart failure in patients using sitagliptin: a population-based cohort study. Diabet Med. 2016 May;33(5):621–30. doi: 10.1111/dme.12867. PMID: 26206341. Exclusion Code: X2.26206341
707 Evangelista AF, Collares CV, Xavier DJ, . Integrative analysis of the transcriptome profiles observed in type 1, type 2 and gestational diabetes mellitus reveals the role of inflammation. BMC Med Genomics. 2014 May 23;7:28. doi: 10.1186/1755-8794-7-28. PMID: 24885568. Exclusion Code: X8.24885568
708 Evans M, Billings LK, Hakan-Bloch J, . An indirect treatment comparison of the efficacy of insulin degludec/liraglutide (IDegLira) and insulin glargine/lixisenatide (iGlarLixi) in patients with type 2 diabetes uncontrolled on basal insulin. J Med Econ. 2018 Apr;21(4):340–7. doi: 10.1080/13696998.2017.1409228. PMID: 29164973. Exclusion Code: X8.29164973
709 Evans M, Schweizer A, Foley J. Blood pressure and fasting lipid changes after 24 weeks’ treatment with vildagliptin: a pooled analysis in >2,000 previously drug-naive patients with type 2 diabetes mellitus. Vascular health and risk management. 2016;12:337–40. doi: 10.2147/VHRM.S112148. PMID: CN-01211506. Exclusion Code: X8.27574437
710 Everett BM, Mora S, Glynn RJ, . Safety profile of subjects treated to very low low-density lipoprotein cholesterol levels (<30 mg/dl) with rosuvastatin 20 mg daily (from JUPITER). Am J Cardiol. 2014 Dec 1;114(11):1682–9. doi: 10.1016/j.amjcard.2014.08.041. PMID: 25439449. Exclusion Code: X5.25439449
711 Faber R, Zander M, Pena A, . Effect of the glucagon-like peptide-1 analogue liraglutide on coronary microvascular function in patients with type 2 diabetes - a randomized, single-blinded, cross-over pilot study. Cardiovasc Diabetol. 2015 Apr 22;14:41. doi: 10.1186/s12933-015-0206-3. PMID: 25896352. Exclusion Code: X6.25896352
712 Facila L, Fabregat-Andres O, Bertomeu V, . Metformin and risk of long-term mortality following an admission for acute heart failure. J Cardiovasc Med (Hagerstown). 2017 Feb;18(2):69–73. doi: 10.2459/jcm.0000000000000420. PMID: 27341193. Exclusion Code: X2.27341193
713 Fadini GP, Avogaro A, Degli Esposti L, . Risk of hospitalization for heart failure in patients with type 2 diabetes newly treated with DPP-4 inhibitors or other oral glucose-lowering medications: a retrospective registry study on 127,555 patients from the Nationwide OsMed Health-DB Database. Eur Heart J. 2015 Sep 21;36(36):2454–62. doi: 10.1093/eurheartj/ehv301. PMID: 26112890. Exclusion Code: X5.26112890
714 Fadini GP, Bonora BM, Albiero M, . DPP-4 inhibition has no acute effect on BNP and its N-terminal pro-hormone measured by commercial immune-assays. A randomized cross-over trial in patients with type 2 diabetes. Cardiovasc Diabetol. 2017 Feb 10;16(1):22. doi: 10.1186/s12933-017-0507-9. PMID: 28183314. Exclusion Code: X2.28183314
715 Fadini GP, Rigato M, Boscari F, . Short-term statin discontinuation increases endothelial progenitor cells without inflammatory rebound in type 2 diabetic patients. Vascul Pharmacol. 2015 Apr-Jun;67–69:21–9. doi: 10.1016/j.vph.2014.11.005. PMID: 25483979. Exclusion Code: X4.25483979
716 Faerch K, Amadid H, Nielsen LB, . Protocol for a randomised controlled trial of the effect of dapagliflozin, metformin and exercise on glycaemic variability, body composition and cardiovascular risk in prediabetes (the PRE-D Trial). BMJ Open. 2017 Jun 6;7(5):e013802. doi: 10.1136/bmjopen-2016-013802. PMID: 28592573. Exclusion Code: X6.28592573
717 Faerch K, Witte DR, Brunner EJ, . Physical activity and improvement of glycemia in prediabetes by different diagnostic criteria. J Clin Endocrinol Metab. 2017 Oct 1;102(10):3712–21. doi: 10.1210/jc.2017-00990. PMID: 28973497. Exclusion Code: X8.28973497
718 Fagherazzi G, Vilier A, Bonnet F, . Dietary acid load and risk of type 2 diabetes: the E3N-EPIC cohort study. Diabetologia. 2014 Feb;57(2):313–20. doi: 10.1007/s00125-013-3100-0. PMID: 24232975. Exclusion Code: X4.24232975
719 Faillie JL, Babai S, Crepin S, . Pancreatitis associated with the use of GLP-1 analogs and DPP-4 inhibitors: a case/non-case study from the French Pharmacovigilance Database. Acta Diabetol. 2014;51(3):491–7. doi: 10.1007/s00592-013-0544-0. PMID: 24352344. Exclusion Code: X2.24352344
720 Faillie JL, Filion KB, Patenaude V, . Dipeptidyl peptidase-4 inhibitors and the risk of community-acquired pneumonia in patients with type 2 diabetes. Diabetes Obes Metab. 2015 Apr;17(4):379–85. doi: 10.1111/dom.12431. PMID: 25581902. Exclusion Code: X5.25581902
721 Faillie JL, Yu OH, Yin H, . Association of bile duct and gallbladder diseases with the use of incretin-based drugs in patients with type 2 diabetes mellitus. JAMA Intern Med. 2016 Oct 1;176(10):1474–81. doi: 10.1001/jamainternmed.2016.1531. PMID: 27478902. Exclusion Code: X2.27478902
722 Fan H, Sun X, Zhang H, . Effect of metformin on fibroblast growth factor-21 levels in patients with newly diagnosed type 2 diabetes. Diabetes Technol Ther. 2016 Mar;18(3):120–6. doi: 10.1089/dia.2015.0261. PMID: 26950284. Exclusion Code: X6.26950284
723 Fan MH, Huang BT, Tang YC, . Effect of individualized diabetes education for type 2 diabetes mellitus: a single-center randomized clinical trial. Afr Health Sci. 2016 Dec;16(4):1157–62. doi: 10.4314/ahs.v16i4.34. PMID: 28479909. Exclusion Code: X2.28479909
724 Fan Y, Zhang Y, Li X, . Treatment with metformin and a dipeptidyl peptidase-4 inhibitor elevates apelin levels in patients with type 2 diabetes mellitus. Drug Des Devel Ther. 2015;9:4679–83. doi: 10.2147/dddt.s85740. PMID: 26316706. Exclusion Code: X6.26316706
725 Fang R, Deng X. Electronic messaging intervention for management of cardiovascular risk factors in type 2 diabetes mellitus: A randomised controlled trial. J Clin Nurs. 2018 Feb;27(3–4):612–20. doi: 10.1111/jocn.13962. PMID: 28700102. Exclusion Code: X6.28700102
726 Farabi S, Carley D, Smith D, . Impact of exercise on diurnal and nocturnal markers of glycaemic variability and oxidative stress in obese individuals with type 2 diabetes or impaired glucose tolerance. Diab Vasc Dis Res. 2015;12(5):381–5. doi: 10.1177/1479164115579003. PMID: CN-01258209. Exclusion Code: X6.25994591
727 Farmer AJ, McSharry J, Rowbotham S, . Effects of interventions promoting monitoring of medication use and brief messaging on medication adherence for people with Type 2 diabetes: a systematic review of randomized trials. Diabet Med. 2016 May;33(5):565–79. doi: 10.1111/dme.12987. PMID: 26470750. Exclusion Code: X8.26470750
728 Farmer AJ, Rodgers LR, Lonergan M, . Adherence to oral glucose-lowering therapies and associations with 1-year HbA1c: a retrospective cohort analysis in a large primary care database. Diabetes Care. 2016 Feb;39(2):258–63. doi: 10.2337/dc15-1194. PMID: 26681714. Exclusion Code: X6.26681714
729 Farmer AJ, Stevens R, Hirst J, . Optimal strategies for identifying kidney disease in diabetes: properties of screening tests, progression of renal dysfunction and impact of treatment - systematic review and modelling of progression and cost-effectiveness. Health Technol Assess. 2014 Feb;18(14):1–128. doi: 10.3310/hta18140. PMID: 24576414. Exclusion Code: X8.24576414
730 Farr OM, Sofopoulos M, Tsoukas MA, . GLP-1 receptors exist in the parietal cortex, hypothalamus and medulla of human brains and the GLP-1 analogue liraglutide alters brain activity related to highly desirable food cues in individuals with diabetes: a crossover, randomised, placebo-controlled trial. Diabetologia. 2016 May;59(5):954–65. doi: 10.1007/s00125-016-3874-y. PMID: 26831302. Exclusion Code: X8.26831302
731 Farr OM, Tsoukas MA, Triantafyllou G, . Short-term administration of the GLP-1 analog liraglutide decreases circulating leptin and increases GIP levels and these changes are associated with alterations in CNS responses to food cues: A randomized, placebo-controlled, crossover study. Metabolism. 2016 Jul;65(7):945–53. doi: 10.1016/j.metabol.2016.03.009. PMID: 27282865. Exclusion Code: X6.27282865
732 Fayehun A, Olowookere O, Ogunbode A, . Walking prescription of 10 000 steps per day in patients with type 2 diabetes mellitus: a randomised trial in Nigerian general practice. British journal of general practice. 2018;68(667):e139–e45. doi: 10.3399/bjgp18X694613. PMID: CN-01461429. Exclusion Code: X2.
733 Fazzi C, Saunders DH, Linton K, . Sedentary behaviours during pregnancy: a systematic review. Int J Behav Nutr Phys Act. 2017 Mar 16;14(1):32. doi: 10.1186/s12966-017-0485-z. PMID: 28298219. Exclusion Code: X8.28298219
734 Feng W, Bi Y, Li P, . Effect of liraglutide, metformin, and gliclazide on body composition in type 2 diabetic patients with nonalcoholic fatty liver disease-a randomised trial. Diabetes. 2018;67:A361-. PMID: CN-01631181. Exclusion Code: X5.
735 Feng W, Gao C, Bi Y, . Randomized trial comparing the effects of gliclazide, liraglutide, and metformin on diabetes with non-alcoholic fatty liver disease. J Diabetes. 2017 Aug;9(8):800–9. doi: 10.1111/1753-0407.12555. PMID: 28332301. Exclusion Code: X5.28332301
736 Ferdinand KC, Botros FT, Atisso CM, . Cardiovascular safety for once-weekly dulaglutide in type 2 diabetes: a pre-specified meta-analysis of prospectively adjudicated cardiovascular events. Cardiovasc Diabetol. 2016 Feb 24;15:38. doi: 10.1186/s12933-016-0355-z. PMID: 26912057. Exclusion Code: X8.26912057
737 Ferdinand KC, White WB, Calhoun DA, . Effects of the once-weekly glucagon-like peptide-1 receptor agonist dulaglutide on ambulatory blood pressure and heart rate in patients with type 2 diabetes mellitus. Hypertension. 2014 Oct;64(4):731–7. doi: 10.1161/hypertensionaha.114.03062. PMID: 24980665. Exclusion Code: X2.24980665
738 Ferguson LD, Ntuk UE, Celis-Morales C, . Men across a range of ethnicities have a higher prevalence of diabetes: findings from a cross-sectional study of 500 000 UK Biobank participants. Diabet Med. 2018 Feb;35(2):270–6. doi: 10.1111/dme.13551. PMID: 29171078. Exclusion Code: X8.29171078
739 Ferguson S, Swan M, Smaldone A. Does diabetes self-management education in conjunction with primary care improve glycemic control in Hispanic patients? A systematic review and meta-analysis. Diabetes Educ. 2015 Aug;41(4):472–84. doi: 10.1177/0145721715584404. PMID: 25941192. Exclusion Code: X8.25941192
740 Ferjan S, Jensterle M, Janez A. Dipeptidyl peptidase-4 (DPP-4) inhibitor sitagliptin improved beta-cell function and prevented a conversion rate to MTG and DM2 in metformin intolerant PCOS with high metabolic risk. Diabetes. 2017;66:A563-. PMID: CN-01756062. Exclusion Code: X2.
741 Fernando ME, Seneviratne RM, Tan YM, . Intensive versus conventional glycaemic control for treating diabetic foot ulcers. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
742 Fianu A, Bourse L, Naty N, . Long-term effectiveness of a lifestyle intervention for the primary prevention of type 2 diabetes in a low socio-economic community--an intervention follow-up study on Reunion Island. PLoS One. 2016;11(1):e0146095. doi: 10.1371/journal.pone.0146095. PMID: 26731676. Exclusion Code: X4.26731676
743 Fikri-Benbrahim N, Martinez-Martinez F, Saez-Benito L, . Assessment of a screening protocol for type 2 diabetes in community pharmacy. The DiabNow Study. Diabetes Res Clin Pract. 2015 Jun;108(3):e49–52. doi: 10.1016/j.diabres.2015.03.006. PMID: 25819481. Exclusion Code: X8.25819481
744 Firouzjaei A, Li GC, Wang N, . Comparative evaluation of the therapeutic effect of metformin monotherapy with metformin and acupuncture combined therapy on weight loss and insulin sensitivity in diabetic patients. Nutr Diabetes. 2016 May 2;6:e209. doi: 10.1038/nutd.2016.16. PMID: 27136447. Exclusion Code: X6.27136447
745 Fischer H, Fischer I, Pereira R, . Text message support for weight loss in patients with prediabetes: a randomized clinical trial. Diabetes care. 2016;39(8):1364–70. doi: 10.2337/dc15-2137. PMID: CN-01425202. Exclusion Code: X5.26861922
746 Fisher M, Petrie MC, Ambery PD, . Cardiovascular safety of albiglutide in the Harmony programme: a meta-analysis. Lancet Diabetes Endocrinol. 2015 Sep;3(9):697–703. doi: 10.1016/s2213-8587(15)00233-8. PMID: 26276240. Exclusion Code: X8.26276240
747 Fitzpatrick SL, Golden SH, Stewart K, . Effect of DECIDE (Decision-making Education for Choices In Diabetes Everyday) program delivery modalities on clinical and behavioral outcomes in urban African Americans with type 2 diabetes: a randomized trial. Diabetes Care. 2016 Dec;39(12):2149–57. doi: 10.2337/dc16-0941. PMID: 27879359. Exclusion Code: X6.27879359
748 Fleg JL, Evans GW, Margolis KL, . Orthostatic hypotension in the ACCORD (Action to Control Cardiovascular Risk in Diabetes) blood pressure trial: prevalence, incidence, and prognostic significance. Hypertension. 2016 Oct;68(4):888–95. doi: 10.1161/hypertensionaha.116.07474. PMID: 27504006. Exclusion Code: X2.27504006
749 Flodgren G, Rachas A, Farmer AJ, . Interactive telemedicine: effects on professional practice and health care outcomes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
750 Florez H, Reaven PD, Bahn G, . Rosiglitazone treatment and cardiovascular disease in the Veterans Affairs Diabetes Trial. Diabetes Obes Metab. 2015 Oct;17(10):949–55. doi: 10.1111/dom.12487. PMID: 25964070. Exclusion Code: X2.25964070
751 Florez H, Temprosa MG, Orchard TJ, . Metabolic syndrome components and their response to lifestyle and metformin interventions are associated with differences in diabetes risk in persons with impaired glucose tolerance. Diabetes Obes Metab. 2014 Apr;16(4):326–33. doi: 10.1111/dom.12220. PMID: 24118860. Exclusion Code: X6.24118860
752 Flory JH, Mushlin AI. Observational and clinical trial findings on the comparative effectiveness of diabetes drugs showed agreement. J Clin Epidemiol. 2015 Feb;68(2):200–10. doi: 10.1016/j.jclinepi.2014.09.001. PMID: 25432086. Exclusion Code: X8.25432086
753 Flowers N, Hartley L, Todkill D, . Co-enzyme Q10 supplementation for the primary prevention of cardiovascular disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
754 Floyd JS, Sitlani CM, Avery CL, . Large-scale pharmacogenomic study of sulfonylureas and the QT, JT and QRS intervals: CHARGE Pharmacogenomics Working Group. Pharmacogenomics J. 2018 Jan;18(1):127–35. doi: 10.1038/tpj.2016.90. PMID: 27958378. Exclusion Code: X8.27958378
755 Floyd JS, Wiggins KL, Sitlani CM, . Case-control study of second-line therapies for type 2 diabetes in combination with metformin and the comparative risks of myocardial infarction and stroke. Diabetes Obes Metab. 2015 Dec;17(12):1194–7. doi: 10.1111/dom.12537. PMID: 26179389. Exclusion Code: X8.26179389
756 Fogelholm M, Larsen T, Westerterp-Plantenga M, . PREVIEW-Design, methods and baseline participant description of an international intervention to prevent type-2 diabetes. Annals of nutrition and metabolism. 2015;67:414. doi: 10.1159/000440895. PMID: CN-01160326. Exclusion Code: X10.
757 Fogelholm M, Larsen TM, Westerterp-Planten M, . PREVIEW: prevention of diabetes through lifestyle intervention and population studies in Europe and around the world. design, methods, and baseline participant description of an adult cohort enrolled into a three-year randomised clinical trial. Nutrients. 2017;9(6)doi: 10.3390/nu9060632. PMID: CN-01770835. Exclusion Code: X6.
758 Foley JE, Bhosekar V, Kawamori R. Does the treatment of type 2 diabetes mellitus with the DPP-4 inhibitor vildagliptin reduce HbA1c to a greater extent in Japanese patients than in Caucasian patients? Vasc Health Risk Manag. 2016;12:9–12. doi: 10.2147/vhrm.s96971. PMID: 26855580. Exclusion Code: X8.26855580
759 Fonseca VA, Devries JH, Henry RR, . Reductions in systolic blood pressure with liraglutide in patients with type 2 diabetes: insights from a patient-level pooled analysis of six randomized clinical trials. J Diabetes Complications. 2014 May-Jun;28(3):399–405. doi: 10.1016/j.jdiacomp.2014.01.009. PMID: 24561125. Exclusion Code: X8.24561125
760 Fontes-Villalba M, Lindeberg S, Granfeldt Y, . Palaeolithic diet decreases fasting plasma leptin concentrations more than a diabetes diet in patients with type 2 diabetes: a randomised cross-over trial. Cardiovasc Diabetol. 2016;15:80. doi: 10.1186/s12933-016-0398-1. PMID: CN-01263797. Exclusion Code: X2.27216013
761 Forbes D, Forbes SC, Blake CM, . Exercise programs for people with dementia. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
762 Forbes SC, Forbes D, Forbes S, . Exercise interventions for preventing dementia or delaying cognitive decline in people with mild cognitive impairment. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
763 Forbes SC, Forbes D, Forbes S, . Exercise interventions for maintaining cognitive function in cognitively healthy people in mid life. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
764 Forbes SC, Forbes D, Forbes S, . Exercise interventions for maintaining cognitive function in cognitively healthy people in late life. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
765 Ford CN, Weber MB, Staimez LR, . Dietary changes in a diabetes prevention intervention among people with prediabetes: the Diabetes Community Lifestyle Improvement Program trial. Acta Diabetol. 2019 Feb;56(2):197–209. doi: 10.1007/s00592-018-1249-1. PMID: 30426214. Exclusion Code: X6.30426214
766 Forero-Schwanhaeuser S, Jones-Leone A, Acusta A, . Glycaemic lowering with albiglutide: effective at 1 week and efficacy maintained for 1 year. Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S379–s80. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212749. Exclusion Code: X8.
767 Forjuoh S, Bolin J, Huber J, . Behavioral and technological interventions targeting glycemic control in a racially/ethnically diverse population: a randomized controlled trial. BMC public health. 2014;14:71. doi: 10.1186/1471-2458-14-71. PMID: CN-01014260. Exclusion Code: X2.24450992
768 Forst T, Falk A, Andersen G, . Effects on alpha- and beta-cell function of sequentially adding empagliflozin and linagliptin to therapy in people with type 2 diabetes previously receiving metformin: An exploratory mechanistic study. Diabetes Obes Metab. 2017 Apr;19(4):489–95. doi: 10.1111/dom.12838. PMID: 28009472. Exclusion Code: X2.28009472
769 Forst T, Koch C, Dworak M. Vildagliptin versus insulin in patients with type 2 diabetes mellitus inadequately controlled with sulfonylurea: results from a randomized, 24 week study. Curr Med Res Opin. 2015 Jun;31(6):1079–84. doi: 10.1185/03007995.2015.1039936. PMID: 25867771. Exclusion Code: X5.25867771
770 Fottrell E, Jennings H, Kuddus A, . The effect of community groups and mobile phone messages on the prevention and control of diabetes in rural Bangladesh: study protocol for a three-arm cluster randomised controlled trial. Trials. 2016;17(1) (no pagination)doi: 10.1186/s13063-016-1738-x. PMID: CN-01286921. Exclusion Code: X6.
771 Fountoulakis S, Papanastasiou L, Gryparis A, . Impact and duration effect of telemonitoring on ?bA1c, BMI and cost in insulin-treated Diabetes Mellitus patients with inadequate glycemic control: a randomized controlled study. Hormones (athens, greece). 2015;14(4):632–43. doi: 10.14310/horm.2002.1603. PMID: CN-01215167. Exclusion Code: X2.
772 Fouqueray P, Pirags V, Diamant M, . The efficacy and safety of imeglimin as add-on therapy in patients with type 2 diabetes inadequately controlled with sitagliptin monotherapy. Diabetes Care. 2014 Jul;37(7):1924–30. doi: 10.2337/dc13-2349. PMID: 24722500. Exclusion Code: X2.24722500
773 Fournier M, Germe M, Theobald K, . Indirect comparison of lixisenatide versus neutral protamine Hagedorn insulin as add-on to metformin and sulphonylurea in patients with type 2 diabetes mellitus. Ger Med Sci. 2014;12:Doc14. doi: 10.3205/000199. PMID: 25332702. Exclusion Code: X8.25332702
774 Fowles JR, Shields C, Barron B, . Implementation of resources to support patient physical activity through diabetes centres in Atlantic Canada: the effectiveness of toolkit-based physical activity counselling. Can J Diabetes. 2014 Dec;38(6):415–22. doi: 10.1016/j.jcjd.2014.02.020. PMID: 25065474. Exclusion Code: X8.25065474
775 Fowles JR, Shields C, d’Entremont L, . Implementation of resources to support patient physical activity through diabetes centres in Nova Scotia: the effectiveness of enhanced support for exercise participation. Can J Diabetes. 2014 Dec;38(6):423–31. doi: 10.1016/j.jcjd.2014.02.008. PMID: 25065476. Exclusion Code: X8.25065476
776 Franchi M, Asciutto R, Nicotra F, . Metformin, other antidiabetic drugs, and endometrial cancer risk: a nested case-control study within Italian healthcare utilization databases. Eur J Cancer Prev. 2017 May;26(3):225–31. doi: 10.1097/cej.0000000000000235. PMID: 27222938. Exclusion Code: X5.27222938
777 Francis DK, Smith J, Saljuqi T, . Oral protein calorie supplementation for children with chronic disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
778 Francois M, Durrer C, Pistawka K, . Resistance-based interval exercise acutely improves endothelial function in type 2 diabetes. American journal of physiology. Heart and circulatory physiology. 2016;311(5):H1258–h67. doi: 10.1152/ajpheart.00398.2016. PMID: CN-01382199. Exclusion Code: X6.27638878
779 Franik S, Kremer JA, Nelen WL, . Aromatase inhibitors for subfertile women with polycystic ovary syndrome. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
780 Franks PW, Christophi CA, Jablonski KA, . Common variation at PPARGC1A/B and change in body composition and metabolic traits following preventive interventions: the Diabetes Prevention Program. Diabetologia. 2014 Mar;57(3):485–90. doi: 10.1007/s00125-013-3133-4. PMID: 24317794. Exclusion Code: X6.24317794
781 Freckelton J, Evans JA, Croagh D, . Metformin use in diabetics with diverticular disease is associated with reduced incidence of diverticulitis. Scand J Gastroenterol. 2017 Sep;52(9):969–72. doi: 10.1080/00365521.2017.1325930. PMID: 28503973. Exclusion Code: X8.28503973
782 Fretts AM, Howard BV, McKnight B, . Life’s Simple 7 and incidence of diabetes among American Indians: the Strong Heart Family Study. Diabetes Care. 2014 Aug;37(8):2240–5. doi: 10.2337/dc13-2267. PMID: 24804696. Exclusion Code: X8.24804696
783 Freude S, Heise T, Nordaby M, . Safety and efficacy of bi 187004, a selective 11beta-hydroxysteroid dehydrogenase 1 (11B-HSD1) inhibitor, after 4 weeks of treatment in patients with type 2 diabetes. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A312. doi: 10.2337/db16-861-1374. PMID: CN-01449973. Exclusion Code: X4.
784 Freudenberg N, Franzosa E, Sohler N, . The state of evaluation research on food policies to reduce obesity and diabetes among adults in the United States, 2000-2011. Prev Chronic Dis. 2015 Oct 29;12:E182. doi: 10.5888/pcd12.150237. PMID: 26513438. Exclusion Code: X8.26513438
785 Frias J, Virdi N, Raja P, . Effectiveness of digital medicines to improve clinical outcomes in patients with uncontrolled hypertension and type 2 diabetes: prospective, open-label, cluster-randomized pilot clinical trial. J Med Internet Res. 2017 Jul 11;19(7):e246. doi: 10.2196/jmir.7833. PMID: 28698169. Exclusion Code: X6.28698169
786 Frias JP, Bastyr EJ, 3rd, Vignati L, . The sustained effects of a dual GIP/GLP-1 receptor agonist, NNC0090-2746, in patients with type 2 diabetes. Cell Metab. 2017 Aug 1;26(2):343–52.e2. doi: 10.1016/j.cmet.2017.07.011. PMID: 28768173. Exclusion Code: X2.28768173
787 Frias JP, Guja C, Hardy E, . Exenatide once weekly plus dapagliflozin once daily versus exenatide or dapagliflozin alone in patients with type 2 diabetes inadequately controlled with metformin monotherapy (DURATION-8): a 28 week, multicentre, double-blind, phase 3, randomised controlled trial. Lancet Diabetes Endocrinol. 2016 Dec;4(12):1004–16. doi: 10.1016/s2213-8587(16)30267-4. PMID: 27651331. Exclusion Code: X2.27651331
788 Frias JP, Nauck MA, Van J, . Efficacy and safety of LY3298176, a novel dual GIP and GLP-1 receptor agonist, in patients with type 2 diabetes: a randomised, placebo-controlled and active comparator-controlled phase 2 trial. Lancet. 2018 Nov 17;392(10160):2180–93. doi: 10.1016/s0140-6736(18)32260-8. PMID: 30293770. Exclusion Code: X2.30293770
789 Friedman A, Marrero D, Ma Y, . Value of urinary albumin-to-creatinine ratio as a predictor of type 2 diabetes in pre-diabetic individuals. Diabetes care. 2008;31(12):2344–8. doi: 10.2337/dc08-0148. PMID: CN-01720061. Exclusion Code: X4.18796622
790 Friis A, Johnson M, Cutfield R, . Kindness matters: a randomized controlled trial of a mindful self-compassion intervention improves depression, distress, and HbA1c among patients with diabetes. Diabetes care. 2016;39(11):1963–71. doi: 10.2337/dc16-0416. PMID: CN-01414123. Exclusion Code: X2.27335319
791 Fu AZ, Johnston SS, Ghannam A, . Association between hospitalization for heart failure and dipeptidyl peptidase 4 inhibitors in patients with type 2 diabetes: an observational study. Diabetes Care. 2016 May;39(5):726–34. doi: 10.2337/dc15-0764. PMID: 26740636. Exclusion Code: X8.26740636
792 Fu AZ, Sheehan JJ. Change in HbA1c associated with treatment intensification among patients with type 2 diabetes and poor glycemic control. Curr Med Res Opin. 2017 May;33(5):853–8. doi: 10.1080/03007995.2017.1292231. PMID: 28166431. Exclusion Code: X8.28166431
793 Fu H, Cao D, Boye K, . Early glycemic response predicts achievement of subsequent treatment targets in the treatment of type 2 diabetes: a post hoc analysis. Diabetes therapy. 2015;6(3 // *Eli Lilly and Company*):317–28. doi: 10.1007/s13300-015-0119-x. PMID: CN-01472999. Exclusion Code: X2.26142890
794 Fu H, Curtis BH, Schuster DP, . Treatment patterns among older patients with type 2 diabetes in the United States: a retrospective cohort study. Diabetes Technol Ther. 2014 Dec;16(12):833–9. doi: 10.1089/dia.2014.0039. PMID: 25068375. Exclusion Code: X2.25068375
795 Fuentes S, Fosse-Edorh S, Regnault N, . Prevalence of prediabetes and undiagnosed diabetes among adults aged 18 to 70 years in France-the constances cohort. Diabetes. 2018;67:A443-. PMID: CN-01631268. Exclusion Code: X8.
796 Fujioka K, Greenway F, Krempf M, . Liraglutide 3.0 mg reduces body weight and improves cardiometabolic risk factors in adults with obesity or overweight and prediabetes: the scale obesity and prediabetes randomized, double-blind, placebo-controlled 3-year trial. Endocrine reviews. Conference: 98th annual meeting and expo of the endocrine society, ENDO 2016. United states. Conference start: 20160401. Conference end: 20160404. 2016;37(2 Supplement 1) (no pagination)doi: 10.1210/endo-meetings.2016.CE.1.OR36-1. PMID: CN-01295255. Exclusion Code: X10.
797 Fujioka K, O’Neil PM, Davies M, . Early weight loss with liraglutide 3.0 mg predicts 1-year weight loss and is associated with improvements in clinical markers. Obesity (Silver Spring). 2016 Nov;24(11):2278–88. doi: 10.1002/oby.21629. PMID: 27804269. Exclusion Code: X8.27804269
798 Fujioka K, Wilding J, Astrup A, . Efficacy and safety of liraglutide 3.0 mg for weight management in overweight/obese adults: the SCALE obesity and prediabetes trial. Diabetologia. 2014;57(Suppl1):S368–9. PMID: CN-01369455. Exclusion Code: X10.
799 Fujita Y, Kuwata H, Fujiwara Y, . Effects of dietary instructions including meal sequencing in prediabetic subjects. Journal of diabetes investigation. 2018;9:17-. doi: 10.1111/jdi.12937. PMID: CN-01788758. Exclusion Code: X10.
800 Fukuda M, Doi K, Sugawara M, . Efficacy and safety of sitagliptin in elderly patients with type 2 diabetes mellitus: A focus on hypoglycemia. J Diabetes Investig. 2019 Mar;10(2):383–91. doi: 10.1111/jdi.12915. PMID: 30136435. Exclusion Code: X6.30136435
801 Fukuoka Y, Gay CL, Joiner KL, . A novel diabetes prevention intervention using a mobile app: a randomized controlled trial with overweight adults at risk. Am J Prev Med. 2015 Aug;49(2):223–37. doi: 10.1016/j.amepre.2015.01.003. PMID: 26033349. Exclusion Code: X5.26033349
802 Fukuoka Y, Vittinghoff E, Hooper J. A weight loss intervention using a commercial mobile application in Latino Americans-Adelgaza Trial. Transl Behav Med. 2018 Sep 8;8(5):714–23. doi: 10.1093/tbm/ibx039. PMID: 29474702. Exclusion Code: X2.29474702
803 Fulcher G, Matthews DR, Perkovic V, . Efficacy and safety of canagliflozin when used in conjunction with incretin-mimetic therapy in patients with type 2 diabetes. Diabetes Obes Metab. 2016 Jan;18(1):82–91. doi: 10.1111/dom.12589. PMID: 26450639. Exclusion Code: X2.26450639
804 Fulcher G, Roberts A, Sinha A, . What happens when patients require intensification from basal insulin? A retrospective audit of clinical practice for the treatment of type 2 diabetes from four Australian centres. Diabetes Res Clin Pract. 2015 Jun;108(3):405–13. doi: 10.1016/j.diabres.2015.03.004. PMID: 25887419. Exclusion Code: X2.25887419
805 Fuller N, Sainsbury A, Caterson I, . Examining mindfulness as a predictor of weight loss - Findings from the DIABEGG study. Obes Res Clin Pract. 2017;11(1):88–96. doi: 10.1016/j.orcp.2016.03.004. PMID: CN-01341112. Exclusion Code: X6.27050109
806 Fuller NR, Sainsbury A, Caterson ID, . Effect of a high-egg diet on cardiometabolic risk factors in people with type 2 diabetes: the Diabetes and Egg (DIABEGG) Study-randomized weight-loss and follow-up phase. American journal of clinical nutrition. 2018;107(6):921–31. doi: 10.1093/ajcn/nqy048. PMID: CN-01955274. Exclusion Code: X5.
807 Fullerton B, Jeitler K, Seitz M, . Intensive glucose control versus conventional glucose control for type 1 diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
808 Fullerton B, Siebenhofer A, Jeitler K, . Short-acting insulin analogues versus regular human insulin for adult, non-pregnant persons with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2018(12)doi: 10.1002/14651858.CD013228. PMID: CD013228. Exclusion Code: X8.
809 Funck KL, Laugesen E, Hoyem P, . Low physical activity is associated with increased arterial stiffness in patients recently diagnosed with type 2 diabetes. Am J Hypertens. 2016 Jul;29(7):882–8. doi: 10.1093/ajh/hpv197. PMID: 26714500. Exclusion Code: X8.26714500
810 Fung CS, Wan EY, Wong CK, . Effect of metformin monotherapy on cardiovascular diseases and mortality: a retrospective cohort study on Chinese type 2 diabetes mellitus patients. Cardiovasc Diabetol. 2015 Oct 9;14:137. doi: 10.1186/s12933-015-0304-2. PMID: 26453464. Exclusion Code: X2.26453464
811 Fung CSC, Wan EYF, Chan AKC, . Statin use reduces cardiovascular events and all-cause mortality amongst Chinese patients with type 2 diabetes mellitus: a 5-year cohort study. BMC Cardiovasc Disord. 2017 Jun 24;17(1):166. doi: 10.1186/s12872-017-0599-x. PMID: 28645252. Exclusion Code: X8.28645252
812 Gaal L, Astrup A, Fujioka K, . Liraglutide 3.0 mg reduced the risk of developing type 2 diabetes and decreased body weight in the SCALE Obesity and Prediabetes randomised, double-blind, placebocontrolled trial. Obesity facts. Conference: european obesity summit (EOS): 1st joint congress of EASO and IFSO-EC. Gothenburg sweden. Conference start: 20160601. Conference end: 20160604. Conference publication: (var.pagings). 2016;9:182. doi: 10.1159/000446744. PMID: CN-01266565. Exclusion Code: X10.
813 Gaal L, Pi-Sunyer X, Udden HJ, . Liraglutide 3.0 Mg: weight-loss dependent and independent effects. Obesity facts. 2015;8:41–2. doi: 10.1159/000382140. PMID: CN-01100861. Exclusion Code: X8.
814 Gaal L, Souhami E, Zhou T, . Efficacy and safety of the glucagon-like peptide-1 receptor agonist lixisenatide versus the dipeptidyl peptidase-4 inhibitor sitagliptin in young (<50 years) obese patients with type 2 diabetes mellitus. Journal of clinical and translational endocrinology. 2014;1(2):31–7. doi: 10.1016/j.jcte.2014.03.001. PMID: CN-00995451. Exclusion Code: X2.29159080
815 Gadde KM, Vetter ML, Iqbal N, . Efficacy and safety of autoinjected exenatide once-weekly suspension versus sitagliptin or placebo with metformin in patients with type 2 diabetes: The DURATION-NEO-2 randomized clinical study. Diabetes Obes Metab. 2017 Jul;19(7):979–88. doi: 10.1111/dom.12908. PMID: 28205322. Exclusion Code: X2.28205322
816 Gaede P, Lund-Andersen H, Parving HH, . Effect of a multifactorial intervention on mortality in type 2 diabetes. N Engl J Med. 2008 Feb 7;358(6):580–91. doi: 10.1056/NEJMoa0706245. PMID: 18256393. Exclusion Code: X2.18256393
817 Gaede P, Pedersen O. Rosiglitazone monotherapy for type 2 diabetes mellitus - Too soon to ADOPT? Nature clinical practice endocrinology and metabolism. 2007;3(6):456–7. doi: 10.1038/ncpendmet0503. PMID: CN-01772614. Exclusion Code: X5.
818 Gaede P, Vedel P, Larsen N, . Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. 2003 Jan 30;348(5):383–93. doi: 10.1056/NEJMoa021778. PMID: 12556541. Exclusion Code: X2.12556541
819 Gagliardino J, Elgart J, Bourgeois M, . Diabetes primary prevention program: new insights from data analysis of recruitment period. Diabetes Metab Res Rev. 2017;(no pagination)doi: 10.1002/dmrr.2943. PMID: CN-01421080. Exclusion Code: X8.
820 Gaillard T, Amponsah G, Osei K. Patient-centered community diabetes education program improves glycemic control in African-American patients with poorly controlled type 2 diabetes: importance of point of care metabolic measurements. J Natl Black Nurses Assoc. 2015 Jul;26(1):50–7. PMID: 26371360. Exclusion Code: X2.26371360
821 Gajanand T, Ramos J, Ramos M, . Arterial stiffness and central blood pressures after 8 weeks of supervised exercise training in participants with type 2 diabetes mellitus: a randomised controlled trial. Journal of science and medicine in sport. Conference: 2017 ASICS sports medicine australia conference. Malaysia. 2017;20(Supplement 3):67. doi: 10.1016/j.jsams.2017.09.325. PMID: CN-01440013. Exclusion Code: X6.
822 Galaviz KI, Weber MB, Straus A, . Global Diabetes Prevention Interventions: A Systematic Review and Network Meta-analysis of the Real-World Impact on Incidence, Weight, and Glucose. Diabetes Care. 2018 Jul;41(7):1526–34. doi: 10.2337/dc17-2222. PMID: 29934481. Exclusion Code: X8.29934481
823 Gallagher D, Heshka S, Kelley DE, . Changes in adipose tissue depots and metabolic markers following a 1-year diet and exercise intervention in overweight and obese patients with type 2 diabetes. Diabetes Care. 2014 Dec;37(12):3325–32. doi: 10.2337/dc14-1585. PMID: 25336745. Exclusion Code: X6.25336745
824 Gallagher D, Kelley DE, Thornton J, . Changes in skeletal muscle and organ size after a weight-loss intervention in overweight and obese type 2 diabetic patients. Am J Clin Nutr. 2017 Jan;105(1):78–84. doi: 10.3945/ajcn.116.139188. PMID: 27881389. Exclusion Code: X2.27881389
825 Gallagher R, Zelestis E, Hollams D, . Impact of the Healthy Eating and Exercise Lifestyle Programme on depressive symptoms in overweight people with heart disease and diabetes. Eur J Prev Cardiol. 2014 Sep;21(9):1117–24. doi: 10.1177/2047487313486043. PMID: 23572477. Exclusion Code: X2.23572477
826 Galle F, Di Onofrio V, Miele A, . Effects of a community-based exercise and motivational intervention on physical fitness of subjects with type 2 diabetes. Eur J Public Health. 2019 Apr 1;29(2):281–6. doi: 10.1093/eurpub/cky140. PMID: 30052924. Exclusion Code: X6.30052924
827 Galle F, Krakauer JC, Krakauer NY, . Can an Exercise-Based Educational and Motivational Intervention be Durably Effective in Changing Compliance to Physical Activity and Anthropometric Risk in People with Type 2 Diabetes? A Follow-Up Study. Int J Environ Res Public Health. 2019 Feb 27;16(5)doi: 10.3390/ijerph16050701. PMID: 30818773. Exclusion Code: X6.30818773
828 Gallo S, Charbonnel B, Goldman A, . Long-term efficacy and safety of ertugliflozin in patients (PTS) with type 2 diabetes mellitus (T2DM) inadequately controlled with metformin (MET) monotherapy-104-week vertis met trial. Diabetes. 2018;67:A302-. PMID: CN-01631208. Exclusion Code: X2.
829 Gallo S, Charbonnel B, Goldman A, . Long-term efficacy and safety of ertugliflozin in patients with type 2 diabetes mellitus inadequately controlled with metformin monotherapy: 104-week VERTIS MET trial. Diabetes, obesity & metabolism. 2019doi: 10.1111/dom.13631. PMID: CN-01791557. Exclusion Code: X2.
830 Gallwitz B, Rosenstock J, Patel S, . Regardless of the degree of glycaemic control, linagliptin has lower hypoglycaemia risk than all doses of glimepiride, at all time points, over the course of a 2-year trial. Diabetes Obes Metab. 2015 Mar;17(3):276–84. doi: 10.1111/dom.12419. PMID: 25425502. Exclusion Code: X5.25425502
831 Gamble JM, Chibrikov E, Twells LK, . Association of insulin dosage with mortality or major adverse cardiovascular events: a retrospective cohort study. Lancet Diabetes Endocrinol. 2017 Jan;5(1):43–52. doi: 10.1016/s2213-8587(16)30316-3. PMID: 27865756. Exclusion Code: X2.27865756
832 Gamble JM, Donnan JR, Chibrikov E, . The risk of fragility fractures in new users of dipeptidyl peptidase-4 inhibitors compared to sulfonylureas and other anti-diabetic drugs: A cohort study. Diabetes Res Clin Pract. 2018 Feb;136:159–67. doi: 10.1016/j.diabres.2017.12.008. PMID: 29258886. Exclusion Code: X6.29258886
833 Gamboa Moreno E, Mateo-Abad M, Ochoa de Retana Garcia L, . Efficacy of a self-management education programme on patients with type 2 diabetes in primary care: A randomised controlled trial. Prim Care Diabetes. 2019 Apr;13(2):122–33. doi: 10.1016/j.pcd.2018.10.001. PMID: 30409669. Exclusion Code: X2.30409669
834 Gamiochipi M, Cruz M, Kumate J, . Effect of an intensive metabolic control lifestyle intervention in type-2 diabetes patients. Patient Educ Couns. 2016 Jul;99(7):1184–9. doi: 10.1016/j.pec.2016.01.017. PMID: 26947102. Exclusion Code: X6.26947102
835 Gangwar S, Parimalakrishnan S, Monisha N, . Impact of medication and psychological behavior assessment by community pharmacists in type 2 diabetes mellitus patients after hospital stay. International research journal of pharmacy. 2014;5(4):332–9. doi: 10.7897/2230-8407.050470. PMID: CN-00988083. Exclusion Code: X2.
836 Gantz I, Chen M, Suryawanshi S, . A randomized, placebo-controlled study of the cardiovascular safety of the once-weekly DPP-4 inhibitor omarigliptin in patients with type 2 diabetes mellitus. Cardiovasc Diabetol. 2017 Sep 11;16(1):112. doi: 10.1186/s12933-017-0593-8. PMID: 28893244. Exclusion Code: X2.28893244
837 Gantz I, Okamoto T, Ito Y, . A randomized, placebo- and sitagliptin-controlled trial of the safety and efficacy of omarigliptin, a once-weekly dipeptidyl peptidase-4 inhibitor, in Japanese patients with type 2 diabetes. Diabetes Obes Metab. 2017 Nov;19(11):1602–9. doi: 10.1111/dom.12988. PMID: 28449368. Exclusion Code: X6.28449368
838 Gantz I, Sokolova L, Jain L, . Use of prohibited medication, a potentially overlooked confounder in clinical trials: omarigliptin (once-weekly DPP-4 inhibitor) monotherapy trial in 18- to 45-year-olds. Clin Ther. 2017 Oct;39(10):2024–37. doi: 10.1016/j.clinthera.2017.08.009. PMID: 28923291. Exclusion Code: X2.28923291
839 Gao W, Dong J, Liu J, . Efficacy and safety of initial combination of DPP-IV inhibitors and metformin versus metformin monotherapy in type 2 diabetes: a systematic review of randomized controlled trials (Structured abstract). Diabetes Obesity and Metabolism; 2014. p. 179–85. Exclusion Code: X8.
840 Garberg G, Lovestam-Adrian M, Nasic S, . The prognosis of diabetic retinopathy in patients with type 2 diabetes since 1996-1998: the Skaraborg Diabetes Register. Int Ophthalmol. 2015 Aug;35(4):503–11. doi: 10.1007/s10792-014-9976-y. PMID: 25143261. Exclusion Code: X8.25143261
841 Garcia AA, Brown SA, Horner SD, . Home-based diabetes symptom self-management education for Mexican Americans with type 2 diabetes. Health Educ Res. 2015 Jun;30(3):484–96. doi: 10.1093/her/cyv018. PMID: 25953971. Exclusion Code: X2.25953971
842 Garcia Diaz E, Guagnozzi D, Gutierrez V, . Effect of incretin therapies compared to pioglitazone and gliclazide in non-alcoholic fatty liver disease in diabetic patients not controlled on metformin alone: An observational, pilot study. Endocrinol Nutr. 2016 May;63(5):194–201. doi: 10.1016/j.endonu.2016.01.006. PMID: 26976710. Exclusion Code: X2.26976710
843 Garcia-Egido A, Andrey JL, Puerto JL, . Beta-blocker therapy and prognosis of heart failure patients with new-onset diabetes mellitus. Int J Clin Pract. 2015 May;69(5):550–9. doi: 10.1111/ijcp.12567. PMID: 25707623. Exclusion Code: X2.25707623
844 Garg R, Rao AD, Baimas-George M, . Mineralocorticoid receptor blockade improves coronary microvascular function in individuals with type 2 diabetes. Diabetes. 2015 Jan;64(1):236–42. doi: 10.2337/db14-0670. PMID: 25125488. Exclusion Code: X4.25125488
845 Garvey WT, Ryan DH, Bohannon NJ, . Weight-loss therapy in type 2 diabetes: effects of phentermine and topiramate extended release. Diabetes Care. 2014 Dec;37(12):3309–16. doi: 10.2337/dc14-0930. PMID: 25249652. Exclusion Code: X4.25249652
846 Garvey WT, Ryan DH, Henry R, . Prevention of type 2 diabetes in subjects with prediabetes and metabolic syndrome treated with phentermine and topiramate extended release. Diabetes Care. 2014 Apr;37(4):912–21. doi: 10.2337/dc13-1518. PMID: 24103901. Exclusion Code: X4.24103901
847 Gary-Webb TL, Walker EA, Realmuto L, . Translation of the National Diabetes Prevention Program to Engage Men in Disadvantaged Neighborhoods in New York City: A Description of Power Up for Health. Am J Mens Health. 2018 Jul;12(4):998–1006. doi: 10.1177/1557988318758788. PMID: 29540131. Exclusion Code: X6.29540131
848 Gastaldelli A, Brodows RG, D’Alessio D. The effect of chronic twice daily exenatide treatment on beta-cell function in new onset type 2 diabetes. Clin Endocrinol (Oxf). 2014 Apr;80(4):545–53. doi: 10.1111/cen.12199. PMID: 23574529. Exclusion Code: X6.23574529
849 Gathu CW, Shabani J, Kunyiha N, . Effect of diabetes self-management education on glycaemic control among type 2 diabetic patients at a family medicine clinic in Kenya: A randomised controlled trial. Afr J Prim Health Care Fam Med. 2018 Nov 19;10(1):e1–e9. doi: 10.4102/phcfm.v10i1.1762. PMID: 30456964. Exclusion Code: X2.30456964
850 Gautier JF, Monguillon P, Verier-Mine O, . Which oral antidiabetic drug to combine with metformin to minimize the risk of hypoglycemia when initiating basal insulin?: A randomized controlled trial of a DPP4 inhibitor versus insulin secretagogues. Diabetes Res Clin Pract. 2016 Jun;116:26–8. doi: 10.1016/j.diabres.2016.04.008. PMID: 27321312. Exclusion Code: X2.27321312
851 Gavin JR, 3rd, Jones MR, Ford DM, . Safety and efficacy of colesevelam HCl in the treatment of elderly patients. Drugs Aging. 2014 Jun;31(6):461–70. doi: 10.1007/s40266-014-0174-4. PMID: 24777691. Exclusion Code: X8.24777691
852 Gay JL, Buchner DM, Erickson ML, . Effect of short bouts of high intensity activity on glucose among adults with prediabetes: A pilot randomized crossover study. Diabetes Res Clin Pract. 2018 Jul;141:168–74. doi: 10.1016/j.diabres.2018.04.045. PMID: 29746878. Exclusion Code: X8.29746878
853 Gay JL, Buchner DM, Schmidt MD. Dose-response association of physical activity with HbA1c: Intensity and bout length. Prev Med. 2016 May;86:58–63. doi: 10.1016/j.ypmed.2016.01.008. PMID: 26827616. Exclusion Code: X2.26827616
854 Gebreab SY, Hickson DA, Sims M, . Neighborhood social and physical environments and type 2 diabetes mellitus in African Americans: The Jackson Heart Study. Health Place. 2017 Jan;43:128–37. doi: 10.1016/j.healthplace.2016.12.001. PMID: 28033588. Exclusion Code: X4.28033588
855 Geho WB, Rosenberg LN, Schwartz SL, . A single-blind, placebo-controlled, dose-ranging trial of oral hepatic-directed vesicle insulin add-on to oral antidiabetic treatment in patients with type 2 diabetes mellitus. J Diabetes Sci Technol. 2014 May;8(3):551–9. doi: 10.1177/1932296814524871. PMID: 24876619. Exclusion Code: X4.24876619
856 Geng DF, Jin DM, Wu W, . Angiotensin receptor blockers for prevention of new-onset type 2 diabetes: a meta-analysis of 59,862 patients. Int J Cardiol. 2012;155(2):236–42. doi: 10.1016/j.ijcard.2010.10.011. PMID: CN-01769928. Exclusion Code: X8.21036409
857 Geng DF, Sun WF, Yang L, . Antiproteinuric effect of angiotensin receptor blockers in normotensive patients with proteinuria: a meta-analysis of randomized controlled trials. J Renin Angiotensin Aldosterone Syst. 2014 Mar;15(1):44–51. doi: 10.1177/1470320312474054. PMID: 23378528. Exclusion Code: X8.23378528
858 George A, Jewel V, Manohar M, . Impact of patient counselling on knowledge, attitude, practices of patients with type 2 diabetes mellitus at a tertiary care teaching hospital. Asian journal of pharmaceutical and clinical research. 2017;10(5):293–6. doi: 10.22159/ajpcr.2017.v10i5.17637. PMID: CN-01373285. Exclusion Code: X6.
859 Gepner Y, Golan R, Harman-Boehm I, . Effects of initiating moderate alcohol intake on cardiometabolic risk in adults with type 2 diabetes: a 2-year randomized, controlled trial. Ann Intern Med. 2015;163(8):569–79. doi: 10.7326/M14-1650. PMID: CN-01106334. Exclusion Code: X4.26458258
860 Ghavami H, Radfar M, Soheily S, . Effect of lifestyle interventions on diabetic peripheral neuropathy in patients with type 2 diabetes, result of a randomized clinical trial. Agri. 2018 Oct;30(4):165–70. doi: 10.5505/agri.2018.45477. PMID: 30403270. Exclusion Code: X6.30403270
861 Gholamin S, Razavi SM, Taghavi-Garmestani SM, . Lovastatin for reduction of leptin in nondialysis patients with type 2 diabetic nephropathy. Iran J Kidney Dis. 2014 May;8(3):201–6. PMID: 24878942. Exclusion Code: X2.24878942
862 Ghosh A, Sengupta N, Sahana P, . Efficacy and safety of add on therapy of bromocriptine with metformin in Indian patients with type 2 diabetes mellitus: a randomized open labeled phase IV clinical trial. Indian J Pharmacol. 2014 Jan-Feb;46(1):24–8. doi: 10.4103/0253-7613.125160. PMID: 24550580. Exclusion Code: X5.24550580
863 Giacco R, Costabile G, Della PG, . A whole-grain cereal-based diet lowers postprandial plasma insulin and triglyceride levels in individuals with metabolic syndrome. Nutrition, metabolism, and cardiovascular diseases : NMCD. 2014;24(8):837–44. doi: 10.1016/j.numecd.2014.01.007. PMID: CN-01071751. Exclusion Code: X6.24598599
864 Gibbs BB, Brancati FL, Chen H, . Effect of improved fitness beyond weight loss on cardiovascular risk factors in individuals with type 2 diabetes in the Look AHEAD study. Eur J Prev Cardiol. 2014 May;21(5):608–17. doi: 10.1177/2047487312462823. PMID: 23012688. Exclusion Code: X6.23012688
865 Gidlund E, Walden F, Venojärvi M, . Humanin skeletal muscle protein levels increase after resistance training in men with impaired glucose metabolism. Physiological reports. 2016;4(23)doi: 10.14814/phy2.13063. PMID: CN-01367995. Exclusion Code: X6.
866 Gilbertson NM, Eichner NZM, Francois M, . Glucose Tolerance is Linked to Postprandial Fuel Use Independent of Exercise Dose. Med Sci Sports Exerc. 2018 Oct;50(10):2058–66. doi: 10.1249/mss.0000000000001667. PMID: 29762253. Exclusion Code: X4.29762253
867 Gilis-Januszewska A, Piwonska-Solska B, Lindstrom J, . Determinants of weight outcomes in type 2 diabetes prevention intervention in primary health care setting (the DE-PLAN project). BMC Public Health. 2018 Jan 2;18(1):97. doi: 10.1186/s12889-017-4977-1. PMID: 29291708. Exclusion Code: X5.29291708
868 Gillani SM, Nevill A, Singh BM. Provision of structured diabetes information encourages activation amongst people with diabetes as measured by diabetes care process attainment: the WICKED Project. Diabet Med. 2015 Jul;32(7):865–71. doi: 10.1111/dme.12737. PMID: 25764229. Exclusion Code: X2.25764229
869 Gillani SW, Sari YO, Sulaiman SA, . Glucose tolerance: hypothesis testing on Malaysian diabetic community. Curr Diabetes Rev. 2014;10(5):311–26. PMID: 25316148. Exclusion Code: X2.25316148
870 Gillani SW, Sulaiman SAS, Abdul MIM, . Combined effect of metformin with ascorbic acid versus acetyl salicylic acid on diabetes-related cardiovascular complication; a 12-month single blind multicenter randomized control trial. Cardiovasc Diabetol. 2017 Aug 14;16(1):103. doi: 10.1186/s12933-017-0584-9. PMID: 28807030. Exclusion Code: X2.28807030
871 Gilmer T, O’Connor PJ, Schiff JS, . Cost-Effectiveness of a Community-Based Diabetes Prevention Program with Participation Incentives for Medicaid Beneficiaries. Health Serv Res. 2018 Dec;53(6):4704–24. doi: 10.1111/1475-6773.12973. PMID: 29770445. Exclusion Code: X4.29770445
872 Giorda CB, Picariello R, Tartaglino B, . Hospitalisation for heart failure and mortality associated with dipeptidyl peptidase 4 (DPP-4) inhibitor use in an unselected population of subjects with type 2 diabetes: a nested case-control study. BMJ Open. 2015 Jun 5;5(6):e007959. doi: 10.1136/bmjopen-2015-007959. PMID: 26048211. Exclusion Code: X5.26048211
873 Glechner A, Keuchel L, Affengruber L, . Effects of lifestyle changes on adults with prediabetes: A systematic review and meta-analysis. Prim Care Diabetes. 2018 Oct;12(5):393–408. doi: 10.1016/j.pcd.2018.07.003. PMID: 30076075. Exclusion Code: X8.30076075
874 Gnesin F, Thuesen AC, Kähler LK, . Metformin monotherapy for adults with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2018. Exclusion Code: X8.
875 Goday A, Bellido D, Sajoux I, . Short-term safety, tolerability and efficacy of a very low-calorie-ketogenic diet interventional weight loss program versus hypocaloric diet in patients with type 2 diabetes mellitus. Nutr Diabetes. 2016 Sep 19;6(9):e230. doi: 10.1038/nutd.2016.36. PMID: 27643725. Exclusion Code: X2.27643725
876 Godino JG, van Sluijs EM, Marteau TM, . Lifestyle advice combined with personalized estimates of genetic or phenotypic risk of type 2 diabetes, and objectively measured physical activity: a randomized controlled trial. PLoS Med. 2016 Nov;13(11):e1002185. doi: 10.1371/journal.pmed.1002185. PMID: 27898672. Exclusion Code: X6.27898672
877 Goh GB, Pan A, Chow WC, . Association between diabetes mellitus and cirrhosis mortality: the Singapore Chinese Health Study. Liver Int. 2017 Feb;37(2):251–8. doi: 10.1111/liv.13241. PMID: 27566448. Exclusion Code: X4.27566448
878 Goh K, Lee H, Lau D, . Effects of resveratrol in patients with type 2 diabetes mellitus on skeletal muscle SIRT1 expression and energy expenditure. International journal of sport nutrition and exercise metabolism. 2014;24(1):2–13. doi: 10.1123/ijsnem.2013-0045. PMID: CN-00988098. Exclusion Code: X2.23918588
879 Goins RT, Noonan C, Gonzales K, . Association of depressive symptomology and psychological trauma with diabetes control among older American Indian women: Does social support matter? J Diabetes Complications. 2017 Apr;31(4):669–74. doi: 10.1016/j.jdiacomp.2017.01.004. PMID: 28161383. Exclusion Code: X4.28161383
880 Gokhale M, Buse JB, Jonsson Funk M, . No increased risk of cardiovascular events in older adults initiating dipeptidyl peptidase-4 inhibitors vs therapeutic alternatives. Diabetes Obes Metab. 2017 Jul;19(7):970–8. doi: 10.1111/dom.12906. PMID: 28195389. Exclusion Code: X5.28195389
881 Goldberg RB, Aroda VR, Bluemke DA, . Effect of long-term metformin and lifestyle in the diabetes prevention program and its outcome study on coronary artery calcium. Circulation. 2017 Jul 4;136(1):52–64. doi: 10.1161/circulationaha.116.025483. PMID: 28476766. Exclusion Code: X6.28476766
882 Goldberg RB, Bittner VA, Dunbar RL, . Effects of extended-release niacin added to simvastatin/ezetimibe on glucose and insulin values in AIM-HIGH. Am J Med. 2016 Jul;129(7):753.e13–22. doi: 10.1016/j.amjmed.2016.02.039. PMID: 27036394. Exclusion Code: X6.27036394
883 Goldberg RB, Bray GA, Marcovina SM, . Non-traditional biomarkers and incident diabetes in the Diabetes Prevention Program: comparative effects of lifestyle and metformin interventions. Diabetologia. 2018;(no pagination)doi: 10.1007/s00125-018-4748-2. PMID: CN-01650676. Exclusion Code: X6.
884 Goldberg RB, Temprosa M, Mele L, . Change in adiponectin explains most of the change in HDL particles induced by lifestyle intervention but not metformin treatment in the Diabetes Prevention Program. Metabolism. 2016 May;65(5):764–75. doi: 10.1016/j.metabol.2015.11.011. PMID: 27085783. Exclusion Code: X6.27085783
885 Goldberg RB, Temprosa MG, Mather KJ, . Lifestyle and metformin interventions have a durable effect to lower CRP and tPA levels in the diabetes prevention program except in those who develop diabetes. Diabetes Care. 2014 Aug;37(8):2253–60. doi: 10.2337/dc13-2471. PMID: 24824548. Exclusion Code: X6.24824548
886 Gomes GKA, de Camargos Ramos AI, de Sousa CT, . Linagliptin safety profile: A systematic review. Prim Care Diabetes. 2018 Dec;12(6):477–90. doi: 10.1016/j.pcd.2018.04.006. PMID: 29853297. Exclusion Code: X8.29853297
887 Gomes J, Fabrini S, Alfenas R. Low glycemic index diet reduces body fat and attenuates inflammatory and metabolic responses in patients with type 2 diabetes. Archives of endocrinology and metabolism. 2017;61(2):137–44. doi: 10.1590/2359-3997000000206. PMID: CN-01411169. Exclusion Code: X2.27598983
888 Gomes LC, Coelho ACM, Gomides DDS, . Contribution of family social support to the metabolic control of people with diabetes mellitus: A randomized controlled clinical trial. Appl Nurs Res. 2017 Aug;36:68–76. doi: 10.1016/j.apnr.2017.05.009. PMID: 28720242. Exclusion Code: X6.28720242
889 Gong Q, Zhang P, Ma J, . Lifestyle interventions lower cardiovascular disease in chinese adults with IgT-thirty-year follow-up of Da Qing diabetes prevention study. Diabetes. 2018;67:A35-. PMID: CN-01631388. Exclusion Code: X10.
890 Gong Q, Zhang P, Wang J, . Changes in mortality in people with IGT before and after the onset of diabetes during the 23-year follow-up of the Da Qing Diabetes Prevention Study. Diabetes Care. 2016 Sep;39(9):1550–5. doi: 10.2337/dc16-0429. PMID: 27411697. Exclusion Code: X8.27411697
891 Gong QH, Kang JF, Ying YY, . Lifestyle interventions for adults with impaired glucose tolerance: a systematic review and meta-analysis of the effects on glycemic control. Intern Med. 2015;54(3):303–10. doi: 10.2169/internalmedicine.54.2745. PMID: 25748739. Exclusion Code: X8.25748739
892 Goni L, Qi L, Cuervo M, . Effect of the interaction between diet composition and the. American journal of clinical nutrition. 2017;106(3):902–8. doi: 10.3945/ajcn.117.156281. PMID: CN-01410161. Exclusion Code: X2.
893 Gonzalez-Duarte A, Lem M, Diaz-Diaz E, . The efficacy of pregabalin in the treatment of prediabetic neuropathic pain. Clin J Pain. 2016 Nov;32(11):927–32. doi: 10.1097/ajp.0000000000000339. PMID: 26670614. Exclusion Code: X6.26670614
894 Gonzalez-Heredia T, Hernandez-Corona DM, Gonzalez-Ortiz M, . Effect of linagliptin versus metformin on glycemic variability in patients with impaired glucose tolerance. Diabetes Technol Ther. 2017 Aug;19(8):471–5. doi: 10.1089/dia.2017.0020. PMID: 28581818. Exclusion Code: X5.28581818
895 Goodman C, Man B, Xia Y, . Diabetes incidence by bmi category in the diabetes prevention program. J Gen Intern Med. 2018;33(2):158-. PMID: CN-01606170. Exclusion Code: X10.
896 Goonesekera SD, Yang MH, Hall SA, . Racial ethnic differences in type 2 diabetes treatment patterns and glycaemic control in the Boston Area Community Health Survey. BMJ Open. 2015 May 12;5(5):e007375. doi: 10.1136/bmjopen-2014-007375. PMID: 25967997. Exclusion Code: X8.25967997
897 Goossens ME, Buntinx F, Zeegers MP, . Influence of metformin intake on the risk of bladder cancer in type 2 diabetes patients. Br J Clin Pharmacol. 2015 Dec;80(6):1464–72. doi: 10.1111/bcp.12740. PMID: 26256299. Exclusion Code: X5.26256299
898 Gopalan A, Lorincz IS, Wirtalla C, . Awareness of prediabetes and engagement in diabetes risk-reducing behaviors. Am J Prev Med. 2015 Oct;49(4):512–9. doi: 10.1016/j.amepre.2015.03.007. PMID: 26091928. Exclusion Code: X8.26091928
899 Gopalan A, Paramanund J, Shaw PA, . Randomised controlled trial of alternative messages to increase enrolment in a healthy food programme among individuals with diabetes. BMJ Open. 2016 Nov 30;6(11):e012009. doi: 10.1136/bmjopen-2016-012009. PMID: 27903559. Exclusion Code: X6.27903559
900 Gopalan A, Tahirovic E, Moss H, . Translating the hemoglobin A1C with more easily understood feedback: a randomized controlled trial. J Gen Intern Med. 2014 Jul;29(7):996–1003. doi: 10.1007/s11606-014-2810-4. PMID: 24567202. Exclusion Code: X6.24567202
901 Gordon BA, Benson AC, Bird SR, . Resistance training improves metabolic health in type 2 diabetes: a systematic review (Structured abstract). Diabetes Res Clin Pract; 2009. p. 157–75. Exclusion Code: X8.
902 Gordon J, McEwan P, Evans M, . Managing glycaemia in older people with type 2 diabetes: A retrospective, primary care-based cohort study, with economic assessment of patient outcomes. Diabetes Obes Metab. 2017 May;19(5):644–53. doi: 10.1111/dom.12867. PMID: 28026911. Exclusion Code: X2.28026911
903 Gorgojo-Martinez JJ, Serrano-Moreno C, Sanz-Velasco A, . Real-world effectiveness and safety of dapagliflozin therapy added to a GLP1 receptor agonist in patients with type 2 diabetes. Nutr Metab Cardiovasc Dis. 2017 Feb;27(2):129–37. doi: 10.1016/j.numecd.2016.11.007. PMID: 28077257. Exclusion Code: X2.28077257
904 Goring S, Hawkins N, Wygant G, . Dapagliflozin compared with other oral anti-diabetes treatments when added to metformin monotherapy: a systematic review and network meta-analysis. Diabetes Obes Metab. 2014 May;16(5):433–42. doi: 10.1111/dom.12239. PMID: 24237939. Exclusion Code: X8.24237939
905 Gormsen LC, Sondergaard E, Christensen NL, . Metformin does not affect postabsorptive hepatic free fatty acid uptake, oxidation or resecretion in humans: A 3-month placebo-controlled clinical trial in patients with type 2 diabetes and healthy controls. Diabetes Obes Metab. 2018 Jun;20(6):1435–44. doi: 10.1111/dom.13244. PMID: 29405635. Exclusion Code: X2.29405635
906 Gorricho J, Garjon J, Alonso A, . Use of oral antidiabetic agents and risk of community-acquired pneumonia: a nested case-control study. Br J Clin Pharmacol. 2017 Sep;83(9):2034–44. doi: 10.1111/bcp.13288. PMID: 28294379. Exclusion Code: X2.28294379
907 Gough SC, Bode B, Woo V, . Efficacy and safety of a fixed-ratio combination of insulin degludec and liraglutide (IDegLira) compared with its components given alone: results of a phase 3, open-label, randomised, 26-week, treat-to-target trial in insulin-naive patients with type 2 diabetes. Lancet Diabetes Endocrinol. 2014 Nov;2(11):885–93. doi: 10.1016/s2213-8587(14)70174-3. PMID: 25190523. Exclusion Code: X5.25190523
908 Gough SC, Bode BW, Woo VC, . One-year efficacy and safety of a fixed combination of insulin degludec and liraglutide in patients with type 2 diabetes: results of a 26-week extension to a 26-week main trial. Diabetes Obes Metab. 2015 Oct;17(10):965–73. doi: 10.1111/dom.12498. PMID: 25980900. Exclusion Code: X2.25980900
909 Gower EW, Lovato JF, Ambrosius WT, . Lack of Longitudinal Association Between Thiazolidinediones and Incidence and Progression of Diabetic Eye Disease: The ACCORD Eye Study. Am J Ophthalmol. 2018 Mar;187:138–47. doi: 10.1016/j.ajo.2017.12.007. PMID: 29275147. Exclusion Code: X2.29275147
910 Goyal A, Singh S, Tandon N, . Effect of atorvastatin on pancreatic Beta-cell function and insulin resistance in type 2 diabetes mellitus patients: a randomized pilot study. Can J Diabetes. 2014 Dec;38(6):466–72. doi: 10.1016/j.jcjd.2014.01.006. PMID: 24933106. Exclusion Code: X6.24933106
911 Grabner M, Peng X, Geremakis C, . Demographic and clinical profiles of type 2 diabetes mellitus patients initiating canagliflozin versus DPP-4 inhibitors in a large U.S. managed care population. J Manag Care Spec Pharm. 2015 Dec;21(12):1204–12. doi: 10.18553/jmcp.2015.21.12.1204. PMID: 26679969. Exclusion Code: X6.26679969
912 Grandy S, Hashemi M, Langkilde AM, . Changes in weight loss-related quality of life among type 2 diabetes mellitus patients treated with dapagliflozin. Diabetes Obes Metab. 2014 Jul;16(7):645–50. doi: 10.1111/dom.12263. PMID: 24443876. Exclusion Code: X2.24443876
913 Grandy S, Langkilde AM, Sugg JE, . Health-related quality of life (EQ-5D) among type 2 diabetes mellitus patients treated with dapagliflozin over 2 years. Int J Clin Pract. 2014 Apr;68(4):486–94. doi: 10.1111/ijcp.12341. PMID: 24499168. Exclusion Code: X2.24499168
914 Grant SJ, Bensoussan A, Chang D, . Chinese herbal medicines for people with impaired glucose tolerance or impaired fasting blood glucose. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2009. Exclusion Code: X8.
915 Graybill SD, Vigersky RA. Effects of alpha-blocker therapy on active duty military and military retirees for benign prostatic hypertrophy on diabetic complications. Mil Med. 2015 Mar;180(3):355–60. doi: 10.7205/milmed-d-14-00392. PMID: 25735029. Exclusion Code: X4.25735029
916 Greenway F, Le Roux C, Lau D, . Additional analyses of the weight-lowering efficacy of liraglutide 3.0 mg in overweight and obese adults: the SCALE obesity and prediabetes randomized trial. Diabetologie und stoffwechsel. Conference: 50. Jahrestagung der DDG, diabetes kongress 2015. Germany. 2015;10(4) (no pagination)doi: 10.1055/s-0035-1556575. PMID: CN-01669704. Exclusion Code: X10.
917 Greenway FL. Severe hypoglycemia in the Look AHEAD Trial. J Diabetes Complications. 2016 Jul;30(5):935–43. doi: 10.1016/j.jdiacomp.2016.03.016. PMID: 27114389. Exclusion Code: X2.27114389
918 Greenwood D, Blozis S, Young H, . Overcoming clinical inertia: a randomized clinical trial of a telehealth remote monitoring intervention using paired glucose testing in adults with type 2 diabetes. J Med Internet Res. 2015;17(7):e178. doi: 10.2196/jmir.4112. PMID: CN-01170705. Exclusion Code: X2.26199142
919 Greenwood DC, Threapleton DE, Evans CE, . Association between sugar-sweetened and artificially sweetened soft drinks and type 2 diabetes: systematic review and dose-response meta-analysis of prospective studies. Br J Nutr. 2014 Sep 14;112(5):725–34. doi: 10.1017/s0007114514001329. PMID: 24932880. Exclusion Code: X8.24932880
920 Gregg EW, Jakicic JM, Blackburn G, . Association of the magnitude of weight loss and changes in physical fitness with long-term cardiovascular disease outcomes in overweight or obese people with type 2 diabetes: a post-hoc analysis of the Look AHEAD randomised clinical trial. Lancet Diabetes Endocrinol. 2016 Nov;4(11):913–21. doi: 10.1016/s2213-8587(16)30162-0. PMID: 27595918. Exclusion Code: X2.27595918
921 Gregg EW, Lin J, Bardenheier B, . Impact of Intensive Lifestyle Intervention on Disability-Free Life Expectancy: The Look AHEAD Study. Diabetes Care. 2018 May;41(5):1040–8. doi: 10.2337/dc17-2110. PMID: 29545462. Exclusion Code: X2.29545462
922 Grenier A, Brassard P, Bertrand OF, . Rosiglitazone influences adipose tissue distribution without deleterious impact on heart rate variability in coronary heart disease patients with type 2 diabetes. Clin Auton Res. 2016 Dec;26(6):407–14. doi: 10.1007/s10286-016-0373-7. PMID: 27498095. Exclusion Code: X2.27498095
923 Grey A, Bolland M, Fenwick S, . The skeletal effects of pioglitazone in type 2 diabetes or impaired glucose tolerance: a randomized controlled trial. Eur J Endocrinol. 2014 Feb;170(2):255–62. doi: 10.1530/eje-13-0793. PMID: 24217934. Exclusion Code: X2.24217934
924 Griffin SJ, Simmons RK, Prevost AT, . Multiple behaviour change intervention and outcomes in recently diagnosed type 2 diabetes: the ADDITION-Plus randomised controlled trial. Diabetologia. 2014 Jul;57(7):1308–19. doi: 10.1007/s00125-014-3236-6. PMID: 24759957. Exclusion Code: X5.24759957
925 Griffin TP, Islam MN, Blake L, . Effect of Sodium Glucose Co-Transporter-2 Inhibition on the Aldosterone/Renin Ratio in Type 2 Diabetes Mellitus. Horm Metab Res. 2019 Feb;51(2):91–9. doi: 10.1055/a-0794-7026. PMID: 30522145. Exclusion Code: X2.30522145
926 Grigoropoulou P, Tentolouris A, Eleftheriadou I, . Effect of 12-month intervention with low-dose atorvastatin on pulse wave velocity in subjects with type 2 diabetes and dyslipidaemia. Diab Vasc Dis Res. 2019 Jan;16(1):38–46. doi: 10.1177/1479164118805320. PMID: 30328360. Exclusion Code: X6.30328360
927 Grillo Mde F, Neumann CR, Scain SF, . Diabetes education in primary care: a randomized clinical trial. Cad Saude Publica. 2016 May 31;32(5)doi: 10.1590/0102-311x00097115. PMID: 27253458. Exclusion Code: X2.27253458
928 Grimaldi M, Ciano O, Manzo M, . Intensive dietary intervention promoting the Mediterranean diet in people with high cardiometabolic risk: a non-randomized study. Acta Diabetol. 2018 Mar;55(3):219–26. doi: 10.1007/s00592-017-1078-7. PMID: 29218417. Exclusion Code: X2.29218417
929 Grimes RT, Ensor J, Bennett K, . Use of cardiovascular medicines in newly treated type 2 diabetes patients: a retrospective cohort study in general practice. Prim Care Diabetes. 2016 Aug;10(4):237–43. doi: 10.1016/j.pcd.2015.11.002. PMID: 26654852. Exclusion Code: X6.26654852
930 Grobler L, Nagpal S, Sudarsanam TD, . Nutritional supplements for people being treated for active tuberculosis. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
931 Gron AO, Dalsgaard EM, Ribe AR, . Improving diabetes care among patients with severe mental illness: A systematic review of the effect of interventions. Prim Care Diabetes. 2018 Aug;12(4):289–304. doi: 10.1016/j.pcd.2018.03.008. PMID: 29709403. Exclusion Code: X8.29709403
932 Groop PH, Cooper ME, Perkovic V, . Linagliptin and its effects on hyperglycaemia and albuminuria in patients with type 2 diabetes and renal dysfunction: the randomized MARLINA-T2D trial. Diabetes Obes Metab. 2017 Nov;19(11):1610–9. doi: 10.1111/dom.13041. PMID: 28636754. Exclusion Code: X2.28636754
933 Groop PH, Cooper ME, Perkovic V, . Dipeptidyl peptidase-4 inhibition with linagliptin and effects on hyperglycaemia and albuminuria in patients with type 2 diabetes and renal dysfunction: Rationale and design of the MARLINA-T2D trial. Diab Vasc Dis Res. 2015 Nov;12(6):455–62. doi: 10.1177/1479164115579002. PMID: 26224765. Exclusion Code: X6.26224765
934 Groop PH, Del Prato S, Taskinen MR, . Linagliptin treatment in subjects with type 2 diabetes with and without mild-to-moderate renal impairment. Diabetes Obes Metab. 2014 Jun;16(6):560–8. doi: 10.1111/dom.12281. PMID: 24612167. Exclusion Code: X8.24612167
935 Group AS, Cushman WC, Evans GW, . Effects of intensive blood-pressure control in type 2 diabetes mellitus. N Engl J Med. 2010 Apr 29;362(17):1575–85. doi: 10.1056/NEJMoa1001286. PMID: 20228401. Exclusion Code: X2.20228401
936 Group AS, Gerstein HC, Miller ME, . Long-term effects of intensive glucose lowering on cardiovascular outcomes. N Engl J Med. 2011 Mar 3;364(9):818–28. doi: 10.1056/NEJMoa1006524. PMID: 21366473. Exclusion Code: X2.21366473
937 Group AS, Ginsberg HN, Elam MB, . Effects of combination lipid therapy in type 2 diabetes mellitus. N Engl J Med. 2010 Apr 29;362(17):1563–74. doi: 10.1056/NEJMoa1001282. PMID: 20228404. Exclusion Code: X2.20228404
938 Group AS, Group AES, Chew EY, . Effects of medical therapies on retinopathy progression in type 2 diabetes. N Engl J Med. 2010 Jul 15;363(3):233–44. doi: 10.1056/NEJMoa1001288. PMID: 20587587. Exclusion Code: X2.20587587
939 Gu J, Hu W, Song Z-P, . PPARgamma agonist use and recurrence of atrial fibrillation after successful electrical cardioversion. Hellenic journal of cardiology. 2017;58(5):387–90. doi: 10.1016/j.hjc.2017.01.025. PMID: CN-01451628. Exclusion Code: X2.28347792
940 Gu N, Park MK, Kim TE, . Multiple-dose pharmacokinetics and pharmacodynamics of evogliptin (DA-1229), a novel dipeptidyl peptidase IV inhibitor, in healthy volunteers. Drug Des Devel Ther. 2014;8:1709–21. doi: 10.2147/dddt.s65678. PMID: 25336915. Exclusion Code: X2.25336915
941 Guardado-Mendoza R, Alvarez-Canales M, Farfan D, . Effect of linagliptin + metformin vs. Metformin alone to improve glucose metabolism and beta-cell function in prediabetes. Diabetes. 2017;66:A330-. PMID: CN-01756378. Exclusion Code: X5.
942 Guardado-Mendoza R, Jimenez-Ceja L, Farfan D, . Diabetes prevention with lifestyle, linagliptin and metformin in patients with prediabetes: the PRELLIM project. Diabetologia. 2018;61:S22–S3. doi: 10.1007/s00125-018-4693-0. PMID: CN-01647075. Exclusion Code: X5.
943 Gulati S, Misra A, Nanda K, . Efficacy and tolerance of a diabetes specific formula in patients with type 2 diabetes mellitus: An open label, randomized, crossover study. Diabetes Metab Syndr. 2015 Oct-Dec;9(4):252–7. doi: 10.1016/j.dsx.2014.10.001. PMID: 25458669. Exclusion Code: X4.25458669
944 Guldbrand H, Lindstrom T, Dizdar B, . Randomization to a low-carbohydrate diet advice improves health related quality of life compared with a low-fat diet at similar weight-loss in Type 2 diabetes mellitus. Diabetes Res Clin Pract. 2014 Nov;106(2):221–7. doi: 10.1016/j.diabres.2014.08.032. PMID: 25271116. Exclusion Code: X5.25271116
945 Gumbiner B, Esteves B, Dell V, . Single and multiple ascending-dose study of glucagon-receptor antagonist RN909 in type 2 diabetes: a phase 1, randomized, double-blind, placebo-controlled trial. Endocrine. 2018 Nov;62(2):371–80. doi: 10.1007/s12020-018-1597-1. PMID: 30203123. Exclusion Code: X5.30203123
946 Guo F, Garvey WT. Cardiometabolic disease staging predicts effectiveness of weight-loss therapy to prevent type 2 diabetes: pooled results from phase III clinical trials assessing phentermine/topiramate extended release. Diabetes Care. 2017 Jul;40(7):856–62. doi: 10.2337/dc17-0088. PMID: 28455281. Exclusion Code: X8.28455281
947 Guo J, Chen JL, Whittemore R, . Postpartum lifestyle interventions to prevent type 2 diabetes among women with history of gestational diabetes: a systematic review of randomized clinical trials. J Womens Health (Larchmt). 2016 Jan;25(1):38–49. doi: 10.1089/jwh.2015.5262. PMID: 26700931. Exclusion Code: X8.26700931
948 Guo J, Tang Y, Wiley J, . Effectiveness of a diabetes prevention program for rural women with prior gestational diabetes mellitus: study protocol of a multi-site randomized clinical trial. BMC Public Health. 2018 Jun 28;18(1):809. doi: 10.1186/s12889-018-5725-x. PMID: 29954367. Exclusion Code: X6.29954367
949 Guo L, Guo X, Li Y, . Effects of body mass index or dosage on gastrointestinal disorders associated with extended-release metformin in type 2 diabetes: Sub-analysis of a Phase IV open-label trial in Chinese patients. Diabetes Metab Syndr. 2016 Jul-Sep;10(3):137–42. doi: 10.1016/j.dsx.2016.01.004. PMID: 26948203. Exclusion Code: X5.26948203
950 Guo M, Mi J, Jiang QM, . Metformin may produce antidepressant effects through improvement of cognitive function among depressed patients with diabetes mellitus. Clin Exp Pharmacol Physiol. 2014 Sep;41(9):650–6. doi: 10.1111/1440-1681.12265. PMID: 24862430. Exclusion Code: X6.24862430
951 Guo R, Su Y, Yan J, . Fasudil improves short-term echocardiographic parameters of diastolic function in patients with type 2 diabetes with preserved left ventricular ejection fraction: a pilot study. Heart Vessels. 2015 Jan;30(1):89–97. doi: 10.1007/s00380-013-0458-3. PMID: 24390764. Exclusion Code: X4.24390764
952 Guo VY, Brage S, Ekelund U, . Objectively measured sedentary time, physical activity and kidney function in people with recently diagnosed Type 2 diabetes: a prospective cohort analysis. Diabet Med. 2016 Sep;33(9):1222–9. doi: 10.1111/dme.12886. PMID: 26282583. Exclusion Code: X2.26282583
953 Gupta Y, Kapoor D, Josyula LK, . A lifestyle intervention programme for the prevention of Type 2 diabetes mellitus among South Asian women with gestational diabetes mellitus [LIVING study]: protocol for a randomized trial. Diabetic medicine. 2019;36(2):243–51. doi: 10.1111/dme.13850. PMID: CN-01762510. Exclusion Code: X2.30368898
954 Gurbel PA, Bliden KP, Chaudhary R, . Antiplatelet effect durability of a novel, 24-hour, extended-release prescription formulation of acetylsalicylic acid in patients with type 2 diabetes mellitus. Am J Cardiol. 2016 Dec 15;118(12):1941–7. doi: 10.1016/j.amjcard.2016.08.088. PMID: 27769511. Exclusion Code: X6.27769511
955 Guthrie R. Practice pearl: liraglutide and cardiovascular and renal events in type 2 diabetes. Postgrad Med. 2018 Mar;130(2):154–8. doi: 10.1080/00325481.2018.1430446. PMID: 29350569. Exclusion Code: X8.29350569
956 Gutierrez AD, Andre KBS, Hamidi V, . Chronic, but not acute, incretin therapy reduces postprandial free fatty acid levels in prediabetic individuals. Diabetes. 2017;66:A626-. PMID: CN-01708777. Exclusion Code: X8.
957 Gutierrez AP, Fortmann AL, Savin K, . Effectiveness of Diabetes Self-Management Education Programs for US Latinos at Improving Emotional Distress: A Systematic Review. Diabetes Educ. 2019 Feb;45(1):13–33. doi: 10.1177/0145721718819451. PMID: 30569831. Exclusion Code: X8.30569831
958 Gutierrez Herrera VR, Zeron HM, Mendieta Alcantara MR. Adherence to two methods of education and metabolic control in type 2 diabetics. Ethiop J Health Sci. 2015 Apr;25(2):163–70. PMID: 26124624. Exclusion Code: X5.26124624
959 Gutierrez MJ, Rosenberg NL, Macdougall DE, . Efficacy and safety of ETC-1002, a novel investigational low-density lipoprotein-cholesterol-lowering therapy for the treatment of patients with hypercholesterolemia and type 2 diabetes mellitus. Arterioscler Thromb Vasc Biol. 2014 Mar;34(3):676–83. doi: 10.1161/atvbaha.113.302677. PMID: 24385236. Exclusion Code: X2.24385236
960 Guzman CB, Zhang XM, Liu R, . Treatment with LY2409021, a glucagon receptor antagonist, increases liver fat in patients with type 2 diabetes. Diabetes Obes Metab. 2017 Nov;19(11):1521–8. doi: 10.1111/dom.12958. PMID: 28371155. Exclusion Code: X2.28371155
961 Gyberg V, De Bacquer D, De Backer G, . Patients with coronary artery disease and diabetes need improved management: a report from the EUROASPIRE IV survey: a registry from the EuroObservational Research Programme of the European Society of Cardiology. Cardiovasc Diabetol. 2015 Oct 1;14:133. doi: 10.1186/s12933-015-0296-y. PMID: 26427624. Exclusion Code: X8.26427624
962 Ha Dinh TT, Bonner A, Clark R, . The effectiveness of the teach-back method on adherence and self-management in health education for people with chronic disease: a systematic review. JBI Database System Rev Implement Rep. 2016 Jan;14(1):210–47. doi: 10.11124/jbisrir-2016-2296. PMID: 26878928. Exclusion Code: X8.26878928
963 Ha V, Viguiliouk E, Kendall C, . Effect of a low glycemic index diet versus a high-cereal fibre diet on markers of subclinical cardiac injury in healthy individuals with type 2 diabetes mellitus: an exploratory analysis of a randomized dietary trial. Clin Biochem. 2017;(no pagination)doi: 10.1016/j.clinbiochem.2017.09.021. PMID: CN-01422028. Exclusion Code: X2.
964 Hackett G, Cole N, Bhartia M, . Testosterone replacement therapy improves metabolic parameters in hypogonadal men with type 2 diabetes but not in men with coexisting depression: the BLAST study. Journal of sexual medicine. 2014;11(3):840–56. doi: 10.1111/jsm.12404. PMID: CN-00986463. Exclusion Code: X4.
965 Hadi N, Abdelhussein M, Rudha A, . Simvastatin use in patients with type 2 diabetes mellitus: the effects on oxidative stress. Oman medical journal. 2015;30(4):237–40. doi: 10.5001/omj.2015.49. PMID: CN-01091663. Exclusion Code: X2.26366256
966 Hadjadj S, Rosenstock J, Meinicke T, . Initial combination of empagliflozin and metformin in patients with type 2 diabetes. Diabetes Care. 2016 Oct;39(10):1718–28. doi: 10.2337/dc16-0522. PMID: 27493136. Exclusion Code: X2.27493136
967 Haering HU, Merker L, Christiansen AV, . Empagliflozin as add-on to metformin plus sulphonylurea in patients with type 2 diabetes. Diabetes Res Clin Pract. 2015 Oct;110(1):82–90. doi: 10.1016/j.diabres.2015.05.044. PMID: 26324220. Exclusion Code: X2.26324220
968 Hagberg KW, McGlynn KA, Sahasrabuddhe VV, . Anti-diabetic medications and risk of primary liver cancer in persons with type II diabetes. Br J Cancer. 2014 Oct 28;111(9):1710–7. doi: 10.1038/bjc.2014.447. PMID: 25093492. Exclusion Code: X2.25093492
969 Hage C, Brismar K, Lundman P, . The DPP-4 inhibitor sitagliptin and endothelial function in patients with acute coronary syndromes and newly detected glucose perturbations: a report from the BEGAMI study. Diab Vasc Dis Res. 2014;11(4):290–3. doi: 10.1177/1479164114533355. PMID: CN-00998279. Exclusion Code: X6.24845072
970 Haggstrom C, Van Hemelrijck M, Zethelius B, . Prospective study of Type 2 diabetes mellitus, anti-diabetic drugs and risk of prostate cancer. Int J Cancer. 2017 Feb 1;140(3):611–7. doi: 10.1002/ijc.30480. PMID: 27770555. Exclusion Code: X6.27770555
971 Haidinger M, Antlanger M, Kopecky C, . Post-transplantation diabetes mellitus: evaluation of treatment strategies. Clin Transplant. 2015 May;29(5):415–24. doi: 10.1111/ctr.12541. PMID: 25777150. Exclusion Code: X2.25777150
972 Haidinger M, Werzowa J, Hecking M, . Efficacy and safety of vildagliptin in new-onset diabetes after kidney transplantation--a randomized, double-blind, placebo-controlled trial. Am J Transplant. 2014 Jan;14(1):115–23. doi: 10.1111/ajt.12518. PMID: 24279801. Exclusion Code: X2.24279801
973 Haire-Joshu D, Schwarz CD, Steger-May K, . A randomized trial of weight change in a national home visiting program. Am J Prev Med. 2018 Mar;54(3):341–51. doi: 10.1016/j.amepre.2017.12.012. PMID: 29455756. Exclusion Code: X2.29455756
974 Hall K, Gregg J, Bosworth H, . Physical activity counseling promotes physical and psychological resilience in older veterans with posttraumatic stress disorder. Mental health and physical activity. 2016;11:53–9. doi: 10.1016/j.mhpa.2016.10.001. PMID: CN-01245156. Exclusion Code: X8.28458721
975 Halliday TM, Savla J, Marinik EL, . Resistance training is associated with spontaneous changes in aerobic physical activity but not overall diet quality in adults with prediabetes. Physiol Behav. 2017 Aug 1;177:49–56. doi: 10.1016/j.physbeh.2017.04.013. PMID: 28414072. Exclusion Code: X6.28414072
976 Halvari H, Healey J, Olafsen AH, . Physical activity and motivational predictors of changes in health behavior and health among DM2 and CAD patients. Scand J Med Sci Sports. 2017 Nov;27(11):1454–69. doi: 10.1111/sms.12757. PMID: 27688002. Exclusion Code: X6.27688002
977 Hamano K, Nishiyama H, Matsui A, . Efficacy and safety analyses across 4 subgroups combining low and high age and body mass index groups in Japanese phase 3 studies of dulaglutide 0.75 mg after 26 weeks of treatment. Endocr J. 2017 Apr 29;64(4):449–56. doi: 10.1507/endocrj.EJ16-0428. PMID: 28302958. Exclusion Code: X8.28302958
978 Hameed M, Khan K, Salman S, . Dose comparison and side effect profile of metformin extended release versus metformin immediate release. Journal of Ayub Medical College, Abbottabad. 2017;29(2):225–9. PMID: CN-01930802. Exclusion Code: X8.
979 Hamid S, Dunsiger S, Seiden A, . Impact of a diabetes control and management intervention on health care utilization in American Samoa. Chronic illness. 2014;10(2):122–34. doi: 10.1177/1742395313502367. PMID: CN-01050918. Exclusion Code: X2.24085749
980 Hamman RF, Horton E, Barrett-Connor E, . Factors affecting the decline in incidence of diabetes in the Diabetes Prevention Program Outcomes Study (DPPOS). Diabetes. 2015 Mar;64(3):989–98. doi: 10.2337/db14-0333. PMID: 25277389. Exclusion Code: X6.25277389
981 Han E, Jang SY, Kim G, . Rosiglitazone use and the risk of bladder cancer in patients with type 2 diabetes. Medicine (Baltimore). 2016 Feb;95(6):e2786. doi: 10.1097/md.0000000000002786. PMID: 26871835. Exclusion Code: X5.26871835
982 Han J, Yu H, Tu Y, . Different clinical prognostic factors are associated with improved glycaemic control: findings from MARCH randomized trial. Diabet Med. 2017 Apr;34(4):490–9. doi: 10.1111/dme.13154. PMID: 27151271. Exclusion Code: X6.27151271
983 Han K, Pintilie M, Lipscombe LL, . Association between metformin use and mortality after cervical cancer in older women with diabetes. Cancer Epidemiol Biomarkers Prev. 2016 Mar;25(3):507–12. doi: 10.1158/1055-9965.epi-15-1008. PMID: 26721670. Exclusion Code: X2.26721670
984 Han K, Yu J, Jang H, . Efficacy and safety of gemigliptin as add-on therapy in patients with type 2 diabetes inadequately controlled on metformin and glimepiride. Diabetes. Conference: 76th Scientific Sessions of the American Diabetes Association, ADA 2016. United states. 2016;65(Supplement 1):A307. doi: 10.2337/db16-861-1374. PMID: CN-01449898. Exclusion Code: X2.
985 Han KA, Yu JM, Jang HC, . Efficacy and safety of gemigliptin as add-on therapy in patients with type 2 diabetes inadequately controlled on metformin and glimepiride. Diabetes. 2016;65:A307-. doi: 10.2337/db16-861-1374. PMID: CN-01449898. Exclusion Code: X2.
986 Han S, Middleton P, Shepherd E, . Different types of dietary advice for women with gestational diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
987 Han S, Yoon S, Han B, . Comparative efficacy and safety of gemigliptin versus linagliptin in type 2 diabetes patients with renal impairment: a 40-week extension of the GUARD randomized study. Diabetes, obesity & metabolism. 2017;(no pagination)doi: 10.1111/dom.13059. PMID: CN-01418306. Exclusion Code: X5.
988 Han Y, Zhu G, Han L, . Short-term rosuvastatin therapy for prevention of contrast-induced acute kidney injury in patients with diabetes and chronic kidney disease. J Am Coll Cardiol. 2014 Jan 7–14;63(1):62–70. doi: 10.1016/j.jacc.2013.09.017. PMID: 24076297. Exclusion Code: X2.24076297
989 Hanai K, Babazono T, Uchigata Y. Effects of statins on the kidneys in patients with type 2 diabetes. Clin Exp Nephrol. 2017 Aug;21(4):633–42. doi: 10.1007/s10157-016-1329-x. PMID: 27631405. Exclusion Code: X2.27631405
990 Handelsman Y, Fain R, Wang Z, . Lorcaserin treatment allows for decreased number needed to treat for weight and glycemic parameters in week 12 responders with ?5% weight loss. Postgrad Med. 2016;128(8):740–6. doi: 10.1080/00325481.2016.1240591. PMID: CN-01263302. Exclusion Code: X2.27659698
991 Handelsman Y, Mathieu C, Prato S, . Sustained 52 week efficacy and safety of triple therapy with dapagliflozin + saxagliptin vs dual therapy with sitagliptin as addon to metformin in uncontrolled type 2 diabetes. Diabetologia. Conference: 53rd annual meeting of the european association for the study of diabetes, EASD 2017. Portugal. 2017;60(1 Supplement 1):S406. doi: 10.1007/s00125-017-4350-z. PMID: CN-01419014. Exclusion Code: X2.
992 Handelsman Y, Odeh S, Troupin B. Use of phentermine/topiramate extended-release (PHEN/TPM ER) in obese/overweight subjects with dysglycemia. Endocrine practice. 2014;20(1):40a–1a. PMID: CN-01061767. Exclusion Code: X4.
993 Handjieva-Darlenska T, Larsen T, Westerterp-Plantenga M, . Prevention of type 2 diabetes through diet and physical activity: the PREVIEW study. Vnitrni lekarstvi. Conference: 6th central european congress on obesity, CECON and 15th slovak congress on obesity. Slovakia. 2017;63(9 Supplement 2):2s20. PMID: CN-01470924. Exclusion Code: X6.
994 Hanefeld M, Arteaga JM, Leiter LA, . Efficacy and safety of lixisenatide in patients with type 2 diabetes and renal impairment. Diabetes Obes Metab. 2017 Nov;19(11):1594–601. doi: 10.1111/dom.12986. PMID: 28449324. Exclusion Code: X8.28449324
995 Hanefeld M, Berria R, Lin J, . Lixisenatide treatment for older patients with type 2 diabetes mellitus uncontrolled on oral antidiabetics: meta-analysis of five randomized controlled trials. Adv Ther. 2014 Aug;31(8):861–72. doi: 10.1007/s12325-014-0146-4. PMID: 25143188. Exclusion Code: X8.25143188
996 Hannon TS, Carroll AE, Palmer KN, . Rationale and design of a comparative effectiveness trial to prevent type 2 diabetes in mothers and children: the ENCOURAGE healthy families study. Contemp Clin Trials. 2015 Jan;40:105–11. doi: 10.1016/j.cct.2014.11.016. PMID: 25457793. Exclusion Code: X6.25457793
997 Hannon TS, Kirkman MS, Patel YR, . Profound defects in beta-cell function in screen-detected type 2 diabetes are not improved with glucose-lowering treatment in the Early Diabetes Intervention Program (EDIP). Diabetes Metab Res Rev. 2014 Nov;30(8):767–76. doi: 10.1002/dmrr.2553. PMID: 24819707. Exclusion Code: X6.24819707
998 Hanon O, Boully C, Caillard L, . Treatment of hypertensive patients with diabetes and microalbuminuria with combination indapamide SR/Amlodipine: retrospective analysis of NESTOR. Am J Hypertens. 2015 Aug;28(8):1064–71. doi: 10.1093/ajh/hpu297. PMID: 25628416. Exclusion Code: X2.25628416
999 Hanprasertpong J, Jiamset I, Geater A, . The effect of metformin on oncological outcomes in patients with cervical cancer with type 2 diabetes mellitus. Int J Gynecol Cancer. 2017 Jan;27(1):131–7. doi: 10.1097/igc.0000000000000855. PMID: 27870711. Exclusion Code: X8.27870711
1000 Hansel B, Giral P, Gambotti L, . A fully automated web-based program improves lifestyle habits and HbA1c in patients with type 2 diabetes and abdominal obesity: randomized trial of patient e-coaching nutritional support (The ANODE Study). J Med Internet Res. 2017 Nov 8;19(11):e360. doi: 10.2196/jmir.7947. PMID: 29117929. Exclusion Code: X6.29117929
1001 Hansen L, Zee P, Li Y, . Randomised, double-blind trial of dual add-on saxagliptin plus dapagliflozin vs saxagliptin or dapagliflozin add-on alone in poorly controlled type 2 diabetes on metformin. Diabetologia. 2014;57(1 suppl. 1):S8. doi: 10.1007/s00125-014-3355-0. PMID: CN-01055740. Exclusion Code: X2.
1002 Hansson L, Zanchetti A, Carruthers SG, . Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet. 1998 Jun 13;351(9118):1755–62. PMID: 9635947. Exclusion Code: X2.9635947
1003 Haque M, Shahjahan M, Haque M, . A regulatory approach on serum bilirubin level in subjects with impaired glucose tolerance. Mymensingh medical journal : MMJ. 2015;24(2):326–33. PMID: CN-01459655. Exclusion Code: X5.26007261
1004 Haring HU, Merker L, Seewaldt-Becker E, . Empagliflozin as add-on to metformin in patients with type 2 diabetes: a 24-week, randomized, double-blind, placebo-controlled trial. Diabetes Care. 2014 Jun;37(6):1650–9. doi: 10.2337/dc13-2105. PMID: 24722494. Exclusion Code: X2.24722494
1005 Harishankar MK, Logeshwaran S, Sujeevan S, . Genotoxicity evaluation of metformin and glimepiride by micronucleus assay in exfoliated urothelial cells of type 2 diabetes mellitus patients. Food Chem Toxicol. 2015 Sep;83:146–50. doi: 10.1016/j.fct.2015.06.013. PMID: 26115598. Exclusion Code: X6.26115598
1006 Harmer JA, Keech AC, Veillard AS, . Fenofibrate effects on arterial endothelial function in adults with type 2 diabetes mellitus: A FIELD substudy. Atherosclerosis. 2015 Sep;242(1):295–302. doi: 10.1016/j.atherosclerosis.2015.07.038. PMID: 26233916. Exclusion Code: X6.26233916
1007 Harmer JA, Keech AC, Veillard AS, . Fenofibrate effects on carotid artery intima-media thickness in adults with type 2 diabetes mellitus: A FIELD substudy. Diabetes Res Clin Pract. 2018 Jul;141:156–67. doi: 10.1016/j.diabres.2018.05.006. PMID: 29763709. Exclusion Code: X2.29763709
1008 Harris MD, Kirsh S, Higgins PA. Shared medical appointments: Impact on clinical and quality outcomes in veterans with diabetes. Qual Manag Health Care. 2016 Jul-Sep;25(3):176–80. doi: 10.1097/qmh.0000000000000098. PMID: 27367218. Exclusion Code: X2.27367218
1009 Harris S, Chew A. Predictors of weight loss in African Americans with prediabetes or early diabetes. Journal of the national medical association. 2014;106(1):8–14. PMID: CN-01041477. Exclusion Code: X6.26744110
1010 Harris SB, Kocsis G, Prager R, . Safety and efficacy of IDegLira titrated once weekly versus twice weekly in patients with type 2 diabetes uncontrolled on oral antidiabetic drugs: DUAL VI randomized clinical trial. Diabetes Obes Metab. 2017 Jun;19(6):858–65. doi: 10.1111/dom.12892. PMID: 28124817. Exclusion Code: X4.28124817
1011 Hartley L, Dyakova M, Holmes J, . Yoga for the primary prevention of cardiovascular disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
1012 Hartley L, May MD, Loveman E, . Dietary fibre for the primary prevention of cardiovascular disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
1013 Hartmann B, Bramlage P, Schneider S, . Impact of body weight on antidiabetic treatment and predictors of weight control under real-world conditions: a 2-year follow-up of DiaRegis cohort. Acta Diabetol. 2015 Dec;52(6):1093–101. doi: 10.1007/s00592-015-0794-0. PMID: 26239142. Exclusion Code: X5.26239142
1014 Harumi Higuchi Dos Santos M, Sharma A, Sun JL, . International variation in outcomes among people with cardiovascular disease or cardiovascular risk factors and impaired glucose tolerance: insights from the NAVIGATOR Trial. J Am Heart Assoc. 2017 Jan 13;6(1)doi: 10.1161/jaha.116.003892. PMID: 28087508. Exclusion Code: X2.28087508
1015 Hashemi R, Rahimlou M, Baghdadian S, . Investigating the effect of DASH diet on blood pressure of patients with type 2 diabetes and prehypertension: Randomized clinical trial. Diabetes Metab Syndr. 2019 Jan - Feb;13(1):1–4. doi: 10.1016/j.dsx.2018.06.014. PMID: 30641678. Exclusion Code: X6.30641678
1016 Hassan MH, Abd-Allah GM. Effects of metformin plus gliclazide versus metformin plus glimepiride on cardiovascular risk factors in patients with type 2 diabetes mellitus. Pak J Pharm Sci. 2015 Sep;28(5):1723–30. PMID: 26408873. Exclusion Code: X5.26408873
1017 Hassoun AA, Al-Arouj M, Ibrahim M. The effect of vildagliptin relative to sulfonylurea as dual therapy with metformin (or as monotherapy) in Muslim patients with type 2 diabetes fasting during Ramadan in the Middle East: the VIRTUE study. Curr Med Res Opin. 2017 Jan;33(1):161–7. doi: 10.1080/03007995.2016.1243093. PMID: 27684469. Exclusion Code: X2.27684469
1018 Hayashi T, Kubota K, Kawashima S, . Efficacy of HMG-CoA reductase inhibitors in the prevention of cerebrovascular attack in 1016 patients older than 75 years among 4014 type 2 diabetic individuals. Int J Cardiol. 2014 Dec 20;177(3):860–6. doi: 10.1016/j.ijcard.2014.10.093. PMID: 25466567. Exclusion Code: X2.25466567
1019 Hayes RP, DeLozier AM. Reliability, validity, and responsiveness of the Impact of Weight on Self-Perceptions Questionnaire (IW-SP) in individuals with type 2 diabetes and obesity. Diabetes Technol Ther. 2015 Mar;17(3):210–4. doi: 10.1089/dia.2014.0142. PMID: 25353705. Exclusion Code: X4.25353705
1020 He F, Liu M, Chen Z, . Assessment of human tribbles homolog 3 genetic variation (rs2295490) effects on type 2 diabetes patients with glucose control and blood pressure lowering treatment. EBioMedicine. 2016 Nov;13:181–9. doi: 10.1016/j.ebiom.2016.10.025. PMID: 27793583. Exclusion Code: X2.27793583
1021 Heaton PC, Desai VC, Kelton CM, . Sulfonylurea use and the risk of hospital readmission in patients with type 2 diabetes. BMC Endocr Disord. 2016 Jan 20;16:4. doi: 10.1186/s12902-016-0084-z. PMID: 26786291. Exclusion Code: X6.26786291
1022 Heerspink HJ, Johnsson E, Gause-Nilsson I, . Dapagliflozin reduces albuminuria in patients with diabetes and hypertension receiving renin-angiotensin blockers. Diabetes Obes Metab. 2016 Jun;18(6):590–7. doi: 10.1111/dom.12654. PMID: 26936519. Exclusion Code: X2.26936519
1023 Heerspink HJ, Ninomiya T, Persson F, . Is a reduction in albuminuria associated with renal and cardiovascular protection? A post hoc analysis of the ALTITUDE trial. Diabetes Obes Metab. 2016 Feb;18(2):169–77. doi: 10.1111/dom.12600. PMID: 26511599. Exclusion Code: X6.26511599
1024 Heerspink HJ, Persson F, Brenner BM, . Renal outcomes with aliskiren in patients with type 2 diabetes: a prespecified secondary analysis of the ALTITUDE randomised controlled trial. Lancet Diabetes Endocrinol. 2016 Apr;4(4):309–17. doi: 10.1016/s2213-8587(15)00469-6. PMID: 26774608. Exclusion Code: X2.26774608
1025 Heianza Y, Suzuki A, Fujihara K, . Impact on short-term glycaemic control of initiating diabetes care versus leaving diabetes untreated among individuals with newly screening-detected diabetes in Japan. J Epidemiol Community Health. 2014 Dec;68(12):1189–95. doi: 10.1136/jech-2014-204054. PMID: 25187645. Exclusion Code: X8.25187645
1026 Heise T, Morrow L, Hompesch M, . Safety, efficacy and weight effect of two 11?-HSD1 inhibitors in metformin-treated patients with type 2 diabetes. Diabetes, obesity & metabolism. 2014;16(11):1070–7. doi: 10.1111/dom.12317. PMID: CN-01116608. Exclusion Code: X2.
1027 Heise T, Morrow L, Hompesch M, . Safety, efficacy and weight effect of two 11beta-HSD1 inhibitors in metformin-treated patients with type 2 diabetes. Diabetes Obes Metab. 2014 Nov;16(11):1070–7. doi: 10.1111/dom.12317. PMID: 24828020. Exclusion Code: X6.24828020
1028 Heiskanen MA, Motiani KK, Mari A, . Exercise training decreases pancreatic fat content and improves beta cell function regardless of baseline glucose tolerance: a randomised controlled trial. Diabetologia. 2018 Aug;61(8):1817–28. doi: 10.1007/s00125-018-4627-x. PMID: 29717337. Exclusion Code: X5.29717337
1029 Heisler M, Choi H, Palmisano G, . Comparison of community health worker-led diabetes medication decision-making support for low-income Latino and African American adults with diabetes using e-health tools versus print materials: a randomized, controlled trial. Ann Intern Med. 2014 Nov 18;161(10 Suppl):S13–22. doi: 10.7326/m13-3012. PMID: 25402398. Exclusion Code: X4.25402398
1030 Heisler M, Mase R, Brown B, . Study protocol: the Technology-Enhanced Coaching (TEC) program to improve diabetes outcomes - A randomized controlled trial. Contemp Clin Trials. 2017;55:24–33. doi: 10.1016/j.cct.2017.01.006. PMID: CN-01944694. Exclusion Code: X6.28132876
1031 Heller SR, Bergenstal RM, White WB, . Relationship of glycated haemoglobin and reported hypoglycaemia to cardiovascular outcomes in patients with type 2 diabetes and recent acute coronary syndrome events: The EXAMINE trial. Diabetes Obes Metab. 2017 May;19(5):664–71. doi: 10.1111/dom.12871. PMID: 28058763. Exclusion Code: X2.28058763
1032 Heltberg A, Andersen JS, Sandholdt H, . Predictors of undiagnosed prevalent type 2 diabetes - the Danish general suburban population study. Prim Care Diabetes. 2018 Feb;12(1):13–22. doi: 10.1016/j.pcd.2017.08.005. PMID: 28964672. Exclusion Code: X8.28964672
1033 Hemmati Maslakpak M, Razmara S, Niazkhani Z. Effects of face-to-face and telephone-based family-oriented education on self-care behavior and patient outcomes in type 2 diabetes: a randomized controlled trial. Journal of diabetes research. 2017;2017:8404328. doi: 10.1155/2017/8404328. PMID: CN-01627461. Exclusion Code: X2.29359166
1034 Hemmingsen B, Krogh J, Metzendorf M-I, . Sodium-glucose cotransporter (SGLT) 2 inhibitors for prevention or delay of type 2 diabetes mellitus and its associated complications in people at risk for the development of type 2 diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
1035 Hemmingsen B, Lund SS, Gluud C, . Intensive glycaemic control for patients with type 2 diabetes: systematic review with meta-analysis and trial sequential analysis of randomised clinical trials. BMJ. 2011 Nov 24;343:d6898. doi: 10.1136/bmj.d6898. PMID: 22115901. Exclusion Code: X8.22115901
1036 Hemmingsen B, Lund SS, Gluud C, . Targeting intensive glycaemic control versus targeting conventional glycaemic control for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2013 Nov 11(11):CD008143. doi: 10.1002/14651858.CD008143.pub3. PMID: 2421428024214280. Exclusion Code: X8.
1037 Hemmingsen B, Schroll JB, Lund SS, . Sulphonylurea monotherapy for patients with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
1038 Hemmingsen B, Sonne DP, Metzendorf MI, . Insulin secretagogues for prevention or delay of type 2 diabetes mellitus and its associated complications in persons at increased risk for the development of type 2 diabetes mellitus. Cochrane Database Syst Rev. 2016 Oct 17;10:Cd012151. doi: 10.1002/14651858.CD012151.pub2. PMID: 27749986. Exclusion Code: X8.27749986
1039 Hemmingsen B, Sonne DP, Metzendorf M-I, . Dipeptidyl-peptidase (DPP)-4 inhibitors and glucagon-like peptide (GLP)-1 analogues for prevention or delay of type 2 diabetes mellitus and its associated complications in people at increased risk for the development of type 2 diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
1040 Henderson D, Frieson D, Zuber J, . Metformin has positive therapeutic effects in colon cancer and lung cancer. Am J Med Sci. 2017 Sep;354(3):246–51. doi: 10.1016/j.amjms.2017.05.006. PMID: 28918830. Exclusion Code: X2.28918830
1041 Henry RR, Buse JB, Wu H, . Efficacy, safety and tolerability of aleglitazar in patients with type 2 diabetes: pooled findings from three randomized phase III trials. Diabetes Obes Metab. 2015 Jun;17(6):560–5. doi: 10.1111/dom.12455. PMID: 25728612. Exclusion Code: X8.25728612
1042 Henry RR, Frias JP, Walsh B, . Improved glycemic control with minimal systemic metformin exposure: Effects of Metformin Delayed-Release (Metformin DR) targeting the lower bowel over 16 weeks in a randomized trial in subjects with type 2 diabetes. PLoS One. 2018;13(9):e0203946. doi: 10.1371/journal.pone.0203946. PMID: 30252913. Exclusion Code: X2.30252913
1043 Henry RR, Klein EJ, Han J, . Efficacy and tolerability of exenatide once weekly over 6 years in patients with type 2 diabetes: an uncontrolled open-label extension of the DURATION-1 Study. Diabetes Technol Ther. 2016 Nov;18(11):677–86. doi: 10.1089/dia.2016.0107. PMID: 27525540. Exclusion Code: X2.27525540
1044 Henry RR, Rosenstock J, Logan D, . Continuous subcutaneous delivery of exenatide via ITCA 650 leads to sustained glycemic control and weight loss for 48 weeks in metformin-treated subjects with type 2 diabetes. J Diabetes Complications. 2014 May-Jun;28(3):393–8. doi: 10.1016/j.jdiacomp.2013.12.009. PMID: 24631129. Exclusion Code: X5.24631129
1045 Henry RR, Staels B, Fonseca VA, . Efficacy and safety of initial combination treatment with sitagliptin and pioglitazone--a factorial study. Diabetes Obes Metab. 2014 Mar;16(3):223–30. doi: 10.1111/dom.12194. PMID: 23909985. Exclusion Code: X5.23909985
1046 Herman WH, Pan Q, Edelstein SL, . Impact of lifestyle and metformin interventions on the risk of progression to diabetes and regression to normal glucose regulation in overweight or obese people with impaired glucose regulation. Diabetes Care. 2017 Dec;40(12):1668–77. doi: 10.2337/dc17-1116. PMID: 29021207. Exclusion Code: X8.29021207
1047 Hermanns N, Ehrmann D, Schall S, . The effect of an education programme (MEDIAS 2 BSC) of non-intensive insulin treatment regimens for people with Type 2 diabetes: a randomized, multi-centre trial. Diabet Med. 2017 Aug;34(8):1084–91. doi: 10.1111/dme.13346. PMID: 28257159. Exclusion Code: X2.28257159
1048 Hernandez AF, Green JB, Janmohamed S, . Albiglutide and cardiovascular outcomes in patients with type 2 diabetes and cardiovascular disease (Harmony Outcomes): a double-blind, randomised placebo-controlled trial. Lancet. 2018 Oct 27;392(10157):1519–29. doi: 10.1016/s0140-6736(18)32261-x. PMID: 30291013. Exclusion Code: X2.30291013
1049 Herrmann M, Sullivan DR, Veillard AS, . Serum 25-hydroxyvitamin D: a predictor of macrovascular and microvascular complications in patients with type 2 diabetes. Diabetes Care. 2015 Mar;38(3):521–8. doi: 10.2337/dc14-0180. PMID: 25524951. Exclusion Code: X4.25524951
1050 Herzig KH, Ahola R, Leppaluoto J, . Light physical activity determined by a motion sensor decreases insulin resistance, improves lipid homeostasis and reduces visceral fat in high-risk subjects: PreDiabEx study RCT. Int J Obes (Lond). 2014 Aug;38(8):1089–96. doi: 10.1038/ijo.2013.224. PMID: 24285336. Exclusion Code: X6.24285336
1051 Hesselink AE, Rutten GE, Slootmaker SM, . Effects of a lifestyle program in subjects with Impaired Fasting Glucose, a pragmatic cluster-randomized controlled trial. BMC Fam Pract. 2015 Dec 22;16:183. doi: 10.1186/s12875-015-0394-7. PMID: 26695176. Exclusion Code: X11.26695176
1052 Hessler D, Fisher L, Glasgow R, . Reductions in regimen distress are associated with improved management and glycemic control over time. Diabetes care. 2014;37(3):617–24. doi: 10.2337/dc13-0762. PMID: CN-00981867. Exclusion Code: X2.24170750
1053 Heymann AD, Ravona-Springer R, Moshier EL, . Statin use is associated with better cognitive function in elderly with type 2 diabetes. J Alzheimers Dis. 2015;47(1):55–9. doi: 10.3233/jad-142571. PMID: 26402754. Exclusion Code: X6.26402754
1054 Heymsfield SB, Segal KR, Hauptman J, . Effects of weight loss with orlistat on glucose tolerance and progression to type 2 diabetes in obese adults. Arch Intern Med. 2000 May 8;160(9):1321–6. PMID: 10809036. Exclusion Code: X8.10809036
1055 Hibuse T, Maeda N, Kishida K, . A pilot three-month sitagliptin treatment increases serum adiponectin level in Japanese patients with type 2 diabetes mellitus--a randomized controlled trial START-J study. Cardiovasc Diabetol. 2014 May 24;13:96. doi: 10.1186/1475-2840-13-96. PMID: 24884787. Exclusion Code: X2.24884787
1056 Hibuse T, Maeda N, Kishida K, . A pilot three-month sitagliptin treatment increases serum adiponectin level in Japanese patients with type 2 diabetes mellitus- a randomized controlled trial START-J study. Cardiovasc Diabetol. 2014;13(1)doi: 10.1186/1475-2840-13-96. PMID: CN-00996329. Exclusion Code: X2.
1057 Hickman MA, Patel S, Lauring B, . Incidence of urinary tract infections in patients with type 2 diabetes mellitus receiving ertugliflozin, placebo or active comparator. Endocr Rev. 2018;39(2)PMID: CN-01620359. Exclusion Code: X8.
1058 Hickman MA, Patel S, Lauring B, . Incidence of urinary tract infections in patients with type 2 diabetes receiving ertugliflozin, placebo or active comparator. Diabetologia. 2018;61:S306-. doi: 10.1007/s00125-018-4693-0. PMID: CN-01647112. Exclusion Code: X8.
1059 Hicks BM, Yin H, Sinyavskaya L, . Metformin and the incidence of viral associated cancers in patients with type 2 diabetes. Int J Cancer. 2017 Jul 1;141(1):121–8. doi: 10.1002/ijc.30733. PMID: 28393359. Exclusion Code: X6.28393359
1060 Hicks BM, Yin H, Yu OH, . Glucagon-like peptide-1 analogues and risk of breast cancer in women with type 2 diabetes: population based cohort study using the UK Clinical Practice Research Datalink. Bmj. 2016 Oct 20;355:i5340. doi: 10.1136/bmj.i5340. PMID: 27797785. Exclusion Code: X5.27797785
1061 Hippisley-Cox J, Coupland C. Diabetes treatments and risk of heart failure, cardiovascular disease, and all cause mortality: cohort study in primary care. Bmj. 2016 Jul 12;354:i3477. doi: 10.1136/bmj.i3477. PMID: 27413012. Exclusion Code: X5.27413012
1062 Hippisley-Cox J, Coupland C. Diabetes treatments and risk of amputation, blindness, severe kidney failure, hyperglycaemia, and hypoglycaemia: open cohort study in primary care. Bmj. 2016 Mar 30;352:i1450. doi: 10.1136/bmj.i1450. PMID: 27029547. Exclusion Code: X2.27029547
1063 Hirakawa Y, Arima H, Webster R, . Risks associated with permanent discontinuation of blood pressure-lowering medications in patients with type 2 diabetes. J Hypertens. 2016 Apr;34(4):781–7. doi: 10.1097/hjh.0000000000000841. PMID: 26938813. Exclusion Code: X2.26938813
1064 Hirakawa Y, Arima H, Zoungas S, . Impact of visit-to-visit glycemic variability on the risks of macrovascular and microvascular events and all-cause mortality in type 2 diabetes: the ADVANCE trial. Diabetes Care. 2014 Aug;37(8):2359–65. doi: 10.2337/dc14-0199. PMID: 24812434. Exclusion Code: X2.24812434
1065 Hirose T, Suzuki M, Tsumiyama I. Efficacy and safety of vildagliptin as an add-on to insulin with or without metformin in japanese patients with type 2 diabetes mellitus: a 12-week, double-blind, randomized study. Diabetes therapy. 2015;6(4):559–71. doi: 10.1007/s13300-015-0147-6. PMID: CN-01125281. Exclusion Code: X2.26620049
1066 Hirshberg B, Parker A, Edelberg H, . Safety of saxagliptin: events of special interest in 9156 patients with type 2 diabetes mellitus. Diabetes Metab Res Rev. 2014 Oct;30(7):556–69. doi: 10.1002/dmrr.2502. PMID: 24376173. Exclusion Code: X8.24376173
1067 Hirukawa H, Hashiramoto M, Tanizawa Y, . Remission of hyperglycemia after withdrawal of oral antidiabetic drugs in Japanese patients with early-stage type 2 diabetes. J Diabetes Investig. 2018 Sep;9(5):1119–27. doi: 10.1111/jdi.12813. PMID: 29406607. Exclusion Code: X5.29406607
1068 Hivert MF, Christophi CA, Franks PW, . Lifestyle and metformin ameliorate insulin sensitivity independently of the genetic burden of established insulin resistance variants in diabetes prevention program participants. Diabetes. 2016 Feb;65(2):520–6. doi: 10.2337/db15-0950. PMID: 26525880. Exclusion Code: X6.26525880
1069 Hivert MF, Christophi CA, Jablonski KA, . Genetic ancestry markers and difference in A1c between African American and White in the Diabetes Prevention Program. J Clin Endocrinol Metab. 2019 Feb 1;104(2):328–36. doi: 10.1210/jc.2018-01416. PMID: 30358859. Exclusion Code: X5.30358859
1070 Hjerpsted JB, Flint A, Brooks A, . Semaglutide improves postprandial glucose and lipid metabolism, and delays first-hour gastric emptying in subjects with obesity. Diabetes Obes Metab. 2018 Mar;20(3):610–9. doi: 10.1111/dom.13120. PMID: 28941314. Exclusion Code: X2.28941314
1071 Hjorth MF, Astrup A, Zohar Y, . Personalized nutrition: pretreatment glucose metabolism determines individual long-term weight loss responsiveness in individuals with obesity on low-carbohydrate versus low-fat diet. International journal of obesity. 2018doi: 10.1038/s41366-018-0298-4. PMID: CN-01752918. Exclusion Code: X5.
1072 Ho MJ, Li EC, Wright JM. Blood pressure lowering efficacy of coenzyme Q10 for primary hypertension. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
1073 Hoekman J, Lambers Heerspink HJ, Viberti G, . Predictors of congestive heart failure after treatment with an endothelin receptor antagonist. Clin J Am Soc Nephrol. 2014 Mar;9(3):490–8. doi: 10.2215/cjn.07040713. PMID: 24408122. Exclusion Code: X5.24408122
1074 Holland-Carter L, Tuerk PW, Wadden TA, . Impact on psychosocial outcomes of a nationally available weight management program tailored for individuals with type 2 diabetes: Results of a randomized controlled trial. J Diabetes Complications. 2017 May;31(5):891–7. doi: 10.1016/j.jdiacomp.2017.01.022. PMID: 28319001. Exclusion Code: X4.28319001
1075 Hollander P, Hill J, Johnson J, . Results of VERTIS SU extension study: safety and efficacy of ertugliflozin treatment over 104 weeks compared to glimepiride in patients with type 2 diabetes mellitus inadequately controlled on metformin. Curr Med Res Opin. 2019doi: 10.1080/03007995.2019.1583450. PMID: CN-01938994. Exclusion Code: X5.
1076 Hollander P, Liu J, Hill J, . Safety and efficacy of ertugliflozin compared to glimepiride in patients with type 2 diabetes inadequately controlled on metformin: the VERTIS SU trial. Diabetologia. Conference: 53rd annual meeting of the european association for the study of diabetes, EASD 2017. Portugal. 2017;60(1 Supplement 1):S19–s20. doi: 10.1007/s00125-017-4350-z. PMID: CN-01418954. Exclusion Code: X5.
1077 Hollander P, Mathieu C, Tong C, . Canagliflozin provides reductions in HbA_1c_, body weight, and blood pressure in patients with type 2 diabetes on metformin with or without other antihyperglycaemic agents. Diabetologia. 2015;58(1 suppl. 1):S352. doi: 10.1007/s00125-015-3687-4. PMID: CN-01136800. Exclusion Code: X2.
1078 Holman R, Bethel M, Chan J, . Rationale for and design of the Acarbose Cardiovascular Evaluation (ACE) trial. Am Heart J. 2014;168(1):23–9.e2. doi: 10.1016/j.ahj.2014.03.021. PMID: CN-00995351. Exclusion Code: X6.24952856
1079 Holman RR, Bethel MA, George J, . Rationale and design of the EXenatide Study of Cardiovascular Event Lowering (EXSCEL) trial. Am Heart J. 2016 Apr;174:103–10. doi: 10.1016/j.ahj.2015.12.009. PMID: 26995376. Exclusion Code: X6.26995376
1080 Holman RR, Bethel MA, Mentz RJ, . Effects of once-weekly exenatide on cardiovascular outcomes in type 2 diabetes. N Engl J Med. 2017 Sep 28;377(13):1228–39. doi: 10.1056/NEJMoa1612917. PMID: 28910237. Exclusion Code: X2.28910237
1081 Holtrop JS, Luo Z, Piatt G, . Diabetic and obese patient clinical outcomes improve during a care management implementation in primary care. J Prim Care Community Health. 2017 Oct;8(4):312–8. doi: 10.1177/2150131917715536. PMID: 28645227. Exclusion Code: X6.28645227
1082 Home P, Ahrén B, Reusch J, . Three-year data from 5 HARMONY phase 3 clinical trials of albiglutide in type 2 diabetes mellitus: long-term efficacy with or without rescue therapy. Diabetes Res Clin Pract. 2017;131:49–60. doi: 10.1016/j.diabres.2017.06.013. PMID: CN-01396436. Exclusion Code: X2.28683300
1083 Home P, Shankar RR, Gantz I, . A randomized, double-blind trial evaluating the efficacy and safety of monotherapy with the once-weekly dipeptidyl peptidase-4 inhibitor omarigliptin in people with type 2 diabetes. Diabetes Res Clin Pract. 2018 Apr;138:253–61. doi: 10.1016/j.diabres.2017.10.018. PMID: 29079379. Exclusion Code: X2.29079379
1084 Home PD, Shamanna P, Stewart M, . Efficacy and tolerability of albiglutide versus placebo or pioglitazone over 1 year in people with type 2 diabetes currently taking metformin and glimepiride: HARMONY 5. Diabetes Obes Metab. 2015 Feb;17(2):179–87. doi: 10.1111/dom.12414. PMID: 25406730. Exclusion Code: X2.25406730
1085 Hompesch M, Jones-Leone A, Carr MC, . Albiglutide does not impair the counter-regulatory hormone response to hypoglycaemia: a randomized, double-blind, placebo-controlled, stepped glucose clamp study in subjects with type 2 diabetes mellitus. Diabetes Obes Metab. 2015 Jan;17(1):82–90. doi: 10.1111/dom.12398. PMID: 25263215. Exclusion Code: X4.25263215
1086 Honda T, Kuwahara K, Nakagawa T, . Leisure-time, occupational, and commuting physical activity and risk of type 2 diabetes in Japanese workers: a cohort study. BMC Public Health. 2015 Oct 2;15:1004. doi: 10.1186/s12889-015-2362-5. PMID: 26431831. Exclusion Code: X5.26431831
1087 Honkala S, Motiani K, Eskelinen J, . Exercise training reduces intrathoracic fat regardless of defective glucose tolerance. Med Sci Sports Exerc. 2017;49(7):1313–22. doi: 10.1249/MSS.0000000000001232. PMID: CN-01426171. Exclusion Code: X5.28628064
1088 Hoogeveen RC, Dorresteijn JA, Kriegsman DM, . Complex interventions for preventing diabetic foot ulceration. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
1089 Hoogwerf BJ, Lincoff AM, Rodriguez A, . Major adverse cardiovascular events with basal insulin peglispro versus comparator insulins in patients with type 1 or type 2 diabetes: a meta-analysis. Cardiovasc Diabetol. 2016 May 17;15:78. doi: 10.1186/s12933-016-0393-6. PMID: 27188479. Exclusion Code: X8.27188479
1090 Hooper L, Abdelhamid A, Bunn D, . Effects of total fat intake on body weight. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
1091 Hooper L, Al-Khudairy L, Abdelhamid AS, . Omega-6 fats for the primary and secondary prevention of cardiovascular disease. Cochrane Database of Systematic Reviews. 2018(11)doi: 10.1002/14651858.CD011094.pub4. PMID: CD011094. Exclusion Code: X8.
1092 Hooper L, Martin N, Abdelhamid A, . Reduction in saturated fat intake for cardiovascular disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
1093 Hopper I, Billah B, Skiba M, . Prevention of diabetes and reduction in major cardiovascular events in studies of subjects with prediabetes: meta-analysis of randomised controlled clinical trials (Structured abstract). European Journal of Cardiovascular Prevention and Rehabilitation; 2011. p. 813–23. Exclusion Code: X8.
1094 Horigan G, Davies M, Findlay-White F, . Reasons why patients referred to diabetes education programmes choose not to attend: a systematic review. Diabet Med. 2017 Jan;34(1):14–26. doi: 10.1111/dme.13120. PMID: 26996982. Exclusion Code: X8.26996982
1095 Hornbak M, Allin KH, Jensen ML, . A combined analysis of 48 type 2 diabetes genetic risk variants shows no discriminative value to predict time to first prescription of a glucose lowering drug in Danish patients with screen detected type 2 diabetes. PLoS One. 2014;9(8):e104837. doi: 10.1371/journal.pone.0104837. PMID: 25157406. Exclusion Code: X6.25157406
1096 Hoskin M, Bray G, Hattaway K, . Prevention of diabetes through lifestyle intervention: lessons learned from the diabetes prevention program and outcomes study and its translation to practice. Current nutrition reports. 2014;3(4 // () *American Diabetes Association*):364–78. doi: 10.1007/s13668-014-0094-2. PMID: CN-01054024. Exclusion Code: X8.25383256
1097 Hoste J, Daci E, Mathieu C. Effectiveness and tolerability of second-line therapy with vildagliptin versus other oral agents in type 2 diabetes (EDGE): post-hoc subanalysis of the Belgian data. Acta Clin Belg. 2014 Jun;69(3):171–6. doi: 10.1179/2295333714y.0000000018. PMID: 24820924. Exclusion Code: X2.24820924
1098 Hou WH, Chang KC, Li CY, . Dipeptidyl peptidase-4 inhibitor use is not associated with elevated risk of severe joint pain in patients with type 2 diabetes: a population-based cohort study. Pain. 2016 Sep;157(9):1954–9. doi: 10.1097/j.pain.0000000000000596. PMID: 27127847. Exclusion Code: X5.27127847
1099 Hou YC, Hu Q, Huang J, . Metformin therapy and the risk of colorectal adenoma in patients with type 2 diabetes: a meta-analysis. Oncotarget. 2017 Jan 31;8(5):8843–53. doi: 10.18632/oncotarget.13633. PMID: 27903961. Exclusion Code: X8.27903961
1100 Houle J, Beaulieu MD, Chiasson JL, . Glycaemic control and self-management behaviours in Type 2 diabetes: results from a 1-year longitudinal cohort study. Diabet Med. 2015 Sep;32(9):1247–54. doi: 10.1111/dme.12686. PMID: 25581545. Exclusion Code: X2.25581545
1101 Houston DK, Leng X, Bray GA, . A long-term intensive lifestyle intervention and physical function: the look AHEAD Movement and Memory Study. Obesity (Silver Spring). 2015 Jan;23(1):77–84. doi: 10.1002/oby.20944. PMID: 25452229. Exclusion Code: X6.25452229
1102 Howard BV, Aragaki AK, Tinker LF, . A low-fat dietary pattern and diabetes: a secondary analysis from the Women’s Health Initiative Dietary Modification Trial. Diabetes care. 2018;41(4):680–7. doi: 10.2337/dc17-0534. PMID: CN-01570962. Exclusion Code: X2.29282203
1103 Howard BV, Roman MJ, Devereux RB, . Effect of lower targets for blood pressure and LDL cholesterol on atherosclerosis in diabetes: the SANDS randomized trial. JAMA. 2008 Apr 9;299(14):1678–89. doi: 10.1001/jama.299.14.1678. PMID: 18398080. Exclusion Code: X2.18398080
1104 Hoyer A, Rathmann W, Kuss O. Utility of HbA1c and fasting plasma glucose for screening of Type 2 diabetes: a meta-analysis of full ROC curves. Diabet Med. 2018 Mar;35(3):317–22. doi: 10.1111/dme.13560. PMID: 29230866. Exclusion Code: X8.29230866
1105 Hsieh HM, Lin TH, Lee IC, . The association between participation in a pay-for-performance program and macrovascular complications in patients with type 2 diabetes in Taiwan: A nationwide population-based cohort study. Prev Med. 2016 Apr;85:53–9. doi: 10.1016/j.ypmed.2015.12.013. PMID: 26740347. Exclusion Code: X4.26740347
1106 Hsieh PL, Tseng CH, Tseng YJ, . Resistance training improves muscle function and cardiometabolic risks but not quality of life in older people with type 2 diabetes mellitus: a randomized controlled trial. J Geriatr Phys Ther. 2018 Apr/Jun;41(2):65–76. doi: 10.1519/jpt.0000000000000107. PMID: 27893563. Exclusion Code: X2.27893563
1107 Hsu CY, Chen YT, Su YW, . Statin therapy reduces future risk of lower-limb amputation in patients with diabetes and peripheral artery disease. J Clin Endocrinol Metab. 2017 Jul 1;102(7):2373–81. doi: 10.1210/jc.2016-3717. PMID: 28398564. Exclusion Code: X2.28398564
1108 Hsu JC, Cheng CL, Ross-Degnan D, . Effects of safety warnings and risk management plan for Thiazolidinediones in Taiwan. Pharmacoepidemiol Drug Saf. 2015 Oct;24(10):1026–35. doi: 10.1002/pds.3834. PMID: 26251229. Exclusion Code: X6.26251229
1109 Hsu W, Lau K, Matsumoto M, . Improvement of insulin sensitivity by isoenergy high carbohydrate traditional Asian diet: a randomized controlled pilot feasibility study. Plos one. 2014;9(9):e106851. doi: 10.1371/journal.pone.0106851. PMID: CN-01113742. Exclusion Code: X6.25226279
1110 Hsu WC, Lau KH, Huang R, . Utilization of a cloud-based diabetes management program for insulin initiation and titration enables collaborative decision making between healthcare providers and patients. Diabetes Technol Ther. 2016 Feb;18(2):59–67. doi: 10.1089/dia.2015.0160. PMID: 26645932. Exclusion Code: X6.26645932
1111 Htike ZZ, Zaccardi F, Papamargaritis D, . Efficacy and safety of glucagon-like peptide-1 receptor agonists in type 2 diabetes: a systematic review and mixed-treatment comparison analysis. Diabetes Obes Metab. 2017 Apr;19(4):524–36. doi: 10.1111/dom.12849. PMID: 27981757. Exclusion Code: X8.27981757
1112 Hu H, Yuan G, Wang X, . Effects of a diet with or without physical activity on angiopoietin-like protein 8 concentrations in overweight/obese patients with newly diagnosed type 2 diabetes: a randomized controlled trial. Endocr J. 2019 Jan 28;66(1):89–105. doi: 10.1507/endocrj.EJ18-0191. PMID: 30429410. Exclusion Code: X2.30429410
1113 Hu J, Chen JB, Cui Y, . Association of metformin intake with bladder cancer risk and oncologic outcomes in type 2 diabetes mellitus patients: A systematic review and meta-analysis. Medicine (Baltimore). 2018 Jul;97(30):e11596. doi: 10.1097/md.0000000000011596. PMID: 30045293. Exclusion Code: X8.30045293
1114 Hu W, Fan X, Zhou B, . Circulating alarin concentrations are high in patients with type 2 diabetes and increased by glucagon-like peptide-1 receptor agonist treatment: An Consort-compliant study. Medicine (Baltimore). 2019 Jul;98(28):e16428. doi: 10.1097/md.0000000000016428. PMID: 31305464. Exclusion Code: X8.31305464
1115 Hu X, He X, Ma X, . A decrease in serum 1,5-anhydroglucitol levels is associated with the presence of a first-degree family history of diabetes in a Chinese population with normal glucose tolerance. Diabet Med. 2018 Jan;35(1):131–6. doi: 10.1111/dme.13534. PMID: 29057494. Exclusion Code: X5.29057494
1116 Huang C, Lai H, Chen C, . Effects of motivational enhancement therapy plus cognitive behaviour therapy on depressive symptoms and health-related quality of life in adults with type II diabetes mellitus: a randomised controlled trial. Quality of life research. 2016;25(5):1275–83. doi: 10.1007/s11136-015-1165-6. PMID: CN-01153251. Exclusion Code: X2.26497665
1117 Huang R, Feng Y, Wang Y, . Comparative efficacy and safety of antihypertensive agents for adult diabetic patients with microalbuminuric kidney disease: a network meta-analysis. PLoS One. 2017;12(1):e0168582. doi: 10.1371/journal.pone.0168582. PMID: 28045910. Exclusion Code: X8.28045910
1118 Huang W, Castelino RL, Peterson GM. Lactic acidosis and the relationship with metformin usage: case reports. Medicine (Baltimore). 2016 Nov;95(46):e4998. doi: 10.1097/md.0000000000004998. PMID: 27861334. Exclusion Code: X8.27861334
1119 Huang Y, Abdelmoneim AS, Light P, . Comparative cardiovascular safety of insulin secretagogues following hospitalization for ischemic heart disease among type 2 diabetes patients: a cohort study. J Diabetes Complications. 2015 Mar;29(2):196–202. doi: 10.1016/j.jdiacomp.2014.11.012. PMID: 25534984. Exclusion Code: X2.25534984
1120 Huang Y, Sun J, Wang X, . Asymptomatic chronic gastritis decreases metformin tolerance in patients with type 2 diabetes. J Clin Pharm Ther. 2015 Aug;40(4):461–5. doi: 10.1111/jcpt.12290. PMID: 26032654. Exclusion Code: X2.26032654
1121 Huang Y, Sun J, Wang X, . Helicobacter pylori infection decreases metformin tolerance in patients with type 2 diabetes mellitus. Diabetes Technol Ther. 2015;17(2):128–33. doi: 10.1089/dia.2014.0203. PMID: CN-01052952. Exclusion Code: X2.25391019
1122 Huang YQ, Yang QF, Wang H, . Long-term clinical effect of Tangyiping Granules () on patients with impaired glucose tolerance. Chin J Integr Med. 2016 Sep;22(9):653–9. doi: 10.1007/s11655-016-2512-3. PMID: 27614450. Exclusion Code: X4.27614450
1123 Hubers SA, Wilson JR, Yu C, . DPP (dipeptidyl peptidase)-4 inhibition potentiates the vasoconstrictor response to NPY (Neuropeptide Y) in humans during renin-angiotensin-aldosterone system inhibition. Hypertension. 2018 Sep;72(3):712–9. doi: 10.1161/hypertensionaha.118.11498. PMID: 29987109. Exclusion Code: X8.29987109
1124 Huebschmann AG, Leavitt IM, Glasgow R, . A reimbursable counseling intervention improves physical activity and function for primary care patients with type 2 diabetes. Diabetes. 2018;67:A228–A9. PMID: CN-01631440. Exclusion Code: X6.
1125 Huffman KM, Sun JL, Thomas L, . Impact of baseline physical activity and diet behavior on metabolic syndrome in a pharmaceutical trial: results from NAVIGATOR. Metabolism. 2014 Apr;63(4):554–61. doi: 10.1016/j.metabol.2014.01.002. PMID: 24559843. Exclusion Code: X8.24559843
1126 Hung JD, Murray SW, Shaw MA, . Impact of a low carbohydrate diet on traditional CVD risk factors in people with features of the metabolic syndrome and type 2 diabetes. European journal of preventive cardiology. 2018;25(2):S14–S5. PMID: CN-01620675. Exclusion Code: X8.
1127 Hung JY, Chen PF, Livneh H, . Long-term effectiveness of the Diabetes Conversation Map Program: a prepost education intervention study among type 2 diabetic patients in Taiwan. Medicine (Baltimore). 2017 Sep;96(36):e7912. doi: 10.1097/md.0000000000007912. PMID: 28885345. Exclusion Code: X6.28885345
1128 Hung SC, Chang YK, Liu JS, . Metformin use and mortality in patients with advanced chronic kidney disease: national, retrospective, observational, cohort study. Lancet Diabetes Endocrinol. 2015 Aug;3(8):605–14. doi: 10.1016/s2213-8587(15)00123-0. PMID: 26094107. Exclusion Code: X2.26094107
1129 Hunger M, Holle R, Meisinger C, . Longitudinal changes in health-related quality of life in normal glucose tolerance, prediabetes and type 2 diabetes: results from the KORA S4/F4 cohort study. Qual Life Res. 2014 Nov;23(9):2515–20. doi: 10.1007/s11136-014-0689-5. PMID: 24729056. Exclusion Code: X5.24729056
1130 Hunt K, Gray CM, Maclean A, . Do weight management programmes delivered at professional football clubs attract and engage high risk men? A mixed-methods study. BMC Public Health. 2014 Jan 21;14:50. doi: 10.1186/1471-2458-14-50. PMID: 24443845. Exclusion Code: X7.24443845
1131 Huo X, Spatz ES, Ding Q, . Design and rationale of the Cardiovascular Health and Text Messaging (CHAT) Study and the CHAT-Diabetes Mellitus (CHAT-DM) Study: two randomised controlled trials of text messaging to improve secondary prevention for coronary heart disease and diabetes. BMJ open. 2017;7(12):e018302. doi: 10.1136/bmjopen-2017-018302. PMID: CN-01621600. Exclusion Code: X5.
1132 Husain M, Birkenfeld AL, Donsmark M, . Oral semaglutide and cardiovascular outcomes in patients with type 2 diabetes. N Engl J Med. 2019 Aug 29;381(9):841–51. doi: 10.1056/NEJMoa1901118. PMID: 31185157. Exclusion Code: X2.31185157
1133 Hussein Z, Kamaruddin NA, Chan SP, . Hypoglycemia awareness among insulin-treated patients with diabetes in Malaysia: A cohort subanalysis of the HAT study. Diabetes Res Clin Pract. 2017 Nov;133:40–9. doi: 10.1016/j.diabres.2017.08.007. PMID: 28888148. Exclusion Code: X4.28888148
1134 Huth C, Thorand B, Baumert J, . Job strain as a risk factor for the onset of type 2 diabetes mellitus: findings from the MONICA/KORA Augsburg cohort study. Psychosom Med. 2014 Sep;76(7):562–8. doi: 10.1097/psy.0000000000000084. PMID: 25102002. Exclusion Code: X6.25102002
1135 Ibrahim N, Ming Moy F, Awalludin IA, . Effects of a community-based healthy lifestyle intervention program (Co-HELP) among adults with prediabetes in a developing country: a quasi-experimental study. PLoS One. 2016;11(12):e0167123. doi: 10.1371/journal.pone.0167123. PMID: 27935988. Exclusion Code: X4.27935988
1136 Ida S, Kaneko R, Murata K. Effects of oral antidiabetic drugs on left ventricular mass in patients with type 2 diabetes mellitus: a network meta-analysis. Cardiovasc Diabetol. 2018 Sep 27;17(1):129. doi: 10.1186/s12933-018-0773-1. PMID: 30261876. Exclusion Code: X8.30261876
1137 Ida S, Murata K, Kaneko R. Effects of pioglitazone treatment on blood leptin levels in patients with type 2 diabetes. J Diabetes Investig. 2018 Jul;9(4):917–24. doi: 10.1111/jdi.12783. PMID: 29194996. Exclusion Code: X8.29194996
1138 Idorn T, Knop FK, Jorgensen MB, . Safety and efficacy of liraglutide in patients with type 2 diabetes and end-stage renal disease: an investigator-initiated, placebo-controlled, double-blind, parallel-group, randomized trial. Diabetes Care. 2016 Feb;39(2):206–13. doi: 10.2337/dc15-1025. PMID: 26283739. Exclusion Code: X2.26283739
1139 Iftikhar I, Khan M, Das A, . Meta-analysis: continuous positive airway pressure improves insulin resistance in patients with sleep apnea without diabetes (Provisional abstract). Annals of the American Thoracic Society; 2013. p. 115–20. Exclusion Code: X8.
1140 Iglay K, Qiu Y, Steve Fan CP, . Risk factors associated with treatment discontinuation and down-titration in type 2 diabetes patients treated with sulfonylureas. Curr Med Res Opin. 2016 Sep;32(9):1567–75. doi: 10.1080/03007995.2016.1190325. PMID: 27175740. Exclusion Code: X6.27175740
1141 Iglesias P, Civantos S, Vega B, . Clinical effectiveness of exenatide in diabetic patients waiting for bariatric surgery. Obes Surg. 2015 Mar;25(3):575–8. doi: 10.1007/s11695-014-1563-9. PMID: 25589020. Exclusion Code: X6.25589020
1142 Ikeda S, Takano Y, Cynshi O, . A novel and selective sodium-glucose cotransporter-2 inhibitor, tofogliflozin, improves glycaemic control and lowers body weight in patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2015 Oct;17(10):984–93. doi: 10.1111/dom.12538. PMID: 26179482. Exclusion Code: X2.26179482
1143 Ikehara S, Tabak AG, Akbaraly TN, . Age trajectories of glycaemic traits in non-diabetic South Asian and white individuals: the Whitehall II cohort study. Diabetologia. 2015 Mar;58(3):534–42. doi: 10.1007/s00125-014-3448-9. PMID: 25431266. Exclusion Code: X2.25431266
1144 Ikonomidis I, Pavlidis G, Lambadiari V, . Effects of the glucagon like peptide-1 receptor agonist on arterial stiffness, LV myocardial deformation and oxidative stress in newly diagnosed type 2 diabetes after 6-month treatment. Eur Heart J. 2018;39:868–9. doi: 10.1093/eurheartj/ehy563.4324. PMID: CN-01935017. Exclusion Code: X5.
1145 Ikwuka A, Cert S. Clinical effectiveness of SGLT-2 inhibitors in patients with diabetes mellitus type 2 and essential hypertensive disease. Endocrine practice. 2018;24:74-. doi: 10.4158/1530-891X-24.s1.1. PMID: CN-01620819. Exclusion Code: X5.
1146 Imai C, Saito M, Mochizuki K, . Cotreatment with the alpha-glucosidase inhibitor miglitol and DPP-4 inhibitor sitagliptin improves glycemic control and reduces the expressions of CVD risk factors in type 2 diabetic Japanese patients. Metabolism. 2014 Jun;63(6):746–53. doi: 10.1016/j.metabol.2013.12.014. PMID: 24559582. Exclusion Code: X5.24559582
1147 Imamura M, Williams K, Wells M, . Lifestyle interventions for the treatment of urinary incontinence in adults. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
1148 Imazu M, Nakano A, Ito S, . Effects of teneligliptin on the progressive left ventricular diastolic dysfunction in patients with type 2 diabetes mellitus in open-label, marker-stratified randomized, parallel-group comparison, standard treatment-controlled multicenter trial (TOPLEVEL Study): rationale and study design. Cardiovascular drugs and therapy / sponsored by the International Society of Cardiovascular Pharmacotherapy. 2019doi: 10.1007/s10557-019-06871-3. PMID: CN-01916586. Exclusion Code: X6.
1149 Imazu MF, Faria BN, de Arruda GO, . Effectiveness of individual and group interventions for people with type 2 diabetes. Rev Lat Am Enfermagem. 2015 Feb-Apr;23(2):200–7. doi: 10.1590/0104-1169.0247.2543. PMID: 26039289. Exclusion Code: X5.26039289
1150 Inagaki N, Kondo K, Yoshinari T, . Efficacy and safety of canagliflozin monotherapy in Japanese patients with type 2 diabetes inadequately controlled with diet and exercise: a 24-week, randomized, double-blind, placebo-controlled, Phase III study. Expert Opin Pharmacother. 2014;15(11):1501–15. doi: 10.1517/14656566.2014.935764. PMID: CN-00999633. Exclusion Code: X2.25010793
1151 Inagaki N, Onouchi H, Maezawa H, . Once-weekly trelagliptin versus daily alogliptin in Japanese patients with type 2 diabetes: a randomised, double-blind, phase 3, non-inferiority study. The lancet. Diabetes & endocrinology. 2015;3(3):191–7. doi: 10.1016/S2213-8587(14)70251-7. PMID: CN-01052003. Exclusion Code: X2.25609193
1152 Inagaki N, Onouchi H, Sano H, . SYR-472, a novel once-weekly dipeptidyl peptidase-4 (DPP-4) inhibitor, in type 2 diabetes mellitus: a phase 2, randomised, double-blind, placebo-controlled trial. Lancet Diabetes Endocrinol. 2014 Feb;2(2):125–32. doi: 10.1016/s2213-8587(13)70149-9. PMID: 24622716. Exclusion Code: X2.24622716
1153 Inagaki N, Onouchi H, Sano H, . Efficacy and safety of trelagliptin, a novel once-weekly oral DPP-4 inhibitor: a phase 3, double-blind, non-inferiority study in Japanese type 2 diabetes mellitus patients. Diabetologia. 2014;57(1 suppl. 1):S328. doi: 10.1007/s00125-014-3355-0. PMID: CN-01059175. Exclusion Code: X10.
1154 Inagaki N, Sheu WH, Owens DR, . Efficacy and safety of linagliptin in type 2 diabetes patients with self-reported hepatic disorders: A retrospective pooled analysis of 17 randomized, double-blind, placebo-controlled clinical trials. J Diabetes Complications. 2016 Nov - Dec;30(8):1622–30. doi: 10.1016/j.jdiacomp.2016.07.002. PMID: 27499458. Exclusion Code: X2.27499458
1155 Infield J, Ogunsakin A, Zuber J, . Metformin has a positive effect in type 2 diabetes mellitus (T2DM) patients with Squamous Cell Carcinoma (SCC) of the larynx or oropharynx. Journal of investigative medicine. Conference: 2018 southern regional meeting, SRM 2018. United states. 2018;66(2):615. . PMID: CN-01467082. Exclusion Code: X8.
1156 Ing CT, Zhang G, Dillard A, . Social support groups in the maintenance of glycemic control after community-based intervention. J Diabetes Res. 2016;2016:7913258. doi: 10.1155/2016/7913258. PMID: 27563680. Exclusion Code: X2.27563680
1157 Inoue M, Lorenz M, Muto H, . Effect of single dose of insulin glargine/lixisenatide fixed-ratio combination (iglarlixi) on postprandial glucodynamic response in Japanese patients with type 2 diabetes mellitus. Diabetes. 2018;67:A285-. PMID: CN-01631147. Exclusion Code: X2.
1158 Inouye J, Li D, Davis J, . Psychosocial and clinical outcomes of a cognitive behavioral therapy for Asians and Pacific Islanders with type 2 diabetes: a randomized clinical trial. Hawaii J Med Public Health. 2015 Nov;74(11):360–8. PMID: 26568899. Exclusion Code: X5.26568899
1159 Inzucchi SE, Nauck MA, Hehnke U, . Improved glucose control with reduced hypoglycaemic risk when linagliptin is added to basal insulin in elderly patients with type 2 diabetes. Diabetes Obes Metab. 2015 Sep;17(9):868–77. doi: 10.1111/dom.12490. PMID: 25974030. Exclusion Code: X8.25974030
1160 Inzucchi SE, Viscoli CM, Young LH, . Pioglitazone prevents diabetes in patients with insulin resistance and cerebrovascular disease. Diabetes Care. 2016 Oct;39(10):1684–92. doi: 10.2337/dc16-0798. PMID: 27465265. Exclusion Code: X2.27465265
1161 Ionova T, Nikitina T, Rodionova A, . Quality of life (QoL) and health utility (UT) in patients with type 2 diabetes mellitus (DM2) receiving different oral hypoglycemic therapy in a real-world setting. Value in health. Conference: ISPOR 19th annual european congress. Austria. Conference start: 20161029. Conference end: 20161102. 2016;19(7):A678. PMID: CN-01250912. Exclusion Code: X5.
1162 Iqbal N, Allen E, Ohman P. Long-term safety and tolerability of saxagliptin add-on therapy in older patients (aged >/= 65 years) with type 2 diabetes. Clin Interv Aging. 2014;9:1479–87. doi: 10.2147/cia.s68193. PMID: 25214775. Exclusion Code: X2.25214775
1163 Iqbal N, Parker A, Frederich R, . Assessment of the cardiovascular safety of saxagliptin in patients with type 2 diabetes mellitus: pooled analysis of 20 clinical trials. Cardiovasc Diabetol. 2014;13(1)doi: 10.1186/1475-2840-13-33. PMID: CN-01001096. Exclusion Code: X8.
1164 Iraci T, Carlo V, Galvano L, . Screening strategies for early diagnosis of undiagnosed diabetes and other disorders of glucose metabolism. The DSP (Diabetes Screening Palermo) study. Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S156. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212859. Exclusion Code: X8.
1165 Irving BA, Carter RE, Soop M, . Effect of insulin sensitizer therapy on amino acids and their metabolites. Metabolism. 2015 Jun;64(6):720–8. doi: 10.1016/j.metabol.2015.01.008. PMID: 25733201. Exclusion Code: X6.25733201
1166 Ishihara H, Yamaguchi S, Nakao I, . Efficacy and safety of ipragliflozin, an SGLT2 inhibitor, add-on to insulin in Japanese patients: results of a double-blind, placebo-controlled study. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A64. doi: 10.2337/db16-1-381. PMID: CN-01450023. Exclusion Code: X2.
1167 Ishii H, Madin-Warburton M, Strizek A, . The cost-effectiveness of dulaglutide versus insulin glargine for the treatment of type 2 diabetes mellitus in Japan. J Med Econ. 2018 May;21(5):488–96. doi: 10.1080/13696998.2018.1431918. PMID: 29357718. Exclusion Code: X8.29357718
1168 Ishikawa S, Shimano M, Watarai M, . Impact of sitagliptin on carotid intima-media thickness in patients with coronary artery disease and impaired glucose tolerance or mild diabetes mellitus. Am J Cardiol. 2014 Aug 1;114(3):384–8. doi: 10.1016/j.amjcard.2014.04.050. PMID: 24929624. Exclusion Code: X2.24929624
1169 Isik AT, Soysal P, Yay A, . The effects of sitagliptin, a DPP-4 inhibitor, on cognitive functions in elderly diabetic patients with or without Alzheimer’s disease. Diabetes Res Clin Pract. 2017 Jan;123:192–8. doi: 10.1016/j.diabres.2016.12.010. PMID: 28056430. Exclusion Code: X2.28056430
1170 Islam N, Gepts T, Lief I, . Protocol for the CHORD project (community health outreach to reduce diabetes): a cluster-randomized community health worker trial to prevent diabetes. BMC Public Health. 2018 Apr 19;18(1):521. doi: 10.1186/s12889-018-5419-4. PMID: 29673333. Exclusion Code: X6.29673333
1171 Islam N, Riley L, Wyatt L, . Protocol for the DREAM Project (Diabetes Research, Education, and Action for Minorities): a randomized trial of a community health worker intervention to improve diabetic management and control among Bangladeshi adults in NYC. BMC public health. 2014;14:177. doi: 10.1186/1471-2458-14-177. PMID: CN-01118352. Exclusion Code: X6.24548534
1172 Ismail-Beigi F, Craven TE, O’Connor PJ, . Combined intensive blood pressure and glycemic control does not produce an additive benefit on microvascular outcomes in type 2 diabetic patients. Kidney Int. 2012 Mar;81(6):586–94. doi: 10.1038/ki.2011.415. PMID: 22166848. Exclusion Code: X2.22166848
1173 Ito S, Kagawa T, Umeda Y, . The efficacy and safety of imarikiren in patients with type 2 diabetes mellitus and microalbuminuria: a randomized, multi center, double-blind, placebo controlled trial. Nephrology dialysis transplantation. 2018;33:i317-. doi: 10.1093/ndt/gfy104.SaO008. PMID: CN-01613372. Exclusion Code: X2.
1174 Jaacks LM, Ma Y, Davis N, . Long-term changes in dietary and food intake behaviour in the Diabetes Prevention Program Outcomes Study. Diabet Med. 2014 Dec;31(12):1631–42. doi: 10.1111/dme.12500. PMID: 24824893. Exclusion Code: X6.24824893
1175 Jabbour SA, Hardy E, Sugg J, . Dapagliflozin is effective as add-on therapy to sitagliptin with or without metformin: a 24-week, multicenter, randomized, double-blind, placebo-controlled study. Diabetes Care. 2014;37(3):740–50. doi: 10.2337/dc13-0467. PMID: 24144654. Exclusion Code: X2.24144654
1176 Jahangard-Rafsanjani Z, Sarayani A, Nosrati M, . Effect of a community pharmacist-delivered diabetes support program for patients receiving specialty medical care: a randomized controlled trial. Diabetes Educ. 2015 Feb;41(1):127–35. doi: 10.1177/0145721714559132. PMID: 25420946. Exclusion Code: X4.25420946
1177 Jain V, Joshi R, Idiculla J, . Community health worker interventions in type 2 diabetes mellitus patients: assessing the feasibility and effectiveness in Rural Central India. J Cardiovasc Dis Res. 2018;9(3):127–33. doi: 10.5530/jcdr.2018.3.29. PMID: CN-01650380. Exclusion Code: X6.
1178 Jaipakdee J, Jiamjarasrangsi W, Lohsoonthorn V, . Effectiveness of a self-management support program for Thais with type 2 diabetes: evaluation according to the RE-AIM framework. Nurs Health Sci. 2015;17(3):362–9. doi: 10.1111/nhs.12198. PMID: CN-01153641. Exclusion Code: X2.25818472
1179 Jakob T, Nordmann AJ, Schandelmaier S, . Fibrates for primary prevention of cardiovascular disease events. Cochrane Database Syst Rev. 2016 Nov 16;11:Cd009753. doi: 10.1002/14651858.CD009753.pub2. PMID: 27849333. Exclusion Code: X8.27849333
1180 Jakubowicz D, Wainstein J, Ahren B, . High-energy breakfast with low-energy dinner decreases overall daily hyperglycaemia in type 2 diabetic patients: a randomised clinical trial. Diabetologia. 2015 May;58(5):912–9. doi: 10.1007/s00125-015-3524-9. PMID: 25724569. Exclusion Code: X2.25724569
1181 Jakubowicz D, Wainstein J, Landau Z, . High-energy breakfast based on whey protein reduces body weight, postprandial glycemia and HbA1C in Type 2 diabetes. J Nutr Biochem. 2017 Nov;49:1–7. doi: 10.1016/j.jnutbio.2017.07.005. PMID: 28863364. Exclusion Code: X6.28863364
1182 Jameson K, D’Oca K, Leigh P, . Adherence to NICE guidance on glucagon-like peptide-1 receptor agonists among patients with type 2 diabetes mellitus: an evaluation using the Clinical Practice Research Datalink. Curr Med Res Opin. 2016;32(1):49–60. doi: 10.1185/03007995.2015.1101372. PMID: 26428701. Exclusion Code: X6.26428701
1183 Jang WI, Kim MS, Kang SH, . Association between metformin use and mortality in patients with type 2 diabetes mellitus and localized resectable pancreatic cancer: a nationwide population-based study in korea. Oncotarget. 2017 Feb 7;8(6):9587–96. doi: 10.18632/oncotarget.14525. PMID: 28077783. Exclusion Code: X2.28077783
1184 Jani RH, Pai V, Jha P, . A multicenter, prospective, randomized, double-blind study to evaluate the safety and efficacy of Saroglitazar 2 and 4 mg compared with placebo in type 2 diabetes mellitus patients having hypertriglyceridemia not controlled with atorvastatin therapy (PRESS VI). Diabetes Technol Ther. 2014 Feb;16(2):63–71. doi: 10.1089/dia.2013.0253. PMID: 24138536. Exclusion Code: X4.24138536
1185 Janjgava S, Zerekidze T, Uchava L, . Influence of testosterone replacement therapy on metabolic disorders in male patients with type 2 diabetes mellitus and androgen deficiency. Eur J Med Res. 2014 Oct 23;19:56. doi: 10.1186/s40001-014-0056-6. PMID: 25338765. Exclusion Code: X4.25338765
1186 Janjgava S, Zerekidze T, Uchava L, . Influence of testosterone replacement therapy on metabolic disorders in male patient with type 2 diabetes mellitus and androgen deficiency. Macedonian journal of medical sciences. 2014;7(4):601–7. doi: 10.3889/oamjms.2014.107. PMID: CN-01036958. Exclusion Code: X4.
1187 Jansson SP, Svardsudd K, Andersson DK. Effects of fasting blood glucose levels and blood pressure and treatment of diabetes and hypertension on the incidence of cardiovascular disease: a study of 740 patients with incident Type 2 diabetes with up to 30 years’ follow-up. Diabet Med. 2014 Sep;31(9):1055–63. doi: 10.1111/dme.12514. PMID: 24894815. Exclusion Code: X8.24894815
1188 Jax T, Stirban A, Terjung A, . A randomised, active- and placebo-controlled, three-period crossover trial to investigate short-term effects of the dipeptidyl peptidase-4 inhibitor linagliptin on macro- and microvascular endothelial function in type 2 diabetes. Cardiovasc Diabetol. 2017 Jan 21;16(1):13. doi: 10.1186/s12933-016-0493-3. PMID: 28109295. Exclusion Code: X2.28109295
1189 Jayasuriya R, Pinidiyapathirage MJ, Jayawardena R, . Translational research for diabetes self-management in Sri Lanka: a randomized controlled trial. Prim Care Diabetes. 2015 Oct;9(5):338–45. doi: 10.1016/j.pcd.2015.01.014. PMID: 25733343. Exclusion Code: X6.25733343
1190 JD VDB, JHPM VDV, EAC DEW, . Replacement effects of sedentary time on metabolic outcomes: the Maastricht Study. Med Sci Sports Exerc. 2017 Jul;49(7):1351–8. doi: 10.1249/mss.0000000000001248. PMID: 28263284. Exclusion Code: X4.28263284
1191 Jeffers KS, Castellon-Lopez Y, Grotts J, . Association of patient activation with uptake and adherence to the diabetes prevention program (DPP): results from the prediabetes informed decisions and education (pride) study. J Gen Intern Med. 2018;33(2):126–7. PMID: CN-01606092. Exclusion Code: X6.
1192 Jellis CL, Sacre JW, Wright J, . Biomarker and imaging responses to spironolactone in subclinical diabetic cardiomyopathy. Eur Heart J Cardiovasc Imaging. 2014 Jul;15(7):776–86. doi: 10.1093/ehjci/jeu013. PMID: 24472731. Exclusion Code: X6.24472731
1193 Jelsma JGM, van Poppel MNM, Smith BJ, . Changing psychosocial determinants of physical activity and diet in women with a history of gestational diabetes mellitus. Diabetes Metab Res Rev. 2018 Jan;34(1)doi: 10.1002/dmrr.2942. PMID: 28843034. Exclusion Code: X2.28843034
1194 Jenkins AJ, Fu D, Azar M, . Clinical correlates of serum pigment epithelium-derived factor in type 2 diabetes patients. J Diabetes Complications. 2014 May-Jun;28(3):353–9. doi: 10.1016/j.jdiacomp.2014.01.008. PMID: 24560422. Exclusion Code: X8.24560422
1195 Jennersjo P, Ludvigsson J, Lanne T, . Pedometer-determined physical activity level and change in arterial stiffness in Type 2 diabetes over 4 years. Diabet Med. 2016 Jul;33(7):992–7. doi: 10.1111/dme.12873. PMID: 26227869. Exclusion Code: X6.26227869
1196 Jennings AS, Lovett AJ, George TM, . Getting to goal in newly diagnosed type 2 diabetes using combination drug “subtraction therapy”. Metabolism. 2015 Sep;64(9):1005–12. doi: 10.1016/j.metabol.2015.04.008. PMID: 26003501. Exclusion Code: X5.26003501
1197 Jennings CA, Vandelanotte C, Caperchione CM, . Effectiveness of a web-based physical activity intervention for adults with Type 2 diabetes-a randomised controlled trial. Prev Med. 2014 Mar;60:33–40. doi: 10.1016/j.ypmed.2013.12.011. PMID: 24345601. Exclusion Code: X6.24345601
1198 Jensen TM, Saha K, Steinberg WM. Is there a link between liraglutide and pancreatitis? A post hoc review of pooled and patient-level data from completed liraglutide type 2 diabetes clinical trials. Diabetes Care. 2015 Jun;38(6):1058–66. doi: 10.2337/dc13-1210. PMID: 25504028. Exclusion Code: X8.25504028
1199 Jensen TM, Vistisen D, Fleming T, . Impact of intensive treatment on serum methylglyoxal levels among individuals with screen-detected type 2 diabetes: the ADDITION-Denmark study. Acta Diabetol. 2015 Oct;52(5):929–36. doi: 10.1007/s00592-015-0739-7. PMID: 25808642. Exclusion Code: X6.25808642
1200 Jensterle SM, Kocjan T, Pfeifer M, . Short-term combined treatment with liraglutide and metformin leads to significant weight loss in obese women with polycystic ovary syndrome and previous poor response to metformin. European journal of endocrinology. 2014;170(3):451–9. doi: 10.1530/EJE-13-0797. PMID: CN-00985254. Exclusion Code: X2.24362411
1201 Jeong IK, Chung CH, Zhou Z, . Comparison of insulin intensification strategies with insulin lispro low mixture twice daily versus basal insulin glargine and prandial insulin lispro once daily in East Asian and Caucasian patients with type 2 diabetes mellitus. J Diabetes. 2017 Apr;9(4):396–404. doi: 10.1111/1753-0407.12426. PMID: 27171584. Exclusion Code: X5.27171584
1202 Jergensen T, Orsak B, Conde A, . Metformin for preventing frailty in older adults with pre-diabetes. J Am Geriatr Soc. 2018;66:S285-. doi: 10.1111/jgs.15376. PMID: CN-01606965. Exclusion Code: X6.
1203 Jerums G, Panagiotopoulos S, Ekinci E, . Cardiovascular outcomes with antihypertensive therapy in type 2 diabetes: an analysis of intervention trials. J Hum Hypertens. 2015 Aug;29(8):473–7. doi: 10.1038/jhh.2014.117. PMID: 25608943. Exclusion Code: X8.25608943
1204 Ji H, Chen R, Huang Y, . Effect of simulation education and case management on glycemic control in type 2 diabetes. Diabetes Metab Res Rev. 2019 Mar;35(3):e3112. doi: 10.1002/dmrr.3112. PMID: 30520255. Exclusion Code: X5.30520255
1205 Ji L, Han P, Liu Y, . Canagliflozin in Asian patients with type 2 diabetes on metformin alone or metformin in combination with sulphonylurea. Diabetes Obes Metab. 2015 Jan;17(1):23–31. doi: 10.1111/dom.12385. PMID: 25175734. Exclusion Code: X2.25175734
1206 Ji L, Han P, Wang X, . Randomized clinical trial of the safety and efficacy of sitagliptin and metformin co-administered to Chinese patients with type 2 diabetes mellitus. J Diabetes Investig. 2016 Sep;7(5):727–36. doi: 10.1111/jdi.12511. PMID: 27181998. Exclusion Code: X2.27181998
1207 Ji L, Li L, Kuang J, . Efficacy and safety of fixed-dose combination therapy, alogliptin plus metformin, in Asian patients with type 2 diabetes: A phase 3 trial. Diabetes Obes Metab. 2017 May;19(5):754–8. doi: 10.1111/dom.12875. PMID: 28075066. Exclusion Code: X2.28075066
1208 Ji L, Liu Y, Miao H, . Safety and efficacy of ertugliflozin in Asian patients with type 2 diabetes mellitus inadequately controlled with metformin monotherapy: VERTIS Asia. Diabetes, obesity & metabolism. 2019;21(6):1474–82. doi: 10.1111/dom.13681. PMID: CN-01939283. Exclusion Code: X2.
1209 Ji L, Pan C, Lu J, . Vildagliptin add-on to metformin versus metformin uptitration in Chinese patients with type 2 diabetes: a sub-group analysis of the VISION study. Diabetes/metabolism research and reviews. Conference: 19th scientific meeting of the chinese diabetes society. China. 2015;31:1. doi: 10.1002/dmrr.2726. PMID: CN-01361405. Exclusion Code: X2.
1210 Ji L, Zinman B, Patel S, . Efficacy and safety of linagliptin co-administered with low-dose metformin once daily versus high-dose metformin twice daily in treatment-naive patients with type 2 diabetes: a double-blind randomized trial. Adv Ther. 2015 Mar;32(3):201–15. doi: 10.1007/s12325-015-0195-3. PMID: 25805187. Exclusion Code: X5.25805187
1211 Ji L, Zinman B, Patel S, . Efficacy and safety of linagliptin co-administered with low-dose metformin once daily versus high-dose metformin twice daily in treatment-naïve patients with type 2 diabetes: a double-blind randomized trial. Adv Ther. 2015;32(3):201–15. doi: 10.1007/s12325-015-0195-3. PMID: CN-01256547. Exclusion Code: X5.25805187
1212 Jia W, Xiao X, Ji Q, . Comparison of thrice-daily premixed insulin (insulin lispro premix) with basal-bolus (insulin glargine once-daily plus thrice-daily prandial insulin lispro) therapy in east Asian patients with type 2 diabetes insufficiently controlled with twice-daily premixed insulin: an open-label, randomised, controlled trial. Lancet Diabetes Endocrinol. 2015 Apr;3(4):254–62. doi: 10.1016/s2213-8587(15)00041-8. PMID: 25754414. Exclusion Code: X2.25754414
1213 Jiang G, Luk AO, Yang X, . Progression to treatment failure among Chinese patients with type 2 diabetes initiated on metformin versus sulphonylurea monotherapy--The Hong Kong Diabetes Registry. Diabetes Res Clin Pract. 2016 Feb;112:57–64. doi: 10.1016/j.diabres.2015.11.003. PMID: 26703273. Exclusion Code: X6.26703273
1214 Jiang L, Huang H, Johnson A, . Socioeconomic disparities in weight and behavioral outcomes among American Indian and Alaska Native participants of a translational lifestyle intervention project. Diabetes Care. 2015 Nov;38(11):2090–9. doi: 10.2337/dc15-0394. PMID: 26494807. Exclusion Code: X6.26494807
1215 Jiang L, Johnson A, Pratte K, . Long-term outcomes of lifestyle intervention to prevent diabetes in American Indian and Alaska Native Communities: the Special Diabetes Program for Indians Diabetes Prevention Program. Diabetes Care. 2018 Jul;41(7):1462–70. doi: 10.2337/dc17-2685. PMID: 29915128. Exclusion Code: X5.29915128
1216 Jiang X, Fan X, Wu R, . The effect of care intervention for obese patients with type II diabetes. Medicine. 2017;96(42):e7524. doi: 10.1097/MD.0000000000007524. PMID: CN-01424183. Exclusion Code: X2.29049180
1217 Jiang YY, Zhang XX, Mao F, . The impact evaluation of a community-based intervention supporting type 2 diabetes mellitus patients in their self-management of the disease. Zhonghua yu fang yi xue za zhi [Chinese journal of preventive medicine]. 2019;53(2):206–11. doi: 10.3760/cma.j.issn.0253-9624.2019.02.016. PMID: CN-01951728. Exclusion Code: X1.
1218 Jil M, Rajnikant M, Richard D, . The effects of dual-therapy intensification with insulin or dipeptidylpeptidase-4 inhibitor on cardiovascular events and all-cause mortality in patients with type 2 diabetes: A retrospective cohort study. Diab Vasc Dis Res. 2017 Jul;14(4):295–303. doi: 10.1177/1479164116687102. PMID: 28330386. Exclusion Code: X2.28330386
1219 Jiménez-Lucena R, Camargo A, Alcalá-Diaz JF, . A plasma circulating miRNAs profile predicts type 2 diabetes mellitus and prediabetes: from the CORDIOPREV study. Exp Mol Med. 2018;50(12):168. doi: 10.1038/s12276-018-0194-y. PMID: CN-01954991. Exclusion Code: X4.
1220 Jimenez-Navarro MF, Fernandez-Pastor J, Garrido-Sanchez L, . Newly impaired glucose metabolism and prognosis after percutaneous revascularization. Cardiol J. 2015;22(1):44–51. doi: 10.5603/CJ.a2014.0024. PMID: 24671899. Exclusion Code: X8.24671899
1221 Jin SM, Park CY, Cho YM, . Lobeglitazone and pioglitazone as add-ons to metformin for patients with type 2 diabetes: a 24-week, multicentre, randomized, double-blind, parallel-group, active-controlled, phase III clinical trial with a 28-week extension. Diabetes Obes Metab. 2015 Jun;17(6):599–602. doi: 10.1111/dom.12435. PMID: 25580775. Exclusion Code: X5.25580775
1222 Jin SM, Song SO, Jung CH, . Risk of bladder cancer among patients with diabetes treated with a 15 mg pioglitazone dose in Korea: a multi-center retrospective cohort study. J Korean Med Sci. 2014 Feb;29(2):238–42. doi: 10.3346/jkms.2014.29.2.238. PMID: 24550651. Exclusion Code: X2.24550651
1223 Jinnouchi H, Sugiyama S, Yoshida A, . Liraglutide, a glucagon-like peptide-1 analog, increased insulin sensitivity assessed by hyperinsulinemic-euglycemic clamp examination in patients with uncontrolled type 2 diabetes mellitus. J Diabetes Res. 2015;2015:706416. doi: 10.1155/2015/706416. PMID: 25922845. Exclusion Code: X6.25922845
1224 Johansen MY, MacDonald CS, Hansen KB, . Effect of an intensive lifestyle intervention on glycemic control in patients with type 2 diabetes: a randomized clinical trial. Jama. 2017 Aug 15;318(7):637–46. doi: 10.1001/jama.2017.10169. PMID: 28810024. Exclusion Code: X2.28810024
1225 Johansson T, Keller S, Sonnichsen AC, . Cost analysis of a peer support programme for patients with type 2 diabetes: a secondary analysis of a controlled trial. Eur J Public Health. 2017 Apr 1;27(2):256–61. doi: 10.1093/eurpub/ckw158. PMID: 27694160. Exclusion Code: X6.27694160
1226 John M, Cerdas S, Violante R, . Efficacy and safety of canagliflozin in patients with type 2 diabetes mellitus living in hot climates. Int J Clin Pract. 2016 Sep;70(9):775–85. doi: 10.1111/ijcp.12868. PMID: 27600862. Exclusion Code: X2.27600862
1227 Johnson JA, Bowker SL. Intensive glycaemic control and cancer risk in type 2 diabetes: a meta-analysis of major trials. Diabetologia. 2011 Jan;54(1):25–31. doi: 10.1007/s00125-010-1933-3. PMID: 20959956. Exclusion Code: X8.20959956
1228 Johnson KC, Bray GA, Cheskin LJ, . The effect of intentional weight loss on fracture risk in persons with diabetes: results from the Look AHEAD Randomized Clinical Trial. J Bone Miner Res. 2017 Nov;32(11):2278–87. doi: 10.1002/jbmr.3214. PMID: 28678345. Exclusion Code: X2.28678345
1229 Johnson ST, Lubans DR, Mladenovic AB, . Testing social-cognitive mediators for objective estimates of physical activity from the Healthy Eating and Active Living for Diabetes in Primary Care Networks (HEALD-PCN) study. Psychol Health Med. 2016 Dec;21(8):945–53. doi: 10.1080/13548506.2016.1140900. PMID: 26899570. Exclusion Code: X6.26899570
1230 Johnson ST, Mundt C, Qiu W, . Increase in daily steps after an exercise specialist led lifestyle intervention for adults with type 2 diabetes in primary care: a controlled implementation trial. J Phys Act Health. 2015 Nov;12(11):1492–9. doi: 10.1123/jpah.2014-0200. PMID: 25634940. Exclusion Code: X2.25634940
1231 Johnsson K, Johnsson E, Mansfield TA, . Osmotic diuresis with SGLT2 inhibition: analysis of events related to volume reduction in dapagliflozin clinical trials. Postgrad Med. 2016 May;128(4):346–55. doi: 10.1080/00325481.2016.1153941. PMID: 26878357. Exclusion Code: X8.26878357
1232 Johnston CA, Moreno JP, Foreyt JP. Cardiovascular effects of intensive lifestyle intervention in type 2 diabetes. Curr Atheroscler Rep. 2014 Dec;16(12):457. doi: 10.1007/s11883-014-0457-6. PMID: 25288176. Exclusion Code: X2.25288176
1233 Jonasson L, Guldbrand H, Lundberg A, . Advice to follow a low-carbohydrate diet has a favourable impact on low-grade inflammation in type 2 diabetes compared with advice to follow a low-fat diet. Ann Med. 2014;46(3):182–7. doi: 10.3109/07853890.2014.894286. PMID: CN-00997460. Exclusion Code: X2.24779961
1234 Jones EJ, Fraley HE, Mazzawi J. Appreciating recent motherhood and culture: a systematic review of multimodal postpartum lifestyle interventions to reduce diabetes risk in women with prior gestational diabetes. Matern Child Health J. 2017 Jan;21(1):45–57. doi: 10.1007/s10995-016-2092-z. PMID: 27435732. Exclusion Code: X8.27435732
1235 Jones LV, Ray A, Moy FM, . Techniques of monitoring blood glucose during pregnancy for women with pre-existing diabetes. Cochrane Database of Systematic Reviews. 2019(5)doi: 10.1002/14651858.CD009613.pub4. PMID: CD009613. Exclusion Code: X8.
1236 Jones NP, Curtis PS, Home PD. Cancer and bone fractures in observational follow-up of the RECORD study. Acta Diabetol. 2015 Jun;52(3):539–46. doi: 10.1007/s00592-014-0691-y. PMID: 25524432. Exclusion Code: X5.25524432
1237 Jones PH, Bays HE, Chaudhari U, . Safety of alirocumab (A PCSK9 Monoclonal Antibody) from 14 randomized trials. Am J Cardiol. 2016 Dec 15;118(12):1805–11. doi: 10.1016/j.amjcard.2016.08.072. PMID: 27729106. Exclusion Code: X8.27729106
1238 Jones TA, Sautter M, Van Gaal LF, . Addition of rosiglitazone to metformin is most effective in obese, insulin-resistant patients with type 2 diabetes. Diabetes, obesity & metabolism. 2003;5(3):163–70. doi: 10.1046/j.1463-1326.2003.00258.x. PMID: CN-01715722. Exclusion Code: X2.
1239 Jorgensen PG, Jensen MT, Mensberg P, . Effect of exercise combined with glucagon-like peptide-1 receptor agonist treatment on cardiac function: A randomized double-blind placebo-controlled clinical trial. Diabetes Obes Metab. 2017 Jul;19(7):1040–4. doi: 10.1111/dom.12900. PMID: 28188972. Exclusion Code: X6.28188972
1240 Josse RG, Majumdar SR, Zheng Y, . Sitagliptin and risk of fractures in type 2 diabetes: results from the TECOS trial. Diabetes Obes Metab. 2017 Jan;19(1):78–86. doi: 10.1111/dom.12786. PMID: 27607571. Exclusion Code: X2.27607571
1241 Ju C, Shi R, Yao L, . Effect of peer support on diabetes distress: a cluster randomized controlled trial. Diabet Med. 2018 Jun;35(6):770–5. doi: 10.1111/dme.13625. PMID: 29574995. Exclusion Code: X2.29574995
1242 Jung C, Lichtenauer M, Wernly B, . Effect of endothelin-1 and endothelin receptor blockade on the release of microparticles. Eur J Clin Invest. 2016 Aug;46(8):707–13. doi: 10.1111/eci.12652. PMID: 27322814. Exclusion Code: X6.27322814
1243 Jung HY, Lee H, Park J. Comparison of the effects of Korean mindfulness-based stress reduction, walking, and patient education in diabetes mellitus. Nurs Health Sci. 2015 Dec;17(4):516–25. doi: 10.1111/nhs.12229. PMID: 26275164. Exclusion Code: X4.26275164
1244 Jutterstrom L, Hornsten A, Sandstrom H, . Nurse-led patient-centered self-management support improves HbA1c in patients with type 2 diabetes-A randomized study. Patient Educ Couns. 2016 Nov;99(11):1821–9. doi: 10.1016/j.pec.2016.06.016. PMID: 27372525. Exclusion Code: X6.27372525
1245 Kadowaki T, Inagaki N, Kondo K, . Long-term safety and efficacy of canagliflozin as add-on therapy to teneligliptin in Japanese patients with type 2 diabetes. Diabetes Obes Metab. 2018 Jan;20(1):77–84. doi: 10.1111/dom.13038. PMID: 28608617. Exclusion Code: X2.28608617
1246 Kadowaki T, Kondo K. Efficacy and safety of teneligliptin added to glimepiride in Japanese patients with type 2 diabetes mellitus: a randomized, double-blind, placebo-controlled study with an open-label, long-term extension. Diabetes Obes Metab. 2014 May;16(5):418–25. doi: 10.1111/dom.12235. PMID: 24205974. Exclusion Code: X2.24205974
1247 Kahn A, Reynolds JA, Chakkera HA, . Prospective analysis of metabolic parameters in the detection of diabetes and metabolic syndrome in liver transplant recipients. Metab Syndr Relat Disord. 2016 Aug;14(6):305–10. doi: 10.1089/met.2015.0162. PMID: 27164306. Exclusion Code: X5.27164306
1248 Kahya Eren N, Harman E, Dolek D, . Rate of blood pressure control and antihypertensive treatment approaches in diabetic patients with hypertension. Turk Kardiyol Dern Ars. 2014 Dec;42(8):733–40. doi: 10.5543/tkda.2014.53384. PMID: 25620334. Exclusion Code: X8.25620334
1249 Kajiwara M, Tanaka A, Kawasaki T, . Safety and efficacy of liraglutide treatment in Japanese type 2 diabetes patients after acute myocardial infarction: A non-randomized interventional pilot trial. J Cardiol. 2017 Mar;69(3):511–7. doi: 10.1016/j.jjcc.2016.10.009. PMID: 27894787. Exclusion Code: X2.27894787
1250 Kaku K, Haneda M, Tanaka Y, . Linagliptin as add-on to empagliflozin in a fixed-dose combination in Japanese patients with type 2 diabetes: Glycaemic efficacy and safety profile in a two-part, randomized, placebo-controlled trial. Diabetes Obes Metab. 2019 Jan;21(1):136–45. doi: 10.1111/dom.13496. PMID: 30091172. Exclusion Code: X2.30091172
1251 Kaku K, Kiyosue A, Ono Y, . Liraglutide is effective and well tolerated in combination with an oral antidiabetic drug in Japanese patients with type 2 diabetes: A randomized, 52-week, open-label, parallel-group trial. J Diabetes Investig. 2016 Jan;7(1):76–84. doi: 10.1111/jdi.12367. PMID: 26816604. Exclusion Code: X2.26816604
1252 Kaku K, Mori M, Kanoo T, . Efficacy and safety of alogliptin added to insulin in Japanese patients with type 2 diabetes: a randomized, double-blind, 12-week, placebo-controlled trial followed by an open-label, long-term extension phase. Expert Opin Pharmacother. 2014 Oct;15(15):2121–30. doi: 10.1517/14656566.2014.956722. PMID: 25190226. Exclusion Code: X2.25190226
1253 Kaku K, Sumino S, Katou M, . Randomized, double-blind, phase III study to evaluate the efficacy and safety of once-daily treatment with alogliptin and metformin hydrochloride in Japanese patients with type 2 diabetes. Diabetes Obes Metab. 2017 Mar;19(3):463–7. doi: 10.1111/dom.12837. PMID: 27891757. Exclusion Code: X5.27891757
1254 Kaku K, Yamada Y, Watada H, . Safety and efficacy of once-weekly semaglutide vs additional oral antidiabetic drugs in Japanese people with inadequately controlled type 2 diabetes: A randomized trial. Diabetes Obes Metab. 2018 May;20(5):1202–12. doi: 10.1111/dom.13218. PMID: 29322610. Exclusion Code: X2.29322610
1255 Kala P, Jamuna RR, Kumar J. A comparative study of efficacy and safety among metformin with sitagliptin, metformin with voglibose, and metformin with glimepiride in patients with type 2 diabetes mellitus. Asian journal of pharmaceutical and clinical research. 2017;10(12):313–6. doi: 10.22159/ajpcr.2017.v10i12.22050. PMID: CN-01442381. Exclusion Code: X5.
1256 Kamishima K, Ogawa H, Jujo K, . Relationships between blood pressure lowering therapy and cardiovascular events in hypertensive patients with coronary artery disease and type 2 diabetes mellitus: The HIJ-CREATE sub-study. Diabetes Res Clin Pract. 2019 Mar;149:69–77. doi: 10.1016/j.diabres.2019.01.031. PMID: 30735770. Exclusion Code: X2.30735770
1257 Kamiya H. A systematic review of the benefits and harms of dipeptidyl peptidase-4 inhibitor for chronic kidney disease. Hemodial Int. 2017 Jan;21(1):72–83. doi: 10.1111/hdi.12438. PMID: 27436163. Exclusion Code: X8.27436163
1258 Kamiyama H, Aoki K, Nakajima S, . Effect of repaglinide, administered two or three times daily for 3 months, on glycaemic control in Japanese patients with type 2 diabetes mellitus. J Int Med Res. 2014 Oct;42(5):1150–60. doi: 10.1177/0300060514534644. PMID: 25015763. Exclusion Code: X2.25015763
1259 Kanatsuka A, Sato Y, Kawai K, . Relationship between the efficacy of oral antidiabetic drugs and clinical features in type 2 diabetic patients (JDDM38). J Diabetes Investig. 2016 May;7(3):386–95. doi: 10.1111/jdi.12430. PMID: 27330726. Exclusion Code: X8.27330726
1260 Kaneko S, Chow F, Choi DS, . Insulin degludec/insulin aspart versus biphasic insulin aspart 30 in Asian patients with type 2 diabetes inadequately controlled on basal or pre-/self-mixed insulin: a 26-week, randomised, treat-to-target trial. Diabetes Res Clin Pract. 2015 Jan;107(1):139–47. doi: 10.1016/j.diabres.2014.09.026. PMID: 25498130. Exclusion Code: X2.25498130
1261 Kaneko S, Nishijima K, Bosch-Traberg H, . Efficacy and safety of adding liraglutide to existing insulin regimens in Japanese patients with type 2 diabetes mellitus: a post-hoc analysis of a phase 3 randomized clinical trial. Journal of diabetes investigation. 2018;(no pagination)doi: 10.1111/jdi.12793. PMID: CN-01460579. Exclusion Code: X2.
1262 Kang JY, Sung SH, Lee YJ, . Impact of ENPP1 K121Q on change of insulin resistance after web-based intervention in Korean men with diabetes and impaired fasting glucose. J Korean Med Sci. 2014 Oct;29(10):1353–9. doi: 10.3346/jkms.2014.29.10.1353. PMID: 25368487. Exclusion Code: X5.25368487
1263 Kang YA, Choi NK, Seong JM, . The effects of statin use on the development of tuberculosis among patients with diabetes mellitus. Int J Tuberc Lung Dis. 2014 Jun;18(6):717–24. doi: 10.5588/ijtld.13.0854. PMID: 24903944. Exclusion Code: X8.24903944
1264 Kannan S, Pantalone KM, Matsuda S, . Risk of overall mortality and cardiovascular events in patients with type 2 diabetes on dual drug therapy including metformin: A large database study from the Cleveland Clinic. J Diabetes. 2016 Mar;8(2):279–85. doi: 10.1111/1753-0407.12301. PMID: 25929426. Exclusion Code: X5.25929426
1265 Kapitza C, Dahl K, Jacobsen JB, . Effects of semaglutide on beta cell function and glycaemic control in participants with type 2 diabetes: a randomised, double-blind, placebo-controlled trial. Diabetologia. 2017 Aug;60(8):1390–9. doi: 10.1007/s00125-017-4289-0. PMID: 28526920. Exclusion Code: X2.28526920
1266 Karagiannis T, Liakos A, Bekiari E, . Efficacy and safety of once-weekly glucagon-like peptide 1 receptor agonists for the management of type 2 diabetes: a systematic review and meta-analysis of randomized controlled trials. Diabetes Obes Metab. 2015 Nov;17(11):1065–74. doi: 10.1111/dom.12541. PMID: 26395850. Exclusion Code: X8.26395850
1267 Karagiannis T, Liakos A, Branda ME, . Use of the Diabetes Medication Choice Decision Aid in patients with type 2 diabetes in Greece: a cluster randomised trial. BMJ open. 2016;6(11):e012185. doi: 10.1136/bmjopen-2016-012185. PMID: CN-01443720. Exclusion Code: X2.
1268 Karahasanovic A, Vestergaard P, Christensen L, . RTC - The effect of metformin on bone assessed by bone mineral density and trabecular bone score. Journal of bone and mineral research. Conference: 2016 annual meeting of the american society for bone and mineral research, ASBMR 2016. United states. 2017;31(Supplement 1) (no pagination)doi: 10.1002/jbmr.3107. PMID: CN-01462247. Exclusion Code: X2.
1269 Kargar Jahromi M, Ramezanli S, Taheri L. Effectiveness of diabetes self-management education on quality of life in diabetic elderly females. Glob J Health Sci. 2014 Jul 29;7(1):10–5. doi: 10.5539/gjhs.v7n1p10. PMID: 25560339. Exclusion Code: X7.25560339
1270 Karhula T, Vuorinen AL, Raapysjarvi K, . Telemonitoring and mobile phone-based health coaching among finnish diabetic and heart disease patients: randomized controlled trial. J Med Internet Res. 2015 Jun 17;17(6):e153. doi: 10.2196/jmir.4059. PMID: 26084979. Exclusion Code: X2.26084979
1271 Karimi H, Rehman S, Gillani S. Effects of supervised structured aerobic exercise training program on interleukin-6, nitric oxide synthase-1, and cyclooxygenase-2 in type 2 diabetes mellitus. Journal of the college of physicians and surgeons--pakistan : JCPSP. 2017;27(6):352–5. PMID: CN-01395675. Exclusion Code: X2.28689524
1272 Karimifar M, Aminorroaya A, Amini M, . Effect of metformin on thyroid stimulating hormone and thyroid volume in patients with prediabetes: a randomized placebo-controlled clinical trial. Journal of research in medical sciences. 2014;19(11):1019–26. PMID: CN-01040622. Exclusion Code: X6.25657744
1273 Karjalainen JJ, Kiviniemi AM, Hautala AJ, . Effects of physical activity and exercise training on cardiovascular risk in coronary artery disease patients with and without type 2 diabetes. Diabetes Care. 2015 Apr;38(4):706–15. doi: 10.2337/dc14-2216. PMID: 25592198. Exclusion Code: X2.25592198
1274 Karmali KN, Persell SD, Perel P, . Risk scoring for the primary prevention of cardiovascular disease. Cochrane Database of Systematic Reviews. 2017(3)doi: 10.1002/14651858.CD006887.pub4. PMID: CD006887. Exclusion Code: X8.
1275 Karstoft K, Christensen C, Pedersen B, . The acute effects of interval- vs continuous-walking exercise on glycemic control in subjects with type 2 diabetes: a crossover, controlled study. Journal of clinical endocrinology and metabolism. 2014;99(9):3334–42. doi: 10.1210/jc.2014-1837. PMID: CN-01014419. Exclusion Code: X2.24905068
1276 Karstoft K, Clark MA, Jakobsen I, . Glucose effectiveness, but not insulin sensitivity, is improved after short-term interval training in individuals with type 2 diabetes mellitus: a controlled, randomised, crossover trial. Diabetologia. 2017 Dec;60(12):2432–42. doi: 10.1007/s00125-017-4406-0. PMID: 28842722. Exclusion Code: X2.28842722
1277 Karstoft K, Clark MA, Jakobsen I, . The effects of 2 weeks of interval vs continuous walking training on glycaemic control and whole-body oxidative stress in individuals with type 2 diabetes: a controlled, randomised, crossover trial. Diabetologia. 2017 Mar;60(3):508–17. doi: 10.1007/s00125-016-4170-6. PMID: 27942800. Exclusion Code: X2.27942800
1278 Karstoft K, Wallis G, Pedersen B, . The effects of interval- vs. continuous exercise on excess post-exercise oxygen consumption and substrate oxidation rates in subjects with type 2 diabetes. Metabolism. 2016;65(9):1316–25. doi: 10.1016/j.metabol.2016.05.017. PMID: CN-01166168. Exclusion Code: X6.27506739
1279 Karstoft K, Winding K, Knudsen S, . Mechanisms behind the superior effects of interval vs continuous training on glycaemic control in individuals with type 2 diabetes: a randomised controlled trial. Diabetologia. 2014;57(10):2081–93. doi: 10.1007/s00125-014-3334-5. PMID: CN-01070585. Exclusion Code: X2.25099941
1280 Karunakaran S, Hammersley MS, Morris RJ, . The Fasting Hyperglycaemia Study: III. Randomized controlled trial of sulfonylurea therapy in subjects with increased but not diabetic fasting plasma glucose. Metabolism. 1997 Dec;46(12 Suppl 1):56–60. PMID: 9439561. Exclusion Code: X11.9439561
1281 Kashi Z, Mahrooz A, Kianmehr A, . The role of metformin response in lipid metabolism in patients with recent-onset type 2 diabetes: HbA1c level as a criterion for designating patients as responders or nonresponders to metformin. PLoS One. 2016;11(3):e0151543. doi: 10.1371/journal.pone.0151543. PMID: 26978661. Exclusion Code: X6.26978661
1282 Kashi Z, Masoumi P, Mahrooz A, . The variant organic cation transporter 2 (OCT2)-T201M contribute to changes in insulin resistance in patients with type 2 diabetes treated with metformin. Diabetes Res Clin Pract. 2015 Apr;108(1):78–83. doi: 10.1016/j.diabres.2015.01.024. PMID: 25662675. Exclusion Code: X6.25662675
1283 Kashiwagi A, Takahashi H, Ishikawa H, . A randomized, double-blind, placebo-controlled study on long-term efficacy and safety of ipragliflozin treatment in patients with type 2 diabetes mellitus and renal impairment: results of the long-term ASP1941 safety evaluation in patients with type 2 diabetes with renal impairment (LANTERN) study. Diabetes, obesity & metabolism. 2015;17(2):152–60. doi: 10.1111/dom.12403. PMID: CN-01048929. Exclusion Code: X2.
1284 Kashiwagi A, Yoshida S, Nakamura I, . Efficacy and safety of ipragliflozin in Japanese patients with type 2 diabetes stratified by body mass index: A subgroup analysis of five randomized clinical trials. J Diabetes Investig. 2016 Jul;7(4):544–54. doi: 10.1111/jdi.12471. PMID: 27181576. Exclusion Code: X8.27181576
1285 Katabami T, Murakami M, Kobayashi S, . Efficacy of low-dose rosuvastatin in patients with type 2 diabetes and hypo high-density lipoprotein cholesterolaemia. J Int Med Res. 2014 Apr;42(2):457–67. doi: 10.1177/0300060513507648. PMID: 24595147. Exclusion Code: X5.24595147
1286 Katakami N, Mita T, Irie Y, . Effect of sitagliptin on tissue characteristics of the carotid wall in patients with type 2 diabetes: a post hoc sub-analysis of the sitagliptin preventive study of intima-media thickness evaluation (SPIKE). Cardiovasc Diabetol. 2018;17(1) (no pagination)doi: 10.1186/s12933-018-0666-3. PMID: CN-01460174. Exclusion Code: X2.
1287 Kataoka Y, Yasuda S, Miyamoto Y, . Clinical predictors of atheroma progression despite optimal glycemic control in early-stage diabetic patients with coronary artery disease: Insight from the DIANA study. J Atheroscler Thromb. 2014;21(5):509–18. PMID: 24430787. Exclusion Code: X2.24430787
1288 Katayama S, Yamada D, Nakayama M, . A randomized controlled study of finerenone versus placebo in Japanese patients with type 2 diabetes mellitus and diabetic nephropathy. J Diabetes Complications. 2017 Apr;31(4):758–65. doi: 10.1016/j.jdiacomp.2016.11.021. PMID: 28025025. Exclusion Code: X2.28025025
1289 Kato S, Fukui K, Kirigaya H, . Inhibition of DPP-4 by alogliptin improves coronary flow reserve and left ventricular systolic function evaluated by phase contrast cine magnetic resonance imaging in patients with type 2 diabetes and coronary artery disease. Int J Cardiol. 2016 Nov 15;223:770–5. doi: 10.1016/j.ijcard.2016.08.306. PMID: 27573605. Exclusion Code: X2.27573605
1290 Kato S, Maruyama S, Makino H, . Anti-albuminuric effects of spironolactone in patients with type 2 diabetic nephropathy: a multicenter, randomized clinical trial. Clin Exp Nephrol. 2015 Dec;19(6):1098–106. doi: 10.1007/s10157-015-1106-2. PMID: 25795029. Exclusion Code: X2.25795029
1291 Katula JA, Kirk JK, Pedley CF, . The Lifestyle Intervention for the Treatment of Diabetes study (LIFT Diabetes): design and baseline characteristics for a randomized translational trial to improve control of cardiovascular disease risk factors. Contemp Clin Trials. 2017 Feb;53:89–99. doi: 10.1016/j.cct.2016.12.005. PMID: 27940180. Exclusion Code: X6.27940180
1292 Katz M, Califf RM, Sun JL, . Venous thromboembolism and cardiovascular risk: results from the NAVIGATOR trial. Am J Med. 2015 Mar;128(3):297–302. doi: 10.1016/j.amjmed.2014.08.022. PMID: 25447626. Exclusion Code: X5.25447626
1293 Katzeff HL, Williams-Herman D, Xu L, . Long-term efficacy of sitagliptin as either monotherapy or add-on therapy to metformin: improvement in glycemic control over 2 years in patients with type 2 diabetes. Curr Med Res Opin. 2015 Jun;31(6):1071–7. doi: 10.1185/03007995.2015.1037259. PMID: 25850968. Exclusion Code: X8.25850968
1294 Kaufmann P. Decomposing the effects of the study population on null results: the look ahead trial. Trials. Conference: 4th international clinical trials methodology conference , ICTMC and the 38th annual meeting of the society for clinical trials. United kingdom. 2017;18(Supplement 1) (no pagination)doi: 10.1186/s13063-017-1902-y. PMID: CN-01470595. Exclusion Code: X2.
1295 Kaur J, Singh S, Vij J. Optimization of aerobic exercise protocols in diabetes mellitus: a randomized trial. Romanian journal of diabetes, nutrition and metabolic diseases. 2017;24(4):333–44. doi: 10.1515/rjdnmd-2017-0039. PMID: CN-01460449. Exclusion Code: X5.
1296 Kawahara T. Eldecalcitol, a vitamin D analog, for diabetes prevention in impaired glucose tolerance (DPVD study). Diabetes. 2018;67:LB34-. PMID: CN-01631241. Exclusion Code: X4.
1297 Kawahara T, Suzuki G, Inazu T, . Rationale and design of Diabetes Prevention with active Vitamin D (DPVD): a randomised, double-blind, placebo-controlled study. BMJ open. 2016;6(7):e011183. doi: 10.1136/bmjopen-2016-011183. PMID: CN-01444643. Exclusion Code: X6.
1298 Kawahara T, Suzuki G, Inazu T, . Eldecalcitol, a vitamin D analogue, for diabetes prevention in impaired glucose tolerance: DPVD study. Diabetologia. 2018;61:S78–S9. doi: 10.1007/s00125-018-4693-0. PMID: CN-01647131. Exclusion Code: X4.
1299 Kawamori R, Kaku K, Hanafusa T, . Effect of combination therapy with repaglinide and metformin hydrochloride on glycemic control in Japanese patients with type 2 diabetes mellitus. Journal of diabetes investigation. 2014;5(1):70–9. doi: 10.1111/jdi.12121. PMID: CN-00981739. Exclusion Code: X2.
1300 Kawazu S, Kanazawa Y, Iwamoto Y, . Effect of antihyperglycemic drug monotherapy to prevent the progression of mild hyperglycemia in early type 2 diabetic patients: the Japan Early Diabetes Intervention Study (JEDIS). Diabetology international. 2017;8(4):350–65. doi: 10.1007/s13340-017-0319-x. PMID: CN-01432077. Exclusion Code: X8.30603341
1301 Kazda CM, Frias J, Foga I, . Treatment with the glucagon receptor antagonist LY2409021 increases ambulatory blood pressure in patients with type 2 diabetes. Diabetes Obes Metab. 2017 Aug;19(8):1071–7. doi: 10.1111/dom.12904. PMID: 28191913. Exclusion Code: X2.28191913
1302 Kazierad DJ, Bergman A, Tan B, . Effects of multiple ascending doses of the glucagon receptor antagonist PF-06291874 in patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2016 Aug;18(8):795–802. doi: 10.1111/dom.12672. PMID: 27059951. Exclusion Code: X2.27059951
1303 Kazierad DJ, Chidsey K, Somayaji VR, . Efficacy and safety of the glucagon receptor antagonist PF-06291874: A 12-week, randomized, dose-response study in patients with type 2 diabetes mellitus on background metformin therapy. Diabetes Obes Metab. 2018 Nov;20(11):2608–16. doi: 10.1111/dom.13440. PMID: 29923286. Exclusion Code: X2.29923286
1304 Ke W, Liu L, Liu J, . Effects of liraglutide combined with short-term continuous subcutaneous insulin infusion on glycemic control and beta cell function in patients with newly diagnosed type 2 diabetes mellitus: a pilot study. J Diabetes Res. 2016;2016:6839735. doi: 10.1155/2016/6839735. PMID: 26640805. Exclusion Code: X5.26640805
1305 Kearney M, Orrell RW, Fahey M, . Pharmacological treatments for Friedreich ataxia. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
1306 Keerthi G, Pal P, Pal G, . Effect of 12 weeks of yoga therapy on quality of life and indian diabetes risk score in normotensive Indian young adult prediabetics and diabetics: randomized control trial. Journal of clinical and diagnostic research. 2017;11(9):Cc10–cc4. doi: 10.7860/JCDR/2017/29307.10633. PMID: CN-01422586. Exclusion Code: X6.
1307 Kellner C, Kuniss N, Kloos C, . No selection, but higher satisfaction of people participating in the disease management programme diabetes type 2 in Germany. Acta Diabetol. 2018 Apr;55(4):363–7. doi: 10.1007/s00592-018-1106-2. PMID: 29383585. Exclusion Code: X8.29383585
1308 Kellow NJ, Coughlan MT, Reid CM. Metabolic benefits of dietary prebiotics in human subjects: a systematic review of randomised controlled trials. Br J Nutr. 2014 Apr 14;111(7):1147–61. doi: 10.1017/s0007114513003607. PMID: 24230488. Exclusion Code: X8.24230488
1309 Kelly TN, Bazzano LA, Fonseca VA, . Systematic review: glucose control and cardiovascular disease in type 2 diabetes. Ann Intern Med. 2009 Sep 15;151(6):394–403. PMID: 19620144. Exclusion Code: X8.19620144
1310 Kempf K, Röhling M, Niedermeier K, . Individualized meal replacement therapy improves clinically relevant long-term glycemic control in poorly controlled type 2 diabetes patients. Nutrients. 2018;10(8)doi: 10.3390/nu10081022. PMID: CN-01664763. Exclusion Code: X2.
1311 Kender Z, Fleming T, Kopf S, . Effect of metformin on methylglyoxal metabolism in patients with type 2 diabetes. Exp Clin Endocrinol Diabetes. 2014 May;122(5):316–9. doi: 10.1055/s-0034-1371818. PMID: 24710646. Exclusion Code: X5.24710646
1312 Kent LM, Reierson P, Morton DP. ‘Live more’: study protocol for a community-based lifestyle education program addressing non-communicable diseases in low-literacy areas of the South Pacific. BMC Public Health. 2015 Dec 9;15:1221. doi: 10.1186/s12889-015-2560-1. PMID: 26652606. Exclusion Code: X2.26652606
1313 Kerfoot BP, Gagnon DR, McMahon GT, . A team-based online game improves blood glucose control in veterans with type 2 diabetes: a randomized controlled trial. Diabetes Care. 2017 Sep;40(9):1218–25. doi: 10.2337/dc17-0310. PMID: 28790131. Exclusion Code: X6.28790131
1314 Kern W, Wehrhahn T, Le Roux C, . Reduction in the risk of developing type 2 diabetes (T2D) with liraglutide 3.0 mg in people with prediabetes from the SCALE Obesity and Prediabetes randomized, double-blind, placebo-controlled trial. Diabetologie und stoffwechsel. 2016;11doi: 10.1055/s-0036-1580798. PMID: CN-01768958. Exclusion Code: X10.
1315 Kerrison G, Gillis RB, Jiwani SI, . The effectiveness of lifestyle adaptation for the prevention of prediabetes in adults: a systematic review. J Diabetes Res. 2017;2017:8493145. doi: 10.1155/2017/8493145. PMID: 28567425. Exclusion Code: X8.28567425
1316 Khalangot MD, Kovtun VA, Gurianov VG, . Evaluation of type 2 diabetes prevention through diet modification in people with impaired glucose regulation: a population-based study. Prim Care Diabetes. 2019doi: 10.1016/j.pcd.2019.03.011. PMID: CN-01939528. Exclusion Code: X5.
1317 Khan I, Siddiqui AH, Singhal S, . Glycaemic status in patients of acute myocardial infarction: a detailed analysis. Diabetes Metab Syndr. 2016 Jan-Mar;10(1 Suppl 1):S140–3. doi: 10.1016/j.dsx.2015.09.026. PMID: 26701341. Exclusion Code: X2.26701341
1318 Khan KM, Windt A, Davis JC, . Group Medical Visits (GMVs) in primary care: an RCT of group-based versus individual appointments to reduce HbA1c in older people. BMJ Open. 2015 Jul 13;5(7):e007441. doi: 10.1136/bmjopen-2014-007441. PMID: 26169803. Exclusion Code: X4.26169803
1319 Khan O, Ferriter M, Huband N, . Pharmacological interventions for those who have sexually offended or are at risk of offending. Cochrane Database of Systematic Reviews. 2015(2)doi: 10.1002/14651858.CD007989.pub2. PMID: CD007989. Exclusion Code: X8.
1320 Khanna R, Stoddard P, Gonzales E, . An automated telephone nutrition support system for Spanish-speaking patients with diabetes. J Diabetes Sci Technol. 2014;8(6):1115–20. doi: 10.1177/1932296814550186. PMID: CN-01101391. Exclusion Code: X2.25239122
1321 Ki YJ, Kim HJ, Kim MS, . Association between metformin use and survival in nonmetastatic rectal cancer treated with a curative resection: a nationwide population study. Cancer Res Treat. 2017 Jan;49(1):29–36. doi: 10.4143/crt.2016.128. PMID: 27384155. Exclusion Code: X2.27384155
1322 Kim C, Barrett-Connor E, Aroda VR, . Testosterone and depressive symptoms among men in the Diabetes Prevention Program. Psychoneuroendocrinology. 2016 Oct;72:63–71. doi: 10.1016/j.psyneuen.2016.06.009. PMID: 27371769. Exclusion Code: X6.27371769
1323 Kim C, Golden S, Kong S, . Does hormone therapy affect blood pressure changes in the Diabetes Prevention Program? Menopause. 2014;21(5):477–83. doi: 10.1097/GME.0b013e3182a0e3ea. PMID: CN-00997478. Exclusion Code: X5.23942251
1324 Kim C, Randolph JF, Golden SH, . Weight loss increases follicle stimulating hormone in overweight postmenopausal women [corrected]. Obesity (Silver Spring). 2015 Jan;23(1):228–33. doi: 10.1002/oby.20917. PMID: 25294746. Exclusion Code: X6.25294746
1325 Kim C, Ricardo AC, Boyko EJ, . Sex hormones and measures of kidney function in the Diabetes Prevention Program Outcomes Study. J Clin Endocrinol Metab. 2019 Apr 1;104(4):1171–80. doi: 10.1210/jc.2018-01495. PMID: 30398516. Exclusion Code: X5.30398516
1326 Kim CRJGSLFKSNBB-CE. Weight loss decreases follicle stimulating hormone in overweight postmenopausal women. Obesity (Silver Spring, Md.). 2015;23(1):228–33. doi: 10.1002/oby.20917. PMID: CN-01076586. Exclusion Code: X8.
1327 Kim D, Koh K, Swaminathan S, . Association of diabetes diagnosis with dietary changes and weight reduction. Expert Rev Pharmacoecon Outcomes Res. 2018 Oct;18(5):543–50. doi: 10.1080/14737167.2018.1468257. PMID: 29676589. Exclusion Code: X8.29676589
1328 Kim G, Jang SY, Han E, . Effect of statin on hepatocellular carcinoma in patients with type 2 diabetes: a nationwide nested case-control study. Int J Cancer. 2017 Feb 15;140(4):798–806. doi: 10.1002/ijc.30506. PMID: 27861855. Exclusion Code: X2.27861855
1329 Kim HJ, Ahn HY, Kwak JH, . The effects of chitosan oligosaccharide (GO2KA1) supplementation on glucose control in subjects with prediabetes. Food Funct. 2014 Oct;5(10):2662–9. doi: 10.1039/c4fo00469h. PMID: 25222285. Exclusion Code: X4.25222285
1330 Kim HJ, Lee S, Chun KH, . Metformin reduces the risk of cancer in patients with type 2 diabetes: An analysis based on the Korean National Diabetes Program Cohort. Medicine (Baltimore). 2018 Feb;97(8):e0036. doi: 10.1097/md.0000000000010036. PMID: 29465545. Exclusion Code: X2.29465545
1331 Kim HM, Seong JM, Kim J. Risk of hospitalization for hypoglycemia among older Korean people with diabetes mellitus: Interactions between treatment modalities and comorbidities. Medicine (Baltimore). 2016 Oct;95(42):e5016. doi: 10.1097/md.0000000000005016. PMID: 27759630. Exclusion Code: X8.27759630
1332 Kim J, Back M, Yi H-S, . Effect of atorvastatin on growth differentiation factor-15 in patients with type 2 diabetes mellitus and dyslipidemia. Diabetes & metabolism journal. 2016;40(1):70–8. doi: 10.4093/dmj.2016.40.1.70. PMID: CN-01137815. Exclusion Code: X2.26616597
1333 Kim K, Kim M, Lee H, . Community health workers versus nurses as counselors or case managers in a self-help diabetes management program. Am J Public Health. 2016;106(6):1052–8. doi: 10.2105/AJPH.2016.303054. PMID: CN-01379977. Exclusion Code: X6.26985607
1334 Kim KM, Park KS, Lee HJ, . Efficacy of a new medical information system, ubiquitous healthcare service with voice inception technique in elderly diabetic patients. Sci Rep. 2015 Dec 11;5:18214. doi: 10.1038/srep18214. PMID: 26658492. Exclusion Code: X2.26658492
1335 Kim MT, Kim KB, Huh B, . The effect of a community-based self-help intervention: Korean Americans with type 2 diabetes. Am J Prev Med. 2015 Nov;49(5):726–37. doi: 10.1016/j.amepre.2015.04.033. PMID: 26184986. Exclusion Code: X6.26184986
1336 Kim NH, Choi J, Kim NH, . Dipeptidyl peptidase-4 inhibitor use and risk of diabetic retinopathy: a population-based study. Diabetes Metab. 2018 Sep;44(4):361–7. doi: 10.1016/j.diabet.2018.03.004. PMID: 29752167. Exclusion Code: X8.29752167
1337 Kim SG, Kim DM, Woo JT, . Efficacy and safety of lobeglitazone monotherapy in patients with type 2 diabetes mellitus over 24-weeks: a multicenter, randomized, double-blind, parallel-group, placebo controlled trial. PLoS One. 2014;9(4):e92843. doi: 10.1371/journal.pone.0092843. PMID: 24736628. Exclusion Code: X2.24736628
1338 Kim SH, Kim SG, Kim DM, . Safety and efficacy of lobeglitazone monotherapy in patients with type 2 diabetes mellitus over 52 weeks: An open-label extension study. Diabetes Res Clin Pract. 2015 Dec;110(3):e27–30. doi: 10.1016/j.diabres.2015.09.009. PMID: 26458774. Exclusion Code: X5.26458774
1339 Kim SH, Lee SH, Ahn KY, . Effect of lifestyle modification on serum chemerin concentration and its association with insulin sensitivity in overweight and obese adults with type 2 diabetes. Clin Endocrinol (Oxf). 2014 Jun;80(6):825–33. doi: 10.1111/cen.12249. PMID: 23682797. Exclusion Code: X2.23682797
1340 Kim SH, Liu A, Ariel D, . Pancreatic beta cell function following liraglutide-augmented weight loss in individuals with prediabetes: analysis of a randomised, placebo-controlled study. Diabetologia. 2014 Mar;57(3):455–62. doi: 10.1007/s00125-013-3134-3. PMID: 24326527. Exclusion Code: X6.24326527
1341 Kim S-H, Yu J, Jang H, . Efficacy and safety of gemigliptin as add-on therapy in patients with type 2 diabetes inadequately controlled on metformin and glimepiride. Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S357. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212720. Exclusion Code: X2.
1342 Kim SS, Kim IJ, Lee KJ, . Efficacy and safety of sitagliptin/metformin fixed-dose combination compared with glimepiride in patients with type 2 diabetes: A multicenter randomized double-blind study. J Diabetes. 2017 Apr;9(4):412–22. doi: 10.1111/1753-0407.12432. PMID: 27229178. Exclusion Code: X2.27229178
1343 Kim TM, Kim H, Jeong YJ, . The differences in the incidence of diabetes mellitus and prediabetes according to the type of HMG-CoA reductase inhibitors prescribed in Korean patients. Pharmacoepidemiol Drug Saf. 2017 Oct;26(10):1156–63. doi: 10.1002/pds.4237. PMID: 28556206. Exclusion Code: X8.28556206
1344 Kim YG, Byun J, Yoon D, . Renal protective effect of DPP-4 inhibitors in type 2 diabetes mellitus patients: a cohort study. J Diabetes Res. 2016;2016:1423191. doi: 10.1155/2016/1423191. PMID: 28119930. Exclusion Code: X2.28119930
1345 Kim YG, Yoon D, Park S, . Dipeptidyl peptidase-4 inhibitors and risk of heart failure in patients with type 2 diabetes mellitus: a population-based cohort study. Circ Heart Fail. 2017 Sep;10(9)doi: 10.1161/circheartfailure.117.003957. PMID: 28899989. Exclusion Code: X8.28899989
1346 Kirilmaz U, Guzel O, Aslan Y, . The effect of lifestyle modification and glycemic control on the efficiency of sildenafil citrate in patients with erectile dysfunction due to type-2 diabetes mellitus. Aging Male. 2015;18(4):244–8. doi: 10.3109/13685538.2015.1072154. PMID: 26248034. Exclusion Code: X4.26248034
1347 Kirk JK, Graves DE, Craven TE, . Restricted-carbohydrate diets in patients with type 2 diabetes: a meta-analysis (Structured abstract). Journal of the American Dietetic Association; 2008. p. 91–100. Exclusion Code: X8.
1348 Kiss LZ, Bagyura Z, Vadas R, . Signs of subclinical atherosclerosis in asymptomatic patients at increased risk of type 2 diabetes mellitus. J Diabetes Complications. 2017 Aug;31(8):1293–8. doi: 10.1016/j.jdiacomp.2017.05.007. PMID: 28576484. Exclusion Code: X8.28576484
1349 Kistner I, Zeymer U, Dechend R, . Benefits and risks of aliskiren treatment in patients with type 2 diabetes: analyses of the 3A Registry. J Clin Hypertens (Greenwich). 2016 Oct;18(10):1045–53. doi: 10.1111/jch.12828. PMID: 27094460. Exclusion Code: X8.27094460
1350 Kitabchi A, Brewer A, Wan J, . Remission of impaired glucose tolerance (IGT) to normal glucose tolerance (NGT) in obese adults with high protein vs. High carbohydrate diet. Diabetes. 2015;64:A23–a4. doi: 10.2337/db151385. PMID: CN-01103860. Exclusion Code: X5.
1351 Kitao N, Miyoshi H, Furumoto T, . The effects of vildagliptin compared with metformin on vascular endothelial function and metabolic parameters: a randomized, controlled trial (Sapporo Athero-Incretin Study 3). Cardiovasc Diabetol. 2017 Oct 10;16(1):125. doi: 10.1186/s12933-017-0607-6. PMID: 29017497. Exclusion Code: X6.29017497
1352 Kitzman H, Dodgen L, Mamun A, . Community-based participatory research to design a faith-enhanced diabetes prevention program: The Better Me Within randomized trial. Contemp Clin Trials. 2017 Nov;62:77–90. doi: 10.1016/j.cct.2017.08.003. PMID: 28807739. Exclusion Code: X7.28807739
1353 Kivela J, Lindstrom J, Uusitupa M, . Serum branched chain amino acids, dietary macronutrients and development of type 2 diabetes in the Finnish Diabetes study. Diabetologia. Conference: 53rd annual meeting of the european association for the study of diabetes, EASD 2017. Portugal. 2017;60(1 Supplement 1):S295–s6. doi: 10.1007/s00125-017-4350-z. PMID: CN-01418938. Exclusion Code: X5.
1354 Kleinman NJ, Shah A, Shah S, . Improved medication adherence and frequency of blood glucose self-testing using an m-Health platform versus usual care in a multisite randomized clinical trial among people with type 2 diabetes in India. Telemed J E Health. 2017;23(9):733–40. doi: 10.1089/tmj.2016.0265. PMID: CN-01604684. Exclusion Code: X2.28328396
1355 Klimas J, Tobin H, Field C-A, . Psychosocial interventions to reduce alcohol consumption in concurrent problem alcohol and illicit drug users. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
1356 Kline CE, Reboussin DM, Foster GD, . The effect of changes in cardiorespiratory fitness and weight on obstructive sleep apnea severity in overweight adults with type 2 diabetes. Sleep. 2016 Feb 1;39(2):317–25. doi: 10.5665/sleep.5436. PMID: 26446118. Exclusion Code: X6.26446118
1357 Klupp NL, Chang D, Hawke F, . Ganoderma lucidum mushroom for the treatment of cardiovascular risk factors. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
1358 Knapen LM, de Jong RG, Driessen JH, . Use of incretin agents and risk of acute and chronic pancreatitis: a population-based cohort study. Diabetes Obes Metab. 2017 Mar;19(3):401–11. doi: 10.1111/dom.12833. PMID: 27883260. Exclusion Code: X5.27883260
1359 Knapen LM, van Dalem J, Keulemans YC, . Use of incretin agents and risk of pancreatic cancer: a population-based cohort study. Diabetes Obes Metab. 2016 Mar;18(3):258–65. doi: 10.1111/dom.12605. PMID: 26537555. Exclusion Code: X8.26537555
1360 Koffert JP, Mikkola K, Virtanen KA, . Metformin treatment significantly enhances intestinal glucose uptake in patients with type 2 diabetes: Results from a randomized clinical trial. Diabetes Res Clin Pract. 2017 Sep;131:208–16. doi: 10.1016/j.diabres.2017.07.015. PMID: 28778047. Exclusion Code: X6.28778047
1361 Kohler S, Kaspers S, Salsali A, . Analysis of fractures in patients with type 2 diabetes treated with empagliflozin in pooled data from placebo-controlled trials and a head-to-head study versus glimepiride. Diabetes Care. 2018 Aug;41(8):1809–16. doi: 10.2337/dc17-1525. PMID: 29907581. Exclusion Code: X8.29907581
1362 Kohler S, Zeller C, Iliev H, . Safety and tolerability of empagliflozin in patients with type 2 diabetes: pooled analysis of phase I-III clinical trials. Adv Ther. 2017 Jul;34(7):1707–26. doi: 10.1007/s12325-017-0573-0. PMID: 28631216. Exclusion Code: X8.28631216
1363 Kollannoor-Samuel G, Shebl FM, Segura-Perez S, . Effects of food label use on diet quality and glycemic control among latinos with type 2 diabetes in a community health worker-supported intervention. Am J Public Health. 2016 Jun;106(6):1059–66. doi: 10.2105/ajph.2016.303091. PMID: 27077337. Exclusion Code: X6.27077337
1364 Kolotkin R, Manning L, Meincke H, . Improvements in impact of weight on quality of life-lite (Iwqollite) with liraglutide 3.0 mg (LIRA) vs. placebo (PBO) for Weight management: 3-Year data. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A69–a70. doi: 10.2337/db16-1-381. PMID: CN-01449787. Exclusion Code: X10.
1365 Kolotkin R, Shapiro ML, Meincke H, . Improvements in ‘impact of weight on quality of life-lite’ score with liraglutide 3.0 mg vs placebo for weight management: 3-year data. Diabetologia. Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference start: 20160912. Conference end: 20160916. 2016;59(1 Supplement 1):S331. doi: 10.1007/s00125-016-4046-9. PMID: CN-01267751. Exclusion Code: X10.
1366 Kolotkin RL, Fujioka K, Wolden ML, . Improvements in health-related quality of life with liraglutide 3.0 mg compared with placebo in weight management. Clin Obes. 2016 Aug;6(4):233–42. doi: 10.1111/cob.12146. PMID: 27198973. Exclusion Code: X2.27198973
1367 Kolotkin RL, Gabriel Smolarz B, Meincke HH, . Improvements in health-related quality of life over 3 years with liraglutide 3.0 mg compared with placebo in participants with overweight or obesity. Clin Obes. 2018 Feb;8(1):1–10. doi: 10.1111/cob.12226. PMID: 29045079. Exclusion Code: X12.29045079
1368 Koloverou E, Esposito K, Giugliano D, . The effect of Mediterranean diet on the development of type 2 diabetes mellitus: a meta-analysis of 10 prospective studies and 136,846 participants. Metabolism. 2014 Jul;63(7):903–11. doi: 10.1016/j.metabol.2014.04.010. PMID: 24931280. Exclusion Code: X8.24931280
1369 Koloverou E, Panagiotakos DB, Pitsavos C, . Adherence to Mediterranean diet and 10-year incidence (2002-2012) of diabetes: correlations with inflammatory and oxidative stress biomarkers in the ATTICA cohort study. Diabetes Metab Res Rev. 2016 Jan;32(1):73–81. doi: 10.1002/dmrr.2672. PMID: 26104243. Exclusion Code: X2.26104243
1370 Koloverou E, Tentolouris N, Bakoula C, . Implementation of a stress management program in outpatients with type 2 diabetes mellitus: a randomized controlled trial. Hormones (Athens). 2014 Oct-Dec;13(4):509–18. doi: 10.14310/horm.2002.1492. PMID: 25555183. Exclusion Code: X4.25555183
1371 Kondo T, Ono K, Kitano S, . Mild electrical stimulation with heat shock reduces visceral adiposity and improves metabolic abnormalities in subjects with metabolic syndrome or type 2 diabetes: randomized crossover trials. Ebiomedicine. 2014;1(1 // () *Ministry of Education, Culture, Sports, Science, and Technology*):80–9. doi: 10.1016/j.ebiom.2014.11.001. PMID: CN-01048511. Exclusion Code: X4.26137510
1372 Kondo Y, Harada N, Hamasaki A, . Sitagliptin monotherapy has better effect on insulinogenic index than glimepiride monotherapy in Japanese patients with type 2 diabetes mellitus: a 52-week, multicenter, parallel-group randomized controlled trial. Diabetology & metabolic syndrome. 2016;8(1) (no pagination)doi: 10.1186/s13098-016-0131-y. PMID: CN-01137532. Exclusion Code: X5.
1373 Kondo Y, Satoh S, Osada UN, . Early liraglutide treatment improves beta-cell function in patients with type 2 diabetes: a retrospective cohort study. Endocr J. 2015;62(11):971–80. doi: 10.1507/endocrj.EJ15-0206. PMID: 26249841. Exclusion Code: X6.26249841
1374 Kongstad MB, Valentiner LS, Ried-Larsen M, . Effectiveness of remote feedback on physical activity in persons with type 2 diabetes: a systematic review and meta-analysis of randomized controlled trials. J Telemed Telecare. 2019 Jan;25(1):26–34. doi: 10.1177/1357633x17733772. PMID: 28958212. Exclusion Code: X8.28958212
1375 Konig D, Kookhan S, Schaffner D, . A meal replacement regimen improves blood glucose levels in prediabetic healthy individuals with impaired fasting glucose. Nutrition. 2014 Nov-Dec;30(11–12):1306–9. doi: 10.1016/j.nut.2014.03.014. PMID: 25194963. Exclusion Code: X6.25194963
1376 Kooiman TJM, de Groot M, Hoogenberg K, . Self-tracking of physical activity in people with type 2 diabetes: a randomized controlled trial. Comput Inform Nurs. 2018 Jul;36(7):340–9. doi: 10.1097/cin.0000000000000443. PMID: 29742550. Exclusion Code: X6.29742550
1377 Kopecky C, Genser B, Drechsler C, . Quantification of HDL proteins, cardiac events, and mortality in patients with type 2 diabetes on hemodialysis. Clin J Am Soc Nephrol. 2015 Feb 6;10(2):224–31. doi: 10.2215/cjn.06560714. PMID: 25424990. Exclusion Code: X2.25424990
1378 Korhonen P, Heintjes EM, Williams R, . Pioglitazone use and risk of bladder cancer in patients with type 2 diabetes: retrospective cohort study using datasets from four European countries. Bmj. 2016 Aug 16;354:i3903. doi: 10.1136/bmj.i3903. PMID: 27530399. Exclusion Code: X5.27530399
1379 Korhonen PE, Kautiainen H, Mantyselka P. Screening for cardiovascular risk factors and self-rated health in a community setting: a cross-sectional study in Finland. Br J Gen Pract. 2014 Oct;64(627):e611–5. doi: 10.3399/bjgp14X681769. PMID: 25267046. Exclusion Code: X8.25267046
1380 Kornelius E, Chiou JY, Yang YS, . The diabetes shared care program and risks of cardiovascular events in type 2 diabetes. Am J Med. 2015 Sep;128(9):977–85.e3. doi: 10.1016/j.amjmed.2015.03.025. PMID: 25908394. Exclusion Code: X8.25908394
1381 Korytkowski MT, Forman DE. Management of atherosclerotic cardiovascular disease risk factors in the older adult patient with diabetes. Diabetes Care. 2017 Apr;40(4):476–84. doi: 10.2337/dc16-0815. PMID: 28325797. Exclusion Code: X8.28325797
1382 Kosiborod M, Gause-Nilsson I, Xu J, . Efficacy and safety of dapagliflozin in patients with type 2 diabetes and concomitant heart failure. J Diabetes Complications. 2017 Jul;31(7):1215–21. doi: 10.1016/j.jdiacomp.2017.02.001. PMID: 28284707. Exclusion Code: X2.28284707
1383 Koska J, Lopez L, D’Souza K, . Effect of liraglutide on dietary lipid-induced insulin resistance in humans. Diabetes, obesity & metabolism. 2018;20(1):69–76. doi: 10.1111/dom.13037. PMID: CN-01440363. Exclusion Code: X2.
1384 Koska J, Ozias M, Deer J, . A human model of dietary saturated fatty acid induced insulin resistance. Metabolism. 2016;65(11):1621–8. doi: 10.1016/j.metabol.2016.07.015. PMID: CN-01368583. Exclusion Code: X2.27733250
1385 Kour H, Goudar S, Kothiwale VA. Impact of lifestyle modifications on obesity parameters at different time intervals in newly diagnosed patients with type 2 diabetes mellitus. Journal of diabetes investigation. 2018;9:149–50. doi: 10.1111/jdi.12939. PMID: CN-01791697. Exclusion Code: X6.
1386 Kovacova Z, Tharp WG, Liu D, . Adipose tissue natriuretic peptide receptor expression is related to insulin sensitivity in obesity and diabetes. Obesity (Silver Spring). 2016 Apr;24(4):820–8. doi: 10.1002/oby.21418. PMID: 26887289. Exclusion Code: X6.26887289
1387 Kovacs CS, Seshiah V, Merker L, . Empagliflozin as add-on therapy to pioglitazone with or without metformin in patients with type 2 diabetes mellitus. Clin Ther. 2015 Aug;37(8):1773–88.e1. doi: 10.1016/j.clinthera.2015.05.511. PMID: 26138864. Exclusion Code: X2.26138864
1388 Kovacs CS, Seshiah V, Swallow R, . Empagliflozin improves glycaemic and weight control as add-on therapy to pioglitazone or pioglitazone plus metformin in patients with type 2 diabetes: a 24-week, randomized, placebo-controlled trial. Diabetes Obes Metab. 2014 Feb;16(2):147–58. doi: 10.1111/dom.12188. PMID: 23906415. Exclusion Code: X2.23906415
1389 Koval O, Pugach T, Kaplan P, . Early combined hypolipidemic therapy in patients with diabetes (T2DM) experienced acute coronary syndrome (ACS) as effective and safe approach for secondary prophylaxis. European journal of preventive cardiology. Conference: europrevent 2017. Spain. 2017;24(1 Supplement 1):S18–s9. PMID: CN-01376188. Exclusion Code: X2.
1390 Kowall B, Rathmann W, Kostev K. Are sulfonylurea and insulin therapies associated with a larger risk of cancer than metformin therapy? A retrospective database analysis. Diabetes Care. 2015 Jan;38(1):59–65. doi: 10.2337/dc14-0977. PMID: 25336750. Exclusion Code: X5.25336750
1391 Kowalski AJ, Poongothai S, Chwastiak L, . The INtegrating DEPrEssioN and Diabetes treatmENT (INDEPENDENT) study: design and methods to address mental healthcare gaps in India. Contemp Clin Trials. 2017 Sep;60:113–24. doi: 10.1016/j.cct.2017.06.013. PMID: 28642211. Exclusion Code: X6.28642211
1392 Kramer CK, Zinman B, Choi H, . The impact of chronic liraglutide therapy on glucagon secretion in type 2 diabetes: insight from the LIBRA Trial. J Clin Endocrinol Metab. 2015 Oct;100(10):3702–9. doi: 10.1210/jc.2015-2725. PMID: 26230296. Exclusion Code: X6.26230296
1393 Kramer CK, Zinman B, Choi H, . Chronic liraglutide therapy induces an enhanced endogenous glucagon-like peptide-1 secretory response in early type 2 diabetes. Diabetes Obes Metab. 2017 May;19(5):744–8. doi: 10.1111/dom.12858. PMID: 28181363. Exclusion Code: X6.28181363
1394 Kramer MK, Miller RG, Siminerio LM. Evaluation of a community diabetes prevention program delivered by diabetes educators in the United States: one-year follow up. Diabetes Res Clin Pract. 2014 Dec;106(3):e49–52. doi: 10.1016/j.diabres.2014.10.012. PMID: 25467620. Exclusion Code: X8.25467620
1395 Kramer MK, Vanderwood KK, Arena VC, . Evaluation of a diabetes prevention program lifestyle intervention in older adults: a randomized controlled study in three senior/community centers of varying socioeconomic status. Diabetes Educ. 2018 Apr;44(2):118–29. doi: 10.1177/0145721718759982. PMID: 29514568. Exclusion Code: X11.29514568
1396 Krass I, Carter R, Mitchell B, . Pharmacy Diabetes Screening Trial: protocol for a pragmatic cluster-randomised controlled trial to compare three screening methods for undiagnosed type 2 diabetes in Australian community pharmacy. BMJ open. 2017;7(12):e017725. doi: 10.1136/bmjopen-2017-017725. PMID: CN-01621583. Exclusion Code: X6.
1397 Kratochvilova S, Skoch A, Wohl P, . Intramyocellular lipid content in subjects with impaired fasting glucose after telmisartan treatment, a randomised cross-over trial. Magn Reson Imaging. 2016 Apr;34(3):353–8. doi: 10.1016/j.mri.2015.10.031. PMID: 26523653. Exclusion Code: X6.26523653
1398 Kraus WE, Yates T, Tuomilehto J, . Relationship between baseline physical activity assessed by pedometer count and new-onset diabetes in the NAVIGATOR trial. BMJ open diabetes research and care. 2018;6(1) (no pagination)doi: 10.1136/bmjdrc-2018-000523. PMID: CN-01617792. Exclusion Code: X5.
1399 Kreider M, Heise M. Rosiglitazone in the management of older patients with type 2 diabetes mellitus. Int J Clin Pract. 2002;56(7):538–41. PMID: CN-01714714. Exclusion Code: X8.12296617
1400 Krempf M, Astrup A, Fujioka K, . Additional analyses of the weight-lowering efficacy of liraglutide 3.0 Mg in overweight and obese adults: the scale obesity and prediabetes randomised trial. Obesity facts. 2015;8:210. doi: 10.1159/000382140. PMID: CN-01100825. Exclusion Code: X10.26087902
1401 Krempf M, Astrup A, Roux C, . Liraglutide 3.0 mg reduces body weight and improves cardiometabolic risk factors in overweight/obese adults: the SCALE obesity and prediabetes randomised trial. Diabetologia. 2014;57(1 suppl. 1):S368. doi: 10.1007/s00125-014-3355-0. PMID: CN-01059145. Exclusion Code: X10.
1402 Krogh-Madsen R, Pedersen M, Solomon TP, . Normal physical activity obliterates the deleterious effects of a high-caloric intake. J Appl Physiol (1985). 2014 Feb 1;116(3):231–9. doi: 10.1152/japplphysiol.00155.2013. PMID: 24201706. Exclusion Code: X2.24201706
1403 Krok-Schoen JL, Shim R, Nagel R, . Outcomes of a health coaching intervention delivered by medical students for older adults with uncontrolled type 2 diabetes. Gerontol Geriatr Educ. 2017 Jul-Sep;38(3):257–70. doi: 10.1080/02701960.2015.1018514. PMID: 25701102. Exclusion Code: X8.25701102
1404 Krysiak R, Drosdzol-Cop A, Skrzypulec-Plinta V, . Sexual functioning and depressive symptoms in women with diabetes and prediabetes receiving metformin therapy: a pilot study. Exp Clin Endocrinol Diabetes. 2017 Jan;125(1):42–8. doi: 10.1055/s-0042-116594. PMID: 27711958. Exclusion Code: X8.27711958
1405 Krysiak R, Gdula-Dymek A, Marek B, . Comparison of the effects of hypolipidemic treatment on monocyte proinflammatory cytokine release in men and women with type 2 diabetes and atherogenic dyslipidemia. Endokrynol Pol. 2015;66(3):224–30. doi: 10.5603/ep.2015.0029. PMID: 26136131. Exclusion Code: X6.26136131
1406 Krysiak R, Gdula-Dymek A, Marek B, . The effect of hypolipidemic treatment on monocyte cytokine release in different age groups of patients with type 2 diabetes and atherogenic dyslipidemia. Endokrynol Pol. 2016;67(2):190–6. doi: 10.5603/EP.a2016.0021. PMID: 26884290. Exclusion Code: X6.26884290
1407 Krysiak R, Gilowska M, Szkrobka W, . The effect of metformin on the hypothalamic-pituitary-thyroid axis in patients with type 2 diabetes and amiodarone-induced hypothyroidism. Pharmacol Rep. 2016 Apr;68(2):490–4. doi: 10.1016/j.pharep.2015.11.010. PMID: 26922558. Exclusion Code: X2.26922558
1408 Krysiak R, Gilowski W, Okopien B. The effect of testosterone on cardiovascular risk factors in men with type 2 diabetes and late-onset hypogonadism treated with metformin or glimepiride. Pharmacol Rep. 2016 Feb;68(1):75–9. doi: 10.1016/j.pharep.2015.06.003. PMID: 26721356. Exclusion Code: X6.26721356
1409 Krysiak R, Gilowski W, Szkrobka W, . The effect of atorvastatin on cardiometabolic risk factors in bromocriptine-treated premenopausal women with isolated hypercholesterolemia. Cardiovasc Ther. 2015 Oct;33(5):282–7. doi: 10.1111/1755-5922.12143. PMID: 26146893. Exclusion Code: X2.26146893
1410 Krysiak R, Kowalcze K, Bednarska-Czerwinska A, . The effect of simvastatin on plasma steroid hormone levels in metformin-treated women with non-classic congenital adrenal hyperplasia. Exp Clin Endocrinol Diabetes. 2016 Apr;124(4):215–9. doi: 10.1055/s-0035-1569375. PMID: 26824284. Exclusion Code: X2.26824284
1411 Krysiak R, Kowalcze K, Szkrobka W, . The effect of metformin on prolactin levels in patients with drug-induced hyperprolactinemia. Eur J Intern Med. 2016 May;30:94–8. doi: 10.1016/j.ejim.2016.01.015. PMID: 26858210. Exclusion Code: X2.26858210
1412 Krysiak R, Szkrobka W, Okopien B. The effect of metformin on hypothalamic-pituitary-thyroid axis activity in women with interferon-induced hypothyroidism: a pilot study. Exp Clin Endocrinol Diabetes. 2016 Feb;124(2):71–6. doi: 10.1055/s-0035-1565207. PMID: 26895275. Exclusion Code: X2.26895275
1413 Kuan YC, Huang KW, Lin CL, . Effects of metformin exposure on neurodegenerative diseases in elderly patients with type 2 diabetes mellitus. Prog Neuropsychopharmacol Biol Psychiatry. 2017 Oct 3;79(Pt B):77–83. doi: 10.1016/j.pnpbp.2017.06.002. PMID: 28583443. Exclusion Code: X8.28583443
1414 Kuan YC, Huang KW, Yen DJ, . Angiotensin-converting enzyme inhibitors and angiotensin II receptor blockers reduced dementia risk in patients with diabetes mellitus and hypertension. Int J Cardiol. 2016 Oct 1;220:462–6. doi: 10.1016/j.ijcard.2016.06.215. PMID: 27390970. Exclusion Code: X6.27390970
1415 Kullgren JT, Hafez D, Fedewa A, . A scoping review of behavioral economic interventions for prevention and treatment of type 2 diabetes mellitus. Curr Diab Rep. 2017 Sep;17(9):73. doi: 10.1007/s11892-017-0894-z. PMID: 28755061. Exclusion Code: X8.28755061
1416 Kullgren JT, Youles B, Shetty S, . ForgIng New paths in DIabetes PrevenTion (FINDIT): study protocol for a randomized controlled trial. Trials. 2017 Apr 8;18(1):167. doi: 10.1186/s13063-017-1887-6. PMID: 28388933. Exclusion Code: X6.28388933
1417 Kulzer B, Daenschel W, Daenschel I, . Integrated Personalized Diabetes Management (PDM): design of the ProValue Studies: prospective, cluster-randomized, controlled, intervention trials for evaluation of the effectiveness and benefit of PDM in patients with insulin-treated type 2 diabetes. J Diabetes Sci Technol. 2016;10(3):772–81. doi: 10.1177/1932296815617487. PMID: CN-01297821. Exclusion Code: X2.26645793
1418 Kumar BS, Ravisankar A, Mohan A, . Effect of oral hypoglycaemic agents on bone metabolism in patients with type 2 diabetes mellitus & occurrence of osteoporosis. Indian J Med Res. 2015 Apr;141(4):431–7. doi: 10.4103/0971-5916.159287. PMID: 26112844. Exclusion Code: X5.26112844
1419 Kumar S, Shewade H, Vasudevan K, . Effect of mobile reminders on screening yield during opportunistic screening for type 2 diabetes mellitus in a primary health care setting: a randomized trial. Preventive medicine reports. 2015;2:640–4. doi: 10.1016/j.pmedr.2015.08.008. PMID: CN-01090133. Exclusion Code: X6.26844130
1420 Kumarathurai P, Anholm C, Fabricius-Bjerre A, . Effects of the glucagon-like peptide-1 receptor agonist liraglutide on 24-h ambulatory blood pressure in patients with type 2 diabetes and stable coronary artery disease: a randomized, double-blind, placebo-controlled, crossover study. J Hypertens. 2017 May;35(5):1070–8. doi: 10.1097/hjh.0000000000001275. PMID: 28129251. Exclusion Code: X2.28129251
1421 Kumarathurai P, Anholm C, Larsen BS, . Effects of liraglutide on heart rate and heart rate variability: a randomized, double-blind, placebo-controlled crossover study. Diabetes Care. 2017 Jan;40(1):117–24. doi: 10.2337/dc16-1580. PMID: 27797930. Exclusion Code: X2.27797930
1422 Kumarathurai P, Anholm C, Nielsen OW, . Effects of the glucagon-like peptide-1 receptor agonist liraglutide on systolic function in patients with coronary artery disease and type 2 diabetes: a randomized double-blind placebo-controlled crossover study. Cardiovasc Diabetol. 2016 Jul 26;15(1):105. doi: 10.1186/s12933-016-0425-2. PMID: 27455835. Exclusion Code: X2.27455835
1423 Kumra S, Oberstar JV, Sikich L, . Efficacy and tolerability of second-generation antipsychotics in children and adolescents with schizophrenia (Structured abstract). Schizophr Bull; 2008. p. 60–71. Exclusion Code: X8.
1424 Kundu A, Sardar P, Ghosh S, . Risk of heart failure with dipeptidyl peptidase-4 inhibitors in patients with type 2 diabetes mellitus: A meta-analysis of randomized controlled trials. Int J Cardiol. 2016 Jun 1;212:203–5. doi: 10.1016/j.ijcard.2016.03.016. PMID: 27043061. Exclusion Code: X8.27043061
1425 Kuramitsu S, Miyauchi K, Yokoi H, . Effect of sitagliptin on plaque changes in coronary artery following acute coronary syndrome in diabetic patients: The ESPECIAL-ACS study. J Cardiol. 2017 Jan;69(1):369–76. doi: 10.1016/j.jjcc.2016.08.011. PMID: 27641967. Exclusion Code: X2.27641967
1426 Kurian GA, Manjusha V, Nair SS, . Short-term effect of G-400, polyherbal formulation in the management of hyperglycemia and hyperlipidemia conditions in patients with type 2 diabetes mellitus. Nutrition. 2014 Oct;30(10):1158–64. doi: 10.1016/j.nut.2014.02.026. PMID: 24976431. Exclusion Code: X4.24976431
1427 Kurozumi A, Okada Y, Mori H, . Detrimental effects of high-fat diet loading on vascular endothelial function and therapeutic efficacy of ezetimibe and statins in patients with type 2 diabetes. Endocr J. 2016 May 31;63(5):431–40. doi: 10.1507/endocrj.EJ15-0623. PMID: 26842592. Exclusion Code: X2.26842592
1428 Kurstjens S, de Baaij JH, Bouras H, . Determinants of hypomagnesemia in patients with type 2 diabetes mellitus. Eur J Endocrinol. 2017 Jan;176(1):11–9. doi: 10.1530/eje-16-0517. PMID: 27707767. Exclusion Code: X6.27707767
1429 Kutoh E, Hirate M, Wada A. Distinct glucose-lowering properties in good responders treated with sitagliptin and alogliptin. Int J Clin Pract. 2015 Nov;69(11):1296–302. doi: 10.1111/ijcp.12697. PMID: 26194442. Exclusion Code: X6.26194442
1430 Kutoh E, Wada A, Murayama T, . Ipragliflozin as an initial therapy in drug naive subjects with type 2 diabetes. Drug Res (Stuttg). 2016 Jul;66(7):345–50. doi: 10.1055/s-0035-1569454. PMID: 27056638. Exclusion Code: X5.27056638
1431 Kuznetsov L, Griffin SJ, Davies MJ, . Diabetes-specific quality of life but not health status is independently associated with glycaemic control among patients with type 2 diabetes: a cross-sectional analysis of the ADDITION-Europe trial cohort. Diabetes Res Clin Pract. 2014 May;104(2):281–7. doi: 10.1016/j.diabres.2013.12.029. PMID: 24636627. Exclusion Code: X8.24636627
1432 Kuznetsov L, Long GH, Griffin SJ, . Are changes in glycaemic control associated with diabetes-specific quality of life and health status in screen-detected type 2 diabetes patients? Four-year follow up of the ADDITION-Cambridge cohort. Diabetes Metab Res Rev. 2015 Jan;31(1):69–75. doi: 10.1002/dmrr.2559. PMID: 24817063. Exclusion Code: X6.24817063
1433 Kuznetsov L, Simmons RK, Sandbaek A, . The impact of intensive multifactorial treatment on perceptions of chronic care among individuals with screen-detected diabetes: results from the ADDITION-Denmark trial. Int J Clin Pract. 2015 Apr;69(4):466–73. doi: 10.1111/ijcp.12570. PMID: 25382351. Exclusion Code: X6.25382351
1434 Lago RM, Singh PP, Nesto RW. Congestive heart failure and cardiovascular death in patients with prediabetes and type 2 diabetes given thiazolidinediones: a meta-analysis of randomised clinical trials (Structured abstract). Lancet. 2007;370(2):1129–36. PMID: DARE-12007008349. Exclusion Code: X8.17905165
1435 Lai SW, Lin HF, Lin CL, . Long-term effects of pioglitazone on first attack of ischemic cerebrovascular disease in older people with type 2 diabetes: A case-control study in Taiwan. Medicine (Baltimore). 2016 Aug;95(31):e4455. doi: 10.1097/md.0000000000004455. PMID: 27495077. Exclusion Code: X2.27495077
1436 Lai S-W, Liao K-F, Lin C-L, . Dipeptidyl peptidase-4 inhibitors use and relative risk of ischemic cerebrovascular disease in type 2 diabetic patients in a case-control study. Frontiers in pharmacology. 2017;8(NOV) (no pagination)doi: 10.3389/fphar.2017.00859. PMID: CN-01432437. Exclusion Code: X8.
1437 Lai Y-C, Li H-Y, Wu T-J, . Correlation of circulating acid-labile subunit levels with insulin sensitivity and serum LDL cholesterol in patients with type 2 diabetes: findings from a prospective study with rosiglitazone. PPAR research. 2014doi: 10.1155/2014/917823. PMID: CN-00996241. Exclusion Code: X2.
1438 Lai YJ, Hu HY, Chen HH, . Dipeptidyl peptidase-4 inhibitors and the risk of acute pancreatitis in patients with type 2 diabetes in Taiwan: a population-based cohort study. Medicine (Baltimore). 2015 Oct;94(43):e1906. doi: 10.1097/md.0000000000001906. PMID: 26512613. Exclusion Code: X11.26512613
1439 Laires PA, Tang J, Fan CP, . Impact of hypoglycemic events and HbA1c level on sulfonylurea discontinuation and down-titration. Expert Rev Pharmacoecon Outcomes Res. 2017 Apr;17(2):213–20. doi: 10.1080/14737167.2016.1203259. PMID: 27345181. Exclusion Code: X5.27345181
1440 Lalla E, Cheng B, Kunzel C, . Six-month outcomes in dental patients identified with hyperglycaemia: a randomized clinical trial. J Clin Periodontol. 2015 Mar;42(3):228–35. doi: 10.1111/jcpe.12358. PMID: 25581313. Exclusion Code: X6.25581313
1441 Lamb MJ, Griffin SJ, Sharp SJ, . Fruit and vegetable intake and cardiovascular risk factors in people with newly diagnosed type 2 diabetes. Eur J Clin Nutr. 2017 Jan;71(1):115–21. doi: 10.1038/ejcn.2016.180. PMID: 27759070. Exclusion Code: X8.27759070
1442 Lamb MJ, Westgate K, Brage S, . Prospective associations between sedentary time, physical activity, fitness and cardiometabolic risk factors in people with type 2 diabetes. Diabetologia. 2016 Jan;59(1):110–20. doi: 10.1007/s00125-015-3756-8. PMID: 26518682. Exclusion Code: X8.26518682
1443 Landman GW, van Dijk PR, Drion I, . Midregional fragment of proadrenomedullin, new-onset albuminuria, and cardiovascular and all-cause mortality in patients with type 2 diabetes (ZODIAC-30). Diabetes Care. 2014;37(3):839–45. doi: 10.2337/dc13-1852. PMID: 24170764. Exclusion Code: X2.24170764
1444 Lane R, Ellis B, Watson L, . Exercise for intermittent claudication. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
1445 Langenberg C, Sharp SJ, Franks PW, . Gene-lifestyle interaction and type 2 diabetes: the EPIC interact case-cohort study. PLoS Med. 2014 May;11(5):e1001647. doi: 10.1371/journal.pmed.1001647. PMID: 24845081. Exclusion Code: X8.24845081
1446 Lanhers C, Walther G, Chapier R, . Long-term cost reduction of routine medications following a residential programme combining physical activity and nutrition in the treatment of type 2 diabetes: a prospective cohort study. BMJ Open. 2017 Apr 16;7(4):e013763. doi: 10.1136/bmjopen-2016-013763. PMID: 28416496. Exclusion Code: X7.28416496
1447 Lankin VZ, Konovalova GG, Tikhaze AK, . Aldehyde inhibition of antioxidant enzymes in the blood of diabetic patients. J Diabetes. 2016 May;8(3):398–404. doi: 10.1111/1753-0407.12309. PMID: 25990785. Exclusion Code: X6.25990785
1448 Lapane KL, Jesdale BM, Dube CE, . Sulfonylureas and risk of falls and fractures among nursing home residents with type 2 diabetes mellitus. Diabetes Res Clin Pract. 2015 Aug;109(2):411–9. doi: 10.1016/j.diabres.2015.05.009. PMID: 26008723. Exclusion Code: X2.26008723
1449 Lapolla A, Frison V, Bettio M, . Correlation between baseline characteristics and clinical outcomes in a large population of diabetes patients treated with liraglutide in a real-world setting in Italy. Clin Ther. 2015 Mar 1;37(3):574–84. doi: 10.1016/j.clinthera.2014.11.015. PMID: 25626486. Exclusion Code: X2.25626486
1450 Lari H, Tahmasebi R, Noroozi A. Effect of electronic education based on health promotion model on physical activity in diabetic patients. Diabetes Metab Syndr. 2018 Jan - Mar;12(1):45–50. doi: 10.1016/j.dsx.2017.08.013. PMID: 28869152. Exclusion Code: X2.28869152
1451 Larsen JR, Vedtofte L, Holst JJ, . Does a GLP-1 receptor agonist change glucose tolerance in patients treated with antipsychotic medications? Design of a randomised, double-blinded, placebo-controlled clinical trial. BMJ Open. 2014 Mar 25;4(3):e004227. doi: 10.1136/bmjopen-2013-004227. PMID: 24667381. Exclusion Code: X2.24667381
1452 Larsen JR, Vedtofte L, Jakobsen MSL, . Effect of liraglutide treatment on prediabetes and overweight or obesity in clozapine- or olanzapine-treated patients with schizophrenia spectrum disorder: a randomized clinical trial. JAMA Psychiatry. 2017 Jul 1;74(7):719–28. doi: 10.1001/jamapsychiatry.2017.1220. PMID: 28601891. Exclusion Code: X2.28601891
1453 Lau CJ, Pisinger C, Husemoen LLN, . Effect of general health screening and lifestyle counselling on incidence of diabetes in general population: Inter99 randomised trial. Prev Med. 2016 Oct;91:172–9. doi: 10.1016/j.ypmed.2016.08.016. PMID: 27514243. Exclusion Code: X6.27514243
1454 Lau D, Astrup A, Fujioka K, . Safety and tolerability of liraglutide 3.0 mg in overweight and obese adults: the scale obesity and prediabetes randomized, double-blind, placebo-controlled 56-week trial. Endocrine reviews. Conference: 96th annual meeting and expo of the endocrine society, ENDO 2014. Chicago, IL united states. Conference start: 20140621. Conference end: 20140624. Conference publication: (var.pagings). 2014;35(no pagination)PMID: CN-01267317. Exclusion Code: X10.
1455 Lau D, Blueher M, Gaal L, . Characteristics of individuals developing type 2 diabetes in the scale obesity and prediabetes randomized, double-blind, liraglutide vs. placebo trial. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A510. doi: 10.2337/db16-1771-2041. PMID: CN-01449849. Exclusion Code: X10.
1456 Lau D, Davies M, Pi-Sunyer F, . Hypoglycemia reported with liraglutide 3.0 mg in overweight and obese adults with and without prediabetes: results of the randomized, double-blind, placebo-controlled 56-week scale obesity and prediabetes trial. Endocrine reviews. Conference: 97th annual meeting and expo of the endocrine society, ENDO 2015. United states. Conference start: 20150305. Conference end: 20150308. 2015;36(no pagination)PMID: CN-01306642. Exclusion Code: X2.
1457 Lau D, Fujioka K, Astrup A, . Liraglutide 3.0 Mg reduces body weight and improves HRQoL in overweight or obese adults without diabetes: scale obesity and prediabetes randomized, double-blind, placebo controlled, 56-week trial. Obesity facts. 2015;8:185. doi: 10.1159/000382140. PMID: CN-01100829. Exclusion Code: X10.
1458 Lau D, Fujioka K, Greenway F, . Early weight loss responders to liraglutide 3.0 Mg had greater weight loss, regression to normoglycaemia, and reduced T2D development at 3 years Vs early non-responders: SCALE obesity and prediabetes. Obesity reviews. 2016;17(Suppl 2):68–9. doi: 10.1111/obr.12401. PMID: CN-01471024. Exclusion Code: X10.
1459 Lau D, Greenway F, Fujioka K, . Additional analyses of the weight-lowering efficacy of liraglutide 3.0 mg in adults with overweight and obesity: the SCALE obesity and prediabetes randomized trial. Canadian journal of diabetes. 2015;39:S48. PMID: CN-01129848. Exclusion Code: X10.
1460 Lau D, Krempf M, Astrup A, . Liraglutide 3.0 mg reduces body weight and improves cardiometabolic risk factors in adults with overweight/obesity: the SCALE obesity and prediabetes randomised trial. Canadian journal of diabetes. 2015;39:S48–s9. PMID: CN-01129847. Exclusion Code: X10.
1461 Lau D, Wilding J, Astrup A, . Liraglutide 3.0 mg improves insulin secretion and action in overweight/obese adults without type 2 diabetes: the SCALE obesity and prediabetes trial. Diabetologia. 2014;57(1):S358. PMID: CN-01369460. Exclusion Code: X10.
1462 Lauring B, Eldor R, Liu J, . Efficacy and safety of ertugliflozin in subjects with type 2 diabetes mellitus inadequately controlled on the dual combination of metformin and sitagliptin: the VERTIS SITA2 trial. Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S93. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212794. Exclusion Code: X2.
1463 Lauring B, Miller S, Krumins T, . Safety and efficacy of ertugliflozin in combination with sitagliptin in patients with type 2 diabetes inadequately controlled on diet and exercise: the VERTIS SITA trial. Diabetologia. Conference: 53rd annual meeting of the european association for the study of diabetes, EASD 2017. Portugal. 2017;60(1 Supplement 1):S407–s8. doi: 10.1007/s00125-017-4350-z. PMID: CN-01418994. Exclusion Code: X2.
1464 Lauritzen T, Griffin S, Borch-Johnsen K, . The ADDITION study: proposed trial of the cost-effectiveness of an intensive multifactorial intervention on morbidity and mortality among people with Type 2 diabetes detected by screening. Int J Obes Relat Metab Disord. 2000 Sep;24 Suppl 3:S6–11. PMID: 11063279. Exclusion Code: X6.11063279
1465 Lavalle-Gonzalez FJ, Eliaschewitz FG, Cerdas S, . Efficacy and safety of canagliflozin in patients with type 2 diabetes mellitus from Latin America. Curr Med Res Opin. 2016;32(3):427–39. doi: 10.1185/03007995.2015.1121865. PMID: 26579834. Exclusion Code: X2.26579834
1466 Lawler SP, Winkler EA, Goode AD, . Moderators of health behavior initiation and maintenance in a randomized telephone counseling trial. Prev Med. 2014 Apr;61:34–41. doi: 10.1016/j.ypmed.2014.01.002. PMID: 24412896. Exclusion Code: X6.24412896
1467 Lawrenson JG, Graham-Rowe E, Lorencatto F, . Interventions to increase attendance for diabetic retinopathy screening. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2018. Exclusion Code: X8.
1468 Laxy M, Wilson ECF, Boothby CE, . How good are GPs at adhering to a pragmatic trial protocol in primary care? Results from the ADDITION-Cambridge cluster-randomised pragmatic trial. BMJ Open. 2018 Jun 14;8(6):e015295. doi: 10.1136/bmjopen-2016-015295. PMID: 29903781. Exclusion Code: X6.29903781
1469 Lazarus B, Wu A, Shin JI, . Association of Metformin Use With Risk of Lactic Acidosis Across the Range of Kidney Function: A Community-Based Cohort Study. JAMA Intern Med. 2018 Jul 1;178(7):903–10. doi: 10.1001/jamainternmed.2018.0292. PMID: 29868840. Exclusion Code: X8.29868840
1470 Leach MJ, Kumar S. Cinnamon for diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2012. Exclusion Code: X8.
1471 Leblanc E, Pratley RE, Dawson-Hughes B, . Baseline characteristics of the vitamin d and type 2 diabetes (D2D) study-a contemporary prediabetes cohort. Diabetes. 2018;67:A200-. PMID: CN-01631217. Exclusion Code: X4.
1472 LeBlanc ES, Patnode CD, Webber EM, . Behavioral and Pharmacotherapy Weight Loss Interventions to Prevent Obesity-Related Morbidity and Mortality in Adults: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. Jama. 2018 Sep 18;320(11):1172–91. doi: 10.1001/jama.2018.7777. PMID: 30326501. Exclusion Code: X8.30326501
1473 LeBlanc ES, Pratley RE, Dawson-Hughes B, . Baseline Characteristics of the Vitamin D and Type 2 Diabetes (D2d) Study: a Contemporary Prediabetes Cohort That Will Inform Diabetes Prevention Efforts. Diabetes care. 2018;41(8):1590–9. doi: 10.2337/dc18-0240. PMID: CN-01626961. Exclusion Code: X4.29941495
1474 Leckie RL. Examining glucose control and working memory as a function of age in older type 2 diabetics: results from the Look AHEAD Brain MRI ancillary study. Dissertation abstracts international: section B: the sciences and engineering. 2017;78:No Pagination Specified. PMID: CN-01415381. Exclusion Code: X2.
1475 Lee AL, Chen BC, Mou CH, . Association of Traditional Chinese Medicine Therapy and the Risk of Vascular Complications in Patients With Type II Diabetes Mellitus: a nationwide, retrospective, Taiwanese-Registry, cohort study. Medicine (Baltimore). 2016 Jan;95(3):e2536. doi: 10.1097/md.0000000000002536. PMID: 26817897. Exclusion Code: X4.26817897
1476 Lee CM, Woodward M, Colagiuri S. Triple therapy combinations for the treatment of type 2 diabetes - a network meta-analysis. Diabetes Res Clin Pract. 2016 Jun;116:149–58. doi: 10.1016/j.diabres.2016.04.037. PMID: 27321330. Exclusion Code: X8.27321330
1477 Lee CMY, Versace VL, Malo JA, . Screening for diabetes prevention with diabetes risk scores - a balancing act. Diabetes Res Clin Pract. 2018 Jan;135:120–7. doi: 10.1016/j.diabres.2017.11.009. PMID: 29155122. Exclusion Code: X6.29155122
1478 Lee D, Chun E, Hur J, . Effect of sarpogrelate, a selective 5-HT. Atherosclerosis. 2017;257:47–54. doi: 10.1016/j.atherosclerosis.2016.12.011. PMID: CN-01424565. Exclusion Code: X6.28068560
1479 Lee DH, Chun EJ, Hur JH, . Effect of sarpogrelate, a selective 5-HT2A receptor antagonist, on characteristics of coronary artery disease in patients with type 2 diabetes. Atherosclerosis. 2017 Feb;257:47–54. doi: 10.1016/j.atherosclerosis.2016.12.011. PMID: 28068560. Exclusion Code: X6.28068560
1480 Lee EY, Hwang S, Lee YH, . Association between metformin use and risk of lactic acidosis or elevated lactate concentration in type 2 diabetes. Yonsei Med J. 2017 Mar;58(2):312–8. doi: 10.3349/ymj.2017.58.2.312. PMID: 28120561. Exclusion Code: X8.28120561
1481 Lee G, Oh SW, Hwang SS, . Comparative effectiveness of oral antidiabetic drugs in preventing cardiovascular mortality and morbidity: A network meta-analysis. PLoS One. 2017;12(5):e0177646. doi: 10.1371/journal.pone.0177646. PMID: 28542373. Exclusion Code: X8.28542373
1482 Lee JY, Lee SW, Nasir NH, . Diabetes telemonitoring reduces the risk of hypoglycaemia during Ramadan: a pilot randomized controlled study. Diabet Med. 2015 Dec;32(12):1658–61. doi: 10.1111/dme.12836. PMID: 26103794. Exclusion Code: X4.26103794
1483 Lee KT, Yeh YH, Chang SH, . Metformin is associated with fewer major adverse cardiac events among patients with a new diagnosis of type 2 diabetes mellitus: A propensity score-matched nationwide study. Medicine (Baltimore). 2017 Jul;96(28):e7507. doi: 10.1097/md.0000000000007507. PMID: 28700501. Exclusion Code: X8.28700501
1484 Lee MC, Chiang CY, Lee CH, . Metformin use is associated with a low risk of tuberculosis among newly diagnosed diabetes mellitus patients with normal renal function: A nationwide cohort study with validated diagnostic criteria. PLoS One. 2018;13(10):e0205807. doi: 10.1371/journal.pone.0205807. PMID: 30335800. Exclusion Code: X6.30335800
1485 Lee S, Pei D, Chi M, . An investigation and comparison of the effectiveness of different exercise programmes in improving glucose metabolism and pancreatic ? cell function of type 2 diabetes patients. Int J Clin Pract. 2015;69(10):1159–70. doi: 10.1111/ijcp.12679. PMID: CN-01257200. Exclusion Code: X2.26119968
1486 Lee S-H, Gantz I, Round E, . A randomized, placebo-controlled clinical trial evaluating the safety and efficacy of the once-weekly DPP-4 inhibitor omarigliptin in patients with type 2 diabetes mellitus inadequately controlled by glimepiride and metformin. BMC Endocr Disord. 2017;17(1) (no pagination)doi: 10.1186/s12902-017-0219-x. PMID: CN-01429972. Exclusion Code: X2.
1487 Lee SW, Lee JY, Tan CS, . Strategies to make Ramadan fasting safer in type 2 diabetics: a systematic review and network meta-analysis of randomized controlled trials and observational studies. Medicine (Baltimore). 2016 Jan;95(2):e2457. doi: 10.1097/md.0000000000002457. PMID: 26765440. Exclusion Code: X8.26765440
1488 Lee WC, Dekoven M, Bouchard J, . Improved real-world glycaemic outcomes with liraglutide versus other incretin-based therapies in type 2 diabetes. Diabetes Obes Metab. 2014 Sep;16(9):819–26. doi: 10.1111/dom.12285. PMID: 24581276. Exclusion Code: X5.24581276
1489 Lee WY, Clark BK, Winkler E, . Responsiveness to change of self-report and device-based physical activity measures in the living well with diabetes trial. J Phys Act Health. 2015 Aug;12(8):1082–7. doi: 10.1123/jpah.2013-0265. PMID: 25243708. Exclusion Code: X6.25243708
1490 Lee Y, Kim S, Lee I, . Effect of a brown rice based vegan diet and conventional diabetic diet on glycemic control of patients with type 2 diabetes: a 12-week randomized clinical trial. Plos one. 2016;11(6):e0155918. doi: 10.1371/journal.pone.0155918. PMID: CN-01382751. Exclusion Code: X2.27253526
1491 Lee YH, Kim JH, Kim SR, . Lobeglitazone, a novel thiazolidinedione, improves non-alcoholic fatty liver disease in type 2 diabetes: its efficacy and predictive factors related to responsiveness. J Korean Med Sci. 2017 Jan;32(1):60–9. doi: 10.3346/jkms.2017.32.1.60. PMID: 27914133. Exclusion Code: X2.27914133
1492 Leehey DJ, Collins E, Kramer HJ, . Structured exercise in obese diabetic patients with chronic kidney disease: a randomized controlled trial. Am J Nephrol. 2016;44(1):54–62. doi: 10.1159/000447703. PMID: 27385652. Exclusion Code: X2.27385652
1493 Lehrke M, Leiter LA, Hehnke U, . Safety and efficacy of linagliptin in patients with type 2 diabetes mellitus and coronary artery disease: analysis of pooled events from 19 clinical trials. J Diabetes Complications. 2016 Sep-Oct;30(7):1378–84. doi: 10.1016/j.jdiacomp.2016.06.015. PMID: 27396241. Exclusion Code: X8.27396241
1494 Lehrke M, Marx N, Patel S, . Safety and tolerability of linagliptin in patients with type 2 diabetes: a comprehensive pooled analysis of 22 placebo-controlled studies. Clin Ther. 2014 Aug 1;36(8):1130–46. doi: 10.1016/j.clinthera.2014.06.008. PMID: 25015594. Exclusion Code: X8.25015594
1495 Lehtisalo J, Lindstrom J, Ngandu T, . Association of long-term dietary fat intake, exercise, and weight with later cognitive function in the Finnish Diabetes Prevention Study. J Nutr Health Aging. 2016 Feb;20(2):146–54. doi: 10.1007/s12603-015-0565-1. PMID: 26812510. Exclusion Code: X6.26812510
1496 Lehtisalo J, Lindstrom J, Ngandu T, . Diabetes, glycaemia, and cognition-a secondary analysis of the Finnish Diabetes Prevention Study. Diabetes Metab Res Rev. 2016 Jan;32(1):102–10. doi: 10.1002/dmrr.2679. PMID: 26172529. Exclusion Code: X6.26172529
1497 Leibold C, Shubrook JH, Nakazawa M, . Effectiveness of the complete health improvement program in reducing risk factors for cardiovascular disease in an Appalachian population. J Am Osteopath Assoc. 2016 Feb;116(2):84–91. doi: 10.7556/jaoa.2016.020. PMID: 26830523. Exclusion Code: X8.26830523
1498 Leibowitz G, Cahn A, Bhatt DL, . Impact of treatment with saxagliptin on glycaemic stability and beta-cell function in the SAVOR-TIMI 53 study. Diabetes Obes Metab. 2015 May;17(5):487–94. doi: 10.1111/dom.12445. PMID: 25656169. Exclusion Code: X2.25656169
1499 Leiter L, Gross J, Chow F, . Once weekly glucagon-like peptide-1 receptor agonist albiglutide vs. prandial insulin added to basal insulin in patients with type 2 diabetes mellitus: results over 52 weeks. J Diabetes Complications. 2017;31(8):1283–5. doi: 10.1016/j.jdiacomp.2017.05.010. PMID: CN-01396176. Exclusion Code: X5.28587789
1500 Leiter L, Langslet G, Vijapurkar U, . Simultaneous reduction in both HbA1c and body weight with canagliflozin versus glimepiride in patients with type 2 diabetes on metformin. Diabetes therapy. 2016;7(2):269–78. doi: 10.1007/s13300-016-0163-1. PMID: CN-01165540. Exclusion Code: X2.26984361
1501 Leiter LA, Carr MC, Stewart M, . Efficacy and safety of the once-weekly GLP-1 receptor agonist albiglutide versus sitagliptin in patients with type 2 diabetes and renal impairment: a randomized phase III study. Diabetes Care. 2014 Oct;37(10):2723–30. doi: 10.2337/dc13-2855. PMID: 25048383. Exclusion Code: X2.25048383
1502 Leiter LA, Teoh H, Braunwald E, . Efficacy and safety of saxagliptin in older participants in the SAVOR-TIMI 53 trial. Diabetes Care. 2015 Jun;38(6):1145–53. doi: 10.2337/dc14-2868. PMID: 25758769. Exclusion Code: X2.25758769
1503 Leiter LA, Yoon KH, Arias P, . Canagliflozin provides durable glycemic improvements and body weight reduction over 104 weeks versus glimepiride in patients with type 2 diabetes on metformin: a randomized, double-blind, phase 3 study. Diabetes Care. 2015 Mar;38(3):355–64. doi: 10.2337/dc13-2762. PMID: 25205142. Exclusion Code: X5.25205142
1504 Lentferink YE, Knibbe CAJ, van der Vorst MMJ. Efficacy of Metformin Treatment with Respect to Weight Reduction in Children and Adults with Obesity: A Systematic Review. Drugs. 2018 Dec;78(18):1887–901. doi: 10.1007/s40265-018-1025-0. PMID: 30511324. Exclusion Code: X8.30511324
1505 Leslie WS, Ford I, Sattar N, . The Diabetes Remission Clinical Trial (DiRECT): protocol for a cluster randomised trial. BMC Fam Pract. 2016 Feb 16;17:20. doi: 10.1186/s12875-016-0406-2. PMID: 26879684. Exclusion Code: X6.26879684
1506 Leung M, Leung DY, Wong VW. Effects of dipeptidyl peptidase-4 inhibitors on cardiac and endothelial function in type 2 diabetes mellitus: A pilot study. Diab Vasc Dis Res. 2016 May;13(3):236–43. doi: 10.1177/1479164116629352. PMID: 26993495. Exclusion Code: X6.26993495
1507 Leung M, Wong VW, Hudson M, . Impact of improved glycemic control on cardiac function in type 2 diabetes mellitus. Circ Cardiovasc Imaging. 2016 Mar;9(3):e003643. doi: 10.1161/circimaging.115.003643. PMID: 26962125. Exclusion Code: X6.26962125
1508 Levesque V, Poirier P, Despres JP, . Assessing and targeting key lifestyle cardiovascular risk factors at the workplace: Effect on hemoglobin A1c levels. Ann Med. 2015;47(7):605–14. doi: 10.3109/07853890.2015.1091943. PMID: 26542534. Exclusion Code: X4.26542534
1509 Levin PA, Wei W, Zhou S, . Outcomes and treatment patterns of adding a third agent to 2 OADs in patients with type 2 diabetes. J Manag Care Spec Pharm. 2014 May;20(5):501–12. doi: 10.18553/jmcp.2014.20.5.501. PMID: 24761822. Exclusion Code: X2.24761822
1510 Levy JC, Davies MJ, Holman RR. Continuous glucose monitoring detected hypoglycaemia in the Treating to Target in Type 2 Diabetes Trial (4-T). Diabetes Res Clin Pract. 2017 Sep;131:161–8. doi: 10.1016/j.diabres.2017.01.022. PMID: 28750219. Exclusion Code: X2.28750219
1511 Lewis JD, Habel LA, Quesenberry CP, . Pioglitazone use and risk of bladder cancer and other common cancers in persons with diabetes. Jama. 2015 Jul 21;314(3):265–77. doi: 10.1001/jama.2015.7996. PMID: 26197187. Exclusion Code: X5.26197187
1512 Lewis K. Weight loss achieved with medication can delay onset of type 2 diabetes in at-risk individuals. Journal of clinical outcomes management. 2014;21(9):393–5. PMID: CN-01048574. Exclusion Code: X8.
1513 Ley SH, Ardisson Korat AV, Sun Q, . Contribution of the nurses’ health studies to uncovering risk factors for type 2 diabetes: diet, lifestyle, biomarkers, and genetics. Am J Public Health. 2016 Sep;106(9):1624–30. doi: 10.2105/ajph.2016.303314. PMID: 27459454. Exclusion Code: X8.27459454
1514 Li B, Liu LB, Liu XY, . Effect of moderate-intensity exercise on the insulin sensitivity and plasma level of adiponectin in obese patients with type 2 diabetes mellitus. Chinese journal of clinical rehabilitation. 2005;9(39):22–4. PMID: CN-01739197. Exclusion Code: X1.
1515 Li CJ, Yu Q, Yu P, . Efficacy and safety comparison of add-on therapy with liraglutide, saxagliptin and vildagliptin, all in combination with current conventional oral hypoglycemic agents therapy in poorly controlled Chinese type 2 diabetes. Exp Clin Endocrinol Diabetes. 2014 Sep;122(8):469–76. doi: 10.1055/s-0034-1374586. PMID: 24838155. Exclusion Code: X5.24838155
1516 Li CY, Erickson SR, Wu CH. Metformin use and asthma outcomes among patients with concurrent asthma and diabetes. Respirology. 2016 Oct;21(7):1210–8. doi: 10.1111/resp.12818. PMID: 27245632. Exclusion Code: X8.27245632
1517 Li F, Chen J, Leng F, . Effect of saxagliptin on circulating endothelial progenitor cells and endothelial function in newly diagnosed type 2 diabetic patients. Exp Clin Endocrinol Diabetes. 2017 Jun;125(6):400–7. doi: 10.1055/s-0042-124421. PMID: 28407661. Exclusion Code: X5.28407661
1518 Li FF, Jiang LL, Yan RN, . Effects of saxagliptin add-on therapy to insulin on blood glycemic fluctuations in patients with type 2 diabetes: A randomized, control, open-labeled trial. Medicine (Baltimore). 2016 Oct;95(43):e5229. doi: 10.1097/md.0000000000005229. PMID: 27787387. Exclusion Code: X5.27787387
1519 Li J, Ng EH, Stener-Victorin E, . Acupuncture treatment for insulin sensitivity of women with polycystic ovary syndrome and insulin resistance: a study protocol for a randomized controlled trial. Trials. 2017 Mar 9;18(1):115. doi: 10.1186/s13063-017-1854-2. PMID: 28274268. Exclusion Code: X5.28274268
1520 Li L, Jick S, Gopalakrishnan C, . Metformin use and risk of lactic acidosis in people with diabetes with and without renal impairment: a cohort study in Denmark and the UK. Diabet Med. 2017 Apr;34(4):485–9. doi: 10.1111/dme.13203. PMID: 27504911. Exclusion Code: X2.27504911
1521 Li L, Zhang M, Su F, . Combination therapy analysis of ezetimibe and statins in Chinese patients with acute coronary syndrome and type 2 diabetes. Lipids Health Dis. 2015 Feb 18;14:10. doi: 10.1186/s12944-015-0004-7. PMID: 25879728. Exclusion Code: X2.25879728
1522 Li M, Li D, Tang Y, . Effect of Diabetes Sleep Education for T2DM Who Sleep After Midnight: A Pilot Study from China. Metab Syndr Relat Disord. 2018 Feb;16(1):13–9. doi: 10.1089/met.2017.0069. PMID: 29356602. Exclusion Code: X4.29356602
1523 Li M, Li T, Shi B-Y, . Impact of motivational interviewing on the quality of life and its related factors in type 2 diabetes mellitus patients with poor long-term glycemic control. International journal of nursing sciences. 2014;1(3):250–4. doi: 10.1016/j.ijnss.2014.05.022. PMID: CN-01079459. Exclusion Code: X7.
1524 Li W, Xie B, Qiu S, . Non-lab and semi-lab algorithms for screening undiagnosed diabetes: a cross-sectional study. Ebiomedicine. 2018;(no pagination)doi: 10.1016/j.ebiom.2018.08.009. PMID: CN-01629119. Exclusion Code: X4.
1525 Li X, Cai X, Ma X, . Short- and long-term effects of wholegrain oat intake on weight management and glucolipid metabolism in overweight type-2 diabetics: a randomized control trial. Nutrients. 2016 Sep 7;8(9)doi: 10.3390/nu8090549. PMID: 27618090. Exclusion Code: X2.27618090
1526 Li X, Liu H, Feng H, . Acupuncture paired with herbal medicine for prediabetes: study protocol for a randomized controlled trial. Trials. 2017 Jun 28;18(1):297. doi: 10.1186/s13063-017-2014-4. PMID: 28659162. Exclusion Code: X6.28659162
1527 Li X, Wang J, Gong Q, . Higher blood pressure and predicted rate of diabetes in people with impaired glucose tolerance enhance the subsequent long-term risk of stroke: 23 year follow-up of the Daqing Diabetes Prevention Study. Diabetes/metabolism research and reviews. Conference: 21st scientific meeting of the chinese diabetes society. China. 2017;33(Supplement 1) (no pagination)doi: 10.1002/dmrr.2948. PMID: CN-01431758. Exclusion Code: X5.
1528 Li Y, Xu M, Fan R, . The effects of intensive nutrition education on late middle-aged adults with type 2 diabetes. Int J Environ Res Public Health. 2016 Sep 8;13(9)doi: 10.3390/ijerph13090897. PMID: 27618080. Exclusion Code: X2.27618080
1529 Li Z, Zhang Y, Quan X, . Efficacy and acceptability of glycemic control of glucagon-like peptide-1 receptor agonists among type 2 diabetes: a systematic review and network meta-analysis. PLoS One. 2016;11(5):e0154206. doi: 10.1371/journal.pone.0154206. PMID: 27158818. Exclusion Code: X8.27158818
1530 Liang CY, Yeh YC, Lee CJ, . Flunarizine and the risk of parkinsonism in a newly diagnosed type 2 diabetic population in Taiwan: A nested case-control study. J Clin Neurosci. 2018 Apr;50:281–6. doi: 10.1016/j.jocn.2018.01.017. PMID: 29396059. Exclusion Code: X2.29396059
1531 Liao H, Zhong S, Li P, . Effects and mechanism of moderate aerobic exercise on impaired fasting glucose improvement. Lipids Health Dis. 2015;14:157. doi: 10.1186/s12944-015-0117-z. PMID: CN-01168790. Exclusion Code: X6.26630989
1532 Liao KF, Lin CL, Lai SW, . Sitagliptin use and risk of acute pancreatitis in type 2 diabetes mellitus: a population-based case-control study in Taiwan. Eur J Intern Med. 2016 Jan;27:76–9. doi: 10.1016/j.ejim.2015.09.015. PMID: 26433909. Exclusion Code: X2.26433909
1533 Lilly M, Godwin M. Treating prediabetes with metformin: systematic review and meta-analysis (Structured abstract). Canadian Family Physician; 2009. p. 363–9. Exclusion Code: X8.
1534 Lim LL, Lau ESH, Kong APS, . Aspects of Multicomponent Integrated Care Promote Sustained Improvement in Surrogate Clinical Outcomes: A Systematic Review and Meta-analysis. Diabetes Care. 2018 Jun;41(6):1312–20. doi: 10.2337/dc17-2010. PMID: 29784698. Exclusion Code: X8.29784698
1535 Lim MS, Park B, Kong IG, . Leisure sedentary time is differentially associated with hypertension, diabetes mellitus, and hyperlipidemia depending on occupation. BMC Public Health. 2017 Mar 23;17(1):278. doi: 10.1186/s12889-017-4192-0. PMID: 28335768. Exclusion Code: X8.28335768
1536 Lim S, Han KA, Yu J, . Efficacy and safety of initial combination therapy with gemigliptin and metformin compared with monotherapy with either drug in patients with type 2 diabetes: A double-blind randomized controlled trial (INICOM study). Diabetes Obes Metab. 2017 Jan;19(1):87–97. doi: 10.1111/dom.12787. PMID: 27619558. Exclusion Code: X2.27619558
1537 Lim S, Kang S, Kim K, . Multifactorial intervention in diabetes care using real-time monitoring and tailored feedback in type 2 diabetes. Acta Diabetol. 2016;53(2):189–98. doi: 10.1007/s00592-015-0754-8. PMID: CN-01258599. Exclusion Code: X2.25936739
1538 Lim SS, Hutchison SK, Van Ryswyk E, . Lifestyle changes in women with polycystic ovary syndrome. Cochrane Database of Systematic Reviews. 2019(3)doi: 10.1002/14651858.CD007506.pub4. PMID: CD007506. Exclusion Code: X8.
1539 Limaye T, Kumaran K, Joglekar C, . Efficacy of a virtual assistance-based lifestyle intervention in reducing risk factors for Type 2 diabetes in young employees in the information technology industry in India: LIMIT, a randomized controlled trial. Diabet Med. 2017 Apr;34(4):563–8. doi: 10.1111/dme.13258. PMID: 27589695. Exclusion Code: X7.27589695
1540 Lin HC, Kachingwe BH, Lin HL, . Effects of metformin dose on cancer risk reduction in patients with type 2 diabetes mellitus: a 6-year follow-up study. Pharmacotherapy. 2014 Jan;34(1):36–45. doi: 10.1002/phar.1334. PMID: 23864581. Exclusion Code: X8.23864581
1541 Lin HF, Liao KF, Chang CM, . Use of thiazolidinediones and risk of hip fracture in old people in a case-control study in Taiwan. Medicine (Baltimore). 2017 Sep;96(36):e7712. doi: 10.1097/md.0000000000007712. PMID: 28885328. Exclusion Code: X2.28885328
1542 Lin J, Gill A, Zahm SH, . Metformin use and survival after non-small cell lung cancer: A cohort study in the US Military health system. Int J Cancer. 2017 Jul 15;141(2):254–63. doi: 10.1002/ijc.30724. PMID: 28380674. Exclusion Code: X2.28380674
1543 Lin JC, Lai MS. Antihypertensive drugs and diabetic retinopathy in patients with type 2 diabetes. Ophthalmologica. 2016;235(2):87–96. doi: 10.1159/000441958. PMID: 26695432. Exclusion Code: X8.26695432
1544 Lin JH, Zhang JJ, Lin SL, . Design of a phase 2 clinical trial of an ASK1 inhibitor, GS-4997, in patients with diabetic kidney disease. Nephron. 2015;129(1):29–33. doi: 10.1159/000369152. PMID: 25531162. Exclusion Code: X6.25531162
1545 Lin KD, Lee MY, Feng CC, . Residual effect of reductions in red blood cell count and haematocrit and haemoglobin levels after 10-month withdrawal of pioglitazone in patients with Type 2 diabetes. Diabet Med. 2014 Nov;31(11):1341–9. doi: 10.1111/dme.12481. PMID: 24797920. Exclusion Code: X2.24797920
1546 Lin S, Chen M, Chen W, . A Randomized Trial of Insulin Glargine plus Oral Hypoglycemic Agents versus Continuous Subcutaneous Insulin Infusion to Treat Newly Diagnosed Type 2 Diabetes. J Diabetes Res. 2018;2018:2791584. doi: 10.1155/2018/2791584. PMID: 30420969. Exclusion Code: X5.30420969
1547 Lin SD, Su SL, Wang SY, . Using continuous glucose monitoring to assess contributions of premeal and postmeal glucose levels in diabetic patients treated with metformin alone. Diabetes Metab. 2016 Nov;42(5):336–41. doi: 10.1016/j.diabet.2016.03.002. PMID: 27068362. Exclusion Code: X6.27068362
1548 Lincoff AM, Wolski K, Nicholls SJ, . Pioglitazone and risk of cardiovascular events in patients with type 2 diabetes mellitus: a meta-analysis of randomized trials. J Am Med Assoc. 2007;298(10):1180–8. doi: 10.1001/jama.298.10.1180. PMID: CN-01753548. Exclusion Code: X8.
1549 Lind M, Hirsch I, Tuomilehto J, . Design and methods of a randomised double-blind trial of adding liraglutide to control HbA1c in patients with type 2 diabetes with impaired glycaemic control treated with multiple daily insulin injections (MDI-Liraglutide trial). Prim Care Diabetes. 2015;9(1):15–22. doi: 10.1016/j.pcd.2014.07.010. PMID: CN-01039966. Exclusion Code: X2.25175385
1550 Lindhardt M, Persson F, Oxlund C, . Predicting albuminuria response to spironolactone treatment with urinary proteomics in patients with type 2 diabetes and hypertension. Nephrol Dial Transplant. 2018 Feb 1;33(2):296–303. doi: 10.1093/ndt/gfw406. PMID: 28064163. Exclusion Code: X6.28064163
1551 Lingvay I, Desouza CV, Lalic KS, . A 26-Week Randomized Controlled Trial of Semaglutide Once Daily Versus Liraglutide and Placebo in Patients With Type 2 Diabetes Suboptimally Controlled on Diet and Exercise With or Without Metformin. Diabetes Care. 2018 Sep;41(9):1926–37. doi: 10.2337/dc17-2381. PMID: 30026333. Exclusion Code: X2.30026333
1552 Linz PE, Lovato LC, Byington RP, . Paradoxical reduction in HDL-C with fenofibrate and thiazolidinedione therapy in type 2 diabetes: the ACCORD Lipid Trial. Diabetes Care. 2014;37(3):686–93. doi: 10.2337/dc13-0790. PMID: 24296848. Exclusion Code: X2.24296848
1553 Lipkin EW, Schwartz AV, Anderson AM, . The Look AHEAD Trial: bone loss at 4-year follow-up in type 2 diabetes. Diabetes Care. 2014 Oct;37(10):2822–9. doi: 10.2337/dc14-0762. PMID: 25048381. Exclusion Code: X6.25048381
1554 Lipska KJ, Ross JS, Miao Y, . Potential overtreatment of diabetes mellitus in older adults with tight glycemic control. JAMA Intern Med. 2015 Mar;175(3):356–62. doi: 10.1001/jamainternmed.2014.7345. PMID: 25581565. Exclusion Code: X8.25581565
1555 Liss DT, Finch EA, Cooper A, . One-year effects of a group-based lifestyle intervention in adults with type 2 diabetes: A randomized encouragement trial. Diabetes Res Clin Pract. 2018 Jun;140:36–44. doi: 10.1016/j.diabres.2018.03.030. PMID: 29596950. Exclusion Code: X2.29596950
1556 Liss DT, Finch EA, Gregory DL, . Design and participant characteristics for a randomized effectiveness trial of an intensive lifestyle intervention to reduce cardiovascular risk in adults with type 2 diabetes: The I-D-HEALTH study. Contemp Clin Trials. 2016 Jan;46:114–21. doi: 10.1016/j.cct.2015.11.016. PMID: 26611433. Exclusion Code: X6.26611433
1557 Liu G, Li Y, Hu Y, . Influence of Lifestyle on Incident Cardiovascular Disease and Mortality in Patients With Diabetes Mellitus. J Am Coll Cardiol. 2018 Jun 26;71(25):2867–76. doi: 10.1016/j.jacc.2018.04.027. PMID: 29929608. Exclusion Code: X4.29929608
1558 Liu J, Hu Y, Zhang H, . Exenatide treatment increases serum irisin levels in patients with obesity and newly diagnosed type 2 diabetes. J Diabetes Complications. 2016 Nov - Dec;30(8):1555–9. doi: 10.1016/j.jdiacomp.2016.07.020. PMID: 27503404. Exclusion Code: X6.27503404
1559 Liu J, Zhang P, Tian J, . Ozone therapy for treating foot ulcers in people with diabetes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
1560 Liu K, Wang B, Zhou R, . Effect of combined use of a low-carbohydrate, high-protein diet with omega-3 polyunsaturated fatty acid supplementation on glycemic control in newly diagnosed type 2 diabetes: a randomized, double-blind, parallel-controlled trial. American journal of clinical nutrition. 2018;108(2):256–65. doi: 10.1093/ajcn/nqy120. PMID: CN-01955140. Exclusion Code: X4.
1561 Liu T. The effects of a health partner program on reducing cardiovascular risk factors. West J Nurs Res. 2018 Apr;40(4):537–61. doi: 10.1177/0193945916683184. PMID: 28322645. Exclusion Code: X5.28322645
1562 Liu T. The Effects of a Health Partner Program on Improving Health Status Among Overweight/Obese Individuals With and Without Prediabetes. West J Nurs Res. 2018 Nov;40(11):1638–57. doi: 10.1177/0193945917714031. PMID: 28655285. Exclusion Code: X4.28655285
1563 Liu WY, Lu DJ, Du XM, . Effect of aerobic exercise and low carbohydrate diet on pre-diabetic non-alcoholic fatty liver disease in postmenopausal women and middle aged men--the role of gut microbiota composition: study protocol for the AELC randomized controlled trial. BMC Public Health. 2014 Jan 17;14:48. doi: 10.1186/1471-2458-14-48. PMID: 24438438. Exclusion Code: X6.24438438
1564 Liu X, Li Y, Li L, . Prevalence, awareness, treatment, control of type 2 diabetes mellitus and risk factors in Chinese rural population: the RuralDiab study. Sci Rep. 2016 Aug 11;6:31426. doi: 10.1038/srep31426. PMID: 27510966. Exclusion Code: X8.27510966
1565 Liu X, Mei T, Chen W, . Comparison of antidiabetic medications during the treatment of atherosclerosis in T2DM patients. Mediators Inflamm. 2017;2017:5032708. doi: 10.1155/2017/5032708. PMID: 28539704. Exclusion Code: X5.28539704
1566 Liu X, Men P, Wang Y, . Impact of dipeptidyl peptidase-4 inhibitors on serum adiponectin: a meta-analysis. Lipids Health Dis. 2016 Nov 23;15(1):204. doi: 10.1186/s12944-016-0372-7. PMID: 27881129. Exclusion Code: X8.27881129
1567 Liu X, Shi J, Wang A, . Changes in ideal cardiovascular health status and risk of new-onset type 2 diabetes: The Kailuan prospective study. Medicine (Baltimore). 2016 Aug;95(34):e4571. doi: 10.1097/md.0000000000004571. PMID: 27559955. Exclusion Code: X4.27559955
1568 Liu Y, Liu SX, Zheng F, . Cardiovascular autonomic neuropathy in patients with type 2 diabetes. J Diabetes Investig. 2016 Jul;7(4):615–21. doi: 10.1111/jdi.12438. PMID: 27181277. Exclusion Code: X6.27181277
1569 Liu Y, Tian Q, Yang J, . No pancreatic safety concern following glucagon-like peptide-1 receptor agonist therapies: A pooled analysis of cardiovascular outcome trials. Diabetes Metab Res Rev. 2018 Nov;34(8):e3061. doi: 10.1002/dmrr.3061. PMID: 30109766. Exclusion Code: X8.30109766
1570 Liutkus J, Fujioka K, Astrup A, . Liraglutide 3.0 mg reduces body weight and improves health-related quality of life (HRQoL) in overweight or obese adults without diabetes: the SCALE obesity and prediabetes randomized, double-blind, placebo-controlled, 56-week trial. Canadian journal of diabetes. 2015;39:S36. PMID: CN-01129851. Exclusion Code: X2.
1571 Livingstone SJ, Looker HC, Akbar T, . Effect of atorvastatin on glycaemia progression in patients with diabetes: an analysis from the Collaborative Atorvastatin in Diabetes Trial (CARDS). Diabetologia. 2016 Feb;59(2):299–306. doi: 10.1007/s00125-015-3802-6. PMID: 26577796. Exclusion Code: X6.26577796
1572 Lo C, Jun M, Badve SV, . Glucose-lowering agents for treating pre-existing and new-onset diabetes in kidney transplant recipients. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
1573 Lo C, Toyama T, Wang Y, . Insulin and glucose-lowering agents for treating people with diabetes and chronic kidney disease. Cochrane Database of Systematic Reviews. 2018(9)doi: 10.1002/14651858.CD011798.pub2. PMID: CD011798. Exclusion Code: X8.
1574 Lodovici M, Bigagli E, Luceri C, . Gender-related drug effect on several markers of oxidation stress in diabetes patients with and without complications. Eur J Pharmacol. 2015 Nov 5;766:86–90. doi: 10.1016/j.ejphar.2015.09.041. PMID: 26424110. Exclusion Code: X6.26424110
1575 Lombardi R, Onali S, Thorburn D, . Pharmacological interventions for non-alcohol related fatty liver disease (NAFLD). Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
1576 Long GH, Cooper AJ, Wareham NJ, . Healthy behavior change and cardiovascular outcomes in newly diagnosed type 2 diabetic patients: a cohort analysis of the ADDITION-Cambridge study. Diabetes Care. 2014 Jun;37(6):1712–20. doi: 10.2337/dc13-1731. PMID: 24658389. Exclusion Code: X5.24658389
1577 Long GH, Johansson I, Rolandsson O, . Healthy behaviours and 10-year incidence of diabetes: a population cohort study. Prev Med. 2015 Feb;71:121–7. doi: 10.1016/j.ypmed.2014.12.013. PMID: 25532678. Exclusion Code: X2.25532678
1578 Lorenzatti AJ, Eliaschewitz FG, Chen Y, . Rationale and design of a randomized study to assess the efficacy and safety of evolocumab in patients with diabetes and dyslipidemia: The BERSON clinical trial. Clin Cardiol. 2018 Sep;41(9):1117–22. doi: 10.1002/clc.23018. PMID: 29962050. Exclusion Code: X6.29962050
1579 Lorig K, Ritter PL, Moreland C, . Can a box of mailed materials achieve the triple aims of health care? The Mailed Chronic Disease Self-Management Tool Kit Study. Health Promot Pract. 2015 Sep;16(5):765–74. doi: 10.1177/1524839915571633. PMID: 25690615. Exclusion Code: X8.25690615
1580 Losada E, Soldevila B, Ali MS, . Real-world antidiabetic drug use and fracture risk in 12,277 patients with type 2 diabetes mellitus: a nested case-control study. Osteoporos Int. 2018 Sep;29(9):2079–86. doi: 10.1007/s00198-018-4581-y. PMID: 29860664. Exclusion Code: X5.29860664
1581 Loskutova NY, Tsai AG, Fisher EB, . Patient navigators connecting patients to community resources to improve diabetes outcomes. J Am Board Fam Med. 2016 Jan-Feb;29(1):78–89. doi: 10.3122/jabfm.2016.01.150048. PMID: 26769880. Exclusion Code: X8.26769880
1582 Lotta LA, Sharp SJ, Burgess S, . Association between low-density lipoprotein cholesterol-lowering genetic variants and risk of type 2 diabetes: a meta-analysis. Jama. 2016 Oct 4;316(13):1383–91. doi: 10.1001/jama.2016.14568. PMID: 27701660. Exclusion Code: X8.27701660
1583 Lovshin JA, Barnie A, DeAlmeida A, . Liraglutide promotes natriuresis but does not increase circulating levels of atrial natriuretic peptide in hypertensive subjects with type 2 diabetes. Diabetes Care. 2015 Jan;38(1):132–9. doi: 10.2337/dc14-1958. PMID: 25414155. Exclusion Code: X2.25414155
1584 Lu C, Min K, Chuang L, . Efficacy, safety, and tolerability of ipragliflozin in Asian patients with type 2 diabetes mellitus and inadequate glycemic control with metformin: results of a phase 3 randomized, placebo-controlled, double-blind, multicenter trial. Journal of diabetes investigation. 2016;7(3):366–73. doi: 10.1111/jdi.12422. PMID: CN-01153237. Exclusion Code: X2.27330723
1585 Lu CH, Chung CH, Lee CH, . Combination COX-2 inhibitor and metformin attenuate rate of joint replacement in osteoarthritis with diabetes: A nationwide, retrospective, matched-cohort study in Taiwan. PLoS One. 2018;13(1):e0191242. doi: 10.1371/journal.pone.0191242. PMID: 29385156. Exclusion Code: X8.29385156
1586 Lü Q, Ke Lq, Tong N, . Metformin for people with impaired glucose tolerance or impaired fasting blood glucose. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2010. Exclusion Code: X8.
1587 Lu Y, Garcia Rodriguez LA, Malgerud L, . New-onset type 2 diabetes, elevated HbA1c, anti-diabetic medications, and risk of pancreatic cancer. Br J Cancer. 2015 Dec 1;113(11):1607–14. doi: 10.1038/bjc.2015.353. PMID: 26575601. Exclusion Code: X11.26575601
1588 Luchsinger JA, Lehtisalo J, Lindstrom J, . Cognition in the Finnish diabetes prevention study. Diabetes Res Clin Pract. 2015 Jun;108(3):e63–6. doi: 10.1016/j.diabres.2015.02.023. PMID: 25799080. Exclusion Code: X6.25799080
1589 Luchsinger JA, Ma Y, Christophi CA, . Metformin, lifestyle intervention, and cognition in the Diabetes Prevention Program Outcomes Study. Diabetes Care. 2017 Jul;40(7):958–65. doi: 10.2337/dc16-2376. PMID: 28500216. Exclusion Code: X6.28500216
1590 Ludemann J, Dutting E, Dworak M. Patient preference and tolerability of a DPP-4 inhibitor versus a GLP-1 analog in patients with type 2 diabetes mellitus inadequately controlled with metformin: a 24-week, randomized, multicenter, crossover study. Therapeutic advances in endocrinology and metabolism. 2015;6(4):141–8. doi: 10.1177/2042018815595584. PMID: CN-01091155. Exclusion Code: X5.26301063
1591 Ludvik B, Frias JP, Tinahones FJ, . Dulaglutide as add-on therapy to SGLT2 inhibitors in patients with inadequately controlled type 2 diabetes (AWARD-10): a 24-week, randomised, double-blind, placebo-controlled trial. Lancet Diabetes Endocrinol. 2018 May;6(5):370–81. doi: 10.1016/s2213-8587(18)30023-8. PMID: 29483060. Exclusion Code: X2.29483060
1592 Lundby-Christensen L, Tarnow L, Boesgaard TW, . Metformin versus placebo in combination with insulin analogues in patients with type 2 diabetes mellitus-the randomised, blinded Copenhagen Insulin and Metformin Therapy (CIMT) trial. BMJ Open. 2016 Feb 25;6(2):e008376. doi: 10.1136/bmjopen-2015-008376. PMID: 26916684. Exclusion Code: X2.26916684
1593 Lundby-Christensen L, Vaag A, Tarnow L, . Effects of biphasic, basal-bolus or basal insulin analogue treatments on carotid intima-media thickness in patients with type 2 diabetes mellitus: the randomised Copenhagen Insulin and Metformin Therapy (CIMT) trial. BMJ Open. 2016 Feb 25;6(2):e008377. doi: 10.1136/bmjopen-2015-008377. PMID: 26916685. Exclusion Code: X2.26916685
1594 Lundkvist P, Amini S, Lau BJ, . Metabolic effects of dapagliflozin QD and exenatide QW in obese adults without diabetes: a 24-week randomised placebo-controlled phase 2 study. Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S377–s8. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212759. Exclusion Code: X2.
1595 Lundkvist P, Pereira MJ, Katsogiannos P, . Dapagliflozin once daily plus exenatide once weekly in obese adults without diabetes: sustained reductions in body weight, glycaemia and blood pressure over 1 year. Diabetes, obesity & metabolism. 2017;19(9):1276–88. doi: 10.1111/dom.12954. PMID: CN-01600608. Exclusion Code: X2.
1596 Lundkvist P, Sjostrom CD, Amini S, . Dapagliflozin once-daily and exenatide once-weekly dual therapy: A 24-week randomized, placebo-controlled, phase II study examining effects on body weight and prediabetes in obese adults without diabetes. Diabetes Obes Metab. 2017 Jan;19(1):49–60. doi: 10.1111/dom.12779. PMID: 27550386. Exclusion Code: X2.27550386
1597 Luo Y, Paul SK, Zhou X, . Rationale, design, and baseline characteristics of Beijing prediabetes reversion program: a randomized controlled clinical trial to evaluate the efficacy of lifestyle intervention and/or pioglitazone in reversion to normal glucose tolerance in prediabetes. J Diabetes Res. 2017;2017:7602408. doi: 10.1155/2017/7602408. PMID: 28168204. Exclusion Code: X6.28168204
1598 Lutes LD, Cummings DM, Littlewood K, . A Community Health Worker-Delivered Intervention in African American Women with Type 2 Diabetes: A 12-Month Randomized Trial. Obesity (Silver Spring). 2017 Aug;25(8):1329–35. doi: 10.1002/oby.21883. PMID: 28660719. Exclusion Code: X6.28660719
1599 Lv J, Perkovic V. Blood pressure management in diabetes: a path forward? J Hypertens. 2011 Jul;29(7):1283–4. doi: 10.1097/HJH.0b013e3283491537. PMID: 21659818. Exclusion Code: X8.21659818
1600 Lynch EB, Liebman R, Ventrelle J, . A self-management intervention for African Americans with comorbid diabetes and hypertension: a pilot randomized controlled trial. Prev Chronic Dis. 2014 May 29;11:E90. doi: 10.5888/pcd11.130349. PMID: 24874782. Exclusion Code: X6.24874782
1601 Lynch EB, Liebman R, Ventrelle J, . Design of the Lifestyle Improvement through Food and Exercise (LIFE) study: a randomized controlled trial of self-management of type 2 diabetes among African American patients from safety net health centers. Contemp Clin Trials. 2014 Nov;39(2):246–55. doi: 10.1016/j.cct.2014.09.003. PMID: 25245954. Exclusion Code: X6.25245954
1602 Lyon C, Fields H, Langner S, . Diabetes Education and Glycemic Control. Am Fam Physician. 2018 Feb 15;97(4):269–70. PMID: 29671523. Exclusion Code: X8.29671523
1603 Lyons I, Barber N, Raynor DK, . The Medicines Advice Service Evaluation (MASE): a randomised controlled trial of a pharmacist-led telephone based intervention designed to improve medication adherence. BMJ Qual Saf. 2016 Oct;25(10):759–69. doi: 10.1136/bmjqs-2015-004670. PMID: 26755665. Exclusion Code: X2.26755665
1604 Ma J, Yang W, Fang N, . The association between intensive glycemic control and vascular complications in type 2 diabetes mellitus: a meta-analysis. Nutr Metab Cardiovasc Dis. 2009 Nov;19(9):596–603. doi: 10.1016/j.numecd.2009.07.004. PMID: 19819121. Exclusion Code: X8.19819121
1605 Ma RCW, Del Prato S, Gallwitz B, . Oral glucose lowering with linagliptin and metformin compared with linagliptin alone as initial treatment in Asian patients with newly diagnosed type 2 diabetes and marked hyperglycemia: subgroup analysis of a randomized clinical trial. Journal of diabetes investigation. 2018;9(3):579–86. doi: 10.1111/jdi.12746. PMID: CN-01605503. Exclusion Code: X5.
1606 Macauley M, Hollingsworth KG, Smith FE, . Effect of vildagliptin on hepatic steatosis. J Clin Endocrinol Metab. 2015 Apr;100(4):1578–85. doi: 10.1210/jc.2014-3794. PMID: 25664602. Exclusion Code: X2.25664602
1607 MacHado P, Osark B, Conde A, . Metformin for frailty prevention: a randomized placebo-control trial. J Am Geriatr Soc. 2019;67:S301-. doi: 10.1111/jgs.15898. PMID: CN-01940253. Exclusion Code: X6.
1608 Maciel MG, Beserra BTS, Oliveira FCB, . The effect of glucagon-like peptide 1 and glucagon-like peptide 1 receptor agonists on energy expenditure: A systematic review and meta-analysis. Diabetes Res Clin Pract. 2018 Aug;142:222–35. doi: 10.1016/j.diabres.2018.05.034. PMID: 29857094. Exclusion Code: X8.29857094
1609 Mackerras DEM. Does a combined program of dietary modification and physical activity or the use of metformin reduce the conversion from impaired glucose tolerance to type 2 diabetes? Med J Aust. 2003;178(7):346–7. PMID: CN-01753476. Exclusion Code: X8.12670282
1610 Madjd A, Taylor MA, Delavari A, . Beneficial effects of replacing diet beverages with water on type 2 diabetic obese women following a hypo-energetic diet: A randomized, 24-week clinical trial. Diabetes Obes Metab. 2017 Jan;19(1):125–32. doi: 10.1111/dom.12793. PMID: 27748014. Exclusion Code: X6.27748014
1611 Madjid IS, Backholer K, Williams ED, . The effect of educational status on the relationship between obesity and risk of type 2 diabetes. Obes Res Clin Pract. 2014 Mar-Apr;8(2):e172–7. doi: 10.1016/j.orcp.2013.04.003. PMID: 24743013. Exclusion Code: X8.24743013
1612 Madsbad S, Lieberman G, Skjoth T, . Comparable efficacy and safety of liraglutide 3.0 mg for weight management across baseline BMI subgroups: results from the SCALE obesity and prediabetes trial. Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S40–s1. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212779. Exclusion Code: X10.
1613 Madsen KS, Kähler P, Kähler LK, . Metformin and sulphonylurea (second- or third-generation) combination therapy for adults with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
1614 Madsen KS, Kähler P, Kähler LKA, . Metformin and second- or third-generation sulphonylurea combination therapy for adults with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2019(4)doi: 10.1002/14651858.CD012368.pub2. PMID: CD012368. Exclusion Code: X8.
1615 Madsen SM, Thorup AC, Overgaard K, . Functional and structural vascular adaptations following 8 weeks of low volume high intensity interval training in lower leg of type 2 diabetes patients and individuals at high risk of metabolic syndrome. Arch Physiol Biochem. 2015;121(5):178–86. doi: 10.3109/13813455.2015.1087033. PMID: 26471849. Exclusion Code: X6.26471849
1616 Maeda H, Kubota A, Kanamori A, . Effects of sitagliptin on the serum creatinine in Japanese type 2 diabetes. Diabetes Res Clin Pract. 2015 Jun;108(3):e42–5. doi: 10.1016/j.diabres.2015.03.008. PMID: 25836945. Exclusion Code: X2.25836945
1617 Mahar SA, Hasan MI, Khan MI, . Comparison of hypoglycaemia episodes in people with type-2 diabetes fasting in Ramazan, treated with vildaglipton or sulphonylurea: results of the Pakistani cohort of the VIRTUE study. J Pak Med Assoc. 2014 Nov;64(11):1297–302. PMID: 25831650. Exclusion Code: X8.25831650
1618 Maharaj SS, Nuhu JM. Rebound exercise: a beneficial adjuvant for sedentary non-insulin-dependent type 2 diabetic individuals in a rural environment. Aust J Rural Health. 2016 Apr;24(2):123–9. doi: 10.1111/ajr.12223. PMID: 26255814. Exclusion Code: X7.26255814
1619 Maindal HT, Carlsen AH, Lauritzen T, . Effect of a participant-driven health education programme in primary care for people with hyperglycaemia detected by screening: 3-year results from the Ready to Act randomized controlled trial (nested within the ADDITION-Denmark study). Diabet Med. 2014 Aug;31(8):976–86. doi: 10.1111/dme.12440. PMID: 24646371. Exclusion Code: X11.24646371
1620 Mainous AG, 3rd, Tanner RJ, Anton SD, . Physical activity and abnormal blood glucose among healthy weight adults. Am J Prev Med. 2017 Jul;53(1):42–7. doi: 10.1016/j.amepre.2016.11.027. PMID: 28110936. Exclusion Code: X8.28110936
1621 Maiorino M, Bellastella G, Caputo M, . Effects of Mediterranean diet on sexual function in people with newly diagnosed type 2 diabetes: the MÈDITA trial. J Diabetes Complications. 2016;30(8):1519–24. doi: 10.1016/j.jdiacomp.2016.08.007. PMID: CN-01459416. Exclusion Code: X5.27614727
1622 Maiorino M, Bellastella G, Petrizzo M, . Effect of a Mediterranean diet on endothelial progenitor cells and carotid intima-media thickness in type 2 diabetes: follow-up of a randomized trial. European journal of preventive cardiology. 2017;24(4):399–408. doi: 10.1177/2047487316676133. PMID: CN-01330975. Exclusion Code: X5.27798369
1623 Maiorino M, Bellastella G, Petrizzo M, . Mediterranean diet cools down the inflammatory milieu in type 2 diabetes: the MÉDITA randomized controlled trial. Endocrine. 2016;54(3):634–41. doi: 10.1007/s12020-016-0881-1. PMID: CN-01292205. Exclusion Code: X6.26860514
1624 Maiorino MI, Chiodini P, Bellastella G, . Free and fixed-ratio combinations of basal insulin and GLP-1 receptor agonists versus basal insulin intensification in type 2 diabetes: A systematic review and meta-analysis of randomized controlled trials. Diabetes Obes Metab. 2018 Sep;20(9):2309–13. doi: 10.1111/dom.13343. PMID: 29732679. Exclusion Code: X8.29732679
1625 Majumdar SR, Josse RG, Lin M, . Does sitagliptin affect the rate of osteoporotic fractures in type 2 diabetes? Population-based cohort study. J Clin Endocrinol Metab. 2016 May;101(5):1963–9. doi: 10.1210/jc.2015-4180. PMID: 26930183. Exclusion Code: X5.26930183
1626 Malin S, Louis-Kullman E, Scelsi A, . Whole grain diet improves glucose tolerance, insulin sensitivity, and beta-cell function in overweight prediabetic adults. Diabetes. 2014;63:A78. doi: 10.2337/db14-1-388. PMID: CN-01065606. Exclusion Code: X6.
1627 Mamza J, Mehta R, Donnelly R, . Important differences in the durability of glycaemic response among second-line treatment options when added to metformin in type 2 diabetes: a retrospective cohort study. Ann Med. 2016;48(4):224–34. doi: 10.3109/07853890.2016.1157263. PMID: 26982210. Exclusion Code: X6.26982210
1628 Mancia G, Cannon C, Tikkanen I, . Impact of empagliflozin on blood pressure in patients with type 2 diabetes mellitus and hypertension by background antihypertensive medication. Hypertension (dallas, tex. : 1979). 2016;68(6):1355–64. doi: 10.1161/HYPERTENSIONAHA.116.07703. PMID: CN-01290777. Exclusion Code: X2.
1629 Mann D, Palmisano J, Lin J. A pilot randomized trial of technology-assisted goal setting to improve physical activity among primary care patients with prediabetes. Preventive medicine reports. 2016;4:107–12. doi: 10.1016/j.pmedr.2016.05.012. PMID: CN-01165746. Exclusion Code: X11.27413670
1630 Mann JFE, Orsted DD, Brown-Frandsen K, . Liraglutide and renal outcomes in type 2 diabetes. N Engl J Med. 2017 Aug 31;377(9):839–48. doi: 10.1056/NEJMoa1616011. PMID: 28854085. Exclusion Code: X2.28854085
1631 Mann S, Jimenez A, Steele J, . Programming and supervision of resistance training leads to positive effects on strength and body composition: results from two randomised trials of community fitness programmes. BMC public health. 2018;18(1):420. doi: 10.1186/s12889-018-5289-9. PMID: CN-01703759. Exclusion Code: X2.29587703
1632 Mannucci E, Monami M, Lamanna C, . Prevention of cardiovascular disease through glycemic control in type 2 diabetes: a meta-analysis of randomized clinical trials. Nutr Metab Cardiovasc Dis. 2009 Nov;19(9):604–12. doi: 10.1016/j.numecd.2009.03.021. PMID: 19427768. Exclusion Code: X8.19427768
1633 Mansi I, Frei CR, Wang CP, . Statins and new-onset diabetes mellitus and diabetic complications: a retrospective cohort study of US healthy adults. J Gen Intern Med. 2015 Nov;30(11):1599–610. doi: 10.1007/s11606-015-3335-1. PMID: 25917657. Exclusion Code: X2.25917657
1634 Mao L, Lu J, Zhang Q, . Family-based intervention for patients with type 2 diabetes via WeChat in China: protocol for a randomized controlled trial. BMC Public Health. 2019 Apr 5;19(1):381. doi: 10.1186/s12889-019-6702-8. PMID: 30953483. Exclusion Code: X6.30953483
1635 Marcinak J, Cao C, Lee D, . Fasiglifam for glycaemic control in people with type 2 diabetes: a phase III, placebo-controlled study. Diabetes, obesity & metabolism. 2017;(no pagination)doi: 10.1111/dom.13004. PMID: CN-01395624. Exclusion Code: X2.
1636 Margolis KL, O’Connor PJ, Morgan TM, . Outcomes of combined cardiovascular risk factor management strategies in type 2 diabetes: the ACCORD randomized trial. Diabetes Care. 2014 Jun;37(6):1721–8. doi: 10.2337/dc13-2334. PMID: 24595629. Exclusion Code: X2.24595629
1637 Margolis KL, Palermo L, Vittinghoff E, . Intensive blood pressure control, falls, and fractures in patients with type 2 diabetes: the ACCORD trial. J Gen Intern Med. 2014 Dec;29(12):1599–606. doi: 10.1007/s11606-014-2961-3. PMID: 25127725. Exclusion Code: X2.25127725
1638 Mari A, Del Prato S, Ludvik B, . Differential effects of once-weekly glucagon-like peptide-1 receptor agonist dulaglutide and metformin on pancreatic beta-cell and insulin sensitivity during a standardized test meal in patients with type 2 diabetes. Diabetes Obes Metab. 2016 Aug;18(8):834–9. doi: 10.1111/dom.12671. PMID: 27059816. Exclusion Code: X6.27059816
1639 Marinik EL, Kelleher S, Savla J, . The resist diabetes trial: rationale, design, and methods of a hybrid efficacy/effectiveness intervention trial for resistance training maintenance to improve glucose homeostasis in older prediabetic adults. Contemp Clin Trials. 2014 Jan;37(1):19–32. doi: 10.1016/j.cct.2013.11.006. PMID: 24252311. Exclusion Code: X6.24252311
1640 Markle-Reid M, Ploeg J, Fraser KD, . The ACHRU-CPP versus usual care for older adults with type-2 diabetes and multiple chronic conditions and their family caregivers: study protocol for a randomized controlled trial. Trials. 2017 Feb 6;18(1):55. doi: 10.1186/s13063-017-1795-9. PMID: 28166816. Exclusion Code: X6.28166816
1641 Marquard J, Stirban A, Schliess F, . Effects of dextromethorphan as add-on to sitagliptin on blood glucose and serum insulin concentrations in individuals with type 2 diabetes mellitus: a randomized, placebo-controlled, double-blinded, multiple crossover, single-dose clinical trial. Diabetes Obes Metab. 2016 Jan;18(1):100–3. doi: 10.1111/dom.12576. PMID: 26362564. Exclusion Code: X5.26362564
1642 Marques N, Abreu L, Santos B, . Cardiorespiratory parameters and glycated hemoglobin of patients with type 2 diabetes after a rehabilitation program. Medicine. 2018;97(8):e9321. doi: 10.1097/MD.0000000000009321. PMID: CN-01453956. Exclusion Code: X6.29465549
1643 Marrero D, Pan Q, Barrett-Connor E, . Impact of diagnosis of diabetes on health-related quality of life among high risk individuals: the Diabetes Prevention Program outcomes study. Qual Life Res. 2014 Feb;23(1):75–88. doi: 10.1007/s11136-013-0436-3. PMID: 23709097. Exclusion Code: X5.23709097
1644 Marrero DG, Ma Y, de Groot M, . Depressive symptoms, antidepressant medication use, and new onset of diabetes in participants of the diabetes prevention program and the diabetes prevention program outcomes study. Psychosom Med. 2015 Apr;77(3):303–10. doi: 10.1097/psy.0000000000000156. PMID: 25775165. Exclusion Code: X5.25775165
1645 Marrero DG, Palmer KN, Phillips EO, . Comparison of commercial and self-initiated weight loss programs in people with prediabetes: a randomized control trial. Am J Public Health. 2016 May;106(5):949–56. doi: 10.2105/ajph.2015.303035. PMID: 26890171. Exclusion Code: X7.26890171
1646 Marso SP, Daniels GH, Brown-Frandsen K, . Liraglutide and cardiovascular outcomes in type 2 diabetes. N Engl J Med. 2016 Jul 28;375(4):311–22. doi: 10.1056/NEJMoa1603827. PMID: 27295427. Exclusion Code: X2.27295427
1647 Martin N, Germanò R, Hartley L, . Nut consumption for the primary prevention of cardiovascular disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
1648 Martinez L, Penfornis A, Gautier JF, . Effectiveness and persistence of liraglutide treatment among patients with type 2 diabetes treated in primary care and specialist settings: a subgroup analysis from the EVIDENCE Study, a prospective, 2-year follow-up, observational, post-marketing study. Adv Ther. 2017 Mar;34(3):674–85. doi: 10.1007/s12325-017-0476-0. PMID: 28138803. Exclusion Code: X5.28138803
1649 Martinez R, Al-Jobori H, Ali AM, . Endogenous glucose production and hormonal changes in response to canagliflozin and liraglutide combination therapy. Diabetes. 2018 Jun;67(6):1182–9. doi: 10.2337/db17-1278. PMID: 29602791. Exclusion Code: X6.29602791
1650 Martin-Merino E, Fortuny J, Rivero-Ferrer E, . Risk factors for diabetic macular oedema in type 2 diabetes: a case-control study in a United Kingdom primary care setting. Prim Care Diabetes. 2017 Jun;11(3):288–96. doi: 10.1016/j.pcd.2017.03.002. PMID: 28395937. Exclusion Code: X6.28395937
1651 Martis R, Crowther CA, Shepherd E, . Treatments for women with gestational diabetes mellitus: an overview of Cochrane systematic reviews. Cochrane Database of Systematic Reviews. 2018(8)doi: 10.1002/14651858.CD012327.pub2. PMID: CD012327. Exclusion Code: X8.
1652 Maruhashi T, Higashi Y, Kihara Y, . Long-term effect of sitagliptin on endothelial function in type 2 diabetes: a sub-analysis of the PROLOGUE study. Cardiovasc Diabetol. 2016 Sep 13;15(1):134. doi: 10.1186/s12933-016-0438-x. PMID: 27624168. Exclusion Code: X6.27624168
1653 Marusic S, Melis P, Lucijanic M, . Impact of pharmacotherapeutic education on medication adherence and adverse outcomes in patients with type 2 diabetes mellitus: a prospective, randomized study. Croat Med J. 2018 Dec 31;59(6):290–7. PMID: 30610771. Exclusion Code: X4.30610771
1654 Maruthur NM, Tseng E, Hutfless S, . Diabetes medications as monotherapy or metformin-based combination therapy for type 2 diabetes: a systematic review and meta-analysis. Ann Intern Med. 2016 Jun 7;164(11):740–51. doi: 10.7326/m15-2650. PMID: 27088241. Exclusion Code: X8.27088241
1655 Mary A, Hartemann A, Liabeuf S, . Association between metformin use and below-the-knee arterial calcification score in type 2 diabetic patients. Cardiovasc Diabetol. 2017 Feb 15;16(1):24. doi: 10.1186/s12933-017-0509-7. PMID: 28202017. Exclusion Code: X8.28202017
1656 Mascarenhas P, Fatela B, Barahona I. Effect of diabetes mellitus type 2 on salivary glucose--a systematic review and meta-analysis of observational studies. PLoS One. 2014;9(7):e101706. doi: 10.1371/journal.pone.0101706. PMID: 25025218. Exclusion Code: X8.25025218
1657 Mash RJ, Rhode H, Zwarenstein M, . Effectiveness of a group diabetes education programme in under-served communities in South Africa: a pragmatic cluster randomized controlled trial. Diabet Med. 2014 Aug;31(8):987–93. doi: 10.1111/dme.12475. PMID: 24766179. Exclusion Code: X2.24766179
1658 Massin P, Peto T, Ansquer JC, . Effects of fenofibric acid on diabetic macular edema: the MacuFen study. Ophthalmic Epidemiol. 2014 Oct;21(5):307–17. doi: 10.3109/09286586.2014.949783. PMID: 25133794. Exclusion Code: X2.25133794
1659 Mastellos N, Gunn LH, Felix LM, . Transtheoretical model stages of change for dietary and physical exercise modification in weight loss management for overweight and obese adults. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
1660 Mather KJ, Kim C, Christophi CA, . Steroid sex hormones, sex hormone-binding globulin, and diabetes incidence in the Diabetes Prevention Program. J Clin Endocrinol Metab. 2015 Oct;100(10):3778–86. doi: 10.1210/jc.2015-2328. PMID: 26200237. Exclusion Code: X6.26200237
1661 Mathieu C, Herrera Marmolejo M, Gonzalez Gonzalez JG, . Efficacy and safety of triple therapy with dapagliflozin add-on to saxagliptin plus metformin over 52 weeks in patients with type 2 diabetes. Diabetes Obes Metab. 2016 Nov;18(11):1134–7. doi: 10.1111/dom.12737. PMID: 27385192. Exclusion Code: X2.27385192
1662 Mathieu C, Ranetti AE, Li D, . Randomized, double-blind, phase 3 trial of triple therapy with dapagliflozin add-on to saxagliptin plus metformin in type 2 diabetes. Diabetes Care. 2015 Nov;38(11):2009–17. doi: 10.2337/dc15-0779. PMID: 26246458. Exclusion Code: X2.26246458
1663 Mathieu C, Rodbard HW, Cariou B, . A comparison of adding liraglutide versus a single daily dose of insulin aspart to insulin degludec in subjects with type 2 diabetes (BEGIN: VICTOZA ADD-ON). Diabetes Obes Metab. 2014 Jul;16(7):636–44. doi: 10.1111/dom.12262. PMID: 24443830. Exclusion Code: X5.24443830
1664 Matikainen N, Soderlund S, Bjornson E, . Liraglutide treatment improves postprandial lipid metabolism and cardiometabolic risk factors in humans with adequately controlled type 2 diabetes: A single-centre randomized controlled study. Diabetes Obes Metab. 2019 Jan;21(1):84–94. doi: 10.1111/dom.13487. PMID: 30073766. Exclusion Code: X2.30073766
1665 Matsumoto C, Saito Y, Ogawa H, . Effect of low-dose aspirin on incidence of dementia in patients with type 2 diabetes mellitus: insights from JPAD2 study. Circulation. Conference: resuscitation science symposium, ress 2017. United states. 2017;136(Supplement 1) (no pagination)PMID: CN-01438483. Exclusion Code: X10.
1666 Matthaei S, Aggarwal N, Garcia-Hernandez P, . One-year efficacy and safety of saxagliptin add-on in patients receiving dapagliflozin and metformin. Diabetes Obes Metab. 2016 Nov;18(11):1128–33. doi: 10.1111/dom.12741. PMID: 27403645. Exclusion Code: X2.27403645
1667 Matthaei S, Bowering K, Rohwedder K, . Dapagliflozin improves glycemic control and reduces body weight as add-on therapy to metformin plus sulfonylurea: a 24-week randomized, double-blind clinical trial. Diabetes Care. 2015 Mar;38(3):365–72. doi: 10.2337/dc14-0666. PMID: 25592197. Exclusion Code: X2.25592197
1668 Matthaei S, Catrinoiu D, Celinski A, . Randomized, double-blind trial of triple therapy with saxagliptin add-on to dapagliflozin plus metformin in patients with type 2 diabetes. Diabetes Care. 2015 Nov;38(11):2018–24. doi: 10.2337/dc15-0811. PMID: 26324329. Exclusion Code: X2.26324329
1669 Matthews D, Rosenstock J, Desai M, . Impact of canagliflozin added-on to insulin and metformin in type 2 diabetes: a substudy of the CANVAS trial. Diabetologia. 2015;58(1 suppl. 1):S357. doi: 10.1007/s00125-015-3687-4. PMID: CN-01136795. Exclusion Code: X2.
1670 Mazza A, Schiavon L, Zuin M, . Effects of the antihypertensive fixed-dose combinations on an early marker of hypertensive cardiac damage in subjects at low cardiovascular risk. Am J Hypertens. 2016 Aug;29(8):969–75. doi: 10.1093/ajh/hpw022. PMID: 27053407. Exclusion Code: X2.27053407
1671 McAlister FA, Youngson E, Eurich DT. Treated glycosylated hemoglobin levels in individuals with diabetes mellitus vary little by health status: A retrospective cohort study. Medicine (Baltimore). 2016 Jun;95(24):e3894. doi: 10.1097/md.0000000000003894. PMID: 27310986. Exclusion Code: X6.27310986
1672 McAuley PA, Chen H, Lee DC, . Physical activity, measures of obesity, and cardiometabolic risk: the Multi-Ethnic Study of Atherosclerosis (MESA). J Phys Act Health. 2014 May;11(4):831–7. doi: 10.1123/jpah.2012-0326. PMID: 23676525. Exclusion Code: X8.23676525
1673 McBain H, Mulligan K, Haddad M, . Self management interventions for type 2 diabetes in adult people with severe mental illness. Cochrane Database Syst Rev. 2016 Apr 27;4:Cd011361. doi: 10.1002/14651858.CD011361.pub2. PMID: 27120555. Exclusion Code: X8.27120555
1674 McCarthy M, Edwardson CL, Davies MJ, . Change in sedentary time, physical activity, bodyweight, and hba1c in high-risk adults. Med Sci Sports Exerc. 2017 Jun;49(6):1120–5. doi: 10.1249/mss.0000000000001218. PMID: 28121795. Exclusion Code: X8.28121795
1675 McCormick LM, Kydd AC, Read PA, . Chronic dipeptidyl peptidase-4 inhibition with sitagliptin is associated with sustained protection against ischemic left ventricular dysfunction in a pilot study of patients with type 2 diabetes mellitus and coronary artery disease. Circ Cardiovasc Imaging. 2014 Mar;7(2):274–81. doi: 10.1161/circimaging.113.000785. PMID: 24503784. Exclusion Code: X2.24503784
1676 McCoy RG, Zhang Y, Herrin J, . Changing trends in type 2 diabetes mellitus treatment intensification, 2002-2010. Am J Manag Care. 2015 May 1;21(5):e288–96. PMID: 26167776. Exclusion Code: X6.26167776
1677 McEwan P, Bennett H, Qin L, . An alternative approach to modelling HbA1c trajectories in patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2017 May;19(5):628–34. doi: 10.1111/dom.12865. PMID: 28026908. Exclusion Code: X8.28026908
1678 McEwen M, Pasvogel A, Murdaugh C, . Effects of a family-based diabetes intervention on behavioral and biological outcomes for Mexican American adults. Diabetes educator. 2017;43(3):272–85. doi: 10.1177/0145721717706031. PMID: CN-01454446. Exclusion Code: X2.
1679 McGill JB, Barnett AH, Lewin AJ, . Linagliptin added to sulphonylurea in uncontrolled type 2 diabetes patients with moderate-to-severe renal impairment. Diab Vasc Dis Res. 2014 Jan;11(1):34–40. doi: 10.1177/1479164113507068. PMID: 24169807. Exclusion Code: X2.24169807
1680 McGill JB, Yki-Jarvinen H, Crowe S, . Combination of the dipeptidyl peptidase-4 inhibitor linagliptin with insulin-based regimens in type 2 diabetes and chronic kidney disease. Diab Vasc Dis Res. 2015 Jul;12(4):249–57. doi: 10.1177/1479164115579001. PMID: 25941160. Exclusion Code: X2.25941160
1681 McGowan P. The relative effectiveness of self-management programs for type 2 diabetes. Can J Diabetes. 2015 Oct;39(5):411–9. doi: 10.1016/j.jcjd.2015.04.005. PMID: 26165582. Exclusion Code: X2.26165582
1682 McGuire DK, Van de Werf F, Armstrong PW, . Association between sitagliptin use and heart failure hospitalization and related outcomes in type 2 diabetes mellitus: secondary analysis of a randomized clinical trial. JAMA Cardiol. 2016 May 1;1(2):126–35. doi: 10.1001/jamacardio.2016.0103. PMID: 27437883. Exclusion Code: X8.27437883
1683 McInnes G, Evans M, Del Prato S, . Cardiovascular and heart failure safety profile of vildagliptin: a meta-analysis of 17 000 patients. Diabetes Obes Metab. 2015 Nov;17(11):1085–92. doi: 10.1111/dom.12548. PMID: 26250051. Exclusion Code: X8.26250051
1684 McInnes N, Smith A, Otto R, . Piloting a remission strategy in type 2 diabetes: results of a randomized controlled trial. J Clin Endocrinol Metab. 2017 May 1;102(5):1596–605. doi: 10.1210/jc.2016-3373. PMID: 28324049. Exclusion Code: X2.28324049
1685 McKie EA, Reid JL, Mistry PC, . A study to investigate the efficacy and safety of an anti-interleukin-18 monoclonal antibody in the treatment of type 2 diabetes mellitus. PLoS One. 2016;11(3):e0150018. doi: 10.1371/journal.pone.0150018. PMID: 26930607. Exclusion Code: X2.26930607
1686 McMullan CJ, Lambers Heerspink HJ, Parving HH, . Visit-to-visit variability in blood pressure and kidney and cardiovascular outcomes in patients with type 2 diabetes and nephropathy: a post hoc analysis from the RENAAL study and the Irbesartan Diabetic Nephropathy Trial. Am J Kidney Dis. 2014 Nov;64(5):714–22. doi: 10.1053/j.ajkd.2014.06.008. PMID: 25064674. Exclusion Code: X2.25064674
1687 Mead E, Atkinson G, Richter B, . Drug interventions for the treatment of obesity in children and adolescents. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
1688 Mead E, Brown T, Rees K, . Diet, physical activity and behavioural interventions for the treatment of overweight or obese children from the age of 6 to 11 years. Cochrane Database of Systematic Reviews. 2017(6)doi: 10.1002/14651858.CD012651. PMID: CD012651. Exclusion Code: X8.
1689 Meader N, King K, Wright K, . Multiple risk behavior interventions: meta-analyses of RCTs. Am J Prev Med. 2017 Jul;53(1):e19–e30. doi: 10.1016/j.amepre.2017.01.032. PMID: 28258777. Exclusion Code: X8.28258777
1690 Medairos RA, Clark J, Holoubek S, . Metformin exposure is associated with improved progression-free survival in diabetic patients after resection for early-stage non-small cell lung cancer. J Thorac Cardiovasc Surg. 2016 Jul;152(1):55–61.e1. doi: 10.1016/j.jtcvs.2016.03.094. PMID: 27157918. Exclusion Code: X2.27157918
1691 Medley N, Vogel JP, Care A, . Interventions during pregnancy to prevent preterm birth: an overview of Cochrane systematic reviews. Cochrane Database of Systematic Reviews. 2018(11)doi: 10.1002/14651858.CD012505.pub2. PMID: CD012505. Exclusion Code: X8.
1692 Meek CL. Natural selection? The evolution of diagnostic criteria for gestational diabetes. Ann Clin Biochem. 2017 Jan;54(1):33–42. doi: 10.1177/0004563216674743. PMID: 27687080. Exclusion Code: X8.27687080
1693 Mehdi Hazavehei SM, Khoshravesh S, Taheri-Kharameh Z. Increasing Medical Adherence in Elderly With Type 2 Diabetes Mellitus: A Systematic Review. Int Q Community Health Educ. 2019 Jan;39(2):109–17. doi: 10.1177/0272684x18819969. PMID: 30799762. Exclusion Code: X8.30799762
1694 Mehrholz J, Thomas S, Elsner B. Treadmill training and body weight support for walking after stroke. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
1695 Meier JJ, Rosenstock J, Hincelin-Mery A, . Contrasting effects of lixisenatide and liraglutide on postprandial glycemic control, gastric emptying, and safety parameters in patients with type 2 diabetes on optimized insulin glargine with or without metformin: a randomized, open-label trial. Diabetes Care. 2015 Jul;38(7):1263–73. doi: 10.2337/dc14-1984. PMID: 25887358. Exclusion Code: X2.25887358
1696 Meinert CL, Knatterud GL, Prout TE, . A study of the effects of hypoglycemic agents on vascular complications in patients with adult-onset diabetes. II. Mortality results. Diabetes. 1970;19:Suppl:789–830. PMID: 4926376. Exclusion Code: X2.4926376
1697 Mendham A, Duffield R, Coutts A, . Rugby-specific small-sided games training is an effective alternative to stationary cycling at reducing clinical risk factors associated with the development of type 2 diabetes: a randomized, controlled trial. Plos one. 2015;10(6):e0127548. doi: 10.1371/journal.pone.0127548. PMID: CN-01257890. Exclusion Code: X2.26030423
1698 Menegazzo L, Scattolini V, Cappellari R, . The antidiabetic drug metformin blunts NETosis in vitro and reduces circulating NETosis biomarkers in vivo. Acta Diabetol. 2018:1–9. doi: 10.1007/s00592-018-1129-8. PMID: CN-01463880. Exclusion Code: X6.
1699 Meneghini L, Lingvay I, Chao J, . Efficacy and safety of new insulin glargine 300 units/ml in insulin naive patients with type 2 diabetes mellitus (EDITION 3) using selected hedis measures. Endocrine reviews. Conference: 97th annual meeting and expo of the endocrine society, ENDO 2015. United states. Conference start: 20150305. Conference end: 20150308. 2015;36(no pagination)PMID: CN-01306640. Exclusion Code: X5.
1700 Meneilly GS, Roy-Duval C, Alawi H, . Lixisenatide therapy in older patients with type 2 diabetes inadequately controlled on their current antidiabetic treatment: the GetGoal-O Randomized Trial. Diabetes Care. 2017 Apr;40(4):485–93. doi: 10.2337/dc16-2143. PMID: 28188240. Exclusion Code: X2.28188240
1701 Menne J, Ritz E, Ruilope LM, . The Randomized Olmesartan and Diabetes Microalbuminuria Prevention (ROADMAP) observational follow-up study: benefits of RAS blockade with olmesartan treatment are sustained after study discontinuation. J Am Heart Assoc. 2014;3(2):e000810. PMID: 24772521. Exclusion Code: X2.24772521
1702 Mensberg P, Nyby S, Jorgensen PG, . Near-normalization of glycaemic control with glucagon-like peptide-1 receptor agonist treatment combined with exercise in patients with type 2 diabetes. Diabetes Obes Metab. 2017 Feb;19(2):172–80. doi: 10.1111/dom.12797. PMID: 27717126. Exclusion Code: X2.27717126
1703 Mentz RJ, Bethel MA, Gustavson S, . Baseline characteristics of patients enrolled in the Exenatide Study of Cardiovascular Event Lowering (EXSCEL). Am Heart J. 2017 May;187:1–9. doi: 10.1016/j.ahj.2017.02.005. PMID: 28454792. Exclusion Code: X6.28454792
1704 Merakou K, Knithaki A, Karageorgos G, . Group patient education: effectiveness of a brief intervention in people with type 2 diabetes mellitus in primary health care in Greece: a clinically controlled trial. Health Educ Res. 2015 Apr;30(2):223–32. doi: 10.1093/her/cyv001. PMID: 25724879. Exclusion Code: X2.25724879
1705 Merino J, Jablonski KA, Mercader JM, . Interaction Between Type 2 Diabetes Prevention Strategies and Genetic Determinants of Coronary Artery Disease on Cardiometabolic Risk Factors. Diabetes. 2020 Jan;69(1):112–20. doi: 10.2337/db19-0097. PMID: 31636172. Exclusion Code: X6.31636172
1706 Merker L, Haring HU, Christiansen AV, . Empagliflozin as add-on to metformin in people with Type 2 diabetes. Diabet Med. 2015 Dec;32(12):1555–67. doi: 10.1111/dme.12814. PMID: 26031566. Exclusion Code: X2.26031566
1707 Merovci A, Abdul-Ghani M, Mari A, . Effect of dapagliflozin with and without acipimox on insulin sensitivity and insulin secretion in T2DM males. J Clin Endocrinol Metab. 2016 Mar;101(3):1249–56. doi: 10.1210/jc.2015-2597. PMID: 26765576. Exclusion Code: X6.26765576
1708 Merovci A, Solis-Herrera C, Daniele G, . Dapagliflozin improves muscle insulin sensitivity but enhances endogenous glucose production. J Clin Invest. 2014 Feb;124(2):509–14. doi: 10.1172/jci70704. PMID: 24463448. Exclusion Code: X2.24463448
1709 Miazgowski T, Dziwura-Ogonowska J, Safranow K, . Changes in adiponectin level and fat distribution in patients with type 2 diabetes. Eur J Clin Invest. 2014 Feb;44(2):192–9. doi: 10.1111/eci.12207. PMID: 24251799. Exclusion Code: X6.24251799
1710 Middleton P, Crowther CA. Reminder systems for women with previous gestational diabetes mellitus to increase uptake of testing for type 2 diabetes or impaired glucose tolerance. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
1711 Middleton TL, Wong J, Molyneaux L, . Cardiac effects of sulfonylurea-related hypoglycemia. Diabetes Care. 2017 May;40(5):663–70. doi: 10.2337/dc16-1972. PMID: 28223296. Exclusion Code: X5.28223296
1712 Migliore CL, Vorderstrasse A, Pan W, . Renal disease risk factors among risk groups comprised of African American women with type 2 diabetes: a secondary analysis. Diabetes Educ. 2015 Oct;41(5):569–81. doi: 10.1177/0145721715593814. PMID: 26202051. Exclusion Code: X8.26202051
1713 Mikhail N. Use of sodium-glucose cotransporter type 2 inhibitors in older adults with type 2 diabetes mellitus. South Med J. 2015 Feb;108(2):91–6. doi: 10.14423/smj.0000000000000235. PMID: 25688893. Exclusion Code: X8.25688893
1714 Milicevic Z, Anglin G, Harper K, . Low incidence of anti-drug antibodies in patients with type 2 diabetes treated with once-weekly glucagon-like peptide-1 receptor agonist dulaglutide. Diabetes Obes Metab. 2016 May;18(5):533–6. doi: 10.1111/dom.12640. PMID: 26847401. Exclusion Code: X8.26847401
1715 Miller CK, Kristeller JL, Headings A, . Comparison of a mindful eating intervention to a diabetes self-management intervention among adults with type 2 diabetes: a randomized controlled trial. Health Educ Behav. 2014 Apr;41(2):145–54. doi: 10.1177/1090198113493092. PMID: 23855018. Exclusion Code: X2.23855018
1716 Miller CK, Nagaraja HN, Weinhold KR. Early weight-loss success identifies nonresponders after a lifestyle intervention in a worksite diabetes prevention trial. J Acad Nutr Diet. 2015 Sep;115(9):1464–71. doi: 10.1016/j.jand.2015.04.022. PMID: 26095435. Exclusion Code: X5.26095435
1717 Miller E, Sethi P, Nowson C, . Effects of progressive resistance training and weight loss versus weight loss alone on inflammatory and endothelial biomarkers in older adults with type 2 diabetes. Eur J Appl Physiol. 2017;117(8):1669–78. doi: 10.1007/s00421-017-3657-2. PMID: CN-01458418. Exclusion Code: X2.28597102
1718 Miller GD, Isom S, Morgan TM, . Effects of a community-based weight loss intervention on adipose tissue circulating factors. Diabetes Metab Syndr. 2014 Oct–Dec;8(4):205–11. doi: 10.1016/j.dsx.2014.09.003. PMID: 25293442. Exclusion Code: X6.25293442
1719 Miller S, Krumins T, Zhou H, . Ertugliflozin and sitagliptin co-initiation in patients with type 2 diabetes: the VERTIS SITA Randomized Study. Diabetes therapy. 2018;9(1):253–68. doi: 10.1007/s13300-017-0358-0. PMID: CN-01460106. Exclusion Code: X2.29313282
1720 Min JY, Griffin MR, Hung AM, . Comparative effectiveness of insulin versus combination sulfonylurea and insulin: a cohort study of Veterans with type 2 diabetes. J Gen Intern Med. 2016 Jun;31(6):638–46. doi: 10.1007/s11606-016-3633-2. PMID: 26921160. Exclusion Code: X5.26921160
1721 Min SH, Yoon JH, Hahn S, . Efficacy and safety of combination therapy with an alpha-glucosidase inhibitor and a dipeptidyl peptidase-4 inhibitor in patients with type 2 diabetes mellitus: A systematic review with meta-analysis. J Diabetes Investig. 2018 Jul;9(4):893–902. doi: 10.1111/jdi.12754. PMID: 28950431. Exclusion Code: X8.28950431
1722 Mino-Leon D, Reyes-Morales H, Flores-Hernandez S. Effectiveness of involving pharmacists in the process of ambulatory health care to improve drug treatment adherence and disease control. J Eval Clin Pract. 2014;21(1):7–12. doi: 10.1111/jep.12207. PMID: CN-01052238. Exclusion Code: X8.24953287
1723 Mirmiran P, Hosseinpour-Niazi S, Azizi F. Therapeutic lifestyle change diet enriched in legumes reduces oxidative stress in overweight type 2 diabetic patients: a crossover randomised clinical trial. Eur J Clin Nutr. 2018 Jan;72(1):174–6. doi: 10.1038/ejcn.2017.113. PMID: 28722030. Exclusion Code: X5.28722030
1724 Mita T, Hiyoshi T, Yoshii H, . Study Protocol for the Initial Choice of DPP-4 Inhibitor in Japanese Patients with Type 2 diabetes Mellitus: effect of Linagliptin on QOL (INTEL-QOL) Trial. Diabetes therapy. 2018;9(3):1403–12. doi: 10.1007/s13300-018-0437-x. PMID: CN-01610321. Exclusion Code: X6.29744822
1725 Mita T, Hiyoshi T, Yoshii H, . The Effect of Linagliptin versus Metformin Treatment-Related Quality of Life in Patients with Type 2 Diabetes Mellitus. Diabetes therapy. 2019;10(1):119–34. doi: 10.1007/s13300-018-0539-5. PMID: CN-01793652. Exclusion Code: X5.30483953
1726 Mita T, Katakami N, Shiraiwa T, . The effect of sitagliptin on the regression of carotid intima-media thickening in patients with type 2 diabetes mellitus: a post hoc analysis of the Sitagliptin Preventive Study of Intima-Media Thickness Evaluation. Int J Endocrinol. 2017;2017(no pagination)doi: 10.1155/2017/1925305. PMID: CN-01327973. Exclusion Code: X2.
1727 Mita T, Katakami N, Shiraiwa T, . Rationale, design, and baseline characteristics of a clinical trial for prevention of atherosclerosis in patients with insulin-treated type 2 diabetes mellitus using DPP-4 inhibitor: the Sitagliptin Preventive study of Intima-media thickness Evaluation (SPIKE). Diabetology & metabolic syndrome. 2014;6(1)doi: 10.1186/1758-5996-6-35. PMID: CN-00989457. Exclusion Code: X2.
1728 Mita T, Katakami N, Shiraiwa T, . Sitagliptin attenuates the progression of carotid intima-media thickening in insulin-treated patients with type 2 diabetes: The Sitagliptin Preventive Study of Intima-Media Thickness Evaluation (SPIKE): A Randomized Controlled Trial. Diabetes Care. 2016 Mar;39(3):455–64. doi: 10.2337/dc15-2145. PMID: 26822324. Exclusion Code: X2.26822324
1729 Mita T, Katakami N, Yoshii H, . Alogliptin, a dipeptidyl peptidase 4 inhibitor, prevents the progression of carotid atherosclerosis in patients with type 2 diabetes: The Study of Preventive Effects of Alogliptin on Diabetic Atherosclerosis (SPEAD-A). Diabetes Care. 2016 Jan;39(1):139–48. doi: 10.2337/dc15-0781. PMID: 26628419. Exclusion Code: X2.26628419
1730 Miyagawa J, Odawara M, Takamura T, . Once-weekly glucagon-like peptide-1 receptor agonist dulaglutide is non-inferior to once-daily liraglutide and superior to placebo in Japanese patients with type 2 diabetes: a 26-week randomized phase III study. Diabetes Obes Metab. 2015 Oct;17(10):974–83. doi: 10.1111/dom.12534. PMID: 26179187. Exclusion Code: X2.26179187
1731 Miyamoto T, Fukuda K, Oshima Y, . Non-locomotive physical activity intervention using a tri-axial accelerometer reduces sedentary time in type 2 diabetes. Phys Sportsmed. 2017 Sep;45(3):245–51. doi: 10.1080/00913847.2017.1350084. PMID: 28664755. Exclusion Code: X6.28664755
1732 Mizote A, Yamada M, Yoshizane C, . Daily intake of trehalose is effective in the prevention of lifestyle-related diseases in individuals with risk factors for metabolic syndrome. J Nutr Sci Vitaminol (Tokyo). 2016;62(6):380–7. doi: 10.3177/jnsv.62.380. PMID: 28202842. Exclusion Code: X4.28202842
1733 Mizushige T, Kobori H, Nishijima Y, . Urinary angiotensinogen could be a prognostic marker of renoprotective effects of alogliptin in patients with type 2 diabetes. J Diabetes Res. 2015;2015:517472. doi: 10.1155/2015/517472. PMID: 26380312. Exclusion Code: X2.26380312
1734 Mobasseri M, Yavari A, Najafipoor F, . Effect of a long-term regular physical activity on hypertension and body mass index in type 2 diabetes patients. J Sports Med Phys Fitness. 2015 Jan–Feb;55(1–2):84–90. PMID: 24947808. Exclusion Code: X7.24947808
1735 Modesti PA, Galanti G, Cala P, . Lifestyle interventions in preventing new type 2 diabetes in Asian populations. Intern Emerg Med. 2016 Apr;11(3):375–84. doi: 10.1007/s11739-015-1325-2. PMID: 26475162. Exclusion Code: X8.26475162
1736 Moe B, Midthjell K, Nilsen TI. Glycaemic control in people with diabetes influences the beneficial role of physical activity on cardiovascular mortality. Prospective data from the HUNT Study, Norway. Prim Care Diabetes. 2015 Dec;9(6):451–7. doi: 10.1016/j.pcd.2015.04.007. PMID: 26001311. Exclusion Code: X4.26001311
1737 Moelands SVL, Lucassen P, Akkermans RP, . Alpha-glucosidase inhibitors for prevention or delay of type 2 diabetes mellitus and its associated complications in people at increased risk of developing type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2018(12)doi: 10.1002/14651858.CD005061.pub3. PMID: CD005061. Exclusion Code: X8.
1738 Mohammadi S, Arefhosseini S, Jafarabadi M, . Regulation of serum lipid profile, glucose, insulin, and adiponectin in obese diabetic women under diet therapy: a randomized clinical controlled study. Iranian red crescent medical journal. 2017;19(1) (no pagination)doi: 10.5812/ircmj.36369. PMID: CN-01329926. Exclusion Code: X2.
1739 Mohammadi S, Ebrahimi-Mameghani M, Arefhosseini S, . Dietary regulation of miR-33b and miR-29a in relationship to metabolic biomarkers of glucose and lipids in obese diabetic women: a randomized clinical controlled study. Iranian red crescent medical journal. 2017;19(1) (no pagination)doi: 10.5812/ircmj.37521. PMID: CN-01329925. Exclusion Code: X2.
1740 Mohammed R. Glycemic control with team approach in subrural diabetic patients. Int J Diabetes Dev Ctries. 2018;38:S158–S9. doi: 10.1007/s13410-018-0702-6. PMID: CN-01773698. Exclusion Code: X8.
1741 Moin T, Damschroder LJ, AuYoung M, . Diabetes prevention program translation in the Veterans Health Administration. Am J Prev Med. 2017 Jul;53(1):70–7. doi: 10.1016/j.amepre.2016.11.009. PMID: 28094135. Exclusion Code: X8.28094135
1742 Moin T, Turk N, Mangione C, . Shared decision-making for diabetes prevention-one-year results from the prediabetes informed decision and education (PRIDE) study. Diabetes. 2018;67:A45-. PMID: CN-01631447. Exclusion Code: X10.
1743 Moller G, Andersen HK, Snorgaard O. A systematic review and meta-analysis of nutrition therapy compared with dietary advice in patients with type 2 diabetes. Am J Clin Nutr. 2017 Dec;106(6):1394–400. doi: 10.3945/ajcn.116.139626. PMID: 29092883. Exclusion Code: X8.29092883
1744 Moller G, Andersen J, Ritz C, . Higher protein intake is not associated with decreased kidney function in pre-diabetic older adults following a one-year intervention-a preview sub-study. Nutrients. 2018;10(1) (no pagination)doi: 10.3390/nu10010054. PMID: CN-01449549. Exclusion Code: X5.
1745 Molugulu N, Yee LS, Ye YT, . Systematic review of metformin monotherapy and dual therapy with sodium glucose co-transporter 2 inhibitor (SGLT-2) in treatment of type 2 diabetes mellitus. Diabetes Res Clin Pract. 2017 Oct;132:157–68. doi: 10.1016/j.diabres.2017.07.025. PMID: 28797524. Exclusion Code: X8.28797524
1746 Monami M, Dicembrini I, Mannucci E. Thiazolidinediones and cancer: results of a meta-analysis of randomized clinical trials. Acta Diabetol. 2014 Feb;51(1):91–101. doi: 10.1007/s00592-013-0504-8. PMID: 23851465. Exclusion Code: X8.23851465
1747 Monami M, Ragghianti B, Zannoni S, . Identification of predictors of response to basal insulin and DPP4 inhibitors in patients with type 2 diabetes failing to other therapies. Acta Diabetol. 2016 Feb;53(1):35–40. doi: 10.1007/s00592-015-0732-1. PMID: 25805649. Exclusion Code: X2.25805649
1748 Moncrieft AE, Llabre MM, McCalla JR, . Effects of a multicomponent life-style intervention on weight, glycemic control, depressive symptoms, and renal function in low-income, minority patients with type 2 diabetes: results of the community approach to lifestyle modification for diabetes randomized controlled trial. Psychosom Med. 2016 Sep;78(7):851–60. doi: 10.1097/psy.0000000000000348. PMID: 27359176. Exclusion Code: X2.27359176
1749 Monlezun D, Kasprowicz E, Tosh K, . Medical school-based teaching kitchen improves HbA1c, blood pressure, and cholesterol for patients with type 2 diabetes: results from a novel randomized controlled trial. Diabetes Res Clin Pract. 2015;109(2):420–6. doi: 10.1016/j.diabres.2015.05.007. PMID: CN-01081599. Exclusion Code: X6.26002686
1750 Monnier L, Colette C, Wojtusciszyn A, . Toward defining the threshold between low and high glucose variability in diabetes. Diabetes Care. 2017 Jul;40(7):832–8. doi: 10.2337/dc16-1769. PMID: 28039172. Exclusion Code: X8.28039172
1751 Moody A, Cowley G, Ng Fat L, . Social inequalities in prevalence of diagnosed and undiagnosed diabetes and impaired glucose regulation in participants in the Health Surveys for England series. BMJ Open. 2016 Feb 8;6(2):e010155. doi: 10.1136/bmjopen-2015-010155. PMID: 26857106. Exclusion Code: X8.26857106
1752 Moon J, Ha K, Yoon J, . The effect of glargine versus glimepiride on pancreatic ?-cell function in patients with type 2 diabetes uncontrolled on metformin monotherapy: open-label, randomized, controlled study. Acta Diabetol. 2014;51(2):277–85. doi: 10.1007/s00592-013-0553-z. PMID: CN-01118958. Exclusion Code: X2.24445656
1753 Moore SM, Hardie EA, Hackworth NJ, . Can the onset of type 2 diabetes be delayed by a group-based lifestyle intervention? A randomised control trial. Psychol Health. 2011 Apr;26(4):485–99. doi: 10.1080/08870440903548749. PMID: 20945253. Exclusion Code: X11.20945253
1754 Mor A, Petersen I, Sorensen HT, . Metformin and other glucose-lowering drug initiation and rates of community-based antibiotic use and hospital-treated infections in patients with type 2 diabetes: a Danish nationwide population-based cohort study. BMJ Open. 2016 Aug 19;6(8):e011523. doi: 10.1136/bmjopen-2016-011523. PMID: 27543589. Exclusion Code: X5.27543589
1755 Moran LJ, Hutchison SK, Norman RJ, . Lifestyle changes in women with polycystic ovary syndrome. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2011. Exclusion Code: X8.
1756 Mora-Rodriguez R, Ortega JF, Ramirez-Jimenez M, . Insulin sensitivity improvement with exercise training is mediated by body weight loss in subjects with metabolic syndrome. Diabetes & metabolism. 2019doi: 10.1016/j.diabet.2019.05.004. PMID: CN-01963599. Exclusion Code: X5.
1757 Morgan CL, Inzucchi SE, Puelles J, . Impact of treatment with pioglitazone on stroke outcomes: A real-world database analysis. Diabetes Obes Metab. 2018 Sep;20(9):2140–7. doi: 10.1111/dom.13344. PMID: 29732718. Exclusion Code: X8.29732718
1758 Morgan EH, Schoonees A, Faure M, . Caregiver involvement in interventions for improving children’s dietary intake and physical activity behaviors. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
1759 Mori H, Okada Y, Tanaka Y. The effects of pioglitazone on bone formation and resorption markers in type 2 diabetes mellitus. Intern Med. 2017;56(11):1301–6. doi: 10.2169/internalmedicine.56.8096. PMID: 28566590. Exclusion Code: X5.28566590
1760 Morrison S, Colberg S, Parson H, . Exercise improves gait, reaction time and postural stability in older adults with type 2 diabetes and neuropathy. J Diabetes Complications. 2014;28(5):715–22. doi: 10.1016/j.jdiacomp.2014.04.007. PMID: CN-01115880. Exclusion Code: X2.24929798
1761 Morton J, Shah S, Wolfe B, . Effect of vagal nerve blockade on moderate obesity with an obesity-related comorbid condition: the ReCharge Study. Obes Surg. 2016;26(5):983–9. doi: 10.1007/s11695-016-2143-y. PMID: CN-01139863. Exclusion Code: X4.27048437
1762 Mosalman Haghighi M, Mavros Y, Fiatarone Singh MA. The Effects of Structured Exercise or Lifestyle Behavior Interventions on Long-Term Physical Activity Level and Health Outcomes in Individuals With Type 2 Diabetes: A Systematic Review, Meta-Analysis, and Meta-Regression. J Phys Act Health. 2018 Sep 1;15(9):697–707. doi: 10.1123/jpah.2017-0589. PMID: 29741425. Exclusion Code: X8.29741425
1763 Mosdøl A, Lidal IB, Straumann GH, . Targeted mass media interventions promoting healthy behaviours to reduce risk of non-communicable diseases in adult, ethnic minorities. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
1764 Mosenzon O, Leibowitz G, Bhatt DL, . Effect of saxagliptin on renal outcomes in the SAVOR-TIMI 53 Trial. Diabetes Care. 2017 Jan;40(1):69–76. doi: 10.2337/dc16-0621. PMID: 27797925. Exclusion Code: X2.27797925
1765 Mosenzon O, Wei C, Davidson J, . Incidence of fractures in patients with type 2 diabetes in the SAVOR-TIMI 53 Trial. Diabetes Care. 2015 Nov;38(11):2142–50. doi: 10.2337/dc15-1068. PMID: 26358285. Exclusion Code: X2.26358285
1766 Moses RG, Kalra S, Brook D, . A randomized controlled trial of the efficacy and safety of saxagliptin as add-on therapy in patients with type 2 diabetes and inadequate glycaemic control on metformin plus a sulphonylurea. Diabetes Obes Metab. 2014 May;16(5):443–50. doi: 10.1111/dom.12234. PMID: 24205943. Exclusion Code: X2.24205943
1767 Moses RG, Round E, Shentu Y, . A randomized clinical trial evaluating the safety and efficacy of sitagliptin added to the combination of sulfonylurea and metformin in patients with type 2 diabetes mellitus and inadequate glycemic control. J Diabetes. 2016 Sep;8(5):701–11. doi: 10.1111/1753-0407.12351. PMID: 26625270. Exclusion Code: X2.26625270
1768 Moshki M, Dehnoalian A, Alami A. Effect of precede-proceed model on preventive behaviors for type 2 diabetes mellitus in high-risk individuals. Clin Nurs Res. 2017 Apr;26(2):241–53. doi: 10.1177/1054773815621026. PMID: 26749209. Exclusion Code: X6.26749209
1769 Mostaza JM, Lahoz C, Salinero-Fort MA, . Carotid atherosclerosis severity in relation to glycemic status: a cross-sectional population study. Atherosclerosis. 2015 Oct;242(2):377–82. doi: 10.1016/j.atherosclerosis.2015.07.028. PMID: 26275375. Exclusion Code: X8.26275375
1770 Motiani K, Collado M, Eskelinen J-J, . Effects of short-term exercise training on intestinal metabolism and gut microbiota in subjects with insulin resistance. Diabetologia. Conference: 53rd annual meeting of the european association for the study of diabetes, EASD 2017. Portugal. 2017;60(1 Supplement 1):S48–s9. doi: 10.1007/s00125-017-4350-z. PMID: CN-01419107. Exclusion Code: X5.
1771 Mottalib A, Salsberg V, Mohd-Yusof BN, . Effects of nutrition therapy on HbA1c and cardiovascular disease risk factors in overweight and obese patients with type 2 diabetes. Nutr J. 2018 Apr 7;17(1):42. doi: 10.1186/s12937-018-0351-0. PMID: 29626933. Exclusion Code: X2.29626933
1772 Moutray T, Evans JR, Lois N, . Different lasers and techniques for proliferative diabetic retinopathy. Cochrane Database of Systematic Reviews. 2018(3)doi: 10.1002/14651858.CD012314.pub2. PMID: CD012314. Exclusion Code: X8.
1773 Mraz M, Chytilova E, Klouckova J, . Cardiovascular effects of 3 months of treatment with GLP-1 receptor agonist exenatide and DPP-4 inhibitor linagliptin: the safeguard trial. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A284. doi: 10.2337/db16-861-1374. PMID: CN-01449968. Exclusion Code: X5.
1774 Mraz M, Klouckova J, Kavalkova P, . Gastrointestinal and renal effects of 3 months of treatment with GLP-1 receptor agonist exenatide and DPP-4 inhibitor linagliptin: the safeguard trial. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A284. doi: 10.2337/db16-861-1374. PMID: CN-01449972. Exclusion Code: X8.
1775 Mu Y, Pan C, Fan B, . Efficacy and safety of linagliptin/metformin single-pill combination as initial therapy in drug-naive Asian patients with type 2 diabetes. Diabetes Res Clin Pract. 2017 Feb;124:48–56. doi: 10.1016/j.diabres.2016.11.026. PMID: 28088030. Exclusion Code: X5.28088030
1776 Muchiri JW, Gericke GJ, Rheeder P. Effect of a nutrition education programme on clinical status and dietary behaviours of adults with type 2 diabetes in a resource-limited setting in South Africa: a randomised controlled trial. Public Health Nutr. 2016 Jan;19(1):142–55. doi: 10.1017/s1368980015000956. PMID: 25872641. Exclusion Code: X7.25872641
1777 Mudaliar S, Henry RR, Boden G, . Changes in insulin sensitivity and insulin secretion with the sodium glucose cotransporter 2 inhibitor dapagliflozin. Diabetes Technol Ther. 2014 Mar;16(3):137–44. doi: 10.1089/dia.2013.0167. PMID: 24237386. Exclusion Code: X2.24237386
1778 Mudaliar U, Zabetian A, Goodman M, . Cardiometabolic risk factor changes observed in diabetes prevention programs in US settings: a systematic review and meta-analysis. PLoS Med. 2016 Jul;13(7):e1002095. doi: 10.1371/journal.pmed.1002095. PMID: 27459705. Exclusion Code: X8.27459705
1779 Muilwijk M, Nicolaou M, Qureshi SA, . Dietary and physical activity recommendations to prevent type 2 diabetes in South Asian adults: A systematic review. PLoS One. 2018;13(7):e0200681. doi: 10.1371/journal.pone.0200681. PMID: 30011314. Exclusion Code: X8.30011314
1780 Muilwijk M, Stronks K, Qureshi SA, . Dietary and physical activity strategies to prevent type 2 diabetes in South Asian adults: protocol for a systematic review. BMJ Open. 2017 Jul 2;7(6):e012783. doi: 10.1136/bmjopen-2016-012783. PMID: 28674123. Exclusion Code: X8.28674123
1781 Muktabhant B, Lawrie TA, Lumbiganon P, . Diet or exercise, or both, for preventing excessive weight gain in pregnancy. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
1782 Muller I, Rowsell A, Stuart B, . Effects on engagement and health literacy outcomes of web-based materials promoting physical activity in people with diabetes: an international randomized trial. J Med Internet Res. 2017 Jan 23;19(1):e21. doi: 10.2196/jmir.6601. PMID: 28115299. Exclusion Code: X6.28115299
1783 Muller N, Khunti K, Kuss O, . Is there evidence of potential overtreatment of glycaemia in elderly people with type 2 diabetes? Data from the GUIDANCE study. Acta Diabetol. 2017 Feb;54(2):209–14. doi: 10.1007/s00592-016-0939-9. PMID: 27837286. Exclusion Code: X2.27837286
1784 Muller N, Lehmann T, Gerste B, . Increase in the incidence of severe hypoglycaemia in people with Type 2 diabetes in spite of new drugs: analysis based on health insurance data from Germany. Diabet Med. 2017 Sep;34(9):1212–8. doi: 10.1111/dme.13397. PMID: 28586530. Exclusion Code: X8.28586530
1785 Munshi MN, Slyne C, Segal AR, . Liberating A1C goals in older adults may not protect against the risk of hypoglycemia. J Diabetes Complications. 2017 Jul;31(7):1197–9. doi: 10.1016/j.jdiacomp.2017.02.014. PMID: 28343792. Exclusion Code: X2.28343792
1786 Murphy A, Biringanine M, Roberts B, . Diabetes care in a complex humanitarian emergency setting: a qualitative evaluation. BMC Health Serv Res. 2017 Jun 23;17(1):431. doi: 10.1186/s12913-017-2362-5. PMID: 28645279. Exclusion Code: X8.28645279
1787 Murphy ML, Lubans DR, Cohen KE, . Preliminary efficacy and feasibility of referral to exercise specialists, psychologists and provision of a technology-based behavior change support package to promote physical activity in school teachers ‘at risk’ of, or diagnosed with, type 2 diabetes: the ‘SMART Health’ Pilot Study Protocol. Contemp Clin Trials. 2019;78:53–62. doi: 10.1016/j.cct.2019.01.007. PMID: CN-01788359. Exclusion Code: X7.30639752
1788 Muscelli E, Astiarraga B, Barsotti E, . Metabolic consequences of acute and chronic empagliflozin administration in treatment-naive and metformin pretreated patients with type 2 diabetes. Diabetologia. 2016 Apr;59(4):700–8. doi: 10.1007/s00125-015-3845-8. PMID: 26704626. Exclusion Code: X6.26704626
1789 Muscelli E, Frascerra S, Casolaro A, . The amino acid response to a mixed meal in patients with type 2 diabetes: effect of sitagliptin treatment. Diabetes Obes Metab. 2014 Nov;16(11):1140–7. doi: 10.1111/dom.12350. PMID: 25040945. Exclusion Code: X4.25040945
1790 Musini VM, Gueyffier F, Puil L, . Pharmacotherapy for hypertension in adults aged 18 to 59 years. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
1791 Musini VM, Lawrence KA, Fortin PM, . Blood pressure lowering efficacy of renin inhibitors for primary hypertension. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
1792 Musini VM, Tejani AM, Bassett K, . Pharmacotherapy for hypertension in adults 60 years or older. Cochrane Database of Systematic Reviews. 2019(6)doi: 10.1002/14651858.CD000028.pub3. PMID: CD000028. Exclusion Code: X8.
1793 Naganjani C, Susmitha V. Comparative study of effects of combination of metformin + glimepiride vs metformin + glimepiride + pioglitazone in type 2 diabetes mellitus patients. International journal of pharma and bio sciences. 2014;5(1):P212–p8. PMID: CN-01001169. Exclusion Code: X5.
1794 Nah EH, Chu J, Kim S, . Efficacy of lifestyle interventions in the reversion to normoglycemia in Korean prediabetics: One-year results from a randomised controlled trial. Prim Care Diabetes. 2019 Jun;13(3):212–20. doi: 10.1016/j.pcd.2018.11.017. PMID: 30583933. Exclusion Code: X6.30583933
1795 Nahon KJ, Doornink F, Straat ME, . Effect of sitagliptin on energy metabolism and brown adipose tissue in overweight individuals with prediabetes: a randomised placebo-controlled trial. Diabetologia. 2018 Nov;61(11):2386–97. doi: 10.1007/s00125-018-4716-x. PMID: 30145664. Exclusion Code: X6.30145664
1796 Nakamura H, Arakawa K, Itakura H, . Primary prevention of cardiovascular disease with pravastatin in Japan (MEGA Study): a prospective randomised controlled trial. Lancet. 2006 Sep 30;368(9542):1155–63. doi: 10.1016/S0140-6736(06)69472-5. PMID: 17011942. Exclusion Code: X2.17011942
1797 Nakamura K, Oe H, Kihara H, . DPP-4 inhibitor and alpha-glucosidase inhibitor equally improve endothelial function in patients with type 2 diabetes: EDGE study. Cardiovasc Diabetol. 2014 Jul 30;13:110. doi: 10.1186/s12933-014-0110-2. PMID: 25074318. Exclusion Code: X5.25074318
1798 Nakanekar A, Kohli K, Tatke P. Ayurvedic polyherbal combination (PDBT) for prediabetes: a randomized double blind placebo controlled study. J Ayurveda Integr Med. 2019doi: 10.1016/j.jaim.2018.05.004. PMID: CN-01793844. Exclusion Code: X4.
1799 Namekata T, Shirai K, Tanabe N, . Estimating the extent of subclinical arteriosclerosis of persons with prediabetes and diabetes mellitus among Japanese urban workers and their families: a cross-sectional study. BMC Cardiovasc Disord. 2016 Feb 24;16:52. doi: 10.1186/s12872-016-0230-6. PMID: 26911293. Exclusion Code: X8.26911293
1800 Nanditha A, Snehalatha C, Raghavan A, . The post-trial analysis of the Indian SMS diabetes prevention study shows persistent beneficial effects of lifestyle intervention. Diabetes Res Clin Pract. 2018 Aug;142:213–21. doi: 10.1016/j.diabres.2018.05.042. PMID: 29859274. Exclusion Code: X8.29859274
1801 Nanditha A, Snehalatha C, Ram J, . Impact of lifestyle intervention in primary prevention of Type 2 diabetes did not differ by baseline age and BMI among Asian-Indian people with impaired glucose tolerance. Diabet Med. 2016 Dec;33(12):1700–4. doi: 10.1111/dme.13071. PMID: 26773871. Exclusion Code: X8.26773871
1802 Nandy D, Johnson C, Basu R, . The effect of liraglutide on endothelial function in patients with type 2 diabetes. Diab Vasc Dis Res. 2014 Nov;11(6):419–30. doi: 10.1177/1479164114547358. PMID: 25212693. Exclusion Code: X2.25212693
1803 Nansseu JR, Bigna JJ, Kaze AD, . Rates and drivers of progression to pre-diabetes and diabetes mellitus among HIV-infected adults on antiretroviral therapy: a global systematic review and meta-analysis protocol. BMJ Open. 2016 Sep 15;6(9):e012852. doi: 10.1136/bmjopen-2016-012852. PMID: 27633645. Exclusion Code: X8.27633645
1804 Naruse R, Hori K, Terasawa T, . Alterations of plant sterols, lathosterol, oxidative stress and inflammatory markers after the combination therapy of ezetimibe and statin drugs in type 2 diabetic patients. Obes Res Clin Pract. 2015 Jan–Feb;9(1):67–74. doi: 10.1016/j.orcp.2014.02.001. PMID: 25660177. Exclusion Code: X6.25660177
1805 Nauck M, Araki A, Hehnke U, . Risk of hypoglycaemia in people aged >/=65 years receiving linagliptin: pooled data from 1489 individuals with type 2 diabetes mellitus. Int J Clin Pract. 2018 Oct;72(10):e13240. doi: 10.1111/ijcp.13240. PMID: 30216648. Exclusion Code: X8.30216648
1806 Nauck M, Kind J, Köthe L, . Quantification of the contribution of GLP-1 to mediating insulinotropic effects of DPP-4 inhibition with vildagliptin in healthy subjects and patients with type 2 diabetes using exendin as a GLP-1 receptor antagonist. Diabetes. 2016;65(8):2440–7. doi: 10.2337/db16-0107. PMID: CN-01379828. Exclusion Code: X2.27207543
1807 Nauck MA, Del Prato S, Duran-Garcia S, . Durability of glycaemic efficacy over 2 years with dapagliflozin versus glipizide as add-on therapies in patients whose type 2 diabetes mellitus is inadequately controlled with metformin. Diabetes Obes Metab. 2014 Nov;16(11):1111–20. doi: 10.1111/dom.12327. PMID: 24919526. Exclusion Code: X5.24919526
1808 Nauck MA, Frossard JL, Barkin JS, . Assessment of pancreas safety in the development program of once-weekly GLP-1 receptor agonist dulaglutide. Diabetes Care. 2017 May;40(5):647–54. doi: 10.2337/dc16-0984. PMID: 28283565. Exclusion Code: X8.28283565
1809 Nauck MA, Jensen TJ, Rosenkilde C, . Neoplasms Reported With Liraglutide or Placebo in People With Type 2 Diabetes: Results From the LEADER Randomized Trial. Diabetes Care. 2018 Aug;41(8):1663–71. doi: 10.2337/dc17-1825. PMID: 29898902. Exclusion Code: X2.29898902
1810 Nauck MA, Kahle M, Baranov O, . Addition of a dipeptidyl peptidase-4 inhibitor, sitagliptin, to ongoing therapy with the glucagon-like peptide-1 receptor agonist liraglutide: A randomized controlled trial in patients with type 2 diabetes. Diabetes Obes Metab. 2017 Feb;19(2):200–7. doi: 10.1111/dom.12802. PMID: 27709794. Exclusion Code: X2.27709794
1811 Nauck MA, Petrie JR, Sesti G, . A phase 2, randomized, dose-finding study of the novel once-weekly human GLP-1 analog, semaglutide, compared with placebo and open-label liraglutide in patients with type 2 diabetes. Diabetes Care. 2016 Feb;39(2):231–41. doi: 10.2337/dc15-0165. PMID: 26358288. Exclusion Code: X2.26358288
1812 Nauck MA, Stewart MW, Perkins C, . Efficacy and safety of once-weekly GLP-1 receptor agonist albiglutide (HARMONY 2): 52 week primary endpoint results from a randomised, placebo-controlled trial in patients with type 2 diabetes mellitus inadequately controlled with diet and exercise. Diabetologia. 2016 Feb;59(2):266–74. doi: 10.1007/s00125-015-3795-1. PMID: 26577795. Exclusion Code: X2.26577795
1813 Naude CE, Visser ME, Nguyen KA, . Effects of total fat intake on bodyweight in children. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2018. Exclusion Code: X8.
1814 Neeland IJ, McGuire DK, Chilton R, . Empagliflozin reduces body weight and indices of adipose distribution in patients with type 2 diabetes mellitus. Diab Vasc Dis Res. 2016 Mar;13(2):119–26. doi: 10.1177/1479164115616901. PMID: 26873905. Exclusion Code: X2.26873905
1815 Neergaard-Petersen S, Hvas AM, Grove EL, . The influence of haemoglobin A1c levels on platelet aggregation and platelet turnover in patients with coronary artery disease treated with aspirin. PLoS One. 2015;10(7):e0132629. doi: 10.1371/journal.pone.0132629. PMID: 26148094. Exclusion Code: X2.26148094
1816 Nelson K, Drain N, Robinson J, . Peer Support for Achieving Independence in Diabetes (Peer-AID): design, methods and baseline characteristics of a randomized controlled trial of community health worker assisted diabetes self-management support. Contemp Clin Trials. 2014 Jul;38(2):361–9. doi: 10.1016/j.cct.2014.06.011. PMID: 24956324. Exclusion Code: X6.24956324
1817 Nelson LA, Mulvaney SA, Gebretsadik T, . The MEssaging for Diabetes (MED) intervention improves short-term medication adherence among low-income adults with type 2 diabetes. J Behav Med. 2016 Dec;39(6):995–1000. doi: 10.1007/s10865-016-9774-2. PMID: 27488604. Exclusion Code: X6.27488604
1818 Netchessova TA, Shepelkevich AP, Gorbat TV. Efficacy of single-pill perindopril/indapamide in patients with hypertension and type 2 diabetes. High Blood Press Cardiovasc Prev. 2014 Mar;21(1):63–9. doi: 10.1007/s40292-013-0036-x. PMID: 24357222. Exclusion Code: X5.24357222
1819 Nguyen CT, Pham NM, Lee AH, . Prevalence of and risk factors for type 2 diabetes mellitus in vietnam: a systematic review. Asia Pac J Public Health. 2015 Sep;27(6):588–600. doi: 10.1177/1010539515595860. PMID: 26187848. Exclusion Code: X8.26187848
1820 Nguyen TPL, Edwards H, Do TND, . Effectiveness of a theory-based foot care education program (3STEPFUN) in improving foot self-care behaviours and foot risk factors for ulceration in people with type 2 diabetes. Diabetes Res Clin Pract. 2019 Jun;152:29–38. doi: 10.1016/j.diabres.2019.05.003. PMID: 31082445. Exclusion Code: X2.31082445
1821 Ni C-L, Tang Y-Z, Wang G, . Efficacy and safety of vildagliptin, sitagliptin, and linagliptin as add-on therapy in Chinese patients with T2DM Inadequately controlled with dual combination of insulin and traditional oral hypoglycemic agent. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A302. doi: 10.2337/db16-861-1374. PMID: CN-01449941. Exclusion Code: X5.
1822 Niafar M, Pourafkari L, Porhomayon J, . A systematic review of GLP-1 agonists on the metabolic syndrome in women with polycystic ovaries. Arch Gynecol Obstet. 2016 Mar;293(3):509–15. doi: 10.1007/s00404-015-3976-7. PMID: 26660657. Exclusion Code: X8.26660657
1823 Nicolle LE, Capuano G, Fung A, . Urinary tract infection in randomized phase III studies of canagliflozin, a sodium glucose co-transporter 2 inhibitor. Postgrad Med. 2014 Jan;126(1):7–17. doi: 10.3810/pgm.2014.01.2720. PMID: 24393747. Exclusion Code: X8.24393747
1824 Nield L, Summerbell CD, Hooper L, . Dietary advice for the prevention of type 2 diabetes mellitus in adults. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
1825 Nielsen AB, Jensen P, Gannik D, . Change in self-rated general health is associated with perceived illness burden: a 1-year follow up of patients newly diagnosed with type 2 diabetes. BMC Public Health. 2015 Apr 30;15:439. doi: 10.1186/s12889-015-1790-6. PMID: 25924731. Exclusion Code: X5.25924731
1826 Nieuwlaat R, Wilczynski N, Navarro T, . Interventions for enhancing medication adherence. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
1827 Ning G, Bandgar T, Hehnke U, . Efficacy and safety of linagliptin in 2681 Asian patients stratified by age, obesity, and renal function: A pooled analysis of randomized clinical trials. Adv Ther. 2017 Sep;34(9):2150–62. doi: 10.1007/s12325-017-0595-7. PMID: 28819835. Exclusion Code: X8.28819835
1828 Ning G, Wang W, Li L, . Vildagliptin as add-on therapy to insulin improves glycemic control without increasing risk of hypoglycemia in Asian, predominantly Chinese, patients with type 2 diabetes mellitus. J Diabetes. 2016 May;8(3):345–53. doi: 10.1111/1753-0407.12303. PMID: 25929739. Exclusion Code: X2.25929739
1829 Nino A, Okuda I, Wilson T, . Weekly GLP-1 agonist albiglutide monotherapy improves glycemic parameters in Japanese type 2 diabetes mellitus (T2DM) patients. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A266. doi: 10.2337/db16-861-1374. PMID: CN-01449889. Exclusion Code: X10.
1830 Nino A, Okuda I, Wilson T, . Weekly glucagon-like peptide-1 receptor agonist albiglutide as monotherapy improves glycemic parameters in Japanese patients with type 2 diabetes mellitus: a randomized, double-blind, placebo-controlled study. Journal of diabetes investigation. 2017;(no pagination)doi: 10.1111/jdi.12749. PMID: CN-01430358. Exclusion Code: X2.
1831 Nishimura A, Harashima S, Honda I, . Color record in self-monitoring of blood glucose improves glycemic control by better self-management. Diabetes Technol Ther. 2014;16(7):447–53. doi: 10.1089/dia.2013.0301. PMID: CN-01041202. Exclusion Code: X2.24506479
1832 Nishimura A, Usui S, Kumashiro N, . Efficacy and safety of repaglinide added to sitagliptin in Japanese patients with type 2 diabetes: A randomized 24-week open-label clinical trial. Endocr J. 2016 Dec 30;63(12):1087–98. doi: 10.1507/endocrj.EJ16-0291. PMID: 27647480. Exclusion Code: X2.27647480
1833 Niswender K, Piletic M, Andersen H, . Weight change upon once-daily initiation of insulin detemir with or without dietary intervention in overweight or obese insulin-naive individuals with type 2 diabetes: results from the DIET trial. Diabetes Obes Metab. 2014 Feb;16(2):186–92. doi: 10.1111/dom.12218. PMID: 24112375. Exclusion Code: X2.24112375
1834 Niswender K, Piletic M, Andersen H, . Weight change upon once-daily initiation of insulin detemir with or without dietary intervention in overweight or obese insulin-naïve individuals with type 2 diabetes: results from the DIET trial. Diabetes, obesity & metabolism. 2014;16(2):186–92. doi: 10.1111/dom.12218. PMID: CN-00959236. Exclusion Code: X2.
1835 Niu SW, Chang KT, Lin HY, . Decreased incidence of gout in diabetic patients using pioglitazone. Rheumatology (Oxford). 2018 Jan 1;57(1):92–9. doi: 10.1093/rheumatology/kex363. PMID: 29040733. Exclusion Code: X8.29040733
1836 Njerve IU, Akra S, Weiss TW, . A double-blinded randomized study investigating a possible anti-inflammatory effect of saxagliptin versus placebo as add-on therapy in patients with both type 2 diabetes and stable coronary artery disease. Mediators Inflamm. 2017;2017:5380638. doi: 10.1155/2017/5380638. PMID: 28596642. Exclusion Code: X2.28596642
1837 Njike V, Yarandi N, Petraro P, . Inclusion of walnut in the diets of adults at risk for type 2 diabetes and their dietary pattern changes: a randomized, controlled, crossover trial. Endocrine practice. Conference: 9th world congress on prevention of diabetes and its complications, WCPD. United states. 2016;22:15–6. PMID: CN-01364794. Exclusion Code: X6.
1838 Njike V, Yarandi N, Petraro P, . Inclusion of walnut in the diets of adults at risk for type 2 diabetes and their dietary pattern changes: a randomized, controlled, cross-over trial. BMJ open diabetes research and care. 2016;4(1) (no pagination)doi: 10.1136/bmjdrc-2016-000293. PMID: CN-01248876. Exclusion Code: X6.
1839 Noknoy S, Chamnan P, Anothaisintawee T, . Theory-based behavioural interventions for prediabetic state and people with diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
1840 Noll C, Kunach M, Frisch F, . Seven-day caloric and saturated fat restriction increases myocardial dietary fatty acid partitioning in impaired glucose-tolerant subjects. Diabetes. 2015 Nov;64(11):3690–9. doi: 10.2337/db15-0337. PMID: 26224886. Exclusion Code: X4.26224886
1841 Nomoto H, Miyoshi H, Sugawara H, . A randomized controlled trial comparing the effects of dapagliflozin and DPP-4 inhibitors on glucose variability and metabolic parameters in patients with type 2 diabetes mellitus on insulin UMIN000015033 UMIN. Diabetology & metabolic syndrome. 2017;9(1) (no pagination)doi: 10.1186/s13098-017-0255-8. PMID: CN-01393710. Exclusion Code: X2.
1842 Nomura S, Taniura T, Shouzu A, . Effects of sarpogrelate, eicosapentaenoic acid and pitavastatin on arterioslcerosis obliterans-related biomarkers in patients with type 2 diabetes (SAREPITASO study). Vasc Health Risk Manag. 2018;14:225–32. doi: 10.2147/vhrm.s171143. PMID: 30271161. Exclusion Code: X5.30271161
1843 Nor EA, Che SM, Ball P. The impact of home medication review in patients with type 2 diabetes mellitus living in rural areas of Kuantan, Malaysia. Value in health. 2014;17(3):A127. doi: 10.1016/j.jval.2014.03.736. PMID: CN-01010230. Exclusion Code: X2.
1844 Nordklint AK, Almdal TP, Vestergaard P, . The effect of metformin versus placebo in combination with insulin analogues on bone mineral density and trabecular bone score in patients with type 2 diabetes mellitus: a randomized placebo-controlled trial. Osteoporos Int. 2018 Nov;29(11):2517–26. doi: 10.1007/s00198-018-4637-z. PMID: 30027438. Exclusion Code: X2.30027438
1845 Norris S, Kansagara D, Bougatsos C, . Screening for type 2 diabetes mellitus: update of 2003 systematic evidence review for the U.S. Preventive Services Task Force (Structured abstract). Database of Abstracts of Reviews of Effects: Agency for Healthcare Research and Quality; 2008. Exclusion Code: X8.
1846 Norris SL, Zhang X, Avenell A, . Long-term non-pharmacological weight loss interventions for adults with prediabetes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2005. Exclusion Code: X8.
1847 North SL, Palmer GA. Outcome analysis of hemoglobin A1c, weight, and blood pressure in a VA diabetes education program. J Nutr Educ Behav. 2015 Jan–Feb;47(1):28–35. doi: 10.1016/j.jneb.2014.07.006. PMID: 25270973. Exclusion Code: X6.25270973
1848 Noureldein MH, Abd El-Razek RS, El-Hefnawy MH, . Fenofibrate reduces inflammation in obese patients with or without type 2 diabetes mellitus via sirtuin 1/fetuin A axis. Diabetes Res Clin Pract. 2015 Sep;109(3):513–20. doi: 10.1016/j.diabres.2015.05.043. PMID: 26105582. Exclusion Code: X5.26105582
1849 Novoa M, Baselga E, Beltran S, . Interventions for infantile haemangiomas of the skin. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2018. Exclusion Code: X8.
1850 Nowakowski PE. A meta-analysis of the diagnostic accuracy of the monofilament in detecting diabetic peripheral neuropathy (Structured abstract). Database of Abstracts of Reviews of Effects; 2008. Exclusion Code: X8.
1851 Nowotny B, Zahiragic L, Bierwagen A, . Low-energy diets differing in fibre, red meat and coffee intake equally improve insulin sensitivity in type 2 diabetes: a randomised feasibility trial. Diabetologia. 2015 Feb;58(2):255–64. doi: 10.1007/s00125-014-3457-8. PMID: 25425219. Exclusion Code: X6.25425219
1852 Nozue T, Fukui K, Takamura T, . Effects of alogliptin on fractional flow reserve evaluated by coronary computed tomography angiography in patients with type 2 diabetes: Rationale and design of the TRACT study. J Cardiol. 2017 Mar;69(3):518–22. doi: 10.1016/j.jjcc.2016.04.014. PMID: 27236239. Exclusion Code: X6.27236239
1853 Nunez DJ, Yao X, Lin J, . Glucose and lipid effects of the ileal apical sodium-dependent bile acid transporter inhibitor GSK2330672: double-blind randomized trials with type 2 diabetes subjects taking metformin. Diabetes Obes Metab. 2016 Jul;18(7):654–62. doi: 10.1111/dom.12656. PMID: 26939572. Exclusion Code: X8.26939572
1854 Nunez J, Bonanad C, Navarro JP, . Differential effect of glycosylated hemoglobin value and antidiabetic treatment on the risk of 30-day readmission following a hospitalization for acute heart failure. Rev Esp Cardiol (Engl Ed). 2015 Oct;68(10):852–60. doi: 10.1016/j.rec.2014.10.019. PMID: 25792287. Exclusion Code: X2.25792287
1855 Nyanzi R, Wamala R, Atuhaire LK. Diabetes and quality of life: a Ugandan perspective. J Diabetes Res. 2014;2014:402012. doi: 10.1155/2014/402012. PMID: 24724107. Exclusion Code: X8.24724107
1856 Nyberg ST, Fransson EI, Heikkila K, . Job strain as a risk factor for type 2 diabetes: a pooled analysis of 124,808 men and women. Diabetes Care. 2014 Aug;37(8):2268–75. doi: 10.2337/dc13-2936. PMID: 25061139. Exclusion Code: X8.25061139
1857 Nygaard H, Grindaker E, Ronnestad BR, . Long-term effects of daily postprandial physical activity on blood glucose: a randomized controlled trial. Appl Physiol Nutr Metab. 2017 Apr;42(4):430–7. doi: 10.1139/apnm-2016-0467. PMID: 28177728. Exclusion Code: X4.28177728
1858 O’Connor PJ, Narayan KM, Anderson R, . Effect of intensive versus standard blood pressure control on depression and health-related quality of life in type 2 diabetes: the ACCORD trial. Diabetes Care. 2012 Jul;35(7):1479–81. doi: 10.2337/dc11-1868. PMID: 22584134. Exclusion Code: X2.22584134
1859 Odawara M, Hamada I, Suzuki M. Efficacy and safety of vildagliptin as add-on to metformin in Japanese patients with type 2 diabetes mellitus. Diabetes therapy. 2014;5(1):169–81. doi: 10.1007/s13300-014-0059-x. PMID: CN-01068602. Exclusion Code: X2.24604395
1860 Odawara M, Miyagawa J, Iwamoto N, . Once-weekly glucagon-like peptide-1 receptor agonist dulaglutide significantly decreases glycated haemoglobin compared with once-daily liraglutide in Japanese patients with type 2 diabetes: 52 weeks of treatment in a randomized phase III study. Diabetes Obes Metab. 2016 Mar;18(3):249–57. doi: 10.1111/dom.12602. PMID: 26661514. Exclusion Code: X2.26661514
1861 Odawara M, Yoshiki M, Sano M, . Efficacy and safety of a single-pill combination of vildagliptin and metformin in Japanese patients with type 2 diabetes mellitus: A randomized, double-blind, placebo-controlled trial. Diabetes therapy. 2015;6(1):17–27. doi: 10.1007/s13300-015-0099-x. PMID: CN-01068798. Exclusion Code: X2.25691359
1862 Oddsson S. Effects of a gamified mobile application to support a lifestyle-change program in adults: a controlled pilot. Diabetes. 2017;66:A42-. PMID: CN-01724274. Exclusion Code: X8.
1863 Odgers-Jewell K, Ball LE, Kelly JT, . Effectiveness of group-based self-management education for individuals with Type 2 diabetes: a systematic review with meta-analyses and meta-regression. Diabet Med. 2017 Aug;34(8):1027–39. doi: 10.1111/dme.13340. PMID: 28226200. Exclusion Code: X8.28226200
1864 Odnoletkova I, Goderis G, Nobels F, . Optimizing diabetes control in people with Type 2 diabetes through nurse-led telecoaching. Diabet Med. 2016 Jun;33(6):777–85. doi: 10.1111/dme.13092. PMID: 26872105. Exclusion Code: X2.26872105
1865 O’Donoghue G, Kennedy A, Andersen G, . An evaluation of the DEXLIFE ‘self-selected’ lifestyle intervention aimed at improving insulin sensitivity in people at risk of developing type 2 diabetes: study protocol for a randomised controlled trial. Trials. 2015;16:529. doi: 10.1186/s13063-015-1042-1. PMID: CN-01179843. Exclusion Code: X6.26581687
1866 Oellgaard J, Gaede P, Rossing P, . Long-term reduction in coronary artery disease and stroke with 7,8 years of intensified, multifactorial intervention in patients with type 2 diabetes and microalbuminuria in the steno-2 study. Circulation. Conference: american heart association’s 2016 scientific sessions and resuscitation science symposium. United states. 2016;134(Supplement 1) (no pagination)PMID: CN-01429796. Exclusion Code: X10.
1867 Ofstad A, Johansen O, Gullestad L, . Neutral impact on systolic and diastolic cardiac function of 2 years of intensified multi-intervention in type 2 diabetes: the randomized controlled Asker and Bærum Cardiovascular Diabetes (ABCD) study. Am Heart J. 2014;168(3):280–8.e2. doi: 10.1016/j.ahj.2014.03.026. PMID: CN-01002039. Exclusion Code: X2.25173538
1868 Ofstad A, Ulimoen G, Orvik E, . Long-term follow-up of a hospital-based, multi-intervention programme in type 2 diabetes mellitus: impact on cardiovascular events and death. Journal of international medical research. 2017;45(5):1535–52. doi: 10.1177/0300060517707674. PMID: CN-01421153. Exclusion Code: X2.
1869 Ofstad AP, Johansen OE, Gullestad L, . Neutral impact on systolic and diastolic cardiac function of 2 years of intensified multi-intervention in type 2 diabetes: the randomized controlled Asker and Baerum Cardiovascular Diabetes (ABCD) study. Am Heart J. 2014 Sep;168(3):280–8.e2. doi: 10.1016/j.ahj.2014.03.026. PMID: 25173538. Exclusion Code: X6.25173538
1870 Ogawa H, Nakayama M, Morimoto T, . Low-dose aspirin for primary prevention of atherosclerotic events in patients with type 2 diabetes: a randomized controlled trial. JAMA. 2008 Nov 12;300(18):2134–41. doi: 10.1001/jama.2008.623. PMID: 18997198. Exclusion Code: X2.18997198
1871 Ojala R, Motiani K, Eskelinen J, . Two weeks of exercise training improves bone marrow metabolism. Diabetologia. Conference: 53rd annual meeting of the european association for the study of diabetes, EASD 2017. Portugal. 2017;60(1 Supplement 1):S49–s50. doi: 10.1007/s00125-017-4350-z. PMID: CN-01419093. Exclusion Code: X2.
1872 Ojo O. The use of exenatide in managing markers of cardiovascular risk in patients with type 2 diabetes: a systematic review. Int J Environ Res Public Health. 2016 Sep 23;13(10)doi: 10.3390/ijerph13100941. PMID: 27669277. Exclusion Code: X8.27669277
1873 Okada R, Tsushita K, Wakai K, . Lower risk of progression from prediabetes to diabetes with health checkup with lifestyle education: Japan Ningen Dock study. Nutr Metab Cardiovasc Dis. 2017 Aug;27(8):679–87. doi: 10.1016/j.numecd.2017.06.004. PMID: 28735816. Exclusion Code: X6.28735816
1874 Okada S, Morimoto T, Ogawa H, . Differential effect of low-dose aspirin for primary prevention of atherosclerotic events in diabetes management: a subanalysis of the JPAD trial. Diabetes Care. 2011 Jun;34(6):1277–83. doi: 10.2337/dc10-2451. PMID: 21515838. Exclusion Code: X2.21515838
1875 Okada S, Morimoto T, Ogawa H, . Is long-term low-dose aspirin therapy associated with renal dysfunction in patients with type 2 diabetes? JPAD2 Cohort Study. PLoS One. 2016;11(1):e0147635. doi: 10.1371/journal.pone.0147635. PMID: 26808136. Exclusion Code: X2.26808136
1876 Okajima F, Emoto N, Kato K, . Effect of glycemic control on chylomicron metabolism and correlation between postprandial metabolism of plasma glucose and chylomicron in patients with type 2 diabetes treated with basal-bolus insulin therapy with or without vildagliptin. J Atheroscler Thromb. 2017 Feb 1;24(2):157–68. doi: 10.5551/jat.32409. PMID: 27397060. Exclusion Code: X2.27397060
1877 Okanovic A, Prnjavorac B, Jusufovic E, . Alpha-lipoic acid reduces body weight and regulates triglycerides in obese patients with diabetes mellitus. Med Glas (Zenica). 2015 Aug;12(2):122–7. doi: 10.17392/798-15. PMID: 26276648. Exclusion Code: X2.26276648
1878 Okerson T, Yan P, Stonehouse A, . Effects of exenatide on systolic blood pressure in subjects with type 2 diabetes. Am J Hypertens. 2010;23(3):334–9. doi: 10.1038/ajh.2009.245. PMID: CN-01763814. Exclusion Code: X8.20019672
1879 Olofsson C, Discacciati A, Akesson A, . Changes in fruit, vegetable and juice consumption after the diagnosis of type 2 diabetes: a prospective study in men. Br J Nutr. 2017 Mar;117(5):712–9. doi: 10.1017/s0007114516002257. PMID: 27409648. Exclusion Code: X6.27409648
1880 Olson EA, McAuley E. Impact of a brief intervention on self-regulation, self-efficacy and physical activity in older adults with type 2 diabetes. J Behav Med. 2015 Dec;38(6):886–98. doi: 10.1007/s10865-015-9660-3. PMID: 26162648. Exclusion Code: X6.26162648
1881 Omran D, Majumdar SR, Johnson JA, . Pharmacists on primary care teams: Effect on antihypertensive medication management in patients with type 2 diabetes. J Am Pharm Assoc (2003). 2015 May–Jun;55(3):265–8. doi: 10.1331/JAPhA.2015.14225. PMID: 25909463. Exclusion Code: X2.25909463
1882 Onady GM, Stolfi A. Insulin and oral agents for managing cystic fibrosis-related diabetes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
1883 O’Neil P, Fujioka K, Ortiz R, . Efficacy and safety of liraglutide 3.0 mg in adult overweight and obese weight loss responders without diabetes: results of the randomised, double-blind, placebo-controlled 56-week scale obesity and prediabetes trial. Endocrine reviews. Conference: 97th annual meeting and expo of the endocrine society, ENDO 2015. United states. Conference start: 20150305. Conference end: 20150308. 2015;36(no pagination)PMID: CN-01293706. Exclusion Code: X10.
1884 O’Neil P, Fujioka K, Violante Ortiz R, . Efficacy and safety of liraglutide 3.0 mg in adult overweight and obese weight loss responders without diabetes: results of the randomised, double-blind, placebo-controlled 56-week SCALE Obesity and Prediabetes trial. Diabetologie und stoffwechsel. Conference: 50. Jahrestagung der DDG, diabetes kongress 2015. Germany. 2015;10(4) (no pagination)doi: 10.1055/s-0035-1556574. PMID: CN-01669705. Exclusion Code: X5.
1885 O’Neil PM, Aroda VR, Astrup A, . Neuropsychiatric safety with liraglutide 3.0 mg for weight management: Results from randomized controlled phase 2 and 3a trials. Diabetes Obes Metab. 2017 Nov;19(11):1529–36. doi: 10.1111/dom.12963. PMID: 28386912. Exclusion Code: X8.28386912
1886 O’Neil PM, Miller-Kovach K, Tuerk PW, . Randomized controlled trial of a nationally available weight control program tailored for adults with type 2 diabetes. Obesity (Silver Spring). 2016 Nov;24(11):2269–77. doi: 10.1002/oby.21616. PMID: 27804264. Exclusion Code: X2.27804264
1887 O’Neill SM, Kenny LC, Khashan AS, . Different insulin types and regimens for pregnant women with pre-existing diabetes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
1888 Ong KL, Januszewski AS, O’Connell R, . The relationship of fibroblast growth factor 21 with cardiovascular outcome events in the Fenofibrate Intervention and Event Lowering in Diabetes study. Diabetologia. 2015 Mar;58(3):464–73. doi: 10.1007/s00125-014-3458-7. PMID: 25425220. Exclusion Code: X5.25425220
1889 Onishi Y, Niemoeller E, Ikeda Y, . Efficacy and safety of lixisenatide in Japanese patients with type 2 diabetes mellitus inadequately controlled by sulfonylurea with or without metformin: subanalysis of GetGoal-S. Journal of diabetes investigation. 2015;6(2):201–9. doi: 10.1111/jdi.12275. PMID: CN-01052272. Exclusion Code: X2.25802728
1890 Onishi Y, Oura T, Matsui A, . Analysis of efficacy and safety of dulaglutide 0.75 mg stratified by sex in patients with type 2 diabetes in 2 randomized, controlled phase 3 studies in Japan. Endocr J. 2017 May 30;64(5):553–60. doi: 10.1507/endocrj.EJ16-0552. PMID: 28367916. Exclusion Code: X8.28367916
1891 Ono S, Ono Y, Matsui H, . Impact of clinic follow-up visits on body weight control in people with prediabetes or diabetes mellitus: Japanese nonelderly cohort study. Fam Pract. 2017 Sep 1;34(5):552–7. doi: 10.1093/fampra/cmx016. PMID: 28369304. Exclusion Code: X6.28369304
1892 Ooi EM, Watts GF, Chan DC, . Effects of extended-release niacin on the postprandial metabolism of Lp(a) and ApoB-100-containing lipoproteins in statin-treated men with type 2 diabetes mellitus. Arterioscler Thromb Vasc Biol. 2015 Dec;35(12):2686–93. doi: 10.1161/atvbaha.115.306136. PMID: 26515419. Exclusion Code: X2.26515419
1893 O’Reilly SL, Dunbar JA, Versace V, . Mothers after Gestational Diabetes in Australia (MAGDA): A randomised controlled trial of a postnatal diabetes prevention program. PLoS Med. 2016 Jul;13(7):e1002092. doi: 10.1371/journal.pmed.1002092. PMID: 27459502. Exclusion Code: X2.27459502
1894 Orozco Beltran D. Low-dose aspirin, as primary prevention, does not decrease the risk of cardiovascular morbidity and mortality in patients with type 2 diabetes mellitus. FMC formacion medica continuada en atencion primaria. 2009;16(5):316-. doi: 10.1016/S1134-2072(09)71293-9. PMID: CN-01764261. Exclusion Code: X1.
1895 Orozco LJ, Buchleitner AM, Gimenez-Perez G, . Exercise or exercise and diet for preventing type 2 diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2008. Exclusion Code: X8.
1896 Ortega FJ, Mercader JM, Moreno-Navarrete JM, . Profiling of circulating microRNAs reveals common microRNAs linked to type 2 diabetes that change with insulin sensitization. Diabetes Care. 2014;37(5):1375–83. doi: 10.2337/dc13-1847. PMID: 24478399. Exclusion Code: X6.24478399
1897 Osama A, Shehab A-K. Psychological wellbeing and biochemical modulation in response to weight loss in obese type 2 diabetes patients. African historical studies. 2015;15(2):503–12. doi: 10.4314/ahs.v15i2.25. PMID: CN-01257149. Exclusion Code: X6.
1898 Osei E, Fonville S, Zandbergen A, . Metformin and sitAgliptin in patients with impAired glucose tolerance and a recent TIA or minor ischemic Stroke (MAAS): study protocol for a randomized controlled trial. Trials. 2015;16(1)doi: 10.1186/s13063-015-0882-z. PMID: CN-01091256. Exclusion Code: X6.
1899 Osonoi T, Saito M, Tamasawa A, . Effects of sitagliptin or mitiglinide as an add-on to acarbose on daily blood glucose fluctuations measured by 72 h subcutaneous continuous glucose monitoring in Japanese patients with type 2 diabetes: a prospective randomized study. Expert Opin Pharmacother. 2014 Jul;15(10):1325–35. doi: 10.1517/14656566.2014.920323. PMID: 24866329. Exclusion Code: X5.24866329
1900 Otsuki H, Kosaka T, Nakamura K, . Safety and efficacy of teneligliptin: a novel DPP-4 inhibitor for hemodialysis patients with type 2 diabetes. Int Urol Nephrol. 2014 Feb;46(2):427–32. doi: 10.1007/s11255-013-0552-6. PMID: 24014134. Exclusion Code: X2.24014134
1901 Ott C, Kistner I, Keller M, . Effects of linagliptin on renal endothelial function in patients with type 2 diabetes: a randomised clinical trial. Diabetologia. 2016 Dec;59(12):2579–87. doi: 10.1007/s00125-016-4083-4. PMID: 27586249. Exclusion Code: X2.27586249
1902 Ott C, Raff U, Schmidt S, . Effects of saxagliptin on early microvascular changes in patients with type 2 diabetes. Cardiovasc Diabetol. 2014 Jan 14;13:19. doi: 10.1186/1475-2840-13-19. PMID: 24423149. Exclusion Code: X6.24423149
1903 Otten J, Stomby A, Waling M, . A heterogeneous response of liver and skeletal muscle fat to the combination of a Paleolithic diet and exercise in obese individuals with type 2 diabetes: a randomised controlled trial. Diabetologia. 2018;61(7):1548–59. doi: 10.1007/s00125-018-4618-y. PMID: CN-01665127. Exclusion Code: X5.29696296
1904 Ou HT, Chang KC, Li CY, . Risks of cardiovascular diseases associated with dipeptidyl peptidase-4 inhibitors and other antidiabetic drugs in patients with type 2 diabetes: a nation-wide longitudinal study. Cardiovasc Diabetol. 2016 Mar 1;15:41. doi: 10.1186/s12933-016-0350-4. PMID: 26932742. Exclusion Code: X5.26932742
1905 Ou HT, Chang KC, Li CY, . Comparative cardiovascular risks of dipeptidyl peptidase 4 inhibitors with other second- and third-line antidiabetic drugs in patients with type 2 diabetes. Br J Clin Pharmacol. 2017 Jul;83(7):1556–70. doi: 10.1111/bcp.13241. PMID: 28109184. Exclusion Code: X5.28109184
1906 Ou HT, Chen PC, Wu MH. Effect of metformin by employing 2-hour postload insulin for measuring insulin resistance in Taiwanese women with polycystic ovary syndrome. J Formos Med Assoc. 2017 Feb;116(2):80–9. doi: 10.1016/j.jfma.2016.02.001. PMID: 27131512. Exclusion Code: X5.27131512
1907 Ou SM, Chen HT, Kuo SC, . Dipeptidyl peptidase-4 inhibitors and cardiovascular risks in patients with pre-existing heart failure. Heart. 2017 Mar;103(6):414–20. doi: 10.1136/heartjnl-2016-309687. PMID: 27647170. Exclusion Code: X2.27647170
1908 Ou SM, Shih CJ, Chao PW, . Effects on clinical outcomes of adding dipeptidyl peptidase-4 inhibitors versus sulfonylureas to metformin therapy in patients with type 2 diabetes mellitus. Ann Intern Med. 2015 Nov 3;163(9):663–72. doi: 10.7326/m15-0308. PMID: 26457538. Exclusion Code: X2.26457538
1909 Out M, Top WMC, Lehert P, . Long-term treatment with metformin in type 2 diabetes and vitamin D levels: A post-hoc analysis of a randomized placebo-controlled trial. Diabetes Obes Metab. 2018 Aug;20(8):1951–6. doi: 10.1111/dom.13327. PMID: 29667290. Exclusion Code: X2.29667290
1910 Owens DR, Bolli GB, Charbonnel B, . Effects of age, gender, and body mass index on efficacy and hypoglycaemia outcomes across treat-to-target trials with insulin glargine 100 U/mL added to oral antidiabetes agents in type 2 diabetes. Diabetes Obes Metab. 2017 Nov;19(11):1546–54. doi: 10.1111/dom.12966. PMID: 28449412. Exclusion Code: X8.28449412
1911 Owens DR, Landgraf W, Frier BM, . Commencing insulin glargine 100 U/mL therapy in individuals with type 2 diabetes: Determinants of achievement of HbA1c goal less than 7.0. Diabetes Obes Metab. 2019 Feb;21(2):321–9. doi: 10.1111/dom.13607. PMID: 30520217. Exclusion Code: X8.30520217
1912 Owens DR, Traylor L, Dain MP, . Efficacy and safety of basal insulin glargine 12 and 24 weeks after initiation in persons with type 2 diabetes: a pooled analysis of data from treatment arms of 15 treat-to-target randomised controlled trials. Diabetes Res Clin Pract. 2014 Nov;106(2):264–74. doi: 10.1016/j.diabres.2014.08.003. PMID: 25195151. Exclusion Code: X8.25195151
1913 Oxlund CS, Cangemi C, Henriksen JE, . Low-dose spironolactone reduces plasma fibulin-1 levels in patients with type 2 diabetes and resistant hypertension. J Hum Hypertens. 2015 Jan;29(1):28–32. doi: 10.1038/jhh.2014.27. PMID: 24739800. Exclusion Code: X2.24739800
1914 Oyama J, Murohara T, Kitakaze M, . The effect of sitagliptin on carotid artery atherosclerosis in type 2 diabetes: The PROLOGUE Randomized Controlled Trial. PLoS Med. 2016 Jun;13(6):e1002051. doi: 10.1371/journal.pmed.1002051. PMID: 27351380. Exclusion Code: X2.27351380
1915 Pacini G, Mari A, Fouqueray P, . Imeglimin increases glucose-dependent insulin secretion and improves beta-cell function in patients with type 2 diabetes. Diabetes Obes Metab. 2015 Jun;17(6):541–5. doi: 10.1111/dom.12452. PMID: 25694060. Exclusion Code: X6.25694060
1916 Padhye N, Jing Wn. Effect of self-monitoring clusters on weight and hemoglobin A1c. Conference proceedings : … Annual international conference of the IEEE engineering in medicine and biology society. IEEE engineering in medicine and biology society. Annual conference. 2016;2016:275–8. doi: 10.1109/EMBC.2016.7590693. PMID: CN-01401194. Exclusion Code: X5.
1917 Padwal RS, Rucker D, Li SK, . Long-term pharmacotherapy for obesity and overweight. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2003. Exclusion Code: X8.
1918 Page RL, 2nd, Ghushchyan V, Read RA, . Comparative effectiveness of ranolazine versus traditional therapies in chronic stable angina pectoris and concomitant diabetes mellitus and impact on health care resource utilization and cardiac interventions. Am J Cardiol. 2015 Nov 1;116(9):1321–8. doi: 10.1016/j.amjcard.2015.08.002. PMID: 26358510. Exclusion Code: X2.26358510
1919 Pagels AA, Hylander B, Alvarsson M. A multi-dimensional support programme for patients with diabetic kidney disease. J Ren Care. 2015 Sep;41(3):187–94. doi: 10.1111/jorc.12114. PMID: 25739425. Exclusion Code: X2.25739425
1920 Pagidipati NJ, Navar AM, Pieper KS, . Secondary prevention of cardiovascular disease in patients with type 2 diabetes mellitus: international insights from the TECOS Trial (Trial Evaluating Cardiovascular Outcomes With Sitagliptin). Circulation. 2017 Sep 26;136(13):1193–203. doi: 10.1161/circulationaha.117.027252. PMID: 28626088. Exclusion Code: X2.28626088
1921 Paglialunga S, Bond R, Jaycox SH. Evaluation of HbA1c screening during outreach events for prediabetes subject recruitment for clinical research. Trials. 2018 Jan 22;19(1):60. doi: 10.1186/s13063-018-2459-0. PMID: 29357915. Exclusion Code: X5.29357915
1922 Pahra D, Sharma N, Ghai S, . Impact of post-meal and one-time daily exercise in patient with type 2 diabetes mellitus: a randomized crossover study. Diabetology & metabolic syndrome. 2017;9(1) (no pagination)doi: 10.1186/s13098-017-0263-8. PMID: CN-01417978. Exclusion Code: X2.
1923 Pai PY, Muo CH, Sung FC, . Angiotensin receptor blockers (ARB) outperform angiotensin-converting enzyme (ACE) inhibitors on ischemic stroke prevention in patients with hypertension and diabetes - A real-world population study in Taiwan. Int J Cardiol. 2016 Jul 15;215:114–9. doi: 10.1016/j.ijcard.2016.04.096. PMID: 27111172. Exclusion Code: X5.27111172
1924 Pai V, Paneerselvam A, Mukhopadhyay S, . A multicenter, prospective, randomized, double-blind study to evaluate the safety and efficacy of saroglitazar 2 and 4 mg compared to pioglitazone 45 mg in diabetic dyslipidemia (PRESS V). J Diabetes Sci Technol. 2014;8(1):132–41. doi: 10.1177/1932296813518680. PMID: CN-00993160. Exclusion Code: X5.24876549
1925 Pal K, Dack C, Ross J, . Digital Health Interventions for Adults With Type 2 Diabetes: Qualitative Study of Patient Perspectives on Diabetes Self-Management Education and Support. J Med Internet Res. 2018 Jan 29;20(2):e40. doi: 10.2196/jmir.8439. PMID: 29463488. Exclusion Code: X8.29463488
1926 Pal K, Eastwood SV, Michie S, . Computer-based interventions to improve self-management in adults with type 2 diabetes: a systematic review and meta-analysis. Diabetes Care. 2014 Jun;37(6):1759–66. doi: 10.2337/dc13-1386. PMID: 24855158. Exclusion Code: X8.24855158
1927 Palacios C, Kostiuk LK, Peña-Rosas JP. Vitamin D supplementation for women during pregnancy. Cochrane Database of Systematic Reviews. 2019(7)doi: 10.1002/14651858.CD008873.pub4. PMID: CD008873. Exclusion Code: X8.
1928 Palacios T, Vitetta L, Coulson S, . The effect of a multi-strain probiotic on metabolic bio-markers in adults with prediabetes and recently diagnosed type 2 diabetes mellitus (T2DM). Obesity reviews. 2016;17:31. doi: 10.1111/obr.12399. PMID: CN-01160642. Exclusion Code: X6.26879111
1929 Palakodeti S, Uratsu CS, Schmittdiel JA, . Changes in physical activity among adults with diabetes: a longitudinal cohort study of inactive patients with Type 2 diabetes who become physically active. Diabet Med. 2015 Aug;32(8):1051–7. doi: 10.1111/dme.12748. PMID: 25764298. Exclusion Code: X8.25764298
1930 Palevsky PM, Zhang JH, Seliger SL, . Incidence, severity, and outcomes of AKI associated with dual renin-angiotensin system blockade. Clin J Am Soc Nephrol. 2016 Nov 7;11(11):1944–53. doi: 10.2215/cjn.03470316. PMID: 27679519. Exclusion Code: X5.27679519
1931 Palmer SC, Maggo JK, Campbell KL, . Dietary interventions for adults with chronic kidney disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
1932 Palmer SC, Mavridis D, Navarese E, . Comparative efficacy and safety of blood pressure-lowering agents in adults with diabetes and kidney disease: a network meta-analysis. Lancet. 2015 May 23;385(9982):2047–56. doi: 10.1016/s0140-6736(14)62459-4. PMID: 26009228. Exclusion Code: X8.26009228
1933 Palmer SC, Saglimbene V, Mavridis D, . Erythropoiesis-stimulating agents for anaemia in adults with chronic kidney disease: a network meta-analysis. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
1934 Pan C, Han P, Ji Q, . Efficacy and safety of alogliptin in patients with type 2 diabetes mellitus: A multicentre randomized double-blind placebo-controlled Phase 3 study in mainland China, Taiwan, and Hong Kong. J Diabetes. 2017 Apr;9(4):386–95. doi: 10.1111/1753-0407.12425. PMID: 27171508. Exclusion Code: X2.27171508
1935 Pan XR, Hu YH, Li GW, . Impaired glucose tolerance and its relationship to ECG-indicated coronary heart disease and risk factors among Chinese. Da Qing IGT and diabetes study. Diabetes Care. 1993 Jan;16(1):150–6. doi: 10.2337/diacare.16.1.150. PMID: 8422770. Exclusion Code: X6.8422770
1936 Panda A, Pradhan S, Panigrahi M, . Effect of glimepiride on health related quality of life in type 2 diabetes mellitus. Research journal of pharmaceutical, biological and chemical sciences. 2015;6(4):1666–71. PMID: CN-01091687. Exclusion Code: X8.
1937 Pandey A, Suskin N, Poirier P. The impact of burst exercise on cardiometabolic status of patients newly diagnosed with type 2 diabetes. Canadian journal of cardiology. 2017;33(12):1645–51. doi: 10.1016/j.cjca.2017.09.019. PMID: CN-01431630. Exclusion Code: X5.
1938 Pang B, Ni Q, Lin YQ, . Traditional Chinese Patent Medicine for Treating Impaired Glucose Tolerance: A Systematic Review and Meta-Analysis of Randomized Controlled Trials. J Altern Complement Med. 2018 Jul;24(7):634–55. doi: 10.1089/acm.2017.0302. PMID: 29624416. Exclusion Code: X8.29624416
1939 Pang J, Chan DC, Hamilton SJ, . Effect of niacin on triglyceride-rich lipoprotein apolipoprotein B-48 kinetics in statin-treated patients with type 2 diabetes. Diabetes Obes Metab. 2016 Apr;18(4):384–91. doi: 10.1111/dom.12622. PMID: 26679079. Exclusion Code: X8.26679079
1940 Pantalone KM, Wells BJ, Chagin KM, . Intensification of diabetes therapy and time until A1C goal attainment among patients with newly diagnosed type 2 diabetes who fail metformin monotherapy within a large integrated health system. Diabetes Care. 2016 Sep;39(9):1527–34. doi: 10.2337/dc16-0227. PMID: 27519447. Exclusion Code: X6.27519447
1941 Papademetriou V, Lovato L, Tsioufis C, . Effects of high density lipoprotein raising therapies on cardiovascular outcomes in patients with type 2 diabetes mellitus, with or without renal impairment: the Action to Control Cardiovascular Risk in Diabetes Study. Am J Nephrol. 2017;45(2):136–45. doi: 10.1159/000453626. PMID: 27992863. Exclusion Code: X2.27992863
1942 Papademetriou V, Zaheer M, Doumas M, . Cardiovascular outcomes in action to control cardiovascular risk in diabetes: impact of blood pressure level and presence of kidney disease. Am J Nephrol. 2016;43(4):271–80. doi: 10.1159/000446122. PMID: 27161620. Exclusion Code: X2.27161620
1943 Papakonstantinou E, Mitrou P, Kontogianni M, . Effect of meal frequency on glucose and insulin responses in obese people with impaired glucose tolerance and with type 2 diabetes: a randomised trial. Diabetologia. Conference: 53rd annual meeting of the european association for the study of diabetes, EASD 2017. Portugal. 2017;60(1 Supplement 1):S389. doi: 10.1007/s00125-017-4350-z. PMID: CN-01418966. Exclusion Code: X5.
1944 Papandonatos GD, Pan Q, Pajewski NM, . Genetic predisposition to weight loss and regain with lifestyle intervention: analyses from the diabetes prevention program and the Look AHEAD randomized controlled trials. Diabetes. 2015 Dec;64(12):4312–21. doi: 10.2337/db15-0441. PMID: 26253612. Exclusion Code: X8.26253612
1945 Pareek A, Chandurkar N, Thomas N, . Efficacy and safety of hydroxychloroquine in the treatment of type 2 diabetes mellitus: a double blind, randomized comparison with pioglitazone. Curr Med Res Opin. 2014 Jul;30(7):1257–66. doi: 10.1185/03007995.2014.909393. PMID: 24669876. Exclusion Code: X2.24669876
1946 Pareek M, Bhatt DL, Nielsen ML, . Enhanced predictive capability of a 1-hour oral glucose tolerance test: a prospective population-based cohort study. Diabetes Care. 2018 Jan;41(1):171–7. doi: 10.2337/dc17-1351. PMID: 29138275. Exclusion Code: X6.29138275
1947 Parekh S, Bodicoat DH, Brady E, . Clinical characteristics of people experiencing biochemical hypoglycaemia during an oral glucose tolerance test: cross-sectional analyses from a UK multi-ethnic population. Diabetes Res Clin Pract. 2014 Jun;104(3):427–34. doi: 10.1016/j.diabres.2014.02.013. PMID: 24685116. Exclusion Code: X8.24685116
1948 Parida S, Swain T, Routray S, . Effect of atorvastatin on glycaemic parameters in normoglycaemic and prediabetic subjects: a prospective, panel study. Journal of clinical and diagnostic research. 2017;11(2):Fc04–fc9. doi: 10.7860/JCDR/2017/23741.9427. PMID: CN-01329548. Exclusion Code: X5.
1949 Parikh S, Wilding J, Jabbour S, . Dapagliflozin in type 2 diabetes: effectiveness across the spectrum of disease and over time. Int J Clin Pract. 2015 Feb;69(2):186–98. doi: 10.1111/ijcp.12531. PMID: 25438821. Exclusion Code: X8.25438821
1950 Park JW, Lee JH, Park YH, . Sex-dependent difference in the effect of metformin on colorectal cancer-specific mortality of diabetic colorectal cancer patients. World J Gastroenterol. 2017 Jul 28;23(28):5196–205. doi: 10.3748/wjg.v23.i28.5196. PMID: 28811714. Exclusion Code: X2.28811714
1951 Park S, Lee I. Effects on training and detraining on physical function, control of diabetes and anthropometrics in type 2 diabetes; a randomized controlled trial. Physiotherapy theory and practice. 2015;31(2):83–8. doi: 10.3109/09593985.2014.958265. PMID: CN-01097249. Exclusion Code: X2.25230894
1952 Park SW, Bebakar WM, Hernandez PG, . Insulin degludec/insulin aspart once daily in Type 2 diabetes: a comparison of simple or stepwise titration algorithms (BOOST((R)) : SIMPLE USE). Diabet Med. 2017 Feb;34(2):174–9. doi: 10.1111/dme.13069. PMID: 26773557. Exclusion Code: X5.26773557
1953 Parker AR, Byham-Gray L, Denmark R, . The effect of medical nutrition therapy by a registered dietitian nutritionist in patients with prediabetes participating in a randomized controlled clinical research trial. J Acad Nutr Diet. 2014 Nov;114(11):1739–48. doi: 10.1016/j.jand.2014.07.020. PMID: 25218597. Exclusion Code: X6.25218597
1954 Parra MT, Riera R, Atallah ÁN, . Exercise after bariatric surgery for obese adults. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
1955 Parthan G, Bhansali S, Kurpad AV, . Effect of Linagliptin and Voglibose on metabolic profile in patients with Type 2 Diabetes: a randomized, double-blind, placebo-controlled trial. BMC Pharmacol Toxicol. 2018 Jul 3;19(1):38. doi: 10.1186/s40360-018-0228-z. PMID: 29970184. Exclusion Code: X2.29970184
1956 Parvanova A, Trillini M, Podesta MA, . Blood pressure and metabolic effects of acetyl-L-carnitine in type 2 diabetes: DIABASI randomized controlled trial. Journal of the endocrine society. 2018;2(5):420–36. doi: 10.1210/js.2017-00426. PMID: CN-01573993. Exclusion Code: X4.29696241
1957 Parvanova A, Trillini M, Podesta MA, . Moderate salt restriction with or without paricalcitol in type 2 diabetes and losartan-resistant macroalbuminuria (PROCEED): a randomised, double-blind, placebo-controlled, crossover trial. Lancet Diabetes Endocrinol. 2018 Jan;6(1):27–40. doi: 10.1016/s2213-8587(17)30359-5. PMID: 29104158. Exclusion Code: X2.29104158
1958 Pascale M, Murray N, Bachmann M, . Study Protocol: The Norfolk Diabetes Prevention Study [NDPS]: a 46 month multi - centre, randomised, controlled parallel group trial of a lifestyle intervention [with or without additional support from lay lifestyle mentors with Type 2 diabetes] to prevent transition to Type 2 diabetes in high risk groups with non - diabetic hyperglycaemia, or impaired fasting glucose. BMC Public Health. 2017 Jan 6;17(1):31. doi: 10.1186/s12889-016-3929-5. PMID: 28056894. Exclusion Code: X6.28056894
1959 Pascoe S. Effect of acetylsalicylic acid on antioxidant enzymatic system in patients with type 2 diabetes. Diabetes. 2015;64:A664. . PMID: CN-01086591. Exclusion Code: X6.
1960 Patel A, Group AC, MacMahon S, . Effects of a fixed combination of perindopril and indapamide on macrovascular and microvascular outcomes in patients with type 2 diabetes mellitus (the ADVANCE trial): a randomised controlled trial. Lancet. 2007 Sep 8;370(9590):829–40. doi: 10.1016/S0140-6736(07)61303-8. PMID: 17765963. Exclusion Code: X2.17765963
1961 Patel CA, Bailey RA, Vijapurkar U, . A post-hoc analysis of the comparative efficacy of canagliflozin and glimepiride in the attainment of type 2 diabetes-related quality measures. BMC Health Serv Res. 2016 Aug 5;16(a):356. doi: 10.1186/s12913-016-1607-z. PMID: 27495291. Exclusion Code: X2.27495291
1962 Patel RM, Misra R, Raj S, . Effectiveness of a group-based culturally tailored lifestyle intervention program on changes in risk factors for type 2 diabetes among Asian Indians in the United States. J Diabetes Res. 2017;2017:2751980. doi: 10.1155/2017/2751980. PMID: 28168201. Exclusion Code: X2.28168201
1963 Patel Y, Kirkman M, Considine R, . Changes in weight and glucose can protect against progression in early diabetes independent of improvements in ?-cell function. Journal of clinical endocrinology and metabolism. 2016;101(11):4076–84. doi: 10.1210/jc.2016-2056. PMID: CN-01382177. Exclusion Code: X6.27533307
1964 Patel YR, Gadiraju TV, Gaziano JM, . Adherence to healthy lifestyle factors and risk of death in men with diabetes mellitus: The Physicians’ Health Study. Clin Nutr. 2018 Feb;37(1):139–43. doi: 10.1016/j.clnu.2016.11.003. PMID: 27866759. Exclusion Code: X4.27866759
1965 Patel YR, Kirkman MS, Considine RV, . Changes in weight and glucose can protect against progression in early diabetes independent of improvements in beta-cell function. J Clin Endocrinol Metab. 2016 Nov;101(11):4076–84. doi: 10.1210/jc.2016-2056. PMID: 27533307. Exclusion Code: X6.27533307
1966 Patorno E, Everett BM, Goldfine AB, . Comparative cardiovascular safety of glucagon-like peptide-1 receptor agonists versus other antidiabetic drugs in routine care: a cohort study. Diabetes Obes Metab. 2016 Aug;18(8):755–65. doi: 10.1111/dom.12665. PMID: 27003762. Exclusion Code: X2.27003762
1967 Patorno E, Goldfine AB, Schneeweiss S, . Cardiovascular outcomes associated with canagliflozin versus other non-gliflozin antidiabetic drugs: population based cohort study. Bmj. 2018 Feb 6;360:k119. doi: 10.1136/bmj.k119. PMID: 29437648. Exclusion Code: X5.29437648
1968 Patterson SM, Cadogan CA, Kerse N, . Interventions to improve the appropriate use of polypharmacy for older people. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
1969 Patti AM, Nikolic D, Magan-Fernandez A, . Exenatide once-weekly improves metabolic parameters, endothelial dysfunction and carotid intima-media thickness in patients with type-2 diabetes: An 8-month prospective study. Diabetes Res Clin Pract. 2019 Mar;149:163–9. doi: 10.1016/j.diabres.2019.02.006. PMID: 30759365. Exclusion Code: X2.30759365
1970 Paudel S, Owen AJ, Owusu-Addo E, . Physical activity participation and the risk of chronic diseases among South Asian adults: protocol for a systematic review and meta-analysis. Syst Rev. 2018 Oct 30;7(1):177. doi: 10.1186/s13643-018-0848-9. PMID: 30376892. Exclusion Code: X8.30376892
1971 Paul SK, Agbeve J, Maggs D, . Comparison of trajectories of self-monitored glucose levels by hypoglycemia status over 52 weeks of treatment with insulin glargine or exenatide once weekly. J Diabetes. 2016 Jan;8(1):148–57. doi: 10.1111/1753-0407.12269. PMID: 25586464. Exclusion Code: X8.25586464
1972 Paul SK, Klein K, Maggs D, . The association of the treatment with glucagon-like peptide-1 receptor agonist exenatide or insulin with cardiovascular outcomes in patients with type 2 diabetes: a retrospective observational study. Cardiovasc Diabetol. 2015 Jan 24;14:10. doi: 10.1186/s12933-015-0178-3. PMID: 25616979. Exclusion Code: X8.25616979
1973 Paul SK, Klein K, Majeed A, . Association of smoking and concomitant metformin use with cardiovascular events and mortality in people newly diagnosed with type 2 diabetes. J Diabetes. 2016 May;8(3):354–62. doi: 10.1111/1753-0407.12302. PMID: 25929583. Exclusion Code: X5.25929583
1974 Paul SK, Maggs D, Klein K, . Dynamic risk factors associated with non-severe hypoglycemia in patients treated with insulin glargine or exenatide once weekly. J Diabetes. 2015 Jan;7(1):60–7. doi: 10.1111/1753-0407.12208. PMID: 25168883. Exclusion Code: X2.25168883
1975 Paula TP, Viana LV, Neto AT, . Effects of the DASH diet and walking on blood pressure in patients with type 2 diabetes and uncontrolled hypertension: a randomized controlled trial. J Clin Hypertens (Greenwich). 2015 Nov;17(11):895–901. doi: 10.1111/jch.12597. PMID: 26041459. Exclusion Code: X5.26041459
1976 Paulus JK, Williams CD, Cossor FI, . Metformin, diabetes, and survival among U.S. Veterans with colorectal cancer. Cancer Epidemiol Biomarkers Prev. 2016 Oct;25(10):1418–25. doi: 10.1158/1055-9965.epi-16-0312. PMID: 27496094. Exclusion Code: X2.27496094
1977 Paz-Pacheco E, Sandoval MA, Ardena GJ, . Effectiveness of a community-based diabetes self-management education (DSME) program in a rural agricultural setting. Prim Health Care Res Dev. 2017 Jan;18(1):35–49. doi: 10.1017/s1463423616000335. PMID: 27640303. Exclusion Code: X2.27640303
1978 Peacock OJ, Western MJ, Batterham AM, . Multidimensional individualised Physical ACTivity (Mi-PACT)--a technology-enabled intervention to promote physical activity in primary care: study protocol for a randomised controlled trial. Trials. 2015 Aug 28;16:381. doi: 10.1186/s13063-015-0892-x. PMID: 26314577. Exclusion Code: X6.26314577
1979 Pedersen E, Jesudason D, Clifton P. High protein weight loss diets in obese subjects with type 2 diabetes mellitus. Nutrition, metabolism, and cardiovascular diseases : NMCD. 2014;24(5):554–62. doi: 10.1016/j.numecd.2013.11.003. PMID: CN-00997656. Exclusion Code: X2.
1980 Pedersen LR, Olsen RH, Jurs A, . A randomized trial comparing the effect of weight loss and exercise training on insulin sensitivity and glucose metabolism in coronary artery disease. Metabolism. 2015 Oct;64(10):1298–307. doi: 10.1016/j.metabol.2015.07.007. PMID: 26296452. Exclusion Code: X2.26296452
1981 Peel R, Hure A, Wiggers J, . Zinc in Preventing the Progression of pre-Diabetes (ZIPPeD Study) - study protocol for a randomised placebo-controlled trial in Australia. Trials. 2019 Apr 15;20(1):219. doi: 10.1186/s13063-019-3317-4. PMID: 30992081. Exclusion Code: X4.30992081
1982 Peimani M, Monjazebi F, Ghodssi-Ghassemabadi R, . A peer support intervention in improving glycemic control in patients with type 2 diabetes. Patient Educ Couns. 2018 Mar;101(3):460–6. doi: 10.1016/j.pec.2017.10.007. PMID: 29055655. Exclusion Code: X2.29055655
1983 Peimani M, Rambod C, Omidvar M, . Effectiveness of short message service-based intervention (SMS) on self-care in type 2 diabetes: A feasibility study. Prim Care Diabetes. 2016 Aug;10(4):251–8. doi: 10.1016/j.pcd.2015.11.001. PMID: 26653014. Exclusion Code: X2.26653014
1984 Peiris D, Sun L, Patel A, . Systematic medical assessment, referral and treatment for diabetes care in China using lay family health promoters: protocol for the SMARTDiabetes cluster randomised controlled trial. Implement Sci. 2016 Aug 17;11(1):116. doi: 10.1186/s13012-016-0481-8. PMID: 27535128. Exclusion Code: X6.27535128
1985 Pena A, Chien J, Cui X, . Once weekly dulaglutide 1.5 Mg restores insulin secretion in response to intravenous glucose infusion. Endocrine reviews. Conference: 96th annual meeting and expo of the endocrine society, ENDO 2014. Chicago, IL united states. Conference start: 20140621. Conference end: 20140624. Conference publication: (var.pagings). 2014;35(no pagination)PMID: CN-01267343. Exclusion Code: X6.
1986 Penalba M, Moreno L, Cobo A, . Impact of the <<Conversation Map>> tools on understanding of diabetes by Spanish patients with type 2 diabetes mellitus: a randomized, comparative study. Endocrinol Nutr. 2014 Dec;61(10):505–15. doi: 10.1016/j.endonu.2014.06.001. PMID: 25085598. Exclusion Code: X4.25085598
1987 Penalba M, Moreno L, Cobo A, . Impact of the «Conversation Map?» tools on understanding of diabetes by Spanish patients with type 2 diabetes mellitus: a randomized, comparative study. Endocrinologia y nutricion. 2014;61(10):505–15. doi: 10.1016/j.endonu.2014.06.001. PMID: CN-01215598. Exclusion Code: X2.25085598
1988 Penesova A, Bajer B, Vlcek M, . The effect of 8 weeks of weight loss intervention on cardiometabolic parameters (ongoing study). Vnitrni lekarstvi. Conference: 6th central european congress on obesity, CECON and 15th slovak congress on obesity. Slovakia. 2017;63(9 Supplement 2):2s54. PMID: CN-01470920. Exclusion Code: X5.
1989 Peng L, Wang J, Li F. Weight reduction for non-alcoholic fatty liver disease. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2011. Exclusion Code: X8.
1990 Peng XV, Marcinak JF, Raanan MG, . Combining the G-protein-coupled receptor 40 agonist fasiglifam with sitagliptin improves glycaemic control in patients with type 2 diabetes with or without metformin: A randomized, 12-week trial. Diabetes Obes Metab. 2017 Aug;19(8):1127–34. doi: 10.1111/dom.12921. PMID: 28239939. Exclusion Code: X2.28239939
1991 Pengpid S, Peltzer K, Jayasvasti I, . Two-year results of a community-based randomized controlled lifestyle intervention trial to control prehypertension and/or prediabetes in Thailand: a brief report. International journal of general medicine. 2019;12:131–5. doi: 10.2147/IJGM.S200086. PMID: CN-01963529. Exclusion Code: X7.31118740
1992 Pengpid S, Peltzer K, Puckpinyo A, . Effectiveness of a cluster-randomized controlled trial community-based lifestyle intervention program to control prehypertension and/or prediabetes in Thailand. Int J Diabetes Dev Ctries. 2019;39(1):123–31. doi: 10.1007/s13410-018-0641-2. PMID: CN-01917380. Exclusion Code: X7.
1993 Pereira MJ, Skrtic S, Katsogiannos P, . Impaired adipose tissue lipid storage, but not altered lipolysis, contributes to elevated levels of NEFA in type 2 diabetes. Degree of hyperglycemia and adiposity are important factors. Metabolism. 2016 Dec;65(12):1768–80. doi: 10.1016/j.metabol.2016.09.008. PMID: 27832864. Exclusion Code: X6.27832864
1994 Pereira RI, Casey BA, Swibas TA, . Timing of estradiol treatment after menopause may determine benefit or harm to insulin action. J Clin Endocrinol Metab. 2015 Dec;100(12):4456–62. doi: 10.1210/jc.2015-3084. PMID: 26425886. Exclusion Code: X4.26425886
1995 Perez A, Alos VA, Scanlan A, . The rationale, design, and baseline characteristics of PREVENT-DM: a community-based comparative effectiveness trial of lifestyle intervention and metformin among Latinas with prediabetes. Contemp Clin Trials. 2015 Nov;45(Pt B):320–7. doi: 10.1016/j.cct.2015.10.011. PMID: 26597415. Exclusion Code: X6.26597415
1996 Perez-Escamilla R, Damio G, Chhabra J, . Impact of a community health workers-led structured program on blood glucose control among latinos with type 2 diabetes: the DIALBEST trial. Diabetes Care. 2015 Feb;38(2):197–205. doi: 10.2337/dc14-0327. PMID: 25125508. Exclusion Code: X6.25125508
1997 Perez-Ferre N, Del Valle L, Torrejon MJ, . Diabetes mellitus and abnormal glucose tolerance development after gestational diabetes: a three-year, prospective, randomized, clinical-based, Mediterranean lifestyle interventional study with parallel groups. Clin Nutr. 2015 Aug;34(4):579–85. doi: 10.1016/j.clnu.2014.09.005. PMID: 25262459. Exclusion Code: X2.25262459
1998 Permsuwan U, Dilokthornsakul P, Thavorn K, . Cost-effectiveness of dipeptidyl peptidase-4 inhibitor monotherapy versus sulfonylurea monotherapy for people with type 2 diabetes and chronic kidney disease in Thailand. J Med Econ. 2017 Feb;20(2):171–81. doi: 10.1080/13696998.2016.1238386. PMID: 27645706. Exclusion Code: X8.27645706
1999 Perreault L, Pan Q, Aroda VR, . Exploring residual risk for diabetes and microvascular disease in the Diabetes Prevention Program Outcomes Study (DPPOS). Diabetic medicine. 2017;34(12):1747–55. doi: 10.1111/dme.13453. PMID: CN-01622057. Exclusion Code: X5.28833481
2000 Perreault L, Pan Q, Schroeder EB, . Regression From Prediabetes to Normal Glucose Regulation and Prevalence of Microvascular Disease in the Diabetes Prevention Program Outcomes Study (DPPOS). Diabetes Care. 2019 Sep;42(9):1809–15. doi: 10.2337/dc19-0244. PMID: 31320445. Exclusion Code: X5.31320445
2001 Peter I, Papandonatos GD, Belalcazar LM, . Genetic modifiers of cardiorespiratory fitness response to lifestyle intervention. Med Sci Sports Exerc. 2014 Feb;46(2):302–11. doi: 10.1249/MSS.0b013e3182a66155. PMID: 23899896. Exclusion Code: X4.23899896
2002 Peters AL, Ahmann AJ, Battelino T, . Diabetes technology-continuous subcutaneous insulin infusion therapy and continuous glucose monitoring in adults: an endocrine society clinical practice guideline. J Clin Endocrinol Metab. 2016 Nov;101(11):3922–37. doi: 10.1210/jc.2016-2534. PMID: 27588440. Exclusion Code: X8.27588440
2003 Petersen C, Bertram N, Schliffke M, . DIMINI - Activation of health literacy in persons with an increased risk of type 2 diabetes mellitus by coaching at general practitioners: evaluation concept and study design. Diabetologie und stoffwechsel. 2018;13doi: 10.1055/s-0038-1641955. PMID: CN-01771046. Exclusion Code: X6.
2004 Petersen KS, Clifton PM, Blanch N, . Effect of improving dietary quality on carotid intima media thickness in subjects with type 1 and type 2 diabetes: a 12-mo randomized controlled trial. Am J Clin Nutr. 2015 Oct;102(4):771–9. doi: 10.3945/ajcn.115.112151. PMID: 26354542. Exclusion Code: X2.26354542
2005 Petersen KS, Keogh JB, Lister NB, . Dietary quality and carotid intima media thickness in type 1 and type 2 diabetes: Follow-up of a randomised controlled trial. Nutr Metab Cardiovasc Dis. 2018 Aug;28(8):830–8. doi: 10.1016/j.numecd.2018.05.001. PMID: 29853429. Exclusion Code: X2.29853429
2006 Petrie JR, Morris AD, Ueda S, . Trandolapril does not affect insulin sensitivity in patients with essential hypertension and impaired glucose tolerance/NIDDM. J Hypertens. 1997;15(12 I):1541-. PMID: CN-01772295. Exclusion Code: X6.
2007 Pettus J, McNabb B, Eckel RH, . Effect of ranolazine on glycaemic control in patients with type 2 diabetes treated with either glimepiride or metformin. Diabetes Obes Metab. 2016 May;18(5):463–74. doi: 10.1111/dom.12629. PMID: 26749407. Exclusion Code: X2.26749407
2008 Pfeffer MA, Claggett B, Diaz R, . Lixisenatide in patients with type 2 diabetes and acute coronary syndrome. N Engl J Med. 2015 Dec 3;373(23):2247–57. doi: 10.1056/NEJMoa1509225. PMID: 26630143. Exclusion Code: X2.26630143
2009 Phelan S, Kanaya AM, Ma Y, . Long-term prevalence and predictors of urinary incontinence among women in the Diabetes Prevention Program Outcomes Study. Int J Urol. 2015 Feb;22(2):206–12. doi: 10.1111/iju.12654. PMID: 25352018. Exclusion Code: X6.25352018
2010 Phung O, Baker W, Tongbram V, . Oral antidiabetic drugs and regression from prediabetes to normoglycemia: a meta-analysis (Structured abstract). Annals of Pharmacotherapy; 2012. p. 469–76. Exclusion Code: X8.
2011 Phung OJ, Sobieraj DM, Engel SS, . Early combination therapy for the treatment of type 2 diabetes mellitus: systematic review and meta-analysis. Diabetes Obes Metab. 2014 May;16(5):410–7. doi: 10.1111/dom.12233. PMID: 24205921. Exclusion Code: X8.24205921
2012 Pibernik-Okanovic M, Hermanns N, Ajdukovic D, . Does treatment of subsyndromal depression improve depression-related and diabetes-related outcomes? A randomised controlled comparison of psychoeducation, physical exercise and enhanced treatment as usual. Trials. 2015 Jul 15;16:305. doi: 10.1186/s13063-015-0833-8. PMID: 26174334. Exclusion Code: X4.26174334
2013 Piccolo RS, Araujo AB, Pearce N, . Cohort profile: the Boston Area Community Health (BACH) survey. Int J Epidemiol. 2014 Feb;43(1):42–51. doi: 10.1093/ije/dys198. PMID: 23220718. Exclusion Code: X6.23220718
2014 Pichayapinyo P, Lagampan S, Rueangsiriwat N. Effects of a dietary modification on 2?h postprandial blood glucose in Thai population at risk of type 2 diabetes: an application of the Stages of Change Model. Int J Nurs Pract. 2015;21(3):278–85. doi: 10.1111/ijn.12253. PMID: CN-01343117. Exclusion Code: X6.24621355
2015 Pihlajamaki J, Mannikko R, Tilles-Tirkkonen T, . Digitally supported program for type 2 diabetes risk identification and risk reduction in real-world setting: protocol for the StopDia model and randomized controlled trial. BMC Public Health. 2019 Mar 1;19(1):255. doi: 10.1186/s12889-019-6574-y. PMID: 30823909. Exclusion Code: X6.30823909
2016 Piovesan F, Tres GS, Moreira LB, . Effect of diacerein on renal function and inflammatory cytokines in participants with type 2 diabetes mellitus and chronic kidney disease: A randomized controlled trial. PLoS One. 2017;12(10):e0186554. doi: 10.1371/journal.pone.0186554. PMID: 29049415. Exclusion Code: X2.29049415
2017 Pi-Sunyer F, Astrup A, Fujioka K, . Liraglutide 3.0 mg reduces the prevalence of prediabetes and delays onset of type 2 diabetes in overweight and obese adults: results from scale obesity and prediabetes, a randomized, double-blind and placebo-controlled 56-week trial. Endocrine reviews. Conference: 96th annual meeting and expo of the endocrine society, ENDO 2014. Chicago, IL united states. Conference start: 20140621. Conference end: 20140624. Conference publication: (var.pagings). 2014;35(no pagination)PMID: CN-01267319. Exclusion Code: X10.
2018 Pi-Sunyer X, Astrup A, Fujioka K, . A randomized, controlled trial of 3.0 mg of liraglutide in weight management. N Engl J Med. 2015 Jul 2;373(1):11–22. doi: 10.1056/NEJMoa1411892. PMID: 26132939. Exclusion Code: X2.26132939
2019 Pi-Sunyer X, Fujioka K, Roux C, . Liraglutide 3.0 mg reduces the prevalence of prediabetes and delays onset of type 2 diabetes in overweight/obese adults: the SCALE obesity and prediabetes trial. Diabetologia. 2014;57(1):S37. PMID: CN-01369465. Exclusion Code: X10.
2020 Pi-Sunyer X, Shanahan W, Fain R, . Impact of lorcaserin on glycemic control in overweight and obese patients with type 2 diabetes: analysis of week 52 responders and nonresponders. Postgrad Med. 2016 Aug;128(6):591–7. doi: 10.1080/00325481.2016.1208618. PMID: 27389084. Exclusion Code: X2.27389084
2021 Polcwiartek C, Vang T, Bruhn CH, . Diabetic ketoacidosis in patients exposed to antipsychotics: a systematic literature review and analysis of Danish adverse drug event reports. Psychopharmacology (Berl). 2016 Oct;233(21–22):3663–72. doi: 10.1007/s00213-016-4411-x. PMID: 27592232. Exclusion Code: X8.27592232
2022 Polgreen LA, Anthony C, Carr L, . The effect of automated text messaging and goal setting on pedometer adherence and physical activity in patients with diabetes: A randomized controlled trial. PLoS One. 2018;13(5):e0195797. doi: 10.1371/journal.pone.0195797. PMID: 29718931. Exclusion Code: X5.29718931
2023 Polidori D, Mari A, Ferrannini E. Canagliflozin, a sodium glucose co-transporter 2 inhibitor, improves model-based indices of beta cell function in patients with type 2 diabetes. Diabetologia. 2014 May;57(5):891–901. doi: 10.1007/s00125-014-3196-x. PMID: 24585202. Exclusion Code: X8.24585202
2024 Ponzani P, Scardapane M, Nicolucci A, . Effectiveness and safety of liraglutide after three years of treatment. Minerva Endocrinol. 2016 Mar;41(1):35–42. PMID: 26878560. Exclusion Code: X2.26878560
2025 Pool ER, Dogar O, Lindsay RP, . Interventions for tobacco use cessation in people living with HIV and AIDS. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
2026 Portillo-Sanchez P, Bril F, Lomonaco R, . Effect of pioglitazone on bone mineral density in patients with nonalcoholic steatohepatitis: A 36-month clinical trial. J Diabetes. 2019 Mar;11(3):223–31. doi: 10.1111/1753-0407.12833. PMID: 30073778. Exclusion Code: X2.30073778
2027 Posadzki P, Mastellos N, Ryan R, . Automated telephone communication systems for preventive healthcare and management of long-term conditions. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
2028 Potts JE, Gray LJ, Brady EM, . The effect of glucagon-like peptide 1 receptor agonists on weight loss in type 2 diabetes: a systematic review and mixed treatment comparison meta-analysis. PLoS One. 2015;10(6):e0126769. doi: 10.1371/journal.pone.0126769. PMID: 26121478. Exclusion Code: X8.26121478
2029 Poulter NR. Blood pressure and glucose control in subjects with diabetes: new analyses from ADVANCE. J Hypertens Suppl. 2009 May;27(1):S3–8. doi: 10.1097/01.hjh.0000354417.70192.be. PMID: 19483505. Exclusion Code: X2.19483505
2030 Pouwels KB, Widyakusuma NN, Bos JH, . Association between statins and infections among patients with diabetes: a cohort and prescription sequence symmetry analysis. Pharmacoepidemiol Drug Saf. 2016 Oct;25(10):1124–30. doi: 10.1002/pds.4052. PMID: 27365184. Exclusion Code: X8.27365184
2031 Pownall HJ, Bray GA, Wagenknecht LE, . Changes in body composition over 8 years in a randomized trial of a lifestyle intervention: the look AHEAD study. Obesity (Silver Spring). 2015 Mar;23(3):565–72. doi: 10.1002/oby.21005. PMID: 25707379. Exclusion Code: X6.25707379
2032 Pownall HJ, Schwartz AV, Bray GA, . Changes in regional body composition over 8 years in a randomized lifestyle trial: The look AHEAD study. Obesity (Silver Spring). 2016 Sep;24(9):1899–905. doi: 10.1002/oby.21577. PMID: 27465756. Exclusion Code: X2.27465756
2033 Pradhan J, Rajbhandari S. One off structured dietary education can improve diabetes management in Nepal. Diabetologia. Conference: 53rd annual meeting of the european association for the study of diabetes, EASD 2017. Portugal. 2017;60(1 Supplement 1):S348. doi: 10.1007/s00125-017-4350-z. PMID: CN-01419050. Exclusion Code: X6.
2034 Prasanna Kumar KM, Phadke U, Brath H, . Effectiveness of vildagliptin versus other oral antidiabetes drugs as add-on to sulphonylurea monotherapy: Post hoc analysis from the EDGE study. Prim Care Diabetes. 2016 Dec;10(6):452–8. doi: 10.1016/j.pcd.2016.06.001. PMID: 27353459. Exclusion Code: X2.27353459
2035 Pratley R, Amod A, Hoff ST, . Oral semaglutide versus subcutaneous liraglutide and placebo in type 2 diabetes (PIONEER 4): a randomised, double-blind, phase 3a trial. Lancet. 2019 Jul 6;394(10192):39–50. doi: 10.1016/s0140-6736(19)31271-1. PMID: 31186120. Exclusion Code: X2.31186120
2036 Pratley R, Fleck P, Wilson C. Efficacy and safety of initial combination therapy with alogliptin plus metformin versus either as monotherapy in drug-naïve patients with type 2 diabetes: a randomized, double-blind, 6-month study. Diabetes, obesity & metabolism. 2014;16(7):613–21. doi: 10.1111/dom.12258. PMID: CN-00995644. Exclusion Code: X2.
2037 Pratley R, Rosenstock J, Heller S, . Similar glucose control and hypoglycemia but reduced glucose variability with glucose dependent and independent therapies in older patients with type 2 diabetes mellitus (T2DM). Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A229. doi: 10.2337/db16-861-1374. PMID: CN-01449958. Exclusion Code: X5.
2038 Pratley RE, Fleck P, Wilson C. Efficacy and safety of initial combination therapy with alogliptin plus metformin versus either as monotherapy in drug-naive patients with type 2 diabetes: a randomized, double-blind, 6-month study. Diabetes Obes Metab. 2014 Jul;16(7):613–21. doi: 10.1111/dom.12258. PMID: 24400655. Exclusion Code: X2.24400655
2039 Pratley RE, McCall T, Fleck PR, . Alogliptin use in elderly people: a pooled analysis from phase 2 and 3 studies. J Am Geriatr Soc. 2009;57(11):2011–9. doi: 10.1111/j.1532-5415.2009.02484.x. PMID: CN-01778561. Exclusion Code: X8.19793357
2040 Preiss D, Dawed A, Welsh P, . Sustained influence of metformin therapy on circulating glucagon-like peptide-1 levels in individuals with and without type 2 diabetes. Diabetes Obes Metab. 2017 Mar;19(3):356–63. doi: 10.1111/dom.12826. PMID: 27862873. Exclusion Code: X5.27862873
2041 Preiss D, Thomas L, Wojdyla D, . Prospective relationships between body weight and physical activity: an observational analysis from the NAVIGATOR study. BMJ open. 2015;5(8)doi: 10.1136/bmjopen-2015-007901. PMID: CN-01096866. Exclusion Code: X6.
2042 Prestes M, Gayarre MA, Elgart JF, . Multistrategic approach to improve quality of care of people with diabetes at the primary care level: Study design and baseline data. Prim Care Diabetes. 2017 Apr;11(2):193–200. doi: 10.1016/j.pcd.2016.12.002. PMID: 28065677. Exclusion Code: X6.28065677
2043 Proietto J, Roux C, Pi-Sunyer X, . Efficacy and safety of liraglutide 3.0mg for weight management in overweight and obese adults: the SCALE obesity and prediabetes, a randomised, double-blind and placebo-controlled trial. Obes Res Clin Pract. 2014;8(0):117. PMID: CN-01369466. Exclusion Code: X10.
2044 Protheroe J, Rathod T, Bartlam B, . The feasibility of health trainer improved patient self-management in patients with low health literacy and poorly controlled diabetes: a pilot randomised controlled trial. J Diabetes Res. 2016;2016:6903245. doi: 10.1155/2016/6903245. PMID: 27833922. Exclusion Code: X2.27833922
2045 Prudente S, Morini E, Lucchesi D, . IRS1 G972R missense polymorphism is associated with failure to oral antidiabetes drugs in white patients with type 2 diabetes from Italy. Diabetes. 2014 Sep;63(9):3135–40. doi: 10.2337/db13-1966. PMID: 24947357. Exclusion Code: X8.24947357
2046 Pscherer S, Chou E, Dippel FW, . Treatment persistence after initiating basal insulin in type 2 diabetes patients: A primary care database analysis. Prim Care Diabetes. 2015 Oct;9(5):377–84. doi: 10.1016/j.pcd.2015.01.011. PMID: 25701545. Exclusion Code: X6.25701545
2047 Ptaszynska A, Johnsson KM, Parikh SJ, . Safety profile of dapagliflozin for type 2 diabetes: pooled analysis of clinical studies for overall safety and rare events. Drug Saf. 2014 Oct;37(10):815–29. doi: 10.1007/s40264-014-0213-4. PMID: 25096959. Exclusion Code: X8.25096959
2048 Punthakee Z, Almeras N, Despres JP, . Impact of rosiglitazone on body composition, hepatic fat, fatty acids, adipokines and glucose in persons with impaired fasting glucose or impaired glucose tolerance: a sub-study of the DREAM trial. Diabet Med. 2014 Sep;31(9):1086–92. doi: 10.1111/dme.12512. PMID: 24890138. Exclusion Code: X6.24890138
2049 Pyka L, Kurek A, Strojek K, . Impact of concomitant type 2 diabetes mellitus and its treatment on long-term outcome in systolic heart failure patients. Kardiol Pol. 2016;74:185–6. PMID: CN-01727909. Exclusion Code: X2.26596897
2050 Qaseem A, Barry MJ, Humphrey LL, . Oral pharmacologic treatment of type 2 diabetes mellitus: a clinical practice guideline update from the American College of Physicians. Ann Intern Med. 2017 Feb 21;166(4):279–90. doi: 10.7326/m16-1860. PMID: 28055075. Exclusion Code: X8.28055075
2051 Qiao Q, Keinanen-Kiukaanniemi S, Rajala U, . Random capillary whole blood glucose test as a screening test for diabetes mellitus in a middle-aged population. Scand J Clin Lab Invest. 1995;55(1):3–8. PMID: CN-01762276. Exclusion Code: X4.7624734
2052 Qiu R, Balis D, Xie J, . Longer-term safety and tolerability of canagliflozin in patients with type 2 diabetes: a pooled analysis. Curr Med Res Opin. 2017 Mar;33(3):553–62. doi: 10.1080/03007995.2016.1271780. PMID: 27977934. Exclusion Code: X8.27977934
2053 Qiu R, Capuano G, Meininger G. Efficacy and safety of twice-daily treatment with canagliflozin, a sodium glucose co-transporter 2 inhibitor, added on to metformin monotherapy in patients with type 2 diabetes mellitus. Journal of clinical and translational endocrinology. 2014;1(2):54–60. doi: 10.1016/j.jcte.2014.04.001. PMID: CN-00995450. Exclusion Code: X2.29159083
2054 Quinn CC, Shardell MD, Terrin ML, . Mobile diabetes intervention for glycemic control in 45- to 64-year-old persons with type 2 diabetes. J Appl Gerontol. 2016 Feb;35(2):227–43. doi: 10.1177/0733464814542611. PMID: 25098253. Exclusion Code: X2.25098253
2055 Quinn S, Baur L, Garnett S, . Treatment of clinical insulin resistance in children: a systematic review (Structured abstract). Obesity Reviews; 2010. p. 722–30. Exclusion Code: X8.20003069
2056 Raben A. The preview intervention study-preliminary results from > 2,000 subjects on body weight and risk factors for type-2 diabetes. Annals of nutrition and metabolism. Conference: 21st international congress of nutrition, ICN 2017. Argentina. 2017;71(Supplement 2):122–3. doi: 10.1159/000480486. PMID: CN-01429001. Exclusion Code: X10.
2057 Raccah D, Miossec P, Esposito V, . Efficacy and safety of lixisenatide in elderly (>/=65 years old) and very elderly (>/=75 years old) patients with type 2 diabetes: an analysis from the GetGoal phase III programme. Diabetes Metab Res Rev. 2015 Feb;31(2):204–11. doi: 10.1002/dmrr.2588. PMID: 25115916. Exclusion Code: X8.25115916
2058 Radford NB, DeFina LF, Barlow CE, . Effect of fitness on incident diabetes from statin use in primary prevention. Atherosclerosis. 2015 Mar;239(1):43–9. doi: 10.1016/j.atherosclerosis.2014.12.051. PMID: 25568952. Exclusion Code: X5.25568952
2059 Radholm K, Figtree G, Perkovic V, . Canagliflozin and heart failure in type 2 diabetes mellitus: results from the CANVAS program. Circulation. 2018;138(5):458–68. doi: 10.1161/CIRCULATIONAHA.118.034222. PMID: CN-01935716. Exclusion Code: X2.29526832
2060 Radtke T, Nevitt SJ, Hebestreit H, . Physical exercise training for cystic fibrosis. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2061 Raebel MA, Ellis JL, Schroeder EB, . Intensification of antihyperglycemic therapy among patients with incident diabetes: a Surveillance Prevention and Management of Diabetes Mellitus (SUPREME-DM) study. Pharmacoepidemiol Drug Saf. 2014 Jul;23(7):699–710. doi: 10.1002/pds.3610. PMID: 24639086. Exclusion Code: X8.24639086
2062 Raff U, Ott C, Ruilope LM, . Prevention of electrocardiographic left ventricular remodeling by the angiotensin receptor blocker olmesartan in patients with type 2 diabetes. J Hypertens. 2014 Nov;32(11):2267–76; discussion 76. doi: 10.1097/hjh.0000000000000313. PMID: 25275251. Exclusion Code: X6.25275251
2063 Raghavan RP, Laight DW, Cummings MH. Aspirin in type 2 diabetes, a randomised controlled study: effect of different doses on inflammation, oxidative stress, insulin resistance and endothelial function. Int J Clin Pract. 2014 Feb;68(2):271–7. doi: 10.1111/ijcp.12310. PMID: 24372992. Exclusion Code: X6.24372992
2064 Rahman F, McEvoy JW, Ohkuma T, . Effects of Blood Pressure Lowering on Clinical Outcomes According to Baseline Blood Pressure and Cardiovascular Risk in Patients With Type 2 Diabetes Mellitus. Hypertension (dallas, tex. : 1979). 2019;73(6):1291–9. doi: 10.1161/HYPERTENSIONAHA.118.12414. PMID: CN-01941520. Exclusion Code: X2.
2065 Rajagopalan S, Dutta P, Hota D, . Effect of low dose pioglitazone on glycemic control and insulin resistance in Type 2 diabetes: A randomized, double blind, clinical trial. Diabetes Res Clin Pract. 2015 Sep;109(3):e32–5. doi: 10.1016/j.diabres.2015.05.030. PMID: 26254513. Exclusion Code: X5.26254513
2066 Rajpathak SN, Fu C, Brodovicz K, . Sulfonylurea monotherapy and emergency room utilization among elderly patients with type 2 diabetes. Diabetes Res Clin Pract. 2015 Sep;109(3):507–12. doi: 10.1016/j.diabres.2015.05.046. PMID: 26123984. Exclusion Code: X2.26123984
2067 Rajpathak SN, Fu C, Brodovicz KG, . Sulfonylurea use and risk of hip fractures among elderly men and women with type 2 diabetes. Drugs Aging. 2015 Apr;32(4):321–7. doi: 10.1007/s40266-015-0254-0. PMID: 25825122. Exclusion Code: X2.25825122
2068 Rajpathak SN, Rajgopalan S, Engel SS. Impact of time to treatment intensification on glycemic goal attainment among patients with type 2 diabetes failing metformin monotherapy. J Diabetes Complications. 2014 Nov–Dec;28(6):831–5. doi: 10.1016/j.jdiacomp.2014.06.004. PMID: 25104238. Exclusion Code: X8.25104238
2069 Raju A, Shetty S, Cai B, . Hypoglycemia incidence rates and associated health care costs in patients with type 2 diabetes mellitus treated with second-line linagliptin or sulfonylurea after metformin monotherapy. J Manag Care Spec Pharm. 2016 May;22(5):483–92. doi: 10.18553/jmcp.2016.22.5.483. PMID: 27123911. Exclusion Code: X5.27123911
2070 Ram J, Selvam S, Snehalatha C, . Improvement in diet habits, independent of physical activity helps to reduce incident diabetes among prediabetic Asian Indian men. Diabetes Res Clin Pract. 2014 Dec;106(3):491–5. doi: 10.1016/j.diabres.2014.09.043. PMID: 25458326. Exclusion Code: X7.25458326
2071 Ramadas A, Chan CKY, Oldenburg B, . Randomised-controlled trial of a web-based dietary intervention for patients with type 2 diabetes: changes in health cognitions and glycemic control. BMC Public Health. 2018 Jun 8;18(1):716. doi: 10.1186/s12889-018-5640-1. PMID: 29884161. Exclusion Code: X2.29884161
2072 Ramal E, Champlin A, Bahjri K. Impact of a Plant-Based Diet and Support on Mitigating Type 2 Diabetes Mellitus in Latinos Living in Medically Underserved Areas. Am J Health Promot. 2018 Mar;32(3):753–62. doi: 10.1177/0890117117706793. PMID: 28503930. Exclusion Code: X2.28503930
2073 Ramallo-Farina Y, Garcia-Perez L, Castilla-Rodriguez I, . Effectiveness and cost-effectiveness of knowledge transfer and behavior modification interventions in type 2 diabetes mellitus patients--the INDICA study: a cluster randomized controlled trial. Implement Sci. 2015 Apr 9;10:47. doi: 10.1186/s13012-015-0233-1. PMID: 25880498. Exclusion Code: X6.25880498
2074 Raman RP, Taiyeb-Ali TB, Chan SP, . Effect of nonsurgical periodontal therapy verses oral hygiene instructions on type 2 diabetes subjects with chronic periodontitis: a randomised clinical trial. BMC Oral Health. 2014 Jun 25;14:79. doi: 10.1186/1472-6831-14-79. PMID: 24965218. Exclusion Code: X4.24965218
2075 Ramos IR, Jimenez-Lucena R, Lopez-Moreno J, . Alpha cell function interacts with diet to modulate prediabetes and type 2 diabetes. Eur J Clin Invest. 2018;48:205–6. doi: 10.1111/eci.12926. PMID: CN-01619812. Exclusion Code: X5.
2076 Ramos R, Comas-Cufi M, Marti-Lluch R, . Statins for primary prevention of cardiovascular events and mortality in old and very old adults with and without type 2 diabetes: retrospective cohort study. Bmj. 2018 Sep 5;362:k3359. doi: 10.1136/bmj.k3359. PMID: 30185425. Exclusion Code: X8.30185425
2077 Ranasinghe C, Hills A, Constantine G, . Study protocol: a randomised controlled trial of supervised resistance training versus aerobic training in Sri Lankan adults with type 2 diabetes mellitus: sL-DART study. BMC public health. 2018;18(1):176. doi: 10.1186/s12889-018-5069-6. PMID: CN-01599611. Exclusion Code: X5.29368598
2078 Ranasinghe P, Jayawardena R, Chandrasena L, . Effects of Lysulin supplementation on pre-diabetes: study protocol for a randomized controlled trial. Trials. 2019 Mar 18;20(1):171. doi: 10.1186/s13063-019-3269-8. PMID: 30885259. Exclusion Code: X6.30885259
2079 Ranjani H, Staimez LR, Weber MB, . Reversal of prediabetes to normal glucose regulation in the diabetes community lifestyle improvement program (D-CLIP) translation trial in India. Diabetes. 2017;66:A462-. PMID: CN-01771601. Exclusion Code: X6.
2080 Ranjani H, Weber MB, Anjana RM, . Recruitment challenges in a diabetes prevention trial in a low- and middle-income setting. Diabetes Res Clin Pract. 2015 Oct;110(1):51–9. doi: 10.1016/j.diabres.2015.07.013. PMID: 26321102. Exclusion Code: X6.26321102
2081 Rao U, de Vries B, Ross GP, . Fetal biometry for guiding the medical management of women with gestational diabetes mellitus for improving maternal and perinatal health. Cochrane Database of Systematic Reviews. 2019(9)doi: 10.1002/14651858.CD012544.pub2. PMID: CD012544. Exclusion Code: X8.
2082 Rapp S, Carmichael O, Hayden K, . Long-term impact of weight loss intervention on changes in cognitive function: exploratory analyses from the action for health in diabetes randomized controlled clinical trial. Alzheimer’s & dementia. 2017;13(7):870–1. PMID: CN-01457749. Exclusion Code: X2.
2083 Rapp SR, Luchsinger JA, Baker LD, . Effect of a long-term intensive lifestyle intervention on cognitive function: action for health in diabetes study. J Am Geriatr Soc. 2017 May;65(5):966–72. doi: 10.1111/jgs.14692. PMID: 28067945. Exclusion Code: X2.28067945
2084 Raschi E, Poluzzi E, Koci A, . Dipeptidyl peptidase-4 inhibitors and heart failure: Analysis of spontaneous reports submitted to the FDA Adverse Event Reporting System. Nutr Metab Cardiovasc Dis. 2016 May;26(5):380–6. doi: 10.1016/j.numecd.2016.02.006. PMID: 27067162. Exclusion Code: X2.27067162
2085 Rashed OA, Sabbah HA, Younis MZ, . Diabetes education program for people with type 2 diabetes: An international perspective. Eval Program Plann. 2016 Jun;56:64–8. doi: 10.1016/j.evalprogplan.2016.02.002. PMID: 27060766. Exclusion Code: X8.27060766
2086 Rasmussen SS, Glumer C, Sandbaek A, . General effect on high-risk persons when general practitioners are trained in intensive treatment of type 2 diabetes. Scand J Prim Health Care. 2008;26(3):166–73. doi: 10.1080/02813430802264624. PMID: 18677673. Exclusion Code: X4.18677673
2087 Rathmann W, Bongaerts B, Kostev K. Change in glycated haemoglobin levels after initiating second-line therapy in type 2 diabetes: a primary care database study. Diabetes Obes Metab. 2016 Aug;18(8):840–3. doi: 10.1111/dom.12673. PMID: 27062643. Exclusion Code: X8.27062643
2088 Rathmann W, Kostev K. Association of dipeptidyl peptidase 4 inhibitors with risk of metastases in patients with type 2 diabetes and breast, prostate or digestive system cancer. J Diabetes Complications. 2017 Apr;31(4):687–92. doi: 10.1016/j.jdiacomp.2017.01.012. PMID: 28169131. Exclusion Code: X2.28169131
2089 Ratner RE. An update on the diabetes prevention program. Endocrine practice. 2006;12(SUPPL. 1):20–4. PMID: CN-01762712. Exclusion Code: X8.16627375
2090 Rautio N, Jokelainen J, Oksa H, . Changes in glucose metabolism in people with different glucose metabolism disorders at baseline: follow-up results of a Finnish national diabetes prevention programme. Diabet Med. 2015 Dec;32(12):1611–6. doi: 10.1111/dme.12776. PMID: 25864699. Exclusion Code: X8.25864699
2091 Rautio N, Jokelainen J, Polonen A, . Changes in lifestyle modestly reduce the estimated cardiovascular disease risk in one-year follow-up of the Finnish diabetes prevention program (FIN-D2D). Eur J Cardiovasc Nurs. 2015 Apr;14(2):145–52. doi: 10.1177/1474515114521713. PMID: 24452452. Exclusion Code: X5.24452452
2092 Raval AD, Mattes MD, Madhavan S, . Association between metformin use and cancer stage at diagnosis among elderly medicare beneficiaries with preexisting type 2 diabetes mellitus and incident prostate cancer. J Diabetes Res. 2016;2016:2656814. doi: 10.1155/2016/2656814. PMID: 27547763. Exclusion Code: X2.27547763
2093 Ray KK, Leiter LA, Muller-Wieland D, . Alirocumab vs usual lipid-lowering care as add-on to statin therapy in individuals with type 2 diabetes and mixed dyslipidaemia: The ODYSSEY DM-DYSLIPIDEMIA randomized trial. Diabetes Obes Metab. 2018 Jun;20(6):1479–89. doi: 10.1111/dom.13257. PMID: 29436756. Exclusion Code: X2.29436756
2094 Ray KK, Seshasai SR, Wijesuriya S, . Effect of intensive control of glucose on cardiovascular outcomes and death in patients with diabetes mellitus: a meta-analysis of randomised controlled trials. Lancet. 2009 May 23;373(9677):1765–72. doi: 10.1016/S0140-6736(09)60697-8. PMID: 19465231. Exclusion Code: X8.19465231
2095 Raynor HA, Anderson AM, Miller GD, . Partial meal replacement plan and quality of the diet at 1 year: Action for Health in Diabetes (Look AHEAD) Trial. J Acad Nutr Diet. 2015 May;115(5):731–42. doi: 10.1016/j.jand.2014.11.003. PMID: 25573655. Exclusion Code: X6.25573655
2096 Raz I, Bhatt DL, Hirshberg B, . Incidence of pancreatitis and pancreatic cancer in a randomized controlled multicenter trial (SAVOR-TIMI 53) of the dipeptidyl peptidase-4 inhibitor saxagliptin. Diabetes Care. 2014 Sep;37(9):2435–41. doi: 10.2337/dc13-2546. PMID: 24914244. Exclusion Code: X2.24914244
2097 Reale R, Tumminia A, Romeo L, . Short-term efficacy of high intensity group and individual education in patients with type 2 diabetes: a randomized single-center trial. J Endocrinol Invest. 2019 Apr;42(4):403–9. doi: 10.1007/s40618-018-0929-6. PMID: 30097902. Exclusion Code: X2.30097902
2098 Reaney M, Yu M, Lakshmanan M, . Treatment satisfaction in people with type 2 diabetes mellitus treated with once-weekly dulaglutide: data from the AWARD-1 and AWARD-3 clinical trials. Diabetes Obes Metab. 2015 Sep;17(9):896–903. doi: 10.1111/dom.12527. PMID: 26095190. Exclusion Code: X2.26095190
2099 Reboldi G, Gentile G, Angeli F, . Effects of intensive blood pressure reduction on myocardial infarction and stroke in diabetes: a meta-analysis in 73,913 patients. J Hypertens. 2011 Jul;29(7):1253–69. doi: 10.1097/HJH.0b013e3283469976. PMID: 21505352. Exclusion Code: X8.21505352
2100 Reed SD, Li Y, Dakin HA, . Exscel-once-weekly exenatide reduces medical resource utilization in patients with type 2 diabetes mellitus. Diabetes. 2018;67:A354-. PMID: CN-01631349. Exclusion Code: X6.
2101 Reed SD, Li Y, Leal J, . Longitudinal medical resources and costs among type 2 diabetes patients participating in the Trial Evaluating Cardiovascular Outcomes with Sitagliptin (TECOS). Diabetes Obes Metab. 2018 Jul;20(7):1732–9. doi: 10.1111/dom.13292. PMID: 29573215. Exclusion Code: X2.29573215
2102 Reeds J, Mansuri S, Mamakeesick M, . Dietary patterns and type 2 diabetes mellitus in a first nations community. Can J Diabetes. 2016 Aug;40(4):304–10. doi: 10.1016/j.jcjd.2016.05.001. PMID: 27374251. Exclusion Code: X2.27374251
2103 Reid T, Gao L, Gill J, . How much is too much? Outcomes in patients using high-dose insulin glargine. Int J Clin Pract. 2016;70(1):56–65. doi: 10.1111/ijcp.12747. PMID: CN-01198681. Exclusion Code: X8.26566714
2104 Rejeski WJ, Bray GA, Chen SH, . Aging and physical function in type 2 diabetes: 8 years of an intensive lifestyle intervention. J Gerontol A Biol Sci Med Sci. 2015 Mar;70(3):345–53. doi: 10.1093/gerona/glu083. PMID: 24986062. Exclusion Code: X2.24986062
2105 Retnakaran R, Kramer CK, Choi H, . Liraglutide and the preservation of pancreatic beta-cell function in early type 2 diabetes: the LIBRA trial. Diabetes Care. 2014 Dec;37(12):3270–8. doi: 10.2337/dc14-0893. PMID: 25249651. Exclusion Code: X2.25249651
2106 Reusch J, Stewart MW, Perkins CM, . Efficacy and safety of once-weekly glucagon-like peptide 1 receptor agonist albiglutide (HARMONY 1 trial): 52-week primary endpoint results from a randomized, double-blind, placebo-controlled trial in patients with type 2 diabetes mellitus not controlled on pioglitazone, with or without metformin. Diabetes Obes Metab. 2014 Dec;16(12):1257–64. doi: 10.1111/dom.12382. PMID: 25155146. Exclusion Code: X2.25155146
2107 Rezaei S, Shamsi M, Mahdavi M, . Endurance exercise training decreased serum levels of surfactant protein D and improved aerobic fitness of obese women with type-2 diabetes Fred DiMenna. Diabetology & metabolic syndrome. 2017;9(1) (no pagination)doi: 10.1186/s13098-017-0273-6. PMID: CN-01423503. Exclusion Code: X6.
2108 Rhee SJ, Choi Y, Lee S, . Pharmacokinetic and pharmacodynamic interactions between metformin and a novel dipeptidyl peptidase-4 inhibitor, evogliptin, in healthy subjects. Drug Des Devel Ther. 2016;10:2525–34. doi: 10.2147/dddt.s110712. PMID: 27570447. Exclusion Code: X2.27570447
2109 Ricci C, Gaeta M, Rausa E, . Early impact of bariatric surgery on type II diabetes, hypertension, and hyperlipidemia: a systematic review, meta-analysis and meta-regression on 6,587 patients. Obes Surg. 2014 Apr;24(4):522–8. doi: 10.1007/s11695-013-1121-x. PMID: 24214202. Exclusion Code: X8.24214202
2110 Rice S, Cranch H, Littlemore K, . A pilot service-evaluation examining change in HbA1c related to the prescription of internet-based education films for type 2 diabetes. Prim Care Diabetes. 2017 Jun;11(3):305–8. doi: 10.1016/j.pcd.2017.02.002. PMID: 28291678. Exclusion Code: X5.28291678
2111 Richter B, Hemmingsen B, Metzendorf M-I, . Intermediate hyperglycaemia as a predictor for the development of type 2 diabetes: prognostic factor exemplar review. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2112 Richy FF, Sabido-Espin M, Guedes S, . Incidence of lactic acidosis in patients with type 2 diabetes with and without renal impairment treated with metformin: a retrospective cohort study. Diabetes Care. 2014 Aug;37(8):2291–5. doi: 10.2337/dc14-0464. PMID: 24879835. Exclusion Code: X8.24879835
2113 Riddell MA, Dunbar JA, Absetz P, . Cardiovascular risk outcome and program evaluation of a cluster randomised controlled trial of a community-based, lay peer led program for people with diabetes. BMC Public Health. 2016 Aug 24;16(1):864. doi: 10.1186/s12889-016-3538-3. PMID: 27558630. Exclusion Code: X2.27558630
2114 Ridderstrale M, Andersen KR, Zeller C, . Comparison of empagliflozin and glimepiride as add-on to metformin in patients with type 2 diabetes: a 104-week randomised, active-controlled, double-blind, phase 3 trial. Lancet Diabetes Endocrinol. 2014 Sep;2(9):691–700. doi: 10.1016/s2213-8587(14)70120-2. PMID: 24948511. Exclusion Code: X5.24948511
2115 Ridker PM, Cook NR, Lee IM, . A randomized trial of low-dose aspirin in the primary prevention of cardiovascular disease in women. N Engl J Med. 2005 Mar 31;352(13):1293–304. doi: 10.1056/NEJMoa050613. PMID: 15753114. Exclusion Code: X2.15753114
2116 Riediger ND, Bombak AE, Mudryj A, . A systematic search and qualitative review of reporting bias of lifestyle interventions in randomized controlled trials of diabetes prevention and management. Nutr J. 2018 Sep 7;17(1):83. doi: 10.1186/s12937-018-0390-6. PMID: 30193589. Exclusion Code: X8.30193589
2117 Ried-Larsen M, Christensen R, Hansen KB, . Head-to-head comparison of intensive lifestyle intervention (U-TURN) versus conventional multifactorial care in patients with type 2 diabetes: protocol and rationale for an assessor-blinded, parallel group and randomised trial. BMJ Open. 2015 Dec 9;5(12):e009764. doi: 10.1136/bmjopen-2015-009764. PMID: 26656025. Exclusion Code: X6.26656025
2118 Rigato M, Avogaro A, Fadini GP. Effects of dose escalating liraglutide from 1.2 to 1.8 mg in clinical practice: a case-control study. J Endocrinol Invest. 2015 Dec;38(12):1357–63. doi: 10.1007/s40618-015-0385-5. PMID: 26328783. Exclusion Code: X8.26328783
2119 Ring M, Eriksson M, Fritz T, . Influence of physical activity and gender on arterial function in type 2 diabetes, normal and impaired glucose tolerance. Diab Vasc Dis Res. 2015;12(5 // *Stockholms Lans Landsting*):315–24. doi: 10.1177/1479164115588548. PMID: CN-01091158. Exclusion Code: X6.26092821
2120 Riphagen IJ, Deetman PE, Bakker SJ, . Bilirubin and progression of nephropathy in type 2 diabetes: a post hoc analysis of RENAAL with independent replication in IDNT. Diabetes. 2014 Aug;63(8):2845–53. doi: 10.2337/db13-1652. PMID: 24677717. Exclusion Code: X6.24677717
2121 Risoy AJ, Kjome RLS, Sandberg S, . Risk assessment and HbA1c measurement in Norwegian community pharmacies to identify people with undiagnosed type 2 diabetes - A feasibility study. PLoS One. 2018;13(2):e0191316. doi: 10.1371/journal.pone.0191316. PMID: 29474501. Exclusion Code: X5.29474501
2122 Rizvi AA, Patti AM, Giglio RV, . Liraglutide improves carotid intima-media thickness in patients with type 2 diabetes and non-alcoholic fatty liver disease: an 8-month prospective pilot study. Expert Opin Biol Ther. 2015;15(10):1391–7. doi: 10.1517/14712598.2015.1067299. PMID: 26195184. Exclusion Code: X8.26195184
2123 Rizzo M, Chandalia M, Patti AM, . Liraglutide decreases carotid intima-media thickness in patients with type 2 diabetes: 8-month prospective pilot study. Cardiovasc Diabetol. 2014 Feb 22;13:49. doi: 10.1186/1475-2840-13-49. PMID: 24559258. Exclusion Code: X2.24559258
2124 Rizzo MR, Barbieri M, Fava I, . Sarcopenia in elderly diabetic patients: role of dipeptidyl peptidase 4 inhibitors. J Am Med Dir Assoc. 2016 Oct 1;17(10):896–901. doi: 10.1016/j.jamda.2016.04.016. PMID: 27262494. Exclusion Code: X2.27262494
2125 Rock CL, Flatt SW, Pakiz B, . Weight loss, glycemic control, and cardiovascular disease risk factors in response to differential diet composition in a weight loss program in type 2 diabetes: a randomized controlled trial. Diabetes Care. 2014 Jun;37(6):1573–80. doi: 10.2337/dc13-2900. PMID: 24760261. Exclusion Code: X2.24760261
2126 Rockette-Wagner B, Edelstein S, Venditti EM, . The impact of lifestyle intervention on sedentary time in individuals at high risk of diabetes. Diabetologia. 2015 Jun;58(6):1198–202. doi: 10.1007/s00125-015-3565-0. PMID: 25851102. Exclusion Code: X6.25851102
2127 Rockette-Wagner B, Storti KL, Dabelea D, . Activity and sedentary time 10 years after a successful lifestyle intervention: the Diabetes Prevention Program. Am J Prev Med. 2017 Mar;52(3):292–9. doi: 10.1016/j.amepre.2016.10.007. PMID: 27887769. Exclusion Code: X6.27887769
2128 Rodbard H, Bode B, Harris S, . Safety and efficacy of insulin degludec/liraglutide (IDegLira) added to sulphonylurea alone or to sulphonylurea and metformin in insulin-naïve people with Type 2 diabetes: the DUAL IV trial. Diabetic medicine. 2017;34(2):189–96. doi: 10.1111/dme.13256. PMID: CN-01298615. Exclusion Code: X2.27589252
2129 Rodbard HW, Bode BW, Harris SB, . Safety and efficacy of insulin degludec/liraglutide (IDegLira) added to sulphonylurea alone or to sulphonylurea and metformin in insulin-naive people with Type 2 diabetes: the DUAL IV trial. Diabet Med. 2017 Feb;34(2):189–96. doi: 10.1111/dme.13256. PMID: 27589252. Exclusion Code: X2.27589252
2130 Rodbard HW, Buse JB, Woo V, . Benefits of combination of insulin degludec and liraglutide are independent of baseline glycated haemoglobin level and duration of type 2 diabetes. Diabetes Obes Metab. 2016 Jan;18(1):40–8. doi: 10.1111/dom.12574. PMID: 26343931. Exclusion Code: X8.26343931
2131 Roden M, Merker L, Christiansen A, . Safety, tolerability and effects on cardiometabolic risk factors of empagliflozin monotherapy in drug-naïve patients with type 2 diabetes: a double-blind extension of a Phase III randomized controlled trial. Cardiovasc Diabetol. 2015;14:154. doi: 10.1186/s12933-015-0314-0. PMID: CN-01168578. Exclusion Code: X2.26701110
2132 Roden M, Merker L, Christiansen AV, . Safety, tolerability and effects on cardiometabolic risk factors of empagliflozin monotherapy in drug-naive patients with type 2 diabetes: a double-blind extension of a Phase III randomized controlled trial. Cardiovasc Diabetol. 2015 Dec 23;14:154. doi: 10.1186/s12933-015-0314-0. PMID: 26701110. Exclusion Code: X2.26701110
2133 Rodriguez-Cano A, Mier-Cabrera J, Balas-Nakash M, . Dietary changes associated with improvement of metabolic syndrome components in postmenopausal women receiving two different nutrition interventions. Menopause (new york, N.Y.). 2015;22(7):758–64. doi: 10.1097/GME.0000000000000400. PMID: CN-01255167. Exclusion Code: X5.
2134 Rodriguez-Gutierrez R, Montes-Villarreal J, Rodriguez-Velver KV, . Metformin use and vitamin B12 deficiency: untangling the association. Am J Med Sci. 2017 Aug;354(2):165–71. doi: 10.1016/j.amjms.2017.04.010. PMID: 28864375. Exclusion Code: X8.28864375
2135 Roerink ME, Meijering R, Bosch M, . Diabetes in patients with HIV: patient characteristics, management and screening. Neth J Med. 2015 Aug;73(7):310–5. PMID: 26314713. Exclusion Code: X8.26314713
2136 Rohwedder K, Johnsson E, Parikh S. Reduced risk of hypoglycaemic events with dapagliflozin vs glipizide as add-on therapy in type 2 diabetes mellitus: 4-year data from a phase 3 study. Diabetologia. 2014;57(1 suppl. 1):S326. doi: 10.1007/s00125-014-3355-0. PMID: CN-01059176. Exclusion Code: X5.
2137 Rohwedder K, Parikh S, Johnsson E. Lower risk of hypoglycemic events with dapagliflozin than glipizide over 4 years in a phase 3 study. Diabetes. 2014;63:A563–a4. doi: 10.2337/db14-2207-2292. PMID: CN-01065470. Exclusion Code: X2.
2138 Rojas A, Sposetti G, Gross J, . Insulin lispro low mixture twice daily vs basal insulin glargine once daily and prandial insulin lispro once daily as insulin intensification strategies in patients with type 2 diabetes: latin American subpopulation analysis of a randomized trial. Diabetology & metabolic syndrome. 2016;8(1) (no pagination)doi: 10.1186/s13098-016-0163-3. PMID: CN-01208811. Exclusion Code: X2.
2139 Rolim L, da Silva EMK, Flumignan RLG, . Acetyl-L-carnitine for the treatment of diabetic peripheral neuropathy. Cochrane Database of Systematic Reviews. 2019(6)doi: 10.1002/14651858.CD011265.pub2. PMID: CD011265. Exclusion Code: X8.
2140 Rollo M, Aguiar E, Pursey K, . Impact on dietary intake of a self-directed, gender-tailored diabetes prevention program in men. World journal of diabetes. 2017;8(8):414–21. doi: 10.4239/wjd.v8.i8.414. PMID: CN-01418346. Exclusion Code: X6.28861179
2141 Romanelli RJ, Chung S, Pu J, . Comparative effectiveness of early versus delayed metformin in the treatment of type 2 diabetes. Diabetes Res Clin Pract. 2015 Apr;108(1):170–8. doi: 10.1016/j.diabres.2014.12.019. PMID: 25661984. Exclusion Code: X8.25661984
2142 Romera I, Ampudia-Blasco FJ, Perez A, . Efficacy and safety of empagliflozin in combination with other oral hypoglycemic agents in patients with type 2 diabetes mellitus. Endocrinol Nutr. 2016 Dec;63(10):519–26. doi: 10.1016/j.endonu.2016.06.003. PMID: 27578024. Exclusion Code: X8.27578024
2143 Romera I, Gomis R, Crowe S, . Empagliflozin in combination with oral agents in young and overweight/obese Type 2 diabetes mellitus patients: A pooled analysis of three randomized trials. J Diabetes Complications. 2016 Nov – Dec;30(8):1571–6. doi: 10.1016/j.jdiacomp.2016.07.016. PMID: 27499456. Exclusion Code: X2.27499456
2144 Romley JA, Gong C, Jena AB, . Association between use of warfarin with common sulfonylureas and serious hypoglycemic events: retrospective cohort analysis. Bmj. 2015 Dec 7;351:h6223. doi: 10.1136/bmj.h6223. PMID: 26643108. Exclusion Code: X2.26643108
2145 Ronsein GE, Reyes-Soffer G, He Y, . Targeted proteomics identifies paraoxonase/arylesterase 1 (PON1) and apolipoprotein Cs as potential risk factors for hypoalphalipoproteinemia in diabetic subjects treated with fenofibrate and rosiglitazone. Mol Cell Proteomics. 2016 Mar;15(3):1083–93. doi: 10.1074/mcp.M115.054528. PMID: 26667175. Exclusion Code: X5.26667175
2146 Roquer J, Rodriguez-Campello A, Cuadrado-Godia E, . The role of HbA1c determination in detecting unknown glucose disturbances in ischemic stroke. PLoS One. 2014;9(12):e109960. doi: 10.1371/journal.pone.0109960. PMID: 25485761. Exclusion Code: X2.25485761
2147 Rosales R, Abou Jaoude E, Al-Arouj M, . Clinical effectiveness and safety of vildagliptin in >19 000 patients with type 2 diabetes: the GUARD study. Diabetes Obes Metab. 2015 Jun;17(6):603–7. doi: 10.1111/dom.12436. PMID: 25586779. Exclusion Code: X2.25586779
2148 Rosales R, Domingo F, Javier J. Effectiveness, safety and tolerability of vildagliptin and vildagliptin + metformin in real-world setting in the philippines-results from the guard study. Phillippine journal of internal medicine. 2016;54(4) (no pagination)PMID: CN-01297396. Exclusion Code: X2.
2149 Rosas L, Lv N, Xiao L, . Evaluation of a culturally-adapted lifestyle intervention to treat elevated cardiometabolic risk of Latino adults in primary care (Vida Sana): a randomized controlled trial. Contemp Clin Trials. 2016;48:30–40. doi: 10.1016/j.cct.2016.03.003. PMID: CN-01140704. Exclusion Code: X6.26995280
2150 Rosas L, Vasquez J, Naderi R, . Development and evaluation of an enhanced diabetes prevention program with psychosocial support for urban American Indians and Alaska natives: a randomized controlled trial. Contemp Clin Trials. 2016;50:28–36. doi: 10.1016/j.cct.2016.06.015. PMID: CN-01178624. Exclusion Code: X6.27381232
2151 Rosenson RS, Rigby SP, Jones MR, . Effect of colesevelam HCl monotherapy on lipid particles in type 2 diabetes mellitus. Cardiovasc Drugs Ther. 2014 Jun;28(3):229–36. doi: 10.1007/s10557-014-6516-y. PMID: 24710760. Exclusion Code: X2.24710760
2152 Rosenstock J, Cefalu WT, Lapuerta P, . Greater dose-ranging effects on A1C levels than on glucosuria with LX4211, a dual inhibitor of SGLT1 and SGLT2, in patients with type 2 diabetes on metformin monotherapy. Diabetes Care. 2015 Mar;38(3):431–8. doi: 10.2337/dc14-0890. PMID: 25216510. Exclusion Code: X2.25216510
2153 Rosenstock J, Chuck L, Gonzalez-Ortiz M, . Initial combination therapy with canagliflozin plus metformin versus each component as monotherapy for drug-naive type 2 diabetes. Diabetes Care. 2016 Mar;39(3):353–62. doi: 10.2337/dc15-1736. PMID: 26786577. Exclusion Code: X2.26786577
2154 Rosenstock J, Chuck L, González-Ortiz M, . Initial combination therapy with canagliflozin plus metformin versus each component as monotherapy for drug-naïve type 2 diabetes. Diabetes care. 2016;39(3):353–62. doi: 10.2337/dc15-1736. PMID: CN-01259828. Exclusion Code: X2.26786577
2155 Rosenstock J, Fonseca VA, Gross JL, . Advancing basal insulin replacement in type 2 diabetes inadequately controlled with insulin glargine plus oral agents: a comparison of adding albiglutide, a weekly GLP-1 receptor agonist, versus thrice-daily prandial insulin lispro. Diabetes Care. 2014 Aug;37(8):2317–25. doi: 10.2337/dc14-0001. PMID: 24898300. Exclusion Code: X2.24898300
2156 Rosenstock J, Franco D, Korpachev V, . Inhaled technosphere insulin versus inhaled technosphere placebo in insulin-naïve subjects with type 2 diabetes inadequately controlled on oral antidiabetes agents. Diabetes care. 2015;38(12):2274–81. doi: 10.2337/dc15-0629. PMID: CN-01140760. Exclusion Code: X2.26253730
2157 Rosenstock J, Franco D, Korpachev V, . Inhaled technosphere insulin versus inhaled technosphere placebo in insulin-naive subjects with type 2 diabetes inadequately controlled on oral antidiabetes agents. Diabetes Care. 2015 Dec;38(12):2274–81. doi: 10.2337/dc15-0629. PMID: 26253730. Exclusion Code: X5.26253730
2158 Rosenstock J, Frias J, Pall D, . Effect of ertugliflozin on glucose control, body weight, blood pressure and bone density in type 2 diabetes mellitus inadequately controlled on metformin monotherapy (VERTIS MET). Diabetes Obes Metab. 2018 Mar;20(3):520–9. doi: 10.1111/dom.13103. PMID: 28857451. Exclusion Code: X2.28857451
2159 Rosenstock J, Hanefeld M, Shamanna P, . Beneficial effects of once-daily lixisenatide on overall and postprandial glycemic levels without significant excess of hypoglycemia in type 2 diabetes inadequately controlled on a sulfonylurea with or without metformin (GetGoal-S). J Diabetes Complications. 2014 May–Jun;28(3):386–92. doi: 10.1016/j.jdiacomp.2014.01.012. PMID: 24650952. Exclusion Code: X2.24650952
2160 Rosenstock J, Hansen L, Zee P, . Dual add-on therapy in type 2 diabetes poorly controlled with metformin monotherapy: a randomized double-blind trial of saxagliptin plus dapagliflozin addition versus single addition of saxagliptin or dapagliflozin to metformin. Diabetes Care. 2015 Mar;38(3):376–83. doi: 10.2337/dc14-1142. PMID: 25352655. Exclusion Code: X2.25352655
2161 Rosenstock J, Marx N, Neubacher D, . Cardiovascular safety of linagliptin in type 2 diabetes: a comprehensive patient-level pooled analysis of prospectively adjudicated cardiovascular events. Cardiovasc Diabetol. 2015 May 21;14:57. doi: 10.1186/s12933-015-0215-2. PMID: 25990013. Exclusion Code: X8.25990013
2162 Rosenstock J, Perkovic V, Alexander JH, . Rationale, design, and baseline characteristics of the CArdiovascular safety and Renal Microvascular outcomE study with LINAgliptin (CARMELINA((R))): a randomized, double-blind, placebo-controlled clinical trial in patients with type 2 diabetes and high cardio-renal risk. Cardiovasc Diabetol. 2018 Mar 14;17(1):39. doi: 10.1186/s12933-018-0682-3. PMID: 29540217. Exclusion Code: X2.29540217
2163 Rosenstock J, Perkovic V, Johansen OE, . Effect of Linagliptin vs Placebo on Major Cardiovascular Events in Adults With Type 2 Diabetes and High Cardiovascular and Renal Risk: The CARMELINA Randomized Clinical Trial. Jama. 2019 Jan 1;321(1):69–79. doi: 10.1001/jama.2018.18269. PMID: 30418475. Exclusion Code: X2.30418475
2164 Rosenstock J, Rigby S, Ford D, . The glucose and lipid effects of colesevelam as monotherapy in drug-naïve type 2 diabetes. Hormon- und Stoffwechselforschung / Hormones et metabolisme [Hormone and metabolic research]. 2014;46(5):348–53. doi: 10.1055/s-0033-1358759. PMID: CN-00993580. Exclusion Code: X4.
2165 Rosenstock J, Rigby SP, Ford DM, . The glucose and lipid effects of colesevelam as monotherapy in drug-naive type 2 diabetes. Horm Metab Res. 2014 May;46(5):348–53. doi: 10.1055/s-0033-1358759. PMID: 24356792. Exclusion Code: X2.24356792
2166 Rosenstock J, Truitt KE, Baz-Hecht M, . Efficacy and safety of colesevelam in combination with pioglitazone in patients with type 2 diabetes mellitus. Horm Metab Res. 2014 Dec;46(13):943–9. doi: 10.1055/s-0034-1383648. PMID: 25054436. Exclusion Code: X2.25054436
2167 Rosety-Rodriguez M, Rosety J, Fornieles G, . Home-based treadmill training improved seminal quality in adults with type 2 diabetes. Actas urologicas espanolas. 2014;38(9):589–93. doi: 10.1016/j.acuro.2013.10.013. PMID: CN-01253815. Exclusion Code: X6.24612998
2168 Ross S, Thamer C, Cescutti J, . Efficacy and safety of empagliflozin twice daily versus once daily in patients with type 2 diabetes inadequately controlled on metformin: a 16-week, randomized, placebo-controlled trial. Diabetes Obes Metab. 2015 Jul;17(7):699–702. doi: 10.1111/dom.12469. PMID: 25827441. Exclusion Code: X2.25827441
2169 Ross SA, Caballero AE, Del Prato S, . Linagliptin plus metformin in patients with newly diagnosed type 2 diabetes and marked hyperglycemia. Postgrad Med. 2016 Nov;128(8):747–54. doi: 10.1080/00325481.2016.1238280. PMID: 27684308. Exclusion Code: X5.27684308
2170 Rossen J, Buman MP, Johansson UB, . Reallocating bouted sedentary time to non-bouted sedentary time, light activity and moderate-vigorous physical activity in adults with prediabetes and type 2 diabetes. PLoS One. 2017;12(7):e0181053. doi: 10.1371/journal.pone.0181053. PMID: 28753626. Exclusion Code: X8.28753626
2171 Rossen J, Yngve A, Hagstromer M, . Physical activity promotion in the primary care setting in pre- and type 2 diabetes - the Sophia step study, an RCT. BMC Public Health. 2015 Jul 12;15:647. doi: 10.1186/s12889-015-1941-9. PMID: 26164092. Exclusion Code: X6.26164092
2172 Rotroff DM, Yee SW, Zhou K, . Genetic Variants in CPA6 and PRPF31 Are Associated With Variation in Response to Metformin in Individuals With Type 2 Diabetes. Diabetes. 2018 Jul;67(7):1428–40. doi: 10.2337/db17-1164. PMID: 29650774. Exclusion Code: X8.29650774
2173 Roumie CL, Min JY, Greevy RA, . Risk of hypoglycemia following intensification of metformin treatment with insulin versus sulfonylurea. Cmaj. 2016 Apr 5;188(6):E104–12. doi: 10.1503/cmaj.150904. PMID: 26811361. Exclusion Code: X2.26811361
2174 Round EM, Engel SS, Golm GT, . Safety of sitagliptin in elderly patients with type 2 diabetes: a pooled analysis of 25 clinical studies. Drugs Aging. 2014 Mar;31(3):203–14. doi: 10.1007/s40266-014-0155-7. PMID: 24510656. Exclusion Code: X8.24510656
2175 Roux C, Aroda V, Hemmingsson J, . Comparison of efficacy and safety of liraglutide 3.0 mg in individuals with BMI above and below 35 kg/m2: a post-hoc analysis. Obesity facts. 2017:531–44. doi: 10.1159/000478099. PMID: CN-01432095. Exclusion Code: X2.29145215
2176 Roux C, Astrup A, Fujioka K, . Liraglutide 3.0 mg improves body weight and cardiometabolic risk factors in overweight or obese adults without diabetes: the scale obesity and prediabetes randomized, double-blind, placebo-controlled 56-week trial. Endocrine reviews. Conference: 96th annual meeting and expo of the endocrine society, ENDO 2014. Chicago, IL united states. Conference start: 20140621. Conference end: 20140624. Conference publication: (var.pagings). 2014;35(no pagination)PMID: CN-01267314. Exclusion Code: X10.
2177 Roux C, Astrup A, Greenway F, . Liraglutide 3.0 mg reduces body weight and improves cardiometabolic risk factors: SCALE obesity and prediabetes randomised, double-blind, placebo-controlled 3-year trial. Diabetologia. Conference: 52nd annual meeting of the european association for the study of diabetes, EASD 2016. Germany. Conference start: 20160912. Conference end: 20160916. 2016;59(1 Supplement 1):S329. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212751. Exclusion Code: X10.
2178 Roux C, Lau D, Astrup A, . Safety and tolerability of liraglutide 3.0 mg in overweight and obese adults: the SCALE obesity and prediabetes randomised trial. Diabetologia. 2014;57(1 suppl. 1):S338. doi: 10.1007/s00125-014-3355-0. PMID: CN-01059165. Exclusion Code: X2.
2179 Roux C, Lau D, Fujioka K, . Early weight loss responders to liraglutide 3.0mg had greater weight loss, regression to normoglycaemia, and reduced Type 2 diabetes development at three years vs early non-responders: SCALE Obesity and Prediabetes. Diabetic medicine. Conference: diabetes UK professional conference 2017. United kingdom. 2017;34:57. doi: 10.1111/dme.13302. PMID: CN-01361262. Exclusion Code: X10.
2180 Rowan CP, Riddell MC, Gledhill N, . Aerobic exercise training modalities and prediabetes risk reduction. Med Sci Sports Exerc. 2017 Mar;49(3):403–12. doi: 10.1249/mss.0000000000001135. PMID: 27776003. Exclusion Code: X6.27776003
2181 Roy-Duval C, Hanefeld M, Gentile S, . Advancing basal insulin glargine with prandial lixisenatide QD vs insulin glulisine QD or TID in type 2 diabetes: the GetGoal-Duo2 evidence-based trial. Diabetologia. 2015;58(1 suppl. 1):S39. doi: 10.1007/s00125-015-3687-4. PMID: CN-01471987. Exclusion Code: X5.
2182 Rubin RR, Wadden TA, Bahnson JL, . Impact of intensive lifestyle intervention on depression and health-related quality of life in type 2 diabetes: the Look AHEAD Trial. Diabetes Care. 2014 Jun;37(6):1544–53. doi: 10.2337/dc13-1928. PMID: 24855155. Exclusion Code: X2.24855155
2183 Ruffino J, Songsorn P, Haggett M, . A comparison of the health benefits of reduced-exertion high-intensity interval training (REHIT) and moderate-intensity walking in type 2 diabetes patients. Physiologie appliquee, nutrition et metabolisme [Applied physiology, nutrition, and metabolism]. 2017;42(2):202–8. doi: 10.1139/apnm-2016-0497. PMID: CN-01262933. Exclusion Code: X2.
2184 Ruggenenti P, Abbate M, Ruggiero B, . Renal and systemic effects of calorie restriction in patients with type 2 diabetes with abdominal obesity: a randomized controlled trial. Diabetes. 2017;66(1):75–86. doi: 10.2337/db16-0607. PMID: CN-01302002. Exclusion Code: X2.27634224
2185 Ruijgrok C, Dekker JM, Beulens JW, . Size and shape of the associations of glucose, HbA1c, insulin and HOMA-IR with incident type 2 diabetes: the Hoorn Study. Diabetologia. 2018 Jan;61(1):93–100. doi: 10.1007/s00125-017-4452-7. PMID: 29018885. Exclusion Code: X5.29018885
2186 Ruiz-Tovar J, Llavero C, Ortega I, . Percutaneous electric neurostimulation of dermatome T7 improves glycemic profile in obese and type 2 diabetic patients. A randomized clinical study. Cir Esp. 2015 Aug–Sep;93(7):460–5. doi: 10.1016/j.ciresp.2014.06.010. PMID: 25649338. Exclusion Code: X4.25649338
2187 Russell J, Zilliox L, Kumar P. A randomized, blinded, lifestyle intervention study improves the expiration: inspiration ratio in diabetic neuropathy. Journal of neuromuscular diseases. 2018;5:S240–S1. doi: 10.3233/JND-189001. PMID: CN-01653947. Exclusion Code: X6.
2188 Ryan JM, Cassidy EE, Noorduyn SG, . Exercise interventions for cerebral palsy. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2189 Rynders C, Weltman J, Jiang B, . Effects of exercise intensity on postprandial improvement in glucose disposal and insulin sensitivity in prediabetic adults. Journal of clinical endocrinology and metabolism. 2014;99(1):220–8. doi: 10.1210/jc.2013-2687. PMID: CN-00979256. Exclusion Code: X6.24243632
2190 Ryuk JA, Lixia M, Cao S, . Efficacy and safety of Gegen Qinlian decoction for normalizing hyperglycemia in diabetic patients: A systematic review and meta-analysis of randomized clinical trials. Complement Ther Med. 2017 Aug;33:6–13. doi: 10.1016/j.ctim.2017.05.004. PMID: 28735827. Exclusion Code: X8.28735827
2191 Saab C, Al-Saber FA, Haddad J, . Effectiveness and tolerability of second-line treatment with vildagliptin versus other oral drugs for type 2 diabetes in a real-world setting in the Middle East: results from the EDGE study. Vasc Health Risk Manag. 2015;11:149–55. doi: 10.2147/vhrm.s73703. PMID: 25750538. Exclusion Code: X2.25750538
2192 Sabatine MS, Leiter LA, Wiviott SD, . Cardiovascular safety and efficacy of the PCSK9 inhibitor evolocumab in patients with and without diabetes and the effect of evolocumab on glycaemia and risk of new-onset diabetes: a prespecified analysis of the FOURIER randomised controlled trial. The lancet. Diabetes & endocrinology. 2017;5(12):941–50. doi: 10.1016/S2213-8587(17)30313-3. PMID: CN-01615411. Exclusion Code: X8.28927706
2193 Sacco M, Pellegrini F, Roncaglioni MC, . Primary prevention of cardiovascular events with low-dose aspirin and vitamin E in type 2 diabetic patients: results of the Primary Prevention Project (PPP) trial. Diabetes Care. 2003 Dec;26(12):3264–72. PMID: 14633812. Exclusion Code: X2.14633812
2194 Sacre J, Jellis C, Jenkins C, . A six-month exercise intervention in subclinical diabetic heart disease: effects on exercise capacity, autonomic and myocardial function. Metabolism. 2014;63(9):1104–14. doi: 10.1016/j.metabol.2014.05.007. PMID: CN-01002528. Exclusion Code: X2.24997499
2195 Sadeghian H, Madhu S, Kannan A, . Effects of a self-management educational program on metabolic control in type 2 diabetes. Turkish journal of medical sciences. 2016;46(3):719–26. doi: 10.3906/sag-1501-115. PMID: CN-01153700. Exclusion Code: X6.27513247
2196 Sadler MD, Saperstein SL, Carpenter C, . Community evaluation of the National Diabetes Education Program’s Diabetes HealthSense Website. Diabetes Educ. 2017 Oct;43(5):476–85. doi: 10.1177/0145721717721183. PMID: 28766403. Exclusion Code: X6.28766403
2197 Saengtipbovorn S, Taneepanichskul S. Effectiveness of lifestyle change plus dental care (LCDC) program on improving glycemic and periodontal status in the elderly with type 2 diabetes. BMC Oral Health. 2014 Jun 16;14:72. doi: 10.1186/1472-6831-14-72. PMID: 24934646. Exclusion Code: X2.24934646
2198 Saengtipbovorn S, Taneepanichskul S. Lifestyle Change Plus Dental Care (LCDC) program improves knowledge, attitude, and practice (KAP) toward oral health and diabetes mellitus among the elderly with type 2 diabetes. J Med Assoc Thai. 2015 Mar;98(3):279–90. PMID: 25920299. Exclusion Code: X6.25920299
2199 Saengtipbovorn S, Taneepanichskul S. Effectiveness of lifestyle change plus dental care program in improving glycemic and periodontal status in aging patients with diabetes: a cluster, randomized, controlled trial. J Periodontol. 2015 Apr;86(4):507–15. doi: 10.1902/jop.2015.140563. PMID: 25597411. Exclusion Code: X2.25597411
2200 Saffari M, Ghanizadeh G, Koenig H. Health education via mobile text messaging for glycemic control in adults with type 2 diabetes: a systematic review and meta-analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2014(2):275–85. PMID: DARE-12014031070. Exclusion Code: X8.
2201 Saffari M, Ghanizadeh G, Koenig HG. Health education via mobile text messaging for glycemic control in adults with type 2 diabetes: a systematic review and meta-analysis. Prim Care Diabetes. 2014 Dec;8(4):275–85. doi: 10.1016/j.pcd.2014.03.004. PMID: 24793589. Exclusion Code: X8.24793589
2202 Safren SA, Gonzalez JS, Wexler DJ, . A randomized controlled trial of cognitive behavioral therapy for adherence and depression (CBT-AD) in patients with uncontrolled type 2 diabetes. Diabetes Care. 2014;37(3):625–33. doi: 10.2337/dc13-0816. PMID: 24170758. Exclusion Code: X4.24170758
2203 Sagara M, Suzuki K, Aoki C, . Impact of teneligliptin on oxidative stress and endothelial function in type 2 diabetes patients with chronic kidney disease: a case-control study. Cardiovasc Diabetol. 2016 May 17;15:76. doi: 10.1186/s12933-016-0396-3. PMID: 27184495. Exclusion Code: X2.27184495
2204 Sagarra R, Costa B, Cabre JJ, . Lifestyle interventions for diabetes mellitus type 2 prevention. Rev Clin Esp (Barc). 2014 Mar;214(2):59–68. doi: 10.1016/j.rce.2013.10.005. PMID: 24267869. Exclusion Code: X8.24267869
2205 Saida T, Juul Sorensen T, Langberg H. Long-term exercise adherence after public health training in at-risk adults. Ann Phys Rehabil Med. 2017 Jul;60(4):237–43. doi: 10.1016/j.rehab.2017.02.006. PMID: 28462861. Exclusion Code: X5.28462861
2206 Saito I, Azuma K, Kakikawa T, . A randomized, double-blind, placebo-controlled study of the effect of ezetimibe on glucose metabolism in subjects with type 2 diabetes mellitus and hypercholesterolemia. Lipids Health Dis. 2015 May 1;14:40. doi: 10.1186/s12944-015-0036-z. PMID: 25929253. Exclusion Code: X2.25929253
2207 Sakane N, Kotani K, Suganuma A, . Prevention of Metabolic Syndrome by Telephone-Delivered Lifestyle Intervention in a Real-World Setting: sub-Analysis of a Cluster-Randomized Trial. Metab Syndr Relat Disord. 2019doi: 10.1089/met.2018.0130. PMID: CN-01958075. Exclusion Code: X8.
2208 Sakane N, Nirengi S, Takahashi K, . The impact of lifestyle intervention on stage of change toward healthy eating and development of diabetes in prediabetic individuals in precontemplation stage. Diabetes. 2018;67:A177-. PMID: CN-01631451. Exclusion Code: X6.
2209 Sakane N, Oshima Y, Nirengi S, . Frequent self-weighing delays or prevents the development of type 2 diabetes in a real-world setting: a subanalysis of Japan diabetes outcome trial-1. Diabetes. 2017;66:A43-. PMID: CN-01724287. Exclusion Code: X4.
2210 Sakane N, Sato J, Tsushita K, . Effects of lifestyle intervention on weight and metabolic parameters in patients with impaired glucose tolerance related to beta-3 adrenergic receptor gene polymorphism Trp64Arg(C/T): Results from the Japan Diabetes Prevention Program. J Diabetes Investig. 2016 May;7(3):338–42. doi: 10.1111/jdi.12426. PMID: 27330719. Exclusion Code: X6.27330719
2211 Sakoda LC, Ferrara A, Achacoso NS, . Metformin use and lung cancer risk in patients with diabetes. Cancer Prev Res (Phila). 2015 Feb;8(2):174–9. doi: 10.1158/1940-6207.capr-14-0291. PMID: 25644512. Exclusion Code: X2.25644512
2212 Salahuddin UI, Pandey A, Ayers CR, . Effect of treatment with rosiglitazone on high-sensitivity cardiac troponin levels among patients with type 2 diabetes mellitus. Diab Vasc Dis Res. 2016 Mar;13(2):113–8. doi: 10.1177/1479164115618517. PMID: 26701964. Exclusion Code: X2.26701964
2213 Salas-Salvadó J, Bulló M, Estruch R, . Prevention of diabetes with Mediterranean diets: a subgroup analysis of a randomized trial. Ann Intern Med. 2014;160(1):1–10. doi: 10.7326/M13-1725. PMID: CN-00959086. Exclusion Code: X2.
2214 Salas-Salvado J, Diaz-Lopez A, Ruiz-Canela M, . Effect of a lifestyle intervention program with energy-restricted Mediterranean diet and exercise on weight loss and cardiovascular risk factors: one-year results of the PREDIMED-Plus trial. Diabetes care. 2019;42(5):777–88. doi: 10.2337/dc18-0836. PMID: CN-01941816. Exclusion Code: X2.30389673
2215 Salazar CA, Basilio FJE, Veramendi ELE, . Ranolazine for stable angina pectoris. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2216 Salazar-Lopez S, Alvarez-Canales M, Farfan D, . Rescue therapy with linagliptin to improve glucose metabolism and pancretic beta cell function in patients with prediabetes with no response to metformin. Diabetologia. 2018;61:S388–S9. doi: 10.1007/s00125-018-4693-0. PMID: CN-01647076. Exclusion Code: X5.
2217 Saleh F, Ara F, Mumu SJ, . Assessment of health-related quality of life of Bangladeshi patients with type 2 diabetes using the EQ-5D: a cross-sectional study. BMC Res Notes. 2015 Sep 29;8:497. doi: 10.1186/s13104-015-1453-9. PMID: 26420245. Exclusion Code: X8.26420245
2218 Salimi Y, Fotouhi A, Mohammad K, . Causal effects of intensive lifestyle and metformin interventions on cardiovascular disease risk factors in pre-diabetic people: an application of G-estimation. Arch Iran Med. 2017 Jan;20(1):55–9. . PMID: 28112533. Exclusion Code: X6.28112533
2219 Samkani A, Skytte M, Kandel D, . A carbohydrate-reduced high-protein diet acutely decreases postprandial and diurnal glucose excursions in type 2 diabetes patients. British journal of nutrition. 2018;119(8):910–7. doi: 10.1017/S0007114518000521. PMID: CN-01569535. Exclusion Code: X6.
2220 Samuel-Hodge CD, Holder-Cooper JC, Gizlice Z, . Family PArtners in Lifestyle Support (PALS): family-based weight loss for African American adults with type 2 diabetes. Obesity (Silver Spring). 2017 Jan;25(1):45–55. doi: 10.1002/oby.21700. PMID: 27911049. Exclusion Code: X2.27911049
2221 Sanchez A, Silvestre C, Campo N, . Effective translation of a type-2 diabetes primary prevention programme into routine primary care: The PreDE cluster randomised clinical trial. Diabetes Res Clin Pract. 2018 May;139:32–42. doi: 10.1016/j.diabres.2018.01.006. PMID: 29476888. Exclusion Code: X2.29476888
2222 Sanguankeo A, Lazo M, Upala S, . Effects of visceral adipose tissue reduction on CVD risk factors independent of weight loss: The Look AHEAD study. Endocr Res. 2017 May;42(2):86–95. doi: 10.1080/07435800.2016.1194856. PMID: 27351077. Exclusion Code: X2.27351077
2223 Sani M, Makeen A, Albasheer OBA, . Effect of telemedicine messages integrated with peer group support on glycemic control in type 2 diabetics, Kingdom of Saudi Arabia. Int J Diabetes Dev Ctries. 2018;38(4):495–501. doi: 10.1007/s13410-018-0608-3. PMID: CN-01723675. Exclusion Code: X2.
2224 Santilli F, Simeone P, Guagnano M, . Effects of liraglutide on weight loss, fat distribution, and b-cell function in obese subjects with prediabetes or early type 2 diabetes. Diabetes care. 2017;40(11):1556–64. doi: 10.2337/dc17-0589. PMID: CN-01429833. Exclusion Code: X6.28912305
2225 Santilli F, Simeone PG, Guagnano MT, . Effects of Liraglutide on Weight Loss, Fat Distribution, and beta-Cell Function in Obese Subjects With Prediabetes or Early Type 2 Diabetes. Diabetes Care. 2017 Nov;40(11):1556–64. doi: 10.2337/dc17-0589. PMID: 28912305. Exclusion Code: X6.28912305
2226 Sarafidis P, Lasaridis A, Hatzistavri L, . The Effect of Telmisartan and Lekarnidipine on Blood Pressure and Insulin Resistance in Hypertensive Patients. Review of clinical pharmacology and pharmacokinetics, international edition. 2004;18(1):60–6. PMID: CN-01756764. Exclusion Code: X2.
2227 Sarashina A, Friedrich C, Crowe S, . Comparable pharmacodynamics, efficacy, and safety of linagliptin 5 mg among Japanese, Asian and white patients with type 2 diabetes. J Diabetes Investig. 2016 Sep;7(5):744–50. doi: 10.1111/jdi.12482. PMID: 27180969. Exclusion Code: X2.27180969
2228 Sardar M, Boghrabadi V, Sohrabi M, . The effects of aerobic exercise training on psychosocial aspects of men with type 2 diabetes mellitus. Global journal of health science. 2014;6(2):196–202. doi: 10.5539/gjhs.v6n2p196. PMID: CN-00993376. Exclusion Code: X2.
2229 Sardina PD, Martin JS, Dzieza WK, . Enhanced external counterpulsation (EECP) decreases advanced glycation end products and proinflammatory cytokines in patients with non-insulin-dependent type II diabetes mellitus for up to 6 months following treatment. Acta Diabetol. 2016 Oct;53(5):753–60. doi: 10.1007/s00592-016-0869-6. PMID: 27278477. Exclusion Code: X6.27278477
2230 Sarfati D, McLeod M, Stanley J, . BetaMe: impact of a comprehensive digital health programme on HbA1c and weight at 12 months for people with diabetes and pre-diabetes: study protocol for a randomised controlled trial. Trials. 2018 Mar 5;19(1):161. doi: 10.1186/s13063-018-2528-4. PMID: 29506562. Exclusion Code: X6.29506562
2231 Sarzynski M, Ruiz-Ramie J, Barber J, . Effects of Increasing Exercise Intensity and Dose on Multiple Measures of HDL (High-Density Lipoprotein) Function. Arterioscler Thromb Vasc Biol. 2018;38(4):943–52. doi: 10.1161/ATVBAHA.117.310307. PMID: CN-01464885. Exclusion Code: X5.29437573
2232 Sarzynski M, Slentz C, Apolzan J, . High-amount and high-intensity exercise training improves HDL cholesterol efflux capacity. Arteriosclerosis, thrombosis, and vascular biology. Conference: american heart association’s arteriosclerosis, thrombosis and vascular biology/peripheral vascular disease 2016 scientific sessions. United states. 2016;36(no pagination)PMID: CN-01407521. Exclusion Code: X5.
2233 Saslow L, Daubenmier J, Moskowitz J, . Twelve-month outcomes of a randomized trial of a moderate-carbohydrate versus very low-carbohydrate diet in overweight adults with type 2 diabetes mellitus or prediabetes. Nutrition and diabetes. 2017;7(12) (no pagination)doi: 10.1038/s41387-017-0006-9. PMID: CN-01466343. Exclusion Code: X2.
2234 Saslow LR, Kim S, Daubenmier JJ, . A randomized pilot trial of a moderate carbohydrate diet compared to a very low carbohydrate diet in overweight or obese individuals with type 2 diabetes mellitus or prediabetes. PLoS One. 2014;9(4):e91027. doi: 10.1371/journal.pone.0091027. PMID: 24717684. Exclusion Code: X5.24717684
2235 Saslow LR, Mason AE, Kim S, . An online intervention comparing a very low-carbohydrate ketogenic diet and lifestyle recommendations versus a plate method diet in overweight individuals with type 2 diabetes: a randomized controlled trial. J Med Internet Res. 2017 Feb 13;19(2):e36. doi: 10.2196/jmir.5806. PMID: 28193599. Exclusion Code: X2.28193599
2236 Sasso FC, Lascar N, Ascione A, . Moderate-intensity statin therapy seems ineffective in primary cardiovascular prevention in patients with type 2 diabetes complicated by nephropathy. A multicenter prospective 8 years follow up study. Cardiovasc Diabetol. 2016 Oct 13;15(1):147. doi: 10.1186/s12933-016-0463-9. PMID: 27733159. Exclusion Code: X2.27733159
2237 Sasso FC, Marfella R, Pagano A, . Lack of effect of aspirin in primary CV prevention in type 2 diabetic patients with nephropathy: results from 8 years follow-up of NID-2 study. Acta Diabetol. 2015 Apr;52(2):239–47. doi: 10.1007/s00592-014-0623-x. PMID: 25109286. Exclusion Code: X2.25109286
2238 Sathish T, Oldenburg B, Lotfalian M, . Effectiveness of lifestyle intervention in prevention of type 2 diabetes in India: a cluster randomised controlled trial of the Kerala diabetes prevention program. Diabetes. 2017;66:A458-. PMID: CN-01740368. Exclusion Code: X2.
2239 Sathish T, Oldenburg B, Tapp RJ, . Baseline characteristics of participants in the Kerala Diabetes Prevention Program: a cluster randomized controlled trial of lifestyle intervention in Asian Indians. Diabet Med. 2017 May;34(5):647–53. doi: 10.1111/dme.13165. PMID: 27279083. Exclusion Code: X6.27279083
2240 Satirapoj B, Kaewput W, Supasyndh O, . Effect of sulodexide on urinary biomarkers of kidney injury in normoalbuminuric type 2 diabetes: a randomized controlled trial. J Diabetes Res. 2015;2015:172038. doi: 10.1155/2015/172038. PMID: 25918727. Exclusion Code: X4.25918727
2241 Sato J, Kanazawa A, Hatae C, . One year follow-up after a randomized controlled trial of a 130 g/day low-carbohydrate diet in patients with type 2 diabetes mellitus and poor glycemic control. Plos one. 2017;12(12):e0188892. doi: 10.1371/journal.pone.0188892. PMID: CN-01440944. Exclusion Code: X2.29206237
2242 Sato J, Kanazawa A, Ikeda F, . Effect of treatment guidance using a retrospective continuous glucose monitoring system on glycaemic control in outpatients with type 2 diabetes mellitus: a randomized controlled trial. Journal of international medical research. 2016;44(1):109–21. doi: 10.1177/0300060515600190. PMID: CN-01138192. Exclusion Code: X2.
2243 Sato J, Kanazawa A, Makita S, . A randomized controlled trial of 130 g/day low-carbohydrate diet in type 2 diabetes with poor glycemic control. Clin Nutr. 2017 Aug;36(4):992–1000. doi: 10.1016/j.clnu.2016.07.003. PMID: 27472929. Exclusion Code: X2.27472929
2244 Sato J, Kanazawa A, Makita S, . The efficacy and safety of 130g/day low-carbohydrate diet in Japanese type 2 diabetes patients with poor glycemic control. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A394. doi: 10.2337/db16-1375-1656. PMID: CN-01449876. Exclusion Code: X6.
2245 Sato S, Saisho Y, Kou K, . Efficacy and safety of sitagliptin added to insulin in Japanese patients with type 2 diabetes: the EDIT randomized trial. PLoS One. 2015;10(3):e0121988. doi: 10.1371/journal.pone.0121988. PMID: 25816296. Exclusion Code: X2.25816296
2246 Satpute DA, Patil PH, Kuchake VG, . Assessment of impact of patient counselling, nutrition and exercise in patients with Type 2 Diabetes Mellitus. International journal of pharmtech research. 2009;1(1):1–21. PMID: CN-01780410. Exclusion Code: X5.
2247 Sauder KA, McCrea CE, Ulbrecht JS, . Pistachio nut consumption modifies systemic hemodynamics, increases heart rate variability, and reduces ambulatory blood pressure in well-controlled type 2 diabetes: a randomized trial. J Am Heart Assoc. 2014 Jun 30;3(4)doi: 10.1161/jaha.114.000873. PMID: 24980134. Exclusion Code: X4.24980134
2248 Saunders DH, Mead GE, Fitzsimons C, . Interventions for reducing sedentary behaviour in people with stroke. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2018. Exclusion Code: X8.
2249 Savory LA, Griffin SJ, Williams KM, . Changes in diet, cardiovascular risk factors and modelled cardiovascular risk following diagnosis of diabetes: 1-year results from the ADDITION-Cambridge trial cohort. Diabet Med. 2014 Feb;31(2):148–55. doi: 10.1111/dme.12316. PMID: 24102972. Exclusion Code: X6.24102972
2250 Savvidou S, Karatzidou K, Tsakiri K, . Circulating adiponectin levels in type 2 diabetes mellitus patients with or without non-alcoholic fatty liver disease: Results of a small, open-label, randomized controlled intervention trial in a subgroup receiving short-term exenatide. Diabetes Res Clin Pract. 2016 Mar;113:125–34. doi: 10.1016/j.diabres.2015.12.003. PMID: 26803355. Exclusion Code: X2.26803355
2251 Sbroma Tomaro E, Pippi R, Reginato E, . Intensive lifestyle intervention is particularly advantageous in poorly controlled type 2 diabetes. Nutr Metab Cardiovasc Dis. 2017 Aug;27(8):688–94. doi: 10.1016/j.numecd.2017.06.009. PMID: 28735815. Exclusion Code: X6.28735815
2252 Scalzo RL, Moreau KL, Ozemek C, . Exenatide improves diastolic function and attenuates arterial stiffness but does not alter exercise capacity in individuals with type 2 diabetes. J Diabetes Complications. 2017 Feb;31(2):449–55. doi: 10.1016/j.jdiacomp.2016.10.003. PMID: 27884660. Exclusion Code: X2.27884660
2253 Schandelmaier S, Briel M, Saccilotto R, . Niacin for primary and secondary prevention of cardiovascular events. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2254 Schernthaner G, Barnett AH, Patel S, . Safety and efficacy of the dipeptidyl peptidase-4 inhibitor linagliptin in elderly patients with type 2 diabetes: a comprehensive analysis of data from 1331 individuals aged >/= 65 years. Diabetes Obes Metab. 2014 Nov;16(11):1078–86. doi: 10.1111/dom.12321. PMID: 24865132. Exclusion Code: X2.24865132
2255 Schernthaner G, Duran-Garcia S, Hanefeld M, . Efficacy and tolerability of saxagliptin compared with glimepiride in elderly patients with type 2 diabetes: a randomized, controlled study (GENERATION). Diabetes Obes Metab. 2015 Jul;17(7):630–8. doi: 10.1111/dom.12461. PMID: 25761977. Exclusion Code: X2.25761977
2256 Schernthaner G, Khunti K, Patel S, . Safety of linagliptin in 8778 patients with type 2 diabetes mellitus: pooled analysis of 23 placebo-controlled randomized clinical trials. Canadian journal of diabetes. 2014;38:S58. PMID: CN-01471749. Exclusion Code: X8.
2257 Schernthaner G, Khunti K, Patel S, . Safety of linagliptin in 8,778 patients with type 2 diabetes mellitus: pooled analysis of 23 placebo-controlled, randomized clinical trials. Diabetes. 2014;63:A281. doi: 10.2337/db14-833-1316. PMID: CN-01065510. Exclusion Code: X8.
2258 Schernthaner G, Khunti K, Patel S, . Safety of linagliptin in 8778 patients with type 2 diabetes mellitus: pooled analysis of 23 placebo-controlled randomised clinical trials. Diabetologia. 2014;57(1 suppl. 1):S360. doi: 10.1007/s00125-014-3355-0. PMID: CN-01059151. Exclusion Code: X8.
2259 Schernthaner G, Rosas-Guzman J, Dotta F, . Treatment escalation options for patients with type 2 diabetes after failure of exenatide twice daily or glimepiride added to metformin: results from the prospective European Exenatide (EUREXA) study. Diabetes Obes Metab. 2015 Jul;17(7):689–98. doi: 10.1111/dom.12471. PMID: 25846577. Exclusion Code: X2.25846577
2260 Schlender L, Martinez YV, Adeniji C, . Efficacy and safety of metformin in the management of type 2 diabetes mellitus in older adults: a systematic review for the development of recommendations to reduce potentially inappropriate prescribing. BMC Geriatr. 2017 Oct 16;17(Suppl 1):227. doi: 10.1186/s12877-017-0574-5. PMID: 29047344. Exclusion Code: X8.29047344
2261 Schmiedel K, Mayr A, Fiessler C, . Effects of the lifestyle intervention program GLICEMIA in people at risk for type 2 diabetes: a cluster-randomized controlled trial. Diabetes Care. 2015 May;38(5):937–9. doi: 10.2337/dc14-2206. PMID: 25784662. Exclusion Code: X2.25784662
2262 Schmieder RE, Bramlage P, Haller H, . The effect of resting heart rate on the new onset of microalbuminuria in patients with type 2 diabetes: a subanalysis of the ROADMAP Study. Medicine (Baltimore). 2016 Apr;95(15):e3122. doi: 10.1097/md.0000000000003122. PMID: 27082551. Exclusion Code: X2.27082551
2263 Schmittdiel JA, Adams SR, Goler N, . The impact of telephonic wellness coaching on weight loss: a “Natural Experiments for Translation in Diabetes (NEXT-D)” study. Obesity (Silver Spring). 2017 Feb;25(2):352–6. doi: 10.1002/oby.21723. PMID: 28124501. Exclusion Code: X8.28124501
2264 Schneider KL, Panza E, Handschin B, . Feasibility of pairing behavioral activation with exercise for women with type 2 diabetes and depression: the Get It Study Pilot Randomized Controlled Trial. Behav Ther. 2016 Mar;47(2):198–212. doi: 10.1016/j.beth.2015.10.005. PMID: 26956652. Exclusion Code: X2.26956652
2265 Schott G, Martinez YV, Ediriweera de Silva RE, . Effectiveness and safety of dipeptidyl peptidase 4 inhibitors in the management of type 2 diabetes in older adults: a systematic review and development of recommendations to reduce inappropriate prescribing. BMC Geriatr. 2017 Oct 16;17(Suppl 1):226. doi: 10.1186/s12877-017-0571-8. PMID: 29047372. Exclusion Code: X8.29047372
2266 Schreuder TH, Duncker DJ, Hopman MT, . Randomized controlled trial using bosentan to enhance the impact of exercise training in subjects with type 2 diabetes mellitus. Exp Physiol. 2014 Nov;99(11):1538–47. doi: 10.1113/expphysiol.2014.081182. PMID: 25172889. Exclusion Code: X4.25172889
2267 Schrier RW, Estacio RO, Esler A, . Effects of aggressive blood pressure control in normotensive type 2 diabetic patients on albuminuria, retinopathy and strokes. Kidney Int. 2002 Mar;61(3):1086–97. doi: 10.1046/j.1523-1755.2002.00213.x. PMID: 11849464. Exclusion Code: X2.11849464
2268 Schrier RW, Estacio RO, Mehler PS, . Appropriate blood pressure control in hypertensive and normotensive type 2 diabetes mellitus: a summary of the ABCD trial. Nat Clin Pract Nephrol. 2007 Aug;3(8):428–38. doi: 10.1038/ncpneph0559. PMID: 17653121. Exclusion Code: X8.17653121
2269 Schrijnders D, Wever R, Kleefstra N, . Addition of sulphonylurea to metformin does not relevantly change body weight: a prospective observational cohort study (ZODIAC-39). Diabetes Obes Metab. 2016 Oct;18(10):973–9. doi: 10.1111/dom.12700. PMID: 27265756. Exclusion Code: X8.27265756
2270 Schumm-Draeger PM, Burgess L, Koranyi L, . Twice-daily dapagliflozin co-administered with metformin in type 2 diabetes: a 16-week randomized, placebo-controlled clinical trial. Diabetes Obes Metab. 2015 Jan;17(1):42–51. doi: 10.1111/dom.12387. PMID: 25200570. Exclusion Code: X2.25200570
2271 Schutt M, Zimmermann A, Hood R, . Gender-specific effects of treatment with lifestyle, metformin or sulfonylurea on glycemic control and body weight: a German multicenter analysis on 9 108 patients. Exp Clin Endocrinol Diabetes. 2015 Nov;123(10):622–6. doi: 10.1055/s-0035-1559608. PMID: 26285070. Exclusion Code: X6.26285070
2272 Schwartz AV, Chen H, Ambrosius WT, . Effects of TZD use and discontinuation on fracture rates in ACCORD Bone Study. J Clin Endocrinol Metab. 2015 Nov;100(11):4059–66. doi: 10.1210/jc.2015-1215. PMID: 26305617. Exclusion Code: X2.26305617
2273 Schwartz AV, Margolis KL, Sellmeyer DE, . Intensive glycemic control is not associated with fractures or falls in the ACCORD randomized trial. Diabetes Care. 2012 Jul;35(7):1525–31. doi: 10.2337/dc11-2184. PMID: 22723583. Exclusion Code: X2.22723583
2274 Schwingshackl L, Hoffmann G. Comparison of the long-term effects of high-fat v. low-fat diet consumption on cardiometabolic risk factors in subjects with abnormal glucose metabolism: a systematic review and meta-analysis (Provisional abstract). Database of Abstracts of Reviews of Effects; 2014. p. 2047–58. Exclusion Code: X8.
2275 Scirica BM, Braunwald E, Raz I, . Heart failure, saxagliptin, and diabetes mellitus: observations from the SAVOR-TIMI 53 randomized trial. Circulation. 2014 Oct 28;130(18):1579–88. doi: 10.1161/circulationaha.114.010389. PMID: 25189213. Exclusion Code: X2.25189213
2276 Seida J, Mitri J, Colmers I, . Effect of vitamin D3 supplementation on improving glucose homeostasis and preventing diabetes: a systematic review and meta-analysis (Provisional abstract). Database of Abstracts of Reviews of Effects; 2014. p. 3551–60. Exclusion Code: X8.
2277 Seimon R, Dodds J, Muirhead R, . Effect of an 8-week Low energy diet on muscle strength in adults with overweight and obesity-the PREVIEW study Australia. Obesity reviews. 2016;17:168. doi: 10.1111/obr.12403. PMID: CN-01160616. Exclusion Code: X6.
2278 Seimon RV, Espinoza D, Ivers L, . Changes in body weight and blood pressure: paradoxical outcome events in overweight and obese subjects with cardiovascular disease. Int J Obes (Lond). 2014 Sep;38(9):1165–71. doi: 10.1038/ijo.2014.2. PMID: 24406481. Exclusion Code: X2.24406481
2279 Seino Y, Ikeda Y, Niemoeller E, . Efficacy and Safety of Lixisenatide in Japanese Patients with Type 2 Diabetes Insufficiently Controlled with Basal Insulin+/-Sulfonylurea: A Subanalysis of the GetGoal-L-Asia Study. Horm Metab Res. 2015 Nov;47(12):895–900. doi: 10.1055/s-0035-1549875. PMID: 26039935. Exclusion Code: X4.26039935
2280 Seino Y, Ikeda Y, Niemoeller E, . Efficacy and Safety of Lixisenatide in Japanese Patients with Type 2 Diabetes Insufficiently Controlled with Basal Insulin±Sulfonylurea: a Subanalysis of the GetGoal-L-Asia Study. Hormon- und Stoffwechselforschung / Hormones et metabolisme [Hormone and metabolic research]. 2015;47(12):895–900. doi: 10.1055/s-0035-1549875. PMID: CN-01257820. Exclusion Code: X2.
2281 Seino Y, Inagaki N, Haneda M, . Efficacy and safety of luseogliflozin added to various oral antidiabetic drugs in Japanese patients with type 2 diabetes mellitus. Journal of diabetes investigation. 2015;6(4):443–53. doi: 10.1111/jdi.12316. PMID: CN-01082844. Exclusion Code: X2.26221523
2282 Seino Y, Inagaki N, Miyahara H, . A randomized dose-finding study demonstrating the efficacy and tolerability of albiglutide in Japanese patients with type 2 diabetes mellitus. Curr Med Res Opin. 2014;30(6):1095–106. doi: 10.1185/03007995.2014.896327. PMID: CN-00993273. Exclusion Code: X2.24552155
2283 Seino Y, Terauchi Y, Wang X, . Safety, tolerability and efficacy of lixisenatide as monotherapy in Japanese patients with type 2 diabetes mellitus: An open-label, multicenter study. J Diabetes Investig. 2018 Jan;9(1):108–18. doi: 10.1111/jdi.12646. PMID: 28195447. Exclusion Code: X5.28195447
2284 Seino Y, Yabe D, Takami A, . Long-term safety of once-daily lixisenatide in Japanese patients with type 2 diabetes mellitus: GetGoal-Mono-Japan. J Diabetes Complications. 2015 Nov–Dec;29(8):1304–9. doi: 10.1016/j.jdiacomp.2015.07.003. PMID: 26342556. Exclusion Code: X5.26342556
2285 Selcuk-Tosun A, Zincir H. The effect of a transtheoretical model-based motivational interview on self-efficacy, metabolic control, and health behaviour in adults with type 2 diabetes mellitus: a randomized controlled trial. Int J Nurs Pract. 2019:e12742-. doi: 10.1111/ijn.12742. PMID: CN-01956067. Exclusion Code: X6.31090161
2286 Selph S, Dana T, Blazina I, . Screening for type 2 diabetes mellitus: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2015 Jun 2;162(11):765–76. doi: 10.7326/m14-2221. PMID: 25867111. Exclusion Code: X8.25867111
2287 Senechal M, Johannsen NM, Swift DL, . Association between changes in muscle quality with exercise training and changes in cardiorespiratory fitness measures in individuals with type 2 diabetes mellitus: results from the HART-D Study. PLoS One. 2015;10(8):e0135057. doi: 10.1371/journal.pone.0135057. PMID: 26252477. Exclusion Code: X6.26252477
2288 Sentinelli F, Cava V, Serpe R, . Positive effects of Nordic Walking on anthropometric and metabolic variables in women with type 2 diabetes mellitus. Science & sports. 2015;30(1):25–32. doi: 10.1016/j.scispo.2014.10.005. PMID: CN-01069448. Exclusion Code: X2.
2289 Seo YS, Kim YJ, Kim MS, . Association of metformin use with cancer-specific mortality in hepatocellular carcinoma after curative resection: a nationwide population-based study. Medicine (Baltimore). 2016 Apr;95(17):e3527. doi: 10.1097/md.0000000000003527. PMID: 27124061. Exclusion Code: X2.27124061
2290 Seong JM, Choi NK, Shin JY, . Differential cardiovascular outcomes after dipeptidyl peptidase-4 inhibitor, sulfonylurea, and pioglitazone therapy, all in combination with metformin, for type 2 diabetes: a population-based cohort study. PLoS One. 2015;10(5):e0124287. doi: 10.1371/journal.pone.0124287. PMID: 25992614. Exclusion Code: X8.25992614
2291 Serebruany VL, Pokov AN, Aradi D, . Effect of aliskiren and valsartan combination versus aliskiren monotherapy on hemostatic biomarkers in hypertensive diabetics: Aliskiren and Valsartan Impact in Diabetics pilot trial. Am J Ther. 2014 Nov–Dec;21(6):482–90. doi: 10.1097/MJT.0b013e31826915ab. PMID: 23698186. Exclusion Code: X5.23698186
2292 Seron P, Lanas F, Pardo HH, . Exercise for people with high cardiovascular risk. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
2293 Serra MC, Blumenthal JB, Addison OR, . Effects of weight loss with and without exercise on regional body fat distribution in postmenopausal women. Ann Nutr Metab. 2017;70(4):312–20. doi: 10.1159/000475766. PMID: 28595173. Exclusion Code: X5.28595173
2294 Serrano-Ferrer J, Crendal E, Walther G, . Effects of lifestyle intervention on left ventricular regional myocardial function in metabolic syndrome patients from the RESOLVE randomized trial. Metabolism. 2016 Sep;65(9):1350–60. doi: 10.1016/j.metabol.2016.05.006. PMID: 27506742. Exclusion Code: X2.27506742
2295 Seshasai SR, Bennett RL, Petrie JR, . Cardiovascular safety of the glucagon-like peptide-1 receptor agonist taspoglutide in people with type 2 diabetes: an individual participant data meta-analysis of randomized controlled trials. Diabetes Obes Metab. 2015 May;17(5):505–10. doi: 10.1111/dom.12448. PMID: 25656522. Exclusion Code: X8.25656522
2296 Seufert J, Aggarwal N, Bailey R, . Target achievement and quality measure (QM) attainment with titrated canagliflozin (CANA) in patients with type 2 diabetes mellitus (T2DM) as add-on to metformin (MET) + sitagliptin (SITA). Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A308. doi: 10.2337/db16-861-1374. PMID: CN-01449884. Exclusion Code: X2.
2297 Seufert J, Patel S, Pfarr E, . HbA1c changes with empagliflozin/linagliptin are independent of baseline age in subjects with type 2 diabetes. Endocrine reviews. Conference: 98th annual meeting and expo of the endocrine society, ENDO 2016. United states. Conference start: 20160401. Conference end: 20160404. 2016;37(2 Supplement 1) (no pagination)doi: 10.1210/endo-meetings.2016.DGM.23.FRI-717. PMID: CN-01295127. Exclusion Code: X5.
2298 Sevick MA, Woolf K, Mattoo A, . The Healthy Hearts and Kidneys (HHK) study: design of a 2×2 RCT of technology-supported self-monitoring and social cognitive theory-based counseling to engage overweight people with diabetes and chronic kidney disease in multiple lifestyle changes. Contemp Clin Trials. 2018;64:265–73. doi: 10.1016/j.cct.2017.08.020. PMID: CN-01708590. Exclusion Code: X6.28867396
2299 Sha S, Polidori D, Heise T, . Effect of the sodium glucose co-transporter 2 inhibitor canagliflozin on plasma volume in patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2014 Nov;16(11):1087–95. doi: 10.1111/dom.12322. PMID: 24939043. Exclusion Code: X2.24939043
2300 Shaddinger BC, Soffer J, Vlasakakis G, . Efficacy and safety of an albiglutide liquid formulation compared with the lyophilized formulation: A 26-week randomized, double-blind, repeat-dose study in patients with type 2 diabetes mellitus. Diabetes Res Clin Pract. 2019 Jun;152:125–34. doi: 10.1016/j.diabres.2019.04.018. PMID: 31004676. Exclusion Code: X2.31004676
2301 Shahbazi S, Vahdat Shariatpanahi Z. Prevention of type 2 diabetes mellitus by changes in diet among subjects with abnormal glucose metabolism: a randomized clinical trial. Int J Diabetes Dev Ctries. 2018;38(1):69–74. doi: 10.1007/s13410-017-0548-3. PMID: CN-01651535. Exclusion Code: X4.
2302 Shahim B, Gyberg V, De Bacquer D, . Undetected dysglycaemia common in primary care patients treated for hypertension and/or dyslipidaemia: on the need for a screening strategy in clinical practice. A report from EUROASPIRE IV a registry from the EuroObservational Research Programme of the European Society of Cardiology. Cardiovasc Diabetol. 2018 Jan 24;17(1):21. doi: 10.1186/s12933-018-0665-4. PMID: 29368616. Exclusion Code: X4.29368616
2303 Shakil-ur-Rehman S, Karimi H, Gillani S. Effects of supervised structured aerobic exercise training program on fasting blood glucose level, plasma insulin level, glycemic control, and insulin resistance in type 2 diabetes mellitus. Pakistan journal of medical sciences. 2017;33(3):576–80. doi: 10.12669/pjms.333.12023. PMID: CN-01396048. Exclusion Code: X2.28811774
2304 Shakil-ur-Rehman S, Karimi H, Gillani S. Effects of supervised structured aerobic exercise training program on high and low density lipoprotein in patients with type II diabetes mellitus. Pakistan journal of medical sciences. 2017;33(1):96–9. doi: 10.12669/pjms.331.11758. PMID: CN-01338403. Exclusion Code: X4.28367180
2305 Shakil-ur-Rehman S, Karimi H, Gillani S, . Response to a supervised structured aerobic exercise training program in patients with type 2 diabetes mellitus - does gender make a difference? A randomized controlled clinical trial. Journal of the national medical association. 2017;(no pagination)doi: 10.1016/j.jnma.2017.10.003. PMID: CN-01440290. Exclusion Code: X6.
2306 Shakil-ur-Rehman S, Karimi H, Gillani SA, . Response to a Supervised Structured Aerobic Exercise Training Program in Patients with Type 2 Diabetes Mellitus – Does Gender Make a Difference? A Randomized Controlled Clinical Trial. Journal of the national medical association. 2018;110(5):431–9. doi: 10.1016/j.jnma.2017.10.003. PMID: CN-01440290. Exclusion Code: X2.30129517
2307 Shamizadeh T, Jahangiry L, Sarbakhsh P, . Social cognitive theory-based intervention to promote physical activity among prediabetic rural people: a cluster randomized controlled trial. Trials. 2019 Feb 4;20(1):98. doi: 10.1186/s13063-019-3220-z. PMID: 30717779. Exclusion Code: X6.30717779
2308 Shankar R, Inzucchi S, Scarabello V, . A randomized clinical trial evaluating the efficacy and safety of the once-weekly dipeptidyl peptidase-4 inhibitor omarigliptin in patients with type 2 diabetes inadequately controlled on metformin monotherapy. Curr Med Res Opin. 2017;33(10):1853–60. doi: 10.1080/03007995.2017.1335637. PMID: CN-01416249. Exclusion Code: X2.28547998
2309 Shankar SS, Shankar RR, Mixson LA, . Native oxyntomodulin has significant glucoregulatory effects independent of weight loss in obese humans with and without type 2 diabetes. Diabetes. 2018 Jun;67(6):1105–12. doi: 10.2337/db17-1331. PMID: 29545266. Exclusion Code: X6.29545266
2310 Sharma A, de Souza Brito F, Sun JL, . Noncardiovascular deaths are more common than cardiovascular deaths in patients with cardiovascular disease or cardiovascular risk factors and impaired glucose tolerance: Insights from the Nateglinide and Valsartan in Impaired Glucose Tolerance Outcomes Research (NAVIGATOR) trial. Am Heart J. 2017 Apr;186:73–82. doi: 10.1016/j.ahj.2016.12.011. PMID: 28454835. Exclusion Code: X8.28454835
2311 Sharma R, Sharma B, Jindal M, . Evaluation of hypolipidemic effect of stem part of Berberis aristata in type 2 diabetes mellitus patients as add on therapy. National journal of physiology, pharmacy and pharmacology. 2017;7(11):1159–69. doi: 10.5455/njppp.2017.7.0517510062017. PMID: CN-01432177. Exclusion Code: X2.
2312 Sharp LK, Tilton JJ, Touchette DR, . Community Health Workers Supporting Clinical Pharmacists in Diabetes Management: A Randomized Controlled Trial. Pharmacotherapy. 2018 Jan;38(1):58–68. doi: 10.1002/phar.2058. PMID: 29121408. Exclusion Code: X2.29121408
2313 Shaya FT, Chirikov VV, Howard D, . Effect of social networks intervention in type 2 diabetes: a partial randomised study. J Epidemiol Community Health. 2014 Apr;68(4):326–32. doi: 10.1136/jech-2013-203274. PMID: 24297971. Exclusion Code: X4.24297971
2314 Shechter A, St-Onge MP, Kuna ST, . Sleep architecture following a weight loss intervention in overweight and obese patients with obstructive sleep apnea and type 2 diabetes: relationship to apnea-hypopnea index. J Clin Sleep Med. 2014 Nov 15;10(11):1205–11. doi: 10.5664/jcsm.4202. PMID: 25325608. Exclusion Code: X6.25325608
2315 Shek NW, Ngai CS, Lee CP, . Lifestyle modifications in the development of diabetes mellitus and metabolic syndrome in Chinese women who had gestational diabetes mellitus: a randomized interventional trial. Arch Gynecol Obstet. 2014 Feb;289(2):319–27. doi: 10.1007/s00404-013-2971-0. PMID: 23897066. Exclusion Code: X2.23897066
2316 Shelbaya S, Rakha S. Effectiveness and safety of vildagliptin and vildagliptin add-on to metformin in real-world settings in Egypt - results from the GUARD study. Curr Med Res Opin. 2017 May;33(5):797–801. doi: 10.1080/03007995.2016.1277199. PMID: 28303721. Exclusion Code: X2.28303721
2317 Shellington EM, Reichert SM, Heath M, . Results From a Feasibility Study of Square-Stepping Exercise in Older Adults With Type 2 Diabetes and Self-Reported Cognitive Complaints to Improve Global Cognitive Functioning. Canadian journal of diabetes. 2018;42(6):603–12.e1. doi: 10.1016/j.jcjd.2018.02.003. PMID: CN-01913514. Exclusion Code: X2.29884522
2318 Shen X. Reversion to normal blood glucose within six years reduces the risk of diabetes in high-risk groups. Diabetes Metab Res Rev. 2018;34:2-. doi: 10.1002/dmrr.3079. PMID: CN-01748061. Exclusion Code: X5.
2319 Shen X, An Y, Zhang P, . Both fasting and 2-hour post load glycemic progression predicts subsequent cardiovascular events in persons with impaired glucose tolerance: long-term follow-up of the Da qing diabetes prevention study. Diabetes. 2014;63:A350. doi: 10.2337/db14-1317-1629. PMID: CN-01065484. Exclusion Code: X10.
2320 Shen X, An Y, Zhang P, . Both Fasting and 2-hour post load glycemic progression predicts subsequent cardiovascular events in persons with impaired glucose tolerance: 23-year follow-up of the da Qing diabetes prevention study. Cardiology (switzerland). 2014;129:11. PMID: CN-01055174. Exclusion Code: X10.
2321 Shen XX, Wang JP, Chen YY, . Subjects with impaired glucose tolerance returned to normal glucose status for six years had lower long-term risk of diabetes: 20 years follow up of Daqing diabetes prevention study. Zhonghua nei ke za zhi [Chinese journal of internal medicine]. 2019;58(5):372–6. doi: 10.3760/cma.j.issn.0578-1426.2019.05.008. PMID: CN-01929677. Exclusion Code: X1.
2322 Shepherd E, Gomersall JC, Tieu J, . Combined diet and exercise interventions for preventing gestational diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2323 Shestakova MV, Wilding JPH, Wilpshaar W, . A phase 3 randomized placebo-controlled trial to assess the efficacy and safety of ipragliflozin as an add-on therapy to metformin in Russian patients with inadequately controlled type 2 diabetes mellitus. Diabetes Res Clin Pract. 2018 Dec;146:240–50. doi: 10.1016/j.diabres.2018.10.018. PMID: 30391333. Exclusion Code: X2.30391333
2324 Sheu WH, Brunell SC, Blase E. Efficacy and tolerability of exenatide twice daily and exenatide once weekly in Asian versus White patients with type 2 diabetes mellitus: A pooled analysis. Diabetes Res Clin Pract. 2016 Apr;114:160–72. doi: 10.1016/j.diabres.2015.12.004. PMID: 26827116. Exclusion Code: X2.26827116
2325 Sheu WH, Gantz I, Chen M, . Safety and efficacy of omarigliptin (MK-3102), a novel once-weekly DPP-4 inhibitor for the treatment of patients with type 2 diabetes. Diabetes Care. 2015 Nov;38(11):2106–14. doi: 10.2337/dc15-0109. PMID: 26310692. Exclusion Code: X2.26310692
2326 Sheu WH, Park SW, Gong Y, . Linagliptin improves glycemic control after 1 year as add-on therapy to basal insulin in Asian patients with type 2 diabetes mellitus. Curr Med Res Opin. 2015 Mar;31(3):503–12. doi: 10.1185/03007995.2015.1010638. PMID: 25629790. Exclusion Code: X2.25629790
2327 Shi C, Men L, Yu C, . Atherosclerosis associated with dynamic inflammation changes after multifactorial intervention in short-duration type 2 diabetes: A randomized, controlled, 10-year follow-up trial. J Diabetes Complications. 2017 Aug;31(8):1286–92. doi: 10.1016/j.jdiacomp.2017.05.008. PMID: 28610945. Exclusion Code: X6.28610945
2328 Shi FH, Li H, Cui M, . Efficacy and safety of once-weekly semaglutide for the treatment of type 2 diabetes: Protocol for a systematic review and meta-analysis. Medicine (Baltimore). 2018 Apr;97(16):e0420. doi: 10.1097/md.0000000000010420. PMID: 29668601. Exclusion Code: X8.29668601
2329 Shi L, Tan GS, Zhang K. Relationship of the serum CRP level with the efficacy of metformin in the treatment of type 2 diabetes mellitus: a meta-analysis. J Clin Lab Anal. 2016 Jan;30(1):13–22. doi: 10.1002/jcla.21803. PMID: 25277876. Exclusion Code: X8.25277876
2330 Shi M, Liu Z-L, Zhu Y-B, . Effect of health education based on integrative therapy of Chinese and western medicine for adult patients with type 2 diabetes mellitus: a randomized controlled study. Chin J Integr Med. 2018;24(2):94–102. doi: 10.1007/s11655-015-2113-6. PMID: CN-01460674. Exclusion Code: X2.26688178
2331 Shi M, Xu MY, Liu ZL, . Effectiveness of family involvement in newly diagnosed type 2 diabetes patients: a follow-up study. Patient Educ Couns. 2016 May;99(5):776–82. doi: 10.1016/j.pec.2015.12.018. PMID: 26763869. Exclusion Code: X5.26763869
2332 Shi Z, Zhen S, Zimmet PZ, . Association of impaired fasting glucose, diabetes and dietary patterns with mortality: a 10-year follow-up cohort in Eastern China. Acta Diabetol. 2016 Oct;53(5):799–806. doi: 10.1007/s00592-016-0875-8. PMID: 27311686. Exclusion Code: X4.27311686
2333 Shibuya T, Fushimi N, Kawai M, . Luseogliflozin improves liver fat deposition compared to metformin in type 2 diabetes patients with non-alcoholic fatty liver disease: A prospective randomized controlled pilot study. Diabetes Obes Metab. 2018 Feb;20(2):438–42. doi: 10.1111/dom.13061. PMID: 28719078. Exclusion Code: X5.28719078
2334 Shigiyama F, Kumashiro N, Miyagi M, . Linagliptin improves endothelial function in patients with type 2 diabetes: a randomized study of linagliptin effectiveness on endothelial function. J Diabetes Investig. 2017 May;8(3):330–40. doi: 10.1111/jdi.12587. PMID: 27868359. Exclusion Code: X5.27868359
2335 Shigiyama F, Kumashiro N, Miyagi M, . Effectiveness of dapagliflozin on vascular endothelial function and glycemic control in patients with early-stage type 2 diabetes mellitus: DEFENCE study. Cardiovasc Diabetol. 2017 Jul 6;16(1):84. doi: 10.1186/s12933-017-0564-0. PMID: 28683796. Exclusion Code: X5.28683796
2336 Shih CJ, Chen HT, Kuo SC, . Cardiovascular outcomes of dipeptidyl peptidase-4 inhibitors in elderly patients with type 2 diabetes: a nationwide study. J Am Med Dir Assoc. 2016 Jan;17(1):59–64. doi: 10.1016/j.jamda.2015.10.009. PMID: 26612484. Exclusion Code: X2.26612484
2337 Shih CJ, Chu H, Ou SM, . Comparative effectiveness of angiotensin-converting enzyme inhibitors and angiotensin II receptor blockers on major adverse cardiac events in patients with newly diagnosed type 2 diabetes: a nationwide study. Int J Cardiol. 2015 Nov 15;199:283–9. doi: 10.1016/j.ijcard.2015.07.053. PMID: 26218587. Exclusion Code: X5.26218587
2338 Shih CJ, Lee YJ, Lo YH, . Association between use of dipeptidyl peptidase-4 inhibitors and the risk of acute kidney injury: a nested case-control study. Mayo Clin Proc. 2016 Jul;91(7):867–72. doi: 10.1016/j.mayocp.2016.03.022. PMID: 27236426. Exclusion Code: X2.27236426
2339 Shilpa M, Mahdi A, Gupta K, . Treatment with gliptins and study of the variations in serum amylase and serum lipase levels in type 2 diabetes mellitus. International journal of pharmaceutical sciences and research. 2016;7(5):2109–15. doi: 10.13040/IJPSR.0975-8232.7%285%29.2109-15. PMID: CN-01158323. Exclusion Code: X5.
2340 Shimada YJ, Cannon CP, Liu Y, . Ischemic cardiac outcomes and hospitalizations according to prior macrovascular disease status in patients with type 2 diabetes and recent acute coronary syndrome from the Examination of Cardiovascular Outcomes with Alogliptin versus Standard of Care trial. Am Heart J. 2016 May;175:18–27. doi: 10.1016/j.ahj.2016.01.011. PMID: 27179720. Exclusion Code: X2.27179720
2341 Shimodaira M, Niwa T, Nakajima K, . Beneficial effects of vildagliptin on metabolic parameters in patients with type 2 diabetes. Endocr Metab Immune Disord Drug Targets. 2015;15(3):223–8. PMID: 25809193. Exclusion Code: X6.25809193
2342 Shoji M, Onda M, Okada H, . Cost-effectiveness of community pharmacists’ intervention for patients with type 2 diabetes in prevention of diabetic retinopathy. Value in health. Conference: ISPOR 20th annual european congress. United kingdom. 2017;20(9):A479–a80. doi: 10.1016/j.jval.2017.08.459. PMID: CN-01431309. Exclusion Code: X8.
2343 Shono A, Kondo M, Hoshi SL, . Cost-effectiveness of a New Opportunistic Screening Strategy for Walk-in Fingertip HbA1c Testing at Community Pharmacies in Japan. Diabetes Care. 2018 Jun;41(6):1218–26. doi: 10.2337/dc17-1307. PMID: 29686159. Exclusion Code: X8.29686159
2344 Shreck E, Gonzalez J, Cohen H, . Risk perception and self-management in urban, diverse adults with type 2 diabetes: the improving diabetes outcomes study. Int J Behav Med. 2014;21(1):88–98. doi: 10.1007/s12529-013-9291-4. PMID: CN-00993357. Exclusion Code: X2.23385488
2345 Shrestha A, Karmacharya BM, Khudyakov P, . Dietary interventions to prevent and manage diabetes in worksite settings: a meta-analysis. J Occup Health. 2018 Jan 25;60(1):31–45. doi: 10.1539/joh.17-0121-RA. PMID: 29187673. Exclusion Code: X8.29187673
2346 Shrestha N, Kukkonen-Harjula KT, Verbeek JH, . Workplace interventions for reducing sitting at work. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
2347 Shrestha N, Kukkonen-Harjula KT, Verbeek JH, . Workplace interventions for reducing sitting at work. Cochrane Database of Systematic Reviews. 2018(12)doi: 10.1002/14651858.CD010912.pub5. PMID: CD010912. Exclusion Code: X8.
2348 Siddiqui F, Kurbasic A, Lindblad U, . Effects of a culturally adapted lifestyle intervention on cardiometabolic outcomes: a randomized controlled trial in Iraqi immigrants to Sweden at high risk for Type 2 diabetes. Metabolism. 2017 Jan;66:1–13. doi: 10.1016/j.metabol.2016.10.001. PMID: 27923444. Exclusion Code: X2.27923444
2349 Siddiqui F, Winther V, Kurbasic A, . Changes in dietary intake following a culturally adapted lifestyle intervention among Iraqi immigrants to Sweden at high risk of type 2 diabetes: a randomised trial. Public Health Nutr. 2017 Oct;20(15):2827–38. doi: 10.1017/s136898001700146x. PMID: 28738912. Exclusion Code: X6.28738912
2350 Siddiqui MK, Veluchamy A, Maroteau C, . CKM Glu83Gly is associated with blunted creatine kinase variation, but not with myalgia. Circ Cardiovasc Genet. 2017 Aug;10(4)doi: 10.1161/circgenetics.117.001737. PMID: 28790154. Exclusion Code: X8.28790154
2351 Siebenhofer A, Jeitler K, Horvath K, . Long-term effects of weight-reducing drugs in people with hypertension. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
2352 Silva EFF, Ferreira CMM, Pinho L. Risk factors and complications in type 2 diabetes outpatients. Rev Assoc Med Bras (1992). 2017 Jul;63(7):621–7. doi: 10.1590/1806-9282.63.07.621. PMID: 28977088. Exclusion Code: X2.28977088
2353 Silva M, Gouvêa G, Claro A, . Impact of the activation of intention to perform physical activity in type II diabetics: a randomized clinical trial. Ciencia & saude coletiva. 2015;20(3):875–86. doi: 10.1590/1413-81232015203.06452014. PMID: CN-01264986. Exclusion Code: X1.25760127
2354 Simard P, Presse N, Roy L, . Association Between Metformin Adherence and All-Cause Mortality Among New Users of Metformin: A Nested Case-Control Study. Ann Pharmacother. 2018 Apr;52(4):305–13. doi: 10.1177/1060028017743517. PMID: 29144162. Exclusion Code: X5.29144162
2355 Simeone P, Liani R, Tripaldi R, . Thromboxane-Dependent Platelet Activation in Obese Subjects with Prediabetes or Early Type 2 Diabetes: Effects of Liraglutide- or Lifestyle Changes-Induced Weight Loss. Nutrients. 2018 Dec 2;10(12)doi: 10.3390/nu10121872. PMID: 30513818. Exclusion Code: X5.30513818
2356 Simmons RK, Bruun NH, Witte DR, . Does training of general practitioners for intensive treatment of people with screen-detected diabetes have a spillover effect on mortality and cardiovascular morbidity in ‘at risk’ individuals with normoglycaemia? Results from the ADDITION-Denmark cluster-randomised controlled trial. Diabetologia. 2017 Jun;60(6):1016–21. doi: 10.1007/s00125-017-4230-6. PMID: 28280901. Exclusion Code: X2.28280901
2357 Simmons RK, Griffin SJ, Lauritzen T, . Effect of screening for type 2 diabetes on risk of cardiovascular disease and mortality: a controlled trial among 139,075 individuals diagnosed with diabetes in Denmark between 2001 and 2009. Diabetologia. 2017;60(11):2192–9. doi: 10.1007/s00125-017-4299-y. PMID: CN-01615538. Exclusion Code: X11.28831539
2358 Simmons RK, Griffin SJ, Witte DR, . Effect of population screening for type 2 diabetes and cardiovascular risk factors on mortality rate and cardiovascular events: a controlled trial among 1,912,392 Danish adults. Diabetologia. 2017;60(11):2183–91. doi: 10.1007/s00125-017-4323-2. PMID: CN-01615539. Exclusion Code: X11.28831535
2359 Simonson DC, Halperin F, Foster K, . Clinical and Patient-Centered Outcomes in Obese Patients With Type 2 Diabetes 3 Years After Randomization to Roux-en-Y Gastric Bypass Surgery Versus Intensive Lifestyle Management: The SLIMM-T2D Study. Diabetes Care. 2018 Apr;41(4):670–9. doi: 10.2337/dc17-0487. PMID: 29432125. Exclusion Code: X4.29432125
2360 Simpson KA, Mavros Y, Kay S, . Graded Resistance Exercise And Type 2 Diabetes in Older adults (The GREAT2DO study): methods and baseline cohort characteristics of a randomized controlled trial. Trials. 2015 Nov 10;16:512. doi: 10.1186/s13063-015-1037-y. PMID: 26554457. Exclusion Code: X6.26554457
2361 Simpson RW, Nicholson GC, Proietto J, . Efficacy and safety of oral methazolamide in patients with type 2 diabetes: a 24-week, placebo-controlled, double-blind study. Diabetes Care. 2014 Nov;37(11):3121–3. doi: 10.2337/dc14-1038. PMID: 25125506. Exclusion Code: X2.25125506
2362 Simpson SH, Lee J, Choi S, . Mortality risk among sulfonylureas: a systematic review and network meta-analysis. Lancet Diabetes Endocrinol. 2015 Jan;3(1):43–51. doi: 10.1016/s2213-8587(14)70213-x. PMID: 25466239. Exclusion Code: X8.25466239
2363 Simpson TC, Weldon JC, Worthington HV, . Treatment of periodontal disease for glycaemic control in people with diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
2364 Singh A, Dwivedi S. Study of adverse drug reactions in patients with diabetes attending a tertiary care hospital in New Delhi, India. Indian J Med Res. 2017 Feb;145(2):247–9. doi: 10.4103/ijmr.IJMR_109_16. PMID: 28639602. Exclusion Code: X2.28639602
2365 Singh K, Chandrasekaran AM, Bhaumik S, . Cost-effectiveness of interventions to control cardiovascular diseases and diabetes mellitus in South Asia: a systematic review. BMJ Open. 2018 Apr 3;8(4):e017809. doi: 10.1136/bmjopen-2017-017809. PMID: 29615442. Exclusion Code: X8.29615442
2366 Singh RF, Kelly P, Tam A, . Evaluation of a short, interactive diabetes self-management program by pharmacists for type 2 diabetes. BMC Res Notes. 2018 Nov 26;11(1):828. doi: 10.1186/s13104-018-3952-y. PMID: 30477584. Exclusion Code: X8.30477584
2367 Singh RK, Gupta B, Tripathi K, . Anti oxidant potential of metformin and pioglitazone in type 2 diabetes mellitus: beyond their anti glycemic effect. Diabetes Metab Syndr. 2016 Apr–Jun;10(2):102–4. doi: 10.1016/j.dsx.2015.08.016. PMID: 26341927. Exclusion Code: X6.26341927
2368 Singh V, Mishra A, Gupta K, . Reduction of microalbuminuria in type-2 diabetes mellitus with angiotensin-converting enzyme inhibitor alone and with cilnidipine. Indian journal of nephrology; 2015. p. 334–9. Exclusion Code: X5.26664207
2369 Sirois C, Moisan J, Poirier P, . Myocardial infarction and gastrointestinal bleeding risks associated with aspirin use among elderly individuals with type 2 diabetes. Ann Med. 2014 Aug;46(5):335–40. doi: 10.3109/07853890.2014.902636. PMID: 24785356. Exclusion Code: X8.24785356
2370 Sjostrom L. Analysis of the XENDOS study (Xenical in the Prevention of Diabetes in Obese Subjects). Endocrine practice. 2006;12(SUPPL. 1):31–3. PMID: CN-01762713. Exclusion Code: X4.16627377
2371 Skaaby T, Jorgensen T, Linneberg A. A randomized general population study of the effects of repeated health checks on incident diabetes. Endocrine. 2018 Apr;60(1):122–8. doi: 10.1007/s12020-018-1542-3. PMID: 29417371. Exclusion Code: X4.29417371
2372 Skinner TC, Khunti K, Carey ME, . Stability and predictive utility, over 3 years, of the illness beliefs of individuals recently diagnosed with Type 2 diabetes mellitus. Diabet Med. 2014 Oct;31(10):1260–3. doi: 10.1111/dme.12484. PMID: 24798395. Exclusion Code: X6.24798395
2373 Skolnik N, Bonnes H, Yeh H, . Dapagliflozin in the treatment of patients with type 2 diabetes presenting with high baseline A1C. Postgrad Med. 2016 May;128(4):356–63. doi: 10.1080/00325481.2016.1173514. PMID: 27043045. Exclusion Code: X8.27043045
2374 Skoradal MB, Weihe P, Patursson P, . Football training improves metabolic and cardiovascular health status in 55- to 70-year-old women and men with prediabetes. Scand J Med Sci Sports. 2018 Aug;28 Suppl 1:42–51. doi: 10.1111/sms.13081. PMID: 29718556. Exclusion Code: X5.29718556
2375 Skov J, Pedersen M, Holst JJ, . Short-term effects of liraglutide on kidney function and vasoactive hormones in type 2 diabetes: a randomized clinical trial. Diabetes Obes Metab. 2016 Jun;18(6):581–9. doi: 10.1111/dom.12651. PMID: 26910107. Exclusion Code: X6.26910107
2376 Skov V, Cangemi C, Gram J, . Metformin, but not rosiglitazone, attenuates the increasing plasma levels of a new cardiovascular marker, fibulin-1, in patients with type 2 diabetes. Diabetes Care. 2014;37(3):760–6. doi: 10.2337/dc13-1022. PMID: 24135389. Exclusion Code: X5.24135389
2377 Skrivanek Z, Gaydos BL, Chien JY, . Dose-finding results in an adaptive, seamless, randomized trial of once-weekly dulaglutide combined with metformin in type 2 diabetes patients (AWARD-5). Diabetes Obes Metab. 2014 Aug;16(8):748–56. doi: 10.1111/dom.12305. PMID: 24762094. Exclusion Code: X2.24762094
2378 Slentz CA, Bateman LA, Willis LH, . Effects of exercise training alone vs a combined exercise and nutritional lifestyle intervention on glucose homeostasis in prediabetic individuals: a randomised controlled trial. Diabetologia. 2016 Oct;59(10):2088–98. doi: 10.1007/s00125-016-4051-z. PMID: 27421729. Exclusion Code: X5.27421729
2379 Smink PA, Hoekman J, Grobbee DE, . A prediction of the renal and cardiovascular efficacy of aliskiren in ALTITUDE using short-term changes in multiple risk markers. Eur J Prev Cardiol. 2014 Apr;21(4):434–41. doi: 10.1177/2047487313481754. PMID: 23467676. Exclusion Code: X8.23467676
2380 Smith BJ, Cinnadaio N, Cheung NW, . Investigation of a lifestyle change strategy for high-risk women with a history of gestational diabetes. Diabetes Res Clin Pract. 2014 Dec;106(3):e60–3. doi: 10.1016/j.diabres.2014.09.035. PMID: 25451910. Exclusion Code: X5.25451910
2381 Smith SM, Wallace E, O’Dowd T, . Interventions for improving outcomes in patients with multimorbidity in primary care and community settings. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
2382 Smits M, Tonneijck L, Muskiet M, . GLP-1-based therapies have no microvascular effects in type 2 diabetes mellitus. Arterioscler Thromb Vasc Biol. 2016;36(10):2125–32. doi: 10.1161/ATVBAHA.116.307930. PMID: CN-01208168. Exclusion Code: X6.27562916
2383 Smits MM, Tonneijck L, Muskiet MH, . Biliary effects of liraglutide and sitagliptin, a 12-week randomized placebo-controlled trial in type 2 diabetes patients. Diabetes Obes Metab. 2016 Dec;18(12):1217–25. doi: 10.1111/dom.12748. PMID: 27451030. Exclusion Code: X2.27451030
2384 Smits MM, Tonneijck L, Muskiet MH, . GLP-1-based therapies have no microvascular effects in type 2 diabetes mellitus: an acute and 12-week randomized, double-blind, placebo-controlled trial. Arterioscler Thromb Vasc Biol. 2016 Oct;36(10):2125–32. doi: 10.1161/atvbaha.116.307930. PMID: 27562916. Exclusion Code: X2.27562916
2385 Smits MM, Tonneijck L, Muskiet MH, . Heart rate acceleration with GLP-1 receptor agonists in type 2 diabetes patients: an acute and 12-week randomised, double-blind, placebo-controlled trial. Eur J Endocrinol. 2017 Jan;176(1):77–86. doi: 10.1530/eje-16-0507. PMID: 27777261. Exclusion Code: X2.27777261
2386 Smits MM, Tonneijck L, Muskiet MH, . Cardiovascular, renal and gastrointestinal effects of incretin-based therapies: an acute and 12-week randomised, double-blind, placebo-controlled, mechanistic intervention trial in type 2 diabetes. BMJ Open. 2015 Nov 19;5(11):e009579. doi: 10.1136/bmjopen-2015-009579. PMID: 26586327. Exclusion Code: X6.26586327
2387 Smits MM, Tonneijck L, Muskiet MH, . Glucagon-like peptide-1 receptor agonist exenatide has no acute effect on MRI-measured exocrine pancreatic function in patients with type 2 diabetes: a randomized trial. Diabetes Obes Metab. 2016 Mar;18(3):281–8. doi: 10.1111/dom.12612. PMID: 26640129. Exclusion Code: X6.26640129
2388 Smits MM, Tonneijck L, Muskiet MH, . Pancreatic effects of liraglutide or sitagliptin in overweight patients with type 2 diabetes: a 12-week randomized, placebo-controlled trial. Diabetes Care. 2017 Mar;40(3):301–8. doi: 10.2337/dc16-0836. PMID: 27998910. Exclusion Code: X2.27998910
2389 Smits MM, Tonneijck L, Muskiet MH, . Twelve week liraglutide or sitagliptin does not affect hepatic fat in type 2 diabetes: a randomised placebo-controlled trial. Diabetologia. 2016 Dec;59(12):2588–93. doi: 10.1007/s00125-016-4100-7. PMID: 27627981. Exclusion Code: X2.27627981
2390 Soedamah-Muthu SS, Livingstone SJ, Charlton-Menys V, . Effect of atorvastatin on C-reactive protein and benefits for cardiovascular disease in patients with type 2 diabetes: analyses from the Collaborative Atorvastatin Diabetes Trial. Diabetologia. 2015 Jul;58(7):1494–502. doi: 10.1007/s00125-015-3586-8. PMID: 25899452. Exclusion Code: X2.25899452
2391 Soejima H, Ogawa H, Morimoto T, . One quarter of total myocardial infarctions are silent manifestation in patients with type 2 diabetes mellitus. J Cardiol. 2019;73(1):33–7. doi: 10.1016/j.jjcc.2018.05.017. PMID: CN-01618860. Exclusion Code: X5.30487058
2392 Softeland E, Meier JJ, Vangen B, . Empagliflozin as add-on therapy in patients with type 2 diabetes inadequately controlled with linagliptin and metformin: a 24-week randomized, double-blind, parallel-group trial. Diabetes Care. 2017 Feb;40(2):201–9. doi: 10.2337/dc16-1347. PMID: 27913576. Exclusion Code: X2.27913576
2393 Soliman EZ, Byington RP, Bigger JT, . Effect of intensive blood pressure lowering on left ventricular hypertrophy in patients with diabetes mellitus: action to control cardiovascular risk in Diabetes Blood Pressure Trial. Hypertension. 2015 Dec;66(6):1123–9. doi: 10.1161/hypertensionaha.115.06236. PMID: 26459421. Exclusion Code: X6.26459421
2394 Solorio R, Bansal A, Comstock B, . Impact of a chronic care coordinator intervention on diabetes quality of care in a community health center. Health Serv Res. 2015 Jun;50(3):730–49. doi: 10.1111/1475-6773.12253. PMID: 25355532. Exclusion Code: X8.25355532
2395 Son J, Nyklí?ek I, Pop V, . Mindfulness-based cognitive therapy for people with diabetes and emotional problems: long-term follow-up findings from the DiaMind randomized controlled trial. J Psychosom Res. 2014;77(1):81–4. doi: 10.1016/j.jpsychores.2014.03.013. PMID: CN-00996339. Exclusion Code: X4.24913347
2396 Song JH, Chin HS, Kwon OW, . Effect of sulodexide in patients with non-proliferative diabetic retinopathy: diabetic retinopathy sulodexide study (DRESS). Graefes Arch Clin Exp Ophthalmol. 2015 Jun;253(6):829–37. doi: 10.1007/s00417-014-2746-8. PMID: 25112845. Exclusion Code: X2.25112845
2397 Soran H, Liu Y, Adam S, . A comparison of the effects of low- and high-dose atorvastatin on lipoprotein metabolism and inflammatory cytokines in type 2 diabetes: Results from the Protection Against Nephropathy in Diabetes with Atorvastatin (PANDA) randomized trial. J Clin Lipidol. 2018 Jan – Feb;12(1):44–55. doi: 10.1016/j.jacl.2017.10.011. PMID: 29246729. Exclusion Code: X2.29246729
2398 Sorkin DH, Mavandadi S, Rook KS, . Dyadic collaboration in shared health behavior change: the effects of a randomized trial to test a lifestyle intervention for high-risk Latinas. Health Psychol. 2014 Jun;33(6):566–75. doi: 10.1037/hea0000063. PMID: 24884910. Exclusion Code: X2.24884910
2399 Sortso C, Komkova A, Sandbaek A, . Effect of screening for type 2 diabetes on healthcare costs: a register-based study among 139,075 individuals diagnosed with diabetes in Denmark between 2001 and 2009. Diabetologia. 2018 Jun;61(6):1306–14. doi: 10.1007/s00125-018-4594-2. PMID: 29549417. Exclusion Code: X6.29549417
2400 Spencer MS, Kieffer EC, Sinco B, . Outcomes at 18 Months From a Community Health Worker and Peer Leader Diabetes Self-Management Program for Latino Adults. Diabetes Care. 2018 Jul;41(7):1414–22. doi: 10.2337/dc17-0978. PMID: 29703724. Exclusion Code: X2.29703724
2401 Srinivasapura Venkateshmurthy N, Soundappan K, Gummidi B, . Are people at high risk for diabetes visiting health facility for confirmation of diagnosis? A population-based study from rural India. Glob Health Action. 2018;11(1):1416744. doi: 10.1080/16549716.2017.1416744. PMID: 29334333. Exclusion Code: X5.29334333
2402 Srivastava PK, Pradhan AD, Cook NR, . Randomized Trial of the Effects of Insulin and Metformin on Myocardial Injury and Stress in Diabetes Mellitus: a Post Hoc Exploratory Analysis. Journal of the american heart association. 2017;6(12)doi: 10.1161/JAHA.117.007268. PMID: CN-01934201. Exclusion Code: X6.
2403 Stacey D, Légaré F, Lewis K, . Decision aids for people facing health treatment or screening decisions. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2404 Standl E, Stevens SR, Armstrong PW, . Increased Risk of Severe Hypoglycemic Events Before and After Cardiovascular Outcomes in TECOS Suggests an At-Risk Type 2 Diabetes Frail Patient Phenotype. Diabetes Care. 2018 Mar;41(3):596–603. doi: 10.2337/dc17-1778. PMID: 29311155. Exclusion Code: X2.29311155
2405 Starup-Linde J, Gregersen S, Frost M, . Use of glucose-lowering drugs and risk of fracture in patients with type 2 diabetes. Bone. 2017 Feb;95:136–42. doi: 10.1016/j.bone.2016.11.026. PMID: 27890548. Exclusion Code: X2.27890548
2406 Stavrakis S, Stoner JA, Azar M, . Low-dose aspirin for primary prevention of cardiovascular events in patients with diabetes: a meta-analysis. Am J Med Sci. 2011 Jan;341(1):1–9. doi: 10.1097/MAJ.0b013e3181f1fba8. PMID: 21191260. Exclusion Code: X8.21191260
2407 Stefan N, Staiger H, Wagner R, . A high-risk phenotype associates with reduced improvement in glycaemia during a lifestyle intervention in prediabetes. Diabetologia. 2015 Dec;58(12):2877–84. doi: 10.1007/s00125-015-3760-z. PMID: 26404062. Exclusion Code: X8.26404062
2408 Stefansdottir G, Zoungas S, Chalmers J, . Intensive glucose control and risk of cancer in patients with type 2 diabetes. Diabetologia. 2011 Jul;54(7):1608–14. doi: 10.1007/s00125-011-2104-x. PMID: 21509444. Exclusion Code: X2.21509444
2409 Steinberg WM, Buse JB, Ghorbani MLM, . Amylase, lipase, and acute pancreatitis in people with type 2 diabetes treated with liraglutide: results from the LEADER Randomized Trial. Diabetes Care. 2017 Jul;40(7):966–72. doi: 10.2337/dc16-2747. PMID: 28476871. Exclusion Code: X2.28476871
2410 Steinberg WM, Nauck MA, Zinman B, . LEADER 3--lipase and amylase activity in subjects with type 2 diabetes: baseline data from over 9000 subjects in the LEADER Trial. Pancreas. 2014 Nov;43(8):1223–31. doi: 10.1097/mpa.0000000000000229. PMID: 25275271. Exclusion Code: X6.25275271
2411 Steiner G. Treating lipid abnormalities in patients with type 2 diabetes mellitus. Am J Cardiol. 2001;88(12 SUPPL.):37N–40N. PMID: CN-01730312. Exclusion Code: X8.
2412 Steiner S. Effect of amiloride, or amiloride plus hydrochlorothiazide, versus hydrochlorothiazide on glucose tolerance and blood pressure (PATHWAY-3): a parallel-group, double-blind randomised phase 4 Trial. Zeitschrift fur gefassmedizin. 2016;13(1):16–7. PMID: CN-01142303. Exclusion Code: X5.
2413 Steinsbekk A, Rygg LØ, Lisulo M, . Group based diabetes self-management education compared to routine treatment, waiting list control or no intervention for people with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
2414 Steinsbekk A, Rygg LO, Lisulo M, . WITHDRAWN: group based diabetes self-management education compared to routine treatment, waiting list control or no intervention for people with type 2 diabetes mellitus. Cochrane Database Syst Rev. 2015 Jun 30(6):Cd003417. doi: 10.1002/14651858.CD003417.pub3. PMID: 26125655. Exclusion Code: X8.26125655
2415 Stenlof K, Cefalu WT, Kim KA, . Long-term efficacy and safety of canagliflozin monotherapy in patients with type 2 diabetes inadequately controlled with diet and exercise: findings from the 52-week CANTATA-M study. Curr Med Res Opin. 2014 Feb;30(2):163–75. doi: 10.1185/03007995.2013.850066. PMID: 24073995. Exclusion Code: X2.24073995
2416 Stentz F, Brewer A, Wan J, . Remission of pre-diabetes to normal glucose tolerance in obese adults with high protein versus high carbohydrate diet: randomized control trial. BMJ open diabetes research and care. 2016;4(1) (no pagination)doi: 10.1136/bmjdrc-2016-000258. PMID: CN-01248296. Exclusion Code: X4.
2417 Stentz F, Garber C, Kitabchi A. Efficacy of high protein vs. high carbohydrate diet on remission of impaired glucose tolerance (IGT) to normal glucose tolerance (NGT) and physiological parameters in obese adults. Diabetes. 2015;64:A512. doi: 10.2337/db1519292253. PMID: CN-01103666. Exclusion Code: X5.
2418 Stenvers D, Schouten L, Jurgens J, . Breakfast replacement with a low-glycaemic response liquid formula in patients with type 2 diabetes: a randomised clinical trial. British journal of nutrition. 2014;112(4):504–12. doi: 10.1017/S0007114514001123. PMID: CN-00998528. Exclusion Code: X2.
2419 Stern D, Smith LP, Zhang B, . Changes in waist circumference relative to body mass index in Chinese adults, 1993-2009. Int J Obes (Lond). 2014 Dec;38(12):1503–10. doi: 10.1038/ijo.2014.74. PMID: 24813367. Exclusion Code: X8.24813367
2420 Stettler C, Allemann S, Juni P, . Glycemic control and macrovascular disease in types 1 and 2 diabetes mellitus: meta-analysis of randomized trials. Am Heart J. 2006 Jul;152(1):27–38. doi: 10.1016/j.ahj.2005.09.015. PMID: 16824829. Exclusion Code: X8.16824829
2421 Steurer J. Endurance training and walking improve blood glucose metabolism in type 2 diabetes mellitus. Praxis. 2015;104(21):1157. doi: 10.1024/1661-8157/a002143. PMID: CN-01169439. Exclusion Code: X1.26463908
2422 Steven S, Taylor R. Restoring normoglycaemia by use of a very low calorie diet in long- and short-duration Type 2 diabetes. Diabet Med. 2015 Sep;32(9):1149–55. doi: 10.1111/dme.12722. PMID: 25683066. Exclusion Code: X6.25683066
2423 Stevens A, Hansen D, Herbots L, . Exercise training improves insulin release during glucose tolerance testing in stable chronic heart failure patients. J Cardiopulm Rehabil Prev. 2015;35(1):37–46. doi: 10.1097/HCR.0000000000000092. PMID: CN-01040198. Exclusion Code: X2.25533903
2424 Stevens JW, Khunti K, Harvey R, . Preventing the progression to type 2 diabetes mellitus in adults at high risk: a systematic review and network meta-analysis of lifestyle, pharmacological and surgical interventions. Diabetes Res Clin Pract. 2015 Mar;107(3):320–31. doi: 10.1016/j.diabres.2015.01.027. PMID: 25638454. Exclusion Code: X8.25638454
2425 Steyn NP, Lambert EV, Tabana H. Nutrition interventions for the prevention of type 2 diabetes (Structured abstract). Proceedings of the Nutrition Society; 2009. p. 55–70. Exclusion Code: X8.
2426 Stockl D, Ruckert-Eheberg IM, Heier M, . Regional variability of lifestyle factors and hypertension with prediabetes and newly diagnosed type 2 diabetes mellitus: the population-based KORA-F4 and SHIP-TREND Studies in Germany. PLoS One. 2016;11(6):e0156736. doi: 10.1371/journal.pone.0156736. PMID: 27275745. Exclusion Code: X6.27275745
2427 Strauss MH, Hall AS. The Divergent Cardiovascular Effects of Angiotensin-Converting Enzyme Inhibitors and Angiotensin II Type 1 Receptor Blockers in Adult Patients With Type 2 Diabetes Mellitus. Can J Diabetes. 2018 Apr;42(2):124–9. doi: 10.1016/j.jcjd.2017.09.011. PMID: 29277343. Exclusion Code: X8.29277343
2428 Stringer F, DeJongh J, Enya K, . Evaluation of the long-term durability and glycemic control of fasting plasma glucose and glycosylated hemoglobin for pioglitazone in Japanese patients with type 2 diabetes. Diabetes Technol Ther. 2015 Mar;17(3):215–23. doi: 10.1089/dia.2014.0222. PMID: 25531677. Exclusion Code: X2.25531677
2429 Stringhini S, Zaninotto P, Kumari M, . Lifecourse socioeconomic status and type 2 diabetes: the role of chronic inflammation in the English Longitudinal Study of Ageing. Sci Rep. 2016 Apr 22;6:24780. doi: 10.1038/srep24780. PMID: 27101929. Exclusion Code: X5.27101929
2430 Stroes E, Robinson JG, Raal FJ, . Consistent LDL-C response with evolocumab among patient subgroups in PROFICIO: A pooled analysis of 3146 patients from phase 3 studies. Clin Cardiol. 2018 Oct;41(10):1328–35. doi: 10.1002/clc.23049. PMID: 30120772. Exclusion Code: X8.30120772
2431 Strojek K, Yoon K-H, Hruba V, . Dapagliflozin added to glimepiride in patients with type 2 diabetes mellitus sustains glycemic control and weight loss over 48 weeks: a randomized, double-blind, parallel-group, placebo-controlled trial. Diabetes therapy. 2014;5(1):267–83. doi: 10.1007/s13300-014-0072-0. PMID: CN-01068687. Exclusion Code: X2.24920277
2432 Strongman H, D’Oca K, Langerman H, . Comparison of diabetes-associated secondary healthcare utilization between alternative oral antihyperglycaemic dual therapy combinations with metformin in patients with type 2 diabetes: an observational cohort study. Diabetes Obes Metab. 2015 Jun;17(6):573–80. doi: 10.1111/dom.12458. PMID: 25735201. Exclusion Code: X5.25735201
2433 Strozik A, Steposz A, Basiak M, . Multifactorial effects of vildagliptin added to ongoing metformin therapy in patients with type 2 diabetes mellitus. Pharmacol Rep. 2015 Feb;67(1):24–31. doi: 10.1016/j.pharep.2014.07.016. PMID: 25560571. Exclusion Code: X2.25560571
2434 Suarez O, Pardo M, Gonzalez S, . Diabetes mellitus and renal transplantation in adults: is there enough evidence for diagnosis, treatment, and prevention of new-onset diabetes after renal transplantation? Transplant Proc. 2014 Nov;46(9):3015–20. doi: 10.1016/j.transproceed.2014.07.011. PMID: 25420813. Exclusion Code: X8.25420813
2435 Suissa S, Moodie EE, Dell’Aniello S. Prevalent new-user cohort designs for comparative drug effect studies by time-conditional propensity scores. Pharmacoepidemiol Drug Saf. 2017 Apr;26(4):459–68. doi: 10.1002/pds.4107. PMID: 27610604. Exclusion Code: X2.27610604
2436 Sukumar N, Dallosso H, Saravanan P, . Baby Steps - A structured group education programme with accompanying mobile web application designed to promote physical activity in women with a history of gestational diabetes: study protocol for a randomised controlled trial. Trials. 2018;19(1)doi: 10.1186/s13063-018-3067-8. PMID: CN-01787527. Exclusion Code: X6.
2437 Sullivan MD, Anderson RT, Aron D, . Health-related quality of life and cost-effectiveness components of the Action to Control Cardiovascular Risk in Diabetes (ACCORD) trial: rationale and design. Am J Cardiol. 2007 Jun 18;99(12A):90i–102i. doi: 10.1016/j.amjcard.2007.03.027. PMID: 17599429. Exclusion Code: X2.17599429
2438 Sullivan SD, Jablonski KA, Florez JC, . Genetic risk of progression to type 2 diabetes and response to intensive lifestyle or metformin in prediabetic women with and without a history of gestational diabetes mellitus. Diabetes Care. 2014 Apr;37(4):909–11. doi: 10.2337/dc13-0700. PMID: 24271189. Exclusion Code: X3.24271189
2439 Sumlin LL, Garcia TJ, Brown SA, . Depression and adherence to lifestyle changes in type 2 diabetes: a systematic review. Diabetes Educ. 2014 Nov–Dec;40(6):731–44. doi: 10.1177/0145721714538925. PMID: 24939883. Exclusion Code: X8.24939883
2440 Sun F, Chai S, Yu K, . Gastrointestinal adverse events of glucagon-like peptide-1 receptor agonists in patients with type 2 diabetes: a systematic review and network meta-analysis. Diabetes Technol Ther. 2015 Jan;17(1):35–42. doi: 10.1089/dia.2014.0188. PMID: 25375397. Exclusion Code: X8.25375397
2441 Sun F, Yu K, Yang Z, . Impact of GLP-1 receptor agonists on major gastrointestinal disorders for type 2 diabetes mellitus: a mixed treatment comparison meta-analysis. Exp Diabetes Res. 2012;2012doi: 10.1155/2012/230624. PMID: CN-01725408. Exclusion Code: X8.
2442 Sun W, Zeng C, Liao L, . Comparison of acarbose and metformin therapy in newly diagnosed type 2 diabetic patients with overweight and/or obesity. Curr Med Res Opin. 2016 Aug;32(8):1389–96. doi: 10.1080/03007995.2016.1176013. PMID: 27052634. Exclusion Code: X5.27052634
2443 Sun X, Guo L, Shang H, . The cost-effectiveness analysis of JinQi Jiangtang tablets for the treatment on prediabetes: a randomized, double-blind, placebo-controlled, multicenter design. Trials. 2015 Nov 3;16:496. doi: 10.1186/s13063-015-0990-9. PMID: 26530718. Exclusion Code: X4.26530718
2444 Suriyawongpaisal P, Tansirisithikul R, Sakulpipat T, . A participatory randomized controlled trial in knowledge translation (KT) to promote the adoption of self-monitoring of blood glucose for type 2 diabetes mellitus patients in an urban district of Thailand. Chotmaihet thangphaet [Journal of the Medical Association of Thailand]. 2016;99(2):125–32. PMID: CN-01142089. Exclusion Code: X2.
2445 Suryanegara J, Cassidy S, Ninkovic V, . High intensity interval training protects the heart during increased metabolic demand in patients with type 2 diabetes: a randomised controlled trial. Acta Diabetol. 2019 Mar;56(3):321–9. doi: 10.1007/s00592-018-1245-5. PMID: 30387015. Exclusion Code: X2.30387015
2446 Suzuki S, Oura T, Takeuchi M, . Evaluation of the impact of once weekly dulaglutide on patient-reported outcomes in Japanese patients with type 2 diabetes: comparisons with liraglutide, insulin glargine, and placebo in two randomized studies. Health Qual Life Outcomes. 2017 Jun 12;15(1):123. doi: 10.1186/s12955-017-0696-7. PMID: 28606095. Exclusion Code: X6.28606095
2447 Swerdlow DI, Preiss D, Kuchenbaecker KB, . HMG-coenzyme A reductase inhibition, type 2 diabetes, and bodyweight: evidence from genetic analysis and randomised trials. Lancet. 2015 Jan 24;385(9965):351–61. doi: 10.1016/s0140-6736(14)61183-1. PMID: 25262344. Exclusion Code: X8.25262344
2448 Swinburn BA, Metcalf PA, Ley SJ. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001 Apr;24(4):619–24. PMID: 11315819. Exclusion Code: X2.11315819
2449 Swoboda CM, Miller CK, Wills CE. Setting single or multiple goals for diet and physical activity behaviors improves cardiovascular disease risk factors in adults with type 2 diabetes: a pragmatic pilot randomized trial. Diabetes Educ. 2016 Aug;42(4):429–43. doi: 10.1177/0145721716650043. PMID: 27194048. Exclusion Code: X2.27194048
2450 Swoboda CM, Miller CK, Wills CE. Impact of a goal setting and decision support telephone coaching intervention on diet, psychosocial, and decision outcomes among people with type 2 diabetes. Patient Educ Couns. 2017 Jul;100(7):1367–73. doi: 10.1016/j.pec.2017.02.007. PMID: 28215827. Exclusion Code: X6.28215827
2451 Sykes AP, Kemp GL, Dobbins R, . Randomized efficacy and safety trial of once-daily remogliflozin etabonate for the treatment of type 2 diabetes. Diabetes Obes Metab. 2015 Jan;17(1):98–101. doi: 10.1111/dom.12393. PMID: 25238025. Exclusion Code: X2.25238025
2452 Sykes AP, O’Connor-Semmes R, Dobbins R, . Randomized trial showing efficacy and safety of twice-daily remogliflozin etabonate for the treatment of type 2 diabetes. Diabetes Obes Metab. 2015 Jan;17(1):94–7. doi: 10.1111/dom.12391. PMID: 25223369. Exclusion Code: X2.25223369
2453 Sylvetsky AC, Edelstein SL, Walford G, . A high-carbohydrate, high-fiber, low-fat diet results in weight loss among adults at high risk of type 2 diabetes. J Nutr. 2017 Nov;147(11):2060–6. doi: 10.3945/jn.117.252395. PMID: 28954840. Exclusion Code: X6.28954840
2454 Szilágyi B, Kukla A, Makai A, . Sports therapy and recreation exercise program in type 2 diabetes: randomized controlled trial, 3-month follow-up. Journal of sports medicine and physical fitness. 2019;59(4):676–85. doi: 10.23736/S0022-4707.18.08591-2. PMID: CN-01942473. Exclusion Code: X2.
2455 Tada Y, Kanazawa I, Notsu M, . Long-term efficacy and safety of sitagliptin in elderly patients with type 2 diabetes mellitus. Intern Med. 2016;55(10):1275–8. doi: 10.2169/internalmedicine.55.6011. PMID: 27181532. Exclusion Code: X2.27181532
2456 Taggart L, Truesdale M, Carey ME, . Pilot feasibility study examining a structured self-management diabetes education programme, DESMOND-ID, targeting HbA1c in adults with intellectual disabilities. Diabet Med. 2018 Jan;35(1):137–46. doi: 10.1111/dme.13539. PMID: 29083501. Exclusion Code: X6.29083501
2457 Tahara N, Yamagishi SI, Bekki M, . Anagliptin, a dipeptidyl peptidase-4 inhibitor ameliorates arterial stiffness in association with reduction of remnant-like particle cholesterol and alanine transaminase levels in type 2 diabetic patients. Curr Vasc Pharmacol. 2016;14(6):552–62. PMID: 27357182. Exclusion Code: X5.27357182
2458 Taheri S, Asim M, al MH, . Intervention using vitamin D for elevated urinary albumin in type 2 diabetes mellitus (IDEAL-2 Study): study protocol for a randomised controlled trial. Trials. 2018;19(1) (no pagination)doi: 10.1186/s13063-018-2616-5. PMID: CN-01569330. Exclusion Code: X6.
2459 Tajima N, Kadowaki T, Odawara M, . Safety and efficacy of addition of sitagliptin to rapid-acting insulin secretagogues for glycemic control, including post-prandial hyperglycemia, among Japanese with type 2 diabetes mellitus. Diabetology international. 2016;7(2):155–66. doi: 10.1007/s13340-015-0230-2. PMID: CN-01167116. Exclusion Code: X2.30603259
2460 Tajima N, Kurata H, Nakaya N, . Pravastatin reduces the risk for cardiovascular disease in Japanese hypercholesterolemic patients with impaired fasting glucose or diabetes: diabetes subanalysis of the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) Study. Atherosclerosis. 2008 Aug;199(2):455–62. doi: 10.1016/j.atherosclerosis.2008.05.027. PMID: 18635188. Exclusion Code: X2.18635188
2461 Takahara M, Shiraiwa T, Katakami N, . Efficacy of adding once- and thrice-daily voglibose in Japanese type 2 diabetic patients treated with alogliptin. Endocr J. 2014;61(5):447–56. PMID: 24561488. Exclusion Code: X4.24561488
2462 Takahashi E, Moriyama K, Yamakado M. Lifestyle and glycemic control in Japanese adults receiving diabetes treatment: an analysis of the 2009 Japan Society of Ningen Dock database. Diabetes Res Clin Pract. 2014 May;104(2):e50–3. doi: 10.1016/j.diabres.2014.01.025. PMID: 24598264. Exclusion Code: X8.24598264
2463 Takahashi S, Katada J, Daida H, . Effects of mineralocorticoid receptor antagonists in patients with hypertension and diabetes mellitus: a systematic review and meta-analysis. J Hum Hypertens. 2016 Sep;30(9):534–42. doi: 10.1038/jhh.2015.119. PMID: 26674759. Exclusion Code: X8.26674759
2464 Takatori S, Hamada Y, Tanaka A, . Factors contributing to the clinical effectiveness of the DPP-4 inhibitor sitagliptin in patients with type 2 diabetes. Clin Ther. 2016 Feb;38(2):398–403. doi: 10.1016/j.clinthera.2015.12.014. PMID: 26804641. Exclusion Code: X5.26804641
2465 Takebayashi K, Sakurai S, Suzuki T, . Effect of combination therapy with alogliptin and lansoprazole on glycemic control in patients with type 2 diabetes. Endocr J. 2014;61(10):1031–9. PMID: 25185672. Exclusion Code: X5.25185672
2466 Tamblyn R, Girard N, Dixon WG, . Pharmacosurveillance without borders: electronic health records in different countries can be used to address important methodological issues in estimating the risk of adverse events. J Clin Epidemiol. 2016 Sep;77:101–11. doi: 10.1016/j.jclinepi.2016.03.033. PMID: 27212138. Exclusion Code: X5.27212138
2467 Tamez-Pérez H. Efficacy and safety of initial treatment with glimpeiride versus sitagliptin in type 2 diabetes. Revista medica del instituto mexicano del seguro social. 2015;53(2):142–8. PMID: CN-01256914. Exclusion Code: X5.25760742
2468 Tan ML, Manski-Nankervis JA, Thuraisingam S, . Socioeconomic status and time in glucose target range in people with type 2 diabetes: a baseline analysis of the GP-OSMOTIC study. BMC Endocr Disord. 2018 Jul 21;18(1):47. doi: 10.1186/s12902-018-0279-6. PMID: 30031385. Exclusion Code: X2.30031385
2469 Tanabe A, Kaneto H, Kamei S, . Clinical effects of liraglutide are possibly influenced by hypertriglyceridemia and remaining pancreatic beta-cell function in subjects with type 2 diabetes mellitus. J Diabetes Complications. 2016 Aug;30(6):1201–3. doi: 10.1016/j.jdiacomp.2016.04.005. PMID: 27220544. Exclusion Code: X6.27220544
2470 Tanaka A, Kawaguchi A, Oyama JI, . Differential effect of concomitant antidiabetic agents on carotid atherosclerosis: a subgroup analysis of the PROLOGUE study. Heart Vessels. 2019 Feb;34(2):375–84. doi: 10.1007/s00380-018-1275-5. PMID: 30284018. Exclusion Code: X2.30284018
2471 Tanaka A, Shimabukuro M, Okada Y, . Rationale and design of a multicenter placebo-controlled double-blind randomized trial to evaluate the effect of empagliflozin on endothelial function: the EMBLEM trial. Cardiovasc Diabetol. 2017 Apr 12;16(1):48. doi: 10.1186/s12933-017-0532-8. PMID: 28403850. Exclusion Code: X6.28403850
2472 Tanaka A, Yoshida H, Nanasato M, . Sitagliptin on carotid intima-media thickness in type 2 diabetes patients receiving primary or secondary prevention of cardiovascular disease: A subgroup analysis of the PROLOGUE study. Int J Cardiol. 2018 Nov 15;271:331–5. doi: 10.1016/j.ijcard.2018.05.055. PMID: 29803341. Exclusion Code: X2.29803341
2473 Tanaka K, Saisho Y, Kawai T, . Efficacy and safety of liraglutide monotherapy compared with metformin in Japanese overweight/obese patients with type 2 diabetes. Endocr J. 2015;62(5):399–409. doi: 10.1507/endocrj.EJ14-0602. PMID: 25739726. Exclusion Code: X5.25739726
2474 Tanaka N, Hiura Y. Effects of rapid-acting insulin analogues insulin glulisine and insulin aspart on postprandial glycemic excursion with single bout of exercise in patients with type 2 diabetes. Endocr J. 2015;62(5):411–6. doi: 10.1507/endocrj.EJ14-0610. PMID: CN-01257089. Exclusion Code: X2.25739586
2475 Tanaka R, Yamashiro K, Okuma Y, . Effects of pioglitazone for secondary stroke prevention in patients with impaired glucose tolerance and newly diagnosed diabetes: the J-SPIRIT Study. J Atheroscler Thromb. 2015;22(12):1305–16. doi: 10.5551/jat.30007. PMID: 26269002. Exclusion Code: X2.26269002
2476 Tanaka S, Tanaka S, Iimuro S, . Cohort profile: the Japan diabetes complications study: a long-term follow-up of a randomised lifestyle intervention study of type 2 diabetes. Int J Epidemiol. 2014 Aug;43(4):1054–62. doi: 10.1093/ije/dyt057. PMID: 23687126. Exclusion Code: X2.23687126
2477 Tanamas SK, Saulnier PJ, Fufaa GD, . Long-term effect of losartan on kidney disease in american indians with type 2 diabetes: a follow-up analysis of a randomized clinical trial. Diabetes Care. 2016 Nov;39(11):2004–10. doi: 10.2337/dc16-0795. PMID: 27612501. Exclusion Code: X2.27612501
2478 Tanenbaum ML, Kane NS, Kenowitz J, . Diabetes distress from the patient’s perspective: qualitative themes and treatment regimen differences among adults with type 2 diabetes. J Diabetes Complications. 2016 Aug;30(6):1060–8. doi: 10.1016/j.jdiacomp.2016.04.023. PMID: 27217023. Exclusion Code: X8.27217023
2479 Tang T, Funnell M, Sinco B, . Peer-Led, Empowerment-Based Approach to Self-Management Efforts in Diabetes (PLEASED): a randomized controlled trial in an African American community. Ann Fam Med. 2015;13 Suppl 1:S27–35. doi: 10.1370/afm.1819. PMID: CN-01170152. Exclusion Code: X2.26304969
2480 Tang TS, Funnell M, Sinco B, . Comparative effectiveness of peer leaders and community health workers in diabetes self-management support: results of a randomized controlled trial. Diabetes Care. 2014 Jun;37(6):1525–34. doi: 10.2337/dc13-2161. PMID: 24722495. Exclusion Code: X2.24722495
2481 Tani S, Takahashi A, Nagao K, . Effect of dipeptidyl peptidase-4 inhibitor, vildagliptin on plasminogen activator inhibitor-1 in patients with diabetes mellitus. Am J Cardiol. 2015 Feb 15;115(4):454–60. doi: 10.1016/j.amjcard.2014.11.044. PMID: 25637323. Exclusion Code: X6.25637323
2482 Tao T, Wu P, Wang Y, . Comparison of glycemic control and beta-cell function in new onset T2DM patients with PCOS of metformin and saxagliptin monotherapy or combination treatment. BMC Endocr Disord. 2018;18(1) (no pagination)doi: 10.1186/s12902-018-0243-5. PMID: CN-01465670. Exclusion Code: X5.
2483 Tarride JE, Smofsky A, Nykoliation P, . Effectiveness of a Type 2 Diabetes Screening Intervention in the Canadian Workplace. Can J Diabetes. 2018 Oct;42(5):493–9.e1. doi: 10.1016/j.jcjd.2017.12.008. PMID: 29555342. Exclusion Code: X5.29555342
2484 Taskinen MR, Del Prato S, Bujas-Bobanovic M, . Efficacy and safety of alirocumab in individuals with type 2 diabetes mellitus with or without mixed dyslipidaemia: analysis of the ODYSSEY LONG TERM trial. Atherosclerosis. 2018;276:124–30. doi: 10.1016/j.atherosclerosis.2018.07.017. PMID: CN-01630348. Exclusion Code: X8.30059843
2485 Tawfik M, Mohamed R. The impact of communicating cardiovascular risk in type 2 diabetics on patient risk perception, diabetes self-care, glycosylated hemoglobin, and cardiovascular risk. Journal of public health (germany). 2016;24(2):153–64. doi: 10.1007/s10389-016-0710-2. PMID: CN-01141476. Exclusion Code: X2.
2486 Tay J, Thompson C, Luscombe-Marsh N, . Long-term effects of a very low carbohydrate compared with a high carbohydrate diet on renal function in individuals with type 2 diabetes: a randomized trial. Medicine. 2015;94(47):e2181. doi: 10.1097/MD.0000000000002181. PMID: CN-01168779. Exclusion Code: X2.26632754
2487 Taylor-Cousar JL, Janssen JS, Wilson A, . Glucose >200 mg/dL during Continuous Glucose Monitoring Identifies Adult Patients at Risk for Development of Cystic Fibrosis Related Diabetes. J Diabetes Res. 2016;2016:1527932. doi: 10.1155/2016/1527932. PMID: 27999822. Exclusion Code: X2.27999822
2488 Teljeur C, Moran PS, Walshe S, . Economic evaluation of chronic disease self-management for people with diabetes: a systematic review. Diabet Med. 2017 Aug;34(8):1040–9. doi: 10.1111/dme.13281. PMID: 27770591. Exclusion Code: X8.27770591
2489 Ten Kulve JS, Veltman DJ, van Bloemendaal L, . Endogenous GLP1 and GLP1 analogue alter CNS responses to palatable food consumption. J Endocrinol. 2016 Apr;229(1):1–12. doi: 10.1530/joe-15-0461. PMID: 26769912. Exclusion Code: X6.26769912
2490 Teng A, Blakely T, Scott N, . What protects against pre-diabetes progressing to diabetes? Observational study of integrated health and social data. Diabetes Res Clin Pract. 2019 Feb;148:119–29. doi: 10.1016/j.diabres.2018.12.003. PMID: 30633935. Exclusion Code: X4.30633935
2491 Tenkorang EY. Early onset of type 2 diabetes among visible minority and immigrant populations in Canada. Ethn Health. 2017 Jun;22(3):266–84. doi: 10.1080/13557858.2016.1244623. PMID: 27771960. Exclusion Code: X4.27771960
2492 Terada T, Wilson B, Myette-C?té E, . Targeting specific interstitial glycemic parameters with high-intensity interval exercise and fasted-state exercise in type 2 diabetes. Metabolism. 2016;65(5):599–608. doi: 10.1016/j.metabol.2016.01.003. PMID: CN-01140591. Exclusion Code: X2.27085769
2493 Terauchi Y, Naito Y, Ikeda Y. Evaluation of unmet medical need among Japanese patients with type 2 diabetes mellitus and efficacy of Lixisenatide treatment among Asian type 2 diabetes mellitus patients. Diabetes Metab Syndr. 2016 Jan–Mar;10(1):23–8. doi: 10.1016/j.dsx.2015.08.008. PMID: 26341928. Exclusion Code: X8.26341928
2494 Terauchi Y, Riddle MC, Hirose T, . Glycaemic control, hypoglycaemia, and weight change with insulin glargine 300 U/mL versus insulin glargine 100 U/mL in Japanese adults with type 2 diabetes: A 12-month comparison by concomitant sulphonylurea and/or glinide use. Diabetes Obes Metab. 2018 Nov;20(11):2541–50. doi: 10.1111/dom.13414. PMID: 29888454. Exclusion Code: X2.29888454
2495 Terauchi Y, Satoi Y, Takeuchi M, . Monotherapy with the once weekly GLP-1 receptor agonist dulaglutide for 12 weeks in Japanese patients with type 2 diabetes: dose-dependent effects on glycaemic control in a randomised, double-blind, placebo-controlled study. Endocr J. 2014;61(10):949–59. PMID: 25029955. Exclusion Code: X2.25029955
2496 Terauchi Y, Tamura M, Senda M, . Efficacy and safety of tofogliflozin in Japanese patients with type 2 diabetes mellitus with inadequate glycaemic control on insulin therapy (J-STEP/INS): results of a 16-week randomized, double-blind, placebo-controlled multicentre trial. Diabetes, obesity & metabolism. 2017;(no pagination)doi: 10.1111/dom.12957. PMID: CN-01395420. Exclusion Code: X2.
2497 Terauchi Y, Yamada Y, Ishida H, . Efficacy and safety of sitagliptin as compared with glimepiride in Japanese patients with type 2 diabetes mellitus aged >= 60 years (START-J trial). Diabetes, obesity & metabolism. 2017;19(8):1188–92. doi: 10.1111/dom.12933. PMID: CN-01394843. Exclusion Code: X5.
2498 Terra S, Focht K, Davies M, . Phase III, efficacy and safety study of ertugliflozin monotherapy in people with type 2 diabetes mellitus inadequately controlled with diet and exercise alone. Diabetes, obesity & metabolism. 2017;(no pagination)doi: 10.1111/dom.12888. PMID: CN-01328913. Exclusion Code: X2.
2499 Tessier DM, Meneilly GS, Moleski L, . Influence of blood pressure and other clinical variables on long-term mortality in a cohort of elderly subjects with type 2 diabetes. Can J Diabetes. 2016 Feb;40(1):12–6. doi: 10.1016/j.jcjd.2015.09.089. PMID: 26827682. Exclusion Code: X2.26827682
2500 Teston EF, Arruda GO, Sales CA, . Nursing appointment and cardiometabolic control of diabetics: a randomized clinical trial. Rev Bras Enferm. 2017 May–Jun;70(3):468–74. doi: 10.1590/0034-7167-2016-0352. PMID: 28562792. Exclusion Code: X6.28562792
2501 Thaker V, Carter B, Putman M. Recombinant growth hormone therapy for cystic fibrosis in children and young adults. Cochrane Database of Systematic Reviews. 2018(12)doi: 10.1002/14651858.CD008901.pub4. PMID: CD008901. Exclusion Code: X8.
2502 Thaker V, Haagensen AL, Carter B, . Recombinant growth hormone therapy for cystic fibrosis in children and young adults. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
2503 Thankappan KR, Sathish T, Tapp RJ, . A peer-support lifestyle intervention for preventing type 2 diabetes in India: A cluster-randomized controlled trial of the Kerala Diabetes Prevention Program. PLoS Med. 2018 Jun;15(6):e1002575. doi: 10.1371/journal.pmed.1002575. PMID: 29874236. Exclusion Code: X2.29874236
2504 Thapa S, Trivedi N, Omer A. Elevated serum beta-hydroxybutyrate levels (B-hb) in patients with type 2 diabetes mellitus using sodium-glucose cotransporter 2 (SGLT-2) inhibitor. Endocrine reviews. Conference: 98th annual meeting and expo of the endocrine society, ENDO 2016. United states. Conference start: 20160401. Conference end: 20160404. 2016;37(2 Supplement 1) (no pagination)doi: 10.1210/endo-meetings.2016.DGM.23.FRI-715. PMID: CN-01295136. Exclusion Code: X2.
2505 Thavorasak T, Kamkaen P, Rattanasri A, . Diabetic risk score and fasting plasma glucose testing in the screening for type 2 diabetes mellitus risk. International journal of pharmaceutical and clinical research; 2017. p. 435–8. Exclusion Code: X7.
2506 Thazhath SS, Marathe CS, Wu T, . The glucagon-like peptide 1 receptor agonist exenatide inhibits small intestinal motility, flow, transit, and absorption of glucose in healthy subjects and patients with type 2 diabetes: a randomized controlled trial. Diabetes. 2016 Jan;65(1):269–75. doi: 10.2337/db15-0893. PMID: 26470783. Exclusion Code: X5.26470783
2507 Thazhath SS, Marathe CS, Wu T, . Acute effects of the glucagon-like peptide-1 receptor agonist, exenatide, on blood pressure and heart rate responses to intraduodenal glucose infusion in type 2 diabetes. Diab Vasc Dis Res. 2017 Jan;14(1):59–63. doi: 10.1177/1479164116666761. PMID: 27941058. Exclusion Code: X2.27941058
2508 Thompson D, Walhin JP, Batterham AM, . Effect of diet or diet plus physical activity versus usual care on inflammatory markers in patients with newly diagnosed type 2 diabetes: the Early ACTivity in Diabetes (ACTID) randomized, controlled trial. J Am Heart Assoc. 2014 May 8;3(3):e000828. doi: 10.1161/jaha.114.000828. PMID: 24811615. Exclusion Code: X6.24811615
2509 Thomsen RW, Baggesen LM, Sogaard M, . Early glycaemic control in metformin users receiving their first add-on therapy: a population-based study of 4,734 people with type 2 diabetes. Diabetologia. 2015 Oct;58(10):2247–53. doi: 10.1007/s00125-015-3698-1. PMID: 26277380. Exclusion Code: X2.26277380
2510 Thomsen RW, Baggesen LM, Svensson E, . Early glycaemic control among patients with type 2 diabetes and initial glucose-lowering treatment: a 13-year population-based cohort study. Diabetes Obes Metab. 2015 Aug;17(8):771–80. doi: 10.1111/dom.12484. PMID: 25929277. Exclusion Code: X8.25929277
2511 Thomsen RW, Pedersen L, Moller N, . Incretin-based therapy and risk of acute pancreatitis: a nationwide population-based case-control study. Diabetes Care. 2015 Jun;38(6):1089–98. doi: 10.2337/dc13-2983. PMID: 25633664. Exclusion Code: X5.25633664
2512 Thomson H, Oliver N, Godsland IF, . Protocol for a clinical trial of text messaging in addition to standard care versus standard care alone in prevention of type 2 diabetes through lifestyle modification in India and the UK. BMC Endocr Disord. 2018 Sep 10;18(1):63. doi: 10.1186/s12902-018-0293-8. PMID: 30200935. Exclusion Code: X6.30200935
2513 Thomson SR, Chogtu B, Shetty R, . Analysis of glycemic status in diabetes-naive patients on statins: A hospital-based cross-sectional study. Indian J Pharmacol. 2018 Nov–Dec;50(6):320–5. doi: 10.4103/ijp.IJP_132_18. PMID: 30783324. Exclusion Code: X8.30783324
2514 Thong KY, Gupta PS, Blann AD, . The influence of age and metformin treatment status on reported gastrointestinal side effects with liraglutide treatment in type 2 diabetes. Diabetes Res Clin Pract. 2015 Jul;109(1):124–9. doi: 10.1016/j.diabres.2015.04.009. PMID: 25937541. Exclusion Code: X6.25937541
2515 Thorpe CT, Gellad WF, Good CB, . Tight glycemic control and use of hypoglycemic medications in older veterans with type 2 diabetes and comorbid dementia. Diabetes Care. 2015 Apr;38(4):588–95. doi: 10.2337/dc14-0599. PMID: 25592195. Exclusion Code: X2.25592195
2516 Thrasher J, Daniels K, Patel S, . Efficacy and safety of linagliptin in Black/African American patients with type 2 diabetes: a 6-month, randomized, double-blind, placebo-controlled study. Endocr Pract. 2014 May;20(5):412–20. doi: 10.4158/ep13365.or. PMID: 24326003. Exclusion Code: X2.24326003
2517 Threatt TB, Ward ED. Telehealth for diabetes self-management education and support in an underserved, free clinic population: A pilot study. J Am Pharm Assoc (2003). 2017 May – Jun;57(3):402–6. doi: 10.1016/j.japh.2017.01.019. PMID: 28285805. Exclusion Code: X2.28285805
2518 Tian F, Zheng Z, Zhang D, . Efficacy of liraglutide in treating type 2 diabetes mellitus complicated with non-alcoholic fatty liver disease. Biosci Rep. 2018 Dec 21;38(6)doi: 10.1042/bsr20181304. PMID: 30473540. Exclusion Code: X5.30473540
2519 Tian M, Liang Z, Liu R, . Effects of sitagliptin on circulating zinc-?2-glycoprotein levels in newly diagnosed type 2 diabetes patients: a randomized trial. European journal of endocrinology. 2016;174(2):147–55. doi: 10.1530/EJE-15-0637. PMID: CN-01169061. Exclusion Code: X6.26546612
2520 Tian M, Liang Z, Liu R, . Effects of sitagliptin on circulating zinc-alpha2-glycoprotein levels in newly diagnosed type 2 diabetes patients: a randomized trial. Eur J Endocrinol. 2016 Feb;174(2):147–55. doi: 10.1530/eje-15-0637. PMID: 26546612. Exclusion Code: X6.26546612
2521 Tieu J, Coat S, Hague W, . Oral anti-diabetic agents for women with established diabetes/impaired glucose tolerance or previous gestational diabetes planning pregnancy, or pregnant women with pre-existing diabetes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2522 Tieu J, McPhee AJ, Crowther CA, . Screening for gestational diabetes mellitus based on different risk profiles and settings for improving maternal and infant health. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2523 Tieu J, Middleton P, Crowther CA, . Preconception care for diabetic women for improving maternal and infant health. Cochrane Database Syst Rev. 2017 Aug 11;8:Cd007776. doi: 10.1002/14651858.CD007776.pub3. PMID: 28799164. Exclusion Code: X8.28799164
2524 Tieu J, Shepherd E, Middleton P, . Interconception care for women with a history of gestational diabetes for improving maternal and infant outcomes. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2525 Tieu J, Shepherd E, Middleton P, . Dietary advice interventions in pregnancy for preventing gestational diabetes mellitus. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2526 Tikkanen I, Narko K, Zeller C, . Empagliflozin reduces blood pressure in patients with type 2 diabetes and hypertension. Diabetes Care. 2015 Mar;38(3):420–8. doi: 10.2337/dc14-1096. PMID: 25271206. Exclusion Code: X6.25271206
2527 Timmers S, de Ligt M, Phielix E, . Resveratrol as add-on therapy in subjects with well-controlled type 2 diabetes: a randomized controlled trial. Diabetes Care. 2016 Dec;39(12):2211–7. doi: 10.2337/dc16-0499. PMID: 27852684. Exclusion Code: X2.27852684
2528 Tinahones FJ, Gallwitz B, Nordaby M, . Linagliptin as add-on to empagliflozin and metformin in patients with type 2 diabetes: Two 24-week randomized, double-blind, double-dummy, parallel-group trials. Diabetes Obes Metab. 2017 Feb;19(2):266–74. doi: 10.1111/dom.12814. PMID: 27762093. Exclusion Code: X2.27762093
2529 Tiryaki O, Usalan C, Sayiner ZA. Vitamin D receptor activation with calcitriol for reducing urinary angiotensinogen in patients with type 2 diabetic chronic kidney disease. Ren Fail. 2016;38(2):222–7. doi: 10.3109/0886022x.2015.1128250. PMID: 26707134. Exclusion Code: X2.26707134
2530 Tjokroprawiro A, Murtiwi S, Tjandrawinata RR. DLBS3233, a combined bioactive fraction of Cinnamomum burmanii and Lagerstroemia speciosa, in type-2 diabetes mellitus patients inadequately controlled by metformin and other oral antidiabetic agents. J Complement Integr Med. 2016 Dec 1;13(4):413–20. doi: 10.1515/jcim-2016-0031. PMID: 27451997. Exclusion Code: X4.27451997
2531 Toh S, Hampp C, Reichman ME, . Risk for hospitalized heart failure among new users of saxagliptin, sitagliptin, and other antihyperglycemic drugs: a retrospective cohort study. Ann Intern Med. 2016 Jun 7;164(11):705–14. doi: 10.7326/m15-2568. PMID: 27110660. Exclusion Code: X5.27110660
2532 Tolba M, Khashab K, Said A. The effect of dipeptidyl peptidase-4 inhibitors on cardiovascular disease risk in type 2 diabetes mellitus. International journal of pharmacy and pharmaceutical sciences. 2017;9(1):254–9. doi: 10.22159/ijpps.2017v9i1.15496. PMID: CN-01299088. Exclusion Code: X2.
2533 Tomiyama H, Miwa T, Kan K, . Impact of glycemic control with sitagliptin on the 2-year progression of arterial stiffness: a sub-analysis of the PROLOGUE study. Cardiovasc Diabetol. 2016 Nov 3;15(1):150. doi: 10.1186/s12933-016-0472-8. PMID: 27809848. Exclusion Code: X6.27809848
2534 Tong G, Hua X, Zhong Y, . Intensive insulin therapy increases sex hormone-binding globulin in newly diagnosed type 2 diabetic patients. Eur J Endocrinol. 2014 Feb;170(2):237–45. doi: 10.1530/eje-13-0557. PMID: 24194532. Exclusion Code: X6.24194532
2535 Tonneijck L, Smits MM, Muskiet MH, . Renal Effects of DPP-4 Inhibitor Sitagliptin or GLP-1 Receptor Agonist Liraglutide in Overweight Patients With Type 2 Diabetes: A 12-Week, Randomized, Double-Blind, Placebo-Controlled Trial. Diabetes Care. 2016 Nov;39(11):2042–50. doi: 10.2337/dc16-1371. PMID: 27585605. Exclusion Code: X2.27585605
2536 Tonneijck L, Smits MM, Muskiet MHA, . Acute renal effects of the GLP-1 receptor agonist exenatide in overweight type 2 diabetes patients: a randomised, double-blind, placebo-controlled trial. Diabetologia. 2016 Jul;59(7):1412–21. doi: 10.1007/s00125-016-3938-z. PMID: 27038451. Exclusion Code: X2.27038451
2537 Tonstad S, Malik N, Haddad E. A high-fibre bean-rich diet versus a low-carbohydrate diet for obesity. Journal of human nutrition and dietetics. 2014;27 Suppl 2:109–16. doi: 10.1111/jhn.12118. PMID: CN-01049171. Exclusion Code: X2.23627924
2538 Torenholt R, Schwennesen N, Willaing I. Lost in translation--the role of family in interventions among adults with diabetes: a systematic review. Diabet Med. 2014 Jan;31(1):15–23. doi: 10.1111/dme.12290. PMID: 23870045. Exclusion Code: X8.23870045
2539 Torres-Pena J, Garcia-Rios A, Delgado-Casado N, . Mediterranean diet improves endothelial function in patients with diabetes and prediabetes: a report from the CORDIOPREV study. Atherosclerosis. 2018;269:50–6. doi: 10.1016/j.atherosclerosis.2017.12.012. PMID: CN-01452710. Exclusion Code: X5.29274507
2540 Toulis KA, Hanif W, Saravanan P, . All-cause mortality in patients with diabetes under glucagon-like peptide-1 agonists: A population-based, open cohort study. Diabetes Metab. 2017 Jun;43(3):211–6. doi: 10.1016/j.diabet.2017.02.003. PMID: 28325589. Exclusion Code: X8.28325589
2541 Toulis KA, Jiang CQ, Hemming K, . Glycated Hemoglobin, Albuminuria and Surrogate Markers of Macrovascular Disease in Adults Without Diabetes: The Guangzhou Biobank Cohort Study, Cardiovascular Disease Subcohort. Can J Diabetes. 2018 Jun;42(3):245–50.e1. doi: 10.1016/j.jcjd.2017.06.001. PMID: 28689704. Exclusion Code: X5.28689704
2542 Tovote K, Fleer J, Snippe E, . Individual mindfulness-based cognitive therapy and cognitive behavior therapy for treating depressive symptoms in patients with diabetes: results of a randomized controlled trial. Diabetes care. 2014;37(9):2427–34. doi: 10.2337/dc13-2918. PMID: CN-01002152. Exclusion Code: X4.24898301
2543 Toyoda M, Yokoyama H, Abe K, . Predictors of response to liraglutide in Japanese type 2 diabetes. Diabetes Res Clin Pract. 2014 Dec;106(3):451–7. doi: 10.1016/j.diabres.2014.09.052. PMID: 25458335. Exclusion Code: X6.25458335
2544 Tran S, Retnakaran R, Zinman B, . Efficacy of glucagon-like peptide-1 receptor agonists compared to dipeptidyl peptidase-4 inhibitors for the management of type 2 diabetes: A meta-analysis of randomized clinical trials. Diabetes Obes Metab. 2018 Feb;20 Suppl 1:68–76. doi: 10.1111/dom.13137. PMID: 29364587. Exclusion Code: X8.29364587
2545 Trautmann ME, Van Gaal L, Han J, . Three-year efficacy and safety of exenatide once weekly: A pooled analysis of three trials. J Diabetes Complications. 2017 Sep;31(9):1415–22. doi: 10.1016/j.jdiacomp.2017.06.004. PMID: 28669463. Exclusion Code: X8.28669463
2546 Tremblay AJ, Lamarche B, Deacon CF, . Effects of sitagliptin therapy on markers of low-grade inflammation and cell adhesion molecules in patients with type 2 diabetes. Metabolism. 2014 Sep;63(9):1141–8. doi: 10.1016/j.metabol.2014.06.004. PMID: 25034387. Exclusion Code: X7.25034387
2547 Tremblay AJ, Lamarche B, Kelly I, . Effect of sitagliptin therapy on triglyceride-rich lipoprotein kinetics in patients with type 2 diabetes. Diabetes Obes Metab. 2014 Dec;16(12):1223–9. doi: 10.1111/dom.12359. PMID: 25059982. Exclusion Code: X6.25059982
2548 Trevisan DD, Sao-Joao TM, Cornelio ME, . A randomized controlled trial on the effect of behavioral strategies for adherence to oral antidiabetic drugs: study protocol. Contemp Nurse. 2017 Dec;53(6):658–68. doi: 10.1080/10376178.2017.1421862. PMID: 29281941. Exclusion Code: X6.29281941
2549 Trief PM, Fisher L, Sandberg J, . Health and psychosocial outcomes of a telephonic couples behavior change intervention in patients with poorly controlled type 2 diabetes: a randomized clinical trial. Diabetes Care. 2016 Dec;39(12):2165–73. doi: 10.2337/dc16-0035. PMID: 27456837. Exclusion Code: X2.27456837
2550 Triolo M, Annema W, de Boer JF, . Simvastatin and bezafibrate increase cholesterol efflux in men with type 2 diabetes. Eur J Clin Invest. 2014;44(3):240–8. doi: 10.1111/eci.12226. PMID: 24325778. Exclusion Code: X6.24325778
2551 Tripathy D, Clement SC, Schwenke DC, . Baseline adiponectin levels do not influence the response to pioglitazone in ACT NOW. Diabetes Care. 2014 Jun;37(6):1706–11. doi: 10.2337/dc13-1745. PMID: 24705615. Exclusion Code: X6.24705615
2552 Tripathy D, Cobb JE, Gall W, . A novel insulin resistance index to monitor changes in insulin sensitivity and glucose tolerance: the ACT NOW study. J Clin Endocrinol Metab. 2015 May;100(5):1855–62. doi: 10.1210/jc.2014-3824. PMID: 25603459. Exclusion Code: X4.25603459
2553 Tripolt NJ, Aberer F, Riedl R, . The effects of linagliptin on endothelial function and global arginine bioavailability ratio in coronary artery disease patients with early diabetes: study protocol for a randomized controlled trial. Trials. 2016 Oct 13;17(1):495. doi: 10.1186/s13063-016-1627-3. PMID: 27733180. Exclusion Code: X6.27733180
2554 Troughton J, Chatterjee S, Hill SE, . Development of a lifestyle intervention using the MRC framework for diabetes prevention in people with impaired glucose regulation. J Public Health (Oxf). 2016 Sep;38(3):493–501. doi: 10.1093/pubmed/fdv110. PMID: 26311822. Exclusion Code: X6.26311822
2555 True MW, Strickland LE, Lewi JE, . Impact of a Diabetes Risk Score on Lifestyle Education and Patient Adherence (IDEA) in Prediabetes: a multisite randomized controlled trial. Mil Med. 2015 Oct;180(10):1091–7. doi: 10.7205/milmed-d-14-00656. PMID: 26444473. Exclusion Code: X5.26444473
2556 Tschope D, Bramlage P, Schneider S, . Incidence, characteristics and impact of hypoglycaemia in patients receiving intensified treatment for inadequately controlled type 2 diabetes mellitus. Diab Vasc Dis Res. 2016 Jan;13(1):2–12. doi: 10.1177/1479164115610470. PMID: 26567123. Exclusion Code: X2.26567123
2557 Tseng CH. Prolonged use of human insulin increases breast cancer risk in Taiwanese women with type 2 diabetes. BMC Cancer. 2015 Nov 4;15:846. doi: 10.1186/s12885-015-1876-7. PMID: 26537234. Exclusion Code: X2.26537234
2558 Tseng CH. Sitagliptin increases acute pancreatitis risk within 2 years of its initiation: a retrospective cohort analysis of the National Health Insurance database in Taiwan. Ann Med. 2015;47(7):561–9. doi: 10.3109/07853890.2015.1091944. PMID: 26426676. Exclusion Code: X2.26426676
2559 Tseng CH. Metformin use and cervical cancer risk in female patients with type 2 diabetes. Oncotarget. 2016 Sep 13;7(37):59548–55. doi: 10.18632/oncotarget.10934. PMID: 27486978. Exclusion Code: X5.27486978
2560 Tseng CH. Sitagliptin and heart failure hospitalization in patients with type 2 diabetes. Oncotarget. 2016 Sep 20;7(38):62687–96. doi: 10.18632/oncotarget.10507. PMID: 27409676. Exclusion Code: X2.27409676
2561 Tseng CH. Metformin may reduce oral cancer risk in patients with type 2 diabetes. Oncotarget. 2016 Jan 12;7(2):2000–8. doi: 10.18632/oncotarget.6626. PMID: 26683519. Exclusion Code: X2.26683519
2562 Tseng CH. Sitagliptin and pancreatic cancer risk in patients with type 2 diabetes. Eur J Clin Invest. 2016 Jan;46(1):70–9. doi: 10.1111/eci.12570. PMID: 26584246. Exclusion Code: X8.26584246
2563 Tseng CH. Metformin is associated with a lower risk of colorectal cancer in Taiwanese patients with type 2 diabetes: A retrospective cohort analysis. Diabetes Metab. 2017 Oct;43(5):438–45. doi: 10.1016/j.diabet.2017.03.004. PMID: 28438547. Exclusion Code: X8.28438547
2564 Tseng CH. Sitagliptin may reduce breast cancer risk in women with type 2 diabetes. Clin Breast Cancer. 2017 Jun;17(3):211–8. doi: 10.1016/j.clbc.2016.11.002. PMID: 27986440. Exclusion Code: X2.27986440
2565 Tseng CH. Rosiglitazone reduces breast cancer risk in Taiwanese female patients with type 2 diabetes mellitus. Oncotarget. 2017 Jan 10;8(2):3042–8. doi: 10.18632/oncotarget.13824. PMID: 27936468. Exclusion Code: X2.27936468
2566 Tseng CH. Sitagliptin may reduce prostate cancer risk in male patients with type 2 diabetes. Oncotarget. 2017 Mar 21;8(12):19057–64. doi: 10.18632/oncotarget.12137. PMID: 27661113. Exclusion Code: X2.27661113
2567 Tseng CM, Liao WC, Chang CY, . Incretin-based pharmacotherapy and risk of adverse pancreatic events in the ethnic Chinese with diabetes mellitus: A population-based study in Taiwan. Pancreatology. 2017 Jan – Feb;17(1):76–82. doi: 10.1016/j.pan.2016.10.003. PMID: 27743712. Exclusion Code: X8.27743712
2568 Tsikas D, Pham VV, Suchy MT, . No effects of atorvastatin (10 mg/d or 80 mg/d) on nitric oxide, prostacyclin, thromboxane and oxidative stress in type 2 diabetes mellitus patients of the DALI study. Pharmacol Res. 2015 Apr;94:1–8. doi: 10.1016/j.phrs.2015.01.004. PMID: 25662039. Exclusion Code: X6.25662039
2569 Tsilidis KK, Capothanassi D, Allen NE, . Metformin does not affect cancer risk: a cohort study in the U.K. Clinical Practice Research Datalink analyzed like an intention-to-treat trial. Diabetes Care. 2014 Sep;37(9):2522–32. doi: 10.2337/dc14-0584. PMID: 24898303. Exclusion Code: X5.24898303
2570 Tsujimoto T, Kajio H. Benefits of Intensive Blood Pressure Treatment in Patients With Type 2 Diabetes Mellitus Receiving Standard but Not Intensive Glycemic Control. Hypertension. 2018 Aug;72(2):323–30. doi: 10.1161/hypertensionaha.118.11408. PMID: 29967045. Exclusion Code: X2.29967045
2571 Tsujimoto T, Sugiyama T, Kajio H. Effects of beta-blockers on all-cause mortality in patients with type 2 diabetes and coronary heart disease. Diabetes Obes Metab. 2017 Jun;19(6):800–8. doi: 10.1111/dom.12878. PMID: 28094466. Exclusion Code: X2.28094466
2572 Tsujimoto T, Sugiyama T, Noda M, . Intensive glycemic therapy in patients with type 2 diabetes on beta-blockers. Diabetes Care. 2016 Oct;39(10):1818–26. doi: 10.2337/dc16-0721. PMID: 27460066. Exclusion Code: X2.27460066
2573 Tsunoda F, Asztalos IB, Horvath KV, . Fenofibrate, HDL, and cardiovascular disease in Type-2 diabetes: The DAIS trial. Atherosclerosis. 2016 Apr;247:35–9. doi: 10.1016/j.atherosclerosis.2016.01.028. PMID: 26854974. Exclusion Code: X6.26854974
2574 Tsurutani Y, Omura M, Matsuzawa Y, . Efficacy and safety of the dipeptidyl peptidase-4 inhibitor sitagliptin on atherosclerosis, beta-cell function, and glycemic control in japanese patients with type 2 diabetes mellitus who are treatment naive or poorly responsive to antidiabetes agents: a multicenter, prospective observational, uncontrolled study. Current therapeutic research - clinical and experimental. 2017;(no pagination)doi: 10.1016/j.curtheres.2016.12.002. PMID: CN-01373883. Exclusion Code: X5.
2575 Tuccori M, Filion KB, Yin H, . Pioglitazone use and risk of bladder cancer: population based cohort study. Bmj. 2016 Mar 30;352:i1541. doi: 10.1136/bmj.i1541. PMID: 27029385. Exclusion Code: X5.27029385
2576 Tuccori M, Wu JW, Yin H, . The use of glyburide compared with other sulfonylureas and the risk of cancer in patients with type 2 diabetes. Diabetes Care. 2015 Nov;38(11):2083–9. doi: 10.2337/dc15-1358. PMID: 26341130. Exclusion Code: X5.26341130
2577 Tucker CM, Lopez MT, Campbell K, . The effects of a culturally sensitive, empowerment-focused, community-based health promotion program on health outcomes of adults with type 2 diabetes. J Health Care Poor Underserved. 2014 Feb;25(1):292–307. doi: 10.1353/hpu.2014.0044. PMID: 24509027. Exclusion Code: X6.24509027
2578 Turnbull F, Neal B, Algert C, . Effects of different blood pressure-lowering regimens on major cardiovascular events in individuals with and without diabetes mellitus: results of prospectively designed overviews of randomized trials. Arch Intern Med. 2005 Jun 27;165(12):1410–9. doi: 10.1001/archinte.165.12.1410. PMID: 15983291. Exclusion Code: X8.15983291
2579 Tzanetakos C, Bargiota A, Kourlaba G, . Cost effectiveness of exenatide once weekly versus insulin glargine and liraglutide for the treatment of type 2 diabetes mellitus in greece. Clin Drug Investig. 2018 Jan;38(1):67–77. doi: 10.1007/s40261-017-0586-0. PMID: 29080210. Exclusion Code: X8.29080210
2580 Udell JA, Bhatt DL, Braunwald E, . Saxagliptin and cardiovascular outcomes in patients with type 2 diabetes and moderate or severe renal impairment: observations from the SAVOR-TIMI 53 Trial. Diabetes Care. 2015 Apr;38(4):696–705. doi: 10.2337/dc14-1850. PMID: 25552421. Exclusion Code: X2.25552421
2581 Ueda S, Morimoto T, Ando S, . A randomised controlled trial for the evaluation of risk for type 2 diabetes in hypertensive patients receiving thiazide diuretics: Diuretics In the Management of Essential hypertension (DIME) study. BMJ Open. 2014 Jul 16;4(7):e004576. doi: 10.1136/bmjopen-2013-004576. PMID: 25031188. Exclusion Code: X2.25031188
2582 Umayahara R, Yonemoto T, Kyou C, . Low-dose glimepiride with sitagliptin improves glycemic control without dose-dependency in patients with type 2 diabetes inadequately controlled on high-dose glimepiride. Endocr J. 2014;61(12):1163–70. doi: 10.1507/endocrj.EJ14-0233. PMID: 25168659. Exclusion Code: X2.25168659
2583 Umezawa S, Kubota A, Maeda H, . Two-year assessment of the efficacy and safety of sitagliptin in elderly patients with type 2 diabetes: Post hoc analysis of the ASSET-K study. BMC Endocr Disord. 2015 Jul 3;15:34. doi: 10.1186/s12902-015-0033-2. PMID: 26137940. Exclusion Code: X2.26137940
2584 Umpierrez G, Atkin S, Bain S, . Efficacy and safety of liraglutide versus placebo in subjects with type 2 diabetes and moderate renal impairment (LIRA-RENAL): a randomised trial. Diabetologia. 2014;57(1 suppl. 1):S84. doi: 10.1007/s00125-014-3355-0. PMID: CN-01059210. Exclusion Code: X2.
2585 Umpierrez G, Cardona S, Chachkhiani D, . A randomized controlled study comparing a DPP4 inhibitor (linagliptin) and basal insulin (glargine) in patients with type 2 diabetes in long-term care and skilled nursing facilities: linagliptin-LTC Trial. J Am Med Dir Assoc. 2017;(no pagination)doi: 10.1016/j.jamda.2017.11.002. PMID: CN-01440929. Exclusion Code: X2.
2586 Unick JL, Gaussoin SA, Hill JO, . Four-year physical activity levels among intervention participants with type 2 diabetes. Med Sci Sports Exerc. 2016 Dec;48(12):2437–45. doi: 10.1249/mss.0000000000001054. PMID: 27471785. Exclusion Code: X2.27471785
2587 Unick JL, Hogan PE, Neiberg RH, . Evaluation of early weight loss thresholds for identifying nonresponders to an intensive lifestyle intervention. Obesity (Silver Spring). 2014 Jul;22(7):1608–16. doi: 10.1002/oby.20777. PMID: 24771618. Exclusion Code: X5.24771618
2588 Unick JL, Neiberg RH, Hogan PE, . Weight change in the first 2 months of a lifestyle intervention predicts weight changes 8 years later. Obesity (Silver Spring). 2015 Jul;23(7):1353–6. doi: 10.1002/oby.21112. PMID: 26110890. Exclusion Code: X6.26110890
2589 Ur RS, Karimi H, Gillani S, . Effects of supervised structured aerobic exercise training programme on level of exertion, dyspnoea, VO_2_ max and body mass index in patients with type 2 diabetes mellitus. Journal of the pakistan medical association. 2017;67(11):1670–3. PMID: CN-01421856. Exclusion Code: X2.29171557
2590 Urpilainen E, Marttila M, Hautakoski A, . The role of metformin and statins in the incidence of epithelial ovarian cancer in type 2 diabetes: a cohort and nested case-control study. BJOG. 2018 Jul;125(8):1001–8. doi: 10.1111/1471-0528.15151. PMID: 29412502. Exclusion Code: X2.29412502
2591 Usui R, Yabe D, Kuwata H, . Retrospective analysis of safety and efficacy of liraglutide monotherapy and sulfonylurea-combination therapy in Japanese type 2 diabetes: Association of remaining beta-cell function and achievement of HbA1c target one year after initiation. J Diabetes Complications. 2015 Nov–Dec;29(8):1203–10. doi: 10.1016/j.jdiacomp.2015.07.020. PMID: 26279320. Exclusion Code: X2.26279320
2592 Utami DB, Findyartini A. Plant-based Diet for HbA1c Reduction in Type 2 Diabetes Mellitus: an Evidence-based Case Report. Acta Med Indones. 2018 Jul;50(3):260–7. PMID: 30333278. Exclusion Code: X8.30333278
2593 Uthman OA, Hartley L, Rees K, . Multiple risk factor interventions for primary prevention of cardiovascular disease in low- and middle-income countries. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
2594 Uusitupa M, Aro A, Kauppinen A, . Decreased occurrence of early diabetic retinopathy in lifestyle intervention group of the Finnish Diabetes Prevention Study. Diabetologia. 2018;61:S482-. doi: 10.1007/s00125-018-4693-0. PMID: CN-01647157. Exclusion Code: X10.
2595 Vaduganathan M, White W, Charytan D, . Renal outcomes associated with alogliptin vs. Placebo in patients with type 2 diabetes mellitus and recent acute coronary syndrome: results from the EXAMINE Trial. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A316. doi: 10.2337/db16-861-1374. PMID: CN-01449934. Exclusion Code: X2.
2596 Valencia WM, Botros D, Vera-Nunez M, . Diabetes Treatment in the Elderly: Incorporating Geriatrics, Technology, and Functional Medicine. Curr Diab Rep. 2018 Sep 5;18(10):95. doi: 10.1007/s11892-018-1052-y. PMID: 30187176. Exclusion Code: X8.30187176
2597 Valent F. Diabetes mellitus and cancer of the digestive organs: An Italian population-based cohort study. J Diabetes Complications. 2015 Nov–Dec;29(8):1056–61. doi: 10.1016/j.jdiacomp.2015.07.017. PMID: 26275864. Exclusion Code: X5.26275864
2598 van Bloemendaal L, RG IJ, Ten Kulve JS, . GLP-1 receptor activation modulates appetite- and reward-related brain areas in humans. Diabetes. 2014 Dec;63(12):4186–96. doi: 10.2337/db14-0849. PMID: 25071023. Exclusion Code: X5.25071023
2599 van Dalem J, Brouwers MC, Stehouwer CD, . Risk of hypoglycaemia in users of sulphonylureas compared with metformin in relation to renal function and sulphonylurea metabolite group: population based cohort study. Bmj. 2016 Jul 13;354:i3625. doi: 10.1136/bmj.i3625. PMID: 27413017. Exclusion Code: X5.27413017
2600 van de Weijer T, Phielix E, Bilet L, . Evidence for a direct effect of the NAD+ precursor acipimox on muscle mitochondrial function in humans. Diabetes. 2015 Apr;64(4):1193–201. doi: 10.2337/db14-0667. PMID: 25352640. Exclusion Code: X6.25352640
2601 van der Heijden AA, Rauh SP, Dekker JM, . The Hoorn Diabetes Care System (DCS) cohort. A prospective cohort of persons with type 2 diabetes treated in primary care in the Netherlands. BMJ Open. 2017 Jun 6;7(5):e015599. doi: 10.1136/bmjopen-2016-015599. PMID: 28588112. Exclusion Code: X6.28588112
2602 van der Leeuw J, Visseren FL, Woodward M, . Estimation of individual beneficial and adverse effects of intensive glucose control for patients with type 2 diabetes. Diabetologia. 2016 Dec;59(12):2603–12. doi: 10.1007/s00125-016-4082-5. PMID: 27586250. Exclusion Code: X2.27586250
2603 van der Leeuw J, Visseren FL, Woodward M, . Predicting the effects of blood pressure-lowering treatment on major cardiovascular events for individual patients with type 2 diabetes mellitus: results from Action in Diabetes and Vascular Disease: Preterax and Diamicron MR Controlled Evaluation. Hypertension. 2015 Jan;65(1):115–21. doi: 10.1161/hypertensionaha.114.04421. PMID: 25312436. Exclusion Code: X2.25312436
2604 van der Weegen S, Verwey R, Spreeuwenberg M, . It’s LiFe! Mobile and web-based monitoring and feedback tool embedded in primary care increases physical activity: a cluster randomized controlled trial. J Med Internet Res. 2015 Jul 24;17(7):e184. doi: 10.2196/jmir.4579. PMID: 26209025. Exclusion Code: X2.26209025
2605 Van dLFA, Lucassen PL, Akkermans RP, . Alpha-glucosidase inhibitors for people with impaired glucose tolerance or impaired fasting blood glucose. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2006. Exclusion Code: X8.
2606 van Dongen EJ, Duijzer G, Jansen SC, . Process evaluation of a randomised controlled trial of a diabetes prevention intervention in Dutch primary health care: the SLIMMER study. Public Health Nutr. 2016 Nov;19(16):3027–38. doi: 10.1017/s1368980016001282. PMID: 27256153. Exclusion Code: X6.27256153
2607 van Genugten RE, van Raalte DH, Muskiet MH, . Does dipeptidyl peptidase-4 inhibition prevent the diabetogenic effects of glucocorticoids in men with the metabolic syndrome? A randomized controlled trial. Eur J Endocrinol. 2014 Mar;170(3):429–39. doi: 10.1530/eje-13-0610. PMID: 24297090. Exclusion Code: X2.24297090
2608 van Puffelen AL, Heijmans MJ, Rijken M, . Illness perceptions and self-care behaviours in the first years of living with type 2 diabetes; does the presence of complications matter? Psychol Health. 2015;30(11):1274–87. doi: 10.1080/08870446.2015.1045511. PMID: 25925788. Exclusion Code: X8.25925788
2609 Van Raalte DH, van Genugten RE, Eliasson B, . The effect of alogliptin and pioglitazone combination therapy on various aspects of beta-cell function in patients with recent-onset type 2 diabetes. Eur J Endocrinol. 2014 Apr;170(4):565–74. doi: 10.1530/eje-13-0639. PMID: 24421302. Exclusion Code: X5.24421302
2610 van Steen SC, Woodward M, Chalmers J, . Haemoglobin glycation index and risk for diabetes-related complications in the Action in Diabetes and Vascular Disease: Preterax and Diamicron Modified Release Controlled Evaluation (ADVANCE) trial. Diabetologia. 2018 Apr;61(4):780–9. doi: 10.1007/s00125-017-4539-1. PMID: 29308539. Exclusion Code: X2.29308539
2611 van Vugt M, de Wit M, Bader S, . Does low well-being modify the effects of PRISMA (Dutch DESMOND), a structured self-management-education program for people with type 2 diabetes? Prim Care Diabetes. 2016 Apr;10(2):103–10. doi: 10.1016/j.pcd.2015.06.008. PMID: 26186886. Exclusion Code: X4.26186886
2612 van ZEJ, Fedorowicz Z, Carter B, . Interventions for hirsutism (excluding laser and photoepilation therapy alone). Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
2613 Vancampfort D, Mitchell AJ, De Hert M, . Type 2 diabetes in patients with major depressive disorder: a meta-analysis of prevalence estimates and predictors. Depress Anxiety. 2015 Oct;32(10):763–73. doi: 10.1002/da.22387. PMID: 26114259. Exclusion Code: X8.26114259
2614 Vanderwood K, Kramer M, Arena V, . Does waiting matter? The effects of weight change during intervention delay on participants’ success in a community diabetes prevention effort. Diabetes. 2014;63:A179. doi: 10.2337/db14-665-832. PMID: CN-01065577. Exclusion Code: X5.
2615 Vanroy J, Seghers J, Bogaerts A, . Short- and long-term effects of a need-supportive physical activity intervention among patients with type 2 diabetes mellitus: A randomized controlled pilot trial. PLoS One. 2017;12(4):e0174805. doi: 10.1371/journal.pone.0174805. PMID: 28384237. Exclusion Code: X6.28384237
2616 Vardarli I, Arndt E, Deacon CF, . Effects of sitagliptin and metformin treatment on incretin hormone and insulin secretory responses to oral and “isoglycemic" intravenous glucose. Diabetes. 2014 Feb;63(2):663–74. doi: 10.2337/db13-0805. PMID: 24186866. Exclusion Code: X2.24186866
2617 Varney JE, Weiland TJ, Inder WJ, . Effect of hospital-based telephone coaching on glycaemic control and adherence to management guidelines in type 2 diabetes, a randomised controlled trial. Intern Med J. 2014 Sep;44(9):890–7. doi: 10.1111/imj.12515. PMID: 24963611. Exclusion Code: X2.24963611
2618 Varvaki Rados D, Catani Pinto L, Reck Remonti L, . The association between sulfonylurea use and all-cause and cardiovascular mortality: a meta-analysis with trial sequential analysis of randomized clinical trials. PLoS Med. 2016 Apr;13(4):e1001992. doi: 10.1371/journal.pmed.1001992. PMID: 27071029. Exclusion Code: X8.27071029
2619 Vaughan EM, Johnston CA, Cardenas VJ, . Integrating CHWs as Part of the Team Leading Diabetes Group Visits: a Randomized Controlled Feasibility Study. Diabetes educator. 2017;43(6):589–99. doi: 10.1177/0145721717737742. PMID: CN-01615246. Exclusion Code: X4.
2620 Vazquez LA, Tofe Povedano S, Tinahones FJ, . Daily self-monitored glucose profiles in patients with type 2 diabetes mellitus (T2DM) treated with once-weekly dulaglutide vs once-daily insulin glargine in award-2 and-4. Revista portuguesa de endocrinologia, diabetes e metabolismo. 2016;11(1):104-. PMID: CN-01784523. Exclusion Code: X5.
2621 Vedanthan R, Kamano JH, Lee H, . Bridging income generation with group integrated care for cardiovascular risk reduction: rationale and design of the BIGPIC Study. Am Heart J. 2017 Jun;188:175–85. doi: 10.1016/j.ahj.2017.03.012. PMID: 28577673. Exclusion Code: X6.28577673
2622 Veelken R, Delles C, Hilgers KF, . Outcome survey in unselected hypertensive patients with type 2 diabetes mellitus: effects of ACE inhibition. Am J Hypertens. 2001;14(7 I):672–8. doi: 10.1016/S0895-7061(01)01300-0. PMID: CN-01726978. Exclusion Code: X5.11465652
2623 Velázquez-López L, Muñoz-Torres AV, Medina-Bravo P, . Multimedia education program and nutrition therapy improves HbA1c, weight, and lipid profile of patients with type 2 diabetes: a randomized clinical trial. Endocrine. 2017;58(2):236–45. doi: 10.1007/s12020-017-1416-0. PMID: CN-01615423. Exclusion Code: X2.28921414
2624 Velez-Garza J, Giuseppe D, Alonzo R, . Pioglitazone does not modulate plasma sclerostin levels in subjects with impaired glucose tolerance (IGT): results from the act now study. Diabetes. Conference: 76th scientific sessions of the american diabetes association, ADA 2016. United states. 2016;65(Supplement 1):A291–a2. doi: 10.2337/db16-861-1374. PMID: CN-01449897. Exclusion Code: X6.
2625 Vellanki P, Smiley DD, Stefanovski D, . Randomized controlled study of metformin and sitagliptin on long-term normoglycemia remission in African American patients with hyperglycemic crises. Diabetes Care. 2016 Nov;39(11):1948–55. doi: 10.2337/dc16-0406. PMID: 27573938. Exclusion Code: X6.27573938
2626 Vellanki P, Stefanovski D, Narwani V, . Carbohydrate tolerance at near-normoglycaemia remission in obese African American patients with hyperglycaemic crises. Diabetologia. 2018;61:S340-. doi: 10.1007/s00125-018-4693-0. PMID: CN-01647039. Exclusion Code: X2.
2627 Vercruysse F, Davies M, Merton K, . Achievement of glycaemic goals without hypoglycaemia with canagliflozin versus glimepiride in patients with type 2 diabetes. Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S339–s40. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212851. Exclusion Code: X5.
2628 Verges B, Patois-Verges B, Iliou MC, . Influence of glycemic control on gain in VO2 peak, in patients with type 2 diabetes enrolled in cardiac rehabilitation after an acute coronary syndrome. The prospective DARE study. BMC Cardiovasc Disord. 2015 Jul 8;15:64. doi: 10.1186/s12872-015-0055-8. PMID: 26152221. Exclusion Code: X2.26152221
2629 Verma S, Poulter NR, Bhatt DL, . Effects of liraglutide on cardiovascular outcomes in patients with type 2 diabetes mellitus with or without history of myocardial infarction or stroke: post hoc analysis from the leader trial. Circulation. 2018;138(25):2884–94. doi: 10.1161/CIRCULATIONAHA.118.034516. PMID: CN-01936115. Exclusion Code: X2.30566004
2630 Verwey R, van der Weegen S, Spreeuwenberg M, . A monitoring and feedback tool embedded in a counselling protocol to increase physical activity of patients with COPD or type 2 diabetes in primary care: study protocol of a three-arm cluster randomised controlled trial. BMC Fam Pract. 2014 May 12;15:93. doi: 10.1186/1471-2296-15-93. PMID: 24885096. Exclusion Code: X6.24885096
2631 Verwey R, van der Weegen S, Spreeuwenberg M, . Process evaluation of physical activity counselling with and without the use of mobile technology: A mixed methods study. Int J Nurs Stud. 2016 Jan;53:3–16. doi: 10.1016/j.ijnurstu.2015.10.008. PMID: 26518108. Exclusion Code: X5.26518108
2632 Vetter ML, Johnsson K, Hardy E, . Pancreatitis Incidence in the Exenatide BID, Exenatide QW, and Exenatide QW Suspension Development Programs: pooled Analysis of 35 Clinical Trials. Diabetes therapy. 2019;10(4):1249–70. doi: 10.1007/s13300-019-0627-1. PMID: CN-01955927. Exclusion Code: X8.31077072
2633 Vettor R, Roux C, Astrup A, . Reduction in the risk of developing type 2 diabetes with liraglutide 3.0 mg in people with prediabetes from the SCALE Obesity and Prediabetes randomized, double-blind, placebo-controlled trial. Italian journal of medicine. Conference: 21st congresso nazionale della societa scientifica FADOI. Italy. 2016;10:121. PMID: CN-01360600. Exclusion Code: X10.
2634 Vicentini M, Ballotari P, Giorgi Rossi P, . Effect of different glucose-lowering therapies on cancer incidence in type 2 diabetes: An observational population-based study. Diabetes Res Clin Pract. 2018 Sep;143:398–408. doi: 10.1016/j.diabres.2018.04.036. PMID: 29807100. Exclusion Code: X2.29807100
2635 Villar MM, Martinez-Abundis E, Preciado-Marquez RO, . Effect of diacerein as an add-on to metformin in patients with type 2 diabetes mellitus and inadequate glycemic control. Arch Endocrinol Metab. 2017 Mar–Apr;61(2):188–92. doi: 10.1590/2359-3997000000242. PMID: 28225996. Exclusion Code: X2.28225996
2636 Villegas-Rivera G, Roman-Pintos LM, Cardona-Munoz EG, . Effects of ezetimibe/simvastatin and rosuvastatin on oxidative stress in diabetic neuropathy: a randomized, double-blind, placebo-controlled clinical trial. Oxid Med Cell Longev. 2015;2015:756294. doi: 10.1155/2015/756294. PMID: 26290682. Exclusion Code: X2.26290682
2637 Vilsboll T, Bain SC, Leiter LA, . Semaglutide, reduction in glycated haemoglobin and the risk of diabetic retinopathy. Diabetes Obes Metab. 2018 Apr;20(4):889–97. doi: 10.1111/dom.13172. PMID: 29178519. Exclusion Code: X2.29178519
2638 Vilsboll T, Vora J, Jarlov H, . Type 2 diabetes patients reach target glycemic control faster using IDegLira than either insulin degludec or liraglutide given alone. Clin Drug Investig. 2016;36(4):293–303. doi: 10.1007/s40261-016-0376-0. PMID: CN-01140911. Exclusion Code: X5.
2639 Vincent D, McEwen MM, Hepworth JT, . The effects of a community-based, culturally tailored diabetes prevention intervention for high-risk adults of Mexican descent. Diabetes Educ. 2014 Mar–Apr;40(2):202–13. doi: 10.1177/0145721714521020. PMID: 24510942. Exclusion Code: X2.24510942
2640 Vinceti M, Dennert G, Crespi CM, . Selenium for preventing cancer. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
2641 Vinceti M, Filippini T, Del Giovane C, . Selenium for preventing cancer. Cochrane Database of Systematic Reviews. 2018(1)doi: 10.1002/14651858.CD005195.pub4. PMID: CD005195. Exclusion Code: X8.
2642 Vinetti G, Mozzini C, Desenzani P, . Supervised exercise training reduces oxidative stress and cardiometabolic risk in adults with type 2 diabetes: a randomized controlled trial. Sci Rep. 2015;5:9238. doi: 10.1038/srep09238. PMID: CN-01110121. Exclusion Code: X4.25783765
2643 Vinik A, Rosenstock J, Sharma U, . Efficacy and safety of mirogabalin (DS-5565) for the treatment of diabetic peripheral neuropathic pain: a randomized, double-blind, placebo- and active comparator-controlled, adaptive proof-of-concept phase 2 study. Diabetes Care. 2014 Dec;37(12):3253–61. doi: 10.2337/dc14-1044. PMID: 25231896. Exclusion Code: X4.25231896
2644 Violi F, Targher G, Vestri A, . Effect of aspirin on renal disease progression in patients with type 2 diabetes: a multicenter, double-blind, placebo-controlled, randomized trial. The renaL disEase progression by aspirin in diabetic pAtients (LEDA) trial. Rationale and study design. Am Heart J. 2017;189:120–7. doi: 10.1016/j.ahj.2017.04.005. PMID: CN-01374294. Exclusion Code: X6.28625368
2645 Visek J, Lacigova S, Cechurova D, . Comparison of a low-glycemic index vs standard diabetic diet. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. 2014;158(1):112–6. doi: 10.5507/bp.2012.103. PMID: CN-01124407. Exclusion Code: X2.23235718
2646 Viskochil R, Malin SK, Blankenship JM, . Exercise training and metformin, but not exercise training alone, decreases insulin production and increases insulin clearance in adults with prediabetes. J Appl Physiol (1985). 2017 Jul 1;123(1):243–8. doi: 10.1152/japplphysiol.00790.2016. PMID: 28473613. Exclusion Code: X6.28473613
2647 Vissers PA, Cardwell CR, van de Poll-Franse LV, . The association between glucose-lowering drug use and mortality among breast cancer patients with type 2 diabetes. Breast Cancer Res Treat. 2015 Apr;150(2):427–37. doi: 10.1007/s10549-015-3331-5. PMID: 25762476. Exclusion Code: X2.25762476
2648 Vita P, Cardona-Morrell M, Bauman A, . Type 2 diabetes prevention in the community: 12-Month outcomes from the Sydney Diabetes Prevention Program. Diabetes Res Clin Pract. 2016 Feb;112:13–9. doi: 10.1016/j.diabres.2015.11.010. PMID: 26724186. Exclusion Code: X2.26724186
2649 Vitale M, Masulli M, Calabrese I, . Impact of a Mediterranean Dietary Pattern and Its Components on Cardiovascular Risk Factors, Glucose Control, and Body Weight in People with Type 2 Diabetes: A Real-Life Study. Nutrients. 2018 Aug 10;10(8)doi: 10.3390/nu10081067. PMID: 30103444. Exclusion Code: X8.30103444
2650 Vitale M, Masulli M, Rivellese A, . Influence of dietary fat and carbohydrates proportions on plasma lipids, glucose control and low-grade inflammation in patients with type 2 diabetes-The TOSCA.IT Study. Eur J Nutr. 2016;55(4):1645–51. doi: 10.1007/s00394-015-0983-1. PMID: CN-01167452. Exclusion Code: X2.26303195
2651 Vitolins MZ, Isom SP, Blackwell CS, . The healthy living partnerships to prevent diabetes and the diabetes prevention program: a comparison of year 1 and 2 intervention results. Transl Behav Med. 2017 Jun;7(2):371–8. doi: 10.1007/s13142-016-0447-z. PMID: 27796775. Exclusion Code: X8.27796775
2652 Vlaar EMA, Nierkens V, Nicolaou M, . Effectiveness of a targeted lifestyle intervention in primary care on diet and physical activity among South Asians at risk for diabetes: 2-year results of a randomised controlled trial in the Netherlands. BMJ Open. 2017 Jul 2;7(6):e012221. doi: 10.1136/bmjopen-2016-012221. PMID: 28674122. Exclusion Code: X6.28674122
2653 Voils CI, Coffman CJ, Grubber JM, . Does type 2 diabetes genetic testing and counseling reduce modifiable risk factors? A randomized controlled trial of veterans. J Gen Intern Med. 2015 Nov;30(11):1591–8. doi: 10.1007/s11606-015-3315-5. PMID: 25876740. Exclusion Code: X3.25876740
2654 von Eyben FE. Quality improvement of metabolic control for patients with type 2 diabetes treated at a general hospital: a quantitative open cohort study. J Eval Clin Pract. 2014 Aug;20(4):429–35. doi: 10.1111/jep.12168. PMID: 24828614. Exclusion Code: X5.24828614
2655 von Philipsborn P, Stratil JM, Burns J, . Environmental interventions to reduce the consumption of sugar-sweetened beverages and their effects on health. Cochrane Database of Systematic Reviews. 2019(6)doi: 10.1002/14651858.CD012292.pub2. PMID: CD012292. Exclusion Code: X8.
2656 von PP, Stratil JM, Burns J, . Environmental interventions to reduce the consumption of sugar-sweetened beverages and their effects on health. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
2657 von Scholten BJ, Davies MJ, Persson F, . Effect of weight reductions on estimated kidney function: Post-hoc analysis of two randomized trials. J Diabetes Complications. 2017 Jul;31(7):1164–8. doi: 10.1016/j.jdiacomp.2017.04.003. PMID: 28462892. Exclusion Code: X8.28462892
2658 von Scholten BJ, Hansen TW, Goetze JP, . Glucagon-like peptide 1 receptor agonist (GLP-1 RA): long-term effect on kidney function in patients with type 2 diabetes. J Diabetes Complications. 2015 Jul;29(5):670–4. doi: 10.1016/j.jdiacomp.2015.04.004. PMID: 25935863. Exclusion Code: X2.25935863
2659 von Scholten BJ, Persson F, Rosenlund S, . Effects of liraglutide on cardiovascular risk biomarkers in patients with type 2 diabetes and albuminuria: A sub-analysis of a randomized, placebo-controlled, double-blind, crossover trial. Diabetes Obes Metab. 2017 Jun;19(6):901–5. doi: 10.1111/dom.12884. PMID: 28105731. Exclusion Code: X2.28105731
2660 von Scholten BJ, Persson F, Rosenlund S, . The effect of liraglutide on renal function: A randomized clinical trial. Diabetes Obes Metab. 2017 Feb;19(2):239–47. doi: 10.1111/dom.12808. PMID: 27753201. Exclusion Code: X2.27753201
2661 Vorderstrasse AA, Melkus GD, Pan W, . Diabetes learning in virtual environments: testing the efficacy of self-management training and support in virtual environments (randomized controlled trial protocol). Nurs Res. 2015 Nov–Dec;64(6):485–93. doi: 10.1097/nnr.0000000000000128. PMID: 26505161. Exclusion Code: X6.26505161
2662 Vuorio A, Kuoppala J, Kovanen PT, . Statins for children with familial hypercholesterolemia. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2017. Exclusion Code: X8.
2663 Wagner J, Armeli S, Tennen H, . Effects of stress management and relaxation training on the relationship between diabetes symptoms and affect among Latinos. Psychol Health. 2018;33(9):1172–90. doi: 10.1080/08870446.2018.1478975. PMID: CN-01666439. Exclusion Code: X4.29857776
2664 Waidyatilaka I, Lanerolle P, Wickramasinghe R, . Effectiveness of a culturally appropriate lifestyle modification programme in improving body composition in Urban Sri Lankan women with prediabetes. Annals of nutrition and metabolism. Conference: 21st international congress of nutrition, ICN 2017. Argentina. 2017;71(Supplement 2):763–4. doi: 10.1159/000480486. PMID: CN-01429005. Exclusion Code: X10.
2665 Waki K, Aizawa K, Kato S, . DialBetics with a multimedia food recording tool, FoodLog: smartphone-based self-management for type 2 diabetes. J Diabetes Sci Technol. 2015 May;9(3):534–40. doi: 10.1177/1932296815579690. PMID: 25883164. Exclusion Code: X8.25883164
2666 Walford GA, Ma Y, Christophi CA, . Circulating natriuretic peptide concentrations reflect changes in insulin sensitivity over time in the Diabetes Prevention Program. Diabetologia. 2014 May;57(5):935–9. doi: 10.1007/s00125-014-3183-2. PMID: 24554005. Exclusion Code: X6.24554005
2667 Walford GA, Ma Y, Clish C, . Metabolite profiles of diabetes incidence and intervention response in the Diabetes Prevention Program. Diabetes. 2016 May;65(5):1424–33. doi: 10.2337/db15-1063. PMID: 26861782. Exclusion Code: X6.26861782
2668 Walker CL, Kopp M, Binford RM, . Home telehealth interventions for older adults with diabetes. Home Healthc Now. 2017 Apr;35(4):202–10. doi: 10.1097/nhh.0000000000000522. PMID: 28353510. Exclusion Code: X8.28353510
2669 Walker SR, Komenda P, Khojah S, . Dipeptidyl peptidase-4 inhibitors in chronic kidney disease: a systematic review of randomized clinical trials. Nephron. 2017;136(2):85–94. doi: 10.1159/000454683. PMID: 28178698. Exclusion Code: X8.28178698
2670 Wan EYF, Yu EYT, Fung CSC, . Do we need a patient-centered target for systolic blood pressure in hypertensive patients with type 2 diabetes mellitus? Hypertension. 2017 Dec;70(6):1273–82. doi: 10.1161/hypertensionaha.117.10034. PMID: 29038204. Exclusion Code: X4.29038204
2671 Wan H, Zhao D, Shen J, . Comparison of the effects of continuous subcutaneous insulin infusion and add-on therapy with sitagliptin in patients with newly diagnosed type 2 diabetes mellitus. J Diabetes Res. 2016;2016:9849328. doi: 10.1155/2016/9849328. PMID: 26798658. Exclusion Code: X6.26798658
2672 Wang B, Sun Y, Sang Y, . Comparison of dipeptidyl peptidase-4 inhibitors and pioglitazone combination therapy versus pioglitazone monotherapy in type 2 diabetes: A system review and meta-analysis. Medicine (Baltimore). 2018 Nov;97(46):e12633. doi: 10.1097/md.0000000000012633. PMID: 30431561. Exclusion Code: X8.30431561
2673 Wang CP, Lehman DM, Lam YF, . Metformin for reducing racial/ethnic difference in prostate cancer incidence for men with type II diabetes. Cancer Prev Res (Phila). 2016 Oct;9(10):779–87. doi: 10.1158/1940-6207.capr-15-0425. PMID: 27026681. Exclusion Code: X8.27026681
2674 Wang D, Liu B, Tao W, . Fibrates for secondary prevention of cardiovascular disease and stroke. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
2675 Wang F, He Y, Zhang R, . Combination therapy of metformin plus dipeptidyl peptidase-4 inhibitor versus metformin plus sulfonylurea and their association with a decreased risk of cardiovascular disease in type 2 diabetes mellitus patients. Medicine (Baltimore). 2017 Sep;96(36):e7638. doi: 10.1097/md.0000000000007638. PMID: 28885325. Exclusion Code: X8.28885325
2676 Wang G, Zhang Z, Feng Y, . Telemedicine in the management of type 2 diabetes mellitus. American journal of the medical sciences. 2017;353(1):1–5. doi: 10.1016/j.amjms.2016.10.008. PMID: CN-01379043. Exclusion Code: X2.
2677 Wang H, Liu Y, Tian Q, . Incretin-based therapies and risk of pancreatic cancer in patients with type 2 diabetes: A meta-analysis of randomized controlled trials. Diabetes Obes Metab. 2018 Apr;20(4):910–20. doi: 10.1111/dom.13177. PMID: 29193572. Exclusion Code: X8.29193572
2678 Wang H, Song Z, Ba Y, . Nutritional and eating education improves knowledge and practice of patients with type 2 diabetes concerning dietary intake and blood glucose control in an outlying city of China. Public Health Nutr. 2014 Oct;17(10):2351–8. doi: 10.1017/s1368980013002735. PMID: 24124930. Exclusion Code: X6.24124930
2679 Wang J, Ai X, Li L, . Alprostadil protects type 2 diabetes mellitus patients treated with metformin from contrast-induced nephropathy. Int Urol Nephrol. 2017;49(11):2019–26. doi: 10.1007/s11255-017-1639-2. PMID: CN-01420380. Exclusion Code: X4.28656510
2680 Wang J, Ai XB, Wang F, . Efficacy of ezetimibe combined with atorvastatin in the treatment of carotid artery plaque in patients with type 2 diabetes mellitus complicated with coronary heart disease. Int Angiol. 2017 Oct;36(5):467–73. doi: 10.23736/s0392-9590.17.03818-4. PMID: 28641407. Exclusion Code: X2.28641407
2681 Wang KL, Liu CJ, Chao TF, . Risk of new-onset diabetes mellitus versus reduction in cardiovascular events with statin therapy. Am J Cardiol. 2014 Feb 15;113(4):631–6. doi: 10.1016/j.amjcard.2013.10.043. PMID: 24360773. Exclusion Code: X8.24360773
2682 Wang LC, Fang FS, Gong YP, . Characteristics of repaglinide and its mechanism of action on insulin secretion in patients with newly diagnosed type-2 diabetes mellitus. Medicine (Baltimore). 2018 Sep;97(38):e12476. doi: 10.1097/md.0000000000012476. PMID: 30235745. Exclusion Code: X5.30235745
2683 Wang LX, Wang N, Xu QL, . Effects of vitamin D combined with pioglitazone hydrochloride on bone mineral density and bone metabolism in Type 2 diabetic nephropathy. Biosci Rep. 2017 Apr 28;37(2)doi: 10.1042/bsr20160544. PMID: 28153916. Exclusion Code: X6.28153916
2684 Wang M, Gellar L, Nathanson B, . Decrease in glycemic index associated with improved glycemic control among latinos with type 2 diabetes. J Acad Nutr Diet. 2015;115(6):898–906. doi: 10.1016/j.jand.2014.10.012. PMID: CN-01111359. Exclusion Code: X5.25547339
2685 Wang ML, Lemon SC, Whited MC, . Who benefits from diabetes self-management interventions? The influence of depression in the Latinos en Control trial. Ann Behav Med. 2014 Oct;48(2):256–64. doi: 10.1007/s12160-014-9606-y. PMID: 24664615. Exclusion Code: X6.24664615
2686 Wang MT, Lin SC, Tang PL, . The impact of DPP-4 inhibitors on long-term survival among diabetic patients after first acute myocardial infarction. Cardiovasc Diabetol. 2017 Jul 11;16(1):89. doi: 10.1186/s12933-017-0572-0. PMID: 28697774. Exclusion Code: X2.28697774
2687 Wang Q, Imamura F, Ma W, . Circulating and dietary trans fatty acids and incident type 2 diabetes in older adults: the Cardiovascular Health Study. Diabetes care. 2015;38(6):1099–107. doi: 10.2337/dc14-2101. PMID: CN-01110118. Exclusion Code: X2.25784660
2688 Wang Q, Liu L, Gao L, . Cardiovascular safety of GLP-1 receptor agonists for diabetes patients with high cardiovascular risk: A meta-analysis of cardiovascular outcomes trials. Diabetes Res Clin Pract. 2018 Sep;143:34–42. doi: 10.1016/j.diabres.2018.06.009. PMID: 29935211. Exclusion Code: X8.29935211
2689 Wang SH, Chen DY, Lin YS, . Cardiovascular outcomes of sitagliptin in type 2 diabetic patients with acute myocardial infarction, a population-based cohort study in Taiwan. PLoS One. 2015;10(6):e0131122. doi: 10.1371/journal.pone.0131122. PMID: 26115092. Exclusion Code: X2.26115092
2690 Wang W, Li P, Gu L. Efficacy and safety of once-weekly dulaglutide versus insulin glargine in combination with metformin and/or sulfonylurea in Chinese patients with type 2 diabetes. Diabetes/metabolism research and reviews. Conference: 21st scientific meeting of the chinese diabetes society. China. 2017;33(Supplement 1) (no pagination)doi: 10.1002/dmrr.2948. PMID: CN-01431750. Exclusion Code: X2.
2691 Wang W, Li P, Yang J, . Efficacy and safety of once-weekly dulaglutide monotherapy compared to glimepiride in Chinese patients with type 2 diabetes mellitus. Diabetes/metabolism research and reviews. Conference: 19th scientific meeting of the chinese diabetes society. China. 2015;31:10–1. doi: 10.1002/dmrr.2726. PMID: CN-01361397. Exclusion Code: X5.
2692 Wang W, Ning G, Ma J, . A randomized clinical trial of the safety and efficacy of sitagliptin in patients with type 2 diabetes mellitus inadequately controlled by acarbose alone. Curr Med Res Opin. 2017 Apr;33(4):693–9. doi: 10.1080/03007995.2016.1277200. PMID: 28035868. Exclusion Code: X2.28035868
2693 Wang W, Seah B, Jiang Y, . A randomized controlled trial on a nurse-led smartphone-based self-management programme for people with poorly controlled type 2 diabetes: A study protocol. J Adv Nurs. 2018 Jan;74(1):190–200. doi: 10.1111/jan.13394. PMID: 28727183. Exclusion Code: X2.28727183
2694 Wang W, Yang J, Yang G, . Efficacy and safety of linagliptin in Asian patients with type 2 diabetes mellitus inadequately controlled by metformin: A multinational 24-week, randomized clinical trial. J Diabetes. 2016 Mar;8(2):229–37. doi: 10.1111/1753-0407.12284. PMID: 25753488. Exclusion Code: X2.25753488
2695 Wang X, Li X, Qie S, . The efficacy and safety of once-weekly DPP-4 inhibitor omarigliptin in patients with type 2 diabetes mellitus: A systemic review and meta-analysis. Medicine (Baltimore). 2018 Aug;97(34):e11946. doi: 10.1097/md.0000000000011946. PMID: 30142816. Exclusion Code: X8.30142816
2696 Wang Y, Xu B, Zhu L, . Pharmacokinetics and preliminary pharmacodynamics of single- and multiple-dose lyophilized recombinant glucagon-like peptide-1 receptor agonist (rE-4) in Chinese patients with type 2 diabetes mellitus. Clin Drug Investig. 2017 Dec;37(12):1107–15. doi: 10.1007/s40261-017-0569-1. PMID: 28932995. Exclusion Code: X5.28932995
2697 Wang Z, Xu D, Huang L, . Effects of saxagliptin on glucose homeostasis and body composition of obese patients with newly diagnosed pre-diabetes. Diabetes Res Clin Pract. 2017 Aug;130:77–85. doi: 10.1016/j.diabres.2017.05.012. PMID: 28575729. Exclusion Code: X11.28575729
2698 Watanabe M, Gangitano E, Francomano D, . Mangosteen Extract Shows a Potent Insulin Sensitizing Effect in Obese Female Patients: A Prospective Randomized Controlled Pilot Study. Nutrients. 2018 May 9;10(5)doi: 10.3390/nu10050586. PMID: 29747432. Exclusion Code: X4.29747432
2699 Watanabe M, Yamaoka K, Yokotsuka M, . Randomized controlled trial of a new dietary education program to prevent type 2 diabetes in a high-risk group of Japanese male workers. Diabetes Care. 2003 Dec;26(12):3209–14. PMID: 14633803. Exclusion Code: X6.14633803
2700 Watson L, Das R, Farquhar R, . Consequences of delaying treatment intensification in type 2 diabetes: evidence from a UK database. Curr Med Res Opin. 2016 Sep;32(9):1465–75. doi: 10.1185/03007995.2016.1157462. PMID: 26907851. Exclusion Code: X6.26907851
2701 Watson N, Dyer K, Buckley J, . A randomised trial comparing low-fat diets differing in carbohydrate and protein ratio, combined with regular moderate intensity exercise, on glycaemic control, cardiometabolic risk factors, food cravings, cognitive function and psychological wellbeing in adults with type 2 diabetes: study protocol. Contemp Clin Trials. 2015;45(Pt B):217–25. doi: 10.1016/j.cct.2015.11.001. PMID: CN-01104990. Exclusion Code: X6.26546883
2702 Watson N, Dyer K, Buckley J, . Effects of low-fat diets differing in protein and carbohydrate content on cardiometabolic risk factors during weight loss and weight maintenance in obese adults with type 2 diabetes. Nutrients. 2016;8(5)doi: 10.3390/nu8050289. PMID: CN-01307387. Exclusion Code: X2.
2703 Watts NB, Bilezikian JP, Usiskin K, . Effects of canagliflozin on fracture risk in patients with type 2 diabetes mellitus. J Clin Endocrinol Metab. 2016 Jan;101(1):157–66. doi: 10.1210/jc.2015-3167. PMID: 26580237. Exclusion Code: X2.26580237
2704 Wayne N, Perez D, Kaplan D, . Health coaching reduces HbA1c in type 2 diabetic patients from a lower-socioeconomic status community: a randomized controlled trial. J Med Internet Res. 2015;17(10):e224. doi: 10.2196/jmir.4871. PMID: CN-01169555. Exclusion Code: X2.26441467
2705 Weaver RG, Hemmelgarn BR, Rabi DM, . Association between participation in a brief diabetes education programme and glycaemic control in adults with newly diagnosed diabetes. Diabet Med. 2014 Dec;31(12):1610–4. doi: 10.1111/dme.12513. PMID: 24890340. Exclusion Code: X8.24890340
2706 Webb D, Dales J, Zaccardi F, . Intensive versus standard multifactorial cardiovascular risk factor control in screen-detected type 2 diabetes: 5-year and longer-term modelled outcomes of the ADDITION-Leicester study. Diabetes Metab Res Rev. 2019 Mar;35(3):e3111. doi: 10.1002/dmrr.3111. PMID: 30521699. Exclusion Code: X6.30521699
2707 Weber MA, Bloch M, Bakris GL, . Cardiovascular outcomes according to systolic blood pressure in patients with and without diabetes: an ACCOMPLISH Substudy. J Clin Hypertens (Greenwich). 2016 Apr;18(4):299–307. doi: 10.1111/jch.12816. PMID: 27060568. Exclusion Code: X5.27060568
2708 Weber MA, Mansfield TA, Alessi F, . Effects of dapagliflozin on blood pressure in hypertensive diabetic patients on renin-angiotensin system blockade. Blood Press. 2016;25(2):93–103. doi: 10.3109/08037051.2015.1116258. PMID: 26623980. Exclusion Code: X2.26623980
2709 Weber MA, Mansfield TA, Cain VA, . Blood pressure and glycaemic effects of dapagliflozin versus placebo in patients with type 2 diabetes on combination antihypertensive therapy: a randomised, double-blind, placebo-controlled, phase 3 study. Lancet Diabetes Endocrinol. 2016 Mar;4(3):211–20. doi: 10.1016/s2213-8587(15)00417-9. PMID: 26620248. Exclusion Code: X2.26620248
2710 Weeks G, George J, Maclure K, . Non-medical prescribing versus medical prescribing for acute and chronic disease management in primary and secondary care. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2016. Exclusion Code: X8.
2711 Wei L, Wang J, Li Z, . Design and implementation of an Omaha System-based integrated nursing management model for patients with newly-diagnosed diabetes. Prim Care Diabetes. 2019 Apr;13(2):142–9. doi: 10.1016/j.pcd.2018.11.001. PMID: 30497955. Exclusion Code: X7.30497955
2712 Wei R, Ma S, Wang C, . Exenatide exerts direct protective effects on endothelial cells through the AMPK/Akt/eNOS pathway in a GLP-1 receptor-dependent manner. Am J Physiol Endocrinol Metab. 2016 Jun 1;310(11):E947–57. doi: 10.1152/ajpendo.00400.2015. PMID: 27072494. Exclusion Code: X6.27072494
2713 Weinstock RS, Guerci B, Umpierrez G, . Safety and efficacy of once-weekly dulaglutide versus sitagliptin after 2 years in metformin-treated patients with type 2 diabetes (AWARD-5): a randomized, phase III study. Diabetes Obes Metab. 2015 Sep;17(9):849–58. doi: 10.1111/dom.12479. PMID: 25912221. Exclusion Code: X5.25912221
2714 Weir MR, Kline I, Xie J, . Effect of canagliflozin on serum electrolytes in patients with type 2 diabetes in relation to estimated glomerular filtration rate (eGFR). Curr Med Res Opin. 2014 Sep;30(9):1759–68. doi: 10.1185/03007995.2014.919907. PMID: 24786834. Exclusion Code: X8.24786834
2715 Welsh P, Preiss D, Lloyd SM, . Contrasting associations of insulin resistance with diabetes, cardiovascular disease and all-cause mortality in the elderly: PROSPER long-term follow-up. Diabetologia. 2014 Dec;57(12):2513–20. doi: 10.1007/s00125-014-3383-9. PMID: 25264116. Exclusion Code: X2.25264116
2716 Wendel CS, Fotieo GG, Shah JH, . Incidence of non-severe hypoglycaemia and intensity of treatment among veterans with type 2 diabetes in the U.S.A.: a prospective observational study. Diabet Med. 2014 Dec;31(12):1524–31. doi: 10.1111/dme.12543. PMID: 24975871. Exclusion Code: X4.24975871
2717 Wennberg AMV, Hagen CE, Edwards K, . Association of antidiabetic medication use, cognitive decline, and risk of cognitive impairment in older people with type 2 diabetes: Results from the population-based Mayo Clinic Study of Aging. Int J Geriatr Psychiatry. 2018 Aug;33(8):1114–20. doi: 10.1002/gps.4900. PMID: 29873112. Exclusion Code: X2.29873112
2718 Wennehorst K, Mildenstein K, Saliger B, . A comprehensive lifestyle intervention to prevent type 2 diabetes and cardiovascular diseases: the German CHIP Trial. Prev Sci. 2016 Apr;17(3):386–97. doi: 10.1007/s11121-015-0623-2. PMID: 26739253. Exclusion Code: X2.26739253
2719 Wens I, Hansen D, Verboven K, . Impact of 24 weeks of resistance and endurance exercise on glucose tolerance in persons with multiple sclerosis. Am J Phys Med Rehabil. 2015 Oct;94(10 Suppl 1):838–47. doi: 10.1097/phm.0000000000000257. PMID: 25768064. Exclusion Code: X2.25768064
2720 Westerterp-Plantenga M, Drummen M, Adam T, . The role of sleep and food reward in prevention of insulin resistance in pre-diabetic overweight subjects-results from the pre-view intervention study. Annals of nutrition and metabolism. Conference: 21st international congress of nutrition, ICN 2017. Argentina. 2017;71(Supplement 2):124. doi: 10.1159/000480486. PMID: CN-01428996. Exclusion Code: X6.
2721 Weymann N, Dirmaier J, von Wolff A, . Effectiveness of a Web-based tailored interactive health communication application for patients with type 2 diabetes or chronic low back pain: randomized controlled trial. J Med Internet Res. 2015 Mar 3;17(3):e53. doi: 10.2196/jmir.3904. PMID: 25736340. Exclusion Code: X6.25736340
2722 Whelan ME, Kingsnorth AP, Orme MW, . Sensing interstitial glucose to nudge active lifestyles (SIGNAL): feasibility of combining novel self-monitoring technologies for persuasive behaviour change. BMJ Open. 2017 Oct 8;7(10):e018282. doi: 10.1136/bmjopen-2017-018282. PMID: 28993396. Exclusion Code: X6.28993396
2723 White DK, Neogi T, Rejeski WJ, . Can an intensive diet and exercise program prevent knee pain among overweight adults at high risk? Arthritis Care Res (Hoboken). 2015 Jul;67(7):965–71. doi: 10.1002/acr.22544. PMID: 25692781. Exclusion Code: X2.25692781
2724 White WB, Cuadra RH, Lloyd E, . Effects of azilsartan medoxomil compared with olmesartan and valsartan on ambulatory and clinic blood pressure in patients with type 2 diabetes and prediabetes. J Hypertens. 2016 Apr;34(4):788–97. doi: 10.1097/hjh.0000000000000839. PMID: 26766564. Exclusion Code: X8.26766564
2725 White WB, Kupfer S, Zannad F, . Cardiovascular mortality in patients with type 2 diabetes and recent acute coronary syndromes from the EXAMINE Trial. Diabetes Care. 2016 Jul;39(7):1267–73. doi: 10.2337/dc16-0303. PMID: 27289121. Exclusion Code: X2.27289121
2726 White WB, Wilson CA, Bakris GL, . Angiotensin-converting enzyme inhibitor use and major cardiovascular outcomes in type 2 diabetes mellitus treated with the dipeptidyl peptidase 4 inhibitor alogliptin. Hypertension. 2016 Sep;68(3):606–13. doi: 10.1161/hypertensionaha.116.07797. PMID: 27480840. Exclusion Code: X2.27480840
2727 Whitehead L, Crowe M, Carter J, . A nurse-led education and cognitive behaviour therapy-based intervention among adults with uncontrolled type 2 diabetes: a randomised controlled trial. J Eval Clin Pract. 2017;23(4):821–9. doi: 10.1111/jep.12725. PMID: CN-01600539. Exclusion Code: X2.28397334
2728 Wichit N, Mnatzaganian G, Courtney M, . Randomized controlled trial of a family-oriented self-management program to improve self-efficacy, glycemic control and quality of life among Thai individuals with Type 2 diabetes. Diabetes Res Clin Pract. 2017 Jan;123:37–48. doi: 10.1016/j.diabres.2016.11.013. PMID: 27918976. Exclusion Code: X2.27918976
2729 Wien M, Oda K, Sabate J. A randomized controlled trial to evaluate the effect of incorporating peanuts into an American Diabetes Association meal plan on the nutrient profile of the total diet and cardiometabolic parameters of adults with type 2 diabetes. Nutr J. 2014 Jan 22;13:10. doi: 10.1186/1475-2891-13-10. PMID: 24450471. Exclusion Code: X4.24450471
2730 Wijesuriya M, Fountoulakis N, Guess N, . A pragmatic lifestyle modification programme reduces the incidence of predictors of cardiometabolic disease and dysglycaemia in a young healthy urban South Asian population: a randomised controlled trial. BMC Med. 2017 Aug 30;15(1):146. doi: 10.1186/s12916-017-0905-6. PMID: 28851373. Exclusion Code: X2.28851373
2731 Wijnen JC, van de Riet IR, Lijfering WM, . Metformin use decreases the anticoagulant effect of phenprocoumon. J Thromb Haemost. 2014 Jun;12(6):887–90. doi: 10.1111/jth.12578. PMID: 24698366. Exclusion Code: X5.24698366
2732 Wilczynska M, Lubans D, Cohen K, . Rationale and study protocol for the ‘eCoFit’ randomized controlled trial: integrating smartphone technology, social support and the outdoor physical environment to improve health-related fitness among adults at risk of, or diagnosed with, Type 2 Diabetes. Contemp Clin Trials. 2016;49:116–25. doi: 10.1016/j.cct.2016.06.013. PMID: CN-01177946. Exclusion Code: X2.27370229
2733 Wilding, Astrup, Fujioka, . Efficacy and safety of liraglutide 3.0 mg for weight management in overweight and obese adults: the scale obesity and prediabetes, a randomised, doubleblind and placebo-controlled trial. Obesity facts. 2014;7:15. doi: 10.1159/000363668. PMID: CN-01042395. Exclusion Code: X10.24457473
2734 Wilding, Astrup, Fujioka, . Efficacy and safety of liraglutide 3.0 mg for weight management in overweight and obese adults: the scaleTM obesity and prediabetes, a randomised, doubleblind and placebo-controlled trial. Obesity facts. 2014;7:15. doi: 10.1159/000363668. PMID: CN-01064658. Exclusion Code: X10.24457473
2735 Wilding J, Astrup A, Fujioka K, . Liraglutide 3.0 mg improves insulin secretion and action in overweight and obese adults without diabetes: results from scale obesity and prediabetes, a randomized, double-blind and placebo-controlled 56-week trial. Endocrine reviews. Conference: 96th annual meeting and expo of the endocrine society, ENDO 2014. Chicago, IL united states. Conference start: 20140621. Conference end: 20140624. Conference publication: (var.pagings); 2014. Exclusion Code: X6.
2736 Wilding J, Astrup A, Fujioka K, . In overweight and obese adults, liraglutide 3.0mg reduces the prevalence of prediabetes and delays the onset of Type 2 diabetes: SCALE obesity and pre-diabetes trial. Diabetic medicine. 2015;32:71. doi: 10.1111/dme.12668. PMID: CN-01078080. Exclusion Code: X10.
2737 Wilding J, Fujioka K, Greenway F, . Greater weight loss and regression to normoglycaemia, and reduced risk of T2D, at 3 years in early weight loss responders to liraglutide 3.0 mg vs early non-responders. Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S330. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212745. Exclusion Code: X10.
2738 Wilding J, Lau D, Astrup A, . Safety and tolerability of liraglutide 3.0mg following 56 weeks of randomised treatment in overweight and obese adults: SCALE obesity and pre-diabetes trial. Diabetic medicine. 2015;32:70. doi: 10.1111/dme.12668. PMID: CN-01078082. Exclusion Code: X10.
2739 Wilding J, Pi-Sunyer X, Gaal L, . Liraglutide 3.0 mg in obese/overweight adults with or without prediabetes with baseline BMI <35 vs >35 kg/m^2^ in the SCALE Obesity and Prediabetes 56-week randomised, double-blind, placebo-controlled trial. Obesity facts. Conference: european obesity summit (EOS): 1st joint congress of EASO and IFSO-EC. Gothenburg sweden. Conference start: 20160601. Conference end: 20160604. Conference publication: (var.pagings). 2016;9:70. doi: 10.1159/000446744. PMID: CN-01266576. Exclusion Code: X10.
2740 Wilding J, Sharma A, Finer N, . The efficacy and safety of liraglutide 3.0mg for weight management are similar across baseline Edmonton Obesity Staging System (EOSS) categories: post-hoc analysis at 56 weeks. Diabetic medicine. Conference: diabetes UK professional conference 2017. United kingdom. Conference start: 20170308. Conference end: 20170310. 2017;34:57. doi: 10.1111/dme.13302. PMID: CN-01369231. Exclusion Code: X5.
2741 Wilding JP, Overgaard RV, Jacobsen LV, . Exposure-response analyses of liraglutide 3.0 mg for weight management. Diabetes Obes Metab. 2016 May;18(5):491–9. doi: 10.1111/dom.12639. PMID: 26833744. Exclusion Code: X8.26833744
2742 Wilding JP, Woo V, Rohwedder K, . Dapagliflozin in patients with type 2 diabetes receiving high doses of insulin: efficacy and safety over 2 years. Diabetes Obes Metab. 2014 Feb;16(2):124–36. doi: 10.1111/dom.12187. PMID: 23911013. Exclusion Code: X2.23911013
2743 Wilken M, Nunn M. Talking circles to improve diabetes self-care management. Diabetes Educ. 2017 Aug;43(4):388–95. doi: 10.1177/0145721717706765. PMID: 28494697. Exclusion Code: X6.28494697
2744 Willard-Grace R, Chen EH, Hessler D, . Health coaching by medical assistants to improve control of diabetes, hypertension, and hyperlipidemia in low-income patients: a randomized controlled trial. Ann Fam Med. 2015 Mar;13(2):130–8. doi: 10.1370/afm.1768. PMID: 25755034. Exclusion Code: X6.25755034
2745 Willems JI, Otto SJ, Klijs B, . Screening for type 2 diabetes in a high-risk population: effects of a negative screening test after 4 years follow-up. Ann Behav Med. 2014 Feb;47(1):102–10. doi: 10.1007/s12160-013-9525-3. PMID: 23818042. Exclusion Code: X8.23818042
2746 Williams JS, Lynch CP, Knapp RG, . Technology-Intensified Diabetes Education Study (TIDES) in African Americans with type 2 diabetes: study protocol for a randomized controlled trial. Trials. 2014 Nov 25;15:460. doi: 10.1186/1745-6215-15-460. PMID: 25425504. Exclusion Code: X6.25425504
2747 Williams KH, Sullivan DR, Nicholson GC, . Opposite associations between alanine aminotransferase and gamma-glutamyl transferase levels and all-cause mortality in type 2 diabetes: Analysis of the Fenofibrate Intervention and Event Lowering in Diabetes (FIELD) study. Metabolism. 2016 May;65(5):783–93. doi: 10.1016/j.metabol.2015.12.008. PMID: 27085785. Exclusion Code: X2.27085785
2748 Williams KH, Sullivan DR, Veillard AS, . Low alanine aminotransferase levels and higher number of cardiovascular events in people with Type 2 diabetes: analysis of the Fenofibrate Intervention and Event Lowering in Diabetes (FIELD) study. Diabet Med. 2016 Mar;33(3):356–64. doi: 10.1111/dme.12972. PMID: 26433207. Exclusion Code: X6.26433207
2749 Williams LK, Padhukasahasram B, Ahmedani BK, . Differing effects of metformin on glycemic control by race-ethnicity. J Clin Endocrinol Metab. 2014 Sep;99(9):3160–8. doi: 10.1210/jc.2014-1539. PMID: 24921653. Exclusion Code: X6.24921653
2750 Williamson JD, Launer LJ, Bryan RN, . Cognitive function and brain structure in persons with type 2 diabetes mellitus after intensive lowering of blood pressure and lipid levels: a randomized clinical trial. JAMA Intern Med. 2014 Mar;174(3):324–33. doi: 10.1001/jamainternmed.2013.13656. PMID: 24493100. Exclusion Code: X6.24493100
2751 Windrum P, Garcia-Goni M, Coad H. The impact of patient-centered versus didactic education programs in chronic patients by severity: the case of type 2 diabetes mellitus. Value Health. 2016 Jun;19(4):353–62. doi: 10.1016/j.jval.2016.01.014. PMID: 27325327. Exclusion Code: X6.27325327
2752 Winett R, Davy B, Savla J, . Theory-based approach for maintaining resistance training in older adults with prediabetes: adherence, barriers, self-regulation strategies, treatment fidelity, costs. Transl Behav Med. 2015;5(2 // R01 DK082383 (NIDDK) *National Institute of Diabetes and Digestive and Kidney Diseases*):149–59. doi: 10.1007/s13142-015-0304-5. PMID: CN-01074305. Exclusion Code: X6.26029277
2753 Wing RR. Implications of Look AHEAD for clinical trials and clinical practice. Diabetes Obes Metab. 2014 Dec;16(12):1183–91. doi: 10.1111/dom.12318. PMID: 24853636. Exclusion Code: X2.24853636
2754 Wing RR, Espeland MA, Clark JM, . Association of weight loss maintenance and weight regain on 4-year changes in CVD risk factors: the Action for Health in Diabetes (Look AHEAD) clinical trial. Diabetes Care. 2016 Aug;39(8):1345–55. doi: 10.2337/dc16-0509. PMID: 27271190. Exclusion Code: X2.27271190
2755 Wing RR, Leahey T, Jeffery R, . Do weight loss and adherence cluster within behavioral treatment groups? Obesity (Silver Spring). 2014 Mar;22(3):638–44. doi: 10.1002/oby.20526. PMID: 23804576. Exclusion Code: X5.23804576
2756 Withidpanyawong U, Lerkiatbundit S, Saengcharoen W. Family-based intervention by pharmacists for type 2 diabetes: A randomised controlled trial. Patient Educ Couns. 2019 Jan;102(1):85–92. doi: 10.1016/j.pec.2018.08.015. PMID: 30150128. Exclusion Code: X2.30150128
2757 Wittert G, Roux C, Astrup A, . Liraglutide 3.0mg improves body weight and cardiometabolic risk factors in overweight or obese adults without diabetes: the SCALE Obesity and Prediabetes randomised, double-blind, placebo-controlled 56-week trial. Obes Res Clin Pract. 2014;8:118. PMID: CN-01369467. Exclusion Code: X10.
2758 Wolf P, Winhofer Y, Krssak M, . Suppression of plasma free fatty acids reduces myocardial lipid content and systolic function in type 2 diabetes. Nutr Metab Cardiovasc Dis. 2016 May;26(5):387–92. doi: 10.1016/j.numecd.2016.03.012. PMID: 27118107. Exclusion Code: X2.27118107
2759 Wolffenbuttel BH, Van Gaal L, Duran-Garcia S, . Relationship of body mass index with efficacy of exenatide twice daily added to insulin glargine in patients with type 2 diabetes. Diabetes Obes Metab. 2016 Aug;18(8):829–33. doi: 10.1111/dom.12669. PMID: 27027802. Exclusion Code: X8.27027802
2760 Wong CK, Lam CL, Wan EY, . Evaluation of patient-reported outcomes data in structured diabetes education intervention: 2-year follow-up data of patient empowerment programme. Endocrine. 2016 Nov;54(2):422–32. doi: 10.1007/s12020-016-1015-5. PMID: 27623970. Exclusion Code: X2.27623970
2761 Wong CK, Wong WC, Wan EY, . Macrovascular and microvascular disease in obese patients with type 2 diabetes attending structured diabetes education program: a population-based propensity-matched cohort analysis of Patient Empowerment Programme (PEP). Endocrine. 2016 Aug;53(2):412–22. doi: 10.1007/s12020-015-0843-z. PMID: 26785847. Exclusion Code: X8.26785847
2762 Wong CK, Wong WC, Wan YF, . Effect of a structured diabetes education programme in primary care on hospitalizations and emergency department visits among people with Type 2 diabetes mellitus: results from the Patient Empowerment Programme. Diabet Med. 2016 Oct;33(10):1427–36. doi: 10.1111/dme.12969. PMID: 26433212. Exclusion Code: X6.26433212
2763 Wong CW, Leung CS, Leung CP, . Association of metformin use with vitamin B12 deficiency in the institutionalized elderly. Arch Gerontol Geriatr. 2018 Nov – Dec;79:57–62. doi: 10.1016/j.archger.2018.07.019. PMID: 30114554. Exclusion Code: X2.30114554
2764 Wong MG, Perkovic V, Chalmers J, . Long-term benefits of intensive glucose control for preventing end-stage kidney disease: ADVANCE-ON. Diabetes Care. 2016 May;39(5):694–700. doi: 10.2337/dc15-2322. PMID: 27006512. Exclusion Code: X2.27006512
2765 Worsley R, Jane F, Robinson PJ, . Metformin for overweight women at midlife: a double-blind, randomized, controlled trial. Climacteric. 2015 Apr;18(2):270–7. doi: 10.3109/13697137.2014.954997. PMID: 25333776. Exclusion Code: X2.25333776
2766 Wright N, Wilson L, Smith M, . The BROAD study: a randomised controlled trial using a whole food plant-based diet in the community for obesity, ischaemic heart disease or diabetes. Nutr Diabetes. 2017;7(3):e256. doi: 10.1038/nutd.2017.3. PMID: CN-01426246. Exclusion Code: X2.28319109
2767 Wu H, Liu J, Lou Q, . Comparative assessment of the efficacy and safety of acarbose and metformin combined with premixed insulin in patients with type 2 diabetes mellitus. Medicine (Baltimore). 2017 Sep;96(35):e7533. doi: 10.1097/md.0000000000007533. PMID: 28858080. Exclusion Code: X2.28858080
2768 Wu H, Walker J, Damhuis RA, . Metformin and survival of people with type 2 diabetes and pleural mesothelioma: A population-based retrospective cohort study. Lung Cancer. 2016 Sep;99:194–9. doi: 10.1016/j.lungcan.2016.07.020. PMID: 27565939. Exclusion Code: X2.27565939
2769 Wu H, Xu MJ, Zou DJ, . Intensive glycemic control and macrovascular events in type 2 diabetes mellitus: a meta-analysis of randomized controlled trials. Chin Med J (Engl). 2010 Oct;123(20):2908–13. PMID: 21034605. Exclusion Code: X8.21034605
2770 Wu PY, Huang CL, Lei WS, . Alternative health eating index and the Dietary Guidelines from American Diabetes Association both may reduce the risk of cardiovascular disease in type 2 diabetes patients. J Hum Nutr Diet. 2016 Jun;29(3):363–73. doi: 10.1111/jhn.12317. PMID: 26010198. Exclusion Code: X4.26010198
2771 Wu T, Ma J, Bound MJ, . Effects of sitagliptin on glycemia, incretin hormones, and antropyloroduodenal motility in response to intraduodenal glucose infusion in healthy lean and obese humans and patients with type 2 diabetes treated with or without metformin. Diabetes. 2014 Aug;63(8):2776–87. doi: 10.2337/db13-1627. PMID: 24647737. Exclusion Code: X5.24647737
2772 Wu T, Trahair LG, Bound MJ, . Effects of sitagliptin on blood pressure and heart rate in response to intraduodenal glucose infusion in patients with Type 2 diabetes: a potential role for glucose-dependent insulinotropic polypeptide? Diabet Med. 2015 May;32(5):595–600. doi: 10.1111/dme.12622. PMID: 25388434. Exclusion Code: X4.25388434
2773 Wu T, Trahair LG, Little TJ, . Effects of vildagliptin and metformin on blood pressure and heart rate responses to small intestinal glucose in type 2 diabetes. Diabetes Care. 2017 May;40(5):702–5. doi: 10.2337/dc16-2391. PMID: 28258090. Exclusion Code: X2.28258090
2774 Wu W, Li Y, Chen X, . Effect of linagliptin on glycemic control in chinese patients with newly-diagnosed, drug-naive type 2 diabetes mellitus: a randomized controlled trial. Med Sci Monit. 2015 Sep 9;21:2678–84. doi: 10.12659/msm.894026. PMID: 26350766. Exclusion Code: X11.26350766
2775 Wvan der Zanden R, de Vries F, Lalmohamed A, . Use of dipeptidyl-peptidase-4 inhibitors and the risk of pneumonia: a population-based cohort study. PLoS One. 2015;10(10):e0139367. doi: 10.1371/journal.pone.0139367. PMID: 26468883. Exclusion Code: X5.26468883
2776 Wysham C, Blevins T, Arakaki R, . Efficacy and safety of dulaglutide added onto pioglitazone and metformin versus exenatide in type 2 diabetes in a randomized controlled trial (AWARD-1). Diabetes Care. 2014 Aug;37(8):2159–67. doi: 10.2337/dc13-2760. PMID: 24879836. Exclusion Code: X2.24879836
2777 Xiang Y, Luo P, Cai X, . Results of a pilot study of patient-to-patient education strategy on self-management among glycemic uncontrolled patients with diabetes. Patient preference and adherence. 2017;11:787–93. doi: 10.2147/PPA.S130060. PMID: CN-01372076. Exclusion Code: X2.28458523
2778 Xiao CC, Ren A, Yang J, . Effects of pioglitazone and glipizide on platelet function in patients with type 2 diabetes. Eur Rev Med Pharmacol Sci. 2015;19(6):963–70. PMID: 25855920. Exclusion Code: X5.25855920
2779 Xiaoyan C, Jing W, Xiaochun H, . Effects of vildagliptin versus saxagliptin on daily acute glucose fluctuations in Chinese patients with T2DM inadequately controlled with a combination of metformin and sulfonylurea. Curr Med Res Opin. 2016 Jun;32(6):1131–6. doi: 10.1185/03007995.2016.1162773. PMID: 26950829. Exclusion Code: X2.26950829
2780 Xu S, Liu X, Ming J, . Comparison of exenatide with biphasic insulin aspart 30 on glucose variability in type 2 diabetes: study protocol for a randomized controlled trial. Trials. 2016 Mar 24;17:160. doi: 10.1186/s13063-016-1258-8. PMID: 27009108. Exclusion Code: X8.27009108
2781 Xu T, Brandmaier S, Messias AC, . Effects of metformin on metabolite profiles and LDL cholesterol in patients with type 2 diabetes. Diabetes Care. 2015 Oct;38(10):1858–67. doi: 10.2337/dc15-0658. PMID: 26251408. Exclusion Code: X6.26251408
2782 Xu W, Bi Y, Sun Z, . Comparison of the effects on glycaemic control and beta-cell function in newly diagnosed type 2 diabetes patients of treatment with exenatide, insulin or pioglitazone: a multicentre randomized parallel-group trial (the CONFIDENCE study). J Intern Med. 2015 Jan;277(1):137–50. doi: 10.1111/joim.12293. PMID: 25039675. Exclusion Code: X5.25039675
2783 Xu W, Mu Y, Zhao J, . Efficacy and safety of metformin and sitagliptin based triple antihyperglycemic therapy (STRATEGY): a multicenter, randomized, controlled, non-inferiority clinical trial. Sci China Life Sci. 2017 Mar;60(3):225–38. doi: 10.1007/s11427-016-0409-7. PMID: 28271251. Exclusion Code: X5.28271251
2784 Xu W, Tan L, Wang HF, . Meta-analysis of modifiable risk factors for Alzheimer’s disease. J Neurol Neurosurg Psychiatry. 2015 Dec;86(12):1299–306. doi: 10.1136/jnnp-2015-310548. PMID: 26294005. Exclusion Code: X8.26294005
2785 Xu X, Lin S, Chen Y, . The effect of metformin on the expression of GPR109A, NF-kappaB and IL-1beta in peripheral blood leukocytes from patients with type 2 diabetes mellitus. Ann Clin Lab Sci. 2017 Sep;47(5):556–62. PMID: 29066482. Exclusion Code: X8.29066482
2786 Xue H, Lu Z, Tang WL, . First-line drugs inhibiting the renin angiotensin system versus other first-line antihypertensive drug classes for hypertension. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2015. Exclusion Code: X8.
2787 Yabe D, Ambos A, Cariou B, . Efficacy of lixisenatide in patients with type 2 diabetes: A post hoc analysis of patients with diverse beta-cell function in the GetGoal-M and GetGoal-S trials. J Diabetes Complications. 2016 Sep–Oct;30(7):1385–92. doi: 10.1016/j.jdiacomp.2016.05.018. PMID: 27267268. Exclusion Code: X2.27267268
2788 Yabe D, Eto T, Shiramoto M, . Effects of DPP-4 inhibitor linagliptin and GLP-1 receptor agonist liraglutide on physiological response to hypoglycaemia in Japanese subjects with type 2 diabetes: A randomized, open-label, 2-arm parallel comparative, exploratory trial. Diabetes Obes Metab. 2017 Mar;19(3):442–7. doi: 10.1111/dom.12817. PMID: 27800649. Exclusion Code: X2.27800649
2789 Yabe D, Kuwata H, Fujiwara Y, . Effects of dietary instructions including meal-sequence for prediabetes subjects-comparison with conventional approach. Diabetes. 2018;67:LB14-. PMID: CN-01631279. Exclusion Code: X4.
2790 Yabiku K, Mutoh A, Miyagi K, . Effects of oral antidiabetic drugs on changes in the liver-to-spleen ratio on computed tomography and inflammatory biomarkers in patients with type 2 diabetes and nonalcoholic fatty liver disease. Clin Ther. 2017 Mar;39(3):558–66. doi: 10.1016/j.clinthera.2017.01.015. PMID: 28185715. Exclusion Code: X5.28185715
2791 Yale JF, Pettus JH, Brito-Sanfiel M, . The effect of concomitant DPPIVi use on glycaemic control and hypoglycaemia with insulin glargine 300 U/mL (Gla-300) versus insulin glargine 100 U/mL (Gla-100) in people with type 2 diabetes: A patient-level meta-analysis of EDITION 2 and 3. PLoS One. 2018;13(1):e0190579. doi: 10.1371/journal.pone.0190579. PMID: 29370218. Exclusion Code: X8.29370218
2792 Yale JF, Xie J, Sherman SE, . Canagliflozin in conjunction with sulfonylurea maintains glycemic control and weight loss over 52 weeks: a randomized, controlled trial in patients with type 2 diabetes mellitus. Clin Ther. 2017 Nov;39(11):2230–42.e2. doi: 10.1016/j.clinthera.2017.10.003. PMID: 29103664. Exclusion Code: X2.29103664
2793 Yamada H, Tanaka A, Kusunose K, . Effect of sitagliptin on the echocardiographic parameters of left ventricular diastolic function in patients with type 2 diabetes: a subgroup analysis of the PROLOGUE study. Cardiovasc Diabetol. 2017 May 11;16(1):63. doi: 10.1186/s12933-017-0546-2. PMID: 28490337. Exclusion Code: X2.28490337
2794 Yamada Y, Terauchi Y, Watada H, . Efficacy and safety of DS-8500a, a GPR119 agonist, in Japanese patients with type 2 diabetes: a randomised, double-blind, placebocontrolled, 12-week study. Diabetologia. Conference: 53rd annual meeting of the european association for the study of diabetes, EASD 2017. Portugal. 2017;60(1 Supplement 1):S392. doi: 10.1007/s00125-017-4350-z. PMID: CN-01418947. Exclusion Code: X6.
2795 Yamada Y, Terauchi Y, Watada H, . Efficacy and safety of GPR119 Agonist DS-8500a in Japanese patients with type 2 diabetes: a randomized, double-blind, placebo-controlled, 12-week study. Adv Ther. 2018;35(3):367–81. doi: 10.1007/s12325-018-0668-2. PMID: CN-01465222. Exclusion Code: X2.29488152
2796 Yamada Y, Uchida J, Izumi H, . A non-calorie-restricted low-carbohydrate diet is effective as an alternative therapy for patients with type 2 diabetes. Internal medicine (tokyo, japan). 2014;53(1):13–9. PMID: CN-00978815. Exclusion Code: X2.
2797 Yamamoto S, Okada Y, Mori H, . Type 2 diabetes mellitus complicated by hypertension in Japanese patients: switching treatment from high-dose angiotensin II receptor blockers to losartan plus hydrochlorothiazide. Intern Med. 2014;53(12):1283–9. PMID: 24930646. Exclusion Code: X2.24930646
2798 Yamamoto T, Moyama S, Yano H. Effect of a newly-devised nutritional guide based on self-efficacy for patients with type 2 diabetes in Japan over 2 years: 1-year intervention and 1-year follow-up studies. J Diabetes Investig. 2017 Mar;8(2):195–200. doi: 10.1111/jdi.12571. PMID: 27565735. Exclusion Code: X8.27565735
2799 Yamamoto-Kabasawa K, Hosojima M, Yata Y, . Benefits of a 12-week lifestyle modification program including diet and combined aerobic and resistance exercise on albuminuria in diabetic and non-diabetic Japanese populations. Clin Exp Nephrol. 2015 Dec;19(6):1079–89. doi: 10.1007/s10157-015-1103-5. PMID: 25749830. Exclusion Code: X8.25749830
2800 Yan H, Xia M, Chang X, . Berberine vs. pioglitazone for treatment of nonalcoholic fatty liver disease and its associated impaired glucose metabolism. Diabetes. 2014;63:A513–a4. doi: 10.2337/db14-1741-2092. PMID: CN-01065474. Exclusion Code: X6.
2801 Yan J, Zhang Y. Influencing factors of fasting plasma glucose after short-term intensive insulin therapy in patients with newly diagnosed type 2 diabetes mellitus. Diabetes/metabolism research and reviews. Conference: 21st scientific meeting of the chinese diabetes society. China. 2017;33(Supplement 1) (no pagination)doi: 10.1002/dmrr.2948. PMID: CN-01431756. Exclusion Code: X5.
2802 Yang GR, Zhao XL, Jin F, . Pharmacokinetics and pharmacodynamics of a polyethylene glycol (PEG)-conjugated GLP-receptor agonist once weekly in Chinese patients with type 2 diabetes. J Clin Pharmacol. 2015 Feb;55(2):152–8. doi: 10.1002/jcph.386. PMID: 25167840. Exclusion Code: X2.25167840
2803 Yang HK, Min KW, Park SW, . A randomized, placebo-controlled, double-blind, phase 3 trial to evaluate the efficacy and safety of anagliptin in drug-naive patients with type 2 diabetes. Endocr J. 2015;62(5):449–62. doi: 10.1507/endocrj.EJ14-0544. PMID: 25819061. Exclusion Code: X2.25819061
2804 Yang J, Huang C, Wu S, . The effects of dipeptidyl peptidase-4 inhibitors on bone fracture among patients with type 2 diabetes mellitus: A network meta-analysis of randomized controlled trials. PLoS One. 2017;12(12):e0187537. doi: 10.1371/journal.pone.0187537. PMID: 29206832. Exclusion Code: X8.29206832
2805 Yang L, Ling W, Yang Y, . Role of purified anthocyanins in improving cardiometabolic risk factors in Chinese men and women with prediabetes or early untreated diabetes-a randomized controlled trial. Nutrients. 2017 Oct 10;9(10)doi: 10.3390/nu9101104. PMID: 28994705. Exclusion Code: X4.28994705
2806 Yang L, Shao J, Bian Y, . Prevalence of type 2 diabetes mellitus among inland residents in China (2000-2014): A meta-analysis. J Diabetes Investig. 2016 Nov;7(6):845–52. doi: 10.1111/jdi.12514. PMID: 27181391. Exclusion Code: X8.27181391
2807 Yang M, Ji L, Liu Y, . Safety and efficacy of ertugliflozin in Asian patients with type 2 diabetes inadequately controlled with metformin monotherapy: vERTIS-Asia. Diabetologia. 2018;61:S307–S8. doi: 10.1007/s00125-018-4693-0. PMID: CN-01647091. Exclusion Code: X2.
2808 Yang TY, Liaw YP, Huang JY, . Association of sitagliptin with cardiovascular outcome in diabetic patients: a nationwide cohort study. Acta Diabetol. 2016 Jun;53(3):461–8. doi: 10.1007/s00592-015-0817-x. PMID: 26687195. Exclusion Code: X8.26687195
2809 Yang W, Han P, Min KW, . Efficacy and safety of dapagliflozin in Asian patients with type 2 diabetes after metformin failure: A randomized controlled trial. J Diabetes. 2016 Nov;8(6):796–808. doi: 10.1111/1753-0407.12357. PMID: 26589253. Exclusion Code: X2.26589253
2810 Yang W, Liu J, Shan Z, . Acarbose compared with metformin as initial therapy in patients with newly diagnosed type 2 diabetes: an open-label, non-inferiority randomised trial. Lancet Diabetes Endocrinol. 2014 Jan;2(1):46–55. doi: 10.1016/s2213-8587(13)70021-4. PMID: 24622668. Exclusion Code: X5.24622668
2811 Yang W, Xing X, Lv X, . Vildagliptin added to sulfonylurea improves glycemic control without hypoglycemia and weight gain in Chinese patients with type 2 diabetes mellitus. J Diabetes. 2015 Mar;7(2):174–81. doi: 10.1111/1753-0407.12169. PMID: 24823599. Exclusion Code: X2.24823599
2812 Yang X, Kong AP, Luk AO, . Validation of methods to control for immortal time bias in a pharmacoepidemiologic analysis of renin-angiotensin system inhibitors in type 2 diabetes. J Epidemiol. 2014;24(4):267–73. PMID: 24747198. Exclusion Code: X8.24747198
2813 Yang Z, Chen R, Zhang Y, . Scoring systems to screen for diabetic peripheral neuropathy. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
2814 Yang Z, Zhang Y, Chen R, . Simple tests to screen for diabetic peripheral neuropathy. Cochrane Database of Systematic Reviews: John Wiley & Sons, Ltd; 2014. Exclusion Code: X8.
2815 Yates MS, Coletta AM, Zhang Q, . Prospective randomized biomarker study of metformin and lifestyle intervention for prevention in obese women at increased risk for endometrial cancer. Cancer Prev Res (Phila). 2018;11(8):477–90. doi: 10.1158/1940-6207.CAPR-17-0398. PMID: CN-01629432. Exclusion Code: X6.29716897
2816 Yates T, Davies MJ, Edwardson C, . Adverse responses and physical activity: secondary analysis of the PREPARE trial. Med Sci Sports Exerc. 2014 Aug;46(8):1617–23. doi: 10.1249/mss.0000000000000260. PMID: 24500536. Exclusion Code: X6.24500536
2817 Yates T, Davies MJ, Haffner SM, . Physical activity as a determinant of fasting and 2-h post-challenge glucose: a prospective cohort analysis of the NAVIGATOR trial. Diabet Med. 2015 Aug;32(8):1090–6. doi: 10.1111/dme.12762. PMID: 25818859. Exclusion Code: X6.25818859
2818 Yates T, Edwardson CL, Henson J, . Walking away from type 2 diabetes: a cluster randomized controlled trial. Diabet Med. 2017 May;34(5):698–707. doi: 10.1111/dme.13254. PMID: 27589017. Exclusion Code: X2.27589017
2819 Yates T, Griffin S, Bodicoat DH, . PRomotion Of Physical activity through structured Education with differing Levels of ongoing Support for people at high risk of type 2 diabetes (PROPELS): study protocol for a randomized controlled trial. Trials. 2015 Jul 2;16:289. doi: 10.1186/s13063-015-0813-z. PMID: 26130075. Exclusion Code: X6.26130075
2820 Yates T, Haffner S, Schulte P, . Association between change in daily ambulatory activity and cardiovascular events in people with impaired glucose tolerance (NAVIGATOR trial): a cohort analysis. Lancet (london, england). 2014;383(9922):1059–66. doi: 10.1016/S0140-6736(13)62061-9. PMID: CN-00985193. Exclusion Code: X5.
2821 Yates T, Khunti K, Bull F, . The role of physical activity in the management of impaired glucose tolerance: a systematic review (Structured abstract). Diabetologia; 2007. p. 1116–26. Exclusion Code: X8.17415549
2822 Yavin Y, Mansfield T, Ptaszynska A, . Effect of the SGLT2 inhibitor dapagliflozin on potassium levels in patients with type 2 diabetes mellitus: a pooled analysis. Diabetes therapy. 2016;7(1):125–37. doi: 10.1007/s13300-015-0150-y. PMID: CN-01141941. Exclusion Code: X8.26758563
2823 Yeh MC, Heo M, Suchday S, . Translation of the Diabetes Prevention Program for diabetes risk reduction in Chinese immigrants in New York City. Diabet Med. 2016 Apr;33(4):547–51. doi: 10.1111/dme.12848. PMID: 26179569. Exclusion Code: X11.26179569
2824 Yilmaz A, Ak M, Cim A, . Factors influencing insulin usage among type 2 diabetes mellitus patients: a study in Turkish primary care. Eur J Gen Pract. 2016 Dec;22(4):255–61. doi: 10.1080/13814788.2016.1230603. PMID: 27652800. Exclusion Code: X8.27652800
2825 Yin Z, Perry J, Duan X, . Cultural adaptation of an evidence-based lifestyle intervention for diabetes prevention in Chinese women at risk for diabetes: results of a randomized trial. Int Health. 2018 Sep 1;10(5):391–400. doi: 10.1093/inthealth/ihx072. PMID: 29447347. Exclusion Code: X5.29447347
2826 Yokoyama H, Araki S, Kawai K, . Pioglitazone treatment and cardiovascular event and death in subjects with type 2 diabetes without established cardiovascular disease (JDDM 36). Diabetes Res Clin Pract. 2015 Sep;109(3):485–92. doi: 10.1016/j.diabres.2015.06.005. PMID: 26261056. Exclusion Code: X2.26261056
2827 Yom-Tov E, Feraru G, Kozdoba M, . Encouraging physical activity in patients with diabetes: intervention using a reinforcement learning system. J Med Internet Res. 2017 Oct 10;19(10):e338. doi: 10.2196/jmir.7994. PMID: 29017988. Exclusion Code: X6.29017988
2828 Yoo JY, Yum KS. Effect of Coenzyme Q10 on Insulin Resistance in Korean Patients with Prediabetes: A Pilot Single-Center, Randomized, Double-Blind, Placebo-Controlled Study. Biomed Res Int. 2018;2018:1613247. doi: 10.1155/2018/1613247. PMID: 30151373. Exclusion Code: X6.30151373
2829 Yoon S, Han B, Kim S, . Efficacy and safety of gemigliptin in type 2 diabetes patients with moderate to severe renal impairment (GUARD study). Diabetologia. 2016;Conference: 52nd Annual Meeting of the European Association for the Study of Diabetes, EASD 2016. Germany. Conference Start: 20160912. Conference End: 20160916. 59(1 Supplement 1):S361–s2. doi: 10.1007/s00125-016-4046-9. PMID: CN-01212877. Exclusion Code: X2.
2830 Yoshii H, Onuma T, Yamazaki T, . Effects of pioglitazone on macrovascular events in patients with type 2 diabetes mellitus at high risk of stroke: the PROFIT-J study. J Atheroscler Thromb. 2014;21(6):563–73. PMID: 24477028. Exclusion Code: X2.24477028
2831 Young LA, Buse JB, Weaver MA, . Glucose self-monitoring in non-insulin-treated patients with type 2 diabetes in primary care settings: a randomized trial. JAMA Intern Med. 2017 Jul 1;177(7):920–9. doi: 10.1001/jamainternmed.2017.1233. PMID: 28600913. Exclusion Code: X2.28600913
2832 Young LH, Viscoli CM, Curtis JP, . Cardiac outcomes after ischemic stroke or transient ischemic attack: effects of pioglitazone in patients with insulin resistance without diabetes mellitus. Circulation. 2017 May 16;135(20):1882–93. doi: 10.1161/circulationaha.116.024863. PMID: 28246237. Exclusion Code: X2.28246237
2833 Younis A, Eskenazi D, Goldkorn R, . The addition of vildagliptin to metformin prevents the elevation of interleukin 1ss in patients with type 2 diabetes and coronary artery disease: a prospective, randomized, open-label study. Cardiovasc Diabetol. 2017 May 22;16(1):69. doi: 10.1186/s12933-017-0551-5. PMID: 28532406. Exclusion Code: X2.28532406
2834 Younis A, Goldkorn R, Goldenberg I, . Impaired fasting glucose is the major determinant of the 20-year mortality risk associated with metabolic syndrome in nondiabetic patients with stable coronary artery disease. J Am Heart Assoc. 2017 Oct 27;6(11)doi: 10.1161/jaha.117.006609. PMID: 29079562. Exclusion Code: X2.29079562
2835 Yu C, Bahniwal R, Laupacis A, . Systematic review and evaluation of web-accessible tools for management of diabetes and related cardiovascular risk factors by patients and healthcare providers (Structured abstract). Journal of the American Medical Informatics Association; 2012. p. 514–22. Exclusion Code: X8.22215057
2836 Yu M, Brunt KV, Milicevic Z, . Patient-reported outcomes in patients with type 2 diabetes treated with dulaglutide added to titrated insulin glargine (AWARD-9). Clin Ther. 2017 Nov;39(11):2284–95. doi: 10.1016/j.clinthera.2017.10.002. PMID: 29110972. Exclusion Code: X2.29110972
2837 Yu M, Chen Y, Chen H. Comparison of glycemic control in patients with type 2 diabetes mellitus initiating insulin therapy at different blood glucose levels. Diabetes Metab Res Rev. 2018;34:18–9. doi: 10.1002/dmrr.3079. PMID: CN-01779857. Exclusion Code: X5.
2838 Yu M, Shankar RR, Zhang R, . Efficacy and safety of sitagliptin added to treatment of patients with type 2 diabetes inadequately controlled with premixed insulin. Diabetes Obes Metab. 2019 Feb;21(2):408–11. doi: 10.1111/dom.13517. PMID: 30178570. Exclusion Code: X8.30178570
2839 Yu M, Van Brunt K, Varnado OJ, . Patient-reported outcome results in patients with type 2 diabetes treated with once-weekly dulaglutide: data from the AWARD phase III clinical trial programme. Diabetes Obes Metab. 2016 Apr;18(4):419–24. doi: 10.1111/dom.12624. PMID: 26691396. Exclusion Code: X8.26691396
2840 Yu Pan C, Han P, Liu X, . Lixisenatide treatment improves glycaemic control in Asian patients with type 2 diabetes mellitus inadequately controlled on metformin with or without sulfonylurea: a randomized, double-blind, placebo-controlled, 24-week trial (GetGoal-M-Asia). Diabetes Metab Res Rev. 2014 Nov;30(8):726–35. doi: 10.1002/dmrr.2541. PMID: 24639432. Exclusion Code: X2.24639432
2841 Yu R, Yan LL, Wang H, . Effectiveness of a community-based individualized lifestyle intervention among older adults with diabetes and hypertension, Tianjin, China, 2008-2009. Prev Chronic Dis. 2014 May 15;11:E84. doi: 10.5888/pcd11.120333. PMID: 24831288. Exclusion Code: X6.24831288
2842 Yu S, Fu AZ, Engel SS, . Association between hypoglycemia risk and hemoglobin A1C in patients with type 2 diabetes mellitus. Curr Med Res Opin. 2016 Aug;32(8):1409–16. doi: 10.1080/03007995.2016.1176017. PMID: 27053004. Exclusion Code: X2.27053004
2843 Yuan C, Lai CW, Chan LW, . The effect of diabetes self-management education on body weight, glycemic control, and other metabolic markers in patients with type 2 diabetes mellitus. J Diabetes Res. 2014;2014:789761. doi: 10.1155/2014/789761. PMID: 25136645. Exclusion Code: X2.25136645
2844 Yuan G, Hu H, Wang S, . Improvement of beta-cell function ameliorated glycemic variability in patients with newly diagnosed type 2 diabetes after short-term continuous subcutaneous insulin infusion or in combination with sitagliptin treatment: a randomized control trial. Endocr J. 2015;62(9):817–34. doi: 10.1507/endocrj.EJ15-0160. PMID: 26194272. Exclusion Code: X5.26194272
2845 Yuan G, Hu H, Wang S, . Improvement of ?-cell function ameliorated glycemic variability in patients with newly diagnosed type 2 diabetes after short-term continuous subcutaneous insulin infusion or in combination with sitagliptin treatment: a randomized control trial. Endocr J. 2015;62(9):817–34. doi: 10.1507/endocrj.EJ15-0160. PMID: CN-01170726. Exclusion Code: X6.26194272
2846 Yuan G, Jia J, Zhang C, . Safety and efficacy of sitagliptin in combination with transient continuous subcutaneous insulin infusion (CSII) therapy in patients with newly diagnosed type 2 diabetes. Endocr J. 2014;61(5):513–21. PMID: 24621778. Exclusion Code: X5.24621778
2847 Yuan X, Dai X, Liu L, . Comparing the effects of 6 months aerobic exercise and resistance training on metabolic control and Î²-cell function in Chinese patients with prediabetes: a multicenter randomized controlled trial. J Diabetes. 2019doi: 10.1111/1753-0407.12955. PMID: CN-01960091. Exclusion Code: X6.
2848 Yuan X, Wang F, Fish A, . Effect of case management on glycemic control and behavioral outcomes for chinese people with type 2 diabetes: a 2-year study. Patient Educ Couns. 2016;99(8):1382–8. doi: 10.1016/j.pec.2016.03.010. PMID: CN-01382969. Exclusion Code: X2.27005564
2849 Yuen A, Sugeng Y, Weiland T, . Lifestyle and medication interventions for the prevention or delay of type 2 diabetes mellitus in prediabetes: a systematic review of randomised controlled trials (Structured abstract). Aust N Z J Public Health; 2010. p. 172–8. Exclusion Code: X8.23331362
2850 Zack J, Berg J, Juan A, . Pharmacokinetic drug-drug interaction study of ranolazine and metformin in subjects with type 2 diabetes mellitus. Clin Pharmacol Drug Dev. 2015 Mar;4(2):121–9. doi: 10.1002/cpdd.174. PMID: 27128216. Exclusion Code: X2.27128216
2851 Zamora-Ros R, Forouhi NG, Sharp SJ, . Dietary intakes of individual flavanols and flavonols are inversely associated with incident type 2 diabetes in European populations. J Nutr. 2014 Mar;144(3):335–43. doi: 10.3945/jn.113.184945. PMID: 24368432. Exclusion Code: X8.24368432
2852 Zang L, Liu Y, Geng J, . Efficacy and safety of liraglutide versus sitagliptin, both in combination with metformin, in Chinese patients with type 2 diabetes: a 26-week, open-label, randomized, active comparator clinical trial. Diabetes Obes Metab. 2016 Aug;18(8):803–11. doi: 10.1111/dom.12674. PMID: 27060930. Exclusion Code: X5.27060930
2853 Zannad F, Cannon CP, Cushman WC, . Heart failure and mortality outcomes in patients with type 2 diabetes taking alogliptin versus placebo in EXAMINE: a multicentre, randomised, double-blind trial. Lancet. 2015 May 23;385(9982):2067–76. doi: 10.1016/s0140-6736(14)62225-x. PMID: 25765696. Exclusion Code: X2.25765696
2854 Zavattaro M, Caputo M, Sama MT, . One-year treatment with liraglutide improved renal function in patients with type 2 diabetes: a pilot prospective study. Endocrine. 2015 Dec;50(3):620–6. doi: 10.1007/s12020-014-0519-0. PMID: 25572181. Exclusion Code: X2.25572181
2855 Zeller M, Labalette-Bart M, Juliard JM, . Metformin and contrast-induced acute kidney injury in diabetic patients treated with primary percutaneous coronary intervention for ST segment elevation myocardial infarction: Amulticenter study. Int J Cardiol. 2016 Oct 1;220:137–42. doi: 10.1016/j.ijcard.2016.06.076. PMID: 27376570. Exclusion Code: X2.27376570
2856 Zeng Z, Choi DS, Mohan V, . Efficacy and safety of linagliptin as monotherapy or add-on treatment in Asian patients with suboptimal glycemic control: a pooled analysis. Curr Med Res Opin. 2015 Jan;31(1):99–106. doi: 10.1185/03007995.2014.964856. PMID: 25215428. Exclusion Code: X8.25215428
2857 Zerm R, Helbrecht B, Pranga D, . A multimodal therapy concept for lifestyle optimization in Type 2 Diabetes-design and methodology of the AIM DIABETES study. BMC complementary and alternative medicine. Conference: world congress integrative medicine and health 2017. Germany. 2017;17(Supplement 1) (no pagination)doi: 10.1186/s12906-017-1783-3. PMID: CN-01439611. Exclusion Code: X6.
2858 Zghebi SS, Steinke DT, Rutter MK, . Comparative risk of major cardiovascular events associated with second-line antidiabetic treatments: a retrospective cohort study using UK primary care data linked to hospitalization and mortality records. Diabetes Obes Metab. 2016 Sep;18(9):916–24. doi: 10.1111/dom.12692. PMID: 27177784. Exclusion Code: X5.27177784
2859 Zgibor JC, Maloney MA, Malmi M, Jr., . Effectiveness of certified diabetes educators following pre-approved protocols to redesign diabetes care delivery in primary care: Results of the REMEDIES 4D trial. Contemp Clin Trials. 2018 Jan;64:201–9. doi: 10.1016/j.cct.2017.10.003. PMID: 28993287. Exclusion Code: X2.28993287
2860 Zhang C, Gao F, Luo H, . Differential response in levels of high-density lipoprotein cholesterol to one-year metformin treatment in prediabetic patients by race/ethnicity. Cardiovasc Diabetol. 2015 Jun 12;14:79. doi: 10.1186/s12933-015-0240-1. PMID: 26068179. Exclusion Code: X6.26068179
2861 Zhang C, Zhang R. More effective glycaemic control by metformin in African Americans than in Whites in the prediabetic population. Diabetes Metab. 2015 Apr;41(2):173–5. doi: 10.1016/j.diabet.2015.01.003. PMID: 25659998. Exclusion Code: X5.25659998
2862 Zhang D, Hou W, Liu F, . Metformin reduces serum CA199 levels in type 2 diabetes Chinese patients with time-effect and gender difference. Diabetes Technol Ther. 2015 Feb;17(2):72–9. doi: 10.1089/dia.2014.0176. PMID: 25548963. Exclusion Code: X6.25548963
2863 Zhang J, Shao Y, Liu Y, . A Multi-Center, Open-Label, Two-Arm Parallel Group Non-inferiority Randomized Controlled Trial Evaluating the Effect of Pitavastatin, Compared to Atorvastatin, on Glucose Metabolism in Prediabetics with Hypertension and Dyslipidemia: Rationale and Design for the China Hemoglobin A1c Metabolism Protection Union Study (CAMPUS). Cardiovasc Drugs Ther. 2018 Dec;32(6):581–9. doi: 10.1007/s10557-018-6826-6. PMID: 30187345. Exclusion Code: X5.30187345
2864 Zhang J, Wang N, Xing X, . Factors that influence the efficacy of acarbose and metformin as initial therapy in Chinese patients with newly diagnosed type 2 diabetes: a subanalysis of the MARCH trial. Curr Med Res Opin. 2016;32(4):713–9. doi: 10.1185/03007995.2015.1136819. PMID: 26714411. Exclusion Code: X5.26714411
2865 Zhang JP, Wang N, Xing XY, . Efficacy of acarbose and metformin in newly diagnosed type 2 diabetes patients stratified by HbA1c levels. J Diabetes. 2016 Jul;8(4):559–67. doi: 10.1111/1753-0407.12337. PMID: 26331290. Exclusion Code: X5.26331290
2866 Zhang L, Ji L, Guo L, . Treatment patterns and glycemic control in older adults with type 2 diabetes mellitus receiving only oral antidiabetes drugs in China. Diabetes Technol Ther. 2015 Nov;17(11):816–24. doi: 10.1089/dia.2015.0094. PMID: 26448574. Exclusion Code: X8.26448574
2867 Zhang M, Zhu Y, Li P, . Associations between dietary patterns and impaired fasting glucose in Chinese men: a cross-sectional study. Nutrients. 2015 Sep 21;7(9):8072–89. doi: 10.3390/nu7095382. PMID: 26402695. Exclusion Code: X8.26402695
2868 Zhang P, Hire D, Espeland MA, . Impact of intensive lifestyle intervention on preference-based quality of life in type 2 diabetes: Results from the Look AHEAD trial. Obesity (Silver Spring). 2016 Apr;24(4):856–64. doi: 10.1002/oby.21445. PMID: 27028282. Exclusion Code: X2.27028282
2869 Zhang Q, Dou J, Lu J. Combinational therapy with metformin and sodium-glucose cotransporter inhibitors in management of type 2 diabetes: systematic review and meta-analyses. Diabetes Res Clin Pract. 2014 Sep;105(3):313–21. doi: 10.1016/j.diabres.2014.06.006. PMID: 25015317. Exclusion Code: X8.25015317
2870 Zhang Q, Dou J, Lu J. Combinational therapy with metformin and sodium-glucose cotransporter inhibitors in management of type 2 diabetes: systematic review and meta-analyses (Structured abstract). Database of Abstracts of Reviews of Effects. 2014(2):313–21. PMID: DARE-12014045647. Exclusion Code: X8.
2871 Zhang R, Cheng K, Xu S, . Metformin and diammonium glycyrrhizinate enteric-coated capsule versus metformin alone versus diammonium glycyrrhizinate enteric-coated capsule alone in patients with nonalcoholic fatty liver disease and type 2 diabetes mellitus. Gastroenterology research and practice. 2017;2017(no pagination)doi: 10.1155/2017/8491742. PMID: CN-01341244. Exclusion Code: X4.
2872 Zhang W, Luan Y, Jin C, . The impact of rosuvastatin on the density score of coronary artery calcification in coronary artery disease patients with type 2 diabetes mellitus: Rationale and design of RosCal Study. Clin Drug Investig. 2016 Dec;36(12):1023–9. doi: 10.1007/s40261-016-0445-4. PMID: 27541380. Exclusion Code: X6.27541380
2873 Zhang X, Imperatore G, Thomas W, . Effect of lifestyle interventions on glucose regulation among adults without impaired glucose tolerance or diabetes: A systematic review and meta-analysis. Diabetes Res Clin Pract. 2017 Jan;123:149–64. doi: 10.1016/j.diabres.2016.11.020. PMID: 28024276. Exclusion Code: X8.28024276
2874 Zhang XM, Li PF, Hou JN, . Blood glucose profiles in East Asian and Caucasian injection-naive patients with type 2 diabetes inadequately controlled on oral medication: a pooled analysis. Diabetes Metab Res Rev. 2018 Nov;34(8):e3062. doi: 10.1002/dmrr.3062. PMID: 30112855. Exclusion Code: X8.30112855
2875 Zhang Y, Chu L. Effectiveness of Systematic Health Education Model for Type 2 Diabetes Patients. Int J Endocrinol. 2018;2018doi: 10.1155/2018/6530607. PMID: CN-01710963. Exclusion Code: X2.
2876 Zhang Y, Ning F, Sun J, . Impact of a diabetes screening program on a rural Chinese population: a 3-year follow-up study. BMC Public Health. 2015 Feb 27;15:198. doi: 10.1186/s12889-015-1570-3. PMID: 25881270. Exclusion Code: X8.25881270
2877 Zhang Y, Sun J, Pang Z, . The impact of new screen-detected and previously known type 2 diabetes on health-related quality of life: a population-based study in Qingdao, China. Qual Life Res. 2014 Oct;23(8):2319–26. doi: 10.1007/s11136-014-0674-z. PMID: 24676896. Exclusion Code: X8.24676896
2878 Zhang Z, Chen X, Lu P, . Incretin-based agents in type 2 diabetic patients at cardiovascular risk: compare the effect of GLP-1 agonists and DPP-4 inhibitors on cardiovascular and pancreatic outcomes. Cardiovasc Diabetol. 2017;16(1) (no pagination)doi: 10.1186/s12933-017-0512-z. PMID: CN-01335417. Exclusion Code: X8.
2879 Zhao FF, Suhonen R, Koskinen S, . Theory-based self-management educational interventions on patients with type 2 diabetes: a systematic review and meta-analysis of randomized controlled trials. J Adv Nurs. 2017 Apr;73(4):812–33. doi: 10.1111/jan.13163. PMID: 27681948. Exclusion Code: X8.27681948
2880 Zhao L, Zhang F, Ding X, . Gut bacteria selectively promoted by dietary fibers alleviate type 2 diabetes. Science (new york, N.Y.). 2018;359(6380):1151–6. doi: 10.1126/science.aao5774. PMID: CN-01464009. Exclusion Code: X6.
2881 Zhao SJ, Zhong ZS, Qi GX, . Effect of pioglitazone in preventing in-stent restenosis after percutaneous coronary intervention in patients with type 2 diabetes: a meta-analysis. PLoS One. 2016;11(5):e0155273. doi: 10.1371/journal.pone.0155273. PMID: 27163676. Exclusion Code: X8.27163676
2882 Zhao X, Li Y, Chen M, . Effects of different doses of metformin treatment for 6 months on aberrant crypt foci in Chinese patients with impaired glucose tolerance. Eur J Cancer Prev. 2015 Jan;24(1):27–36. doi: 10.1097/cej.0000000000000078. PMID: 25162967. Exclusion Code: X6.25162967
2883 Zheng F, Liu S, Liu Y, . Effects of an Outpatient Diabetes Self-Management Education on Patients with Type 2 Diabetes in China: A Randomized Controlled Trial. J Diabetes Res. 2019;2019:1073131. doi: 10.1155/2019/1073131. PMID: 30800684. Exclusion Code: X6.30800684
2884 Zheng Y, Ceglarek U, Huang T, . Plasma taurine, diabetes genetic predisposition, and changes of insulin sensitivity in response to weight-loss diets. Journal of clinical endocrinology and metabolism. 2016;101(10):3820–6. doi: 10.1210/jc.2016-1760. PMID: CN-01382557. Exclusion Code: X6.27466884
2885 Zhiyuan W, Ming Y, Jie J, . Effect of transcutaneous electrical nerve stimulation at acupoints on patients with type 2 diabetes mellitus: a randomized controlled trial. Journal of traditional chinese medicine = chung i tsa chih ying wen pan. 2015;35(2):134–40. PMID: CN-01105977. Exclusion Code: X2.25975045
2886 Zhong VW, Juhaeri J, Cole SR, . Incidence and trends in hypoglycemia hospitalization in adults with type 1 and type 2 diabetes in England, 1998-2013: a retrospective cohort study. Diabetes Care. 2017 Dec;40(12):1651–60. doi: 10.2337/dc16-2680. PMID: 28716781. Exclusion Code: X8.28716781
2887 Zhong X, Zhang T, Liu Y, . Effects of three injectable antidiabetic agents on glycaemic control, weight change and drop-out in type 2 diabetes suboptimally controlled with metformin and/or a sulfonylurea: A network meta-analysis. Diabetes Res Clin Pract. 2015 Sep;109(3):451–60. doi: 10.1016/j.diabres.2015.05.048. PMID: 26233934. Exclusion Code: X8.26233934
2888 Zhou J, Zheng F, Guo X, . Glargine insulin/gliclazide MR combination therapy is more effective than premixed insulin monotherapy in Chinese patients with type 2 diabetes inadequately controlled on oral antidiabetic drugs. Diabetes Metab Res Rev. 2015 Oct;31(7):725–33. doi: 10.1002/dmrr.2661. PMID: 25952634. Exclusion Code: X5.25952634
2889 Zhou JJ, Koska J, Bahn G, . Glycaemic variation is a predictor of all-cause mortality in the Veteran Affairs Diabetes Trial. Diab Vasc Dis Res. 2019 Mar;16(2):178–85. doi: 10.1177/1479164119827598. PMID: 31014099. Exclusion Code: X2.31014099
2890 Zhou L, Cai X, Yang W, . The magnitude of weight loss induced by metformin is independently associated with BMI at baseline in newly diagnosed type 2 diabetes: Post-hoc analysis from data of a phase IV open-labeled trial. Adv Clin Exp Med. 2017 Jul;26(4):671–7. doi: 10.17219/acem/63025. PMID: 28691423. Exclusion Code: X6.28691423
2891 Zhou L, Liu H, Wen X, . Effects of metformin on blood pressure in nondiabetic patients: a meta-analysis of randomized controlled trials. J Hypertens. 2017 Jan;35(1):18–26. doi: 10.1097/hjh.0000000000001119. PMID: 27607453. Exclusion Code: X8.27607453
2892 Zhou M, Wang SV, Leonard CE, . Sentinel modular program for propensity score-matched cohort analyses: application to glyburide, glipizide, and serious hypoglycemia. Epidemiology. 2017 Nov;28(6):838–46. doi: 10.1097/ede.0000000000000709. PMID: 28682851. Exclusion Code: X5.28682851
2893 Zhu D, Gan S, Liu Y, . Pharmacodynamic subgroup analysis of glucose kinase activator (GKA) after 12 weeks of treatment with HMS5552 in T2DM patients in China. Diabetes/metabolism research and reviews. Conference: 21st scientific meeting of the chinese diabetes society. China. 2017;33(Supplement 1)doi: 10.1002/dmrr.2947. PMID: CN-01431754. Exclusion Code: X2.
2894 Zhu D, Gan S, Liu Y, . Dorzagliatin monotherapy in Chinese patients with type 2 diabetes: a dose-ranging, randomised, double-blind, placebo-controlled, phase 2 study. Lancet Diabetes Endocrinol. 2018 Aug;6(8):627–36. doi: 10.1016/s2213-8587(18)30105-0. PMID: 29735394. Exclusion Code: X2.29735394
2895 Zhu H, Chen X, Cai G, . Telmisartan combined with probucol effectively reduces urinary protein in patients with type 2 diabetes: A randomized double-blind placebo-controlled multicenter clinical study. J Diabetes. 2016 Sep;8(5):677–85. doi: 10.1111/1753-0407.12347. PMID: 26458146. Exclusion Code: X5.26458146
2896 Zhu Q, Qi X, Wu Y, . Clinical study of total glucosides of paeony for the treatment of diabetic kidney disease in patients with diabetes mellitus. Int Urol Nephrol. 2016 Nov;48(11):1873–80. doi: 10.1007/s11255-016-1345-5. PMID: 27342654. Exclusion Code: X2.27342654
2897 Ziegler D, Low PA, Freeman R, . Predictors of improvement and progression of diabetic polyneuropathy following treatment with alpha-lipoic acid for 4 years in the NATHAN 1 trial. J Diabetes Complications. 2016 Mar;30(2):350–6. doi: 10.1016/j.jdiacomp.2015.10.018. PMID: 26651260. Exclusion Code: X2.26651260
2898 Zigmont VA, Shoben AB, Kaye GL, . An Evaluation of Reach for a Work Site Implementation of the National Diabetes Prevention Program Focusing on Diet and Exercise. Am J Health Promot. 2018 Jul;32(6):1417–24. doi: 10.1177/0890117117733348. PMID: 28990395. Exclusion Code: X8.28990395
2899 Zilberman-Kravits D, Meyerstein N, Abu-Rabia Y, . The Impact of a Cultural Lifestyle Intervention on Metabolic Parameters After Gestational Diabetes Mellitus A Randomized Controlled Trial. Matern Child Health J. 2018 Jun;22(6):803–11. doi: 10.1007/s10995-018-2450-0. PMID: 29411251. Exclusion Code: X2.29411251
2900 Zilliox L, Kumar P, Russell J. A randomized, blinded, lifestyle intervention study improves the expiration: inspiration ration in diabetic neuropathy. J Peripher Nerv Syst. 2018;23(4):329–30. doi: 10.1111/jns.12290. PMID: CN-01735426. Exclusion Code: X6.
2901 Zilliox L, Morado M, Kumar P, . A randomized, blinded, parallel group lifestyle intervention study improves the expiration: inspiration ratio in subjects with diabetic neuropathy. Clinical autonomic research. Conference: 28th international symposium on the autonomic nervous system. United states. 2017;27(5):340. doi: 10.1007/s10286-017-0462-2. PMID: CN-01428034. Exclusion Code: X6.
2902 Zimmerman RS, Hobbs TM, Wells BJ, . Association of glucagon-like peptide-1 receptor agonist use and rates of acute myocardial infarction, stroke and overall mortality in patients with type 2 diabetes mellitus in a large integrated health system. Diabetes Obes Metab. 2017 Nov;19(11):1555–61. doi: 10.1111/dom.12969. PMID: 28407414. Exclusion Code: X8.28407414
2903 Zinman B, Marso SP, Christiansen E, . Hypoglycemia, Cardiovascular Outcomes, and Death: The LEADER Experience. Diabetes Care. 2018 Aug;41(8):1783–91. doi: 10.2337/dc17-2677. PMID: 29903847. Exclusion Code: X2.29903847
2904 Zografou I, Sampanis C, Gkaliagkousi E, . Effect of vildagliptin on hsCRP and arterial stiffness in patients with type 2 diabetes mellitus. Hormones (Athens). 2015 Jan–Mar;14(1):118–25. doi: 10.14310/horm.2002.1512. PMID: 25402372. Exclusion Code: X5.25402372
2905 Zong G, Valvi D, Coull B, . Persistent organic pollutants and risk of type 2 diabetes: A prospective investigation among middle-aged women in Nurses’ Health Study II. Environ Int. 2018 May;114:334–42. doi: 10.1016/j.envint.2017.12.010. PMID: 29477570. Exclusion Code: X4.29477570
2906 Zoungas S, Chalmers J, Neal B, . Follow-up of blood-pressure lowering and glucose control in type 2 diabetes. N Engl J Med. 2014 Oct 9;371(15):1392–406. doi: 10.1056/NEJMoa1407963. PMID: 25234206. Exclusion Code: X2.25234206
2907 Zoungas S, de Galan BE, Ninomiya T, . Combined effects of routine blood pressure lowering and intensive glucose control on macrovascular and microvascular outcomes in patients with type 2 diabetes: New results from the ADVANCE trial. Diabetes Care. 2009 Nov;32(11):2068–74. doi: 10.2337/dc09-0959. PMID: 19651921. Exclusion Code: X2.19651921
2908 Zuercher E, Bordet J, Burnand B, . CoDiab-VD: protocol of a prospective population-based cohort study on diabetes care in Switzerland. BMC Health Serv Res. 2015 Aug 14;15:329. doi: 10.1186/s12913-015-0991-0. PMID: 26272346. Exclusion Code: X6.26272346