# Appendix B Additional Methods Information

## Appendix B1 Original Search Strategies

### Screening Searches

PubMed, 6-27-2018

Search | Query | Items Found
#1 | Search (“Diabetes Mellitus, Type 2”[Mesh] OR “Glucose Tolerance”[Mesh] OR “glucose tolerance”[All Fields] OR “impaired glucose tolerance”[All Fields] OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance”[MeSH] OR “glucose intolerance”[All Fields] OR “Prediabetic State”[MeSH] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “diabetes mellitus type 2”[All Fields] OR “type 2 diabetes mellitus”[All Fields]) | 183989
#2 | Search (“Blood Glucose”[Mesh] OR “blood glucose”[tiab] OR “Glucose Tolerance Test”[Mesh] OR OGTT[tiab] OR “glucose tolerance test”[ti] OR “Glycated Hemoglobin A”[Mesh] OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose”[tiab]) | 224814
#3 | Search (((“HbA(1c)”[tiab] or HbA1[tiab] or HbA1c[tiab] or “HbA 1c”[tiab] or ((glycosylated[tiab] or glycated[tiab]) AND hemoglobin[tiab])))) | 40212
#4 | Search (#2 or #3) | 228775
#5 | Search (#1 and #4) | 84503
#6 | Search (“Mass Screening”[Mesh] OR screen*[tiab]) | 681189
#7 | Search (#5 and #6) | 5301
#8 | Search (#7 NOT (gestation* OR Pregnancy[Mesh])) | 3904
#9 | Search (#7 NOT (gestation* OR Pregnancy[Mesh])) Filters: English | 3536
#10 | Search (#7 NOT (gestation* OR Pregnancy[Mesh])) Filters: English; Adult: 19+ years | 2353
#11 | Search ((#10 AND humans[mesh:noexp]) OR (#10 NOT animals[mesh:noexp])) | 2353
#12 | Search ((#10 AND humans[mesh:noexp]) OR (#10 NOT animals[mesh:noexp])) Filters: Publication date from 2014/01/01 to 2018/12/31 | 651
#13 | Search ((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] OR “meta synthesis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR “cochrane database syst rev”[ta]) | 244004
#14 | Search (#12 and #13) | 12
#15 | Search (((randomized[tiab] OR randomised[tiab]) AND controlled[tiab] AND trial[tiab]) OR (controlled[tiab] AND trial[tiab]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 713625
#16 | Search (#12 and #15) | 87
#17 | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Cross-Sectional Studies”[MeSH] OR “Organizational Case Studies”[MeSH] OR “Cross-Over Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Seroepidemiologic Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “observational study” OR “observational studies”) | 2458093
#18 | Search (#12 and #17) | 387

Cochrane Library, 6-27-2018

ID | Search | Hits
#1 | [mh “Diabetes Mellitus, Type 2”] or [mh “Glucose Tolerance”] or “glucose tolerance” or “impaired glucose tolerance” or IGT or “impaired fasting glucose” or IFG or [mh “Glucose Intolerance”] or “glucose intolerance” or [mh “Prediabetic State”] or “prediabetic state” or prediabet* or “pre diabetes” or “diabetes mellitus type 2” or “type 2 diabetes mellitus” | 25233
#2 | [mh “Blood Glucose”] or “blood glucose”:ti,ab or [mh “Glucose Tolerance Test”] or OGTT:ti,ab or “glucose tolerance test”:ti or [mh “Glycated Hemoglobin A”] or “hemoglobin A1c" or HbA1c or “fasting plasma glucose”:ti,ab | 30959
#3 | (“HbA(1c)”:ti,ab or HbA1:ti,ab or HbA1c:ti,ab or “HbA 1c":ti,ab or ((glycosylated:ti,ab or glycated:ti,ab) and hemoglobin:ti,ab)) | 11067
#4 | #2 or #3 | 31609
#5 | #1 and #4 | 13452
#6 | [mh “Mass Screening”] or screen*:ti,ab | 39953
#7 | #5 and #6 | 639
#8 | #7 not (gestation* or [mh Pregnancy]) | 522
#9 | Adult* | 522081
#10 | #8 and #9 | 323
#11 | (#10 and [mh ^humans]) or (#10 not [mh ^animals]) | 323
#12 | #11 Publication Year from 2014 to 2018 | 133

### Intervention Searches

PubMed, 6-27-2018

Search | Query | Items Found
#1 | Search (“Diabetes Mellitus, Type 2”[Mesh] OR “impaired glucose tolerance”[All Fields] OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance”[MeSH] OR “glucose intolerance”[All Fields] OR “Prediabetic State”[MeSH] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “diabetes mellitus type 2”[All Fields] OR “type 2 diabetes mellitus”[All Fields]) | 152417
#2 | Search (“ACE inhibitor”[tiab] OR “ACE inhibitors”[tiab] OR “Acebutolol”[Mesh] OR Acebutolol[tiab] OR “Adalat CC”[tiab] OR “Adrenergic beta-Antagonists" [Pharmacological Action] OR “Adrenergic beta-Antagonists“[tiab] OR Altoprev[tiab] OR “Afeditab CR”[tiab] OR “Amlodipine”[Mesh] OR “Amlodipine, Valsartan Drug Combination”[Mesh] OR “Amlodipine Besylate, Olmesartan Medoxomil Drug Combination”[Mesh] OR “amlodipine, perindopril drug combination”[Supplementary Concept] OR Amlodipine[tiab] OR “Adrenergic beta-Antagonists”[Mesh] OR “Adrenergic beta-Antagonists”[tiab] OR “angiotensin II receptor blocker”[tiab] OR “angiotensin II receptor blockers”[tiab] OR “Angiotensin-Converting Enzyme Inhibitors”[Mesh] OR “Angiotensin-converting enzyme inhibitor”[tiab] OR “angiotensin-converting enzyme inhibitors”[tiab] OR “Angiotensin-Converting Enzyme Inhibitors”[Pharmacological Action] OR “Angiotensin Receptor Antagonists”[Mesh] OR “Angiotensin Receptor Antagonists”[Pharmacological Action] OR “Angiotensin Receptor Antagonists”[tiab] OR “Antihypertensive Agents”[Mesh] OR “Antihypertensive Agents”[Pharmacological Action] OR “antihypertensive agent”[tiab] OR “antihypertensive agents”[tiab] OR Aspirin[Mesh] OR aspirin[tiab] OR Atenolol[Mesh] OR Atenolol[tiab] OR “Atorvastatin Calcium”[Mesh] OR Atorvastatin[tiab] OR azilsartan [Supplementary Concept] OR “azilsartan medoxomil”[Supplementary Concept] OR azilsartan[tiab] OR benazepril[Supplementary Concept] OR benazepril[tiab] OR “beta blocker”[tiab] OR “beta blockers”[tiab] OR Betapace[tiab] OR Betaxolol[Mesh] OR Betaxolol[tiab] OR “Bezafibrate”[Mesh] OR Bezafibrate[tiab] OR Bisoprolol[Mesh] OR “bisoprolol, hydrochlorothiazide drug combination”[Supplementary Concept] OR Bisoprolol[tiab] OR Bystolic[tiab] OR Calan[tiab] OR “Calcium Channel Blockers”[Mesh] OR “Calcium Channel Blockers”[Pharmacological Action] OR “calcium channel blockers”[tiab] OR candesartan[Supplementary Concept] OR candesartan[tiab] OR Captopril[MeSH] OR Captopril[tiab] OR Cardizem[tiab] OR carvedilol[Supplementary Concept] OR carvedilol[tiab] OR Chlorothiazide[Mesh] OR Chlorothiazide[tiab] OR Chlorthalidone[Mesh] OR Chlorthalidone[tiab] OR Clofenapate[Mesh] OR clofenapate[tiab] OR “Clofibric Acid”[Mesh] OR “Clofibric Acid”[tiab] OR Coreg[tiab] OR Corgard[tiab] OR Crestor[tiab] OR Diltiazem[Mesh] OR Diltiazem[tiab] OR Diuretics[Mesh] OR Diuretics[Pharmacological Action] OR diuretics[tiab] OR Diuril[tiab] OR Enalapril[Mesh] OR Elanapril[tiab] OR Enduron[tiab] OR eprosartan[Supplementary Concept] OR eprosartan[tiab] OR Esidrix[tiab] OR Felodipine[Mesh] OR Felodipine[tiab] OR Fenofibrate[Mesh] OR Fenofibrate[tiab] OR Fosinopril[Mesh] OR fosinopril[tiab] OR fluvastatin[Supplementary Concept] OR fluvastatin[tiab] OR Gemfibrozil[Mesh] OR Gemfibrozil[tiab] OR HCTZ[tiab] OR Hydrochlorothiazide[Mesh] OR Hydrochlorothiazide[tiab] OR Hydrodiuril[tiab] OR “Hydroxymethylglutaryl-CoA Reductase Inhibitors”[Mesh] OR Hygroton[tiab] OR “Hypolipidemic Agents”[Mesh] OR “Hypolipidemic Agents” [Pharmacological Action] OR “hypolipidemic agents”[tiab] OR Indapamide[Mesh] OR Indapamide[tiab] OR “Inderal LA”[tiab] OR “Inderal XL”[tiab] OR irbesartan[Supplementary Concept] OR irbesartan[tiab] OR Isradipine[Mesh] OR Isradipine[tiab] OR Kerlone[tiab] OR Labetalol[Mesh] OR labetalol[tiab] OR Lescol[tiab] OR “Lescol XL”[tiab] OR Levatol[tiab] OR Lipitor[tiab] OR Lisinopril[Mesh] OR Lisinopril[tiab] OR Livalo[tiab] OR Lopressor[tiab] OR Losartan[Mesh] OR Losartan[tiab] OR Lovastatin[MeSH] OR lovastatin[tiab] OR Lozol[tiab] OR Methyclothiazide[Mesh] OR Methyclothiazide[tiab] OR Metoprolol[Mesh] OR Metoprolol[tiab] OR Mevacor[tiab] OR Microzide[tiab] OR moexipril[Supplementary Concept] OR moexipril[tiab] OR Nadolol[Mesh] OR nadolol[tiab] OR Nebivolol[Mesh] OR nebivolol[tiab] OR Nicardipine[Mesh] OR Nicardipine[tiab] OR Nifedipine[Mesh] OR Nifedipine[tiab] OR Nisoldipine[Mesh] OR Nisoldipine[tiab] OR Norvasc[tiab] OR “Olmesartan Medoxomil”[Mesh] OR olmesartan[Supplementary Concept] OR olmesartan[tiab] OR Penbutolol[Mesh] OR penbutolol[tiab] OR Perindopril[Mesh] OR Perindopril[tiab] OR Pindolol[Mesh] OR pindolol[tiab] OR pitavastatin[Supplementary Concept] OR pitavastatin[tiab] OR Pravachol[tiab] OR Pravastatin[MeSH] OR pravastatin[tiab] OR Procardia[tiab] OR Propranolol[Mesh] OR Propranolol[tiab] OR quinapril[Supplementary Concept] OR quinapril[tiab] OR Ramipril[Mesh] OR Ramipril[tiab] OR “Rosuvastatin Calcium”[MeSH Terms] OR rosuvastatin[tiab] OR Sectral[tiab] OR Simvastatin[Mesh] OR simvastatin[tiab] OR Sotalol[Mesh] OR sotalol[tiab] OR statins[tiab] OR Sular[tiab] OR telmisartan[Supplementary Concept] OR telmisartan[tiab] OR Tenormin[tiab] OR Tiazac[tiab] OR Timolol[Mesh] OR timolol[tiab] OR “Toprol XL”[tiab] OR ToprolXL[tiab] OR Trandate[tiab] OR trandolapril[Supplementary Concept] OR trandolapril[tiab] OR Valsartan[Mesh] OR valsartan[tiab] OR Verapamil[Mesh] OR Verapamil[tiab] OR Verelan[tiab] OR Visken[tiab] OR Zebeta[tiab] OR Ziac[tiab] OR Zocor[tiab]) | 664232
#3 | Search (#1 and #2) | 9778
#4 | Search (Actos[tiab] OR Albiglutide[tiab] OR Amaryl[tiab] OR “antidyslipidemic agent”[tiab] OR “antidyslipidemic agents”[tiab] OR Avandia[tiab] OR “beta blocker”[tiab] “beta blockers”[tiab] OR Biguanides[Mesh] OR Biguanides[tiab] OR Bydureon[tiab] OR Byetta[tiab] OR DiaBeta[tiab] OR “Dipeptidyl-Peptidase IV Inhibitors”[Mesh] OR “Dipeptidyl-Peptidase IV Inhibitors”[Pharmacological Action] OR “Dipeptidyl peptidase IV inhibitor”[tiab] OR “Dipeptidyl peptidase IV inhibitors”[tiab] OR dulaglutide[Supplementary Concept] OR dulaglutide[tiab] OR exenatide[Supplementary Concept] OR Exenatide[tiab] OR Ezetimibe[Mesh] OR “Ezetimibe, Simvastatin Drug Combination”[Mesh] OR Ezetimibe[tiab] OR Fortamet[tiab] OR Gliclazide[Mesh] OR Gliclazide[tiab] OR glimepiride[tiab] OR Glipizide[Mesh] OR glipizide[tiab] OR “GLP-1 receptor agonist”[tiab] OR “GLP-1 receptor agonists”[tiab] OR “Glucagon-like peptide-1 receptor agonist”[tiab] OR “Glucagon-like peptide-1 receptor agonists”[tiab] OR Glucophage[tiab] OR Glucotrol[tiab] OR “Glucotrol XL”[tiab] OR Glumetza[tiab] OR Glyburide[Mesh] OR glyburide[tiab] OR “Glynase PresTab”[tiab] OR Linagliptin[Mesh] OR Linagliptin[tiab] OR Liraglutide[Mesh] OR liraglutide[tiab] OR lixisenatide[Supplementary Concept] OR lixisenatide[tiab] OR Lyxumia[tiab] OR Meglitinides[tiab] OR Metformin[Mesh] OR Metformin[tiab] OR Micronase[tiab] OR nateglinide[Supplementary Concept] OR Nateglinide[tiab] OR Niacin[Mesh] OR niacin[tiab] OR Ozempic[tiab] OR pioglitazone[Supplementary Concept] OR Pioglitazone[tiab] OR Prandin[tiab] OR Repaglinide[tiab] OR rosiglitazone[Supplementary Concept] OR Rosiglitazone[tiab] OR Saxagliptin[tiab] OR semaglutide[Supplementary Concept] OR semaglutide[tiab] OR Sitagliptin[tiab] OR “Sitagliptin Phosphate”[Mesh] OR “Sitagliptin Phosphate, Metformin Hydrochloride Drug Combination”[Mesh] OR “Sulfonylurea Compounds”[Mesh] OR Starlix[tiab] OR Sulfonylureas[tiab] OR Tanzeum[tiab] OR Thiazolidinediones[Mesh] OR Thiazolidinediones[tiab] OR Tolazamide[Mesh] OR Tolazamide[tiab] OR Tolbutamide[Mesh] OR tolbutamide[tiab] OR Trulicity[tiab] OR TZDs[tiab] OR Victoza[tiab] OR vildagliptin[Supplementary Concept] OR vildagliptin[tiab]) | 88394
#5 | Search (#1 and #4) | 18217
#6 | Search (advice[tiab] OR “Behavior Therapy”[Mesh] OR “behavior therapy”[tiab] OR (behavior*[tiab] AND therap*[tiab]) OR (behavior*[tiab] AND chang*[tiab]) OR (behavior*[tiab] AND modification*[tiab]) OR “Caloric Restriction”[Mesh] OR Counseling[Mesh] OR counsel*[tiab] OR “Diabetes Prevention Program”[tiab] OR “Diabetes Prevention Programme”[tiab] OR DPP[tiab] OR (“Diabetes Prevention”[tiab] AND (program*[tiab] OR stud*[tiab] OR trial*[tiab])) OR diet[ti] OR “Diet, Carbohydrate-Restricted”[Mesh] OR “Diet, Fat-Restricted”[Mesh] OR “Diet, Mediterranean”[Mesh] OR “Diet, Reducing”[Mesh] OR “Diet Therapy”[Mesh] OR dietary[ti] OR “Directive Counseling”[Mesh] OR Exercise[Mesh] OR exercise[ti] OR “Exercise Therapy”[Mesh] OR “Feedback, Psychological”[Mesh] OR “Health Behavior”[Majr] OR “health behavior”[tiab] OR “health behaviors”[tiab] OR “health behavioral”[tiab] “health behaviours”[tiab] OR “health behaviour”[tiab] OR “Health Education”[Mesh] OR “Health Education as Topic”[Mesh] OR “health education”[tiab] OR “Health Promotion”[Majr] OR “health promotion”[tiab] OR “Life Style”[Mesh] OR lifestyle[tiab] OR “life style”[tiab] OR “Lifestyle Intervention”[Mesh] OR “Motivational Interviewing”[Mesh] OR “motivational interviewing”[tiab] OR “non pharmacologic intervention”[tiab] OR “nonpharmacologic intervention”[tiab] OR “Patient Education as Topic”[Mesh] OR “patient education”[tiab] OR “physical activity”[ti] OR “physically active”[ti] OR “psychological feedback”[tiab] OR “Risk Reduction Behavior”[Mesh] OR “Risk Reduction Behavior”[tiab]) | 415785
#7 | Search (#1 and #6) | 13211
#8 | Search (#3 or #5 or #7) | 38015
#9 | Search (#3 or #5 or #7) Filters: English | 34169
#10 | Search (#3 or #5 or #7) Filters: Publication date from 2014/01/01 to 2018/12/31; English | 10761
#11 | Search ((#10 and Humans[Mesh:NOEXP]) OR (#10 not Animals[Mesh:NOEXP])) | 10146
#12 | Search ((#10 and Humans[Mesh:NOEXP]) OR (#10 not Animals[Mesh:NOEXP])) Filters: Adult: 19+ years | 5194
#13 | Search (letter[pt] OR newspaper article[pt] OR editorial[pt] OR comment[pt] OR case reports[pt]) | 3341617
#14 | Search (#12 not #13) | 4961
#15 | Search ((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields]) | 239210
#16 | Search (#14 and #15) | 174
#17 | Search ((randomized[tiab] OR randomised[tiab]) AND controlled[tiab] AND trial[tiab]) OR (controlled[tiab] AND trial[tiab]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 713625
#18 | Search (#14 and #17) | 1703
#19 | Search “Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Cross-Sectional Studies”[MeSH] OR “Organizational Case Studies”[MeSH] OR “Cross-Over Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Seroepidemiologic Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “observational study”[tw] OR “observational studies”[tw] OR cohort[tw] OR compared[tw] OR groups[tw] OR “case control”[tw] OR “cross sectional”[tw] OR multivariate[tw] OR (first[Tiab] AND episode[Tiab]) OR cohort[Tiab])) | 6211555
#20 | Search (#14 and #17) | 4037
#21 | Search (#20 not (#18 or #16)) | 2518

Cochrane Library, 6-27-2018

ID | Search | Hits
#1 | [mh “Diabetes Mellitus, Type 2”] or “impaired glucose tolerance” or IGT or “impaired fasting glucose” or IFG or [mh “Glucose Intolerance”] or “glucose intolerance” or [mh “Prediabetic State”] or “prediabetic state” or prediabet* or “pre diabetes” or “diabetes mellitus type 2” or “type 2 diabetes mellitus” | 22234
#2 | “ACE inhibitor”:ti,ab or “ACE inhibitors”:ti,ab or [mh Acebutolol] or Acebutolol:ti,ab or “Adalat CC”:ti,ab or “Adrenergic beta-Antagonists":ti,ab or Altoprev:ti,ab or “Afeditab CR”:ti,ab or [mh Amlodipine] or [mh “Amlodipine, Valsartan Drug Combination”] or [mh “Amlodipine Besylate, Olmesartan Medoxomil Drug Combination”] or Amlodipine:ti,ab or [mh “Adrenergic beta-Antagonists”] or “Adrenergic beta-Antagonists":ti,ab or “angiotensin II receptor blocker”:ti,ab or “angiotensin II receptor blockers”:ti,ab or [mh “Angiotensin-Converting Enzyme Inhibitors”] or “Angiotensin-converting enzyme inhibitor”:ti,ab or “angiotensin-converting enzyme inhibitors”:ti,ab or [mh “Angiotensin Receptor Antagonists”] or “Angiotensin Receptor Antagonists”:ti,ab or [mh “Antihypertensive Agents”] or “antihypertensive agent”:ti,ab or “antihypertensive agents”:ti,ab or [mh Aspirin] or aspirin:ti,ab or [mh Atenolol] or Atenolol:ti,ab or [mh “Atorvastatin Calcium”] or Atorvastatin:ti,ab or azilsartan:ti,ab or benazepril:ti,ab or “beta blocker”:ti,ab or “beta blockers”:ti,ab or Betapace:ti,ab or [mh Betaxolol] or Betaxolol:ti,ab or [mh Bezafibrate] or Bezafibrate:ti,ab or [mh Bisoprolol] or Bisoprolol:ti,ab or Bystolic:ti,ab or Calan:ti,ab or [mh “Calcium Channel Blockers”] or “calcium channel blockers”:ti,ab or candesartan:ti,ab or [mh Captopril] or Captopril:ti,ab or Cardizem:ti,ab or carvedilol:ti,ab or [mh Chlorothiazide] or Chlorothiazide:ti,ab or [mh Chlorthalidone] or Chlorthalidone:ti,ab or [mh Clofenapate] or clofenapate:ti,ab or [mh “Clofibric Acid”] or “Clofibric Acid”:ti,ab or Coreg:ti,ab or Corgard:ti,ab or Crestor:ti,ab or [mh Diltiazem] or Diltiazem:ti,ab or [mh Diuretics] or diuretics:ti,ab or Diuril:ti,ab or [mh Enalapril] or Elanapril:ti,ab or Enduron:ti,ab or eprosartan:ti,ab or Esidrix:ti,ab or [mh Felodipine] or Felodipine:ti,ab or [mh Fenofibrate] or Fenofibrate:ti,ab or [mh Fosinopril] or fosinopril:ti,ab or fluvastatin:ti,ab or [mh Gemfibrozil] or Gemfibrozil:ti,ab or HCTZ:ti,ab or [mh Hydrochlorothiazide] or Hydrochlorothiazide:ti,ab or Hydrodiuril:ti,ab or [mh “Hydroxymethylglutaryl-CoA Reductase Inhibitors”] or Hygroton:ti,ab or [mh “Hypolipidemic Agents”] or “hypolipidemic agents”:ti,ab or [mh Indapamide] or Indapamide:ti,ab or “Inderal LA”:ti,ab or “Inderal XL”:ti,ab or irbesartan:ti,ab or [mh Isradipine] or Isradipine:ti,ab or Kerlone:ti,ab or [mh Labetalol] or labetalol:ti,ab or Lescol:ti,ab or “Lescol XL”:ti,ab or Levatol:ti,ab or Lipitor:ti,ab or [mh Lisinopril] or Lisinopril:ti,ab or Livalo:ti,ab or Lopressor:ti,ab or [mh Losartan] or Losartan:ti,ab or [mh Lovastatin] or lovastatin:ti,ab or Lozol:ti,ab or [mh Methyclothiazide] or Methyclothiazide:ti,ab or [mh Metoprolol] or Metoprolol:ti,ab or Mevacor:ti,ab or Microzide:ti,ab or moexipril:ti,ab or [mh Nadolol] or nadolol:ti,ab or [mh Nebivolol] or nebivolol:ti,ab or [mh Nicardipine] or Nicardipine:ti,ab or [mh Nifedipine] or Nifedipine:ti,ab or [mh Nisoldipine] or Nisoldipine:ti,ab or Norvasc:ti,ab or [mh “Olmesartan Medoxomil”] or olmesartan:ti,ab or [mh Penbutolol] or penbutolol:ti,ab or [mh Perindopril] or Perindopril:ti,ab or [mh Pindolol] or pindolol:ti,ab or pitavastatin:ti,ab or Pravachol:ti,ab or [mh Pravastatin] or pravastatin:ti,ab or Procardia:ti,ab or [mh Propranolol] or Propranolol:ti,ab or quinapril:ti,ab or [mh Ramipril] or Ramipril:ti,ab or [mh “Rosuvastatin Calcium”] or rosuvastatin:ti,ab or Sectral:ti,ab or [mh Simvastatin] or simvastatin:ti,ab or [mh Sotalol] or sotalol:ti,ab or statins:ti,ab or Sular:ti,ab or telmisartan:ti,ab or Tenormin:ti,ab or Tiazac:ti,ab or [mh Timolol] or timolol:ti,ab or “Toprol XL”:ti,ab or ToprolXL:ti,ab or Trandate:ti,ab or trandolapril:ti,ab or [mh Valsartan] or valsartan:ti,ab or [mh Verapamil] or Verapamil:ti,ab or Verelan:ti,ab or Visken:ti,ab or Zebeta:ti,ab or Ziac:ti,ab or Zocor:ti,ab | 68414
#3 | #1 and #2 | 2557
#4 | Actos:ti,ab or Albiglutide:ti,ab or Amaryl:ti,ab or “antidyslipidemic agent”:ti,ab or “antidyslipidemic agents”:ti,ab or Avandia:ti,ab or “beta blocker”:ti,ab “beta blockers”:ti,ab or [mh Biguanides] or Biguanides:ti,ab or Bydureon:ti,ab or Byetta:ti,ab or DiaBeta:ti,ab or [mh “Dipeptidyl-Peptidase IV Inhibitors”] or “Dipeptidyl peptidase IV inhibitor”:ti,ab or “Dipeptidyl peptidase IV inhibitors”:ti,ab or dulaglutide:ti,ab or Exenatide:ti,ab or [mh Ezetimibe] or [mh “Ezetimibe, Simvastatin Drug Combination”] or Ezetimibe:ti,ab or Fortamet:ti,ab or [mh Gliclazide] or Gliclazide:ti,ab or glimepiride:ti,ab or [mh Glipizide] or glipizide:ti,ab or “GLP-1 receptor agonist”:ti,ab or “GLP-1 receptor agonists”:ti,ab or “Glucagon-like peptide-1 receptor agonist”:ti,ab or “Glucagon-like peptide-1 receptor agonists”:ti,ab or Glucophage:ti,ab or Glucotrol:ti,ab or “Glucotrol XL”:ti,ab or Glumetza:ti,ab or [mh Glyburide] or glyburide:ti,ab or “Glynase PresTab”:ti,ab or [mh Linagliptin] or Linagliptin:ti,ab or [mh Liraglutide] or liraglutide:ti,ab or lixisenatide:ti,ab or Lyxumia:ti,ab or Meglitinides:ti,ab or [mh Metformin] or Metformin:ti,ab or Micronase:ti,ab or Nateglinide:ti,ab or [mh Niacin] or niacin:ti,ab or Ozempic:ti,ab or Pioglitazone:ti,ab or Prandin:ti,ab or Repaglinide:ti,ab or Rosiglitazone:ti,ab or Saxagliptin:ti,ab or semaglutide:ti,ab or Sitagliptin:ti,ab or [mh “Sitagliptin Phosphate”] or [mh “Sitagliptin Phosphate, Metformin Hydrochloride Drug Combination”] or [mh “Sulfonylurea Compounds”] or Starlix:ti,ab or Sulfonylureas:ti,ab or Tanzeum:ti,ab or [mh Thiazolidinediones] or Thiazolidinediones:ti,ab or [mh Tolazamide] or Tolazamide:ti,ab or [mh Tolbutamide] or tolbutamide:ti,ab or Trulicity:ti,ab or TZDs:ti,ab or Victoza:ti,ab or vildagliptin:ti,ab | 17545
#5 | #1 and #4 | 6201
#6 | advice:ti,ab or [mh “Behavior Therapy”] or “behavior therapy”:ti,ab or (behavior*:ti,ab and therap*:ti,ab) or (behavior*:ti,ab and chang*:ti,ab) or (behavior*:ti,ab and modification*:ti,ab) or [mh “Caloric Restriction”] or [mh Counseling] or counsel*:ti,ab or “Diabetes Prevention Program”:ti,ab or “Diabetes Prevention Programme”:ti,ab or DPP:ti,ab or (“Diabetes Prevention”:ti,ab and (program*:ti,ab or stud*:ti,ab or trial*:ti,ab)) or diet:ti or [mh “Diet, Carbohydrate-Restricted”] or [mh “Diet, Fat-Restricted”] or [mh “Diet, Mediterranean”] or [mh “Diet, Reducing”] or [mh “Diet Therapy”] or dietary:ti or [mh “Directive Counseling”] or [mh Exercise] or exercise:ti or [mh “Exercise Therapy”] or [mh “Feedback, Psychological”] or [mh “Health Behavior” [mj]] or “health behavior”:ti,ab or “health behaviors”:ti,ab or “health behavioral”:ti,ab “health behaviours”:ti,ab or “health behaviour”:ti,ab or [mh “Health Education”] or [mh “Health Education as Topic”] or “health education”:ti,ab or [mh “Health Promotion” [mj]] or “health promotion”:ti,ab or [mh “Life Style”] or lifestyle:ti,ab or “life style”:ti,ab or [mh “Lifestyle Intervention”] or [mh “Motivational Interviewing”] or “motivational interviewing”:ti,ab or “non pharmacologic intervention”:ti,ab or “nonpharmacologic intervention”:ti,ab or [mh “Patient Education as Topic”] or “patient education”:ti,ab or “physical activity”:ti or “physically active”:ti or “psychological feedback”:ti,ab or [mh “Risk Reduction Behavior”] or “Risk Reduction Behavior”:ti,ab | 130176
#7 | #1 and #6 | 5373
#8 | #3 or #5 or #7 | 12588
#9 | #8 Publication Year from 2014 to 2018 | 4299
#10 | (#9 and [mh ^Humans]) or (#9 not [mh ^Animal]) | 4299
#11 | #10 not (letter:pt or newspaper article:pt or editorial:pt or comment:pt or “case reports”:pt) | 4269
#12 | #11 and adult* (All Cochrane Library results) | 2288

### Prediabetes Search

Cochrane Library, 6-27-2018

ID | Search | Hits
#1 | [mh “Prediabetic State”] or prediabet* or “pre diabetes” in Cochrane Reviews and Other Reviews | 60

### Risk Prediction Systematic Review Search

PubMed, 6-27-2018

Search | Query | Items Found
#1 | Search (“ARIC diabetes risk score” OR “ARIC diabetes risk calculator” OR “Australian Type 2 Diabetes Risk Assessment Tool” OR AUSDRISK OR QDiabetes OR QDScore OR “Cambridge diabetes risk score”[all fields] OR “Cambridge risk score” OR (“Canadian Diabetes Risk Assessment” AND Questionnaire) OR CANRISK OR “Finnish Diabetes Risk Score” OR FINDRISC OR “Leicester Practice Risk Score” OR “QRISK 2”[all fields] OR QRISK2) | 408
#2 | Search (“Diabetes Mellitus, Type 2”[Mesh] OR “Type 2 Diabetes”[ALL FIELDS] OR “Prediabetic State”[MeSH] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “diabetes mellitus type 2”[All Fields] OR “type 2 diabetes mellitus”[All Fields] OR (“diabetes” AND “mellitus” AND “type 2”)) | 163235
#3 | Search (#1 and #2) | 249
#4 | Search “Risk Assessment”[Mesh] OR “risk assessment”[all fields] OR “risk assessments”[all fields] OR “risk score”[all fields] OR “risk scores”[all fields] “risk identification”[all Fields] OR “risk reduction”[all fields] OR “Know Your Risk”[all fields] OR (risk* and (calculator* OR calculation*)) | 39878
#5 | Search (#2 and #4) | 2029
#6 | Search (#3 or #5) | 2243
#7 | Search (#3 or #5) Filters: English | 2111
#8 | Search (#3 or #5) Filters: English; Adult: 19+ years | 1104
#9 | Search (#3 or #5) Filters: Publication date from 2008/06/27 to 2018/12/31; English; Adult: 19+ years | 902
#10 | Search (#9 AND Humans[Mesh:NOEXP]) OR (#9 NOT Animals[Mesh:NOEXP]) | 902
#11 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 239210
#12 | Search (#10 and #11) | 36

### Risk Prediction Search

Cochrane Library, 6-28-2018

ID | Search | Hits
#1 | “ARIC diabetes risk score” or “ARIC diabetes risk calculator” or “Australian Type 2 Diabetes Risk Assessment Tool” or AUSDRISK or QDiabetes or QDScore or “Cambridge Diabetes Risk Score” or “Cambridge risk score” or (“Canadian Diabetes Risk Assessment” and Questionnaire) or CANRISK or “Finnish Diabetes Risk Score” or FINDRISC or “Leicester Practice Risk Score” or “QRISK 2” or QRISK2 | 57
#2 | [mh “Diabetes Mellitus, Type 2”] or “Type 2 Diabetes” or [mh “Prediabetic State”] or “prediabetic state” or prediabet* or “pre diabetes” or “diabetes mellitus type 2” or “type 2 diabetes mellitus” or (“diabetes” and “mellitus” and “type 2”) | 28001
#3 | #1 and #2 | 44
#4 | [mh “Risk Assessment”] or “risk assessment” or “risk assessments” or “risk score” or “risk scores” “risk identification” or “risk reduction” or “Know Your Risk” or (risk* and (calculator* or calculation*)) | 35040
#5 | #2 and #4 | 1832
#6 | #3 or #5 | 1844
#7 | #6 Publication Year from 2008 to 2018 | 1536
#8 | (#7 and [mh ^Humans]) or (#7 not [mh ^Animals]) | 1536
#9 | #8 and Adult* | 1003
#10 | #9 in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 318

### Screening Searches

PubMed, 9-10-2019

Search | Query | Items Found
#1 | Search (“Diabetes Mellitus, Type 2”[Mesh] OR “Glucose Tolerance”[Mesh] OR “glucose tolerance”[All Fields] OR “impaired glucose tolerance”[All Fields] OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance”[MeSH] OR “glucose intolerance”[All Fields] OR “Prediabetic State”[MeSH] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “diabetes mellitus type 2”[All Fields] OR “type 2 diabetes mellitus”[All Fields]) | 200064
#2 | Search (“Blood Glucose”[Mesh] OR “blood glucose”[tiab] OR “Glucose Tolerance Test”[Mesh] OR OGTT[tiab] OR “glucose tolerance test”[ti] OR “Glycated Hemoglobin A”[Mesh] OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose”[tiab]) | 239252
#3 | Search (((“HbA(1c)”[tiab] or HbA1[tiab] or HbA1c[tiab] or “HbA 1c”[tiab] or ((glycosylated[tiab] or glycated[tiab]) AND hemoglobin[tiab])))) | 44994
#4 | Search (#2 OR #3) | 243499
#5 | Search (#1 AND #4) | 90906
#6 | Search (“Mass Screening”[Mesh] OR screen*[tiab]) | 743905
#7 | Search (#5 AND #6) | 5788
#8 | Search (#7 NOT (gestation* OR Pregnancy[Mesh])) | 4275
#9 | Search (#7 NOT (gestation* OR Pregnancy[Mesh])) Filters: English | 3903
#10 | Search (#7 NOT (gestation* OR Pregnancy[Mesh])) Filters: English; Adult: 19+ years | 2575
#11 | Search ((#10 AND humans[mesh:noexp]) OR (#10 NOT animals[mesh:noexp])) | 2575
#12 | Search ((#10 AND humans[mesh:noexp]) OR (#10 NOT animals[mesh:noexp])) Filters: Publication date from 2018/01/01 to 2019/12/31 | 206
#13 | Search ((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] OR “meta synthesis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR “cochrane database syst rev”[ta]) | 286249
#14 | Search (#12 AND #13) | 6
#15 | Search (((randomized[tiab] OR randomised[tiab]) AND controlled[tiab] AND trial[tiab]) OR (controlled[tiab] AND trial[tiab]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | 757903
#16 | Search (#12 AND #15) | 35
#17 | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Cross-Sectional Studies”[MeSH] OR “Organizational Case Studies”[MeSH] OR “Cross-Over Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Seroepidemiologic Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “observational study” OR “observational studies”) | 2664953
#18 | Search (#12 NOT #17) | 89
#19 | Search (#11 AND (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields])) | 1

Cochrane Library, 9-10-2019

ID | Search | Hits
#1 | [mh “Diabetes Mellitus, Type 2”] or [mh “Glucose Tolerance”] or “glucose tolerance” or “impaired glucose tolerance” or IGT or “impaired fasting glucose” or IFG or [mh “Glucose Intolerance”] or “glucose intolerance” or [mh “Prediabetic State”] or “prediabetic state” or prediabet* or “pre diabetes” or “diabetes mellitus type 2” or “type 2 diabetes mellitus” | 30591
#2 | [mh “Blood Glucose”] or “blood glucose”:ti,ab or [mh “Glucose Tolerance Test”] or OGTT:ti,ab or “glucose tolerance test”:ti or [mh “Glycated Hemoglobin A”] or “hemoglobin A1c" or HbA1c or “fasting plasma glucose”:ti,ab | 41937
#3 | (“HbA(1c)”:ti,ab or HbA1:ti,ab or HbA1c:ti,ab or “HbA 1c”:ti,ab or ((glycosylated:ti,ab or glycated:ti,ab) and hemoglobin:ti,ab)) | 19541
#4 | #2 or #3 | 43118
#5 | #1 and #4 | 17573
#6 | [mh “Mass Screening”] or screen*:ti,ab | 61933
#7 | #5 and #6 | 1486
#8 | #7 not (gestation* or [mh Pregnancy]) | 1337
#9 | Adult* | 609506
#10 | #8 and #9 | 609
#11 | (#10 and [mh ^humans]) or (#10 not [mh ^animals]) | 609
#12 | #11 Publication Year from 2018 to 2019 | 336

### Intervention Searches

PubMed, 9-10-2019

Search | Query | Items Found
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Diabetes Mellitus, Type 2”[Mesh] OR “impaired glucose tolerance”[All Fields] OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance”[MeSH] OR “glucose intolerance”[All Fields] OR “Prediabetic State”[MeSH] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “diabetes mellitus type 2”[All Fields] OR “type 2 diabetes mellitus”[All Fields]) | 166921 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “ACE inhibitor”[tiab] OR “ACE inhibitors”[tiab] OR “Acebutolol”[Mesh] OR Acebutolol[tiab] OR “Adalat CC”[tiab] OR “Adrenergic beta-Antagonists" [Pharmacological Action] OR “Adrenergic beta-Antagonists“[tiab] OR Altoprev[tiab] OR “Afeditab CR”[tiab] OR “Amlodipine”[Mesh] OR “Amlodipine, Valsartan Drug Combination”[Mesh] OR “Amlodipine Besylate, Olmesartan Medoxomil Drug Combination”[Mesh] OR “amlodipine, perindopril drug combination”[Supplementary Concept] OR Amlodipine[tiab] OR “Adrenergic beta-Antagonists”[Mesh] OR “Adrenergic beta-Antagonists”[tiab] OR “angiotensin II receptor blocker”[tiab] OR “angiotensin II receptor blockers”[tiab] OR “Angiotensin-Converting Enzyme Inhibitors”[Mesh] OR “Angiotensin-converting enzyme inhibitor”[tiab] OR “angiotensin-converting enzyme inhibitors”[tiab] OR “Angiotensin-Converting Enzyme Inhibitors”[Pharmacological Action] OR “Angiotensin Receptor Antagonists”[Mesh] OR “Angiotensin Receptor Antagonists”[Pharmacological Action] OR “Angiotensin Receptor Antagonists”[tiab] OR “Antihypertensive Agents”[Mesh] OR “Antihypertensive Agents”[Pharmacological Action] OR “antihypertensive agent”[tiab] OR “antihypertensive agents”[tiab] OR Aspirin[Mesh] OR aspirin[tiab] OR Atenolol[Mesh] OR Atenolol[tiab] OR “Atorvastatin Calcium”[Mesh] OR Atorvastatin[tiab] OR azilsartan [Supplementary Concept] OR “azilsartan medoxomil”[Supplementary Concept] OR azilsartan[tiab] OR benazepril[Supplementary Concept] OR benazepril[tiab] OR “beta blocker”[tiab] OR “beta blockers”[tiab] OR Betapace[tiab] OR Betaxolol[Mesh] OR Betaxolol[tiab] OR “Bezafibrate”[Mesh] OR Bezafibrate[tiab] OR Bisoprolol[Mesh] OR “bisoprolol, hydrochlorothiazide drug combination”[Supplementary Concept] OR Bisoprolol[tiab] OR Bystolic[tiab] OR Calan[tiab] OR “Calcium Channel Blockers”[Mesh] OR “Calcium Channel Blockers”[Pharmacological Action] OR “calcium channel blockers”[tiab] OR candesartan[Supplementary Concept] OR candesartan[tiab] OR Captopril[MeSH] OR Captopril[tiab] OR Cardizem[tiab] OR carvedilol[Supplementary Concept] OR carvedilol[tiab] OR Chlorothiazide[Mesh] OR Chlorothiazide[tiab] OR Chlorthalidone[Mesh] OR Chlorthalidone[tiab] OR Clofenapate[Mesh] OR clofenapate[tiab] OR “Clofibric Acid”[Mesh] OR “Clofibric Acid”[tiab] OR Coreg[tiab] OR Corgard[tiab] OR Crestor[tiab] OR Diltiazem[Mesh] OR Diltiazem[tiab] OR Diuretics[Mesh] OR Diuretics[Pharmacological Action] OR diuretics[tiab] OR Diuril[tiab] OR Enalapril[Mesh] OR Elanapril[tiab] OR Enduron[tiab] OR eprosartan[Supplementary Concept] OR eprosartan[tiab] OR Esidrix[tiab] OR Felodipine[Mesh] OR Felodipine[tiab] OR Fenofibrate[Mesh] OR Fenofibrate[tiab] OR Fosinopril[Mesh] OR fosinopril[tiab] OR fluvastatin[Supplementary Concept] OR fluvastatin[tiab] OR Gemfibrozil[Mesh] OR Gemfibrozil[tiab] OR HCTZ[tiab] OR Hydrochlorothiazide[Mesh] OR Hydrochlorothiazide[tiab] OR Hydrodiuril[tiab] OR “Hydroxymethylglutaryl-CoA Reductase Inhibitors”[Mesh] OR Hygroton[tiab] OR “Hypolipidemic Agents”[Mesh] OR “Hypolipidemic Agents” [Pharmacological Action] OR “hypolipidemic agents”[tiab] OR Indapamide[Mesh] OR Indapamide[tiab] OR “Inderal LA”[tiab] OR “Inderal XL”[tiab] OR irbesartan[Supplementary Concept] OR irbesartan[tiab] OR Isradipine[Mesh] OR Isradipine[tiab] OR Kerlone[tiab] OR Labetalol[Mesh] OR labetalol[tiab] OR Lescol[tiab] OR “Lescol XL”[tiab] OR Levatol[tiab] OR Lipitor[tiab] OR Lisinopril[Mesh] OR Lisinopril[tiab] OR Livalo[tiab] OR Lopressor[tiab] OR Losartan[Mesh] OR Losartan[tiab] OR Lovastatin[MeSH] OR lovastatin[tiab] OR Lozol[tiab] OR Methyclothiazide[Mesh] OR Methyclothiazide[tiab] OR Metoprolol[Mesh] OR Metoprolol[tiab] OR Mevacor[tiab] OR Microzide[tiab] OR moexipril[Supplementary Concept] OR moexipril[tiab] OR Nadolol[Mesh] OR nadolol[tiab] OR Nebivolol[Mesh] OR nebivolol[tiab] OR Nicardipine[Mesh] OR Nicardipine[tiab] OR Nifedipine[Mesh] OR Nifedipine[tiab] OR Nisoldipine[Mesh] OR Nisoldipine[tiab] OR Norvasc[tiab] OR “Olmesartan Medoxomil”[Mesh] OR olmesartan[Supplementary Concept] OR olmesartan[tiab] OR Penbutolol[Mesh] OR penbutolol[tiab] OR Perindopril[Mesh] OR Perindopril[tiab] OR Pindolol[Mesh] OR pindolol[tiab] OR pitavastatin[Supplementary Concept] OR pitavastatin[tiab] OR Pravachol[tiab] OR Pravastatin[MeSH] OR pravastatin[tiab] OR Procardia[tiab] OR Propranolol[Mesh] OR Propranolol[tiab] OR quinapril[Supplementary Concept] OR quinapril[tiab] OR Ramipril[Mesh] OR Ramipril[tiab] OR “Rosuvastatin Calcium”[MeSH Terms] OR rosuvastatin[tiab] OR Sectral[tiab] OR Simvastatin[Mesh] OR simvastatin[tiab] OR Sotalol[Mesh] OR sotalol[tiab] OR statins[tiab] OR Sular[tiab] OR telmisartan[Supplementary Concept] OR telmisartan[tiab] OR Tenormin[tiab] OR Tiazac[tiab] OR Timolol[Mesh] OR timolol[tiab] OR “Toprol XL”[tiab] OR ToprolXL[tiab] OR Trandate[tiab] OR trandolapril[Supplementary Concept] OR trandolapril[tiab] OR Valsartan[Mesh] OR valsartan[tiab] OR Verapamil[Mesh] OR Verapamil[tiab] OR Verelan[tiab] OR Visken[tiab] OR Zebeta[tiab] OR Ziac[tiab] OR Zocor[tiab] | 685376 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) | 10308 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Actos[tiab] OR Albiglutide[tiab] OR Amaryl[tiab] OR “antidyslipidemic agent”[tiab] OR “antidyslipidemic agents”[tiab] OR Avandia[tiab] OR “beta blocker”[tiab] “beta blockers”[tiab] OR Biguanides[Mesh] OR Biguanides[tiab] OR Bydureon[tiab] OR Byetta[tiab] OR DiaBeta[tiab] OR “Dipeptidyl-Peptidase IV Inhibitors”[Mesh] OR “Dipeptidyl-Peptidase IV Inhibitors”[Pharmacological Action] OR “Dipeptidyl peptidase IV inhibitor”[tiab] OR “Dipeptidyl peptidase IV inhibitors”[tiab] OR dulaglutide[Supplementary Concept] OR dulaglutide[tiab] OR exenatide[Supplementary Concept] OR Exenatide[tiab] OR Ezetimibe[Mesh] OR “Ezetimibe, Simvastatin Drug Combination”[Mesh] OR Ezetimibe[tiab] OR Fortamet[tiab] OR Gliclazide[Mesh] OR Gliclazide[tiab] OR glimepiride[tiab] OR Glipizide[Mesh] OR glipizide[tiab] OR “GLP-1 receptor agonist”[tiab] OR “GLP-1 receptor agonists”[tiab] OR “Glucagon-like peptide-1 receptor agonist”[tiab] OR “Glucagon-like peptide-1 receptor agonists”[tiab] OR Glucophage[tiab] OR Glucotrol[tiab] OR “Glucotrol XL”[tiab] OR Glumetza[tiab] OR Glyburide[Mesh] OR glyburide[tiab] OR “Glynase PresTab”[tiab] OR Linagliptin[Mesh] OR Linagliptin[tiab] OR Liraglutide[Mesh] OR liraglutide[tiab] OR lixisenatide[Supplementary Concept] OR lixisenatide[tiab] OR Lyxumia[tiab] OR Meglitinides[tiab] OR Metformin[Mesh] OR Metformin[tiab] OR Micronase[tiab] OR nateglinide[Supplementary Concept] OR Nateglinide[tiab] OR Niacin[Mesh] OR niacin[tiab] OR Ozempic[tiab] OR pioglitazone[Supplementary Concept] OR Pioglitazone[tiab] OR Prandin[tiab] OR Repaglinide[tiab] OR rosiglitazone[Supplementary Concept] OR Rosiglitazone[tiab] OR Saxagliptin[tiab] OR semaglutide[Supplementary Concept] OR semaglutide[tiab] OR Sitagliptin[tiab] OR “Sitagliptin Phosphate”[Mesh] OR “Sitagliptin Phosphate, Metformin Hydrochloride Drug Combination”[Mesh] OR “Sulfonylurea Compounds”[Mesh] OR Starlix[tiab] OR Sulfonylureas[tiab] OR Tanzeum[tiab] OR Thiazolidinediones[Mesh] OR Thiazolidinediones[tiab] OR Tolazamide[Mesh] OR Tolazamide[tiab] OR Tolbutamide[Mesh] OR tolbutamide[tiab] OR Trulicity[tiab] OR TZDs[tiab] OR Victoza[tiab] OR vildagliptin[Supplementary Concept] OR vildagliptin[tiab]) | 94774 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #4) | 20097 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (advice[tiab] OR “Behavior Therapy”[Mesh] OR “behavior therapy”[tiab] OR (behavior*[tiab] AND therap*[tiab]) OR (behavior*[tiab] AND chang*[tiab]) OR (behavior*[tiab] AND modification*[tiab]) OR “Caloric Restriction”[Mesh] OR Counseling[Mesh] OR counsel*[tiab] OR “Diabetes Prevention Program”[tiab] OR “Diabetes Prevention Programme”[tiab] OR DPP[tiab] OR (“Diabetes Prevention”[tiab] AND (program*[tiab] OR stud*[tiab] OR trial*[tiab])) OR diet[ti] OR “Diet, Carbohydrate-Restricted”[Mesh] OR “Diet, Fat-Restricted”[Mesh] OR “Diet, Mediterranean”[Mesh] OR “Diet, Reducing”[Mesh] OR “Diet Therapy”[Mesh] OR dietary[ti] OR “Directive Counseling”[Mesh] OR Exercise[Mesh] OR exercise[ti] OR “Exercise Therapy”[Mesh] OR “Feedback, Psychological”[Mesh] OR “Health Behavior”[Majr] OR “health behavior”[tiab] OR “health behaviors”[tiab] OR “health behavioral”[tiab] “health behaviours”[tiab] OR “health behaviour”[tiab] OR “Health Education”[Mesh] OR “Health Education as Topic”[Mesh] OR “health education”[tiab] OR “Health Promotion”[Majr] OR “health promotion”[tiab] OR “Life Style”[Mesh] OR lifestyle[tiab] OR “life style”[tiab] OR “Lifestyle Intervention”[Mesh] OR “Motivational Interviewing”[Mesh] OR “motivational interviewing”[tiab] OR “non pharmacologic intervention”[tiab] OR “nonpharmacologic intervention”[tiab] OR “Patient Education as Topic”[Mesh] OR “patient education”[tiab] OR “physical activity”[ti] OR “physically active”[ti] OR “psychological feedback”[tiab] OR “Risk Reduction Behavior”[Mesh] OR “Risk Reduction Behavior”[tiab]) | 445942 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #6) | 14598 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 OR #5 OR #7) | 41546 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 OR #5 OR #7) Filters: English | 37550 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 OR #5 OR #7) Filters: Publication date from 2018/01/01 to 2019/12/31; English | 3822 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#10 and Humans[Mesh:NOEXP]) OR (#10 not Animals[Mesh:NOEXP])) | 3619 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#10 and Humans[Mesh:NOEXP]) OR (#10 not Animals[Mesh:NOEXP])) Filters: Adult: 19+ years | 1449 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (letter[pt] OR newspaper article[pt] OR editorial[pt] OR comment[pt] OR case reports[pt]) | 3613181 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 NOT #13) | 1379 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields]) | 285477 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 AND #15) | 60 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((randomized[tiab] OR randomised[tiab]) AND controlled[tiab] AND trial[tiab]) OR (controlled[tiab] AND trial[tiab]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] | 757903 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 AND #17) | 418 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Case-Control Studies”[MeSH] OR “Cohort Studies”[MeSH] OR “Cross-Sectional Studies”[MeSH] OR “Organizational Case Studies”[MeSH] OR “Cross-Over Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Seroepidemiologic Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “observational study”[tw] OR “observational studies”[tw] OR cohort[tw] OR compared[tw] OR groups[tw] OR “case control”[tw] OR “cross sectional”[tw] OR multivariate[tw] OR (first[Tiab] AND episode[Tiab]) OR cohort[Tiab])) | 6724215 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 AND #19) | 1097 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#20 NOT (#18 OR #16)) | 717 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#9 AND (“retraction”[All Fields] OR “Retracted Publication”[pt] OR Duplicate Publication [PT] OR Erratum[All Fields])) | 27 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((#22 and Humans[Mesh:NOEXP]) OR (#22 not Animals[Mesh:NOEXP]))) | 25 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#21 OR #18 OR #16) AND #23) One retraction was among new update search results Jung 2018 | 1 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)

Cochrane Library, 9-10-2019

ID | Search | Hits
#1 | [mh “Diabetes Mellitus, Type 2”] or “impaired glucose tolerance” or IGT or “impaired fasting glucose” or IFG or [mh “Glucose Intolerance”] or “glucose intolerance” or [mh “Prediabetic State”] or “prediabetic state” or prediabet* or “pre diabetes” or “diabetes mellitus type 2” or “type 2 diabetes mellitus” | 26772
#2 | “ACE inhibitor”:ti,ab or “ACE inhibitors”:ti,ab or [mh Acebutolol] or Acebutolol:ti,ab or “Adalat CC”:ti,ab or “Adrenergic beta-Antagonists”:ti,ab or Altoprev:ti,ab or “Afeditab CR”:ti,ab or [mh Amlodipine] or [mh “Amlodipine, Valsartan Drug Combination”] or [mh “Amlodipine Besylate, Olmesartan Medoxomil Drug Combination”] or Amlodipine:ti,ab or [mh “Adrenergic beta-Antagonists”] or “Adrenergic beta-Antagonists”:ti,ab or “angiotensin II receptor blocker”:ti,ab or “angiotensin II receptor blockers”:ti,ab or [mh “Angiotensin-Converting Enzyme Inhibitors”] or “Angiotensin-converting enzyme inhibitor”:ti,ab or “angiotensin-converting enzyme inhibitors”:ti,ab or [mh “Angiotensin Receptor Antagonists”] or “Angiotensin Receptor Antagonists”:ti,ab or [mh “Antihypertensive Agents”] or “antihypertensive agent”:ti,ab or “antihypertensive agents”:ti,ab or [mh Aspirin] or aspirin:ti,ab or [mh Atenolol] or Atenolol:ti,ab or [mh “Atorvastatin Calcium”] or Atorvastatin:ti,ab or azilsartan:ti,ab or benazepril:ti,ab or “beta blocker”:ti,ab or “beta blockers”:ti,ab or Betapace:ti,ab or [mh Betaxolol] or Betaxolol:ti,ab or [mh Bezafibrate] or Bezafibrate:ti,ab or [mh Bisoprolol] or Bisoprolol:ti,ab or Bystolic:ti,ab or Calan:ti,ab or [mh “Calcium Channel Blockers”] or “calcium channel blockers”:ti,ab or candesartan:ti,ab or [mh Captopril] or Captopril:ti,ab or Cardizem:ti,ab or carvedilol:ti,ab or [mh Chlorothiazide] or Chlorothiazide:ti,ab or [mh Chlorthalidone] or Chlorthalidone:ti,ab or [mh Clofenapate] or clofenapate:ti,ab or [mh “Clofibric Acid”] or “Clofibric Acid”:ti,ab or Coreg:ti,ab or Corgard:ti,ab or Crestor:ti,ab or [mh Diltiazem] or Diltiazem:ti,ab or [mh Diuretics] or diuretics:ti,ab or Diuril:ti,ab or [mh Enalapril] or Elanapril:ti,ab or Enduron:ti,ab or eprosartan:ti,ab or Esidrix:ti,ab or [mh Felodipine] or Felodipine:ti,ab or [mh Fenofibrate] or Fenofibrate:ti,ab or [mh Fosinopril] or fosinopril:ti,ab or fluvastatin:ti,ab or [mh Gemfibrozil] or Gemfibrozil:ti,ab or HCTZ:ti,ab or [mh Hydrochlorothiazide] or Hydrochlorothiazide:ti,ab or Hydrodiuril:ti,ab or [mh “Hydroxymethylglutaryl-CoA Reductase Inhibitors”] or Hygroton:ti,ab or [mh “Hypolipidemic Agents”] or “hypolipidemic agents”:ti,ab or [mh Indapamide] or Indapamide:ti,ab or “Inderal LA”:ti,ab or “Inderal XL”:ti,ab or irbesartan:ti,ab or [mh Isradipine] or Isradipine:ti,ab or Kerlone:ti,ab or [mh Labetalol] or labetalol:ti,ab or Lescol:ti,ab or “Lescol XL”:ti,ab or Levatol:ti,ab or Lipitor:ti,ab or [mh Lisinopril] or Lisinopril:ti,ab or Livalo:ti,ab or Lopressor:ti,ab or [mh Losartan] or Losartan:ti,ab or [mh Lovastatin] or lovastatin:ti,ab or Lozol:ti,ab or [mh Methyclothiazide] or Methyclothiazide:ti,ab or [mh Metoprolol] or Metoprolol:ti,ab or Mevacor:ti,ab or Microzide:ti,ab or moexipril:ti,ab or [mh Nadolol] or nadolol:ti,ab or [mh Nebivolol] or nebivolol:ti,ab or [mh Nicardipine] or Nicardipine:ti,ab or [mh Nifedipine] or Nifedipine:ti,ab or [mh Nisoldipine] or Nisoldipine:ti,ab or Norvasc:ti,ab or [mh “Olmesartan Medoxomil”] or olmesartan:ti,ab or [mh Penbutolol] or penbutolol:ti,ab or [mh Perindopril] or Perindopril:ti,ab or [mh Pindolol] or pindolol:ti,ab or pitavastatin:ti,ab or Pravachol:ti,ab or [mh Pravastatin] or pravastatin:ti,ab or Procardia:ti,ab or [mh Propranolol] or Propranolol:ti,ab or quinapril:ti,ab or [mh Ramipril] or Ramipril:ti,ab or [mh “Rosuvastatin Calcium”] or rosuvastatin:ti,ab or Sectral:ti,ab or [mh Simvastatin] or simvastatin:ti,ab or [mh Sotalol] or sotalol:ti,ab or statins:ti,ab or Sular:ti,ab or telmisartan:ti,ab or Tenormin:ti,ab or Tiazac:ti,ab or [mh Timolol] or timolol:ti,ab or “Toprol XL”:ti,ab or ToprolXL:ti,ab or Trandate:ti,ab or trandolapril:ti,ab or [mh Valsartan] or valsartan:ti,ab or [mh Verapamil] or Verapamil:ti,ab or Verelan:ti,ab or Visken:ti,ab or Zebeta:ti,ab or Ziac:ti,ab or Zocor:ti,ab | 77302
#3 | #1 and #2 | 2871
#4 | Actos:ti,ab or Albiglutide:ti,ab or Amaryl:ti,ab or “antidyslipidemic agent”:ti,ab or “antidyslipidemic agents”:ti,ab or Avandia:ti,ab or “beta blocker”:ti,ab “beta blockers”:ti,ab or [mh Biguanides] or Biguanides:ti,ab or Bydureon:ti,ab or Byetta:ti,ab or DiaBeta:ti,ab or [mh “Dipeptidyl-Peptidase IV Inhibitors”] or “Dipeptidyl peptidase IV inhibitor”:ti,ab or “Dipeptidyl peptidase IV inhibitors”:ti,ab or dulaglutide:ti,ab or Exenatide:ti,ab or [mh Ezetimibe] or [mh “Ezetimibe, Simvastatin Drug Combination”] or Ezetimibe:ti,ab or Fortamet:ti,ab or [mh Gliclazide] or Gliclazide:ti,ab or glimepiride:ti,ab or [mh Glipizide] or glipizide:ti,ab or “GLP-1 receptor agonist”:ti,ab or “GLP-1 receptor agonists”:ti,ab or “Glucagon-like peptide-1 receptor agonist”:ti,ab or “Glucagon-like peptide-1 receptor agonists”:ti,ab or Glucophage:ti,ab or Glucotrol:ti,ab or “Glucotrol XL”:ti,ab or Glumetza:ti,ab or [mh Glyburide] or glyburide:ti,ab or “Glynase PresTab”:ti,ab or [mh Linagliptin] or Linagliptin:ti,ab or [mh Liraglutide] or liraglutide:ti,ab or lixisenatide:ti,ab or Lyxumia:ti,ab or Meglitinides:ti,ab or [mh Metformin] or Metformin:ti,ab or Micronase:ti,ab or Nateglinide:ti,ab or [mh Niacin] or niacin:ti,ab or Ozempic:ti,ab or Pioglitazone:ti,ab or Prandin:ti,ab or Repaglinide:ti,ab or Rosiglitazone:ti,ab or Saxagliptin:ti,ab or semaglutide:ti,ab or Sitagliptin:ti,ab or [mh “Sitagliptin Phosphate”] or [mh “Sitagliptin Phosphate, Metformin Hydrochloride Drug Combination”] or [mh “Sulfonylurea Compounds”] or Starlix:ti,ab or Sulfonylureas:ti,ab or Tanzeum:ti,ab or [mh Thiazolidinediones] or Thiazolidinediones:ti,ab or [mh Tolazamide] or Tolazamide:ti,ab or [mh Tolbutamide] or tolbutamide:ti,ab or Trulicity:ti,ab or TZDs:ti,ab or Victoza:ti,ab or vildagliptin:ti,ab | 22875
#5 | #1 and #4 | 7823
#6 | advice:ti,ab or [mh “Behavior Therapy”] or “behavior therapy”:ti,ab or (behavior*:ti,ab and therap*:ti,ab) or (behavior*:ti,ab and chang*:ti,ab) or (behavior*:ti,ab and modification*:ti,ab) or [mh “Caloric Restriction”] or [mh Counseling] or counsel*:ti,ab or “Diabetes Prevention Program”:ti,ab or “Diabetes Prevention Programme”:ti,ab or DPP:ti,ab or (“Diabetes Prevention”:ti,ab and (program*:ti,ab or stud*:ti,ab or trial*:ti,ab)) or diet:ti or [mh “Diet, Carbohydrate-Restricted”] or [mh “Diet, Fat-Restricted”] or [mh “Diet, Mediterranean”] or [mh “Diet, Reducing”] or [mh “Diet Therapy”] or dietary:ti or [mh “Directive Counseling”] or [mh Exercise] or exercise:ti or [mh “Exercise Therapy”] or [mh “Feedback, Psychological”] or [mh “Health Behavior” [mj]] or “health behavior”:ti,ab or “health behaviors”:ti,ab or “health behavioral”:ti,ab “health behaviours”:ti,ab or “health behaviour”:ti,ab or [mh “Health Education”] or [mh “Health Education as Topic”] or “health education”:ti,ab or [mh “Health Promotion” [mj]] or “health promotion”:ti,ab or [mh “Life Style”] or lifestyle:ti,ab or “life style”:ti,ab or [mh “Lifestyle Intervention”] or [mh “Motivational Interviewing”] or “motivational interviewing”:ti,ab or “non pharmacologic intervention”:ti,ab or “nonpharmacologic intervention”:ti,ab or [mh “Patient Education as Topic”] or “patient education”:ti,ab or “physical activity”:ti or “physically active”:ti or “psychological feedback”:ti,ab or [mh “Risk Reduction Behavior”] or “Risk Reduction Behavior”:ti,ab | 159258
#7 | #1 and #6 | 6747
#8 | #3 or #5 or #7 | 15322
#9 | #8 Publication date from Jan 2018 to Dec 2019 | 5789
#10 | (#9 and [mh ^Humans]) or (#9 not [mh ^Animal]) | 5789
#11 | #10 not (letter:pt or newspaper article:pt or editorial:pt or comment:pt or “case reports”:pt) | 5776
#12 | #11 and Adult* (All Cochrane Library results) | 1915

Gray Literature

ClinicalTrials.gov , 8-7-2018

ClinicalTrials.gov Screening:

74 Studies found for: screen OR screening | “Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “glucose tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance” OR “glucose intolerance” OR “Prediabetic State” OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus” | “Blood Glucose” OR “Glucose Tolerance Test” OR OGTT OR “glucose tolerance test” OR “Glycated Hemoglobin A” OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose” OR “HbA(1c)” OR HbA1 OR HbA1c OR “HbA 1c” OR “glycosylated hemoglobin” OR “glycated hemoglobin” | Adult, Older Adult | Last update posted from 01/01/2014 to 12/31/2018

ClinicalTrials.gov [underlined: and ICTRP Interventions:] too big 3000-4000 results, not saved, we will rely on Cochrane Trials results for Interventions

ClinicalTrials.gov Prediabetes:

577 Studies found for: “Prediabetic State” OR prediabetes OR prediabetic OR “pre diabetes” | Adult, Older Adult | Last update posted from 01/01/2014 to 12/31/2018

The system automatically also searched for Glucose Intolerance, Pre diabetics, Prediabetes.

WHO ICTRP, 8-9-2018

[underlined: WHO ICTRP - Screening]

97 trials,

[underlined: Advanced search:]

[underlined: In Title box:] screen or screening

[underlined: Condition box:]

glucose tolerance OR impaired glucose tolerance OR IGT OR impaired fasting glucose OR IFG OR Glucose Intolerance OR diabetes mellitus type 2 OR type 2 diabetes mellitus

Recruitment status: ALL

Date of registration between 01/01/2014 and 12/31/2018

[underlined: WHO ICTRP - Prediabetes]

137 trials,

In Title box:

Prediabetic State OR prediabet* OR pre diabetes

Recruitment status: ALL

Date of registration between 01/01/2014 and 12/31/2018

ClinicalTrials.gov , 9-11-2019

ClinicalTrials.gov [underlined: Screening:]

67 Studies found for: (“Blood Glucose” OR “Glucose Tolerance Test” OR OGTT OR “glucose tolerance test” OR “Glycated Hemoglobin A” OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose” OR “HbA(1c)” OR HbA1 OR HbA1c OR “HbA 1c” OR “glycosylated hemoglobin” OR “glycated hemoglobin” ) AND ( “Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “glucose tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance” OR “glucose intolerance” OR “Prediabetic State” OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus” ) | screen OR screening | Adult, Older Adult | Last update posted from 06/01/2018 to 09/11/2019

Team relying on Cochrane Library Trials results for the interventions search.

WHO ICTRP, 9-11-2019

[underlined: WHO ICTRP - Screening]

42 trials,

[underlined: Advanced search:]

[underlined: In Title box:] screen or screening

[underlined: Condition box:]

glucose tolerance OR impaired glucose tolerance OR IGT OR impaired fasting glucose OR IFG OR Glucose Intolerance OR diabetes mellitus type 2 OR type 2 diabetes mellitus

Recruitment status: ALL

Date of registration between 06/01/2014 and 9/11/2019

## Appendix B2 Eligibility Criteria

| Include | Exclude
Populations | All KQs: Studies of participants without obvious symptoms of diabetes (e.g., for KQ 1, studies of unselected populations that may include some participants with unrecognized symptoms of diabetes such as fatigue); nonpregnant women with a history of gestational diabetes (if they are >1 year postpartum); KQs 1, 2: Asymptomatic, nonpregnant adults; KQs 3, 4: Asymptomatic, nonpregnant adults with screen-detected prediabetes or type 2 diabetes; KQ 5: Asymptomatic, nonpregnant adults with recently diagnosed type 2 diabetes; KQ 6: Asymptomatic, nonpregnant adults with screen-detected prediabetes or type 2 diabetes; nonpregnant adults with recently diagnosed type 2 diabetes; KQs 7-9: Asymptomatic, nonpregnant adults with screen-detected prediabetes | KQs 1-9: Studies limited to or predominately comprising children, adolescents, and pregnant women; persons with symptomatic prediabetes or type 2 diabetes (e.g., weight loss, polyuria, blurred vision, headache); persons with a recent hospitalization; persons with a recent myocardial infarction; persons taking antipsychotics or glucocorticoids; persons with known cardiovascular disease or severe chronic kidney disease; persons living in an institution; other persons with medical conditions limiting their applicability to primary care–based populations (e.g., those with acute illness); KQ 5: Studies limited to or predominately comprising persons who have had diabetes for more than 1 year or with more advanced diabetes (e.g., persons already taking insulin or other medications; persons with proliferative retinopathy, nephropathy)
Screening | KQs 1, 2: Screening (targeted or universal) for prediabetes^*^ or diabetes; tests include hemoglobin A1c, fasting plasma glucose, and the oral glucose tolerance test | All other tests, such as genetic testing for the risk of prediabetes or diabetes or testing for autoantibodies, which may be used for further evaluation after a diabetes diagnosis (e.g., to assess for type 1 or type 2 diabetes)
Interventions | All KQs: Behavioral counseling interventions can be provided alone or as part of a larger multicomponent intervention on diet and nutrition, physical activity, sedentary behavior, or a combination thereof, including but not limited to assessment with feedback, advice, collaborative goal setting, assistance, exercise prescriptions (referral to exercise facility or program), or arranging of further contacts.; Interventions may be delivered via face-to-face contact, telephone, print materials, or technology (e.g., computer based, text messages, remote video feed) and can be delivered by a number of potential interventionists, including but not limited to clinicians, nurses, exercise specialists, dietitians, nutritionists, and behavioral health specialists.; Dietary counseling may involve:; Increased consumption of fruits, vegetables, whole grains, fat-free or low-fat dairy, and/or lean proteins; Limited consumption of sodium, saturated fat, trans fat, and/or sugar-sweetened food and beverages; Physical activity counseling may involve:; Aerobic activities that involve repeated use of large muscles, such as walking, cycling, and swimming; Resistance training designed to improve physical strength; Reduction of sedentary behaviors; Optional or access to guided physical activity or exercise classes; Limited guided physical activity (i.e., 1 to 2 sessions) or provision of food samples is allowed if intention is to teach or demonstrate healthy lifestyle principles; KQs 3-6: Primary care–relevant behavioral counseling or pharmacotherapy interventions for glycemic control or for more intensive risk reduction of atherosclerotic cardiovascular disease, including more intensive blood pressure control, lipid control, or aspirin; KQs 7-9: Primary care–relevant behavioral counseling or pharmacotherapy interventions for glycemic control | Counseling interventions aimed at falls prevention, balance, flexibility, gait, depression, or cognitive functioning; Prenatal or postnatal dietary counseling; Counseling interventions with components that are not feasible for implementation in health care settings (e.g., occupational/worksite-, church-, or school-based interventions conducted within existing social networks); Social marketing (e.g., media campaigns); Policy (e.g., local or state public/health policy); Stress management interventions (e.g., meditation, yoga, tai chi); Use of incentives (e.g., paying persons to lose weight); Supervised exercise with the goal of assessing effects of exercise; Dietary counseling solely focused on increasing intake of specific vitamins, micronutrients, herbal supplements, spices (e.g., ginger, cinnamon), or antioxidants through dietary change or supplementation, or counseling on alcohol moderation; Surgery
Comparisons | KQs 1, 2: No screening or alternative screening strategies; KQ 3: Comparison based on timing; sooner vs. later intervention (i.e., starting intervention upon detection by screening vs. starting later based on clinical diagnosis); clinical diagnosis refers to any approach based on development of symptoms (e.g., polyuria, polydipsia, paresthesia) or monitoring of biomarkers (e.g., increase in hemoglobin A1c above a certain threshold); KQs 4, 5: No intervention, placebo, usual care (can include minimal intervention), different treatment targets (e.g., glucose or blood pressure targets), waitlist, or attention control (for lifestyle interventions); KQ 6: All comparisons eligible for KQs 3-5; KQs 7-9: Sooner vs. later intervention, no intervention, placebo, usual care, waitlist, or attention control (for lifestyle interventions) | Comparative effectiveness (head-to-head) trials of medications or behavioral counseling without another eligible control group
Outcomes | KQs 1, 3-5, 8: Mortality, cardiovascular morbidity (including myocardial infarction, stroke, congestive heart failure), chronic kidney disease, amputation, skin ulcers, visual impairment (including blindness), periodontitis (including tooth loss), moderate to severe neuropathy, and quality of life; KQ 2: Labeling, anxiety, harms from false-positive results, burden, inconvenience, depression, and unnecessary testing and treatment; KQ 6: Serious side effects from treatment, including mortality, myocardial infarction, stroke, cancer, and hypoglycemic events requiring medical attention, burden and inconvenience; KQ 7: Development of type 2 diabetes; KQ 9: Blood pressure; total, low-density lipoprotein, and high-density lipoprotein cholesterol; BMI, weight; calculated 10-year cardiovascular disease risk | KQs 1, 3-5, 7–9: Studies with less than 6 months of followup
Study Designs | All KQs: Controlled clinical trials; KQs 2, 6: Controlled prospective cohort studies and case-control studies are also eligible; KQ 8: Controlled prospective cohort studies are also eligible | Modeling studies, systematic reviews,^**^ case series, case reports, uncontrolled observational studies, retrospective cohort studies, editorials, and all other study designs not mentioned
Settings | Studies conducted in or recruited from primary care settings or settings otherwise applicable to primary care (i.e., screening/interventions that could feasibly be implemented in or referred from primary care) | Settings not generalizable to primary care (e.g., inpatient hospital units, emergency departments, nursing home and other institutional settings, school-based programs, occupational settings)
Countries | Studies conducted in countries categorized as “Medium” or higher on the 2016 Human Development Index (as defined by the United Nations Development Programme) | Studies conducted in countries that are not categorized as “Medium” or higher on the 2016 Human Development Index
Language | English language | Languages other than English
Study quality | Good or fair quality | Poor quality (according to design-specific USPSTF criteria)

* Prediabetes includes persons who meet criteria for impaired fasting glucose or impaired glucose tolerance and persons with an A1c level of 5.7 percent to 6.4 percent.

** Systematic reviews were excluded from the evidence review; however, separate searches were conducted to identify relevant systematic reviews, and the citations of all studies included in those systematic reviews were reviewed to ensure that the database searches captured all relevant primary studies.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of Ratings Based on Above Criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies will be graded “fair” if any or all of the following problems occur without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.

Poor: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Sources: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015 ^78^

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

#### Definition of Ratings Based on Above Criteria

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (greater than 100) of broad-spectrum patients with and without disease.

Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.

Poor: Has a fatal flaw, such as uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015 ^78^

## Appendix B4 Supplemental Questions

To address the supplemental questions, we used an approach similar to that used for contextual questions with targeted searches and streamlined methods (e.g., less comprehensive electronic literature searches were conducted, dual risk-of-bias assessment of studies was not conducted). The methods used included identifying relevant information from within the evidence review and from currently included studies (at a minimum) for each question. We conducted targeted supplemental literature searches of PubMed/MEDLINE. The additional searches (focused mainly on Questions 4 through 8) for these questions yielded 1,489 citations that we reviewed. The reference lists of relevant articles were also reviewed to supplement the electronic searches. To answer the supplemental questions, we used a best-evidence approach when possible (e.g., if we identified a recent, good-quality systematic review for a question, we focused on it).

### Supplemental Question 1 What is the evidence on the magnitude of the marginal benefit of starting metformin in the prediabetes state (i.e., A1c=5.7) vs. when diagnosed with diabetes (i.e., A1c=6.5)?

[underlined: No randomized, controlled trials (RCTs) were directly designed to answer this question]: No trials directly answer this question by randomizing persons to be treated at an A1c around 5.7 versus waiting until their A1c is around 6.5. If there were, they would fall within the current scope of the review and we would include them. We continue to look for evidence on this question in our literature surveillance, and we have not identified any new trials. The Diabetes Prevention Program (DPP) and other trials of metformin (and other interventions) for prediabetes enrolled persons with prediabetes (often defined by their oral glucose tolerance test [OGTT] or fasting plasma glucose [FPG], rather than defined by A1c 5.7 to 6.4) and were designed to assess the outcome of progression to diabetes (as defined by OGTT, FPG, A1c, or some combination of those). They did not include a comparison of starting metformin at a lower versus higher A1c and subsequently follow persons for the development of the health outcomes listed in the analytic framework (e.g., microvascular outcomes, cardiovascular events).

[underlined: Subgroup analyses for the aggregate microvascular outcome from the] Diabetes Prevention Program Outcomes Study [underlined: (DPPOS) are potentially relevant]: DPPOS (intensive lifestyle intervention [ILI] vs. metformin vs. placebo) reported an aggregate microvascular outcome that combined intermediate outcomes and health outcomes (e.g., nephropathy includes urine microalbumin as well as renal failure/dialysis/transplant) for the comparison of ILI versus metformin vs. placebo. At 15-year followup, the metformin group had the highest percentage of participants with that adverse health outcome, although there was no statistically significant difference between groups (ILI 11.3% vs. metformin 13.0% vs. placebo 12.4%). As described in the evidence review, DPPOS was not focused on a comparison based on treating at different A1c thresholds (recall that it invited all DPP participants to continue into DPPOS; all participants were offered the ILI in a group format during the 1-year bridge between DPP and DPPOS; placebo was discontinued; metformin became unmasked; the ILI group was offered supplementary group programs and lifestyle check-ins).

Subgroup analyses from DPPOS showed that higher baseline A1c was associated with higher prevalence of the aggregate microvascular outcome, and the raw numbers showed higher percentages for metformin than for placebo in the lower A1c categories, but the interaction across A1c subgroups was not significant for the metformin vs. placebo comparison (for metformin vs. placebo: baseline A1c 3.2 to 5.7, RR 1.19 [0.84, 1.67]; baseline A1c 5.7 to 6.0, RR 1.17 [0.87-1.57]; baseline A1c 6.0 to 8.5, RR 0.96 [0.78, 1.19]; p=0.44) (shown in Table 2 of the 15-year followup paper^79^ and on backup slide 127 from the October 2019 in-person U.S. Preventive Services Task Force (USPSTF) meeting presentation). Figure 4 of the 15-year DPPOS followup paper shows an inflection point for increased risk of the aggregate microvascular endpoint around an A1c of 6.2.^79^

Subgroup analyses from DPP were highlighted by the DPP authors as post hoc, and they emphasized that DPP was not designed or powered to assess subgroups. DPPOS reported that it prespecified subgroup analyses for sex, age, race/ethnic origin, and glycemia (although it is possibly a stretch to consider these as prespecified by DPPOS considering how DPP describes its design and subgroups approach and given that DPPOS is an extension of a subset of DPP participants).

### Supplemental Question 2 Does the effectiveness of metformin vary by subpopulation, such as age, body mass index (BMI), gender, race/ethnicity, or baseline A1c?

[underlined: Baseline A1c]: The answer to Supplemental Question 1 above addresses what we found for baseline A1c (no significant effect modification) and comes from DPPOS for that aggregate microvascular outcome. We found no other eligible studies that reported on health outcomes in our analytic framework. For the outcome of diabetes incidence, the main DPP paper does not include baseline A1c among its subgroup analyses, although it does have baseline FPG and OGTT results (in Table 2 of the paper^80^), and it found no statistically significant effect modification for OGTT for metformin versus placebo but found a statistically significant effect modification for baseline FPG for metformin vs. placebo for the outcome of diabetes incidence (relative reduction of 48% [33% to 60%] for FPG 110 to 125 vs. 15% [−12% to 36%] for FPG 95 to 109 p<0.05). A publication focused on the subgroups that benefited most over 15 years of DPP/DPPOS for the outcome of diabetes incidence compared metformin with placebo groups.^81^ The study reported that metformin was more effective in subjects with higher baseline A1c levels (6.0% to 6.4% vs. <6.0%), higher baseline fasting glucose levels, and women with a history of gestational diabetes mellitus. There were no significant interactions with baseline age, BMI, sex, or race/ethnicity.^81^

[underlined: Age, BMI, gender, race/ethnicity]: DPPOS reported no significant effect modifications by age, BMI, sex, or race/ethnicity^79^ (table shown on backup slide 127 from the October 2019 in-person USPSTF meeting presentation). We found no other eligible studies that reported on health outcomes in our analytic framework. For the outcome of diabetes incidence, Table 2 of the primary DPP article provides the main results^80^ (shown on backup slide 120 from the slide deck used at the in-person October 2019 USPSTF meeting). We had included this information in the evidence review (key question [KQ] 7 section on pharmacologic interventions: subgroups), specifically stating the following:

With the caveat that their subgroup analyses were post hoc and underpowered, the DPP authors noted that after 3 years of followup, the effect of metformin compared with placebo was not statistically significantly different for subgroups defined by age, sex, or race and ethnicity. However, they reported statistically significant effect modification by BMI (p<0.05), with greater effect on diabetes incidence for those with higher BMIs (e.g., reduction in diabetes incidence 53% [95% CI 36% to 65%] for BMI ≥35 kg/m^2^ vs. 3% [95% CI −36% to 30%] for BMI 22 to <30 kg/m^2^). After 15 years of followup within DPPOS, the effect of metformin compared with control was not significantly different between males and females. The Indian Diabetes Prevention Program investigators found that age, sex, and BMI did not independently influence the development of diabetes for the control group compared with any of its three treatment groups, including the metformin only group.

[underlined: Comparative effectiveness of metformin vs. ILI]: We note that the head-to-head comparison of metformin and ILI does not directly address Supplemental Question 2 (because the question is about the effectiveness of metformin, and not comparative effectiveness), but DPPOS and DPP both reported on this comparison; therefore, we include it here. DPPOS reported no statistically significant effect modification for ILI vs. metformin for the aggregate microvascular outcome by baseline A1c, age, sex, BMI, and race or ethnicity^79^ (table shown on backup slide 127 from the October 2019 in-person USPSTF meeting presentation). For the outcome of diabetes incidence, Table 2 from the main DPP publication shows that the advantage of ILI over metformin was greater in older persons (than younger persons, ages 25 to 44 years) and those with lower BMI (than higher BMI ≥35).^80^ DPP authors noted that their subgroup analyses were post hoc and underpowered, and they tested many comparisons.

### Supplemental Question 3 What is the natural history of prediabetes, as currently defined?

Levels of glucose and glycemia in the prediabetes range are associated with an increased risk of adverse health outcomes. The introduction to the evidence review (Etiology and Natural History section) and Supplemental Questions 7 and 9 have information about the risk of mortality and adverse health outcomes associated with prediabetic glucose and glycemic levels. Various studies have demonstrated that increasing glucose and glycemia levels are associated with a continuously increasing risk of adverse health outcomes without a clear inflection point (i.e., without a clear threshold/value at which the risk escalates).

[underlined: Data from control groups of randomized trials included in the Evidence-based Practice Center evidence review]: The randomized trials included in KQ 7 of the evidence review (on interventions for prediabetes to delay or prevent progression to diabetes) provided control group data to inform this question. Those trials, including the DPP and DPPOS, described rates of progression from prediabetes to diabetes (defined by FPG, OGTT, or A1c). These data were in the review and presented at the in-person October 2019 USPSTF meeting (some of the data are shown on backup slide 76 from the in-person presentation). Overall, the studies show a wide range of rates of progression from prediabetes to type 2 diabetes mellitus, perhaps due to heterogeneity of prediabetes itself, differences in enrolled populations, and variation in followup duration and measures.

Looking at all the trials of lifestyle interventions compared with controls that were included in the evidence review, we see that control group event rates indicate that an average of 20 percent of persons (range across trials: 3.3% at 1 year to 90% at 23 years) progress from prediabetes to diabetes (defined by FPG, OGTT, or A1c) over a broad range of followup periods from 1 to 23 years. When limiting to studies with 1 year of followup (k=8), the mean was 9 percent (range 3.3% to 20%) of persons progressing to incident diabetes. The breakdown by control group event rate is as follows; we include the number of studies (k) for each event rate and the followup duration of those studies:

- <5%: k=3 (all 1 year)
- 5% to <10%: k=6 (3 were 1 year and 1 study each of 2, 4, and 5.5 years)
- 10% to <20%: k=5 (4 studies of 3 years; 1 study of 1 year)
- 20% to <30%: k=4 (all different durations: 1 year, 3 years, 5 years, and 6 years)
- ≥30%: k=3 (55% in the IDDP at 3 years, 52% in DPPOS at 15 years, and 90% in Da Qing at 23 years)

If we focus on the placebo arm of the DPP, we see that 29 to 30 percent progressed to type 2 diabetes mellitus over 3 years. In the DPPOS, 52 percent of those in the placebo group progressed to type 2 diabetes mellitus over 15 years (raw data shown in the figures in Appendix F).

[underlined: Data from other studies that used current definitions of prediabetes]: Three cohort studies that used current definitions were identified in targeted searches.^82–84^ Briefly, a cohort study of over 77,000 Kaiser Foundation Health Plan members with prediabetes (based on A1c) reported that the 2-year risk of incident diabetes varied widely by A1c and BMI.^82^ A small subset (5.2% of the population) had a very high risk (18.0% probability) of developing type 2 diabetes mellitus within 2 years, about 13 percent of the population had a moderate 2-year risk (8.2% probability), and most (81.5%) of the population was at much lower risk (1.6% probability). The authors developed a simple stratification scheme based on A1c and BMI to estimate the risk of developing type 2 diabetes mellitus. The high-risk group comprised 4,001 of the 77,107 persons and generally had baseline A1c 6.3 to 6.4%. The risk of developing diabetes increased with increasing A1c and with increasing BMI.

A longitudinal cohort study of American Indians reported on incident type 2 diabetes mellitus over 10 years.^83^ The study included 2,005 adults. Of those, 168 had prediabetes (based on A1c 5.7 to 6.4%) at baseline and their mean age was 30 years and mean BMI was 39. Over a median followup of 4.6 years (total person-years of followup were 11,520), the incidence rate was about 100 type 2 diabetes mellitus cases per 1,000 person-years for men and about 114 cases per 1,000 person-years for women (data reported in the figure only).

The third cohort study assessed 406 persons of Asian ethnicity with prediabetes and followed them every 3 to 6 months for up to 9 years.^84^ About 20 percent (n=81) were diagnosed with type 2 diabetes mellitus over a median followup of 46 months. The study showed variation in rates of progression to type 2 diabetes mellitus by the prediabetes category/definition, with the highest rates for persons with combined glucose intolerance (i.e., those with both impaired fasting glucose [IFG] and impaired glucose tolerance [IGT]) (31.9%) or isolated IGT (18.5%) than for those with isolated IFG (15.2%) or isolated elevated A1c (10.9%).

### Supplemental Question 4 What is the amount of overdiagnosis and overtreatment in prediabetes and diabetes?

### Supplemental Question 4a What percentage of patients with prediabetes, by today’s definitions (e.g., A1c=5.7 to 6.4), progress to diabetes, remain prediabetic, or return to normal glucose tolerance (without intervention), and over what time frame? How does this differ by baseline A1C?

[underlined: Data from control groups of randomized trials included in the EPC evidence review]: Supplemental Question 3 addresses how many people with prediabetes progress to type 2 diabetes mellitus. Among DPP participants in the placebo arm, after 3 years, 40.7 percent remained prediabetic and 24 percent were reported to have at least one episode of return to normal glucose tolerance without intervention. The study did not report on how long normal glucose tolerance was maintained. It is unclear in the other studies that we identified whether individuals who did not progress to diabetes remained prediabetic or returned to normal glucose tolerance.

[underlined: Data from other studies that used current definitions of prediabetes]: The Supplemental Question 3 response provides information from such studies on how many people with prediabetes progress to type 2 diabetes mellitus. No additional studies were identified that report how many people with prediabetes remained prediabetic or returned to normal glucose tolerance.

[underlined: Difference by baseline A1c]: Six studies reported progression to diabetes by baseline A1c.^64,82,85–88^ Overall, these studies show an increasing risk of progression to T2DM with increasing baseline A1c and show that people with both IFG and IGT have an increased risk of progression to diabetes than those with only IFG or IGT or isolated elevated A1c.

A cohort study with more than 77,000 participants, described in Supplemental Question 3, reported increased risk of diabetes progression for individuals as their A1c increased.^82^ Persons in the low-risk category (with an A1c of 6.0% or less or 6.1-6.2% if their BMI was less than 30) had a much lower risk of progressing to diabetes than individuals in the highest risk category (A1c 6.2-6.4% with BMI 25 or more) (1.6% vs. 18.0% progressed to diabetes over 2 years).

A cohort study in New Zealand followed 18,728 individuals with elevated A1c in the prediabetes range for a median of 4 years.^64^ Participants were categorized by baseline A1c into three categories: A1c 5.8-6.0%, 6.1-6.2%, and 6.3-6.7%. Progression to diabetes increased as baseline A1c increased (progression to T2DM occurred in 9.9% vs. 11.1% vs. 28.8% of participants, respectively).

The Singapore Chinese Health Study reported incident diabetes in men and women among participants (n=2,191) who were categorized by baseline A1c (5.7 or less, 5.8-5.9, 6.0-6.1, 6.2-6.4, and 6.5 or greater).^88^ Over a mean followup of 5.2 years, progression to diabetes for participants in A1c categories that meet criteria for prediabetes (A1c 5.8-5.9, 6.0-6.1, and 6.2-6.4) were 14 percent, 11 percent, and 10 percent, respectively. Using a standardized incidence rate, progression to diabetes was calculated at 243, 366, and 579 per 100,000 person-years for participants with baseline A1c of 5.8-5.9, 6.0-6.1, and 6.2-6.4, respectively.

Another cohort study, based in the United States, followed 4,714 middle-aged adults without diabetes for a median of 14 years.^85^ Individuals were categorized by baseline A1c of less than 5.0 percent, 5 to less than 5.5 percent, 5.5 to less than 6.0 percent, 6.0 to less than 6.5 percent, and 6.5 percent or greater. Cumulative incidence for progression to diabetes was reported as 21 percent for individuals with baseline A1c of 5.5 percent to less than 6.0 percent compared with 44 percent for individuals with a baseline A1c of 6.0 percent to less than 6.5 percent.

One additional cohort study of 406 adults^84^ and two randomized controlled trials^86,87^ addressed progression to diabetes by examining subgroups of patients with IFG, IGT, or a combination of both. All three studies found higher rates of progression for participants with combined IFG and IGT (31.3-32.9% over 36-46 months) than for those with only IFG or only IGT (5-15.2% for IFG; 11.2-18.5% for IGT). Two studies also differentiated participants who had isolated elevated HbA1c and found lower progression rates (10.9-15.2% over 36-46 months) than for those with combined IFG and IGT.^84,86^

### Supplemental Question 4b What percentage of patients with early-stage diabetes progress to complications with current medical therapy?

We aimed to identify evidence for people with early stage T2DM diabetes who were on no more than 1 hypoglycemic agent (and did not use insulin), had an A1c of less than 9.0 percent, and were diagnosed with T2DM within 5 years. Key Question 4 (KQ 4) in the evidence review provides information relevant to this supplemental question. Targeted searches identified a cost-effectiveness analysis and two additional cohort studies that provide additional information regarding progression to complications for early-stage diabetes, although neither cohort study provided details on the medical therapies received over the course of followup.^89–91^

[underlined: Data from randomized trials included in the evidence report:]Key Question (KQ 5) of the evidence report included two studies relevant to this question.^1,92–94^ In summary, UKPDS reported outcomes for participants in two different trials with early-stage diabetes on one of two sulphonylureas (chlorpropamide or glibenclamide) or metformin during a 10-year followup with additional 10-year post-trial monitoring period. The DESMOND trial reported outcomes for an education-based program during a 3-year period. All-cause mortality was variable in these studies (3.9-44%, highest noted for metformin in post-trial monitoring and lowest for group education). UKPDS reported lower rates of diabetes-related death, MI, and stroke for participants in the metformin group than participants in either sulphonylurea group during the initial 10 years of followup. During the post-trial monitoring, rates for metformin surpassed those of the sulphonylurea group. Progression to chronic kidney disease, amputations, and blindness were all low (less than 5%), with retinal photocoagulation slightly higher (7.3-8.9%).

[underlined: Data from other studies that included participants with early-stage diabetes:] Two additional cohort studies were identified in a targeted search. Data from the studies were uncertain, however, because the participants did not have an identified medical therapy. A cost-effectiveness analysis modeled complications from early-stage diabetes using UKPDS data.^89,90^

In a cohort study from New Zealand, 62,002 patients with type 2 diabetes and a mean duration of disease of 3-4 years were followed for a median of slightly more than 7 years. It is unclear what medical therapy participants were using in this cohort study. Participants were followed for progression to lower limb amputations, which was calculated at 2.11 amputations per 1,000 person-years (based on a total of 892 lower limb amputations).^89^

Another cohort study used data from the Nurses’ Health study for women and the Health Professionals Follow-Up Study for men, following participants with newly diagnosed diabetes for an average of 13.3 years.^90^ Outcomes for this study were cardiovascular disease incidence and mortality, which included fatal and nonfatal coronary heart disease (including myocardial infarction, fatal and nonfatal stroke, and coronary artery bypass graft surgery). Among the 8,970 women and 2,557 men enrolled, there were 2,311 adverse cardiovascular events (20.0%). These included 498 fatal and nonfatal strokes (4.3%) and 1,844 instances of nonfatal coronary heart disease (16.0%). There were also 858 deaths from cardiovascular disease (7.4%). The study did not comment on current medical therapy or how these therapies may have changed during the followup period.

A cost-effectiveness analysis focused on lifestyle modification or metformin in preventing diabetes in adults with IGT estimated that incidence of complications in a 10-year period from diagnosis was very low.^88^ Specifically, mimicking UKPDS data, it estimated an incidence of 6.5 percent for microalbuminuria and 3.3 percent for peripheral neuropathy (and zero for retinopathy).

### Supplemental Question 4c What percentage of the diabetes prevented in the DPPOS represents overdiagnosed diabetes?

#### i Were microvascular complications prevented by metformin in DPPOS? Was uncontrolled diabetes (A1c>9) prevented by metformin in DPPOS?

Published studies did not report on how much of the diabetes in DPPOS represents overdiagnosed diabetes, but information related to microvascular complications and uncontrolled diabetes may inform discussions about that question. Overall, data from DPPOS did not indicate that metformin prevented adverse microvascular outcomes when compared with placebo, and the data suggest that metformin is less effective than lifestyle interventions.

One of the primary outcomes for DPPOS was the prevalence of an aggregate microvascular outcome (retinopathy, nephropathy, and neuropathy), as described in the evidence review. The aggregate outcome combined intermediate outcomes and health outcomes (e.g., the nephropathy component included urine microalbumin as well as renal failure/dialysis/transplant). At 15-year followup, prevalence of the aggregate microvascular outcome was not statistically significantly different between trial arms (ILI 11.3% vs. metformin 13.0% vs. placebo 12.4%).^79^ As detailed in the evidence review, there were no significant differences in treatment effects among subgroups defined by age at DPP enrollment, but sex-specific analyses found a significant interaction between sex and intervention, with a benefit only in women. Among women (n=1,887), the lifestyle intervention was associated with a lower prevalence than the placebo group (8.7% vs. 11.0%; p<0.05) or the metformin group (8.7% vs. 11.2%; p<0.05); rates were similar among women in the metformin and placebo groups (11.2% vs. 11.0%).^79^ Among men, rates were similar for those in the placebo group (15.1%), metformin group (16.8%), and lifestyle intervention group (16.6%). A post hoc analysis among participants whose most-recent HbA1c was 6.5 percent or greater (n=607, approximately 26% of the DPPOS cohort) found lower rates of retinopathy (RR 0.61 [95% CI, 0.37 to 1.01]) and neuropathy (RR 0.38 [95% CI, 0.19 to 0.75]) for the intensive lifestyle group than placebo; there were no significant differences between the metformin and placebo groups.

We did not identify any DPPOS studies that specifically reported information regarding prevention of uncontrolled diabetes, defined by A1c greater than 9 percent. The DPPOS 15-year followup study reported that the mean A1cs for participants who developed T2DM in three trial arms were 6.7 (SD 1.4) for placebo, 6.5 (SD 1.3) for metformin, and 6.7 (SD 1.4) for lifestyle intervention (at DPPOS end in year 2013).^79^ Among all participants (any study group) who developed T2DM (n=1550), the mean A1c was 6.6 percent (SD 1.4). The corresponding data for the DPP end (year 2001) were 6.5 (SD 0.9) for placebo, 6.3 (SD 0.7) for metformin, and 6.4 (SD 0.7) for lifestyle intervention. Although standard deviations are reported, there is uncertainty about the distribution of the data (i.e., uncertainty about whether the data were normally distributed). Therefore, it is not possible to reliably estimate how many participants in any group had an A1c greater than 9 percent.

### Supplemental Question 4d Prepare an outcomes table on the benefits and harms (including overdiagnosis and overtreatment of prediabetes) of metformin as a preventive medication in a hypothetical cohort of 10,000 unscreened asymptomatic adults. (Consider including “opportunity costs” [i.e. not receiving benefits of diet/physical activity because metformin is prescribed instead of diet/physical activity].)

Table 1 provides projected 10-year outcomes of treating 10,000 adults with prediabetes, comparing intensive lifestyle intervention versus metformin started at the time of prediabetes diagnosis versus metformin started (later) at the time of diabetes diagnosis. Overall, we did not identify reliable inputs for many cells in the outcomes table, precluding our ability to provide reliable total estimates for benefits and for harms under each scenario.

### Supplemental Question 5 What is the distribution of disutilities of having diabetes, screen-detected or early diabetes (precomplications), or prediabetes?

Eight studies (4 RCTs and 4 cross sectional studies) using data from across 13 articles provided health utility data for individuals with screen-detected or uncomplicated early diabetes or prediabetes.^76,86,95–105^ The findings represent individuals not on metformin or making intensive lifestyle changes. Four articles from the ADDITION-Europe trial provided health utility values for a population with screen-detected diabetes,^76,95,98,102^ two studies provided health utilities for a population with uncomplicated early diabetes (diagnosed within the previous 5 years),^96,101^ and 10 articles from eight studies provided health utilities for populations with prediabetes.^86,96–101,103–105^ RCT data reflected either baseline or control group results. Appendix B5 provides additional details on measures of utilities used in studies addressing this Supplemental Question.

Studies included populations with a mean or median age between 44 and 67 years and with sample sizes varying widely from 47 to 7,632. Of the eight included studies, six (represented in nine articles) were conducted in Europe^76,86,95,98,100–102,104,105^ and two (represented in four articles) were conducted in the United States.^76,96,97,99,103^ Multiple instruments were used to measure health utilities, including the EQ-5D, used in three studies (described in five articles);^76,95,98,102,104^ the SF-6D, used in four studies (described in five articles);^97,99–101,103^ the HRQOL 15-D, used in two studies;^101,105^ and the QWB-SA, used in 1 study.^96^ Because health utility instruments differ in several ways, including what aspects of psychological health and well-being are measured, ceiling effects, and the processes by which index values and summary scores are calculated, comparisons cannot simply be made across instruments.^106^ Furthermore, these general health utilities instruments may not be very sensitive to particular health issues that are important to those with diabetes and prediabetes.^107^

Table 2 presents the reported health utility values and corresponding disutility associated with having diabetes (screen-detected or uncomplicated early T2DM) or prediabetes. Disutilities were derived from reported health utility values as 1 minus the utility index score. It is important to note that uncertainty around health state utility values is usually underreported and that frequently, only mean values are used in decision-analytic models.^108^ Disutilities were generally found to be reported without a distribution (i.e., without reported measures of statistical dispersion such as standard deviation, 95% CI, or interquartile range). For cross-sectional studies comparing a group with diabetes or prediabetes to a group without diabetes, disutility values are presented for both groups and provide a within-study comparison to determine whether having uncomplicated diabetes or prediabetes results in a disutility greater than that reported by individuals without diabetes/prediabetes. For all studies, including trials without a “no diabetes/prediabetes” comparison, we report population norm disutilities for each utility measure. Because population norm disutilities reflect disutilities reported by individuals representative of the entire population (both healthy and with chronic diseases), they may be less useful than within-study comparators but provide an anchor for interpreting the reported disutilities associated with having diabetes/prediabetes. To determine whether the disutility findings reflect differences that may meet criteria for a minimal clinically important difference (MCID), Table 2 also presents suggested MCIDs for each health utility measure.

Overall, for screen-detected or early diabetes (precomplications) or prediabetes, the range of estimated disutilities varied widely, from 0.12 to 0.33. There is some limited evidence suggesting that living with screen-detected or uncomplicated early diabetes (without taking metformin or making intensive lifestyle changes or on other therapies) results in greater health disutilities compared with individuals without diabetes. However, results were inconsistent with some evidence suggesting better health (lower disutilities) among individuals with recently diagnosed T2DM when compared with population norms. Among those with prediabetes, most studies reported health disutilities slightly greater than or the same as individuals without prediabetes with no clear evidence that having prediabetes results in health disutilities that are meaningfully greater than disutilities reported by individuals without prediabetes or by the general population.

For screen-detected T2DM, four sites (Leicester and Cambridge in the UK, Denmark, and the Netherlands) involved in the ADDITION-Europe trial reported disutilities ranging from 0.15 to 0.21. The publications did not include data for a “no diabetes” comparator group, so we were unable to determine whether disutilities would differ among similar individuals without diabetes. Compared with estimated population norms for the EQ-5D in the included countries, individuals in the ADDITION-Europe trial living with screen-detected T2DM reported greater disutility compared with the general population, but the reported disutilities did not meet criteria for a MCID in all cases. If the lower bound of the range of a MCID (i.e., 0.04) is used, then the disutility reported among individuals with screen-detected T2DM meets MCID criteria in five of eight reported datasets (with greater disutility for those with screen-detected T2DM compared with norms for the general population). However, if the upper bound of the range of a suggested MCID (i.e., 0.08) is used, the reported disutility from just one site, Leicester, meets criteria for a MCID.

For early diabetes without complications, reported disutilities ranged from 0.12 to 0.33. There was some evidence from one study conducted in Finland (n=920) that early diabetes without complications may result in a disutility that is greater than that of those without diabetes, although the difference between those with and without diabetes was just at the lower range of an estimated MCID.^101^ The study reported a disutility of 0.25 using the SF-6D and 0.12 using the HRQOL 15-D among individuals with uncomplicated T2DM compared with disutilities of 0.22 on the SF-6D and 0.09 on the HRQOL 15-D for those without diabetes.^101^ Results from 155 individuals enrolled in the placebo arm (so not receiving an intervention) of the DPP/DPPOS and diagnosed with T2DM during the study were more difficult to interpret because there was no within-study comparison with a nondiabetic population. There was, however, no difference in the disutility values (using the QWB-SA) reported by those in the placebo arm who developed diabetes within 2-years of enrollment in the DPP/DPPOS and those who remained prediabetic (both groups reported a disutility of 0.32).^96^ The DPP/DPPOS measured health utilities for each year of the study and reported a mean disutility of 0.33 among those in the placebo arm who developed diabetes throughout any of the remaining years of the study, compared with a mean disutility of 0.32 for those who remained prediabetic. These findings are lower than the disutility of 0.36 reported for QWB-SA among individuals in the general population suggesting, better health among those in the DPPOS placebo arm than in the general population even after developing diabetes.^96^

Among eight studies of people with prediabetes, reported disutilities ranged from 0.08 to 0.33. Four of the eight were cross-sectional studies comparing a population living with prediabetes to a population without prediabetes.^100,101,103,105^ As outlined in Table 2 below, studies generally reported a disutility slightly greater than or the same as individuals without prediabetes; just one study reported a greater disutility for those living with prediabetes that was considered to just barely meet criteria for a MCID (0.25 vs. 0.22 on the SF-6D and 0.11 versus 0.09 on the HRQOL-Q15D).^101^ DiBonaventura and colleagues stratified health utilities (using the SF-6D) by weight and found increased obesity levels resulted in more disutility among those with prediabetes as well as among those with normal glucose tolerance. Statistical differences between the prediabetes and normal glucose groups were not performed, but the observed difference did not meet criteria for a MCID. This suggests that obesity, rather than prediabetes, was responsible for the increased disutility. All groups (even the normal weight groups) reported greater disutility than the population norm of 0.21 for the SF-6D.

Control group results from four prediabetes intervention studies, including two articles from the DPP/DPPOS trial, employed different health utility measures and reported mixed findings (Table 2).^86,96,98,99,104^ One UK-based study, which used the EQ-5D measure, found greater disutility over time, ranging from a disutility of 0.18 at baseline to 0.22 at 36 months. These were all greater than the UK population norm for the EQ-5D-3L of 0.14, meeting criteria for MCIDs.^104^ Results from the control arm of the IGT group in the ADDITION-Denmark study also reported a disutility greater than the population norm (0.16 vs. the population norm of 0.13 for the EQ-5D), but this did not meet criteria for a MCID.^98^ In contrast, results from the DPP/DPPOS study, which included two separate measures of health utilities (the SF-6D and the QWB-SA), found no added disutility of having prediabetes compared with population norms.^96,99^ In fact, using both measures, individuals with prediabetes reported better health (i.e., lower disutilities) than the population norm of 0.36 for the QWB-SA. Similarly, results from the usual care group of the Let’s Prevent Diabetes Lifestyle trial in the UK reported disutilities at baseline (0.09) and at 36 months (0.11) that are lower than the population norm of 0.14 for the HRQOL 15-D.^86^

### Supplemental Question 5a What is the distribution of disutilities of taking metformin and of making intensive lifestyle changes?

#### Disutility of Taking Metformin

We found no studies, meeting inclusion criteria, that reported disutilities for individuals with screen-detected diabetes and taking metformin. Two articles from the DPP/DPPOS provided health utility data specific to individuals taking metformin who had prediabetes or who developed T2DM during the study.^96,99^ Table 3 presents the distribution of reported disutilities for individuals in the DPP/DPPOS with uncomplicated early diabetes or prediabetes and taking metformin, and reports the corresponding disutilities for those taking a placebo. The data capture the disutility related to the side effects of taking metformin. Because both groups are taking a pill, however, the data do not capture the disutility related to taking a pill in and of itself. Table 3 also provides population norm disutilities for each measure.

Evidence from the DPP/DPPOS should be considered in the context of the study over 10 years. The initial 3 years represent the randomized controlled trial phase of the study with individuals in the metformin arm prescribed 850 mg of metformin daily for the first month, which was increased to 850 mg twice daily afterwards (if tolerated). At the end of the randomized controlled phase, participants in both the metformin and placebo arms were offered a 16-session lifestyle intervention, and those on metformin were encouraged to maintain (open label) metformin treatment. Thereafter, participants entered the followup observational study phase, during which all participants received the healthy lifestyle intervention and participants in the metformin arm were once again encouraged to maintain metformin treatment. In all, 58 percent of metformin participants also attended at least one lifestyle session during the followup phase. Of the original 3,234 participants enrolled in the RCT, 924 of 1073 from the metformin arm and 932 of 1082 from the placebo participated in the DPPOS phase. Very few participants in the placebo arm (3%) took metformin prescribed outside the study. With this in mind, and noting the lack of distributions around the reported estimates, the findings largely suggest no difference in reported disutilities between individuals taking metformin and those taking placebo (e.g., the mean disutility over 10 years was virtually identical, 0.32 vs. 0.33).^96^

Early uncomplicated T2DM: Among individuals who developed T2DM during the randomized phase of the DPP, those taking placebo report greater disutility (just meeting criteria for a MCID) than those taking metformin, although confidence intervals were not provided and statistical comparison of the disutilities was not conducted by the study. However, in year 2 of the RCT and for all followup years, participants reported identical or similar disutilities whether they were taking metformin or taking a placebo. Over all 10 years of the DPP/DPPOS, the mean disutility was 0.32 for those on metformin versus 0.33 for those taking a placebo.^96^

Prediabetes: Similar results were observed for individuals with prediabetes taking metformin compared with those taking placebo. Using the SF-6D, Marrero and colleagues reported disutilities of 0.22, 0.22, 0.24, 0.26, and 0.28 at years 2, 3, 4, 5, and 6 of the DPPOS, respectively. The corresponding scores for individuals in the placebo arm (not assigned to metformin) were 0.21, 0.22, 0.24, 0.26, and 0.27.^99^ Results using the QWB-SA, which include the randomized phase of the DPP, also suggest that there is no added disutility associated with taking metformin compared with taking placebo, with almost identical disutilities reported across each year of the study (see Table 3).

#### Disutility of Making Intensive Lifestyle Changes

Table 4 presents the distribution of reported disutilities from 5 studies (6 articles)^86,96,98,99,102,104^ for individuals with screen-detected or uncomplicated early diabetes or prediabetes and making intensive lifestyle changes and compares them to reported disutilities from those not making lifestyle changes (where provided) and to population norm disutilities for each health utility measure. Overall, among individuals with screen-detected or complicated early diabetes or prediabetes, there is no clear evidence that making intensive lifestyle changes results in health disutilities greater than that experienced by those not making lifestyle changes. Across studies and measures, individuals making intensive lifestyle changes largely reported almost identical disutilities to those not making lifestyle changes and by some measures reported slightly better health (lower disutilities) than those not making lifestyle changes. This finding should be considered with the caveat that studies did not generally provide a distribution around health utility estimates or statistical comparison of utility estimates between groups, and several studies did not have a within-study comparison.

Screen-detected T2DM: Two studies used the EQ-5D to measure disutilities among individuals with screen-detected T2DM enrolled in the ADDITION-Denmark and ADDITION-Cambridge trials and reported disutilities of 0.16 and 0.15, respectively.^98,102^ Neither study compared results to a group not making lifestyle changes. However, compared with population norms for the EQ-5D in each country (0.13 in Denmark and 0.14 in the UK), the reported disutilities do not suggest significant disutility associated with having diabetes while making intensive lifestyle changes.

Early uncomplicated T2DM: Using the QWB-SA, individuals enrolled in the DPP/DPPOS who were assigned to the intensive lifestyle group and who developed diabetes within 2 years of enrollment (n=51) reported a disutility of 0.36 compared with a reported disutility of 0.32 among those in the placebo group who also developed diabetes within 2 years of enrollment (n=155). This difference of 0.04 is considered a MCID for the QWB-SA, suggesting that making intensive lifestyle changes may have resulted in an added meaningful disutility.^96^ However, this result was not emulated across any other year of either the DPP or the DPPOS. In fact, individuals making intensive lifestyle changes regularly reported slightly better overall health (i.e., lower disutilities) than those in the placebo arm (Table 4). It should be noted that during the DPPOS (i.e., the follow-on observational study from year 3/4 through year 10), participants in the placebo arm were offered a healthy lifestyle program and 58 percent of the placebo arm attended at least one session during the initial 16-session program.^96^ It is therefore possible that participants in the placebo arm of the DPPOS were benefiting from making some lifestyle changes.

Prediabetes: Overall, reported disutilities for individuals with prediabetes and making intensive lifestyle changes were not greater than disutilities reported by those not making intensive lifestyle changes. Results from two studies using the EQ-5D reported disutilities that were greater than the reported population norms for each country,^98,104^ but when compared with study participants not making intensive lifestyle changes, the slightly higher disutility reported by Leal and colleagues for the Let’s Prevent Diabetes Lifestyle trial in the UK did not meet criteria for a MCID^104^ (Table 4). Results among participants in the DPP/DPPOS differed depending on the health utility measure employed. Marrero and colleagues reported slightly higher disutilities among those with prediabetes and making intensive lifestyle changes compared with those with prediabetes not making intensive lifestyle changes, but the results did not meet criteria for a MCID.^99^ When the QWB-SA was employed as the health utility measure, participants with prediabetes making intensive lifestyle changes reported slightly better health (i.e., lower disutilities) than participants with prediabetes not making intensive lifestyle changes, suggesting no added disutility related to making intensive lifestyle changes. Similarly, results from the usual care group of the Let’s Prevent Diabetes Lifestyle trial in the UK reported disutilities at baseline (0.10) and at 36 months (0.09) that are lower than the population norm of 0.14 for the HRQOL 15-D.^86^

Participants in the DPP/DPPOS with prediabetes (IGT) who did not develop diabetes showed little decline in SF-D utility scores over the first 3 years of participation in the DPPOS whether they were in the placebo arm, on metformin, or making intensive lifestyle changes.^99^ From year 3, participants in all treatment groups (including the placebo arm) that remained diabetes-free showed a progressive decline in SF-6D scores. For those on Metformin or making intensive lifestyle changes, reported disutility values on the SF-6D increased from 0.20 at baseline to 0.28 after 6 years of participating in the DPPOS. Similarly, for those in the placebo arm, disutility values on the SF-6D scores increased from 0.20 at baseline to 0.27 after 6 years. These suggest that treatment-specific burden was not responsible for the observed decline in health status and that it was due to other factors (e.g., aging, other additional health problems, study participation).

### Supplemental Question 5b Would the disutility of having prediabetes be similar to diabetes if a patient with prediabetes is taking metformin or is making intensive lifestyle changes?

Table 5 compares the reported disutility of having prediabetes with the reported disutility of having screen-detected or early uncomplicated diabetes among people taking metformin (top row) or making intensive lifestyle changes (bottom two rows). Three studies provided data comparing relevant groups across similar measures.^96,98,102^ Overall, one study (the DPP/DPPOS) suggested that disutilities were similar for persons with prediabetes and those with early uncomplicated diabetes who were taking metformin.^96^ For intensive lifestyle changes, results from the ADDITION-Denmark and ADDITION-Cambridge studies suggest similar disutilities for those with prediabetes and those with screen-detected or early uncomplicated diabetes.^98,102,104^ However, there is some suggestion from the randomized phase of the DPP/DPPOS that those with prediabetes making lifestyle changes may experience less disutility than those with early uncomplicated T2DM making lifestyle changes.

Using the QWB-SA, the DPP/DPPOS measured participant health utilities for each year from enrollment in the program through 7-years of followup (10 years of data). For those on metformin, the reported mean disutility over 10 years of measurement was the same for those with prediabetes (0.32, SD 0.004) as it was for those with uncomplicated early diabetes (0.32, SD 0.02).^96^

For those making intensive lifestyle changes, the results from three studies were mixed. In the DPP/DPPOS, the reported mean disutility (using the QWB-SA) over 10 years of measurement was greater for those with uncomplicated early diabetes (0.33, SD 0.01) than it was for those with prediabetes (0.31, SD 0.01),^96^ although this was beneath the threshold considered a MCID. However, a closer look at the DPP phase of the DPP/DPPOS data (years 1-3) shows that participants with diabetes making intensive lifestyle changes consistently reported meaningfully greater disutilities than those with prediabetes. Two studies from ADDITION-Europe used the EQ-5D to measure health utility. Both reported no meaningful difference between those with prediabetes and those with screen-detected diabetes—the ADDITION-Denmark study reported a disutility of 0.17 for those with prediabetes and 0.16 for those with screen-detected diabetes,^98^ and the ADDITION-Cambridge study reported a disutility of 0.15 for those with screen-detected diabetes.^102^

### Supplemental Question 6 What is the distribution of health impacts of diabetes without complications and prediabetes, measured using patient-reported, non-disease-specific health status measures?

Eleven studies (5 cross-sectional, 5 interventional, 1 longitudinal) provided QOL data relevant to SQ6 (Table 6). One provided data for individuals with screen-detected T2DM,^76^ three provided data for individuals with early uncomplicated T2DM,^109–111^ and nine provided data for those with prediabetes.^99,103,110–116^ The mean age of included populations ranged from 44 to 64, with sample sizes varying widely, from 19 to 7,632. Of the 11 included studies, 6 were conducted in Europe,^76,109–112,116^ 2 in the United States,^99,103^ 1 in Canada,^113^ 1 in Malaysia,^114^ and 1 across 27 countries worldwide.^115^ Of seven RCTs providing QOL data for the main evidence review, including data from the ADDITION-Europe trial,^76,95,117^ the Let’s Prevent Diabetes trial,^86,118^ the DPP,^80,97,119^ the PREDIAS trial,^112^ the Enhancing Fitness in Older Overweight Veterans with Impaired Glucose Tolerance trial,^120^ the SCALE trial,^115^ and the DESMOND trial,^93,94^ one (The Let’s Prevent Diabetes trial) provided a health utility index score and is included in SQ5, four (ADDITION-Europe, DPP, PREDIAS, and SCALE trials) are included in SQ6, and two (the DESMOND trial and the Enhancing Fitness in Older Overweight Veterans with Impaired Glucose Tolerance trial) provided QOL scores from one or more sub-scales but did not provide a summary or total score and were therefore excluded from SQ6.^93,120^ Appendix A provides additional details on measures of health status and quality of life used in studies addressing this Supplemental Question.

The distributions of QOL findings for those with screen-detected diabetes, early uncomplicated diabetes, and prediabetes are provided in Table 7. Overall, among studies that included a within-study comparison to a “no diabetes” group, screen-detected, early diabetes without complications, and prediabetes QOL scores were similar to populations without diabetes (with just one exception). Among studies that could only be compared with population norms (k=7, n=6,189) estimates suggest that individuals with screen-detected T2DM and early uncomplicated T2DM may have slightly lower QOL with respect to physical health but perhaps slightly greater QOL with respect to mental health, although differences were not compared statistically, differences were not greater than the upper bound of the range for a MCID, and distributions around the estimates were not always reported.

For screen-detected T2DM, we found no study comparing individuals with screen-detected T2DM with a group without diabetes. QOL scores from all four sites of the ADDITION-Europe trial reported SF-36 PCS scores ranging from 43.4 (10.5) to 47.0 (10.5), SF-36 MCS scores ranging from 52.2 (7.4) to 54.9 (8.5), and EQ-5D VAS scores ranging from 74.8 (18.4) to 78.4 (16.4).^76^ Comparing the results to the population norm, mean PCS scores were lower than the population norm of 50 points for the PCS summary scores, but higher than the population norm of 50 points for the MCS summary scores, suggesting lower QOL with respect to physical health but greater QOL with respect to mental health. Compared with each country’s population norm, individuals with screen-detected T2DM scored lower on the EQ-5D VAS, but the difference did not meet suggested criteria (7-8 points difference) for a minimally important difference.

For early diabetes without complications, two population-based studies (a cross-sectional and longitudinal study) compared individuals with newly diagnosed diabetes to a population without diabetes and found no difference in QOL scores between groups.^110,111^ Both studies reported similar mean SF-12/SF-36 PCS and MCS summary scores with PCS scores in the mid-40s and each with an MCS score of 52 (SD 9.3 in one study, NR in the other).^110,111^ A German study investigating the longer-term effects of a 12-week self-monitoring of blood glucose intervention reported much higher baseline scores on both the SF-36 PCS (65.2, SD NR) and the SF-36 MCS (68.0, SD NR).^109^ The study did not have a within-study “no diabetes” group, but the scores were significantly higher than the population norm of 50 for the PCS and MCS, suggesting that study participants were healthier than the general population.

For prediabetes, nine studies (5 cross-sectional, 3 intervention, 1 longitudinal) provided QOL data,^99,103,110–116^ with just four providing a within-study “no diabetes” group comparator.^103,110,111,116^ Although somewhat mixed, overall, most studies reported similar QOL using patient-reported, non-disease-specific health status measures for those with prediabetes compared with those without diabetes.

Of the four studies that included a within-study “no diabetes” comparator group, 2 reported no difference in SF-12/SF-36 QOL PCS and MCS summary scores between participants with prediabetes and those with normal glucose tolerance;^110,111^ one reported greater QOL scores among Polish men with normal glucose tolerance compared with those with prediabetes, although the reported scores were well above the population norm for the SF-36;^116^ and one study, which stratified results by BMI, reported significantly lower QOL scores with increasing levels of obesity but did not investigate whether the prediabetic group differed from the normal glucose group.^103^ Differences were not compared statistically, differences were not greater than the upper bound of the range for a MCID for each estimate, and distributions were not reported. However, the reported estimates from the study suggest that compared with participants without diabetes, those with prediabetes had lower scores for physical health but higher scores for mental health.^103^

Of the studies that did not have a within-study “no diabetes” comparator group, three reported summary PCS and MCS scores using the SF-12 or SF-36.^99,114,115^ Two of these reported scores largely similar to population norms,^99,115^ while one reported PCS and MCS scores far higher than the population norm of 50 for both the SF-36 PCS and MCS summary scores.^114^ Among other QOL measures employed, a cross-sectional study of 232 Canadians using the RAND-12 instrument to measure QOL reported a mean (SD) physical health composite score of 46.6 (9.9) and a mean (SD) mental health composite score of 45.2 (9.7),^113^ and Kulzer and colleagues reported a baseline mean QOL score (multiplied by 4 to provide a result on the 0-100 scale) of 57.2 (20) using the WHO-5 well-being index instrument.^112^ Because neither study had a within-study “normal glucose tolerance” comparison group and no other studies meeting eligibility criteria employed these instruments, the results can only be compared with population norms for each instrument (50 for the RAND-12 and 54-70 for the WHO-5) suggesting similar QOL scores for participants with prediabetes compared with the general population.

### Supplemental Question 7 What is the distribution of the health impact of diabetes without complications and prediabetes on length of life?

#### Prediabetes

Overall, results from both a recent systematic review and meta-analysis and some older observational studies consistently reported evidence of a significant association between prediabetes and increased risk of mortality.

A recent systematic review and meta-analysis (with 129 studies involving 10,069,955 persons) assessed the evidence regarding risk of mortality associated with prediabetes.^121^ Among 87 comparisons included, the meta-analysis estimated an increased relative risk of all-cause mortality of 1.13 (95% CI, 1.10 to 1.17) for individuals with prediabetes compared with those without prediabetes or diabetes over a median followup of 9.8 years. This relative risk of all-cause mortality translates to an absolute increase of 9.59 deaths per 10,000 person-years (95% CI, 7.36 to 12.51) for persons with prediabetes.

Meta-analyses identified some differences in estimates by criteria for prediabetes and by analysis subgroups.^121^ Meta-analyses of five of the nine definitions of prediabetes were associated with increased risk of all-cause mortality, including the three most frequent definitions (IFG criteria of the American Diabetes Association; IFG criteria of the World Health Organization; and IGT representing 20, 19, and 15 comparisons, respectively). In addition, studies found an increased risk of all-cause mortality in individuals with prediabetes compared with individuals with normal glucose/glycemia in analyses with an average participant age of 60 years or younger (RR, 1.16; 95% CI, 1.12 to 1.20) and in analyses with an average participant age of 60 years or older (RR, 1.08; 95% CI, 1.03 to 1.14). The estimates for the relative risk of mortality associated with prediabetes compared with normal glucose/glycemia were not significantly different for analyses considering Asian or non-Asian populations, men or women, sample size below or above 5,000, length of followup below or above 10 years, or adequacy of adjustment for confounding characteristics. Studies were considered to be adequately adjusted if they included at least five of the following six covariates: sex; age; hypertension, blood pressure, or antihypertensive treatment; BMI or other measure of overweight or obesity status; cholesterol; and smoking.

Several individual older studies also assessed the relationship between IGT and mortality, although thresholds and study designs varied. These studies generally provided age- or age- and sex-adjusted mortality rates by baseline glucose tolerance classification, but the analyses often did not adjust for other factors. Although these classifications of glucose tolerance do not always align with current thresholds used to define prediabetes, they often overlap and reflect a similar construct.

A study of 18,403 middle-aged male civil servants from London (the Whitehall study) estimated age-adjusted mortality rates for coronary heart disease (CHD) and all causes for two IGT groups relative to those with normal glucose tolerance; however, statistical comparisons of these were not conducted.^122^ Moderate IGT was defined as 2-hour blood glucose after 50-g oral load of 96 to 199 mg/dL, while “borderline diabetics” with more severe IGT was classified as 110 to 199 mg/dL. Seven-and-a-half-year age-adjusted CHD mortality was similar for moderate IGT and borderline diabetics at 49.1 and 49.0 per 1,000, respectively, compared with 23.5 per 1,000 for those with no IGT (we assumed the data were per 1,000 persons rather than per 1,000 person-years, although the article did not specify; also, no CIs were provided and no statistical comparisons were conducted). Similarly, all-cause mortality was similar among the two IGT groups at 94.5 and 94.3 per 1,000 for moderate and severe IGT, respectively, while the rate for those with no IGT was 59.4 per 1,000.

A more recent followup of the Whitehall study estimated differences in mortality by IGT and attributed differences in risk.^123^ This study found greater relative risks of stroke and CHD mortality for those in the IGT group compared with those in the normoglycemic group after adjusting for age, smoking status, cigarettes per day, work type, systolic blood pressure, cholesterol, BMI, electrocardiographic abnormality, and treatment for hypertension (approximately triple and double the relative risk, respectively; actual estimates and CIs not reported; data shown in bar graph only). Although some of this difference in risk of mortality was explained by characteristics they considered (i.e., age and systolic blood pressure), greater than 60 percent of the difference in risk of stroke and CHD mortality between the IGT and normoglycemic groups remained unexplained.

A similar study of male civil servants in Paris (the Paris Prospective Study) assessed differences in mortality by baseline IGT classification.^124^ They also found significant differences in CHD mortality incidence by baseline IGT classification with 1.9 times higher incidence of mortality for those with IGT compared with individuals with normal glucose tolerance (CHD mortality rates of 2.7 vs. 1.4 per 1,000, CIs not reported).

In a population study of nearly 27,000 individuals from Sweden, age- and sex-adjusted mortality rates for individuals with IGT were higher than for individuals with normal glucose tolerance (53.6 deaths/1,000 person-years; 95% CI, 45.4 to 61.9 vs. 37.9 deaths/1,000 person-years; 95% CI, 34.2 to 41.5).^125^

#### Diabetes Without Complications

Most of the evidence surrounding the relationship between diabetes without complications and mortality stems from a collection of cohort studies that focused on the association between “asymptomatic” hyperglycemia and cardiovascular disease and mortality as part of the International Collaborative Group (ICG).^126,127^ ICG included 15 studies from the 1960s to 1970s of middle-aged men from various countries with an established focus on asymptomatic diabetes, 11 of which were prospective studies with at least 4 years of followup.

These cohort studies generally followed similar designs and presented similar analyses.^126,127^ Although often parts of larger studies, analyses presented as part of the ICG focused on males generally ages 40 to 59 years at baseline (Table 6). Samples were often based on employer or insurer. Examples of populations include men in Chicago employed by Peoples Gas Company and Western Electric Co,^128^ policemen from Helsinki,^129^ and civil servants in Paris.^130^ At the beginning of the study, eligible participants completed health surveys and physical exams, including various measures of blood glucose. Based on these results, participants were classified into various categories often including normoglycemia, IGT, asymptomatic hyperglycemia, and known diabetes. Some studies excluded individuals with known diabetes, while others included them. Asymptomatic hyperglycemia was used to describe participants who reported no known diabetes at baseline but then whose blood sugar was above the respective threshold for diabetes during the initial screening. Because different studies used different measures of blood glucose, different thresholds and categorizations were also defined.^126^ Other common exclusion criteria were known cardiovascular disease, history of myocardial infarction, and use of antihypertensive medications.

These studies include a variety of analyses such as differences in mortality by decile, quartile, and quintile of blood glucose; differences in mortality by normoglycemia, impaired glucose tolerance, and hyperglycemia; and multivariate regressions of associations between blood glucose and mortality often controlling for age, systolic blood pressure, BMI, cholesterol, and smoking status or cigarette use. Importantly, these studies considered baseline blood glucose and the association with subsequent mortality.

Overall, although these studies often reported higher age-adjusted mortality rates among groups with the highest blood glucose, adjusted analyses presented limited and inconsistent evidence of the specific association between asymptomatic hyperglycemia and all-cause, cardiovascular-related, or CHD-related mortality (Table 8).^126^ Even though a positive relationship between blood sugar among those initially considered to have asymptomatic hyperglycemia and various types of mortality was sometimes found, many studies found no such relationship, and one study found a negative association.^127^

These studies have several important limitations. First, they focused on a narrow population of middle-aged men, often employed, and often white. Findings from these studies may not be generalizable to other populations. Second, those identified as not having been previously diagnosed with diabetes (as being “asymptomatic diabetics”) may not perfectly capture those who had diabetes without complications. Third, these studies varied in terms of their population, measure of blood glucose, thresholds for different categorizations, length of followup, exclusion criteria, and analyses. It has been suggested that these differences may be contributing to differences in results. Fourth, some of these studies had relatively small samples with few deaths, making it difficult to detect differences in rates of mortality. Finally, although these studies often controlled for a variety of known confounding variables, other characteristics may not have been considered, and many of the findings related to mortality are not from controlled regression analyses. The studies did not consider interventions received over the course of followup (e.g., lifestyle or weight loss interventions) or changes in weight or BMI over time.

Similar but more recent cohort studies have assessed the relationship between newly diagnosed diabetes and mortality. Mortality for a Danish population of 1,323 individuals with diabetes identified between 1989 and 1992 was assessed 16 years later compared with the general Danish population.^131^ This study found an increased risk of all-cause mortality in the followup period after diagnosis of diabetes compared with the general Danish population for both males and females and across the age groups considered. For example, in males ages 60 to 64 years, the hazard ratio (HR) for all-cause mortality for those with diabetes was 39.4 (95% CI, 29.4 to 52.8), and the HR for the general population using 2001 to 2005 mortality tables was 14.2 and using 1991-1995 mortality tables was 19.2. For females ages 60 to 64 years, the same HR was 15.3 compared with 9.2 and was 12.3 in the 2001 to 2005 and 1991 to 1995 life tables. The increased risk of mortality seemed to be greater among males. Even though this study adds more recent data than the ICG studies add and provides data for both males and females, it is not without important limitations. First, these measures were unadjusted; important potential confounders were not considered. Second, this study was part of a randomized trial. The intervention, referred to as “structured care,” included quarterly followup with their general practitioner to discuss treatment goals and progress and annual screenings for complications.^132^ The intervention was found to have no effect on mortality, so this study included individuals in both the intervention and comparison groups.^131^ Third, the comparison group is the general Danish population, not those without diabetes or prediabetes specifically. Finally, this study assessed differences in risk of mortality in the 16 years after incident diabetes diagnosis and was not specifically limited to persons who have diabetes without complications, although 30.4% had cardiovascular disease, 19.3% had peripheral neuropathy, and 4.8% had diabetic retinopathy at baseline.

A cohort study with matched controls (187,968 participants with diabetes, 908,016 matched controls) in the United Kingdom considered life expectancy for those with an incident diabetes diagnosis from 1998 to 2015 compared with the matched control group.^133^ In this study, they found a greater risk of all-cause mortality for those with type 2 diabetes mellitus compared with those without type 2 diabetes mellitus when controlling for gender, age ethnicity, deprivation index, and calendar year (adjusted HR, 2.19 [95% CI, 2.16 to 2.21]). This study also found greater risk of all other causes of mortality considered (except for suicide) for those with type 2 diabetes mellitus compared with those without.

### Supplemental Question 8 When informed patients with prediabetes are offered intensive lifestyle modification and/or metformin for diabetes prevention, what is the uptake and adherence with each strategy over time?

For this question, we adopted a two-pronged approach. First, we examined uptake and adherence in the trials that were included for KQ 7 of the evidence review (i.e., Do interventions for prediabetes delay or prevent progression to type 2 diabetes?). We note that our data on uptake and adherence from controlled trials may be limited by differences in characteristics between participants of trials and people initiating real-world interventions,^134^ differences in settings and locations between research and real-world settings,^135^ differences in recruitment between pragmatic observational research and randomized, controlled trials,^135^ and volunteer bias.^136^ Second, we searched for studies not eligible for the evidence review that describe uptake and adherence (e.g., observational studies of real-world uptake that should have good applicability) because KQ 7 of the evidence review included only controlled trials.

We defined uptake as the initiation of (or the decision to initiate) a lifestyle intervention or medication to prevent diabetes. Adherence for lifestyle interventions was defined as the percentage of participants who attended a given number of intervention sessions for studies with combined exercise and weight loss goals similar to the DPP (i.e., individual and group classes promoting 7% weight loss, 150 minutes/week of physical activity).^80^ For studies that primarily focused on exercise interventions, we defined adherence as the percentage of participants who met an exercise goal. Adherence within studies that assessed metformin was defined as the percentage of metformin doses taken. Eligible study designs included cross-sectional studies, longitudinal studies, and clinical trials. We required studies to include at least 100 participants. To focus on the most applicable evidence, we required observational studies to be conducted in the United States, although trials from KQ 7 were not limited to those conducted in the United States (they could be from any country with a very high Human Development Index).

#### Trials of Lifestyle Interventions Included in KQ 7

Among the lifestyle interventions for delaying or preventing the onset of type 2 diabetes mellitus, we identified relevant adherence data in 14 trials (Table 9).^36,80,86,87,118,120,137–146^

Three trials primarily focused on exercise.^120,137,138^ In one trial, the authors reported that the percentage of the intervention group that met the activity goal of 150 minutes of endurance exercise increased from 16 percent to 42 percent between baseline and the 12-month followup.^120^ In another trial, the authors reported that the intervention groups assigned to receive a group-based exercise condition with and without a pedometer increased their daily step count by an average of 708 and 421 steps, respectively, from baseline to 12 months.^138^ In the third exercise-based intervention, 25.0 percent of the lifestyle intervention group exercised 1 or more times a week at baseline compared with 42.9 percent at the 5-year followup.^137^

Among 10 trials that defined adherence as a percentage of counseling or educational sessions attended by participants,^36,86,87,139–145^ attendance ranged from 40 percent^139^ to 92.4 percent,^87^ with most studies reporting adherence greater than 50 percent (Table 9).

The DPP reported the proportion of participants who met the goal of at least 150 minutes of physical activity per week (assessed using logs kept by the participants).^80^ At 24 weeks, 74 percent of participants met the goal. At the most recent visit (over a mean 2.8 years followup) 58 percent met the goal.^80^ Regarding attendance at lifestyle intervention sessions, the DPP authors reported that the average percentage of participants who attended the quarterly lifestyle sessions offered between the original DPP and followup DPPOS study were 18 percent, 15 percent, and 14 percent in the groups originally randomized to lifestyle, metformin, and placebo, respectively.^146^ Additionally, the percentage who attended at least some of these sessions were 40 percent, 58 percent, and 57 percent for the lifestyle, metformin, and placebo groups, respectively.^146^

#### Trials of Metformin Included in KQ 7

Two trials reported uptake or adherence to metformin, both of which used metformin 850 mg twice daily (Appendix B4 Table 10).^79,142,147^ PREVENT-DM randomized 29 adults to the metformin group and uptake was high, with 89 percent (26 participants) taking at least one dose of medication, but adherence was comparatively low, with 37 percent (11 participants) taking at least 80 percent of dispensed doses.^142^ During the median 3.2 years of followup for the DPP, 89.2 percent (909 participants) took at least some portion of pills, and 71 percent (724 participants) took at least 80 percent of their dispensed doses.^147^ During the DPPOS, 49 percent of participants originally randomized to the metformin group took at least 80 percent of their metformin doses.^79^ The DPP reported that 84 percent of those taking metformin were given the full dose of 850 mg twice a day; the remainder were given one tablet a day to limit side effects.^80^

#### Studies Not in the Draft Evidence Review That Describe Uptake or Adherence

We found six studies in our new, targeted literature searches (Appendix B4 Table 10).^148–153^ Of those six, one trial (the Prediabetes Informed Decision and Education [PRIDE] trial) invited adults with prediabetes to participate in a shared decision making visit with a pharmacist where they were offered DPP-based ILI, metformin, or both;^148^ four trials offered DPP-based ILI;^149,151–153^ and one trial promoted resistance training.^150^

PRIDE was the only trial that offered shared decision making about both ILI and medication interventions to prevent diabetes.^148^ Twenty primary care clinics at UCLA Health were randomized to be intervention sites or not. Within the 10 intervention clinics, eligible patients with prediabetes were invited to schedule a visit with a pharmacist to learn about prediabetes and options for diabetes prevention. Propensity score matching was used to identify control patients from 10 usual care clinics. Pharmacists in the intervention arm of this study used a shared decision making aid developed by Healthwise, “Prediabetes: Which Treatment Should I Use.”^154^ The decision aid provided four possible options: ILI alone (the DPP lifestyle intervention), metformin alone, ILI plus metformin, or usual primary care. The decision aid included the absolute risk of developing diabetes at 3, 10, and 15 years’ followup in patients who underwent major lifestyle change, metformin plus information about lifestyle changes, or a placebo pill, and it presented the smallest risk of developing diabetes for the major lifestyle change condition at 3 and 10 years, but similar absolute risks of developing diabetes for major lifestyle change and for metformin at 15 years. Uptake of the lifestyle intervention or metformin (the study’s primary outcome) was higher among participants who received shared decision making than among controls at 4 months (38% vs. 2%). Among the 351 participants who completed the pharmacist-administered shared decision-making process, 23.4 percent (82 participants) completed at least one DPP lifestyle intervention session, 18.8 percent (65 participants) used any metformin, and 38.2 percent (134 participants) attended at least one DPP lifestyle session or used any metformin. About 74 percent (260 participants) among the shared decision-making group selected the DPP lifestyle intervention with or without metformin, and of these 260 participants, 32 percent (83 participants) adhered to this therapy by attending at least nine sessions.

The four trials that offered DPP-based ILI recruited participants only through advertisements,^149,151^ referrals,^152^ and testing events.^153^ In the only worksite-based intervention, uptake was low, with roughly 10 percent (217 participants) expressing an interest to participant in the program, and only 5 percent (117 participants) enrolling.^149^ In the Prevent trial, 85 percent (187 participants) completed at least four sessions of the initial intervention, and 65 percent (144 participants) completed at least four sessions of the initial intervention and one or more maintenance sessions.^151^ Adults with prediabetes or metabolic syndrome were referred by their primary care physician or self-referred to the Group Lifestyle Balance intervention and attended fewer meetings over time, reaching 52 percent (364 participants) by the fourth meeting.^152^ Adherence was higher in another study in which participants were recruited largely through community- and employer-based testing, with 89 percent (2,104 participants) completing [underlined: more than] four of 16 initial group sessions, and 73 percent (1,723 participants) attending [underlined: more than nine] of 16 initial group sessions.^153^

Resist Diabetes used newspaper, workplace, and church advertisements to recruit participants into a supervised resistance training trial.^150^ Prediabetic participants in this trial first underwent a 3-month run-in period, after which only participants who attended at least 17 of the 24 supervised training sessions were randomized to two different levels of supervised resistance training. During the 3-month run-in, 91 percent (154 participants) went to 22 of 24 supervised training sessions. Seventy-eight percent of the higher supervised group (61 participants) and 72 percent of the lower supervision group (57 participants) completed at least two resistance training sessions per week by month 9. By month 15, 53 percent of both groups (41 participants and 42 participants, respectively) completed at least two resistance training sessions per week.

Our criteria for selecting studies for this supplemental question had some limitations. First, we excluded studies with fewer than 100 participants. This resulted in exclusion of a study that assessed the intention to participate in ILI or use metformin to prevent diabetes.^155^ The study recruited 40 participants with prediabetes from a community health center and reported on the intention to participate before and after using a prediabetes decision aid pamphlet that communicated the absolute risk of developing diabetes for patients who used an intensive lifestyle intervention, metformin, or no treatment.^155^ The decision aid emphasized that ILI had greater efficacy than metformin in preventing diabetes using data from the DPP.^156^ The proportion of participants who expressed an intention to participate in ILI increased from 70 percent (28 participants) to 88 percent (35 participants) after using the pamphlet. The proportion of participants who expressed an intention to use metformin slightly decreased after using the pamphlet, from 25 percent (10 participants) to 23% (9 participants). Second, we excluded studies from countries other than the United States. This led to the exclusion of a very large study assessing uptake of and adherence to an ILI performed by the National Health Service (NHS) in the United Kingdom, the NHS DPP.^157^ In that study, 324,699 patients were referred to the NHS DPP, 46 percent (152,294 participants) attended the initial introductory nonintervention assessment, and 29 percent (96,442 participants) attended one or more group-based intervention sessions. At the time of the publication reporting the results of the assessment, enough time had elapsed for 32,665 of the 96,442 participants who had attended one or more group-based intervention sessions to complete the program, and 52 percent (17,252 participants) had attended at least 60 percent of the sessions.

### Supplemental Question 9 What is the association (from observational studies or others) between changes in fasting glucose levels or A1c levels and changes in risk for target organ damage?

Overall, the included studies consistently reported significant associations between baseline glucose or glycemic levels and risk for future target organ damage. Three studies were identified that examined the associations between glycemic or glucose levels as a continuous measure and risk for target organ damage,^66,89,158^ and six studies were identified that examined the effect of various baseline glucose or glycemia categories on risk for target organ damage (Appendix B4 Table 12).^85,122,159–162^ Two of the studies reported only unadjusted data,^158,161^ three adjusted for some potential confounders,^122,159,160^ and four adjusted for at least five of the following six variables: sex; age; hypertension, blood pressure, or antihypertensive treatment; body mass index or other measure of overweight or obesity status; cholesterol; and smoking.^66,85,89,162^

The three studies that examined the association between glycemic or glucose levels as a continuous measure and risk for target organ damage included two conducted in the United States^66,158^ and one conducted in New Zealand.^89^ Data included within these studies were collected in the 1990s^66,158^ and the 2000s.^89^ The U.S.-based ABC Study (n=2,386) reported that higher fasting glucose, A1c, and 2-h glucose were associated with increased risk of heart failure and adjusted for BMI, age, history of coronary artery disease and smoking, SBP and heart rate, left ventricular hypertrophy on electrocardiogram, and creatinine and albumin levels.^66^ The U.S.-based DPP study^158^ (n=2,476) reported that a higher baseline glucose level and 1-year effect size (1-year change in glucose) were associated with incident CVD, but the results were limited because only unadjusted data were included. Similar associations were found in a large New Zealand study^89^ (n=62,002) that reported that higher HbA1c levels were associated with increased risk of lower limb amputations when adjusting for gender, diabetes history, age at onset, smoking status, height, systolic blood pressure, and TC/HDL ratio.^89^

Six studies examined the effect of various baseline glucose or glycemia categories on risk for target organ damage. Two studies were conducted in the United States,^85,160^ one was conducted in New Zealand,^159^ and three were conducted in the United Kingdom.^122,161,162^ One study used data collected before 1980,^122^ two included data collected in the late 1980s and early 1990s,^85,161^ one collected data in the late 1990s through early 2000s,^160^ and two studies collected data during the 2000s.^159,162^

In a U.S.-based sample (n=26,111),^160^ complications of cardiovascular disease, microvascular complications, and macrovascular complications were significantly lower in those with normoglycemia compared with those with isolated IFG, isolated IGT, and IFG/IGT. However, data were only adjusted for age and sex. The study also found that participants with normoglycemia had a significantly lower prevalence of stroke than those with isolated IGT, but the findings were limited because of only adjusting for age and sex and not controlling for smoking, hypertension, cholesterol, and other important risk factors. In the U.S.-based Atherosclerosis Risk in Communities (ARIC) study (n=11,092),^85^ baseline fasting glucose levels above 100mg/dL were significantly associated with increased risk of coronary heart disease, stroke, and all-cause mortality when adjusted for age, sex, and race/ethnicity, but significance was lost after controlling for other risk factors (e.g., age, sex, race/ethnicity, LDL, HDL, triglyceride level, BMI, waist-to-hip ratio, hypertension, family history of diabetes, education, alcohol use, physical activity index score, smoking status, and glycated hemoglobin value) (Appendix B4 Table 12).

The Whitehall Study, which included male civil servants (n=18, 403),^122^ found that the degree of glucose intolerance was associated with mortality rates. Within the study, males within the normo-glycemic group (2-h glucose <96 mg/dL) had lower rates of mortality at 7.5 years compared with men in the impaired glucose tolerance group (2-h glucose 96-199mg/dL), those newly diagnosed with diabetes (2 h glucose ≥200 mg/dL), and those with known diabetes (both insulin and non-insulin dependent). The mortality rate was the highest among those with a 2-hour glucose >200 mg/dL. The results of the Whitehall study were limited because of only adjusting for age and not conducting statistical comparisons. The Whitehall II Study (n=5,427),^162^ which included a similar population, reported that men with normal glycemia had lower rates of CVD events or cardiovascular disease than those who had higher HbA1c and FPG at 11.5 years when adjusting for age, sex, ethnicity, previous CVD, smoking, total cholesterol, HDL cholesterol, systolic blood pressure, and antihypertensive treatment (Appendix B4 Table 12).

In the U.K. Diabetes Prospective Study (n=5,088),^161^ participants with lower FPG (<140 mg/dL[<7.8 mmol/l]) reported fewer adverse health outcomes (e.g., peripheral vascular disease, myocardial infarction, microvascular disease, diabetes-related deaths, and all-cause mortality) than those with intermediate (<180 mg/dL[<7.8 mmol/l to <10.0 mmol/l]) or high (>180 mg/dL[>10.0 mmol/l]) FPG. There was not a significant difference for strokes. Participants with intermediate FPG, compared with those with high FPG, had a lower risk of all complications except myocardial infarction and stroke. Participants with lower and intermediate FPG also were at a lower risk for progression of retinopathy. The results of the study were based on unadjusted data.

Last, a study conducted in New Zealand (n=31,148) also reported an association between baseline glucose levels and risk of organ damage and reported that participants with higher fasting glucose levels, higher 2-h glucose, and higher HbA1c had an increased risk of retinopathy, renal complications, neuropathy, and circulatory complications. Results were adjusted for age, sex, ethnicity, smoking history, and other glucose measures.^159^

Appendix B4 Table 1 Projected 10-Year Outcomes of Treating 10,000 Adults With Prediabetes With Metformin Compared With Intensive Lifestyle Interventions or No Intervention

| Intensive Lifestyle Intervention | Metformin—Start at Prediabetes Diagnosis | Metformin—Start at Diabetes Diagnosis | Usual Care or No Intervention
Benefits
All-cause deaths | Uncertain^*^ | Unknown | Unknown^†^ | Uncertain^*^
CVD deaths | Uncertain^*^ | Unknown | Unknown | Uncertain^*^
CVD events | Uncertain^*^ | Unknown | Unknown | Uncertain^*^
Myocardial infarction | Unknown | Unknown | Unknown^†^ | Unknown
Heart failure | Unknown | Unknown | Unknown | Unknown
Stroke | Unknown | Unknown | Unknown^†^ | Unknown
Aggregate microvascular outcomes (from DPP; this aggregate combines some intermediate outcomes with some health outcomes) | 753 (based on extrapolation from 11.3% [10.1-12.7] during DPPOS 15-year followup)^ǂ^ | 867 (based on extrapolation from 13.0% [11.7-14.5] during DPPOS 15-year followup)^ǂ^ | Unknown | 827 (based on extrapolation from 12.4% [11.1-13.8] during DPPOS 15-year followup)^ǂ^
ESRD | Uncertain^ǂ^ | Uncertain^ǂ^ | Unknown | Uncertain^ǂ^
Visual impairment (including blindness) | Uncertain^ǂ^ | Uncertain^ǂ^ | Unknown^†^ | Uncertain^ǂ^
Moderate to severe neuropathy | Uncertain^ǂ^ | Uncertain^ǂ^ | Unknown | Uncertain^ǂ^
Amputations | Unknown | Unknown | Unknown^†^ | Unknown
Skin ulcers | Unknown | Unknown | Unknown | Unknown
Harms
Psychological distress due to labeling or requirement to take medication | Unknown | Unknown | Uncertain^§^ | Unknown
Side effects of intervention (e.g., for metformin—nausea, diarrhea, etc.; for lifestyle intervention—joint pain) | Any GI adverse events (diarrhea, flatulence, nausea, vomiting): 1,290^ǁ^; Sprains or fractures: 2,867^¶^ | Any GI adverse events (diarrhea, flatulence, nausea, vomiting): 7,780^ǁ^; Sprains or fractures: 2,733^¶^ | Any GI adverse events (diarrhea, flatulence, nausea, vomiting): 3,890^ǁ^; Sprains or fractures: 2,733^¶^ | Any GI adverse events (diarrhea, flatulence, nausea, vomiting): 3,070^ǁ^; Sprains or fractures: 2,467^¶^
Opportunity costs (e.g., time for more physician visits because of being on a med; time for intensive lifestyle intervention) | 16 sessions (30-60 minutes) for ILI used in DPP over 24 weeks; ongoing maintenance sessions; 150 minutes of exercise weekly | Average of 2 additional office visits per year^79,163^; potentially additional trips or calls if having adverse effects (e.g., GI adverse events); calls or trips to the pharmacy to obtain medication | Average of 2 additional office visits per year after starting metformin^79,163^; potentially additional trips or calls if having adverse effects (e.g., GI adverse events); calls or trips to the pharmacy to obtain medication | No increased opportunity cost
Overdiagnosis | Estimated 5,000 people would have remained prediabetic or returned to normal without treatment over 10 years^#^ | Estimated 5,000 people would have remained prediabetic or returned to normal without treatment over 10 years^#^ | Estimated 5,000 people would have remained prediabetic or returned to normal without treatment over 10 years^#^ | None (if not tested or labeled with prediabetes); estimated 5,000 if they were tested and labeled^#^
Overtreatment | Uncertain; one might consider that there is no overtreatment because people should be following a similar healthy lifestyle for the overall health benefits | Uncertain, but at least 5,000 people (if that many were treated with metformin and would not have progressed to diabetes without treatment) | Uncertain; estimated as no overtreatment because this scenario assumes waiting until they have diabetes before treating, which is routine care (although some people will be treated without benefit) | None, not treated (assuming they were not tested or labeled)
Adherence to metformin and to counseling for lifestyle change | 58-74% in DPP^**^ | 72% during DPP during 3-year followup and 49% DPPOS during 15-year followup^**^ | Likely similar to metformin adherence estimates from DPPOS during 15-year followup | Not applicable

* Finnish Diabetes Prevention Study (FDPS) and Da Qing provided estimates for all-cause deaths in lifestyle intervention groups. Evidence remains uncertain because the estimates have wide confidence intervals (CIs) and there is a higher risk of bias with these trials. After 10 years, all-cause mortality in FDPS was 2.2 deaths per 1,000 person-years for intensive lifestyle intervention vs. 3.8 deaths per 1,000 person-years in control group (hazard ratio [HR], 0.57 [95% CI, 0.21 to 1.58]). Compositive CVD events were 22.9 vs. 22.0 events per 1,000 person-years (HR, 1.04 [95% CI, 0.72 to 1.51]). All-cause mortality in the Da Qing Diabetes Prevention Outcomes Study was not found to be reduced over 10 years. After 23 years in Da Qing, all-cause mortality was 28.1% for intensive lifestyle intervention vs. 38.4% for control (HR, 0.71 [95% CI, 0.51 to 0.99]). CVD-related mortality was 11.9% vs. 19.6% (HR, 0.59 [95% CI, 0.36 to 0.96]). KQ 4 of the evidence report has further details. The evidence from a different USPSTF topic, Behavioral Counseling Interventions to Promote a Healthy Diet and Physical Activity for CVD in Adults With CV Risk Factors (currently a draft report), includes the following in the abstract: behavioral counseling interventions were associated with a lower risk of cardiovascular events (pooled relative risk [RR]=0.80 [95% CI, 0.73 to 0.87]; 9 RCTs [n=12,551]; I2=0%), myocardial infarction (MI) (pooled RR=0.85 [95% CI, 0.70 to 1.02]; 6 RCTs [n=10,375]; I2=0%) and stroke (RR=0.52 [95% CI, 0.25 to 1.10]; 4 RCTs [n=9,800]; I2=0%), although the pooled effect was not statistically significant for stroke or MI.

† The UKPDS metformin for overweight substudy provided 10-year followup data, but those data are not starting from the time of diagnosis of prediabetes; they are from shortly after the time of diagnosis of diabetes. So, we do not have 10-year estimates for outcomes if we were to wait to treat with metformin for those whose A1c increased to 6.5 or higher. The data from the UKPDS metformin for overweight substudy could be considered for bounding, but those data would overestimate an upper bound. The study reported all-cause deaths in 50/342 (14.6%), myocardial infarction in 39/342 (11.4%), stroke in 12/342 (3.5%), risk of blindness in one eye in 3.5% (12/342), and amputation in 1.8% (6/342) over 10-year followup.

ǂ To convert 15-year data to 10-year estimates, we multiplied by two thirds. DPPOS provides information on nephropathy, neuropathy, and retinopathy as an aggregate microvascular events outcome, without reporting specific data by trial arm for each of the individual components of the aggregate outcome separately. The aggregate outcome included intermediate outcomes such as albuminuria on two consecutive spot urine samples and reduced GFR for nephropathy.

§ Multiple studies were identified that evaluated diabetes-related distress. However, most of those included many participants taking insulin with complications of diabetes such as neuropathy or who have had long-standing diabetes.^164–168^ One cross-sectional study conducted in Northern India assessed diabetes distress using the Diabetes Distress Scale (DDS) in a population with more recently diagnosed diabetes (n=410). Medical therapy is not described in this study, so it is unclear how many participants were on insulin. Further, it did not report how many participants had complications of diabetes such as neuropathy. It found that the prevalence of diabetes distress was 18% and that the major predictors for high diabetes distress scores were low education level, retinopathy, neuropathy, and hypertension (but it did not report the number of participants with each of those). Distress was not found to differ based on duration of diabetes (distress present had mean duration of 6.64 years compared with distress absent of 3.53 years).^169^

ǁ Data for any GI adverse events are based on extrapolation from 12.9 events per 100 person-years in DPP for ILI, 77.8 events per 100 person-years for metformin, and 30.7 events per 100 person-years for placebo. For the third column (Metformin–start at diabetes diagnosis), GI adverse events were based on the adverse event rate from the DPP (77.8 events per 100 person-years) and assuming that 50% progressed to diabetes over 10 years, using the rate of progression from 15-year DPPOS figures.

¶ Data for sprains or fractures are based on extrapolation from 15-year DPPOS data (4.3 events per 100 person-years for ILI, 4.1 events per 100 person-years for metformin, and 3.7 events per 100 person-years for placebo) and multiplying by two thirds.

# The estimate of 5,000 over 10 years was based on DPPOS 15-year figures (52% progressed to diabetes over 15 years, but figures in the publication indicate that it was already around 50% by 10 years). Overdiagnosis estimates are based on the assumption that a person who would have remained prediabetic or returned to normal glycemia/glucose was overdiagnosed.

** In the DPP, adherence for metformin was defined as taking medication 80% of the time. Lifestyle intervention: 74% met goal of 150 minutes of physical activity per week over 24 weeks and 58% at most recent visit at trial closure (over 3 years).

Note about QALYs: We had estimates for QALYs in an earlier version of this table but removed them because they were annual estimates, and we would need to multiply them by 10 to extrapolate over 10 years; however, that would assume that QALYs remain consistent each year (and they likely may not) and would neglect discounting over time. A modeling study^91^ estimated the QALYs of living with diabetes for 1 year of 0.7491 vs. 0.7302 for ILI and metformin, respectively.

Abbreviations: CI=confidence interval; CVD=cardiovascular disease; DDS=Diabetes Distress Scale; DPP=Diabetes Prevention Program; DPPOS=Diabetes Prevention Program Outcomes Study; ESRD=end-stage renal disease; FDPS=Finnish Diabetes Prevention Study; GI=gastrointestinal; GFR=glomerular filtration rate; HR=hazard ratio; ILI=intensive lifestyle intervention; KQ=key question; MI=myocardial infarction; QALY=quality-adjusted life-year; RCT=randomized, controlled trial; RR=relative risk; UKPDS=United Kingdom Prospective Diabetes Study; USPSTF=U.S. Preventive Services Task Force.

Appendix B4 Table 2 Health Utilities and Resulting Disutilities of Having Screen-Detected or Early T2DM Without Complications or Prediabetes

Study Author, Year | Study Description | Sample Size | Health Utility Index Score Mean (SD) | Disutility of Having the Condition (1-Utility Index Score) | Disutility of Not Having the Condition | Population Norm Disutility
Screen-detected T2DM
EQ-5D: Mean (SD) population norm utility index score=0.86 (0.50) for the U.S. and UK, 0.87 (NR) for Denmark, 0.89 for Netherlands, MCID=0.04-0.08
van den Donk, 2010^95^; Maindal, 2014^98^; Simmons, 2016^76^; Black, 2015^102^ | ADDITION-Europe Routine Care Group | 156; 463; 852; 312; 85; 157; 157; 144 | 0.83 (NR) Denmark (3 years); 0.84 (0.22) Denmark (5 years); 0.85^§^ (NR) UK Cambridge (baseline); 0.83 (0.22) UK Cambridge (5 years); 0.79 (0.23) UK Leicester (5 years); 0.81 (0.25)^^^ Netherlands (baseline); 0.82 (0.25)^^^ Netherlands (3 years); 0.82 (0.26)^^^ Netherlands (5 years) | 0.17; 0.16; 0.15; 0.17; 0.21; 0.19; 0.18; 0.18 | NA | 0.13^*^; 0.13; 0.14; 0.14; 0.14^*^; 0.11^*^; 0.11^*^; 0.11^*^
Early T2DM (Precomplications)
SF-6D: Mean (SD) population norm utility index score=0.79 (0.50), MID=0.03-0.04
Vaatainen, 2014^101^ | Cross-sectional, Finland | 47 | 0.75 (0.17)^^^ | 0.25 | 0.22^*^ | 0.21^*^
HRQOL 15-D: Mean (SD) population norm utility index score=0.86 (0.12), MID=0.015-0.03
Vaatainen, 2014^101^ | Cross-sectional, Finland | 47 | 0.88 (0.12)^^^ | 0.12 | 0.09^*^ | (0.14)^*^
QWB-SA: Mean (SD) population norm utility index score=0.64 (0.50), MID=0.03
DPP/DPPOS, 2012^96^ | DPP/DPPOS, placebo group, developed T2DM within 2 years of enrollment and anytime over the 10-year study period | 155: 2 years; 439: 10 years | 0.68 (NR); 0.67 (0.01)^^^ | 0.32; 0.33 | NA | (0.36)^*^; (0.36)^*^
Prediabetes
EQ-5D-3L: Mean (SD) population norm utility index score=0.86 (0.50) for the U.S. and UK, 0.8 (NR)7 for Denmark, MID=0.04-0.08
Maindal, 2014^98^ | ADDITION-Denmark control IGT Group | 156 | 0.84 (NR) | 0.16 | NA | 0.13
Leal, 2017^104^ | RCT, UK, Standard Care group | 433 | 0.82 (0.01) baseline; 0.81 (0.01) 6 months; 0.82 (0.01) 12 months; 0.80 (0.01) 24 months; 0.78 (0.01) 36 months | 0.18; 0.19; 0.18; 0.20; 0.22 | NA | 0.14^*^; 0.14^*^; 0.14^*^; 0.14^*^; 0.14^*^
SF-6D: Mean (SD) population norm utility index score=0.79 (0.50), MID=0.03-0.04
Vaatainen, 2014^101^ | Cross-sectional, Finland, IFG group | 75: IFG; 122: IGT | 0.77 (0.22)^^^; 0.75 (0.17)^^^ | 0.23; 0.25 | 0.22; 0.22^*^ | 0.21; 0.21^*^
Marrero, 2014^99^; Florez, 2012^97^ | DPPOS | 3,210 | 0.80 (0.10) | 0.20 | NA | (0.21)
Neumann, 2014^100^ | Cross-sectional, Sweden | 5,275: IFG; 2,261: IGT; 1,122: IFG & IGT | 0.76 (0.11); 0.75 (0.11); 0.75 (0.11) | 0.24; 0.25; 0.25 | 0.23; 0.23; 0.23 | 0.21^*^; 0.21^*^; 0.21^*^
DiBonaventura, 2015^103^ | Cross-sectional, U.S. | 1,441: Normal weight; 7,632: Overweight.; 6,087: Obese I; 2,421: Obese II; 2,331: Obese III | 0.75 (NR); 0.75 (NR); 0.73 (NR); 0.70 (NR); 0.68 (NR) | 0.25; 0.25; 0.27; 0.30; 0.32 | 0.25; (0.27); (0.28); 0.30; (0.31) | 0.21^*^; 0.21^*^; 0.21^*^; 0.21^*^; 0.21^*^
HRQOL 15-D: Mean (SD) population norm utility index score=0.86 (0.12), MID=0.015-0.03
Vaatainen, 2014^101^ | Cross-sectional, Finland, IFG group | 75: IFG; 122: IGT | 0.92 (0.09)^^^; 0.89 (0.11)^^^ | 0.08; 0.11 | (0.09); 0.09^*^ | (0.14)^*^; (0.14)^*^
Makrilakis, 2018^105^ | Cross-sectional, Greece | 172 | 0.90 (NR) | 0.10 | 0.09 | (0.14)^*^
Davies, 2016^86^ | Let’s Prevent Diabetes Lifestyle trial, UK, usual care group | 433 | Median (IQR); 0.91 (0.84, 0.96) Baseline; 0.89 (0.82, 0.95) 36 months | 0.09; 0.11 | NA | (0.14)^*^; (0.14)^*^
QWB-SA: Mean (SD) population norm utility index score=0.64 (0.50), MID=0.03
DPP/DPPOS, 2012^96^ | DPP/DPPOS, U.S., placebo group (mean over 10 years) | 1,082 | 0.68 (0.01)^^^ | 0.32 | NA | (0.36)^*^

Disutilities in parenthesis represent findings where the disutility of having diabetes/prediabetes was lower than that of not having diabetes/prediabetes or lower than the population norm disutility;

^ SD that was calculated using other information in the publication(s);

§ represents a median rather than a mean value;

* represents a disutility that meets suggested criteria for a minimally important difference compared with the diabetes/prediabetes group.

Abbreviations: DPP=Diabetes Prevention Program; DPPOS=Diabetes Prevention Program Outcomes Study; HRQOL=health-related quality of life; IFG=impaired fasting glucose; IGT=impaired glucose tolerance; IQR=interquartile ratio; MCID=minimally clinically important difference; MID=minimally important difference; NA=not applicable; NR=not reported; QWB-SA=quality of well-being self-administered; SD=standard deviation; T2DM=type 2 diabetes mellitus; UK=United Kingdom; U.S.=United States.

Appendix B4 Table 3 Distribution of Disutilities Associated with Taking Metformin

Study Author, Year | Study Description | Sample Size (metformin/placebo) | Health Utility Index for Those Taking Metformin | Disutility for Those Taking Metformin (1-Utility Index Score) | Disutility for Those Taking Placebo | Population Norm Disutility
Early T2DM (Precomplications)
QWB-SA: Mean (SD) population norm utility index score=0.64 (0.50), MID=0.03
DPP/DPPOS, 2012^96^ | DPP/DPPOS, Participants who developed T2DM | | 0.68 (0.02)^^^ mean over 10 years | 0.32 | 0.33 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS, Participants who developed T2DM | 11/39 | 0.72 (NR) 1 year | 0.28 | (0.31)^*^ | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS, Participants who developed T2DM | 98/155 | 0.68 (NR) 2 years | 0.32 | 0.32 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS, Participants who developed T2DM | 175/255 | 0.69 (NR) 3 years | 0.31 | (0.34)^*^ | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS, Participants who developed T2DM | 247/311 | 0.68 (NR) 4 years | 0.32 | (0.33) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS, Participants who developed T2DM | 278/341 | 0.67 (NR) 5 years | 0.33 | 0.33 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS, Participants who developed T2DM | 287/356 | 0.67 (NR) 6 years | 0.33 | (0.34) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS, Participants who developed T2DM | 314/379 | 0.67 (NR) 7 years | 0.33 | 0.33 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS, Participants who developed T2DM | 341/401 | 0.67 (NR) 8 years | 0.33 | 0.33 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS, Participants who developed T2DM | 363/423 | 0.66 (NR) 9 years | 0.34 | 0.34 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS, Participants who developed T2DM | 377/439 | 0.67 (NR) 10 years | 0.33 | (0.34) | (0.36)^*^
Prediabetes
SF-6D: Mean (SD) population norm utility index score=0.79 (0.50), MID=0.03-0.04
Marrero, 2014^99^ | DPPOS prediabetes group | 327/389 | 0.80 (NR) baseline | 0.20 | 0.20 | 0.21
Marrero, 2014^99^ | DPPOS prediabetes group | 318/379 | 0.78 (NR) 2 years | 0.22 | 0.21 | 0.21
Marrero, 2014^99^ | DPPOS prediabetes group | 231/302 | 0.78 (NR) 3 years | 0.22 | 0.22 | 0.21
Marrero, 2014^99^ | DPPOS prediabetes group | 231/302 | 0.76 (NR) 4 years | 0.24 | 0.24 | 0.21^*^
Marrero, 2014^99^ | DPPOS prediabetes group | 141/157 | 0.74 (NR) 5 years | 0.26 | 0.26 | 0.21^*^
Marrero, 2014^99^ | DPPOS prediabetes group | 141/157 | 0.72 (NR) 6 years | 0.28 | 0.27 | 0.21^*^
QWB-SA: Mean (SD) population norm utility index score=0.64 (0.50), MID=0.03
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 1,062/1,043 | 0.69 (NR) 1 year | 0.32 | 0.31 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 944/889 | 0.68 (NR) 2 years | 0.31 | (0.32) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 837/772 | 0.68 (NR) 3 years | 0.32 | 0.32 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 736/679 | 0.68 (NR) 4 years | 0.32 | 0.32 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 663/605 | 0.68 (NR) 5 years | 0.32 | 0.32 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 619/567 | 0.68 (NR) 6 years | 0.32 | 0.32 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 576/524 | 0.69 (NR) 7 years | 0.32 | 0.32 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 536/491 | 0.68 (NR) 8 years | 0.31 | 0.32 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 500/451 | 0.68 (NR) 9 years | 0.32 | (0.33) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 466/416 | 0.68 (NR) 10 years | 0.32 | 0.32 | (0.36)^*^

Disutilities in parenthesis represent findings where the disutility of taking metformin was lower than that of taking placebo or lower than the population norm disutility;

^ SD that was calculated using other information in the publication(s);

* represents a disutility that meets criteria for a suggested MCID compared with the group taking metformin.

Abbreviations: DPP=Diabetes Prevention Program; DPPOS=Diabetes Prevention Program Outcomes Study; MID=minimally important difference; NR=not reported; QWB-SA=quality of well-being self-administered; SD=standard deviation; SF-6D=Short Form Health Survey; T2DM=type 2 diabetes mellitus.

Appendix B4 Table 4 Distribution of Disutilities Associated With Making Intensive Lifestyle Changes

Study Author, Year | Study Description | Sample Size (Lifestyle/Placebo or Usual Care) | Health Utility Index for Those Making Intensive Lifestyle Changes | Disutility for Those Making Intensive Lifestyle Changes (1-Utility Index Score) | Disutility for Those Not Making Intensive Lifestyle Changes | Population Norm Disutility
Screen-detected T2DM
EQ-5D: Mean (SD) population norm utility index score=0.86 (0.50) for the U.S. and UK 0.8 (NR)7 for Denmark, MID=0.04-0.08
Maindal, 2014^98^ | Addition Denmark screen-detected T2DM group at 3 years | NR | 0.84 | 0.16 | NA | 0.13
Black, 2015^102^ | Addition Cambridge, screen-detected T2DM group | 739 | 0.85 3 years | 0.15 | NA | 0.14
Black, 2015^102^ | Addition Cambridge, screen-detected T2DM group | 663 | 0.85 5 years | 0.15 | | 0.14
Early T2DM (Precomplications)
QWB-SA: Mean (SD) population norm utility index score=0.64 (0.50), MID=0.03
DPP/DPPOS, 2012^96^ | DPPOS, placebo group who developed T2DM | | 0.67 (0.01)^^^ Mean over 10 years | 0.33 | 0.33 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPPOS, placebo group who developed T2DM | 10/39 | 0.67 (NR) 1 year | 0.33 | 0.31
DPP/DPPOS, 2012^96^ | DPPOS, placebo group who developed T2DM | 51/155 | 0.64 (NR) 2 years | 0.36 | 0.32^*^ | 0.36
DPP/DPPOS, 2012^96^ | DPPOS, placebo group who developed T2DM | 103/255 | 0.67 (NR) 3 years | 0.33 | (0.34) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPPOS, placebo group who developed T2DM | 151/311 | 0.65 (NR) 4 years | 0.35 | 0.33 | (0.36)
DPP/DPPOS, 2012^96^ | DPPOS, placebo group who developed T2DM | 186/341 | 0.66 (NR) 5 years | 0.34 | 0.33 | (0.36)
DPP/DPPOS, 2012^96^ | DPPOS, placebo group who developed T2DM | 227/356 | 0.68 (NR) 6 years | 0.32 | (0.34) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPPOS, placebo group who developed T2DM | 263/379 | 0.68 (NR) 7 years | 0.32 | (0.33) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPPOS, placebo group who developed T2DM | 288/401 | 0.67 (NR) 8 years | 0.33 | 0.33 | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPPOS, placebo group who developed T2DM | 302/423 | 0.68 (NR) 9 years | 0.32 | (0.34) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPPOS, placebo group who developed T2DM | 322/439 | 0.68 (NR) 10 years | 0.32 | (0.34) | (0.36)^*^
Prediabetes
EQ-5D: Mean (SD) population norm utility index score=0.86 (0.50) for the U.S. and UK 0.8 (NR)7 for Denmark, MID=0.04-0.08
Leal, 2017^104^ | Let’s Prevent Diabetes Intensive lifestyle intervention, UK, prediabetes group | 477/433 | 0.80 (0.01) 6 months | 0.20 | 0.19 | 0.14^*^
Leal, 2017^104^ | Let’s Prevent Diabetes Intensive lifestyle intervention, UK, prediabetes group | | 0.80 (0.01) 12 months | 0.20 | 0.18 | 0.14^*^
Leal, 2017^104^ | Let’s Prevent Diabetes Intensive lifestyle intervention, UK, prediabetes group | | 0.78 (0.01) 24 months | 0.22 | 0.20 | 0.14^*^
Leal, 2017^104^ | Let’s Prevent Diabetes Intensive lifestyle intervention, UK, prediabetes group | | 0.77 (0.01) 36 months | 0.23 | 0.22 | 0.14^*^
Maindal, 2014^98^ | Addition Denmark IGT group at 3 years | NR | 0.83 (NR) | 0.17 | NA | 0.13^*^
SF-6D: Mean (SD) population norm utility index score=0.79 (0.50), MID=0.03-0.04
Marrero, 2014^99^ | DPP/DPPOS prediabetes group | 327/389 | 0.80 (NR) baseline | 0.20 | 0.20 | 0.21
Marrero, 2014^99^ | DPP/DPPOS prediabetes group | 318/379 | 0.78 (NR) 2 years | 0.22 | 0.21 | 0.21
Marrero, 2014^99^ | DPP/DPPOS prediabetes group | 231/302 | 0.78 (NR) 3 years | 0.22 | 0.22 | 0.21
Marrero, 2014^99^ | DPP/DPPOS prediabetes group | 231/302 | 0.76 (NR) 4 years | 0.24 | 0.24 | 0.21^*^
Marrero, 2014^99^ | DPP/DPPOS prediabetes group | 141/157 | 0.74 (NR) 5 years | 0.26 | 0.26 | 0.21^*^
Marrero, 2014^99^ | DPP/DPPOS prediabetes group | 141/157 | 0.72 (NR) 6 years | 0.28 | 0.27 | 0.21^*^
QWB-SA: Mean (SD) population norm utility index score=0.64 (0.50), MID=0.03
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 1,069/1,043 | 0.70 (NR) 1 year | 0.30 | (0.31) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 988/889 | 0.70 (NR) 2 years | 0.30 | (0.32) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 917/772 | 0.70 (NR) 3 years | 0.30 | (0.32) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 827/679 | 0.70 (NR) 4 years | 0.30 | (0.32) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 747/605 | 0.69 (NR) 5 years | 0.31 | (0.32) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 674/567 | 0.69 (NR) 6 years | 0.31 | (0.32) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 620/524 | 0.69 (NR) 7 years | 0.31 | (0.32) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 585/491 | 0.69 (NR) 8 years | 0.31 | (0.32) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 553/451 | 0.69 (NR) 9 years | 0.31 | (0.33) | (0.36)^*^
DPP/DPPOS, 2012^96^ | DPP/DPPOS prediabetes group by year | 511/411 | 0.69 (NR) 10 years | 0.31 | (0.32) | (0.36)^*^
HRQOL 15-D: Mean (SD) population norm utility index score=0.86 (0.12), MID=0.015-0.03
Davies, 2016^86^ | Let’s Prevent Diabetes Lifestyle trial, UK, usual care group | 447/433 | Median (IQR) | 0.10 | NA | (0.14)^*^
Davies, 2016^86^ | Let’s Prevent Diabetes Lifestyle trial, UK, usual care group | | 0.90 (0.82, 0.95) baseline | 0.09 | | (0.14)^*^
Davies, 2016^86^ | Let’s Prevent Diabetes Lifestyle trial, UK, usual care group | | 0.91 (0.84, 0.96) 36 months

Disutilities in parenthesis represent findings where the disutility of making an intensive lifestyle intervention is lower than that of not making a lifestyle change or lower than the population norm disutility;

^ SD that was calculated using other information in the publication(s);

* represents a disutility that meets suggested criteria for a MCID compared with the group making intensive lifestyle changes

Abbreviations: DPP=Diabetes Prevention Program; DPPOS=Diabetes Prevention Program Outcomes Study; EQ-5D=EuroQol 5 dimensions; HRQOL=health-related quality of life; IGT=impaired glucose tolerance; IQR=interquartile ratio; MID=minimally important difference; NA=not applicable; NR=not reported; QWB-SA=quality of well-being self-administered; SD=standard deviation; SF-6D=Short Form Health Survey; T2DM=type 2 diabetes mellitus; UK=United Kingdom; U.S.=United States.

Appendix B4 Table 5 Disutilities of Prediabetes vs. Diabetes

Study Author, Year | Disutility of Having Prediabetes | Study Author, Year | Disutility of Having Screen-Detected or Uncomplicated Early Diabetes
Taking Metformin
QWB-SA: MID=0.03
DPP/DPPOS, 2012^96^ | Range: 0.31-0.32 | DPP/DPPOS, 2012^96^ | Range: 0.28-0.33
DPP/DPPOS, 2012^96^ | Mean (SD): 0.32 (0.004)^^^ | | Mean (SD): 0.32 (0.02)^^^
DPP/DPPOS, 2012^96^ | 0.31 (year 1, n=1,062) | | 0.28^*^ (year 1, n=11)
DPP/DPPOS, 2012^96^ | 0.32 (year 2, n=944) | | 0.32 (year 2, n=98)
DPP/DPPOS, 2012^96^ | 0.32 (year 3, n=837) | | 0.31 (year 3, n=175)
DPP/DPPOS, 2012^96^ | 0.32 (year 4, n=736) | | 0.32 (year 4, n=247)
DPP/DPPOS, 2012^96^ | 0.32 (year 5, n=663) | | 0.33 (year 5, n=278)
DPP/DPPOS, 2012^96^ | 0.32 (year 6, n=619) | | 0.33 (year 6, n=287)
DPP/DPPOS, 2012^96^ | 0.31 (year 7, n=576) | | 0.33 (year 7, n=314)
DPP/DPPOS, 2012^96^ | 0.32 (year 8, n=536) | | 0.33 (year 8 n=341)
DPP/DPPOS, 2012^96^ | 0.32 (year 9, n=500) | | 0.34 (year 9, n=363)
DPP/DPPOS, 2012^96^ | 0.32 (year 10, n=466) | | 0.33 (year 10, n=377)
Making Intensive Lifestyle Changes
EQ-5D-3L: MID=0.04-0.08
Maindal, 2014^98^; ADDITION-Denmark | 0.17 (n=108) | Maindal, 2014^98^; ADDITION-Denmark | 0.16 (n=174)
Maindal, 2014^98^; ADDITION-Denmark | | Black, 2015^102^; ADDITION-Cambridge | 0.15 (n=852)
QWB-SA: MID=0.03
DPP/DPPOS, 2012^96^ | Range: 0.30-0.31 | DPP/DPPOS, 2012^96^ | Range: 0.32-0.34
DPP/DPPOS, 2012^96^ | Mean (SD): 0.31 (0.005)^^^ | | Mean (SD): 0.33 (0.01)^^^
DPP/DPPOS, 2012^96^ | 0.30 (year 1, n=1,069) | | 0.33^*^ (year 1, n=10)
DPP/DPPOS, 2012^96^ | 0.30 (year 2, n=988) | | 0.36^*^ (year 2, n=51)
DPP/DPPOS, 2012^96^ | 0.30 (year 3, n=917) | | 0.33^*^ (year 3, n=103)
DPP/DPPOS, 2012^96^ | 0.30 (year 4, n=827) | | 0.35^*^ (year 4, n=151)
DPP/DPPOS, 2012^96^ | 0.31 (year 5, n=747) | | 0.34^*^ (year 5, n=186)
DPP/DPPOS, 2012^96^ | 0.31 (year 6, n=674) | | 0.32 (year 6, n=227)
DPP/DPPOS, 2012^96^ | 0.31 (year 7, n=620) | | 0.32 (year 7, n=263)
DPP/DPPOS, 2012^96^ | 0.31 (year 8, n=585) | | 0.33 (year 8, n=288)
DPP/DPPOS, 2012^96^ | 0.31 (year 9, n=553) | | 0.32 (year 9, n=302)
DPP/DPPOS, 2012^96^ | 0.31 (year 10, n=511) | | 0.32 (year 10, n=322)

^ SD that was calculated using other information in the publication(s);

* represents a disutility that meets suggested criteria for a MCID compared with the prediabetes group.

Abbreviations: DPP=Diabetes Prevention Program; DPPOS=Diabetes Prevention Program Outcomes Study; EQ-5D=EuroQol 5 dimensions; MID=minimally important difference; QWB-SA=quality of well-being self-administered.

Appendix B4 Table 6 Distribution of HRQOL Among Those With Screen-Detected or Early Uncomplicated T2DM and Those With Prediabetes

Study Author, Year | Study Description | Sample Size | HQOL Score (SD) for Participants with Diabetes or Prediabetes | QoL Score of Participants Who Do Not Have Diabetes or Prediabetes
Screen-detected T2DM
SF-36 PCS Score: Population norm mean (SD)=50 (10), MCID=3-5 points
Simmons, 2016^76^ | ADDITION-Europe trial, routine care group at 5 years F/U | Denmark: 428; Cambridge: 310; Leicester: 84; Netherlands: 144 | 46.7 (9.6); 44.6 (11.3); 43.4 (10.5); 47.0 (10.5) | NA
SF-36 PCS Score: Population norm mean (SD)=50 (10), MCID=3-5 points
Simmons, 2016^76^ | ADDITION-Europe Trial, Routine Care Group at 5 years F/U | Denmark: 428; Cambridge: 310; Leicester: 84; Netherlands: 144 | 54.9 (8.5); 54.6 (8.4); 52.2 (9.8); 53.7 (7.4) | NA
EQ-5D VAS Scores: Population norm for the VAS score mean (SD)=80 (20) for the U.S. and UK, 84 (26) for Denmark, and 82 (20) for the Netherlands, MCID=7-8 points
Simmons, 2016^76^ | ADDITION-Europe Trial, Routine Care Group at 5 years F/U | Denmark: 462; Cambridge: 316; Leicester: 88; Netherlands: 144 | 76.4 (18.5); 78.4 (16.4); 74.8 (18.4); 75.3 (15.6) | NA
Early T2DM (Precomplications)
SF-36 or SF-12 PCS Score: Population norm mean (SD)=50 (10), MCID=3-5 points
Hunger, 2014^111^ | Longitudinal study, Germany, baseline results | T2DM: 80; No DM: 453 | 45.3 (NR) | 45.3 (NR)
Seppala, 2013^110^ | Cross-sectional study, Finland | T2DM grp: 91; No DM: 973 | 44.3 (9.6) | 46.7 (9.5)
Kempf, 2012^109^ | Baseline results from a 12-week intervention study, Germany | 405 | 65.2 (NR) | NA
SF-36 or SF-12 PCS Score: Population norm mean (SD)=50 (10), MCID=3-5 points
Hunger, 2014^111^ | Longitudinal study, Germany, baseline results | T2DM: 80; No DM: 453 | 52.5 (NR) | 52.1 (NR)
Seppala, 2013^110^ | Cross-sectional study, Finland | T2DM grp: 91; No DM: 973 | 52.0 (9.3) | 53.5 (9.1)
Kempf, 2012^109^ | Baseline results from a 12-week intervention study, Germany | 405 | 68.0 (NR) | NA
Prediabetes
SF-36 or SF-12 PCS Scores: Population norm Mean (SD)=50 (10), MCID=3-5 points
Hunger, 2014^111^ | Longitudinal study, Germany, baseline results | Prediabetes: 442; No diabetes: 453 | 46.0 (NR) | 45.3 (NR)
Seppala, 2013^110^ | Cross-sectional study, Finland | IFG: 154; IGT: 165; No DM: 973 | 45.4 (9.8); 46.2 (9.5) | 46.7 (9.5)
Ibrahim, 2014^114^ | Cross-sectional, Malaysia, Total group | Total group: 268; Normal weight group: 19; Overweight group: 58; Obese group: 191 | 81.0 (13.2); 88.0 (9.8); 86.8 (11.1); 78.6 (13.3) | NA
Marrero, 2014^99^ | Baseline results from the DPP/DPPOS U.S. study, total group | 3,210 | 50.3 (7.1) | NA
DiBonaventura, 2015^103^ | Cross-sectional study, U.S. | Normal weight group: 1,441; Overweight group: 7,632; Obese I group: 6,087; Obese II group: 2,421; Obese III group: 2,331 | 50.2 (NR); 49.5 (NR); 47.7 (NR); 45.2 (NR); 42.5 (NR) | 52.8 (NR)^^^; 51.9 (NR)^^^; 51.1 (NR)^^^; 49.9 (NR)^^^; 47.9 (NR)^^^
le Roux, 2017^115^ | SCALE Obesity and Prediabetes trial. Placebo group | 749 | 46.6 (9.0) baseline; 49.2 (7.6) 3 years | NA
Rabijewski, 2018^116^ | Cross-sectional study, Poland, Men only | Prediabetes: 176; No DM: 184 | 79.0 (13.5) | 81.0 (13.9)^*^
SF-36 or SF-12 MCS Scores: Population norm mean (SD)=50 (10), MCID=3-5 points
Hunger, 2014^111^ | Longitudinal study, Germany, baseline results | Prediabetes:442; No diabetes: 453 | 52.9 (NR) | 52.1 (NR)
Seppala, 2013^110^ | Cross-sectional study, Finland | IFG: 154; IGT: 165; No DM: 973 | 54.6 (7.6); 53.9 (8.2) | 53.5 (9.1)
Ibrahim, 2014^114^ | Cross-sectional, Malaysia, Total group | Total group: 268; Normal weight group: 19; Overweight group: 58; Obese group: 191 | 83.9 (11.5); 85.2 (13.1); 85.6 (9.6); 83.1 (11.9) | NA
Marrero. 2014^99^ | DPP/DPPOS U.S. study, total group | 3210 | 54.0 (7.5) | NA
DiBonaventura, 2015^103^ | Cross-sectional study, U.S. | Normal weight group: 1441; Overweight group: 7,632; Obese I group: 6,087; Obese II group: 2,421; Obese III group: 2,331 | 51.4 (NR); 51.6 (NR); 51.1 (NR); 50.8 (NR); 49.7 (NR) | 48.3 (NR)^^^; 47.8 (NR)^^^; 46.6 (NR)^^^; 46.0 (NR)^^^; 45.8 (NR)^^^
le Roux, 2017^115^ | SCALE Obesity and Prediabetes trial. Placebo group | 749 | 54.0 (8.0) baseline; 52.6 (9.2) 3 years | NA
Rabijewski, 2018^116^ | Cross-sectional study, Poland | Prediabetes: 176; No DM: 184 | 80.0 (14.2) | 83 (14.3)^*^
RAND-12 PHC Score: Population norm mean (SD)=50 (10), MCID=3-5 points
Taylor, 2010^113^ | Cross-sectional study, Canada | 232 | 46.6 (9.9) | NA
RAND-12 MHC Score: Population norm mean (SD)=50 (10), MCID=3-5 points
Taylor, 2010^113^ | Cross-sectional study, Canada | 232 | 45.2 (9.7) | NA
WHO-5 Well-Being Index: Population norm mean (SD)=70 (NR), MCID=10 points
Kulzer, 2009^112^ | Prevention of Diabetes Self-Management Program (PREDIAS) trial, control group | 91 | 14.3 (4.9) baseline; 14.3 (5.1) 1 year | NA

* Significant difference between the diabetes/prediabetes group and the group with no diabetes;

^ Differences between the diabetes/prediabetes group and the “no diabetes” group were not provided;

Abbreviations: DPP=Diabetes Prevention Program; DPPOS=Diabetes Prevention Program Outcomes Study; EQ-5D=EuroQol 5 dimensions; HRQOL=health-related quality of life; IFG=impaired fasting glucose; IGT=impaired glucose tolerance; MHC=mental health composite score; MCID=minimally clinically important difference; NA=not applicable; NR=not reported; PHC=physical health composite score; SD=standard deviation; T2DM=type 2 diabetes mellitus; UK=United Kingdom; U.S.=United States.

Appendix B4 Table 7 ICG Study and Sample Characteristics

Author, Year | Location/Study Name | Baseline Year(s) | Sample Size and Description^*^ | Mean Age (SD) | Years of Followup | Glucose Measure Used in Multivariate Analyses | Mean Glucose (SD) | Distribution of Glucose Measure by Quintile
Stamler et al, 1979^170^ | Chicago Heart Association Study | 1972-1973 | 7,841 men employed in various industries in Chicago ages 40-59 | 48.7 (5.6) | 5 | One-hour plasma glucose | 146.5 mg/dL (46.9) | Quintile 1: 40-108 mg/dL; Quintile 2: 109-126; Quintile 3: 127-149; Quintile 4: 150-178; Quintile 5: 179-564
Stamler et al, 1979^128^ | Chicago Peoples Gas Company Employees | 1962 | 891 white male employees of Peoples Gas Company ages 45-64 | NA | 13 | Casual plasma glucose determination | NA | Quintile 1: 70-88 mg/dL; Quintile 2: 89-96; Quintile 3: 97-104; Quintile 4: 105-118; Quintile 5: 119-265
Stamler et al, 1979^128^ | Chicago Peoples Gas Company Employees | 1965 | 865 white male employees of Peoples Gas Company ages 40-64 | 52.9 (6.7) | 10 | Plasma glucose 1 hour after 50-g oral load | 141.4 mg/dL (40.6) | Quintile 1: 58-107 mg/dL; Quintile 2: 108-125; Quintile 3: 126-145; Quintile 4: 146-173; Quintile 5: 174-435
Stamler et al, 1979^128^ | Chicago Western Electric Employees | 1960 | 1,694 white male employees of Western Electric Company employees, ages 42-58 | 49.9 (4.5) | 15 | Two-hour post-load serum glucose after 100-g load | 101.1 mg/dL (33.0) | Quintile 1: 42-77 mg/dL; Quintile 2: 78-89; Quintile 3: 90-102; Quintile 4: 103-119; Quintile 5: 120-420
Stenhouse et al, 1979^171^ | Busselton Population Study | 1966 | 649 men ages 40-59 from Busselton, Australia | 49.0 (5.7) | 11 | One-hour post-load plasma glucose | 100.7 mg/dL (31.9) | Quintile 1: 42-75 mg/dL; Quintile 2: 76-88; Quintile 3: 89-100; Quintile 4: 101-122; Quintile 5: 123-415
Reunanen et al, 1979^172^ | Finnish Social Insurance Institution’s Coronary Heart Disease Study | 1966-1972 | 3,351 men ages 40-59, samples from nine municipalities and three factories | 48.5 (5.8) | 4 | One-hour post-load plasma glucose | 161.1 m/dL (52.8) | Deciles provided for participants examined before and after 12 pm (presented as:; Decile X: before 12 pm/after 12 pm); Decile 1: 52-9 6 mg/dL/52-115 mg/dL; Decile 2: 97-107/116-135; Decile 3: 108-119/136-149; Decile 4: 120-130/150-162; Decile 5: 131-142/163-178; Decile 6: 143-156/179-192; Decile 7: 157-173/193-207; Decile 8: 174-193/208-228; Decile 9: 194-221/229-250; Decile 10: 222-506/251-473
Pyorala et al, 1979^129^ | Helsinki Policemen Study | 1966-1967 | 867 Helsinki policemen ages 40-59 | 47.4 (4.9) | 10 | One-hour post load blood glucose | 119.6 mg/dL (37.9) | Quintile 1: 30-62 mg/dL; Quintile 2: 63-73; Quintile 3: 74-84; Quintile 4: 85-99; Quintile 5: 100-334
Ducimetiere et al, 1979^130^ | Paris Prospective Study | 1967-1972 | 6,589 men working in the Paris Civil Services ages 42-53 | 47.1 (1.9) | 5 | Two-hour post load glucose (75-g glucose load) | 103.3 mg/dL (35.3) | Quintile 1: 30-77 mg/dL; Quintile 2: 78-90; Quintile 3: 91-105; Quintile 4: 106-125; Quintile 5: 126-540
Da Silva et al, 1979^173^ | Basle Longitudinal Study, Switzerland | 1965-1968 | 1,499 men ages 40-59 in Basel, Switzerland | 48.8 (5.6) | 5 | Two-hour post load blood glucose | 107.0 mg/dL (25.1) | Quintile 1: 26-90 mg/dL; Quintile 2: 91-100; Quintile 3: 101-109; Quintile 4: 110-121; Quintile 5: 122-320
Fuller et al, 1979^174^ ^†^ | Whitehall Study, London | 1969 | 18,403 men working as London civil servants ages 40-64 | 50 (NA) | 5 | Two-hour post load blood glucose (50-g glucose load) | 75.4 mg/dL (16.2) | Quintile 1: 27-65; Quintile 2: 66-71; Quintile 3: 72-76; Quintile 4: 77-93; Quintile 5: 83-504
Schroll & Hagerup, 1979^175^ | Glostrup Population Studies, age 50 cohort | 1964 | 375 50-year old males from Glostrup, Denmark | 50 | 10 | Fasting blood glucose | 86.0 mg/dL (11.5) | Quintile 1: 50-76 mg/dL; Quintile 2: 77-83; Quintile 3: 84-89; Quintile 4: 90-95; Quintile 5: 96-225
Hawthorne & Gilmour, 1979^176^ | Renfrew, Scotland | 1972 | 1,134 males from Renfrew, Scotland, ages 45-64 Separate analyses with anti-hypertensive included/excluded | 54.2 (5.5) | 6 | “Casual blood glucose”^‡^ | 96.2 mg/dL (26.7) | Quintile 1: 27-80 mg/dL; Quintile 2: 81-88; Quintile 3: 89-96; Quintile 4: 97-107; Quintile 5: 108-518

* This column contains the sample size for which the demographics of the sample were provided; sample size in actual regression models may differ from this and each other.

† Baseline year, average age, and average glucose were not in the Fuller^126^ publication, so these were taken from the ICG introduction paper.

‡ Authors describe this measure as follows: “Blood samples were collected afternoons and evenings. A 10ml casual sample of venous blood was taken without venous stasis and plasma total cholesterol was measured by an autoanalyzer technique. Glucose was determined (using whole blood) by the measurement of oxygen consumption.”

Abbreviations: ICG=International Collaborative Group; NA=not available; SD=standard deviation.

Appendix B4 Table 8 Associations Between Glucose Measure and All-Cause, Cardiovascular Disease-Related, and CHD-Related Mortality From ICG Studies

Author, Year; Study Name | Glucose/Diabetes Measure | All-Cause Deaths/Sample Size | All-Cause Mortality Estimate | Cardiovascular Disease-Related Deaths/Sample Size | Cardiovascular Disease-Related Mortality Estimate (error estimate) | CHD-Related Deaths/Sample Size | CHD-Related Mortality Estimate | Covariates Adjusted for in Models
Stamler, 1979; Chicago Heart Association Study^170^ | One-hour post-load plasma glucose | 169/6,595 | 0.00409^*^; (SE 0.00175) | 80/6,506 | 0.00115; (SE 0.00253) | 67/6,493 | 0.00085; (SE 0.00277) | Age, SBP, BMI, cholesterol, number of cigarettes, ex-smoker
Stamler, 1979 Peoples Gas Company 1965 cohort^128^ | One-hour post-load plasma glucose | 116/840 | 0.00958^**^; (SE 0.00261) | 53/777 | 0.01295^**^; (SE 0.00378) | 40/764 | 0.01395^***^; (SE 0.00432) | Age, SBP, BMI, BMI^2^, cholesterol, number of cigarettes
Stamler, 1979 Peoples Gas Company 1962 cohort^128^ | Casual plasma glucose | 190/891 | −0.00514; (SE 0.00362) | 103/804 | −0.01007^*^; (SE 0.00480) | 70/771 | −0.00921; (SE 0.00566) | Age, SBP, relative weight, cholesterol, number of cigarettes, pulse
Stamler, 1979; Western Electric Co^128^ | Two-hour post-load serum glucose | 271/1,694 | −0.00187; (SE 0.00207) | 166/1,589 | −0.00217; (SE 0.00261) | 136/1,595 | −0.00272; (SE 0.00287) | Age, SBP, BMI, cholesterol, number of cigarettes
Stenhouse, 1979; Busselton Population Study^171^ | One-hour post-load plasma glucose | 56/638 | 0.0001; (t 0.35) | 21/603 | −0.0003; (t −1.06) | 18/600 | −0.0002; (t −0.78) | Age, SBP, relative weight, cholesterol, cigarette smoking
Reunanen, 1979; Finnish Coronary Heart Disease Study^172^ | One-hour post-load plasma glucose | 121/3,267 | 0.002; (SE 0.002) | 64/3,212 | −0.001; (SE 0.003) | 38/3,186 | −0.007; (SE 0.003) | Age, SBP, BMI, cholesterol, smoking status
Pyorala, 1979; Helsinki policemen^129^ | One-Hour post-load blood glucose | 70/845 | 0.002; (SE 0.003) | 42/817 | 0.002; (SE 0.004) | 31/806 | 0.004; (SE 0.004) | Age, SBP, BMI, plasma cholesterol, smoking status
Ducimetiere, 1979; Paris Prospective Study^130^ | Two-hour post-load plasma glucose | 142/6,484 | 0.006^**^; (SE 0.002) | 41/6,373 | 0.003; (SE 0.003) | 35/6,377 | 0.002; (SE 0.004) | Age, SBP, BMI, cholesterol, cigarette use
Da Silva, 1979; Basle Longitudinal Study^173^ | Two-hour post-load plasma glucose | 34/1,491 | 0.01184; (SE 0.00709) | 12/1,469 | 0.01004; (SE 0.01191) | 7/1,464 | 0.00383; (SE 0.01569) | Age, SBP, BMI, β-lipoproteins, number of cigarettes
Fuller, 1979; Whitehall Study- ages 40-59^174^ | Two-hour post-load plasma glucose | 414/14,756 | −0.001; (t −0.45) | 206/14,756 | 0.002; (t 0.60) | 166/14,756 | 0.003; (t 1.01) | Age, SBP, weight/height^2^, cholesterol, smoking status
Fuller, 1979; Whitehall Study- ages 40-64^174^ | Two-hour post-load plasma glucose | 559/16,873 | 0.0003; (t 0.12) | 275/16,873 | 0.003; (t 1.10) | 221/16,873 | 0.004; (t 1.48) | Age, SBP, weight/height^2^, cholesterol, smoking status
Hawthorne, 1979; Renfrew, Scotland; Those taking antihypertensive medications excluded^176^ | “Casual blood glucose” | 60/1,128 | 0.007; (SE 0.005) | 29/1,097 | 0.014; (SE 0.007) | 22/1,090 | −0.009; (SE 0.009) | Age, SBP, relative weight, cholesterol, cigarettes/day, ex-smoker
Hawthorne, 1979; Renfrew, Scotland; Those taking antihypertensive medications included^176^ | “Casual blood glucose” | 100/1,326 | 0.008; (SE 0.004) | 54/1,280 | 0.011^*^; (SE 0.005) | 39/1,265 | −0.000; (SE 0.007) | Age, SBP, relative weight, cholesterol, cigarettes/day, ex-smoker
Schroll, 1979; Glostrup Population Studies – age 50 cohort^175^ | Fasting blood glucose | 43/375 | −0.0038; (SD 0.0152) | | | | | Glucose, SBP, BMI, cholesterol, smoking status (1-14/day, 15-24/day, 25+/day, ex-smokers)

* p<0.05,

** p<0.001,

*** p<0.01

Note: The mortality estimates represent the association between the continuous measure of glucose used in the study and the risk of mortality during the followup period, adjusting for confounders listed in the “Covariates Adjusted for in Model” column. A positive estimate suggests greater levels of the measure of glucose is associated with increased risk of mortality in the study followup period.

Abbreviations: BMI=body mass index; CHD=coronary heart disease; ICG=International Collaborative Group; SBP=systolic blood pressure; SD=standard deviation; SE=standard error.

Appendix B4 Table 9 Trials of Lifestyle Interventions Included in KQ 7

Author, Year, Study Name | Source of Participants | Number of Participants | Intervention | Uptake | Adherence
Morey, 2012, Enhanced Fitness^120^ | Screening medical records | 180 | Counseling intervention with exercise prescriptions | None | Proportion of participants who performed 150 minutes of endurance exercise increased over time from 16% to 42%.
Lindahl, 2009^137^ | Recruited from an ongoing community intervention for cardiovascular and diabetes | 100 | 1-month residential program with activity and diet goals followed by additional learning and telephone contact | None | For the 83 ITT sample, 25.0% exercised ≥1 times a week at the start of intervention. At one-, three, five-years, 66.3%, 46.6%, and 42.9% exercised ≥1 times a week, respectively.
Yates, 2009, PREPARE^138^ | Recruited from ongoing population-based diabetes screening programs | 33 PREPARE & Pedometer; 31 PREPARE | Single-session group session. One group was given a pedometer and one group was not. | None | Change in steps/day compared to baseline (95% CI). No pedometer: 3 months 475 steps (−112 to 1,064); 6 months 154 steps (−582 to 889); 12 months 421 steps (−224 to 1,067); With pedometer: 3 months 1605 steps (712 to 2498), 6 months 1,083 (517 to 1649), 12 months 708 steps (72 to 1344)
Ackermann, 2015, RAPID^139^ | Electronic medical records | 257 | DPP-based intervention at YMCA | 161/257 (62.6%) attended at least one session | 40% (103/257) completed ≥9 sessions
Sakane, 2015, J-DOIT1^140^ | Internet advertising and direct contact invited community healthcare divisions and worksites | 1240 | Telephone counseling sessions at different frequencies promoting exercise and diet goals | None | The mean number of responses to the calls during the 1-year period was 2.8±0.6 (range 1–3) in centre A, 5.2 ±1.9 (range 1–6) in centre B, and 8.2±3.5 (range 1–13) in centre C. The rates of good adherence were 91.4%, 82.7%, and 81.1% for each centre, respectively.
Davies, 2016, Let’s Prevent Diabetes^86^ | Recruited from community practices | 447 | Group-based ILI | 346/447 attended the first session | 248 participants, 55%, of the intervention participants attended the core session and at least one refresher session. 130 participants, 29%, attended all sessions.
Bhopal, 2014^36^ | Direct referral from healthcare professionals, written invitations to potential recruits from general practices, community recruitment | 85 | Families in the intervention group had 15 visits from a dietitian over 3 years | None | 84/85 were present for year 3 followup with dietician; Attendance ranged from 72/85 to 84/85 over the 15 home visits
Saito, 2011, Zensharen^87^ | Nationwide recruitment of hospitals and clinics | 311 | Individualized instruction on diet and exercise | None | 92.4% attended at least 9 scheduled visits
Van Name, 2016^141^ | Electronic patient registry | 61 | DPP-based intervention | None | 4 participants (7%) attended 0–2 classes, 42 participants (68%) attended at least 14 classes
O’Brien, 2017, PREVENT-DM^142^ | Community health fairs at Latino-serving community health centers | 33 | DPP-based intervention | 30/33 attended at least one session | 23/33 (69.6%) attended at least 9 sessions
Hellgren, 2014^143^ | FINDRISC questionnaire sent to individuals and those with a risk score ≥15 were invited | 19 (adherence data for only 15 who remained at 1 year) | Group sessions focused on physical activity | None | 53% attended 8/8; 80% attended 7/8
Katula, 2013, HELP-PD^144^ | Mass mailings to local zip codes | 151 | DPP-based intervention | None | Participants attended 58.6% of intervention sessions, made up 18.7%, and missed 22.8%
Juul, 2016^145^ | Referrals from general practices | 63 | Group sessions focused on diet and physical activity | None | Attendance rates of the sessions were 95%, 88%, 87%, 73%, 67%, and 51%
Knowler, 2002, DPP^80^ | Mass media, mail, and telephone contacts; recruitment through employment, social groups, and healthcare systems | 1,079 | Individual and group lessons promoting 7% weight loss and at least 150 minutes of exercise weekly | None | 74% and 58% of participants met 150 minutes of physical activity goal at 24 weeks and 2.8 years, respectively

Abbreviations: CI=confidence intervals; DPP=Diabetes Prevention Program; ILI=intensive lifestyle intervention; ITT=intent-to-treat.

Appendix B4 Table 10 Trials of Metformin Included in KQ 7

Author, Year, Study Name | Source of Participants | Number of Participants | Intervention | Uptake | Adherence
O’Brien, 2017, PREVENT-DM^142^ | Community health fairs at Latino-serving community health centers | 29 | Metformin 850 mg twice daily | 26/29 took at least 1 dose of medication | 11/29 took at least 80% of dispensed doses
Knowler, 2002, DPP^80^ | Mass media, mail, and telephone contacts; recruitment through employment, social groups, and healthcare systems | 1,079 | Metformin 850 mg twice daily | 89.2% of metformin group, 91.1% of placebo group took at least some of their pills over time during the original DPP | During DPP, adherence in the original metformin group measured by pill count and defined as ≥80% of pills taken was ~70% during DPP and ~49% over the entire DPPOS

Abbreviations: DPP=Diabetes Prevention Program; DPPOS=Diabetes Prevention Outcome Study.

Appendix B4 Table 11 Studies Not in the Draft Evidence Review That Describe Uptake or Adherence

Author, Year, Study Name | Source of Participants | Number of Participants | Intervention | Uptake | Adherence
Moin, 2019, PRIDE^148^ | Electronic medical record search for prediabetic patients, referrals | 351 | Pharmacist-delivered shared decision making aide offering metformin, DPP, or both | None | 83 of the 260 who chose DPP (with or without metformin) completed ≥ 9 DPP sessions
Zigmont, 2018^149^ | Company intranet and worksite advertisements | 2,158 | DPP-based ILI delivered at worksite | 5% (117 participants) enrolled | None
Davy, 2017, Resist Diabetes^150^ | Newspaper, workplace, and church advertisements | 170 | Supervised resistance training sessions | None | 159/170 (93.5%) went to at least 17/24 sessions for prospective cohort phase (initiation phase); 91% went to 22 of 24 sessions for first 3 months (initiation phase). Self-reported adherence (at least 2 sessions a week) among those present at 9 months was 72% and 78% for low-supervision and high-supervision groups, respectively. At month 15, adherence was 53% in both groups.
Sepah, 2014, Prevent^151^ | Online advertisements | 220 | Online version of DPP | None | 187/220 completed ≥4 core lessons. 144/220 completed ≥4 core lessons and ≥1 post-core lesson. 68.4% of 187 core participants completed all 16 core lessons. 187 core participants completed an average of 13.8 core lessons and an average of 3.2 post-core lessons
Wardian, 2018, GLB^152^ | Self-referral or primary care physician referral | 704 | DPP-based ILI | None | 704/704 attended the baseline meeting, 492/704 attended week 5 meeting, 385/704 attended week 9 meeting, 364/704 attending week 12 meeting
Vojta, 2013, YMCA DPP^153^ | Referrals and community/employer-based testing events with onsite counseling | 2,369 | DPP-based ILI delivered at YMCA | None | 1,723/2,369 completed ≥9/16 core sessions. 2,104/2,369 completed ≥4 core sessions

Abbreviations: DPP=Diabetes Prevention Program; ILI=intensive lifestyle intervention.

Appendix B4 Table 12 Association Between Glucose Levels or Glycemic Levels and Risk for Target Organ Damage

Author, Year | Glucose or Glycemia Categories | Retinopathy | Nephropathy | Neuropathy | CVD Events | Other | Unadjusted or Adjusted (Variables Used)
Colagiuri, 2002^161^ | Low FPG (<140 mg/d L[<7.8 mmol/L]); Intermediate FPG (<180 mg/dL [<7.8 mmol/L to <10.0 mmol/L]); High FPG (>180 mg/dL [>10.0 mmol/L]) (Reference) | Progression of retinopathy; OR (95% CI); 0.64 (0.46 to 0.88); 0.76 (0.58 to 0.99); p<0.00001 | | | Stroke; OR (95% CI); 0.77 (0.53 to 1.31); 0.74 (0.54 to 1.02); p=0.11; Myocardial infarction; OR (95% CI); 0.64 (0.50 to 0.81); 0.96 (0.81 to 1.15); p=0.0014; Microvascular disease; OR (95 % CI); 0.39 (0.28 to 0.55); 0.39 (0.30 to 0.52); p<0.00001 | All-cause mortality; OR (95% CI); 0.68 (0.55 to 0.84); 0.80 (0.68 to 0.94); p=0.0019; Peripheral vascular disease; OR (95% CI); 0.30 (0.11 to 0.82); 0.29 (0.13 to 0.67); p=0.00067 | Unadjusted
DeBoer, 2018^158^ | Glucose; Baseline; 1-year effect size | | | | Incident CVD^*^; 1.14 (1.01-1.29); 1.07 (1.00-1.14) | | Unadjusted
Fuller, 1980^122^ | 2-h blood-sugar (after 50 g oral glucose load) concentrations; Normo-glycemic <96 mg/dL; IGT 96-199 mg/dL; IGT 110-199 mg/dL; New diabetics >200 mg/dL; Known insulin dependent; Known noninsulin dependent | | | | | Death rates per 1,000; 59.4; 94.5; 94.3; 175.3; 104.2; 127.5 | Adjusted for age
Kalogeropoulos, 2009^66^ | Fasting glucose, per SD | | | | Heart failure risk; HR (95% CI); 1.19 (1.04 to 1.35) | | Adjusted for BMI, age, history of coronary artery disease and smoking, SBP and heart rate, left ventricular hypertrophy on electrocardiogram, creatinine, and albumin levels
Kalogeropoulos, 2009^66^ | Hemoglobin A1c, per SD | | | | Heart failure risk; HR (95% CI); 1.01 (0.83 to 1.23) | | Adjusted for BMI, age, history of coronary artery disease and smoking, SBP and heart rate, left ventricular hypertrophy on electrocardiogram, creatinine, and albumin levels
Kalogeropoulos, 2009^66^ | 2-h glucose, per SD | | | | Heart failure risk; HR (95% CI); 0.88 (0.74 to 1.06) | | Adjusted for BMI, age, history of coronary artery disease and smoking, SBP and heart rate, left ventricular hypertrophy on electrocardiogram, creatinine, and albumin levels
Metcalf, 2017^159^ | Fasting glucose; <5.1 mmol/L (91.98 mg/dL) (Reference); 5.1-5.4 (91.98-97.30 mg/dL); 5.5 -5.9 (99.10-106.31 mg/dL); 6.0 -6.7 (108.11-120.72 mg/dL); >6.9 mmol/L (124.32 mg/dL) | Retinopathy; HR (95% CI); 1.33 (0.82 to 2.17); 2.48 (1.66 to 3.83); 3.47 (2.38 to 5.27); 3.33 (2.26 to 5.10) | Renal complications; HR (95% CI); 1.12 (0.70 to 1.80); 1.52 (1.01 to 2.33); 2.11 (1.45 to 3.16); 2.64 (1.81 to 3.98) | Neuropathy; HR (95% CI); 1.11 (0.37 to 3.46); 1.52 (0.61 to 4.30); 3.00 (1.35 to 7.97); 3.98 (1.78 to 10.62) | CVD events^†^; HR (95% CI); 1.02 (0.88 to 1.18); 0.91 (0.79 to 1.05); 1.10 (0.96 to 1.26); 1.07 (0.96 to 1.22) | Circulatory complications; HR (95% CI); 0.65 (0.19 to 2.04); 0.95 (0.37 to 2.58); 1.59 (0.71 to 4.02); 2.40 (1.09 to 6.06) | Adjusted for age, sex, ethnicity, smoking history, 2-h glucose, and HbA1c
Metcalf, 2017^159^ | 2-h glucose; <5.4 mmol/L (97.30mg/dL) (Reference); 5.4-6.8 (97.30-122.52 mg/dL); 6.9-8.9(124.32-160.36 mg/dL); 9.0-12.1 (162.16-218.02 mg/dL); >12.2 mmol/L (219.82 mg/dL) | Retinopathy; HR (95% CI); 2.29 (1.22 to 4.60); 4.58 (2.61 to 8.83); 10.52 (6.15 to 19.95); 13.41 (7.78 to 25.56) | Renal complications; HR (95% CI); 1.30 (0.74 to 2.34); 3.07 (1.92 to 5.15); 6.07 (3.91 to 9.98); 6.92 (4.37 to 11.54) | Neuropathy; HR (95% CI); 1.22 (0.69 to 2.19); 2.79 (1.72 to 4.63); 5.28 (3.40 to 8.67); 6.01 (3.81 to 10.01) | CVD events; HR (95% CI); 1.23 (1.06 to 1.43); 1.29 (1.12 to 1.49); 1.37 (1.19 to 1.58); 1.23 (1.04 to 1.46) | Circulatory complications; HR (95% CI); 1.05 (0.32 to 3.65); 1.06 (0.36 to 3.60); 3.29 (1.38 to 9.78); 3.95 (1.60 to 11.70) | Adjusted for age, sex, ethnicity, smoking history, fasting glucose, and HbA1c
Metcalf, 2017^159^ | HbA1c; <40 mmol/mol (720.72 mg/dL) (Reference); 40 to 42 mmol/mol (720.72-756.76 mg/dL); 43 to 44 mmol/mol (774.77-792.79 mg/dL); 45 to 50 mmol/mol (810.81-900.90 mg/dL); >51 mmol/mol (918.92 mg/dL) | Retinopathy; HR (95% CI); 2.06 (1.43 to 3.04); 1.47 (0.98 to 2.22); 2.81 (2.01 to 4.02); 3.99 (2.85 to 5.73) | Renal complications; HR (95% CI); 1.67 (1.11 to 2.54); 1.50 (0.97 to 2.23); 2.54 (1.77 to 3.74); 3.51 (2.44 to 5.20) | Neuropathy; HR (95% CI); 1.67 (0.70 to 4.22); 1.75 (0.72 to 4.47); 3.57 (1.65 to 7.83); 3.96 (1.91 to 9.62) | CVD events^*^; HR (95% CI); 1.03 (0.90 to 1.18); 1.04 (0.90 to 1.19); 1.17 (1.03 to 1.33); 1.04 (0.89 to 1.22) | Circulatory complications; HR (95% CI); 1.43 (0.55 to 3.96); 1.54 (0.57 to 4.31); 2.78 (1.26 to 6.99); 4.29 (1.96 to 10.84) | Adjusted for age, sex, ethnicity, smoking history, fasting glucose, and 2-h glucose
Metcalf, 2017^159^ | Fasting glucose; <5.1 mmol/L (91.98 mg/dL) (Reference); 5.1-5.4 (91.98-97.30 mg/dL); 5.5-5.9 (99.10-106.31 mg/dL); 6.0-6.7 (108.11-120.72 mg/dL); >6.9 mmol/L (124.32 mg/dL) | | | | CHD events; 1.07 (0.86 to 1.32); 0.92 (0.75 to 1.13); 1.15 (0.94 to 1.40); 1.16 (0.96 to 1.42) | | Adjusted for age, sex, ethnicity, and smoking history
Metcalf, 2017^159^ | 2-h glucose; <5.4 mmol/L (97.30 mg/dL) (Reference); 5.4-6.8 (97.30-122.52 mg/dL); 6.9-8.9 (124.32-160.36 mg/dL); 9.0-12.1 (162.16-218.02 mg/dL); >12.2 mmol/L (219.82 mg/dL) | | | | CHD; HR (95% CI); 1.17 (0.96 to 1.45); 1.15 (0.94 to 1.41); 1.14 (0.93 to 1.40); 1.13 (0.89 to 1.42); Ischemic Stroke; HR (95% CI); 1.40 (1.01 to 1.98); 1.82 (1.34 to 2.51); 1.48 (1.08 to 2.05); 1.47 (1.03 to 2.11) | | Adjusted for age, sex, ethnicity, smoking history, fasting glucose, and HbA1c
Metcalf, 2017^159^ | HbA1c; <40 mmol/mol(720.72mg/dL) (Reference); 40 to 42 mmol/mol (720.72-756.76 mg/dL); 43 to 44 mmol/mol (774.77-792.79 mg/dL); 45 to 50 mmol/mol (810.81-900.90 mg/dL); >51 mmol/mol (918.92 mg/dL) | | | | CHD; HR (95% CI); 1.27 (1.05 to 1.55); 1.12 (0.90 to 1.38); 1.41 (1.17 to 1.70); 1.27 (1.01 to 1.61) | | Adjusted for age, sex, ethnicity, smoking history, fasting glucose, and 2-glucose
Nichols, 2008^160^ ^‡^ | Normoglycemia; Isolated IFG; Isolated IGT; IFG/IGT | Retinopathy; (Prevalence); 0.2; 0.2; 0.4; 0.3; Macular Edema; (Prevalence); 0.3; 0.3; 0.3; 0.5 | GFR<60 mL/min; (Prevalence); 12.3; 13.7; 17.5; 16.8 | Peripheral neuropathy; (Prevalence); 6.7; 6.9; 7; 7.5 | Cardiovascular disease; (Prevalence)^*^; 17.5; 21.5; 23.2; 22.8; Congestive heart failure; (Prevalence); 5.2; 6.7; 8.6; 10.5; Stroke; (Prevalence); 7.6; 8.1; 10.1; 8.8; Any macrovascular complication^ǁ^; (Prevalence); 25.8; 30.6; 33.9; 34.1 | Any complication; (Prevalence); 36.1; 40.9; 45.5; 46.3; Peripheral vascular disease; (Prevalence); 4.1; 5; 4.9; 4.8; Any microvascular complication^§^; (Prevalence); 18.2; 19.8; 23.0; 23.2; Any microvascular or macrovascular complication^*^; (Prevalence); 7.9; 9.5; 11.5; 11.0 | Adjusted for age and sex
Robinson, 2016^89^ | HbA1c, (per 10 mmol/mol); HbA1c, (per 10%) | | | | | Lower limb amputations; 1.27 (1.24-1.31), p<0.001; 1.30 (1.26-1.35), p<0.001 | Adjusted for gender, diabetes history, age at onset, smoking status, height, systolic BP, and TC/HDL ratio.
Selvin, 2010^85^ | Fasting glucose category; <100 mg/dL (Reference); 100 to <126 mg/dL; >126 mg/dL | | | | Coronary heart disease; HR (95% CI); 1.01 (0.88 to 1.14); 1.00 (0.77 to 1.30); p=0.97; Ischemic Stroke; HR (95% CI); 0.93 (0.73 to 1.18); 1.30 (0.85 to 1.98); p=0.63 | All-cause mortality; HR (95% CI); 1.06 (.94 to 1.19); 1.16 (.91 to 1.47); p=0.20 | Adjusted for age, sex, race (black or white), LDL, HDL, log-transformed triglyceride level, BMI, waist to hip ratio, hypertension, family history of diabetes, education, alcohol use, physical-activity index score, and smoking status
Vistisen, 2018^162^ | Normal glycaemia FPG <5.6 mmol/L (100.90 mg/dL) and HbA1c <5.7% (Reference); Prediabetes FPG 5.6-6.9 mmol/L (100.90-124.32mg/dL) or HbA1c 5.7-6.4% | | | | Cardiovascular disease (fatal and nonfatal),; RR (95% CI); 1.07 (0.90 to 1.26) | CVD or mortality; RR (95% CI); 1.12 (0.97 to 1.28) | Adjusted for age, sex, ethnicity, previous CVD, smoking, total cholesterol, HDL cholesterol, systolic blood pressure, and antihypertensive treatment
Vistisen, 2018^162^ | H1bA1c <5.7% (Reference); H1bA1c 5.7-6.4%; H1bA1c 5.7-5.9%; H1bA1c 6.0-6.4% | | | | Cardiovascular disease (fatal and nonfatal); RR (95% CI); 1.12 (0.92 to 1.37); 1.15 (0.91 to 1.44); 1.00 (0.72 to 1.36) | CVD or mortality; RR (95% CI); 1.17 (1.00 to 1.38); 1.18 (0.98 to 1.42); 1.13 (0.87 to 1.46) | Adjusted for age, sex, ethnicity, previous CVD, smoking, total cholesterol, HDL cholesterol, systolic blood pressure, and antihypertensive treatment
Vistisen, 2018^162^ | FPG<5.6 mmol/L (Reference); FPG 5.6-6.9 mmol/L(100.90-124.32 mg/dL); FPG 5.6-6.0 mmol/L(100.90-108.11 mg/dL); FPG 6.1-6.9 mmol/L(109.91-124.32 mg/dL) | | | | Cardiovascular disease (fatal and nonfatal); RR (95% CI); 0.89 (0.74 to 1.08); 0.89 (0.72 to 1.10); 0.90 (0.68 to 1.21) | CVD or mortality; RR (95% CI); 0.93 (0.80 to 1.08); 0.91 (0.76 to 1.08); 0.98 (0.77 to 1.24) | Adjusted for age, sex, ethnicity, previous CVD, smoking, total cholesterol, HDL cholesterol, systolic blood pressure, and antihypertensive treatment
Vistisen, 2018^162^ | 2-h glucose <7.8 mmol/L (140.54) (Reference); 2-h glucose 7.8-11.0 mmol/L(140.54-198.20 mg/dL) | | | | Cardiovascular disease (fatal and nonfatal), rate per 1000 PY (95% CI); 0.88 (0.69 to 1.13) | CVD or mortality; RR (95% CI); 1.00 (0.82 to 1.22) | Adjusted for age, sex, ethnicity, previous CVD, smoking, total cholesterol, HDL cholesterol, systolic blood pressure, and antihypertensive treatment

* Included heart attack (myocardial infarction, coronary occlusion, or coronary thrombosis), stroke, transient attacks or mini-stroke, carotid endarterectomy, or other procedure to open blood vessels in the neck)

† Included stroke, coronary heart disease, and other vascular causes and cardiac procedures

‡ Normoglycemia was significantly different from the other three groups (p<0.001)

§ Included retinopathy, macular edema, and peripheral neuropathy

ǁ Included cardiovascular disease, stroke, peripheral vascular disease, and congestive heart failure

Abbreviations: BMI=body mass index; BP=blood pressure; CHD=chronic heart disease; CI=confidence interval; CVD=cardiovascular disease; FPG=fasting plasma glucose; GFR=glomerular filtration rate; HDL=high-density lipoproteins; HR=hazard ratio; IFG=impaired fasting glucose; IGT=impaired glucose tolerance; LDL=low-density lipoproteins; OR=odds ratio; PY=person-years; RR=relative risk; SBP=systolic blood pressure; SD=standard deviation; TC=total cholesterol.

## Appendix B5 Measures of Utility, Health Status, and Quality of Life Used in Studies Addressing Supplemental Questions 5 and 6

Several instruments have been developed to measure utilities, health status, and QoL. The instruments described here were used in studies found to answer SQ5 and SQ6. They include the EuroQol EQ-5D (EQ-5D), The 36 and 12 item Short Form Survey (SF-36 and SF-12), six-dimensional health state short form (SF-6D), the health-related quality of life 15-D (HRQOL 15-D), the Self-Administered Quality of Well-Being Index (QWB-SA), the RAND-12, and the 5-item World Health Organization well-being index (WHO-5).

The EQ-5D includes both a questionnaire that profiles a respondent’s health state and a visual analog scale (VAS) that allows a respondent to rate their own overall current health.^177^ The EQ VAS is a 0-100 scale that records the respondent’s overall current health (on the day it is administered), with higher scores corresponding to higher HRQOL. The EQ-5D index value uses a set of descriptive questions to generate a health state profile that can be assigned a summary index score, also called a health utility score that represents respondents preferences about whether a health state is good or bad. The EQ-5D VAS and index values therefore differ in that the VAS represents the respondents perspective on their own health while the index/utility value represents a societal perspective on a health state. For the purposes of our work, the EQ-5D utility score provides information to answer SQ5 regarding the distribution of disutilities of having diabetes (screen-detected or early diabetes without complications) or prediabetes, and the EQ-5D VAS score provides information to answer SQ6 regarding the distribution of health impacts of having diabetes (without complications) and prediabetes. It’s important to note that previously reported EQ-5D utility ranges for the general population vary from country to country. For example, in Canada, scores can range from −0.148 to 0.949;^178^ in the United Kingdom, scores can range from −0.285 to 0.950;^179^ and in the United States, scores can range from −0.573 to 1.^180^ Zero represents a health state considered to be equal to death and a negative score represents health states considered to be worse than death. Conversely, high scores (e.g., a score of 1) represent a health state that reflects perfect health. Finally, there are two versions of the EQ-5D, the EQ-5D-5L and its predecessor (still commonly used), the EQ-5D-3L. Both comprise of 5 health dimensions (mobility, self-care, usual activities, pain/discomfort, and anxiety/depression) but responses to the EQ-5D-3L instrument are based on three levels (no problems, some problems, extreme problems) whereas responses to the EQ-5D-5L instrument are based on 5 levels (no problems, slight problems, moderate problems, severe problems, extreme problems/unable to).

The HRQOL 15-D is another generic, preference-based, standardized and self-administered measure of HRQOL consisting of 15 questions which can be presented as a 15-dimensional profile or as a single index/utility score. As with the other index scores, the 15D index score is obtained by weighting the 15 dimensions with population-based preference weights based on an application of the multi-attribute utility theory.^181^ The index scores range from 0 to 1, where 0 represents a state of being dead and 1 represents perfect health.

The QWB-SA is a preference-weighted measure combining three scales of functioning with a measure of symptoms and problems to produce a health state utility score that ranges from 0 (for death) to 1.0 (for asymptomatic full function).^182^

The SF-36 consists of 36 questions that create a profile of scores across 8 health dimensions. The shorter SF-12 includes 12 of the 36 SF-36 questions. In addition to generating scores across each of the 8 dimensions, 2 composite summary scores for mental and physical functioning can be calculated for both the SF-12 and the SF-36—the Physical Component Score (PCS) and the Mental Component Score (MCS). Scores range from 0 (worst health state) to 100 (best health state).^183,184^ The SF-12 and SF-36 PCS and MCS summary scores (and total score where provided) were used to answer SQ6 describing the distribution of health impacts of having diabetes (without complications) and prediabetes. Similar to the EQ-5D Index value, SF-6D score is a preference-based single utility score estimated using the PCS and MCS summary scores from either the SF-12 or SF-36.^185^ Index scores on the SF-6D range from 0.29-1.0.^186^ This preference-based utility score was used to help answer SQ5 on the distribution of disutilities associated with uncomplicated diabetes and prediabetes.

The RAND-12 also measures health impact and was used in studies addressing SQ6. It employs the same 12 questions as the SF-12 but is scored differently. The SF-12 and SF-36 summary scores are based on principle component factor analysis with orthogonal factor rotations whereas the RAND-12 employs item response theory (IRT)-based scaling methods and an oblique scoring algorithm.^187^

Another QOL measure relevant to SQ6 is the WHO-5 which measures subjective well-being on a 0 to 5 rating scale for each of 5 questions. The total score across the 5 questions ranges from 0 to 25 and the score is most often multiplied by 4 to align with other QOL measures. Mean population scores from the WHO-5 were not readily available.

Appendix B5 Table 1 provides population norms for the instruments used to measure health utilities (SQ5) and includes suggested thresholds for the minimal clinically important difference (MCID) for each measure. Appendix B5 Table 2 provides population norms and suggested MIDs for each included QOL measure (SQ6).

Appendix B5 Table 1 Minimal Clinically Important Difference Values and Population Norms for Preference-Based Health Utility Measures Used in Studies Included for SQ5

Measure | MID for Health Utility Values | Population Norms for Health Utility Values^*^ Mean (SD)
QWB-SA | 0.03^188^ | 0.64 (0.50^**^) U.S.^189^
EQ-5D (U.S.) | 0.04-0.08^190^ | 0.86 (0.50^**^) U.S.^189^; 0.86 (0.23) U.K.^191^; 0.87 (NR) Denmark^192^; 0.89 (NR) Netherlands^192^
SF-6D | 0.03^190^−0.04^193^ | 0.79 (0.50^**^) U.S.^189^
15-D^*^ | 0.015^194^−0.03^195^ | 0.86 (0.12) Finland^196^

* 15-D norms could not be found for the U.S. or U.K. populations; population norms are based on a Finnish population (n=2,729) with mean age 66.5.

** SD calculated using other data reported (sample size, mean for ages 45-74, and standard error)

Appendix B5 Table 2 Minimal Clinically Important Difference Values and Population Norms for Quality of Life Measures Used in Studies Included for SQ6

Measure | MID | Mean (SD) Population Norms for QOL Scores*
SF-36 | 3-5 points for the MCS and PCS^193^ | 50 (10) (MCS PCS)^197^
SF-12 | 3-5 points for the MCS and PCS^193^ | 50 (10) (MCS PCS)^197^
EQ-VAS | 7-8 points^198,199^ | US 80.0 (20) (SE 0.1, n=38,678)^200^; Denmark 83.7 (26) (SE 0.2, n=16,861); Netherlands 82.0 (19.5) (SE 0.4, n=2,367); UK 82.8 (23) (SE 0.4, n=3395)
RAND-12 | 3-5 points for the MCS and PCS^193,201^ | 50 (10) (MCS PCS)^197,202^
WHO-5 | 10 points^203^ | 54-70 (NR)^203^