# Appendix A Additional Background and Contextual Questions

Appendix A Table 1 Incidence of Diabetes-Related Conditions in the UKPDS Conventional Care Arm^1^

Outcome | n With Outcome (total N=1,138) | Absolute Risk, Events per 1,000 Patient-Years
All-cause mortality | 213 | 18.9
Diabetes-related deaths | 129 | 11.5
Myocardial infarction | 188 | 17.4
Stroke | 55 | 5.0
Amputation for health from PVD | 18 | 1.6
Death from renal disease | 2 | 0.2
Renal failure | 9 | 0.8
Blind in one eye | 38 | 3.5

Abbreviations: n/N=sample size; PVD=peripheral vascular disease; UKPDS=United Kingdom Prospective Diabetes Study.

Appendix A Table 2 Screening Recommendations of Other Groups

Organization, Year | Screening Recommendation | Risk Factors Considered | Frequency of Screening
American Diabetes Association (ADA), 2018^2^ | Screen all asymptomatic adults for DM risk. Universal blood sugar screening for all adults ≥45 years of age regardless of risk factors. Regardless of age, screen overweight or obese (BMI ≥25 kg/m^2^ or ≥23 kg/m^2^ in Asian Americans) adults with ≥1 risk factor. | Close relative with DM, high-risk race/ethnicity, history (Hx) of CVD, hypertension, HDL cholesterol level <35 mg/dL (0.90 mmol/L), triglyceride level >250 mg/dL (2.82 mmol/L), POS, physical inactivity, other clinical conditions associated with insulin resistance | If normal, repeat at a minimum of 3-year intervals. Annual screening for patients with prediabetes. Screen women with a Hx of GDM at ≤3-year intervals
International Diabetes Federation (IDF), 2017^3^ | No universal blood sugar screening. Screen people above 40 to 45 years of age and/or with high-risk factors using a locally validated screening test such as the FINDRISC score. If unavailable, use fasting blood glucose. | Family Hx of diabetes, obesity, increased waist circumference, and hypertension | If normal, repeat at ≤3 year
The Royal Australian College of General Practitioners (RACGP), 2016-2018^4^ | No universal blood sugar screening. Screen for risk with AUSDRISK at age ≥40. Risk assessment should begin from 18 years of age in Aboriginal and Torres Strait Islander peoples. Screen individuals with ≥1 risk factors. | AUSDRISK score of ≥12, history of previous cardiovascular event, history of GDM, polycystic ovary syndrome, on antipsychotic drugs | Repeat screening every 3 years regardless of age, individuals at high risk with IGT or IFG should be screened annually
American Association of Clinical Endocrinologists and American College of Endocrinology (AACE/ACE), 2015^5^ | Universal blood sugar screening for adults aged ≥45 regardless of risk factors. Screening for high-risk groups | CVD or family Hx of type 2 DM; all obese adults; overweight with additional risk factors; sedentary lifestyle; at-risk racial/ethnic groups; HDL <35 mg/dL (0.90 mmol/L) and/or TG >250 mg/dL (2.82 mmol/L); IGT or IFG and/or metabolic syndrome; POS, acanthosis nigricans, or nonalcoholic fatty liver disease; hypertension; Hx of GDM or baby >9 lbs; antipsychotic therapy; chronic glucocorticoid exposure; sleep disorders in the presence of glucose intolerance | Repeat screening every 3 years with annual screening for individuals with ≥2 risk factors
Institute for Clinical Systems Improvement (ICSI), 2014^6^ | No universal blood sugar screening. Screen people with a BMI ≥25 kg/m^2^ and ≥1 risk factor regardless of age. Regardless of age, screen asymptomatic patients with increased cardiovascular risk | High-risk race/ethnicity; Hx GDM or baby >9 lbs; POS; prediabetes as defined by IFG, IGT or A1c on previous testing; Other clinical conditions associated with insulin resistance (e.g., severe obesity, acanthosis nigricans); Hx of close relative with DM | At least annual monitoring for the development of diabetes in those with prediabetes
Canadian Diabetes Association, 2013^7^ | Annual DM risk assessment; universal blood sugar screening for adults aged ≥ 40 regardless of risk factors and those at high risk using a risk calculator. More frequent and/or earlier screening for those at very high risk or in people with additional risk factors | Close relative with type 2 DM; high-risk racial/ethnic group; Hx of prediabetes, GDM, delivery of a macrosomic infant; presence of end organ damage complications associated with diabetes, vascular risk factors; POS; acanthosis nigricans; obstructive sleep apnea; psychiatric disorders; HIV; use of drugs associated with diabetes; other secondary causes | Screen every 3 years for adults ages ≥40 years regardless of risk factors and for those at high risk. More frequent and/or earlier screening for those at very high risk using a risk calculator or in people with additional risk factors.
The European Society of Cardiology (ESC), 2013^8^ | No universal blood sugar screening. Screen for DM risk using a diabetes risk score (e.g., the FINDRISC) followed by diagnosis testing. In CVD patients, no diabetes risk score is needed but an OGTT is indicated if HbA1c and/or FPG are inconclusive. | NA | NR
Canadian Task Force on Preventive Health Care, 2012^9^ | No universal blood sugar screening. Screen for DM risk using the FINDRISC or the CANRISK. | NA | For adults at high risk, screen every 3-5 years with HbA1c. For adults at very high risk screen annually with HBA1c.
National Institute for Health and Care Excellence (NICE), 2012^10^ (intensive lifestyle-change programs and metformin sections updated in 2017); and; U.K. National Screening Committee (UKNSC), 2013^11^ | No universal blood sugar screening (UKNSC). Use a validated computer-based risk assessment (or a validated self-assessment questionnaire) to identify people at high risk of type 2 DM (NICE). Individuals identified as high risk should be screened. Screen those age 25 years or older of South Asian or Chinese descent whose BMI is >23 kg/m^2^. | NA | Repeat screening every 5 years for those at low risk, every 3 years for those at moderate risk (a high-risk score, but with a fasting plasma glucose <5.5 mmol/l [<99 mg/dL], or HBA1c <42 mmol/mol). Annual screening for those at high risk (a high-risk score and fasting plasma glucose of 5.5-6.9 mmol/l [99-125], or HbA1c of 42-47 mmol/mol).

Abbreviations: A1c=glycated hemoglobin; AACE/ACE=American Association of Clinical Endocrinologists and American College of Endocrinology; ADA=American Diabetes Association; AUSDRISK=Australian Type 2 Diabetes Risk Assessment Tool; BMI=body mass index; CANRISK=Canadian Diabetes Risk Assessment Questionnaire; CVD=cardiovascular disease; DM=diabetes mellitus; ESC=European Society of Cardiology; FINDRISC=Finnish Diabetes Risk Score; FPG=fasting plasma glucose; GDM=gestational diabetes mellitus; HbA1c/HBA1c=hemoglobin A1c; HDL=high-density lipoproteins; HIV=human immunodeficiency virus; HIV=human immunodeficiency virus; Hx=history; ICSI=Institute for Clinical Systems Improvement; IDF=International Diabetes Federation; IFG=impaired fasting glucose; IGT=impaired glucose tolerance; NA=not applicable; NICE=National Institute for Health and Care Excellence; NR=not reported; OGTT=oral glucose tolerance test; POS=polycystic ovary syndrome; RACGP=The Royal Australian College of General Practitioners; TG=triglycerides; UKNSC=U.K. National Screening Committee.

## Additional Background

Other treatments to reduce CVD risk and microvascular complications. Because patients with prediabetes and diabetes are at higher risk for CVD and microvascular complications, screening and treating for conditions such as hyperlipidemia, hypertension, and tobacco abuse are recommended.^12^ Treatments to decrease cardiovascular risk can include antihypertensives, statins, and aspirin. Management to decrease microvascular complications includes routine eye exams for retinopathy, urinary albumin excretion for nephropathy, and foot exams for neuropathy.^6^

Aspirin therapy. The ADA recommends that aspirin (75 to 162 mg daily) may be considered for primary prevention in people with diabetes who are at increased cardiovascular risk after a discussion on the benefits versus increased risk of bleeding.^13^ The American Academy of Family Practice (AAFP) endorses the USPSTF’s recommendation to initiate aspirin therapy for individuals between the ages of 50 and 59 years with at least a 10 percent 10-year risk (calculated using the pooled cohort equations) of CVD.^14^ The 10-year risk calculation incorporates presence or absence of diabetes.

Hypertension treatment. Initial antihypertensive therapy for diabetics with hypertension includes diuretics, calcium channel blockers, and an angiotensin converting enzyme (ACE) inhibitor or angiotensin II receptor blocker (ARB). Either an ACE inhibitor or an ARB is recommended for diabetic patients with microalbuminuria.^12^ There is disagreement, however, about optimal blood pressure targets for hypertensive patients, a controversy that is important for individuals newly diagnosed with diabetes through screening whose 10-year risk of developing CVD is at least 10 percent only because of their new diabetes diagnosis.

In 2017, the American Heart Association and American College of Cardiology jointly published blood pressure targets that were lower than those of most other organizations.^15^ The two professional organizations recommended that hypertensive individuals with CVD or a 10-year atherosclerotic CVD (ASCVD) risk of at least 10 percent should have a blood pressure target of less than 130/80 and lower risk individuals should have a blood pressure goal below 140/90. In response, the ACP and the AAFP jointly recommended less aggressive blood pressure targets for people with hypertension age 60 years or older based on the results of a systematic review they performed.^16,17^ The ACP and AAFP recommended a systolic blood pressure goal of 150 for those with lower CVD risk and a systolic blood pressure goal of less than 140 for those with a history of stroke, history of transient ischemic attack, or high cardiovascular risk. The ADA now recommends that blood pressure targets be individualized through a shared decision making process that addresses CVD risk, potential adverse effects of antihypertension medications, and patient preferences.^13^ They note that a target of <130/80 may be appropriate for those with diabetes and higher CVD risk (10-year ASCVD risk >15%) and recommend to treat to a target of <140/90 for those with lower 10-year risk.^13^

For individuals with a 10-year ASCVD risk of at least 10 percent prior to being screened for diabetes, screening results would not alter blood pressure targets because they are already over the threshold for lower targets. However, for individuals for whom a diabetes diagnosis could increase their 10-year risk (to above 10%), the screening results can potentially alter blood pressure targets.

## Contextual Questions

### CQ 1 Are there risk assessment tools that are feasible for use in primary care settings, accurately predict the risk of prediabetes or type 2 diabetes, and have been externally validated in U.S. populations?

Several risk prediction models have been developed or validated using U.S. populations to assess the risk of developing prediabetes^18^ or diabetes.^19–21^ These models vary in complexity, and most have not been validated in diverse populations.^19^ They also differ in country of origin of the samples used in development and validation, the number and type of variables used to estimate risk, and whether they were basic or extended models. Briefly, basic models were calculated using values collected noninvasively, and extended models required the collection of biomarkers such as HbA1c, glucose, and lipid values. Models that do not require blood testing^22–24^ were similar to the Diabetes Risk Test recommended by the ADA, which includes age, sex, history of gestational diabetes, family history of diabetes among first-degree relatives, hypertension, physical activity, and BMI category (not overweight or obese, overweight, obese, or extremely obese).^25^ The ADA risk score was developed using NHANES data from 1999 to 2004 and validated using NHANES data from 2005 to 2006.^26^ When used to predict either prediabetes (fasting plasma glucose 100-125 mg/dL) or diabetes (fasting plasma glucose ≥126 mg/dL) with fasting plasma glucose as the reference standard, it had an AUROC of 0.72. When HbA1c of 6.5 or greater was used as the reference standard, the AUROC was 0.78.

A 2014 systematic review^18^ identified risk assessment tools to detect patients with prediabetes defined as IFG and/or IGT using OGTT(1998 WHO criteria^27^) or HbA1c using any recommended definition. Studies were required to have at least two or more risk factors, could not include genetic factors, and had to be developed using a population-based sample or volunteers/opportunist sample. Eighteen risk prediction tools (in 12 articles) were identified including the Tool to Assess likelihood of fasting Glucose ImpairmentT (TAG-IT^28^), the TAG-IT for Adolescents (TAG-IT-A),^29^ the Leicester risk assessment score,^30^ the Diabetes Risk Calculator,^31^ eCANRISK,^32^ pCANRISK,^32^ and the Diabetes Classifier,^33^ and 11 tools did not have official names.^34–39^ The number of risk factors for each tool ranged from 6 to 26, and the number of outcome events ranged from 244 to 2,156 (median of 644). Of these 18 risk tools, seven (reported in 6 articles) were developed using samples from the United States. These seven included three unnamed risk tools, TAG-IT-A,^40^ Diabetes Risk Calculator,^41^ TAG-IT,^42^ and the Diabetes Classifier.^43^ Three of the seven risk scores were developed using a sample from the United States with NHANES data and externally validated using an NHANES sample from a different year (TAG-IT-A, TAG-IT, and the Diabetes Risk Calculator). All three risk scores were simple diabetes risk scores. TAG-IT-A and TAG-IT used a definition of prediabetes that would also include those with diabetes (i.e., fasting blood glucose ≥100 mg/dL), while the Diabetes Risk Calculator used fasting plasma glucose 100 to 125 mg/dL and/or 2-hour OGTT 140 to 199 mg/dL without diabetic values for either. TAG-IT-A included age, BMI, gender, and resting heart rate and had a reported AUROC of 0.61. TAG-IT included age, BMI, family history of type 2 diabetes, gender, hypertension, and resting heart rate and had an AUROC of 0.74. The Diabetes Risk Calculator included age, family history of type 2 diabetes, and waist circumference and had an AUROC of 0.70.

A 2011 review included studies that derived and/or validated a statistically weighted risk model for type 2 diabetes in a population not preselected for known risk factors or disease and that could be applied to another population.^20^ It described three diabetes risk models (Framingham Offspring, San Antonio, and Atherosclerosis Risk in Communities [ARIC] risk scores)^22,44,45^ that have been validated in U.S. populations^46^ with the high potential for use in clinical practice (i.e., were externally validated by a separate research team on a different population, had statistically significant calibration, discrimination value greater than 0.70, and 10 or fewer components). The three risk prediction models were a subset of seven models (ARIC, AUSDRISK, Cambridge risk score, FINDRISC, Framingham Offspring, San Antonio risk score, and QDScore) that the authors classified as having high potential for use in practice (i.e., were externally validated by a separate research team on a different population, had statistically significant calibration, had a discrimination value greater than 0.70, and had 10 or fewer components). The Framingham Offspring^22^ and San Antonio^45^ risk scores were developed and validated using samples from the United States, and ARIC^44^ was developed in Germany and validated using a U.S. sample. The Framingham Offspring risk score included fasting plasma glucose, BMI, HDL, parental history of diabetes, triglyceride level, and blood pressure and had a development AUROC of 0.85 and a validation AUROC of 0.78.^46^ The San Antonio risk score included age, sex, ethnicity, fasting plasma glucose, systolic blood pressure, HDL, BMI, and family history of diabetes in a first-degree relative and had a development AUROC of 0.84 (0.82 to 0.87) and a validation AUROC of 0.83. The ARIC used age, ethnicity, waist circumference, height, systolic blood pressure, family history of diabetes, fasting plasma glucose, triglyceride level, and HDL and had a development AUROC of 0.80;^44^ and a validation AUROC of 0.84. For assessing discrimination of all three risk models (Framingham Offspring, San Antonio, and ARIC), incident diabetes was determined using data collected during three in-person MESA followup examinations and was defined as self-reported use of oral hypoglycemic drugs or insulin or had a fasting serum glucose level greater than or equal to 126 mg/dL.

Another systematic review published in 2011 by Buijsse et al. included studies of diabetes risk assessment tools that used prospective cohort studies involving the general adult population for their derivation or validation and evaluated at least three risk factors.^21^ This review found two diabetes risk models that were developed or validated in samples from the United States that were not included among the seven diabetes risk models that Nobel et al. determined had a high potential for use in clinical practice, the Epidemiological Study on the Insulin Resistance Syndrome Diabetes Risk Score^24^ and the Rancho Bernardo Diabetes Risk Score.^47^ Developed in France, the Epidemiological Study on the Insulin Resistance Syndrome Risk Score^24^ included waist circumference, hypertension, current smoking (for men), and family history of diabetes (for women) and had a poor validation discrimination of 0.66 in a U.S. population.^48^ The Rancho Bernardo Diabetes Risk Score^47^ was developed and validated using a sample from the United States and included sex, age, fasting glucose, and triglycerides and had an adequate validation discrimination of 0.71.^47^ Notably, the review by Buijsse et al. reported a lower discrimination value (of 0.70) for the ARIC risk score than reported in the Noble et al. systematic review when waist circumference, triglycerides, HDL cholesterol, hypertension, fasting glucose, and BMI were included in the validation score with a different U.S. sample. Similarly, the Buijsse systematic review also reported Framingham Offspring Diabetes Risk score discrimination values that were not reported in the Noble study. These scores ranged from the 0.66 to 0.86 in validation studies performed using samples from different countries and different simple and extended forms of the Framingham Offspring Diabetes risk score.^21^

A 2012 systematic review and external validation study identified 25 prediction models; 12 were categorized as basic models that can be assessed noninvasively (e.g., using demographics, family history, measures of obesity, lifestyle factors), and 13 were categorized as extended because of the inclusion of data on one or more biomarkers (e.g., A1c, lipid levels, uric acid, and others).^19^ The authors applied all 25 models to the Dutch cohort of the European Prospective Investigation into Cancer and Nutrition cohort study over 10 years of followup and found that most basic models perform similarly well in identifying individuals at high and low risk of developing diabetes (C-statistics ranged from 0.74 [95% CI, 0.73 to 0.75] to 0.84 [95% CI, 0.82 to 0.85] for risk at 7.5 years). Models including biomarkers classified cases slightly better (C-statistics ranged from 0.81 [95% CI, 0.80 to 0.83] to 0.93 [95% CI, 0.92 to 0.94]) than basic ones; however, most models overestimated the actual risk of diabetes, particularly at higher observed rates. After adjusting models for differences in incidence, calibration improved, but significant deviations between predicted and observed risks remained for most models.^19^

### CQ 2 What is the frequency of agreement among screening tests (HbA1c, fasting plasma glucose, and 2-hour glucose tolerance test) for prediabetes and diabetes?

A recent systematic review summarized the prevalence of prediabetes that would be identified by various screening tests.^49^ The review identified five studies (17,108 total adult participants from the United States, Italy, China, Spain, and the United Kingdom) that reported on the prevalence of prediabetes for all three tests (HbA1c, fasting plasma glucose, and 2-hour glucose tolerance test) and found generally low agreement between the three tests for which people were classified as having prediabetes. Using the criteria of the International Expert Committee (IEC) and World Health Organization (WHO), the prevalence of prediabetes by any one of the tests was 27 percent. Of those, 5 percent had isolated IFG (6.0-6.9 mmol/L, 106-125 mg/dl), 24 percent had isolated IGT (7-11.1 mmol/L, 126-200 mg/dl), 48 percent had isolated HbA1c criteria (6.0-6.4%), 3 percent had IFG and IGT, 4 percent had IFG and HbA1c criteria, 12 percent had IGT and HbA1c criteria, and 4 percent had all three.

If ADA criteria for HbA1c (5.7-6.4%) are applied to the same cohort, the prevalence of prediabetes by any test was 49 percent. Use of the ADA criteria for both the oral glucose tolerance test and HbA1c increased the prevalence of prediabetes to 54 percent. Of those, 25 percent had isolated IFG (fasting plasma glucose 5.6-6.9 mmol/L, 100-125 mg/dl), 6 percent isolated IGT (OGTT 2 hour result 140-199 mg/dl), 22 percent isolated HbA1c criteria, 7 percent IFG and IGT, 27 percent IFG and HbA1c criteria, 4 percent IGT and HBA1c criteria, and 9 percent had all three.

### CQ 3 Which of these screening tests (HbA1c, fasting plasma glucose, and 2-hour glucose tolerance test) best predicts future adverse health outcomes associated with type 2 diabetes?

Overall there is no clear evidence that either HbA1c, OGTT, or FPG is better at predicting health outcomes. When considering the evidence on the value of the tests, four previous reviews (ADA, WHO, Canadian Task Force for Preventive Medicine, and U.K. National Screening Committee)^50–54^ all concluded that all three tests were appropriate for diagnosing diabetes.

#### Study Design and Interpretation

Much of the evidence comparing diabetes tests is cross-sectional and has a high risk of bias to address prediction of future outcomes. Therefore, the focus here is on cohort studies from within the identified reviews. Unlike randomized, controlled trials (RCTs), these studies typically do not give associations between test results and outcomes with and without treatment. A strong association between positive test results and adverse health outcomes may indicate that the test is accurate at detecting people at higher risk, but in the presence of treatment it may indicate the test detects people who do not respond well to treatment (or perhaps that a treatment was harmful). Many of the cohort studies available only reported one or two out of the three tests in the same population. Further, there is heterogeneity across studies, particularly in test thresholds used, methods of outcome ascertainment, and methods of reporting results.

There was some evidence of a J-shaped association between glycemic score and all-cause mortality.^55,56^ If such an association is present, the relative risk of mortality in diabetic and nondiabetic subjects depends on the spectrum of scores in the population, with, for example, inclusion of more participants with very low glycemic scores biasing relative risk estimates toward the null. Results are reported using the ADA 2019 thresholds when available (FPG≥126mg/dl, 2hr PG200mg/dl, HbA1c≥6.5 percent).

#### Reviews Comparing Screening Tests

A 2011 systematic review commissioned by the WHO^51,52^ recommended using HbA1c as a diagnostic test for diabetes providing there is stringent quality assurance in place. The question they addressed was how does HbA1c perform in the diagnosis of type 2 diabetes based on the detection and prediction of microvascular complications? They did not consider macrovascular complications. The GRADE assessment for quality of evidence was moderate, but this was based on cross-sectional studies of prevalent retinopathy, rather than incident retinopathy where the quality of evidence was low because of the low number of studies. They describe four longitudinal studies reporting the association between HbA1c and incident retinopathy.^57–60^ These are described alongside studies from the other reviews in Appendix A Table 3. Of the four studies in this review, one gave sufficient information to allow calculation of the relative risk of incident retinopathy in participants with and without diabetes on each test. For the Hoorn study,^59^ reviewers combined normoglycemic and prediabetic categories to give unadjusted relative risks. The relative risk of developing retinopathy in those with HbA1c above 5.8 in comparison to below is 3.1 (95% CI, 1.5 to 6.5). The relative risk of developing retinopathy in those who are diabetic according to WHO 1999 criteria in comparison to normoglycemic or prediabetic is 1.8 (0.9 to 3.7). Microvascular complications (retinopathy and nephropathy) in Pima Indians^60^ were considered in their review but not reported further because data from the HbA1 and HbA1c tests were combined.

A more recent systematic review (2016) compared HbA1c and FPG in accuracy to detect retinopathy.^61^They included 11 studies, of which only one provided any longitudinal data; the remainder were cross-sectional. They concluded the diagnostic odds ratio for diagnosing retinopathy was higher for HbA1c (16.3 [95% CI, 13.9 to 19.2]) than for FPG (4.9 [95% CI, 4.4 to 5.4]). There was more limited data for OGTT (four studies), but the diagnostic odds ratio was described as similar to that of HbA1c. They included a range of thresholds, which makes results more complex to interpret.

The guidance from the ADA suggests that, generally, FPG, 2-h PG during 75-g OGTT and A1C are equally appropriate for diagnostic testing for diabetes,^62^ while acknowledging that the three tests do not necessarily detect the same people (see CQ 2). Similarly, the WHO added HbA1c to FPG and OGTT as an appropriate diabetes test after a systematic review in 2011.^51,52^ The latest Canadian Task Force recommendations on this topic cite the WHO 2011 review.^53^

The U.K. National Screening Committee systematically reviewed the evidence for whether to screen for type 2 diabetes in 2019.^54^ They compared accuracy of the three tests (HbA1c, OGTT, and FPG) in predicting mortality, microvascular complications, and macrovascular complications. To reduce spectrum bias, they only included studies that compared all three tests in the same population and did not include evidence from studies examining one or two of the tests. They concluded that there was consistent evidence for an association between higher blood glucose levels and some of the complications of diabetes (i.e., mortality, retinopathy, and nephropathy) for all three tests, but they found no evidence that any one test was a better predictor of these complications. They identified seven relevant cohort studies (Appendix A Table 3).^55,56,63–66^ Sample sizes ranged from 593^65^ to 31,148.^64^ Two were from the United States^60,66^ and one from each of Australia,^56^ Finland,^65^ Netherlands,^63^ Germany,^55^ and New Zealand.^64^ Four studies reported on all-cause mortality;^55,56,63,64^ two of them also reported cardiovascular mortality.^56,63^ One study^63^ reported mortality outcomes by diabetic status on all three tests using ADA 2019 thresholds. An additional three studies reported mortality outcomes by diabetic status on all three tests but using a different threshold for diabetes for at least one of the tests (see Appendix A Table 3).^55,56,64^ In summary, few studies report mortality outcomes for all three tests, and within them there is heterogeneity in test thresholds. All four included studies showed some evidence of a trend toward OGTT outperforming FPG, but the differences were small and none of them were tested statistically. There were no consistent trends between studies in comparisons between FPG and HbA1c and between HbA1c and OGTT. There was no clear evidence of advantage of one test over another for microvascular or macrovascular outcomes.

The single study that reported mortality outcomes at ADA thresholds was a prospective cohort of 1,484 people from the Netherlands with 8 years of followup.^63^ Relative risk for all-cause mortality for diabetics in comparison to nondiabetics was 2.8 (95% CI, 1.8 to 4.4) using HbA1c, 2.5 (95% CI, 1.6 to 3.8) for OGTT and 2.1 (95% CI, 1.4 to 3.3) for FPG. Relative risk for cardiovascular mortality for diabetics compared with nondiabetics was 3.5 (1.9 to 6.3) using HbA1c, 2.6 (95% CI, 1.4 to 4.7) using OGTT, and 2.4 (95% CI, 1.3 to 4.3) using FPG. While the authors did not statistically compare the three tests, they suggested that high glycemic variables, especially OGTT concentrations and to a lesser extent HbA1c values, may be indicators of increased risk of CVD mortality.

Three studies reported macrovascular complications in cohorts with results on all three tests at baseline, but none use the same thresholds as ADA 2019 for all tests.^64–66^ Two studies followed up participants to incident retinopathy and neuropathy,^60,64^ and one study followed up participants to development of nephropathy.^64^ They are described in Appendix A Table 3.

### CQ 4 What is the yield (i.e., incidence of prediabetes or diabetes) of rescreening at different intervals in adults with an initial normal screening test (HbA1c, fasting plasma glucose, and 2-hour glucose tolerance test) result?

Overall, the four studies directly addressing this question found yields of rescreening persons for diabetes who had an initial normal test that ranged from 1.3 percent to 4.4 percent over 3 to 12 years. Some of the studies highlighted that those with lower HbA1c at baseline or lower calculated risk (using a risk prediction model) had lower yield of rescreening than those with higher HbA1c or higher calculated risk.

A study of adults screened for diabetes with HbA1c at the Cleveland Clinic evaluated persons with an initial HbA1c less than 6.5 percent in 2008 and at least one subsequent HbA1c over the following 5 years.^67^ Of 2,281 people with a normal HbA1c, 100 (4.4%) developed diabetes within 5 years. Of 2,803 people with prediabetes, 772 (27.5%) developed diabetes within 5 years. The authors concluded that screening intervals could be informed by a risk prediction model (including HbA1c, family history, smoking, triglycerides, alanine aminotransferase, BMI, age, and HDL) to determine screening intervals of less than a year for those at highest risk and 3 to 5 years for those at lowest risk.

In the Ely study (described in KQ 1 of the systematic review), participants with initial normal screening tests (OGTT) were rescreened every 5 years. At initial screening, 1,157 people attended and 51 had screen-detected diabetes. Of the 1,106 with initial normal screening results, 1,071 were invited for rescreening at 5 years, yielding 26 additional screen-detected cases (yield 2.4% of those invited), and 994 were invited for rescreening at 10 years, yielding 31 additional screen-detected cases (yield 3.1% of those invited). Number of persons invited who attended screening at each 5-year interval was not reported; thus, the yield calculated is out of the number invited (yield out of number screened would be somewhat higher).

A cohort study of healthy adults older than age 65 years conducted in New Mexico screened annually with fasting serum glucose for up to 18 years (mean 12 years).^68^ Of 299 persons with normal fasting serum glucose (<126 mg/dl) at baseline, four (1.3%) subsequently met criteria for the diagnosis of diabetes. The authors noted that fasting glucose decreased for most participants. None of the participants who passed age 75 developed diabetes or a significant upward slope of fasting glucoses plotted over time.

A retrospective cohort study of over 16,000 Japanese adults with mean BMI 22.5 kg/m^2^ without diabetes at baseline reported a yield of 3.2 percent for annual screening over three consecutive years.^69^ The study also found that the yield was much lower for those with HbA1c less than 5.5 percent at baseline and those with HbA1c 5.5 to 5.9 percent at baseline than for those with HbA1c 6.0 to 6.4 percent at baseline (0.5% vs. 1.2% vs. 20%).

### CQ 5 What is the utility of recently published modeling studies that assess screening for type 2 diabetes and prediabetes (vs. no screening) in examining health outcomes?

The prior report for the USPSTF described four recently published (at that time; from 2007 to 2012) modeling studies that estimated the cost-effectiveness of various screening strategies for diabetes, IFG, or IGT in the United States, United Kingdom, or Canada.^70–74^ The modeling studies evaluated screening with capillary blood glucose, fasting plasma glucose, and OGTT; none evaluated screening with HbA1c. One study evaluated one-time screening,^72^ and the other three modeled rescreening at various intervals (e.g., every 3 years with fasting plasma glucose^71^ or rescreening every 1, 3, or 5 years with annual screening for those with IFG or IGT^73^). All of them were conducted prior to the publication of the ADDITION-Europe and ADDITION-Cambridge trials (described in KQs 1 and 4). All of them found incremental cost-effectiveness ratios less than $15,000 per quality-adjusted life-year for screening strategies beginning at age 40 or 45. Three of the four modeled screening followed by treatment of diabetes, IFG, or IGT; one modeled screening and treatment of diabetes (but not prediabetes/IFG/IGT^71^). The two models that reported on the timing of benefits estimated that they accrued over 10^73^ to 30^72^ years.

One of the modeling studies in the prior report that was conducted in the United States used the Archimedes model, that has been shown to have good calibration (with clinical and epidemiologic studies) for its assumptions regarding rates of diabetes progression and outcomes.^71^ The study compared eight simulated screening strategies with the most optimal incremental cost-effectiveness ratios for strategies starting between the ages of 30 and 45 with rescreening every 3 to 5 years. Beginning screening at age 45 with fasting plasma glucose every 3 years was associated with an incremental cost-effectiveness ratio of less than $10,000 per quality-adjusted life-year. The estimated benefits for health outcomes include an estimated two to five deaths, three to nine myocardial infarctions, and three to nine microvascular complications prevented per 1,000 people screened. Sensitivity analyses found that the results for costs per quality-adjusted life-year were sensitive to the disutility estimated for the state of having diabetes with or without symptoms. Citing this study, the ADA notes that screening beginning at age 30 or 45 (independent of risk factors) may be cost-effective.^13^

Three more recent modeling studies were identified for this update, all using some data from ADDITION.^75–77^ One used data from ADDITION-Europe and the Michigan Model for Type 2 Diabetes to estimate the benefits of screening and intensive treatment, screening and routine treatment, and no screening (with associated 3- or 6-year delay in diagnosis) and routine treatment of diabetes and CVD risk factors.^75^ The computer simulation models accurately predicted the results of the ADDITION-Europe trial (for intensive vs. routine treatment of those with screen-detected diabetes) and estimated greater benefits at 5 years with screening, early diagnosis, and routine treatment compared with a 3- or 6-year delay in diagnosis (no screening) followed by routine treatment. The authors estimated an absolute risk reduction of 3.3 percent for cardiovascular events compared with a 3-year delay in diagnosis and 4.9 percent compared with a 6-year delay. The authors concluded that screening for diabetes to reduce the lead time between diabetes onset and diagnosis is warranted to allow for prompt multifactorial treatment.

A cost-effectiveness analysis from the ADDITION-Europe investigators conducted along with the ADDITION-Europe trial reported that the cost of the intervention was 981 pounds per patient and was not cost-effective (but that it might be if delivered at a reduced cost).^76^ The economic analyses estimated costs and quality-adjusted life-years from the U.K. National Health Service (NHS) perspective and used 2009-2010 U.K. costs and extrapolated data to 30 years using the UKPDS outcomes model.

Finally, and most recently, an updated cost-effectiveness analysis from the perspective of the U.K. NHS estimated the cost-effectiveness of intensive treatment for those with screen-detected diabetes in the ADDITION-UK trial.^77^ It found over 10-, 20-, and 30-year time horizons, incremental cost-effectiveness ratios of about 71,000, 28,000, and 27,500 pounds per quality-adjusted life-year, respectively. The authors concluded that intensive treatment for screen-detected diabetes is of borderline cost-effectiveness over 20 years or more for U.K. willingness-to-pay thresholds.

Appendix A Table 3 Studies Reporting Followup to Health Outcomes After HbA1c, FPG, and OGTT Tests, From Recent Systematic Reviews

Study Reference Country (Source) | Participants | Followup | Relative Risk of Outcome in Diabetic vs. Nondiabetic Subjects^*^
Barr^56^; Australia; (UKNSC review) | 10,026 | Median 6 years | All-cause mortality ^+^; HbA1c RR, 2.2 (1.8 to 2.8) (threshold lower at 6.1%, biasing RR downward); OGTT RR, 3.6 (2.6 to 4.9); FPG RR, 2.1 (1.2 to 3.4); CVD mortality ^+^; HbA1c RR, 2.5 (1.6 to 3.9) (threshold lower at 6.1%, biasing RR downward); OGTT RR, 5.1 (2.8 to 9.1); FPG RR, 3.7 (1.8 to 8.0)
Cederberg^65^; Finland; (UKNSC review) | 593 | Mean 9.7 years | RR of cardiovascular disease (women); HbA1c RR, 2.99 (2.5 to 3.6) [>6% vs. <5.6%, middle category excluded]; OGTT RR, 2.0 (1.2 to 3.4) [>200mg/dl vs. <139mg/dl, middle category excluded]; FPG RR, 1.4 (0.9 to 2.5) [>110mg/dl vs. <99mg/dl, middle category excluded]; RR of cardiovascular disease (men); HbA1c RR, 0.62 (0.11 to 3.42) [>6% vs. <5.6%]; OGTT RR, 0.60 (0.22 to 1.62) [>200mg/dl vs <139mg/dl]; FPG RR, 1.25 (0.75 to 2.07) [>110mg/dl vs <99mg/dl]
de Vegt^63^; Netherlands; (UKNSC review) | 2,484 | 8 years | All-cause mortality ^+^; HbA1c RR, 2.8 (1.8 to 4.4); OGTT RR, 2.5 (1.6 to 3.8); FPG RR, 2.1 (1.4 to 3.3); CVD mortality ^+^; HbA1c RR, 3.5 (1.9 to 6.3); OGTT RR, 2.6 (1.4 to 4.7); FPG RR, 2.4 (1.3 to 4.3)
Kalogeropoulos^66^; USA; (UKNSC review) | 2,386 | Median 7.2 years | Heart failure (hazard ratio per SD, unadjusted); HbA1c: HR, 1.26 (95% CI, 1.13 to 1.41); OGTT: HR, 1.22 (95% CI, 1.07 to 1.39); FPG: HR, 1.22 (95% CI, 1.10 to 1.35); Heart failure (hazard ratio per SD, adjusted for BMI and FPG); HbA1c: HR, 1.08 (95% CI, 0.90 to 1.28); OGTT: HR, 1.01 (95% CI, 0.83 to 1.23)
Kowall^55^; Germany; (UKNSC review) | 1,653 | Median 8.8 years | All-cause mortality (HR adjusted for age and sex); HbA1c5.2%: HR, 2.0 (1.04 to 3.9) 5.4/5.5%: HR 1 (ref) ≥6.1%: HR 2.5 (1.4 to 4.5); OGTT<79: HR, 1.8 (0.8 to 4.2) ≥79, <94: HR 1 (ref) ≥176: HR 3.8 (1.9 to 7.9); FPG <88: HR, 1.9 (0.8 to 4.6) ≥88, <94: HR 1 (ref) ≥115: HR 3.6 (1.7 to 7.5)
Massin DESIR study^57^; France; WHO review | 700 | 10 years | Test accuracy to predict retinopathy; HbA1c: sensitivity 9%, specificity 98%; FPG: sensitivity 19%, specificity 97% (FPG threshold lower at 115, biasing sensitivity upward and specificity downward)
McCance^60^; USA; (UKNSC review) | 960, but varied by analysis | Mean 4.5 years | Retinopathy ^+^; HbA1c RR 20.9 (9.8 to 44.8) (threshold 9.4%); OGTT RR 266 (16 to 4,344) (threshold 227); FPG RR 14.1 (6.7 to 29.7) (threshold 167); Nephropathy ^+^; HbA1c RR 2.4 (0.7 to 8.4) (threshold 9.4%); OGTT RR 3.0 (1.1 to 8.2) (threshold 227); FPG RR 2.8 (0.9 to 8.8) (threshold 167)
Metcalf^64^; New Zealand | 31,148 | Median 4 years | Thresholds used were higher than ADA 2019 for HbA1c (6.8%) and OGTT (220) but lower for FPG (122).
(UKNSC review) | | | All-cause mortality ^+^; HbA1c RR, 1.5 (1.3 to 1.8); OGTT RR, 1.5 (1.3 to 1.8); FPG RR, 1.3 (1.1 to 1.6); Cardiovascular Disease ^+^; HbA1c RR, 1.1 (1.003 to 1.2); OGTT RR, 1.2 (1.1 to 1.3; FPG RR, 1.2 (1.1 to 1.3); Coronary Heart Disease ^+^; HbA1c RR, 1.1 (0.96 to 1.2); OGTT RR, 1.2 (1.04 to 1.4); FPG RR, 1.2 (1.03 to 1.3) | Retinopathy ^+^; HbA1c RR, 3.4 (2.9 to 3.9); OGTT RR, 3.8 (3.3 to 4.4); FPG RR, 3.1 (2.7 to 3.6); Nephropathy ^+^; HbA1c RR, 3.4 (2.9 to 4.0); OGTT RR, 3.1 (2.6 to 3.7); FPG RR, 3.4 (2.9 to 4.0); Neuropathy ^+^; HbA1c RR, 2.7 (1.9 to 3.8); OGTT RR, 4.0 (2.8 to 5.7); FPG RR, 3.6 (2.6 to 5.2)
Tapp, AusDiab study^58^; Australia; (WHO review) | 1,192 | 5 years | Retinopathy; FPG (18 mg/dl increase) OR, 1.52 (1.30 to 1.77) adjusted for age; A1C (1% increase) OR, 2.29 (1.75 to 3.02) adjusted for age
Van Leiden Hoorn study^59^; Netherlands; (WHO Review) | 233 | average 9.4 years | Retinopathy; HbA1c 3.1 (95% CI, 1.5 to 6.5)^+^, (threshold lower at 5.8%).; WHO 1999 criteria RR, 1.8 (0.9 to 3.7)^+^.; HbA1c OR, 3.3 (95% CI, 1.1 to 9.7, HbA1c.>5.8 in comparison to <5.2, adjusted for sex hypertension age and glycemic category according to WHO 1999 criteria); WHO 1999 OR, 1.91 (95% CI, 0.7 to 5.4, WHO diabetic vs. WHO normoglycemic, prediabetics excluded, adjusted for sex and hypertension age and HbA1c category)

Note: Units for FPG and OGTT are in mg/dL and HbA1c in percent.

* Above in comparison to below the ADA threshold or nearest available threshold unless otherwise stated.

+ Unadjusted and not reported by the article (but calculated from data reported in the article).

Abbreviations: A1c=glycated hemoglobin; CI=confidence interval; CVD=cardiovascular disease; DESIR=Data From an Epidemiological Study on the Insulin Resistance Syndrome; FPG=fasting plasma glucose; HbA1c/HBA1c=hemoglobin A1c; OGTT=oral glucose tolerance test; OR=odds ratio; RR=relative risk; UKNSC=U.K. National Screening Committee; USA=United States of America; vs.=versus; WHO=World Health Organization.