# References

1 U.S. Preventive Services Task Force. Screening for Chlamydia and Gonorrhea: Recommendation Statement. American Family Physician. 2015;91(7):486A–D.
2 U.S. Preventive Services Task Force. Screening for chlamydial infection: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2007 Jul 17;147(2):128–34. doi: 10.7326/0003-4819-147-2-200707170-00172. PMID: 17576996.17576996
3 U.S. Preventive Services Task Force. Screening for Gonorrhea: Recommendation Statement. Ann Fam Med. 2005;3(3):263–7. doi: 10.1370/afm.337. PMID: 15928231.15928231
4 Stephens RS. The cellular paradigm of chlamydial pathogenesis. Trends in microbiology. 2003 Jan 16;11(1):44–51. doi: 10.1016/S0966-842X(02)00011-2. PMID: 12526854.12526854
5 Centers for Disease Control and Prevention. CDC Grand Rounds: Chlamydia prevention: challenges and strategies for reducing disease burden and sequelae. MMWR Morb Mortal Wkly Rep. 2011 Apr 1;60(12):370–3. PMID: 21451447.21451447
6 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2017. Atlanta, GA; 2018. https://www.cdc.gov/std/stats17/default.htm. Accessed April 29, 2020.
7 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2011. US Department of Health and Human Services. Atlanta, GA: 2012. http://www.cdc.gov/std/stats11/toc.htm.
8 Edwards JL, Apicella MA. The molecular mechanisms used by Neisseria gonorrhoeae to initiate infection differ between men and women. Clin Microbiol Rev. 2004 Oct 19;17(4):965–81. doi: 10.1128/cmr.17.4.965-981.2004. PMID: 15489357.15489357
9 Merz AJ, So M. Interactions of pathogenic Neisseriae with epithelial cell membranes. Annual review of cell and developmental biology. 2000 Oct 14;16:423–57. doi: 10.1146/annurev.cellbio.16.1.423. PMID: 11031243.11031243
10 American Academy of Pediatrics. Prevention of Neonatal Ophthalmia. In: Kimberlin DW, Brady MT, Jackson MA, eds. Red Book: 2018 Report of the Committee on Infectious Diseases. 31st ed.: American Academy of Pediatrics; 2018:1046.
11 Centers for Disease Control and Prevention. Sexually Transmitted Disease surveillance 2019. Atlanta: U.S Department of Health and Human Services. 2021.
12 Torrone E, Papp J, Weinstock H. Prevalence of Chlamydia trachomatis genital infection among persons aged 14-39 years--United States, 2007-2012. MMWR Morb Mortal Wkly Rep. 2014 Sep 26;63(38):834–8. PMID: 25254560.25254560
13 Andrews WW, Goldenberg RL, Mercer B, . The Preterm Prediction Study: association of second-trimester genitourinary chlamydia infection with subsequent spontaneous preterm birth. Am J Obstet Gynecol. 2000 Sep;183(3):662–8. doi: 10.1067/mob.2000.106556. PMID: 10992190.10992190
14 Kohlhoff SA, Hammerschlag MR. Gonococcal and chlamydial infections in infants and children. In: Holmes K, ed Sexually Transmitted Diseases. 4th ed. New York, NY: McGraw-Hill; 2008:1613–27.
15 Brocklehurst P. Antibiotics for gonorrhoea in pregnancy. Cochrane Database Syst Rev. 2002 Apr 22(2):CD000098. doi: 10.1002/14651858.Cd000098. PMID: 1207638112076381.
16 Woods CR. Gonococcal infections in neonates and young children. Seminars in pediatric infectious diseases. 2005 Oct;16(4):258–70. doi: 10.1053/j.spid.2005.06.006. PMID: 16210106.16210106
17 Curry SJ, Krist AH, Owens DK, . Ocular Prophylaxis for Gonococcal Ophthalmia Neonatorum: US Preventive Services Task Force Reaffirmation Recommendation Statement. JAMA. 2019 Jan 29;321(4):394–8. doi: 10.1001/jama.2018.21367. PMID: 30694327.30694327
18 Brunham RC, Gottlieb SL, Paavonen J. Pelvic Inflammatory Disease. New England Journal of Medicine. 2015;372(21):2039–48. doi: 10.1056/NEJMra1411426. PMID: 25992748.25992748
19 Wiesenfeld HC, Hillier SL, Meyn LA, . Subclinical pelvic inflammatory disease and infertility. Obstet Gynecol. 2012 Jul;120(1):37–43. doi: 10.1097/AOG.0b013e31825a6bc9. PMID: 22678036.22678036
20 Fleming DT, Wasserheit JN. From epidemiological synergy to public health policy and practice: the contribution of other sexually transmitted diseases to sexual transmission of HIV infection. Sex Transm Infect. 1999 Feb;75(1):3–17. doi: 10.1136/sti.75.1.3. PMID: 10448335.10448335
21 Wallin KL, Wiklund F, Luostarinen T, . A population-based prospective study of Chlamydia trachomatis infection and cervical carcinoma. Int J Cancer. 2002 Oct 1;101(4):371–4. doi: 10.1002/ijc.10639. PMID: 12209962.12209962
22 Stamm WE. Chlamydia trachomatis infections of the adult. In: Holmes K, ed Sexually Transmitted Diseases. 4th ed. New York, NY: McGraw-Hill; 2008:575–606.
23 Arya R, Mannion PT, Woodcock K, . Incidence of genital Chlamydia trachomatis infection in the male partners attending an infertility clinic. J Obstet Gynaecol. 2005 May;25(4):364–7. doi: 10.1080/01443610500118749. PMID: 16091321.16091321
24 Hwang L, Shafer MA. Chlamydia trachomatis infection in adolescents. Adv. Pediatr. 2004;51:379–407. PMID: 15366781.15366781
25 Baeten JM, Overbaugh J. Measuring the infectiousness of persons with HIV-1: opportunities for preventing sexual HIV-1 transmission. Current HIV research. 2003 Jan;1(1):69–86. doi: 10.2174/1570162033352110. PMID: 15043213.15043213
26 Rottingen JA, Cameron DW, Garnett GP. A systematic review of the epidemiologic interactions between classic sexually transmitted diseases and HIV: how much really is known? Sex Transm Dis. 2001 Oct;28(10):579–97. PMID: 11689757.11689757
27 Annan NT, Sullivan AK, Nori A, . Rectal chlamydia--a reservoir of undiagnosed infection in men who have sex with men. Sex Transm Infect. 2009 Jun;85(3):176–9. doi: 10.1136/sti.2008.031773. PMID: 19176570.19176570
28 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveilance 2012. Atlanta, GA: National Center for HIV/AIDS, Viral Hepatitis, STD and TB Prevention, Division of STD Prevention; 2013. https://www.cdc.gov/std/stats/archive/Surv2012.pdf. Accessed July 8, 2014.
29 Workowski KA, Bachmann LH, Chan PA, . Sexually Transmitted Infections Treatment Guidelines, 2021. MMWR Recomm Rep. 2021 Jul 23;70(4):1–187. doi: 10.15585/mmwr.rr7004a1. PMID: 34292926.34292926
30 Centers for Disease Control and Prevention, Workowski KA, Berman SM. Sexually transmitted diseases treatment guidelines, 2006. MMWR. Recommendations and reports : Morbidity and mortality weekly report. Recommendations and reports / Centers for Disease Control. 2006;55(RR-11):1–94. PMID: 16888612.16888612
31 Johnson Jones ML, Chapin-Bardales J, Bizune D, . Extragenital chlamydia and gonorrhea among community venue-attending men who have sex with men - five cities, United States, 2017. MMWR. Morbidity and mortality weekly report. 2019;68(14):321–5. doi: 10.15585/mmwr.mm6814a1. PMID: 30973847.30973847
32 Patton ME, Kidd S, Llata E, . Extragenital gonorrhea and chlamydia testing and infection among men who have sex with men-STD Surveillance Network, United States, 2010-2012. Clin Infect Dis. 2014 Jun;58(11):1564–70. doi: 10.1093/cid/ciu184. PMID: 24647015.24647015
33 Dewart CM, Bernstein KT, DeGroote NP, . Prevalence of rectal chlamydial and gonococcal infections: a systematic review. Sexually transmitted diseases. 2018;45(5):287–93. doi: 10.1097/OLQ.0000000000000754. PMID: 29465688.29465688
34 Chan PA, Robinette A, Montgomery M, . Extragenital infections caused by Chlamydia trachomatis and Neisseria gonorrhoeae: a review of the literature. Infect Dis Obstet Gynecol. 2016;2016:5758387. doi: 10.1155/2016/5758387. PMID: 27366021.27366021
35 Trebach JD, Chaulk CP, Page KR, . Neisseria gonorrhoeae and Chlamydia trachomatis among women reporting extragenital exposures. Sexually Transmitted Diseases. 2015 May;42(5):233–9. doi: 10.1097/OLQ.0000000000000248. PMID: 25868133.25868133
36 Danby CS, Cosentino LA, Rabe LK, . Patterns of extragenital chlamydia and gonorrhea in women and men who have sex with men reporting a history of receptive anal intercourse. Sex Transm Dis. 2016 Feb;43(2):105–9. doi: 10.1097/OLQ.0000000000000384. PMID: 26766527.26766527
37 Newman LM, Dowell D, Bernstein K, . A tale of two gonorrhea epidemics: results from the STD surveillance network. Public Health Rep. 2012 May-Jun;127(3):282–92. doi: 10.1177/003335491212700308. PMID: 22547859.22547859
38 Bernstein KT, Marcus Jl Fau - Nieri G, Nieri G Fau - Philip SS, . Rectal gonorrhea and chlamydia reinfection is associated with increased risk of HIV seroconversion. (1944-7884 (Electronic)).
39 Llata E, Braxton J, Asbel L, . New human immunodeficiency virus diagnoses among men who have sex with men attending sexually transmitted disease clinics, STD Surveillance Network, January 2010 to June 2013. Sexually Transmitted Diseases. 2018 Sep;45(9):577–82. doi: 10.1097/OLQ.0000000000000802. PMID: 29465646.29465646
40 Barrow RY, Ahmed F, Bolan GA, . Recommendations for Providing Quality Sexually Transmitted Diseases Clinical Services, 2020. MMWR. Recommendations and reports : Morbidity and mortality weekly report. Recommendations and reports. 2020;68(5):1–20. doi: 10.15585/mmwr.rr6805a1. PMID: 31899459.31899459
41 Kong FY, Tabrizi SN, Law M, . Azithromycin versus doxycycline for the treatment of genital chlamydia infection: a meta-analysis of randomized controlled trials. Clin Infect Dis. 2014 Jul 15;59(2):193–205. doi: 10.1093/cid/ciu220. PMID: 24729507.24729507
42 St Cyr S, Barbee L, Workowski KA, . Update to CDC’s Treatment Guidelines for Gonococcal Infection, 2020. MMWR Morb Mortal Wkly Rep. 2020 Dec 18;69(50):1911–6. doi: 10.15585/mmwr.mm6950a6. PMID: 33332296.33332296
43 U.S. Food and Drug Administration. FDA clears first diagnostic tests for extragenital testing for chlamydia and gonorrhea. 2019. https://www.fda.gov/news-events/press-announcements/fda-clears-first-diagnostic-tests-extragenital-testing-chlamydia-and-gonorrhea. Accessed April 30, 2020.
44 Centers for Disease Control and Prevention. Recommendations for the laboratory-based detection of Chlamydia trachomatis and Neisseria gonorrhoeae--2014. MMWR Recomm Rep. 2014 Mar 14;63(RR-02):1–19. PMID: 24622331.24622331
45 Olshen E, Shrier LA. Diagnostic tests for chlamydial and gonorrheal infections. Seminars in pediatric infectious diseases. 2005 Jul 27;16(3):192–8. doi: 10.1053/j.spid.2005.04.008. PMID: 16044393.16044393
46 LeFevre ML. Screening for Chlamydia and gonorrhea: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014 Dec 16;161(12):902–10. doi: 10.7326/m14-1981. PMID: 25243785.25243785
47 Papp J, Schachter J, Gaydos C, . Recommendations for the Laboratory-Based Detection of Chlamydia trachomatis and Neisseria gonorrhoeae — 2014. Morbidity and Mortality Weekly Report. Atlanta, GA: 2014. https://www.cdc.gov/std/laboratory/2014labrec/2014-lab-rec.pdf.
48 American College of Obstetricians and Gynecologists. Chlamydia, Gonorrhea and Syphilis. 2019. https://www.acog.org/womens-health/faqs/chlamydia-gonorrhea-and-syphilis#:~:text=around%20the%20cervix.-,A%20yearly%20screening%20test%20is%20recommended%20for%20women%20younger%20than,with%20risk%20factors%20for%20gonorrhea. Accessed January 4, 2021.
49 Moyer CS. STDs increasing among young women; more prevention urged. American Medical News; December 2009. http://www.amednews.com/article/20091207/profession/312079972/6/. Accessed Dec 5, 2012.
50 American Academy of Pediatrics. Adolescent Sexual Health: STI Screening Guidelines. https://www.aap.org/en-us/advocacy-and-policy/aap-health-initiatives/adolescent-sexual-health/Pages/STI-Screening-Guidelines.aspx. Accessed October 18, 2018.
51 Lee KC, Ngo-Metzger Q, Wolff T, . Sexually transmitted infections: recommendations from the U.S. Preventive Services Task Force. Am Fam Physician. 2016 Dec 1;94(11):907–15. PMID: 27929270.27929270
52 American College of Physicians. Chlamydia Screening in Women. 2015. https://www.acponline.org/clinical-information/performance-measures/chlamydia-screening-in-women. Accessed October 15, 2020.
53 Public Health Agency of Canada. Canadian Guidelines on Sexually Transmitted Infections: Summary of Recommendations for Chlamydia trachomatis (CT), Neisseria gonorrhoeae (NG) and Syphilis. 2019. https://www.canada.ca/en/services/health/publications/diseases-conditions/guidelines-sti-recommendations-chlamydia-trachomatis-neisseria-gonorrhoeae-syphilis-2019.html. Accessed January 4, 2021.
54 Public Health Agency of Canada. Chlamydia and LGV: Key information and resources. 2020. https://www.canada.ca/en/public-health/services/infectious-diseases/sexual-health-sexually-transmitted-infections/canadian-guidelines/chlamydia-lgv.html#a1.2. Accessed January 4, 2021.
55 Public Health Agency of Canada. Section 6-4: Canadian Guidelines on Sexually Transmitted Infections – Specific populations – Pregnancy. 2017. https://www.canada.ca/en/public-health/services/infectious-diseases/sexual-health-sexually-transmitted-infections/canadian-guidelines/sexually-transmitted-infections/canadian-guidelines-sexually-transmitted-infections-41.html. Accessed January 4, 2021.
56 Tao G, Irwin KL. Receipt of HIV and STD testing services during routine general medical or gynecological examinations: variations by patient sexual risk behaviors. Sex Transm Dis. 2008 Feb;35(2):167–71. doi: 10.1097/OLQ.0b013e3181585be5. PMID: 18090177.18090177
57 US Preventive Services Task Force. US Preventive Services Task Force Procedure Manual. Rockville, MD: Agency for Healthcare Research and Quality; 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.
58 Nelson HD, Zakher B, Cantor A, . Screening for Gonorrhea and Chlamydia: Systematic Review to Update the U.S. Preventive Services Task Force Recommendations. Evidence Synthesis No. 115. AHRQ Publication No. 13-05184-EF-1. Agency for Healthcare Research and Quality (US). Rockville, MD: Quality AfHRa; September 2014. PMID: 2535645125356451.
59 Mayer D. Essential Evidence-Based Medicine. 2nd ed. Cambridge, UK: Cambridge University Press; 2010.
60 Zakher B, Cantor AG, Pappas M, . Screening for gonorrhea and Chlamydia: a systematic review for the U.S. Preventive Services Task Force. Annals of Internal Medicine. 2014 Dec 16;161(12):884–93. doi: 10.7326/M14-1022. PMID: 25244000.25244000
61 Berry L, Stanley B. Comparison of self-collected meatal swabs with urine specimens for the diagnosis of Chlamydia trachomatis and Neisseria gonorrhoeae in men. Journal of Medical Microbiology. 2017 Feb;66(2):134–6. doi: 10.1099/jmm.0.000428. PMID: 28068218.28068218
62 Falasinnu T, Gilbert M, Gustafson P, . Deriving and validating a risk estimation tool for screening asymptomatic chlamydia and gonorrhea. Sex Transm Dis. 2014 Dec;41(12):706–12. doi: 10.1097/OLQ.0000000000000205. PMID: 25581805.25581805
63 Falasinnu T, Gilbert M, Gustafson P, . A validation study of a clinical prediction rule for screening asymptomatic chlamydia and gonorrhoea infections among heterosexuals in British Columbia. Sex Transm Infect. 2016a Feb;92(1):12–8. doi: 10.1136/sextrans-2014-051992. PMID: 25933609.25933609
64 Falasinnu T, Gilbert M, Gustafson P, . An assessment of population-based screening guidelines versus clinical prediction rules for chlamydia and gonorrhea case finding. Prev Med. 2016b Aug;89:51–6. doi: 10.1016/j.ypmed.2016.04.001. PMID: 27143496.27143496
65 Fang J, Husman C, DeSilva L, . Evaluation of self-collected vaginal swab, first void urine, and endocervical swab specimens for the detection of Chlamydia trachomatis and Neisseria gonorrhoeae in adolescent females. J Pediatr Adolesc Gynecol. 2008;21(6):355–60. doi: 10.1016/j.jpag.2008.03.010. PMID: 19064231.19064231
66 Grentzer JM, Peipert JF, Zhao Q, . Risk-based screening for Chlamydia trachomatis and Neisseria gonorrhoeae prior to intrauterine device insertion. Contracept. 2015 Oct;92(4):313–8. doi: 10.1016/j.contraception.2015.06.012. PMID: 26093189.26093189
67 Hocking JS, Temple-Smith M, Guy R, . Population effectiveness of opportunistic chlamydia testing in primary care in Australia: a cluster-randomised controlled trial. Lancet. 2018 Oct 20;392(10156):1413–22. doi: 10.1016/S0140-6736(18)31816-6. PMID: 30343857.30343857
68 Javanbakht M, Westmoreland D, Gorbach P. Factors associated with pharyngeal gonorrhea in young people: implications for prevention. Sex Transm Dis. 2018 Sep;45(9):588–93. doi: 10.1097/OLQ.0000000000000822. PMID: 29485543.29485543
69 Lavoue V, Morcel K, Voltzenlogel MC, . Scoring system avoids Chlamydia trachomatis overscreening in women seeking surgical abortions. Sex Transm Dis. 2014 Aug;41(8):470–4. doi: 10.1097/OLQ.0000000000000153. PMID: 25013973.25013973
70 Miller WC, Hoffman IF, Owen-O’Dowd J, . Selective screening for chlamydial infection: which criteria to use? Am J Prev Med. 2000 Feb;18(2):115–22. doi: 10.1016/s0749-3797(99)00146-4. PMID: 10698241.10698241
71 Nye MB, Osiecki J, Lewinski M, . Detection of Chlamydia trachomatis and Neisseria gonorrhoeae with the cobas CT/NG v2.0 test: performance compared with the BD probetec CT Q and GC Q amplified DNA and aptima AC2 assays. Sex Transm Infect. 2019 03;95(2):87–93. doi: 10.1136/sextrans-2018-053545. PMID: 30126947.30126947
72 Skidmore S, Kaye M, Bayliss D, . Validation of COBAS Taqman CT for the detection of Chlamydia trachomatis in vulvo-vaginal swabs. Sex Transm Infect. 2008 Aug;84(4):277–8; discussion 8-9. doi: 10.1136/sti.2007.029587. PMID: 18305120.18305120
73 Sultan B, White JA, Fish R, . The “3 in 1” study: pooling self-taken pharyngeal, urethral, and rectal samples into a single sample for analysis for detection of Neisseria gonorrhoeae and Chlamydia trachomatis in men who have sex with men. J Clin Microbiol. 2016 Mar;54(3):650–6. doi: 10.1128/JCM.02460-15. PMID: 26719439.26719439
74 Oakeshott P, Kerry S, Aghaizu A, . Randomised controlled trial of screening for Chlamydia trachomatis to prevent pelvic inflammatory disease: the POPI (prevention of pelvic infection) trial. BMJ. 2010 Apr 8;340:c1642. doi: 10.1136/bmj.c1642. PMID: 20378636.20378636
75 Østergaard L, Andersen B, Moller JK, . Home sampling versus conventional swab sampling for screening of Chlamydia trachomatis in women: a cluster-randomized 1-year follow-up study. Clin Infect Dis. 2000 Oct;31(4):951–7. doi: 10.1086/318139. PMID: 11049776.11049776
76 Schachter J, McCormack WM, Chernesky MA, . Vaginal swabs are appropriate specimens for diagnosis of genital tract infection with Chlamydia trachomatis. J Clin Microbiol. 2003 Aug;41(8):3784–9. doi: 10.1128/jcm.41.8.3784-3789.2003. PMID: 12904390.12904390
77 Schoeman SA, Stewart CM, Booth RA, . Assessment of best single sample for finding chlamydia in women with and without symptoms: a diagnostic test study. BMJ. 2012 Dec 12;345:e8013. doi: 10.1136/bmj.e8013. PMID: 23236032.23236032
78 Scholes D, Stergachis A, Heidrich FE, . Prevention of pelvic inflammatory disease by screening for cervical chlamydial infection. N Engl J Med. 1996 May 23;334(21):1362–6. doi: 10.1056/nejm199605233342103. PMID: 8614421.8614421
79 Shrier LA, Dean D, Klein E, . Limitations of screening tests for the detection of Chlamydia trachomatis in asymptomatic adolescent and young adult women. Am J Obstet Gynecol. 2004 Mar;190(3):654–62. doi: 10.1016/j.ajog.2003.09.063. PMID: 15041995.15041995
80 Stewart CM, Schoeman SA, Booth RA, . Assessment of self taken swabs versus clinician taken swab cultures for diagnosing gonorrhoea in women: single centre, diagnostic accuracy study. BMJ. 2012 Dec 12;345:e8107. doi: 10.1136/bmj.e8107. PMID: 23236033.23236033
81 Chernesky MA, Martin DH, Hook EW, . Ability of new APTIMA CT and APTIMA GC assays to detect Chlamydia trachomatis and Neisseria gonorrhoeae in male urine and urethral swabs. J Clin Microbiol. 2005 Jan;43(1):127–31. doi: 10.1128/jcm.43.1.127-131.2005. PMID: 15634960.15634960
82 Gaydos CA, Van Der Pol B, Jett-Goheen M, . Performance of the cepheid CT/NG xpert rapid PCR test for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2013 Jun;51(6):1666–72. doi: 10.1128/jcm.03461-12. PMID: 23467600.23467600
83 Gotz HM, Veldhuijzen IK, Habbema JD, . Prediction of Chlamydia trachomatis infection: application of a scoring rule to other populations. Sex Transm Dis. 2006 Jun;33(6):374–80. doi: 10.1097/01.olq.0000194585.82456.51. PMID: 16505746.16505746
84 Taylor SN, Liesenfeld O, Lillis RA, . Evaluation of the roche cobas(R) CT/NG test for detection of Chlamydia trachomatis and Neisseria gonorrhoeae in male urine. Sex Transm Dis. 2012 Jul;39(7):543–9. doi: 10.1097/OLQ.0b013e31824e26ff. PMID: 22706217.22706217
85 Taylor SN, Van Der Pol B, Lillis R, . Clinical evaluation of the BD probetec Chlamydia trachomatis qx amplified DNA assay on the BD viper system with XTR technology. Sex Transm Dis. 2011 Jul;38(7):603–9. doi: 10.1097/OLQ.0b013e31820a94d2. PMID: 21301389.21301389
86 Van Der Pol B, Liesenfeld O, Williams JA, . Performance of the cobas CT/NG test compared to the aptima AC2 and viper CTQ/GCQ assays for detection of Chlamydia trachomatis and Neisseria gonorrhoeae. J Clin Microbiol. 2012 Jul;50(7):2244–9. doi: 10.1128/jcm.06481-11. PMID: 22518864.22518864
87 Van Der Pol B, Taylor SN, Lebar W, . Clinical evaluation of the BD probetec Neisseria gonorrhoeae qx amplified DNA assay on the BD viper system with XTR technology. Sex Transm Dis. 2012 Feb;39(2):147–53. doi: 10.1097/OLQ.0b013e3182372fd8. PMID: 22249304.22249304
88 Andersen B, Ostergaard L, Moller JK, . Home sampling versus conventional contact tracing for detecting Chlamydia trachomatis infection in male partners of infected women: randomised study. BMJ. 1998 Jan 31;316(7128):350–1. doi: 10.1136/bmj.316.7128.350. PMID: 9487169.9487169
89 Ding A, Challenor R. Rectal Chlamydia in heterosexual women: more questions than answers. Int J STD AIDS. 2014 Jul;25(8):587–92. doi: 10.1177/0956462413515637. PMID: 24352134.24352134
90 Kwong JC, Chow EPF, Stevens K, . Whole-genome sequencing reveals transmission of gonococcal antibiotic resistance among men who have sex with men: an observational study. Sex Transm Infect. 2018 03;94(2):151–7. doi: 10.1136/sextrans-2017-053287. PMID: 29247013.29247013
91 Althaus CL, Turner KM, Mercer CH, . Effectiveness and cost-effectiveness of traditional and new partner notification technologies for curable sexually transmitted infections: observational study, systematic reviews and mathematical modelling. Health Technol Assess. 2014 Jan;18(2):1–100, vii–viii. doi: 10.3310/hta18020. PMID: 24411488.24411488
92 Estcourt CS, Sutcliffe LJ, Copas A, . Developing and testing accelerated partner therapy for partner notification for people with genital Chlamydia trachomatis diagnosed in primary care: a pilot randomised controlled trial. Sexually Transmitted Infections. 2015 Dec;91(8):548–54. doi: 10.1136/sextrans-2014-051994. PMID: 26019232.26019232
93 Ferreira A, Young T, Mathews C, . Strategies for partner notification for sexually transmitted infections, including HIV. Cochrane Database Syst Rev. 2013 Oct 3(10):Cd002843. doi: 10.1002/14651858.CD002843.pub2. PMID: 2409252924092529.
94 Mohammed H, Mitchell H, Sile B, . Increase in Sexually Transmitted Infections among Men Who Have Sex with Men, England, 2014. Emerg Infect Dis. 2016 Jan;22(1):88–91. doi: 10.3201/eid2201.151331. PMID: 26689861.26689861
95 Unemo M, Shafer WM. Antimicrobial resistance in Neisseria gonorrhoeae in the 21st century: past, evolution, and future. Clin Microbiol Rev. 2014 Jul;27(3):587–613. doi: 10.1128/CMR.00010-14. PMID: 24982323.24982323
96 Marcus JL, Bernstein KT, Kohn RP, . Infections missed by urethral-only screening for chlamydia or gonorrhea detection among men who have sex with men. Sex Transm Dis. 2011 Oct;38(10):922–4. doi: 10.1097/OLQ.0b013e31822a2b2e. PMID: 21934565.21934565
97 Centers for Disease Control and Prevention. HIV and Transgender People. 2021. https://www.cdc.gov/hiv/group/gender/transgender/index.html. Accessed May 28, 2021.
98 Pitasi MA, Kerani RP, Kohn R, . Chlamydia, Gonorrhea, and Human Immunodeficiency Virus Infection Among Transgender Women and Transgender Men Attending Clinics that Provide Sexually Transmitted Disease Services in Six US Cities: Results From the Sexually Transmitted Disease Surveillance Network. Sex Transm Dis. 2019 Feb;46(2):112–7. doi: 10.1097/olq.0000000000000917. PMID: 30278030.30278030