# Acknowledgments

The authors thank AHRQ Medical Officers Kathleen Irwin, MD, MPH, Tina Fan, MD, MPH, and Brandy Peaker, MD, MPH; as well as the U.S. Preventive Services Task Force.