# Chapter 4 Discussion

## Summary of Review Findings

The evidence reviewed in this report is summarized in Table 13. The USPSTF previously determined that treatment is effective for chlamydial and gonococcal infections. One new trial of screening was generally consistent with prior screening trials that reported decreased risk of PID associated with screening. New evidence on risk prediction tools indicate suboptimal accuracy and require validation in primary care populations in the U.S. Evidence largely confirmed prior findings regarding high accuracy of diagnostic testing at various anatomic sites and home-based testing, with low false-positive and false-alarm rates. Important gaps include lack of studies on psychosocial or other harms related to screening, studies comparing screening intervals or alternative screening strategies, and studies evaluating changes in risk behaviors or risk perception.

Table 13 Summary of Evidence

Key Question | Population | Studies (k); Participants (n); Study Design | Summary of Findings | Consistency and Precision | Limitations | Strength of Evidence | Applicability
Key Question 1. Effectiveness of screening vs. no screening | Young women; young adults | Prior review:; k=3; n=6,836; New evidence:; k=1 n=63,338; RCTs | The prior review included 3 studies of screening women at increased risk for chlamydia that favored screening; only 1 study showed statistically significantly reduced rates of PID (RR 0.44; 95% CI 0.20 to 0.90). One new RCT of screening men and women age 16 to 29 for chlamydia found reduced rates of hospital diagnosed PID (RR 0.6; 95% CI, 0.4 to 1.0), though absolute effects were small. There was no difference in rates of PID or epididymitis diagnosed in clinics. No studies of gonorrhea screening were identified. | Consistent; imprecise | Prior trials were underpowered to address health outcomes; limited health outcomes reported in studies. No studies of gonorrhea screening. Limited studies of chlamydia screening in men or pregnant women. | Low | Moderate
Key Question 2. Accuracy of risk stratification methods for identifying persons at increased risk | Women, men, MSM, young adults | Prior review:; k=0; New evidence:; k=7; n=93,137 | No diagnostic accuracy studies of risk stratification in prior review. Seven studies evaluated accuracy of risk criteria and demonstrated low to moderate accuracy. Two studies of the “Vancouver” risk tool and one study of a 3-item risk score for identifying persons with chlamydial or gonococcal infections reported AUCs that ranged from 0.64 to 0.73. Age criteria alone (≤ 22) performed nearly as well as multiple item criteria for predicting chlamydia infection in women (AUC 0.687, SD 0.014). No studies compared screening intervals or alternative screening strategies such as testing for concurrent infection, including HIV. | Consistent; precise | Studies were retrospective and cross-sectional; models were applied to patients in one geographic location or population; unclear performance in other geographic locations or other populations. | Moderate | Moderate; Most studies conducted in one geographic location or high prevalence setting.
Key Question 3. Diagnostic accuracy of anatomic site-specific testing and collection methods | Men, Women, MSM; adolescents | Prior review:; k=4; n=9,474; New evidence:; k=5; n=6,730 | Site-specific testing for chlamydia was highly accurate:; Endocervical sensitivity range 89 to 100% (7 studies); vaginal sensitivity range 90 to 100% (7 studies); Specificities were 99 to 100% for endocervical testing, 95 to 100% for vaginal testing, and 96 to 100% for urinalysis. Sensitivities were high for meatal (100%), urethral (99%) and rectal (92%), but low for pharyngeal (69%) testing in males based on one study each. Specificities were ≥99 percent at all sites; specificity was not reported for pharyngeal testing.; Site-specific testing for gonorrhea was highly accurate:; Endocervical sensitivity 96% to 98% (3 studies); vaginal sensitivity range 98% to 100% (3 studies); urinalysis, females: sensitivity 89% and 100% (2 studies); Specificity was high at all sites (95% to 100%).; High sensitivity for urinalysis in males: 93% to 100% (1 study); Other sites, males: 89% to 100% (1 study, including rectal and pharyngeal sites).; Collection methods for chlamydia were highly accurate:; Self-collected, vaginal: sensitivity 90% and 98%, (8 studies, excluding one outlier study that reported 52%); Clinician-collected, vaginal: sensitivity 90% and 100%, (5 studies, excluding one outlier study that reported 56%); Collection methods for gonorrhea in women were highly accurate:; Self-collected, vaginal: sensitivity 100% (3 studies); Clinician-collected, vaginal: sensitivity 100% (1 study); No studies compared collection methods in males for chlamydia or gonorrhea testing. | Consistent; precise, excluding one outlier study | Some studies included symptomatic participants; prevalence of chlamydial or gonococcal infection ranged up to 27%; limited evidence on collection methods. | Moderate for accuracy of chlamydial and gonococcal testing; low for collection methods | High for accuracy of testing; moderate for collection methods
Key Question 4. Harms of screening vs. no screening | Men, Women, MSM; adolescents | Prior review:; k=4; n=9,474; New evidence:; k=4; n=5,666 | False negative rates ranged from 0 to 28% and false positive rates were consistently low (range 0 to 2%) across all anatomic sites for female and male samples. For females, false positive rates for self- versus clinician collected methods ranged from 0 to 1.2%; false positive rates ranged from 0 to 12%. No studies reported harms of collection methods in males.; No studies of psychosocial harms, such as anxiety related to testing, or studies of risk behaviors or risk perception. | Consistent for testing related harms; precise for testing related harms; N/A for psychosocial or risk behavior related harms | Some studies included symptomatic participants; prevalence of chlamydial or gonococcal infection ranged up to 27% | Moderate for testing related harms. | Moderate for testing related harms.

Abbreviations: AUC = area under the receiving operator curve; HIV = human immunodeficiency virus; MSM = men who have sex with men; NA = not applicable; PID = pelvic inflammatory disease; SD = standard deviation; RR = relative risk.

Results of four screening trials, including one new trial, found screening for chlamydia associated with decreased risk of PID, though effects were not statistically significant in most trials and the magnitude of benefit was relatively small. No studies reported on the effectiveness of screening in men, other than one study that reported rates of epididymitis,^67^ and there were no studies of pregnant individuals for any outcome. One large, new, good- quality trial of young men and women in primary care clinics in rural Australia found screening for chlamydia associated with reduced risk of hospital diagnosed PID in hospital diagnosed patients, although absolute effects were small (absolute difference −13.7 per 100,000 women).^67^ In contrast to the three trials included in the prior report, this trial enrolled both men and women in primary care practices. There was no difference in risk of clinic-based PID diagnosis in women, epididymitis in men, or prevalence of chlamydia infection in young men or women. The study did not report data on transmission of infection.

This report included studies on the accuracy of risk criteria that were not addressed in prior USPSTF reviews. Three studies in asymptomatic patients found fair discrimination, but require further validation in diverse clinical and geographic settings. One study in a mixed population of asymptomatic and symptomatic women found similar discrimination of age ≤22 alone versus multi-item risk criteria. In other populations (women presenting for IUD insertion or surgical abortion) risk criteria were not accurate. One study found a high rate of pharyngeal gonorrhea in a population of high risk persons attending STI clinics, with a strong correlation between increasing numbers of oral sex partners in the three month period and rates of pharyngeal gonorrhea. Screening both urogenital and pharyngeal sites in order to increase sensitivity of case detection in certain populations may have implications for extragenital testing in other higher risk populations, especially given data on the association between rectal STI and HIV acquisition in men.^27,94^

Accuracy of diagnostic testing for chlamydia was highly accurate across all genitourinary anatomic sites with vaginal and endocervical testing demonstrating the highest accuracy,^65,71,72,76,77,79^ followed by urine testing in females.^65,71,72,76,79^ In males, meatal,^61^ urethral^73^ and urine^61,71^ testing yielded similarly high sensitivity, as did rectal testing,^73^ based on one study. Gonococcal testing was also highly accurate across anatomic sites for females with endocervical and vaginal sites demonstrating the highest accuracy,^65,71,80^ followed by urine samples.^71^ Urine testing for gonococcal infections demonstrated the highest sensitivity in males compared with meatal testing.^61,71^ One study of pharyngeal testing, conducted in MSM, demonstrated low sensitivity for chlamydial infection (69.2%) but higher sensitivity for gonococcal infection (89.1%).^73^ In females, self- and clinician-collected vaginal samples for chlamydia and gonorrhea diagnosis were both highly sensitive,^71,76,79^ but no studies meeting inclusion criteria compared collection methods in males. These results were largely based on asymptomatic patient populations, increasing relevance to screening populations in the U.S.

In addition to diagnostic accuracy, other factors that may inform testing at extragenital sites include higher prevalence of extragenital chlamydial and gonococcal infection in MSM and persons attending STI clinics, as well as persons engaging in sexual contact at those sites. A small observational study of MSM in Australia reported the prevalence of antibiotic resistant gonorrhea in partners of infected patients using pharyngeal and rectal swabs and demonstrated that asymptomatic MSM can transmit antibiotic resistant strains of gonorrhea directly to their partners.^90^ In the U.S., prevalence data indicates that MSM are disproportionately affected by STIs, including HIV.^31^ In a report of prevalence data from STI and HIV clinic attendees, approximately one in eight men had an extragenital chlamydial or gonococcal infection.^31^ Given the reported rates of antibiotic resistant strains of gonococcal infection for MSM,^95^ considerations to expand the range of specimen types for screening has the potential to increase identification of infected individuals, especially for asymptomatic MSM in whom nearly 90 percent of all gonorrhea infections are in non-genital sites.^96^

There are few harms to screening for infection based on findings from this review, including low rates of false positive or false negative findings, false alarm rates, and false reassurance rates. However, no studies provided data about other potential adverse effects of screening for any population groups, including anxiety, changes in risk behaviors or risk perception. Further research is needed to determine the effectiveness of screening in multiple populations and on various clinical outcomes; trials of gonorrhea screening, including screening high risk groups; effective screening strategies and intervals; and harms of screening.

## Limitations

We restricted inclusion to English language studies and did not include studies published only as abstracts or modeling studies of screening versus no screening; however, we did not identify non-English language studies in our searches or unpublished studies that met inclusion criteria. The inclusion criteria for this review included settings and tests relevant to current U.S. practice and did not re-evaluate the accuracy of NAAT testing. Studies that evaluated that accuracy of rectal or extragenital NAAT prior to their FDA clearance were also not included, which may limit some data informing the performance of certain tests. Therefore, some studies included in the prior USPSTF review were excluded, reducing the potential evidence base. However, this approach improved the relevance of the evidence to the USPSTF screening recommendation. There was variation in the quality and applicability of studies. A number of studies were conducted in STI clinics or other high-risk clinical settings or in persons at higher risk for infection, which may reduce applicability to primary care settings or persons at lower risk. Evidence on men was limited and there were no studies of pregnant individuals. Screening trials focused on PID and epididymitis as the main outcome, but other health outcomes such as infertility, chronic pelvic pain and ectopic pregnancy are also relevant, but may be more challenging to correlate. Detection of PID and epididymitis in one trial may have been limited by relatively low screening rates (17% to 25%).^67^ Differences in assay sensitivity may have contributed to differential impact on PID prevention. There were no screening studies that reported disease acquisition or transmission. Meta-analysis was not performed due to relatively small number of studies and heterogeneity in populations, settings, comparisons, and outcomes. We were not able to do formal graphical or statistical assessments for publication bias due to small numbers of studies.

## Emerging Issues/Next Steps

Despite many years of relatively consistent screening recommendations, rates of chlamydial and gonococcal infections continue to rise. This trend is likely due in part to changes in risk behaviors, though it may also be due other factors. Screening tests for chlamydial and gonococcal infection are accurate regardless of anatomic site or collection method. Further understanding of the clinical significance of asymptomatic infections at extragenital sites and the effectiveness of screening at those sites is needed. Additional screening studies that evaluate extragenital testing may also inform strategies for screening in various settings and among target groups. There were no studies of alternative screening strategies, including testing for concurrent infection, including HIV, and no studies that addressed screening intervals. Further evaluation of expanded screening strategies may provide opportunities to further evaluate testing, especially among those at increased risk.

## Relevance for Priority Populations

Evaluating the effectiveness of testing and risk criteria among priority populations has the potential to increase identification of infected individuals. Evidence on this topic has previously focused on women, with evidence lacking for men in general, and MSM in particular. Since the prior review, additional studies among MSM have emerged that demonstrate disproportionate risk for this group despite the overwhelming lack of screening studies in this population.^31^ For this review, two studies included populations of MSM in the study population (2 to 7%)^68,73^ and no studies included transgender or non-binary populations. While most studies were primarily conducted in heterosexual populations, several groups continue to experience increased risk for sexually transmitted infections including MSM, gender minority and transgender populations, but data are limited.^97,98^ Two studies were exclusively of men,^61,73^ of which one diagnostic accuracy study evaluated anatomic site- specific testing exclusively in MSM.^73^ Two studies were exclusively of adolescents (under age 19)^65,75^ and 17 studies included for this review included adolescents in the study population.^62–70,72–74,76–80^ Two studies were primarily in Black and Hispanic/Latino populations which, based on population data, have a higher prevalence of chlamydial infection, but studies in other populations with high prevalence of infection (e.g., American Indians/Alaska Natives) are lacking.^65,68^ While findings of this review may be applicable across age categories, additional evidence is needed to inform clinical practice for men, including MSM, populations with higher prevalence of infection, rural populations, and in pregnant individuals, for whom no studies were identified.

## Future Research

Research is lacking on the effectiveness of screening for gonorrhea in all population groups and for chlamydia in men, pregnant individuals, and women without risk factors. Studies that evaluate risk assessment criteria require further validation in settings applicable to U.S. primary care practice. Future studies could compare the effectiveness of screening versus no screening in populations at different levels of risk, using specimens from different anatomical sites, screening that includes testing for concurrent STIs including HIV, and screening at different intervals. Studies could evaluate the impact of access to screening for high-risk and known underserved populations. No studies provided data about potential adverse effects of screening other than those related to test performance for any asymptomatic population group. Studies are also needed to evaluate the effect of screening on risk behavior and risk perception. No study addressed screening in pregnant individuals.

## Conclusions

Screening for chlamydial infection may reduce the incidence of PID in young women. Risk prediction criteria to identify persons with asymptomatic chlamydial or gonococcal infection are associated with limited accuracy and require further validation. Testing for asymptomatic chlamydial and gonococcal infections is accurate at most anatomic sites, using urine sampling, and using self-collected specimens. Research is needed to determine the effectiveness of screening in men, optimal screening intervals, and adverse effects of screening.