# Chapter 3 Results

## Included Studies

Our literature search resulted in 2,356 unique citations. A total of 20 studies (reported in 20 publications) met inclusion criteria. Thirteen studies^61–73^ were newly identified for this review and seven^74–80^ were carried forward from the previous USPSTF report. Seven studies from the prior review were not carried forward because they evaluated key questions or outcomes not addressed in this review (e.g., effectiveness of screening strategies, accuracy of diagnostic testing assays, NAAT testing).^81–87^

## Key Question 1 In Sexually Active, Asymptomatic Adolescents and Adults, Including Those Who Are Pregnant, What Is the Effectiveness of Screening for Chlamydial or Gonococcal Infections in Reducing Complications of Infection and Transmission or Acquisition of Disease, Including Gonorrhea, Chlamydia, and HIV?

### Summary

- The prior USPSTF review included three trials of women at increased risk for chlamydia that found screening associated with reduced risk of PID versus no screening. While risk of PID was reduced with screening in all 3 trials, results were statistically significant in only one.
- One large new trial of men and women in primary care clinics found screening associated with a statistically significant reduction in risk of hospital diagnosed PID versus usual care, though absolute effects were small. Screening was not associated with reduced risk of clinic diagnosed PID in young women or epididymitis in young men.
- No study evaluated the effectiveness of screening for gonorrhea versus no screening.
- There were no studies reporting disease acquisition or transmission or clinical outcomes other than PID or epididymitis; there were no studies of pregnant populations.

### Evidence

#### Chlamydia

Four randomized trials evaluated the effectiveness of screening for chlamydial infection for reducing complications of infection (Table 2; Appendix B Tables 1 and 2).^67,74,75,78^ Three of the trials^74,75,78^ were also included in the prior USPSTF review.^58^ One trial was conducted in the United States,^78^ two in Europe,^74,75^ and one in rural Australia.^67^ Sample sizes ranged from 1,700 to 63,338 (total N = 70,174). Three trials enrolled women,^74,75,78^ and one trial enrolled both women and men.^67^ One trial was conducted exclusively in adolescents (high school students, mean age not reported).^75^ The other trials enrolled adolescents and adults (16 to 34 years) from a rural primary care setting,^67^ university setting,^74^ and from a population of higher risk women.^78^ Three trials compared screening versus usual care: one multi-faceted screening program,^67^ one home sampling,^75^ and one clinic-based testing.^78^ One trial compared immediate versus deferred screening.^74^ Three trials used self-collected vaginal^67,74,75^ or male urine testing,^67^ and one study used clinician-collected endocervical samples.^78^ Two trials were rated good- quality^67,74^ and two trials were rated fair- quality (Appendix B Table 3).^75,78^ Methodological limitations of the fair-quality trials included unclear details regarding randomization methods and high loss to follow-up.

Table 2 Randomized Controlled Trials of Screening for Chlamydia to Reduce Adverse Outcomes

Author, Year | Population (n) | Interventions | Duration | Attrition | Outcomes | Quality
Hocking et al., 2018^67^ | Sexually active males and females age 16-29 years in 130 primary care clinics in Australia; (n=63,338) | Multifaceted screening program vs. usual care (control) | Mean 3.1 years | Not reported | [underlined: Incidence of PID in clinic]^‡^:; Screened: 0.45% (293/65,519); Control: 0.39% (237/60,384); RR 1.1 (95% CI 0.7 to 1.8); [underlined: Incidence of PID in hospitals:]; Screened: 0.24% (57/23,527); Control: 0.38% (88/23,219); RR 0.6 (95% CI 0.4 to 1.0); [underlined: Incidence of epididymitis]^§^:; Screened: 0.26% (106/41,168); Control: 0.27% (106/38,717); RR 0.9 (95% CI 0.6 to 1.4) | Good
Oakeshott et al., 2010^†^,^74^ | Sexually active females age [underlined: <]27 years recruited from universities and colleges in the U.K.; (n=2,529) | Immediate screening vs. deferred screening after 1 year (control) | 1 year | Screened: 5%; Control: 7% | [underlined: Incidence of PID in asymptomatic women (n=1648):]; Screened: 0.6% (5/787); Control: 1.6% (14/861); RR 0.39 (95% CI 0.14 to 1.08); [underlined: Incidence of PID in all women:]; Screened: 1.3% (15/1191); Control: 1.9% (23/1186); RR 0.65 (95% CI 0.34 to 1.22) | Good
Ostergaard et al., 2000^†^,^75^ | Female students recruited from high schools in one county in Denmark; (n=1,700) | Home screening vs. usual care opportunistic screening in a clinic (control) | 1 year | Screened: 49%; Control: 42% | [underlined: Incidence of new chlamydia infections in all females:]; Screened: 2.9% (13/443); Control: 6.6% (32/487); RR 0.45 (95% CI 0.24 to 0.84); p= 0.026; [underlined: Incidence of PID in all females:]; Screened: 2.1% (9/443); Control: 4.2% (20/487); RR 0.50 (95% CI 0.23 to 1.08); p= 0.045 | Fair
Scholes et al., 1996^†^,^78^ | Women age 18 to 34 years recruited from a health maintenance organization in the U.S. selected by risk criteria; (n=2,607) | Clinic screening vs. usual care (control) | 1 year | 24% of participants did not return final questionnaire | [underlined: Incidence of PID in all women:]; Screened: 8 per 10,000 women-years (9 cases); Control: 18 per 10,000 women-years (33 cases); RR 0.44 (95% CI 0.20 to 0.90) | Fair

* Only includes participants with followup who were independently tested outside of study protocol.

† Included in prior USPSTF evidence review

‡ Denominator is the number of females aged 16-33 years with at least one consultation during the intervention period

§ Denominator is the number of men aged 16-29 with at least one consultation during the intervention period

Abbreviations: CI = confidence interval; PID = pelvic inflammatory disease; RR = relative risk; vs. = versus; U.K. = United Kingdom; U.S. = United States

The three trials included in the prior USPSTF review reported results that favored screening for chlamydial infection versus no screening for reducing risk of PID, though only one trial reported a statistically significant difference. A good-quality RCT, the Prevention of Pelvic Infection (POPI), included 2,529 sexually active symptomatic (35%) or asymptomatic (65%) young women from universities and colleges in the United Kingdom (U.K., mean age 21 years; range: 16-27 years).^74^ Among all participants, screening was associated with reduced risk of PID, though the difference was not statistically significant (relative risk [RR] 0.65; 95% confidence interval [CI], 0.34 to 1.22). However, 79 percent (30/38) of PID cases occurred in women who had tested negative at baseline. As described in the prior USPSTF review, among the subgroup of participants who reported no symptoms during the 6 months before the study (i.e., pelvic pain, dyspareunia, abnormal vaginal bleeding or discharge), the reduction in risk was larger, but also not statistically significant (0.6% [5/787] vs. 1.6% [14/861], RR 0.39; 95% CI, 0.14 to 1.08) (Sarah Kerry, personal communication). A fair-quality RCT of 2,607 women with increased risk for chlamydia in Washington state reported a statistically significant reduction in PID in the screened versus usual care group after 1 year of followup (0.89% [9/1,009] vs. 2.07% [33/1,598], RR 0.44; 95% CI, 0.20 to 0.90).^78^ A fair-quality RCT of 1,761 female high school students in Denmark found one-time home-based screening to be associated with lower risk of chlamydia compared with usual care (opportunistic physician-based screening) after 1 year (2.9% [13/443] vs. 6.6% [32/487], RR 0.45; 95% CI, 0.24 to 0.84) and PID (2.1% [9/443] vs. 4.2% [20/487], RR 0.50; 95% CI, 0.23 to 1.08).^75^ Since few participants were screened in the usual care group, they were considered to be similar to an unscreened comparison group.

A new, good-quality cluster-randomized trial (the ACCEPt trial) of screening for chlamydia evaluated screening effectiveness in 180,355 young men and women aged 16 to 29 (mean age not reported) in 130 rural Australian primary care clinics.^67^ Participants were eligible for at least one chlamydia test per year, regardless of symptoms or contact history. Clusters were randomized to a multifaceted screening intervention tailored to the clinic (computer alert to test eligible patients, incentive payment for testing, patient recall and reminder system, education for general practitioners and nurses, patient information, partner notification, and feedback on testing performance) versus usual practice for chlamydial testing and management (mean follow-up 3.1 years). Demographics were reported for 63,338 clinic patients; approximately 49 percent (30,759/63,338) were women, 35 percent were 16 to 19 years old (22,212/63,338), 32 percent were 20 to 24 years old (20,319/63,338), and 33 percent were 25 to 29 years old (20,807/63,338).

Screening was associated with a statistically significant reduction in risk of a hospital diagnosed primary PID (RR 0.6; 95% CI, 0.4 to 1.0), but the absolute difference was small (0.24% [57/23,527] vs. 0.38% [88/23,219]). There was no difference in the risk of a repeat chlamydia infection within six weeks to six months of a positive test (odds ratio [OR] 3.1; 95% CI, 0.7 to 13.8), or for PID diagnosed in clinics (0.45% [293/65,519] vs. 0.39% [237/60,384]; RR 1.1; 95% CI, 0.7 to 1.8). In men, there was no difference between screening versus usual care in risk of epididymitis diagnosed in clinics (0.26% [106/41,168] vs. 0.27% [106/38,717]; RR 0.9; 95% CI, 0.6 to 1.4).

#### Gonorrhea

As in prior USPSTF reviews, no study evaluated the effectiveness of screening for gonorrhea versus no screening.

## Key Question 2 What Is the Accuracy of Risk Stratification Methods or Alternative Screening Strategies for Identifying Persons at Increased Risk for Chlamydial or Gonococcal Infections (Such as Younger Persons or Men Who Have Sex With Men)?

### Summary

- The 2014 USPSTF review did not evaluate the diagnostic accuracy of risk criteria for chlamydial or gonococcal infections.
- In asymptomatic patients, two studies of the “Vancouver” risk tool and one study of a 3-item risk score for identifying persons with chlamydial or gonococcal infections reported AUCs that ranged from 0.64 to 0.73.
- One study of women attending family planning or STI clinics (not necessarily asymptomatic) found age ≤22 years was associated with similar discrimination for chlamydial and gonococcal infections (AUC 0.69) compared with multi-item screening criteria (AUC 0.72 to 0.73).
- Two studies of women in other settings (IUD insertion, surgical abortion) found risk prediction tools for chlamydial and gonococcal infections associated with poor accuracy.
- One study conducted in a narrowly-defined, high risk patient population used a survey that strongly correlated increasing numbers of oral sex partners in the preceding 3 month period with rates of pharyngeal gonorrhea.
- No study compared screening intervals or alternative screening strategies, such as testing for concurrent infection with HIV.

### Evidence

The 2014 USPSTF review did not evaluate the accuracy of risk stratification methods or alternative screening strategies for chlamydial or gonococcal infections.^60^ For this report, seven studies evaluated strategies for identifying persons at increased risk for chlamydial or gonococcal infections using different criteria to select patients for testing (Table 3; Appendix B Tables 4 and 5).^62–64,66,68–70^ Enrollment ranged from 245 to 35,818 (total N = 93,137). Two studies enrolled only women,^69,70^ and five included both men and women.^62–64,66,68^ Participants were asymptomatic in 3 studies,^62–64^ symptom status was not reported in three studies,^66,68,69^ and one study included both asymptomatic (52%) and symptomatic (47%) populations.^70^ Three studies were conducted in Canada,^62–64^ three in the U.S.,^66,68,70^ and one in Europe.^69^ Settings included family planning clinics,^70^ STI or sexual health clinics,^62–64,68,70^ university or community clinics,^66^ and a pregnancy termination clinic.^69^ Six studies were cross-sectional^62–64,66,69,70^ and one was a case-control study.^68^ All studies were rated fair- quality (Appendix B Table 6). Methodological limitations included inadequate selection of patients and measurement of exposures or outcomes, including retrospective data collection; some studies reported between-group differences between intervention and control groups, rather than groups being similar at baseline.

Table 3 Studies Evaluating Strategies for Identifying Persons Who Are at Increased Risk for Chlamydial or Gonococcal Infections

Author, year | Strategy | Infection | Sex | Study design | Population, N | Results | Quality rating
Falasinnu et al., 2014^62^ | Risk estimation model | GC, CT | M, F | Cross-sectional | Asymptomatic men and women, attending clinic for STI testing; Canada (n=25,393) | Derivation population (n=10,437): AUC=0.75; 95% CI, 0.72 to 0.80; Validation population (n=14,956): AUC=0.64; 95% CI, 0.61 to 0.67 | Fair
Falasinnu et al., 2016^63^ | Risk estimation model | GC, CT | M, F | Cross-sectional | Asymptomatic men and women, attending clinic for STI testing; Canada (n=20,862) | Derivation population (n=10,437):AUC= 0.74 (95% CI 0.70 to 0.77); Validation population (n=10,425): AUC=0.69 (95% CI 0.67 to 0.71) | Fair
Falasinnu et al., 2016^64^ | Population guideline vs. guideline + number of risk factors vs. clinical risk score^a^ | STI | M, F | Cross-sectional | Asymptomatic men and women, attending clinic for STI testing; Canada (n=35,818) | Guideline (any vs. no risk factors): AUC 0.55 (95% CI 0.54 to 0.56); Guideline (numbers of risk factors): AUC 0.64 (95% CI 0.63 to 0.66); Risk score model: AUC 0.73 (95% CI 0.71 to 0.74) | Fair
Grentzer et al., 2015^66^ | Age vs. age + partner vs. risk-based screening^b^ | GC, CT | F | Cross-sectional | Women age 14 to 45 years attending clinic for IUD insertion; U.S. (n=5087) | Sensitivity; specificity; NPV; PPV; %; Age: 80.7; 48.1; 98.8; 4.5; Age + partner: 84.7; 44.8; 99.0; 4.5; Risk: 99.3; 7.6; 99.7; 3.2 | Fair
Javanbakht et al., 2018^68^ | Risk estimation | GC | M, F | Case-Control | Men and women age 15 to 29 years reporting giving oral sex to partner of opposite sex in past 90 days; U.S. (n=245) | Risk of pharyngeal gonorrhea:; Number of oral sex partners in 3 months: aOR 5.7; 95% CI 1.3 to 25.6 aOR 5.7; 95% CI 1.3 to 25.6; Presence of concurrent urogenital gonorrhea: aOR 6.2; 95% CI 2.6-14.3 | Fair
Lavoue et al., 2014^69^ | Model to predict infection^c^ | CT | F | Cross-sectional | Women with surgical abortion and CT test; France (n=652 derivation, n=326 validation) | Sensitivity, %; specificity, %; Cutoff 40: 100; 26.9; Cutoff 60: 83.3; 58.8 | Fair
Miller, et al., 2000^70^ | Compares 9 sets of screening criteria^d^ | CT | F | Cross-sectional | Women in family planning clinics; U.S. (n=4754) | Criteria; AUC (SD); sensitivity, %; specificity, %; CDC: NA, 85, 38; Seattle-1: 0.599 (0.017); 56; 54; Wisconsin: 0.604 (0.023); 50; 66; Ontario: 0.630 (0.017); 76; 41; California-1: 0.633 (0.016); 94; 20; Age ≤ 22: 0.687 (0.014); 77; 51; California-2: 0.701 (0.015); 97; 9; Seattle-3: 0.723 (0.015); 92; 31; Seattle-2: 0.726 (0.014); 84; 51 | Fair

Abbreviations: aOR = adjusted odds ratio; AUC = area under the receiver operating characteristic curve; CDC = Centers for Disease Control and Prevention; CI = confidence interval; CT = chlamydia; F = female; GC = gonorrhea; IUD = intrauterine device; M = male; NA = not applicable; NPV = negative predictive value; OR = odds ratio; PID = pelvic inflammatory disease; PPV = positive predictive value; RCT = randomized controlled trial; RR = relative risk; SD = standard deviation; STD = sexually transmitted disease; STI = sexually transmitted infection; U.K. = United Kingdom; U.S. = United States.

a Population guideline from the Public Health Agency of Canada (any vs. no risk factors including age <30, 2 or more sexual partners, injection drug use, sexual contact with injection drug user, sexual contact with commercial sex workers, previous STD); guideline (numbers of risk factors including age <30, 2 or more sexual partners, injection drug use, sexual contact with injection drug user, sexual contact with commercial sex workers, previous STD); clinical risk score model (age, race/ethnicity [white/nonwhite], number of sexual partners [0, 1-2, 3 or more], previous CT or GC diagnosis [yes/no], condom use [always, not always]; injection drug use [yes/no]).

b Age-based (≤25 years); age + partner-based (≤25 years + multiple partners); risk-based (≤25 years, multiple partners, history of STI, inconsistent condom use).

c Model includes: 0 or 1 child (43 points); not using contraception (34 points); gestational age of abortion >10 weeks (23 points). Low-risk of CT infection = 0-40 points; intermediate-risk = 40-60; high-risk = 60-100.

d Screening criteria listed in publication (Miller, 2000^69^).

Two cross-sectional studies conducted in Vancouver, British Columbia, evaluated the “Vancouver” risk estimation tool, an instrument for identifying asymptomatic women and heterosexual men at increased risk for chlamydial or gonococcal infection^62,63^ Factors in the model included age, sex, race, number of partners, and other known STI risk factors. In the original study evaluating this tool, discrimination in a validation cohort of 14,956 asymptomatic patients attending STI clinics in Vancouver was fair (AUC 0.64; 95% CI, 0.61 to 0.67). A risk score cutoff of ≥6 points identified 83 percent of cases in the validation cohort, while screening 68 percent of the population.^62^ A followup study^63^ in 10,425 asymptomatic women and heterosexual men in seven sexual health clinics throughout British Columbia (prevalence 5.3%) reported similar discrimination (AUC 0.69; 95% CI, 0.67 to 0.71). A cutoff of ≥8 points detected 86 percent of cases while screening 63 percent of the population and a cutoff of ≥6 identified 95 percent of infections while screening 78 percent of the population.^63^

A cross-sectional study of 35,818 asymptomatic men and women attending clinics for STI testing in Canada evaluated discrimination of a clinical risk score based on 3 criteria (age, indicators of risk, and injection drug use) and criteria derived from population based screening guidelines based on 6 criteria (age, number of sexual partners, injection drug use by patient or partner, transactional sex, prior infection).^64^ The clinical risk score was associated with higher discrimination (AUC 0.73; 95% CI, 0.71 to 0.74) than presence of any guideline risk factors (AUC 0.55; 95% CI, 0.54 to 0.56) or number of guideline risk factors (AUC 0.64; 95% CI, 0.63 to 0.66), though none of the criteria were associated with high discrimination.

A cross-sectional study of 6,672 women attending family planning and STI clinics in the United States compared nine sets of selective screening criteria for chlamydial infection.^70^ In the family planning clinics (n=4,471) 69 percent of women were asymptomatic, while nearly 80 percent of women in STI clinics (n=2201) reported genitourinary symptoms.^70^ Criteria were from the CDC and various states or provinces: Seattle (3 versions), California (2 versions), Wisconsin, and Ontario, in addition to age criteria (≤ 22 years) (see Appendix C). Points were assigned for age 24 or younger, Black, nulliparous, 2 or more sex partners in the past year, and vaginal douche in the past year; while the Seattle-2 version also included unmarried status, and cervical ectopy. Among the nine multi-item criteria, the highest AUC values were for two versions of state specific criteria (Seattle 2 AUC 0.726, standard deviation [SD] 0.014, sensitivity 83 to 84%, specificity 35 to 51%; Seattle-3 AUC 0.723, SD 0.015, sensitivity 92%, specificity 19 to 31%). Age alone (≤ 22 years) performed nearly as well as multiple item criteria, with similar sensitivity (74-77%) and specificity (51-56%), and AUC 0.687 (SD 0.014). Using an age cutoff of 22 or younger, nearly 80 percent of cases were identified while testing 50 percent of the population.

Two studies evaluated the accuracy of screening criteria in other settings. A cross-sectional study of 5,087 women age 14 to 45 years attending clinic for IUD insertion compared three screening criteria for chlamydial and gonococcal infections based on: age alone; age and having multiple partners; or age, having multiple partners, and other risk markers (history of STI, inconsistent condom use).^66^ The risk-based criteria had the highest sensitivity, but very low specificity (sensitivity 99%, specificity 7.6%); age (sensitivity 80.7%; specificity 48.1%) and age plus partner (sensitivity 84.7%; specificity 44.8%) performed similarly. A fair- quality, cross-sectional study evaluated a model using data from women who underwent surgical abortion in France (326 women in the validation set).^69^ The model assigned points for having 1 or no children (43 points); not using contraception (34 points); and gestational age of abortion more than 10 weeks (23 points). At a cutoff of 40 points, sensitivity was 100 percent and specificity 26.9 percent; and at a cutoff 60 points, sensitivity was 83.3 percent and specificity 58.8 percent.

A fair- quality case-control study evaluated the proportion of gonorrhea cases missed by testing only for urogenital gonorrhea. It was conducted among 12 STI clinics in Los Angeles County in 245 consecutive men or women aged 15 to 29 years presenting for chlamydia or gonorrhea testing with a history of oral intercourse in last the 3 months with a partner of the opposite sex.^68^ The study population was largely Hispanic/Latino or Black and symptom status was not reported. Among those with gonorrhea, 28 percent had pharyngeal gonorrhea only. Compared to those without pharyngeal gonorrhea, a higher proportion of those with pharyngeal gonorrhea reported being men who had sex with women and men (25% versus 3%), to have swallowed ejaculate or vaginal fluid in last 3 months (28.6% versus 14.9%), or to have a recently incarcerated sex partner (35.3% versus 19.4%). In a multivariate model, there was a strong association between higher number of oral sex partners in the last 3 months (adjusted odds ratio [aOR] 5.7; 95% CI, 1.3 to 25.6) and the presence of concurrent urogenital gonorrhea (aOR 6.2; 95% CI, 2.6-14.3) and risk of pharyngeal gonorrhea, after adjusting for age, sex, and number of sex partners.^68^

## Key Question 3 What Is the Diagnostic Accuracy of Anatomic Site-Specific Testing and Collection Methods for Identifying Persons With Chlamydial or Gonococcal Infections?

### Summary

- The 2014 USPSTF review included four studies of site-specific testing for chlamydia in females that reported sensitivities that ranged from 86 to 96 percent for endocervical testing, 89 to 100 percent for vaginal testing, and 72 to 98 percent for urine testing. Specificity was high across anatomic sites, ranging from 98 to 100 percent.
- Five studies of diagnostic accuracy of site- specific testing for chlamydial infection, including three studies in the prior USPSTF review, reported sensitivities that ranged from 89 to 100 percent for endocervical testing and 90 to 100 percent for vaginal testing, excluding one outlier study reporting lower sensitivities. Specificities were 99 to 100 percent for endocervical testing and 95 to 100 percent for vaginal testing, and 96 to 100 percent for urine testing.
- The sensitivity of meatal (100%), urethral (99%) and rectal (92%) testing for chlamydia in males was high, but evidence was limited to one study each. Specificities were not reported and data were not provided to calculate specificity for all sites.
- The sensitivity of pharyngeal testing for chlamydia was 69.2% in one study of men who have sex with men; specificity was not reported.
- Three studies of diagnostic accuracy of site- specific testing for gonococcal infections in females reported sensitivities of 98 percent to 100 percent for vaginal samples, 96 percent and 98 percent for endocervical samples, and 89 percent and 100 percent for urine samples. Specificity was high at all sites (95% to 100%).
- Three studies of diagnostic accuracy of gonococcal infections in males reported sensitivities of 93 to 100 percent for urine testing; sensitivity ranged from 89 to 100 percent at other sites.
- The sensitivity of pharyngeal testing for gonorrhea was 89 percent in one study of men who have sex with men; specificity was not reported.
- Three studies of self- and clinician-collected vaginal samples for chlamydia diagnosis and one study of self- and clinician-collected vaginal samples for gonorrhea diagnosis found both collection methods to be highly sensitive (90 to 100%, excluding one outlier study). There were no studies comparing self- versus clinician-collected samples in males.

### Evidence

The prior 2014 USPSTF review^58^ included 10 fair-quality studies on the accuracy of NAATs compared with culture or expanded reference standards in asymptomatic individuals in high prevalence settings. Six studies included in the prior review were excluded from this review, because they compared performance characteristics between different types of assays (assay versus assay). Four studies in the prior review compared the accuracy of testing at different anatomic sites and were carried forward for this review (Table 4; Appendix B Tables 7, 8 and 9).^76,77,79,80^ In these studies, anatomic site-specific testing for chlamydial infection in females indicated sensitivity ranging from 89 to 96 percent for endocervical testing,^76,77^ 89 to 100 percent for vaginal testing,^76,77^ and 72 to 98 percent for urine testing.^76^ One outlier study^79^ reported lower sensitivities than the other studies (51.9%, 55.6%, 51.9%, and 44.4% for endocervical, clinician-collected vaginal, self-collected vaginal, and urine testing, respectively). Specificity ranged from 98 to 100 percent across all sites.^76,77,79^ For gonorrhea, the sensitivity of testing in females was 90 percent (specificity 100%) for endocervical testing and 98 percent for vaginal testing (specificity 100%)^80^ The prior review also found self- and clinician-collected vaginal samples for chlamydia testing equally sensitive (ranging from 98% to 100%) and specific (>99%) in two studies,^76,77^ although one other study found self-collected vaginal samples had lower sensitivity (55%).^79^ Self-collected vaginal specimens were highly sensitive and specific for gonorrhea (98% and 100%).^80^ The 2014 report did not identify studies on the diagnostic accuracy of site-specific testing or collection methods in males.

Table 4 Characteristics of Diagnostic Accuracy Studies

Study, year | Assessment | Country, Setting | Eligibility Criteria | Population | Sample size, Proportion with condition | Study Quality
Berry et al., 2017^61^ | Site-specific testing | U.K. Sexual health clinic | Men attending sexual health clinic for sexual health screening | Age (mean): NR 100% male sex; Race: NR; Symptomatic: NR | 1517; CT: 10.5%; NG: 4.2% | Fair
Fang et al., 2008^65^ | Site-specific testing | U.S. Adolescent clinic | Sexually active adolescent women, age 12 to 18 years | Age (median): 16 years; 100% female sex; Race: 96% black; Symptomatic: NR | 342^†^; CT: 26.6%; NG: 11.7% | Fair
Nye et al., 2019^71^ | Site-specific testing; Collection method | U.S. Family planning, obstetric/gynecology, or STI clinic | Eligible for screening per clinical site’s standard practice, age ≥14 years | Age (mean): 29 years; 88% female sex; Race: 45% black, 46% white; Symptomatic: 38% | 3749^‡^; CT: 6.8% (6.2% women, 11.3% men); NG: 1.5% (1.6% women, 1.5% male | Fair
Schachter et al., 2003^76,*^ | Site-specific testing; Collection method | U.S. and Canada Family planning, obstetric/gynecology, or STI clinic | Women attending family planning, obstetrics/gynecology, or STI clinics for routine care or birth control, Age 16 to 25 years | Age (mean): NR, range 16 to 25 years; 100% female sex; Race NR; Symptomatic: NR | 2,517; CT: 9.6% | Fair
Schoeman et al., 2012^77,*^ | Site-specific testing | U.K. Sexual health clinic | Women, Age ≥16 years | Age (mean): 25 years; 100% female sex; Race: 80% white, 9% black, 7% mixed, 4% other; Symptomatic: 34% | 3974; CT: 10.3% | Fair
Shrier et al., 2004^79,*^ | Site-specific testing; Collection method | U.S.; University medical clinic for adolescents and young adults | Sexually experienced women attending clinic for routine gynecologic care, age 16 to 25 years | Age (mean): 19 years; 100% female sex; Race: NR; Symptomatic: 0% | 139; CT: 21.6% | Fair
Skidmore et al., 2008^72^ | Site-specific testing | U.K. Genitourinary medicine clinic | Women attending genitourinary clinic, age 18 to 24 years | Age (mean): NR; range 18 to 24 years; 100% female sex; Race: NR; Symptomatic: NR | 267; CT: 9.3% | Fair
Stewart et al., 2012^80,*^ | Site-specific testing | U.K. Sexual health clinic | Women attending sexual health clinic, age ≥16 years | Age (mean): 25 years; 100% female sex; Race: 80% white, 9% black, 7% mixed, 4% other; Symptomatic: 28% | 3973 (2,234^‡^); NG: 2.5% (1.8%^‡^) | Fair
Sultan et al., 2016^73^ | Site-specific testing | U.K. Sexual health/HIV clinic | Men who have sex with men, age ≥18 years | Age (median): 37 years; 100% male sex; Race: NR; Symptomatic: 28% | 1064; CT: 15%; NG: 27% | Fair

Abbreviations: CT = Chlamydia trachomatis; NG = Neisseria gonorrhoeae; NR = not reported

* Study included in prior USPSTF review

† Participants were tested multiple times over a 5-year period. The total number of chlamydia tests administered was 1,080; the total number of gonorrhea tests was 1,079.

‡ Asymptomatic population only

The current review compared the accuracy of screening tests obtained from different anatomic sites or from urine samples, or obtained using different collection methods (self-collected versus clinician- collected). Nine studies^61,65,71–73,76,77,79,80^ evaluated the diagnostic accuracy of anatomic site-specific testing and six studies^65,71,76,77,79,80^ compared collection methods for identifying chlamydial or gonococcal infections (Table 4; Appendix B Tables 7, 8 and 9).^61,65,71–73,76,77,79,80^

All of the studies were conducted in the U.S.,^65,71,76,79^ U.K.,^61,72,73,77,80^ or Canada.^76^ Sample sizes ranged from 133 to 3,974 (Total N = 16,204). Six studies enrolled only females,^65,72,76,77,79,80^ two studies enrolled only males,^61,73^ (including one study that enrolled MSM),^73^ and one study^71^ enrolled both male and female participants. One study was conducted exclusively in an adolescent population (mean age 16 years).^65^ Five studies enrolled a mix of adolescents and adults (mean age 19 to 37 years).^71,73,77,79,80^ Two studies did not report mean age but reported age ranges between 16 and 25 years,^72,76^ and age was not reported in one study.^61^ In four studies that reported race, the proportion of Black participants ranged from 9 to 96 percent^65,71,77,80^ Race was not reported in the other five studies. One study^79^ reported that participants were asymptomatic for chlamydia or gonorrhea at baseline, and four did not report symptom status.^61,65,72,76^ Three studies included a mix of asymptomatic and symptomatic participants, but stratified results according to presence or absence of symptoms.^71,77,80^ In the remaining study of MSM attending a sexual health/HIV clinic, the proportion of participants with symptoms at baseline was 28 percent.^73^ Prevalence of infection ranged from 1.5 to 26.6 percent for chlamydial infection and 1.5 to 11.7 percent for gonococcal infection. All studies were rated fair-quality (Appendix B Table 10). Methodological limitations included unclear methods of enrolling patients for study inclusion and unclear description of whether index test results were interpreted independently of the reference standard.

#### Accuracy of Anatomic Site Tests

##### Chlamydia

Female population. Three new studies^65,71,72^ and three studies^76,77,79^ from the prior review evaluated the accuracy of anatomic site-specific testing for chlamydia in females (Table 5; Figure 2).^65,71,72,76,77,79^ Prevalence of chlamydia ranged from 6 to 27 percent (Table 4). Accuracy of site-specific testing was high across all anatomic sites (sensitivity range 84 to 100%; specificity range 95 to 100%), other than one outlier study^79^ that reported consistently lower sensitivity among all sites tested (range 44% to 56%). While this study was conducted in a high prevalence population of university students age 16 to 25 years (chlamydia prevalence 21.6 %), reasons for lower sensitivity are unclear but might be related to the use of a single test to identify chlamydial infection at a time when NAAT testing was not routinely employed.

Table 5 Diagnostic Accuracy of Anatomic Site-Specific Testing for Chlamydial Infection in Females

Author, year; Sample size | Test | Reference standard | Endocervix, clinician-collected; n=number tested | Vagina, clinician-collected; n=number tested | Vagina, self-collected; n=number tested | Urethra; n=number tested | Urine; n=number tested
Schachter et al., 2003^76^; n=2,517; (n=609 tested using Amplicor PCR) | Amplicor CT/NG PCR | LCx Probe System, Amplicor PCR or Amplified CT Assay, clinician-collected cervical swab or urine sample | n=600; Sensitivity: 90.7; (95% CI 81.7-96.2); Specificity: 99.4; (95% CI 98.3-99.9) | n=579; Sensitivity: 93.3; (95% CI 85.1-97.8); Specificity: 98.8; (95% CI 98.4-99.7) | n=568; Sensitivity: 90.1; (95% CI 81.7-96.2); Specificity: 99.0; (95% CI 97.7-99.7) | n=602; Sensitivity: 97.3; (95% CI 90.7-99.8); Specificity: 98.2; (95% CI 96.8-99.2) | n=577; Sensitivity: 84.0; (95% CI 73.7-91.5); Specificity: 99.0; (95% CI 97.7-99.7)
Schachter et al., 2003^76^; n=2,517; (n=1,408 tested using Amplified CT) | Amplified CT Assay | LCx Probe System, Amplicor PCR or Amplified CT Assay, clinician-collected cervical swab or urine sample | n=1,408; Sensitivity: 89.1 (95% CI 82.0-95.0); Specificity: 99.3; (95% CI 98.7-99.7) | n=1,408; Sensitivity: 89.9; (95% CI 83.1-94.7); Specificity: 99.4; (95%CI 98.8-99.7) | n=1,408; Sensitivity: 93.3; (95% CI 87.2-97.1); Specificity: 99.6; (95% CI 99.1-99.9) | n=1,407; Sensitivity: 88.1; (95% CI 81.1-93.4); Specificity: 99.3; (95% CI 98.7-99.7) | n=1,387; Sensitivity: 72.0 (95% CI 63.3-80.1); Specificity: 99.5; (95% CI 99.0-99.8)
Schoeman et al., 2012^77^; n=2,233^*^ | Aptima Combo-2 | Aptima CT, clinician-collected endocervical swab | n=2,233; Sensitivity: 89.0; (95% CI 84.0-93.0); Specificity: 100.0; (95% CI 99.8-100) | - | n=2,233; Sensitivity: 97.0; (95% CI 94.0-99.0); Specificity: 99.9; (95% CI 99.7-100) | - | -
Fang et al., 2008^65^; n=342 (1,080 tests) | BD ProbeTec ET | BD ProbeTec ET, clinician-collected endocervical swab and urine sample | n=1,076; Sensitivity: 90.1; (95% CI 82.9-95.9); Specificity: 99.2; (95% CI 98.9-99.9) | - | n=1,034; Sensitivity: 98.2; (95% CI 93.6-99.8); Specificity: 99.5; (95% CI 98.7-99.8) | - | n=1,042; Sensitivity: 89.2; (95% CI 81.8-94.3); Specificity: 99.5; (95% CI 98.8-99.8)
Shrier et al., 2004^79^; n=139 | Cobas Amplicor PCR | Cobas Amplicor and Abbot LCx assay, clinician-collected urethral, vaginal and endocervical swab | n=126; Sensitivity: 51.9; (95% CI 32.0-71.3); Specificity: 100.0; (95% CI 96.5-100) | n=126; Sensitivity: 55.6; (95% CI 36.4-73.1); Specificity: 100.0; (95% CI 96.5-100) | n=126; Sensitivity: 51.9; (95% CI 32.0-71.3); Specificity: 99.0; (95% CI 95.0-100) | - | n=126; Sensitivity: 44.4; (95% CI 26.9-63.6); Specificity: 100.0; (95% CI 96.5-100)
Nye et al., 2019^71^; n=3,289^*^ | Cobas CT/NG 2.0 | Aptima Combo 2 Assay and BD ProbeTec CTQ/GCQ, clinician-collected endocervical (women) or urethral (men) swab, and/or urine sample | n=3,174; Sensitivity: 93.0; (95% CI 88.5-95.5); Specificity: 99.8; (95% CI 99.6-99.9) | n=2,241; Sensitivity: 97.9; (95% CI 94.0-99.3); Specificity: 99.7; (95% CI 99.4-99.9) | n=996; Sensitivity: 96.0; (95% CI 86.5-98.9); Specificity: 99.4; (95% CI 98.6-99.7) | - | n=3,190; Sensitivity: 93.1; (95% CI 88.7-95.8); Specificity: 99.7; (95% CI 99.4-99.8)
Skidmore et al., 2008^72^ | Cobas Taqman 48 CT | Cobas Taqman 48 CT, clinician-collected endocervical swab | - | - | n=255; Sensitivity: 100.0; (95% CI 85.2-100); Specificity: 100.0; (95% CI 98.4-100) | - | -
Schachter et al., 2003^76^; n=2,517; (n=500 tested using LCx Probe System) | LCx Probe System LCR | LCx Probe System, Amplicor PCR or Amplified CT Assay, clinician-collected cervical swab or urine sample | n=498; Sensitivity: 95.8; (95% CI 85.8-99.5); Specificity: 99.8; (95% CI 98.8-100) | n=497; Sensitivity: 100.0; (95% CI 92.6-100); Specificity: 99.8; (95% CI 98.8-100) | n=500; Sensitivity: 97.9; (95% CI 88.9-99.9); Specificity: 99.5; (95% CI 98.4-99.9) | n=500; Sensitivity: 91.7; (95% CI 80.0-97.7); Specificity: 99.8; (95% CI 98.8-100) | n=499; Sensitivity: 97.9; (95% CI 88.9-99.9); Specificity: 98.1; (95% CI 96.3-99.1)

* Asymptomatic population

Figure 2 Diagnostic Accuracy of Site-Specific Testing for Female Chlamydial Infection

Legend

- ■ Endocervix
- ◆ Vagina, self-collected
- ● Vagina, clinician-collected
- ✕ Urethra
- + Urine

Figure 2 is a scatter plot of the diagnostic accuracy of site-specific testing for female chlamydial infection. On the x-axis is sensitivity and on the y-axis is specificity. There is a legend that describes the symbols used to represent data points. Squares represent diagnostic accuracy for endocervical tests. Diamonds represent diagnostic accuracy of self-collected vaginal tests. Circles represent diagnostic accuracy of clinician-collected vaginal tests. X represents diagnostic accuracy of urethral tests. Plus signs represent diagnostic accuracy of urine tests. For endocervical tests, sensitivity in six studies ranged from 89 to 95.8 percent, and one study 51.9 percent; specificity in seven studies ranged from 99.2 to 100 percent. For self-collected vaginal tests, sensitivity in seven studies ranged from 90.1 to 100 percent, and one study 51.9 percent; specificity in eight studies ranged from 99.0 to 100 percent. For clinician-collected vaginal tests, sensitivity in four studies ranged from 89.9 to 100 percent, and one study 55.6 percent; specificity in five studies ranged from 98.8 to 100 percent. For urethral tests in three studies, sensitivity ranged from 88.1 to 97.3 and specificity ranged from 98.2 to 99.8. For urine tests in six studies, sensitivity ranged from 72 to 97.9 percent, and one study 44.4 percent; specificity ranged from 98.1 to 100 percent. Data represented in this figure is also reported in in Table 5.

The sensitivity and specificity of endocervical and vaginal testing was consistent in five of six studies.^65,71,72,76,77^ For endocervical testing, sensitivity ranged from 89 to 100 and specificity ranged from 99 to 100 percent. Vaginal testing from both patient and clinician- collected samples showed similar sensitivities, ranging from 90 to 100 percent; specificity was also high (range 95% to 100%). The sixth study reported lower but similar sensitivity at both anatomic sites (endocervical 52% and vaginal 56%) but specificity remained high (100% for both sites).^79^ Urethral testing was also highly sensitive, based on one study that used three different NAATs, ranging from 88 to 97 percent (specificity range 98-100 percent).^76^ The sensitivity of urine testing was more variable than anatomic site testing in five studies (range 44 to 100%; median 85%), with specificities ranging from 96 to 100 percent.^65,71,72,76,79^

Male population. Three studies reported on the diagnostic accuracy of anatomic site-specific testing for chlamydial infection in males (Table 6; Figure 3).^61,71,73^ Urine testing was highly sensitive in all three studies (89 to 100%). Meatal (92%),^61^ urethral (99%),^73^ and rectal (92%)^73^ testing were also highly sensitive, while pharyngeal testing was associated with lower sensitivity (69%),^73^ all based on one study each.

Table 6 Diagnostic Accuracy of Anatomic Site-Specific Testing for Chlamydial Infection in Males

Author, year; Sample size | Test | Reference standard | Meatal, self-collected; n=number tested | Urine; n=number tested | Urethra; n=number tested | Rectum; n=number tested | Pharynx; n=number tested
Sultan et al., 2016^73^; n=1,064 | Aptima Combo-2 | Standard of care testing at each anatomical site | - | n=NR; Sensitivity: 89.0-95.0, depending on volume of urine; Specificity: not calculable | n=NR; Sensitivity: 98.6; (95% CI 92.6-100); Specificity: not calculable | n=NR; Sensitivity: 92.1; (95% CI 85-96.5); Specificity: not calculable | n=NR; Sensitivity: 69.2; (95% CI 38.6-90.9); Specificity: not calculable
Berry et al., 2017^61^; n=1,517 | BD ProbeTec ET | Abbott Real-Time CT/NG, urine sample | n=1,517; Sensitivity: 92.0; (95% CI 86.1-95.9); Specificity: 99.7; (95% CI 99.2-99.9) | n=1,517; Sensitivity: 100.0; (95% CI 97.3-100); Specificity: 99.7; (95% CI99.3-99.9) | - | - | -
Nye et al., 2019^71^; n=460^*^ | Cobas CT/NG 2.0 | Aptima Combo 2 Assay and BD ProbeTec CTQ/GCQ, clinician-collected urethral swab, and/or urine sample | - | n=460; Sensitivity: 98.1; (95% CI 89.9-99.7); Specificity: 99.3; (95% CI 97.9-99.7) | - | - | -

* Asymptomatic population

Figure 3 Diagnostic Accuracy of Site-Specific Testing for Male Chlamydial Infection^*^ * Results from one study^79^ are not included in Figure 3 as the study did not report specificity or include data to calculate specificity

Legend

- ■ Meatal
- + Urine

Figure 3 is a scatter plot of diagnostic accuracy of site-specific testing for male chlamydial infection. On the x-axis is sensitivity and on the y-axis is specificity. There is a legend that describes the symbols used to represent data points. Squares represent diagnostic accuracy of meatal tests and plus signs represent urine tests. Sensitivity in one study of self-collected meatal samples was 92.0 percent and specificity was 99.7 percent. Sensitivity in three studies of urine samples ranged from 98.1 to 100 percent and specificity ranged 99.3 to 99.7 percent. Data represented in this figure is also reported in in Table 6.

##### Gonorrhea

Female population. Three studies reported the sensitivity and specificity of site-specific testing for gonorrhea in females (Table 7; Figure 4).^65,71,80^ Prevalence of gonorrhea infection was 2.5^80^ and 2.6^71^ percent in two of the studies and 12 percent in the other.^65^ Reference standards were either clinician-collected samples or urine testing. Across sites, sensitivity and specificity ranged from 90 to 100 percent and 97 to 100 percent, respectively. Vaginal samples (both self- and clinician-collected) were associated with a sensitivity of 98 percent in one trial and 100 percent in three trials (specificity range 99 to 100%). In comparison, endocervical samples (sensitivity 90% and 98%) and urine samples (91% and 100%) were slightly less sensitive. Specificity was also high, ranging from 97 to 100 percent.

Table 7 Diagnostic Accuracy of Anatomic Site-Specific Testing for Gonococcal Infection in Females

Author, year; Sample size | Test | Reference standard | Endocervix; n=number tested | Vagina, clinician-collected; n=number tested | Vagina, self-collected; n=number tested | Urine; n=number tested
Stewart et al., 2012^80^; n=2,234^*^ | Aptima Combo-2 | Aptima Combo-2, clinician-collected urethral and endocervical swab | n=2,234; Sensitivity: 90.0; (95% CI 77.0-96.0); Specificity: 100.0; (95% CI 99.8-100) | - | n=2,234; Sensitivity: 98.0; (95% CI 87.0-100); Specificity: 100.0; (95% CI 99.8-100) | -
Fang et al., 2008^65^; n=342 (1,079 tests) | BD ProbeTec ET | BD ProbeTec ET, clinician-collected endocervical swab and urine sample | n=1,076; Sensitivity: 95.5; (95% CI 84.5-99.4); Specificity: 100.0; (95% CI 99.6-100) | - | n=1,030; Sensitivity: 100.0; (95% CI 92.0-100); Specificity: 99.4; (95% CI 98.7-99.8) | n=1,040; Sensitivity: 90.7; (95% CI 77.9-97.4); Specificity: 96.9; (95% CI 99.4-100)
Nye et al., 2019^71^; n=3,289^*^ | Cobas CT/NG 2.0 | Aptima Combo 2 Assay and BD ProbeTec CTQ/GCQ, clinician-collected endocervical (women) and/or urine sample | n=3,174; Sensitivity: 97.9; (95% CI 88.9-99.6); Specificity: 99.9; (95% CI 99.7-100) | n=2,240; Sensitivity: 100.0; (95% CI 90.6-100); Specificity: 99.7; (99.4-99.9) | n=996; Sensitivity: 100.0; (95% CI 70.1-100); Specificity: 100.0; (95% CI 99.6-100) | n=3,190; Sensitivity: 100; (95% CI 92.6-100); Specificity: 99.6; (95% CI 99.3-99.8)

* Asymptomatic population

Figure 4 Diagnostic Accuracy of Site-Specific Testing for Female Gonococcal Infection

Legend

- ■ Endocervix
- ◆ Vagina, self-collected
- ● Vagina, clinician-collected
- + Urine

Figure 4 is a scatter plot of diagnostic accuracy of site-specific testing for female gonococcal infection. On the x-axis is sensitivity and on the y-axis is specificity. There is a legend that describes the symbols used to represent data points. Squares represent diagnostic accuracy for endocervical tests. Diamonds represent diagnostic accuracy of self-collected vaginal tests. Circles represent diagnostic accuracy of clinician-collected vaginal tests. Plus signs represent diagnostic accuracy of urine tests. For endocervical tests in three studies, sensitivity ranged from 90 to 97.9 percent and specificity ranged from 99.9 to 100 percent. For self-collected vaginal tests, sensitivity ranged from 98 to 100 percent and specificity ranged from 99.4 to 100 percent. For clinician-collected vaginal tests, sensitivity in one study was 100 percent and specificity was 99.7 percent. For urine tests, sensitivity in two studies ranged from 90.7 to 100 percent and specificity ranged from 96.9 to 99.6 percent. Data represented in this figure is also reported in in Table 7.

Male population. Three studies compared site-specific testing for gonorrhea in males (Table 8; Figure 5).^61,71,73^ Gonorrhea infection prevalence was low in two of the studies (1.5 and 4.2%)^61,71^ and was high in the third study (27%).^73^ Urine testing was evaluated in two studies, with sensitivities of 93 percent and 100 percent; corresponding specificities were high (99.8 and 99.3%).^61,73^ The diagnostic accuracy of other sites, based on one study each, was 89 percent sensitivity for pharyngeal testing,^73^ 93 percent for rectal testing,^73^ 98 percent for urethral testing^73^ and 100 percent for meatal testing.^61^

Table 8 Diagnostic Accuracy of Anatomic Site-Specific Testing for Gonococcal Infection in Males

Author, year; Sample size | Test | Reference standard | Meatal, self-collected; n=number tested | Urine; n=number tested | Urethra; n=number tested | Rectum | Pharynx
Sultan et al., 2016^73^; n=1,064 | Aptima Combo-2 | Standard of care testing at each anatomical site | - | n=NR; Sensitivity: 91.0-93.0, depending on volume of urine; (95% CI NR); Specificity: not calculable | n=NR; Sensitivity: 97.9; (95% CI 93.9-99.6); Specificity: not calculable | n=NR; Sensitivity: 93.4; (95% CI 88.5-96.7); Specificity: not calculable | n=NR; Sensitivity: 89.1; (95% CI 83.1-93.5); Specificity: not calculable
Berry et al., 2017^61^; n=1,517 | BD ProbeTec ET | Abbott Real-Time CT/NG, urine sample | n=1517; Sensitivity: 100.0; (95% CI 91.6-100); Specificity: 99.7; (95% CI 99.2-99.9) | n=1517; Sensitivity: 92.9; (95% CI 80.5-98.5); Specificity: 99.8; (95% CI 99.4-99.7) | - | - | -
Nye et al., 2019^71^; n=460 | Cobas CT/NG 2.0 | Aptima Combo 2 Assay and BD ProbeTec CTQ/GCQ, clinician-collected urethral swab, and/or urine sample | - | n=460; Sensitivity: 100.0; (95% CI 64.6-100); Specificity: 99.3; (95% CI 98.1-99.8) | - | - | -

* Asymptomatic population

Figure 5 Diagnostic Accuracy of Site-Specific Testing for Male Gonoccocal Infection^*^ * Results from one study^79^ are not included in Figure 5 as the study did not report specificity or include data to calculate specificity

Legend

- ■ Meatal
- + Urine

Figure 5 is a scatter plot of diagnostic accuracy of site-specific testing for male gonococcal infection. On the x-axis is sensitivity and on the y-axis is specificity. There is a legend that describes the symbols used to represent data points. Squares represent diagnostic accuracy of meatal tests and plus signs represent urine tests. Sensitivity in one study of self-collected meatal samples was 100 percent and specificity was 99.7 percent. Sensitivity in three studies of urine samples ranged from 92.9 to 100 percent and specificity ranged from 99.3 to 99.8 percent. Data represented in this figure is also reported in in Table 8.

#### Accuracy of Clinician and Self-Collected Tests

##### Chlamydia

Female population. Two new studies^62,65^ and two studies^71,76,79^ from the prior review compared the accuracy of clinician- and self-collected vaginal samples for diagnosis of chlamydial infection in females (Table 5; Figure 2), including one study that utilized three different NAATs.^76^ Sensitivity was similarly high for both collection methods. Clinician-collected sample sensitivity was 90 to 100 percent in two studies,^71,76^ and 56 percent in the other study.^79^ Self-collected samples were also highly sensitive for chlamydia diagnosis, ranging from 90 to 98 percent in two studies^71,76^ and was 52 percent in the remaining study.^79^ The outlier study reporting lower sensitivities, also included in the 2014 USPSTF report, only reported results from study participants with complete sets of results from nine different testing strategies, and required two positive NAATs from two separate specimens as a reference standard. This method presumably reduced the number of false positive tests, although the overall prevalence of chlamydia infection was high (22%).^79^ There were no studies comparing clinician- and self-collected testing at other anatomic sites.

Male population. No studies meeting inclusion criteria reported on the accuracy of clinician- versus self-collected testing for chlamydia in males.

##### Gonorrhea

Female population. One study compared clinician- and self-collected vaginal samples for diagnosis of gonorrhea infection (Table 7).^71^ In this study, the accuracy of self-collected samples was nearly identical to those collected by clinicians; sensitivities were 100 percent for both sites, and specificities were 100 and 99.7 percent, respectively. There was no evidence comparing clinician- and self-collected testing for other anatomic sites.

Male population. There were no studies meeting inclusion criteria on the accuracy of clinician- versus self-collected testing for gonorrhea in males.

## Key Question 4 What Are the Harms of Screening for Chlamydial or Gonococcal Infections (Such as Labeling, Anxiety, False-Positive/Alarm Results, False-Negative Results/Reassurance, or Changes in Risk Behaviors or Risk Perception)?

### Summary

- The 2014 USPSTF review included four diagnostic accuracy studies of site-specific testing or collection methods that reported false-positive rates for gonorrhea and chlamydia of 3 percent or lower and false-negative rates ranging from 0 to 9 percent for gonorrhea and 0 to 14 percent for chlamydia across all NAATs and specimen types. False alarm rates (1 – positive predictive value) ranged from 0 to 16 percent and false reassurance rates (1 – negative predictive value) ranged from 0 to 2 percent in three studies, with one outlier study reported higher false reassurance rates (11 to 13%).
- False positive rates for chlamydia ranged from 0 to 2 percent in six studies (2 new studies) across all sites. False negative rates ranged from 0 to 28 percent in five studies; a sixth study reported higher false negative rates (44% to 56%).
- False positive rates for self-collected and clinician-collected tests ranged from 0 to 1.2 percent for chlamydia based on 3 studies in females (1 new study), and was 0 percent (for self-collected samples) and 0.3 percent (for clinician-collected samples) for gonorrhea in females based on one study. False positive rates ranged from 0 to 12 percent for chlamydia and gonorrhea self- and clinician-collected tests, excluding one outlier study.
- Evidence on false positive and false negative rates in males, according to anatomic site, was limited to two new studies for chlamydia and gonorrhea. False positive rates were consistently low (<1%), while false negative rates ranged from (0 to 8%).
- No studies reported on harms of collection methods for chlamydia or gonorrhea in males.
- No studies evaluated psychosocial harms, such as anxiety, related to screening or effects of screening on risk behaviors or risk perception.

### Evidence

The 2014 USPSTF review included four diagnostic accuracy studies of site-specific testing or collection methods that reported false-positive rates (1 – specificity) for gonorrhea and chlamydia as 3 percent or lower and false-negative rates (1 – sensitivity) that ranged from 0 to 9 percent for gonorrhea and 0 to 14 percent for chlamydia across all NAATs and specimen types. In these studies, false alarm rates (1 – positive predictive value) for chlamydia and gonorrhea ranged from 0 to 16 percent,^76,77,79,80^ and false reassurance rates (1 – negative predictive value) ranged from 0 to 2 percent in three studies; one outlier study (see Key Question 3) reported lower sensitivity across anatomic sites reported higher false reassurance rates (11 to 13%).^79^ The false alarm rate refers to the proportion of persons with a positive test who do not have an infection and the false reassurance rate refers to the proportion of persons with a negative tests who do have an infection.

Of the nine diagnostic accuracy studies included in Key Question 3 (including four studies included in the prior review), eight reported rates of false positive and false negative rates (and corresponding false alarm and false reassurance rates) for anatomic site- specific testing and six studies reported these rates for collection methods (Tables 9, 10, 11, and 12).^61,65,71,72,76,77,79,80^ Harms of chlamydia testing were reported in six studies of females^65,71,72,76,77,79^ and two studies of males;^61,71^ harms of gonorrhea testing were reported in three studies of females^65,71,80^ and two studies of males.^61,71^ In these studies, the prevalence of chlamydial infection ranged from 8 to 27 percent in females and 11 percent in males. The prevalence of gonococcal infection was 2 to 12 percent in females and 2 to 4 percent in males. As in prior USPSTF reviews, no study evaluated psychosocial harms (e.g., anxiety) related to screening and no study evaluated effects of screening on changes in risk behaviors or risk perceptions.

Table 9 False Positive, False Alarm, False Negative, and False Reassurance Rates of Testing for Chlamydial Infection in Females

Anatomic site | Number of studies | Prevalence | False positive rate range; (1-specificity) | False alarm rate range; (1-PPV) | False negative rate range; (1-sensitivity) | False reassurance rate range; (1-NPV)
Endocervix | 6 studies^65,71,72,76,77,79^ | 6.2-26.6% | 0%-0.7% | 0%-8.6% | 4.2%-48.1%; (excluding outlier: 4.2%-11.9%) | 0.4%-11.6%; (excluding outlier: 0.4% to 1.5%)
Urethra | 1 study^*^,^76^ | 8.6% | 0.2%-1.7% | 2.2%-11% | 2.7%-11.9% | 0.4%-1.1%
Urine | 5 studies^65,71,72,76,79^ | 6.2-26.6% | 0%-2.0% | 0%-16.1%; (excluding outlier: 0%-7.5%) | 2.1%-55.6%; (excluding outlier: 2.1%-27.7%) | 0.2%-13.2%; (excluding outlier: 0.2%-5.1%)
Vagina, clinician-collected | 3 studies^71,76,79^ | 6.2%-21.6% | 0%-1.2% | 0%-7.9% | 0%-44.4%; (excluding outlier: 0%-11.9%) | 0%-10.8%; (excluding outlier: 0%-1.0%)
Vagina, self-collected | 6 studies^65,71,72,76,77,79^ | 6.2-26.6% | 0%-1.0% | 0%-12.0% | 0%-48.1%; (excluding outlier: 0%-9.3%) | 0%-11.7%; (excluding outlier: 0%-4.8%)

* This study^76^ included results from three different tests

Abbreviations: NPV=negative predictive value; PPV=positive predictive value

Table 10 False Positive, False Alarm, False Negative, and False Reassurance Rates of Testing for Chlamydial Infection in Males

Anatomic site | Number of studies | Prevalence | False positive rate range; (1-specificity) | False alarm rate range; (1-PPV) | False negative rate range; (1-sensitivity) | False reassurance rate range; (1-NPV)
Meatal, self-collected | 1 study^61^ | 10.5% | 0.4% | 3.8% | 8.0% | 0.8%
Urine | 2 studies^61,71^ | 10.5% and 11.3% | 0.3% and 0.7% | 2.8% and 5.6% | 0% and 1.9% | 0% and 0.2%

Abbreviations: NPV=negative predictive value; PPV=positive predictive value

Table 11 False Positive, False Alarm, False Negative, and False Reassurance Rates of Testing for Gonococcal Infections in Females

Anatomic site | Number of studies | Prevalence | False positive rate range; (1-specificity) | False alarm rate range; (1-PPV) | False negative rate range; (1-sensitivity) | False reassurance rate range; (1-NPV)
Endocervix | 3 studies^65,71,80^ | 1.6%-11.7% | 0%-0.1% | 0%-6.1% | 2.1%-10.0% | 0%-0.2%
Urine | 1 study^71^ | 1.6% | 0.4 | 20.0% | 0 | 0%
Vagina, clinician-collected | 1 study^71^ | 11.7% | 0.3 | 14.0% | 0 | 0%
Vagina, self-collected | 3 studies^65,71,80^ | 1.6%-11.7% | 0%-0.6% | 0%-12% | 0%-2.0% | 0%-4.8%

Abbreviations: NPV=negative predictive value; PPV=positive predictive value

Table 12 False Positive, False Alarm, False Negative, and False Reassurance Rates of Testing for Gonococcal Infection in Males

Anatomic site | Number of studies | Prevalence | False positive rate range; (1-specificity) | False alarm rate range; (1-PPV) | False negative rate range; (1-sensitivity) | False reassurance rate range; (1-NPV)
Meatal, self-collected | 1 study^61^ | 4.2% | 0.3% | 10.6% | 0% | 0%
Urine | 2 studies^61,71^ | 1.5% and 4.2% | 0.2% and 0.7% | 7.1% and 30.0% | 0% and 7.1% | 0% and 0.2%

Abbreviations: NPV=negative predictive value; PPV=positive predictive value

#### Site-specific Testing

Across all anatomic sites, the false positive rates for chlamydia testing in females ranged from 0 to 2 percent in six studies and corresponding false alarm rates ranged from 0 to 16 percent (Table 9; Appendix B Tables 7, 8 and 9).^65,71,72,76,77^ By anatomic site, false positive rates were 0 to 0.7 percent for endocervical testing (false alarm rates 0 to 9%), 0 to 1.2 percent for vaginal testing (false alarm rates 0 to 12%), 0.2 to 1.7 percent for urethral testing (false alarm rates 2 to 11%) and 0 to 2 percent for urine testing (false alarm rates 0 to 16%). False negative rates ranged from 0 to 28 percent across sites in five of the studies (corresponding false reassurance rates ranged from 0 to 5%). One outlier study included in the prior report (see Key Question 3) reported higher false negative (range 44 to 56%) and false reassurance (range 11 to 13%) rates across anatomic sites;^79^ this study evaluated a high-prevalence population (22% chlamydia prevalence). Evidence of harms in males was limited to two studies that found false positive rates of 0.4 percent for meatal (false alarm rate 4%) and 0.3 to 0.7 percent for urine (false alarm rates 3 to 6%) testing, with false reassurance rates of <1 percent (Table 10; Appendix B Tables 7, 8 and 9).^61,71^

For gonorrhea testing, evidence was limited to three studies in females^65,71,80^ and two in males.^61,71^ (Tables 11 and 12; Appendix B Tables 7, 8 and 9). In females, false positive rates were <1 percent across sites (corresponding false alarm rates ranged from 0 to 20%); false negative rates ranged from 0 to 10 percent (false reassurance rates 0 to 5%).^65,71,80^ In males, false positive rates were similarly low (<1% across sites). False alarm rates were 7 to 30 percent, but false reassurance rates were very low (0 to 0.2%).^61,71^

#### Collection Methods

One new study^71^ and two studies from the prior report^76,79^ reported false negative rates for clinician- and self-collected vaginal samples for diagnosis of chlamydial infection in females (Table 9; Appendix B Tables 7, 8 and 9). Clinician-collected vaginal sample testing was associated with false positive rates ranging from 0 to 1.2 percent and corresponding false alarm rates that ranged from 0 to 8 percent. Rates were similar for self-collected samples (false positive rates 0 to 1%; false alarm rate range 0 to 12%). False negative and false reassurance rates were low for both collection methods in two studies (range 0 to 12% and 0 to 5%, respectively).^71,76^ The third, outlier study found higher false negative (44% for clinician- and 48% for self-collected specimens) and false reassurance rates (11% for clinician- and 12% for self-collected).^79^ One study directly compared the accuracy of clinician versus self-collected vaginal samples for gonorrhea in females and found a 0.3 percent false positive rate (false alarm rate 14%) with clinician-collected samples and 0 percent false positive and false alarm rate for self-collected samples. (Table 11; Appendix B Tables 7, 8 and 9).^71^ False reassurance rates were 0 percent for both collection methods in this study.

No studies reported the accuracy of clinician- versus self-collected methods for chlamydia or gonorrhea in males.

#### Other Harms of Screening

There were no studies of psychosocial harms, such as anxiety, related to testing that met criteria for this or the prior review, and no studies of risk behaviors or risk perception.

## Contextual Questions

### Contextual Question 1 What Is the Prevalence Rate of Chlamydial or Gonococcal Infections (and Concurrent HIV Infection) in Partners of Patients Who Test Positive for Chlamydial or Gonococcal Infections?

Three studies reported prevalence rates in partners of patients who test positive for infection. Two studies reported prevalence rates for chlamydia^88,89^ and one study for gonorrhea.^90^ Chlamydia rates ranged from 27 to 39 percent in male partners of infected women in a small study^88^ that compared home sampling versus conventional contact tracing. The study did not report the percentage of asymptomatic patients, but aimed to assess whether the test rate of partners could be increased by having male contacts of infected women send a urine sample directly from home compared with a urethral swab obtained in a clinical setting. Contact tracing results were reported as the percentage of partners who were examined in each group.

A prospective study of cervical chlamydia positive heterosexual women who were asymptomatic or had mild symptoms were followed to assess concurrent rectal chlamydia also assessed partner prevalence.^89^ The prevalence of infections in index cases was similar regardless of whether the partner had rectal chlamydia or not. An observational study conducted in Australia reported the prevalence of antibiotic resistant gonorrhea in partners of infected patients using pharyngeal and rectal swabs for asymptomatic MSM.^90^ Thirty-four of 458 partners (7.4%) simultaneously tested from a large prospective cohort were positive for gonorrhea.

### Contextual Question 2 What Is the Effectiveness of Partner Services (Such as Traditional Partner Services or Expedited Partner Therapy)?

Three studies addressed partner services, including expedited partner therapy, in reducing rates of reinfection or acquisition of chlamydial or gonococcal infections in the index patient.^91–93^ Types of partner services addressed in the studies included partner notification, a process by which sexual partners of patients diagnosed with a sexually transmitted infection are informed or notified of their exposure and the need to receive treatment; expedited partner therapy (EPT), in which there is facilitated access to antibiotic treatment or a prescription for medication by the index patient to their partner(s) without the need for a medical exam or evaluation of the partner; and expedited partner notification, when a clinician provides the index patient with antibiotics or a prescription to give to the sex partner.

A systematic review commissioned by the Cochrane collaborative reviewed the effect of strategies of partner notification in persons with sexually transmitted infections.^93^ Expedited partner therapy was compared with simple patient referral (control) with regard to effects on rates of re-infection of the index patient. When combining trials of STI causing urethritis or cervicitis, expedited partner therapy was associated with decreased risk of re-infection of the index patient versus simple patient referral, but was not associated with decreased risk versus enhanced patient referral, in which additional support was given to enhance outcomes. In three trials, expedited partner therapy and enhanced patient referral were associated with similar levels of repeat infection (RR 0.96; 95% CI, 0.60 to 1.53).

Another systematic review evaluated different methods of partner notification on rates of reinfection of the index patient.^91^ There were four randomized controlled trials of partner notification interventions that compared the effectiveness of expedited partner notification with simple patient referral that included verbal advice from the partner (attention-control) on the rate of index patient reinfection with gonorrhea or chlamydia. Expedited partner notification was defined as a doctor providing the index patient with antibiotics or a prescription to give to the sex partner for preventing index reinfection. Effects of expedited partner notification versus simple patient referral appeared smaller in trials that included only women with chlamydia (RR 0.90, 95% CI, 0.60 to 1.35) than in trials that included patients with either gonorrhea or chlamydia (RR 0.61, 95% CI, 0.39 to 0.94).

A pilot RCT of partner notification models in community settings evaluated the effect of accelerated partner therapy (APT), the U.K adaptation of EPT, for partner notification.^92^ APT conforms to U.K. prescribing regulations but is otherwise identical to EPT. One hundred ninety-nine women reported 339 male partners, of whom 313 were contactable. The primary outcome was whether each contactable partner was treated within 6 weeks of the index partner’s diagnosis. Rates of reinfection or persistence of infection in the index patient was reported as a secondary outcome. APT was offered using three different methods, implemented in three different arms of the intervention, as pharmacy notification (community pharmacist assessment of partners plus routine PN) or hotline (telephone assessment of partners plus standard partner notification) versus standard partner notification alone (control). Only 38/199 (19%) index patients returned a postal urine sample for reinfection or persistence and chlamydia positivity was 15 percent (2/13) in the standard arm, 0 percent in the hotline arm, and 10 percent (1/10) in the pharmacy arm.