# Chapter 2 Methods

## Key Questions and Analytic Framework

Using methods developed by the USPSTF^57^ the Evidence-based Practice Center (EPC) developed the scope and Key Questions in collaboration with the USPSTF and Agency for Healthcare Research and Quality (AHRQ). Investigators created an analytic framework with the key questions and the patient populations, interventions, outcomes, and adverse effects reviewed (Figure 1).

Figure 1 Analytic Framework

Note: Numbers in the figure correspond to the Key Question number.

Key Questions

1. In asymptomatic, sexually active adults and adolescents, including those who are pregnant, what is the effectiveness of screening for chlamydial and gonococcal infections in reducing complications of infection and transmission or acquisition of disease, including gonorrhea, chlamydia, and HIV?
2. What is the accuracy of risk stratification methods or alternative screening strategies for identifying persons at increased risk of chlamydial and gonococcal infections (such as younger persons or men who have sex with men)? Screening strategies include testing for concurrent infections, including HIV, or using different screening intervals.
3. What is the diagnostic accuracy of anatomic site-specific testing and collection methods for identifying persons with chlamydial and gonococcal infections?
4. What are the harms of screening for chlamydial and gonococcal infections (such as labeling, anxiety, false-positive/alarm results, false-negative results/reassurance, or change in risk behaviors or risk perception)?

Figure 1 is the analytic framework (AF). The AF depicts the relationship between the populations, interventions, outcomes, and harms of screening for chlamydia and gonorrhea infections. The far left of the framework describes the target population as asymptomatic adults and adolescents, including pregnant persons. To the right of the population is an arrow that represents chlamydia and gonorrhea screening, including screening strategies (key question 2) and anatomic site-specific testing and collection methods (key question 3), that leads to the population with chlamydial and gonococcal infection. An arrow below key questions 2 and 3 represents harms or adverse effects of screening for chlamydia and gonorrhea (key question 4). To the right of the population with chlamydial and gonorrheal infection a dotted line arrow represents treatment and leads to three clinical health outcomes: including reduced complications of chlamydial or gonococcal infection; reduced transmission or acquisition of disease; and reduced adverse maternal, fetal or infant outcomes. The clinical health outcome of reduced transmission or acquisition of disease is an intermediate outcome as noted by the rounded edges of the box. A dotted line arrow below reduced transmission or acquisition of disease is used to depict an association with reduced adverse maternal, fetal, or infant outcomes. Arrows with dotted lines acknowledge the relationship between infection and outcomes, but will not be directly addressed in this systematic review. An overarching arrow that extends from the screened population of asymptomatic adults and adolescents, including pregnant persons to the clinical health outcomes symbolizes the effectiveness of screening on clinical health outcomes (key question 1).

Key differences between this report and the prior reviews are using one framework for all populations; evaluating accuracy of risk stratification and screening strategies for identifying persons at increased risk; diagnostic accuracy of anatomic site-specific testing and collection methods. We did not re-review the diagnostic accuracy of specific assays or tests, which the prior review found to be highly accurate.^58^ This report addresses four Key Questions on the effectiveness of screening for chlamydial and gonococcal infections. The populations addressed were asymptomatic adults and adolescents, including those who are pregnant.

### Key Questions

1. In asymptomatic, sexually active adults and adolescents, including those who are pregnant, what is the effectiveness of screening for chlamydial and gonococcal infections in reducing complications of infection and transmission or acquisition of disease, including gonorrhea, chlamydia, and HIV?
2. What is the accuracy of risk stratification methods or alternative screening strategies for identifying persons at increased risk of chlamydial and gonococcal infections (such as younger persons or men who have sex with men)? Screening strategies include testing for concurrent infections, including HIV, or using different screening intervals.
3. What is the diagnostic accuracy of anatomic site-specific testing and collection methods for identifying persons with chlamydial and gonococcal infections?
4. What are the harms of screening for chlamydial and gonococcal infections (such as labeling, anxiety, false-positive/alarm results, false-negative results/reassurance, or change in risk behaviors or risk perception)?

Key Question 1 focuses on the effectiveness of screening on clinical outcomes including complications of infection, transmission, or acquisition of disease. Key Question 2 evaluates the accuracy of risk stratification methods or alternative screening strategies for increased risk populations, including testing for concurrent sexually transmitted infections or using different screening intervals. Key Question 3 examines the diagnostic accuracy of anatomic site-specific testing and collection methods, including self-collected swabs. Key Question 4 addresses the harms of screening. The USPSTF previously determined that treatment is effective; therefore, there was no Key Question on the effectiveness of treatment.

### Contextual Questions

The USPSTF also requested Contextual Questions to help inform the report. Contextual Questions are not reviewed using systematic review methodology.

1. What is the prevalence rate of chlamydial or gonococcal infections (and concurrent HIV infection) in partners of patients who test positive for chlamydial or gonococcal infections?
2. What is the effectiveness of partner services (such as traditional partner services or expedited partner therapy) in reducing rates of reinfection or acquisition of chlamydial and gonococcal infections in the index patient?

## Search Strategies

We searched the Cochrane Database of Systematic Reviews (January 2014 through May 2020), Cochrane Central Register of Controlled Trials, PsycINFO, Ovid MEDLINE In-Process & Other Non-Indexed Citations (January 2014 through May 2020), and Ovid MEDLINE (January 2014 through May 2020) for relevant English-language studies and systematic reviews. Search strategies are available in Appendix A1. Electronic searches were supplemented by review of reference lists of relevant articles and studies meeting inclusion criteria. We also carried forward studies in the prior USPSTF report^58^ that met inclusion criteria for this update. Ongoing surveillance was conducted to identify major studies published since May 2020 that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on May 21, 2021, and identified no studies affecting review conclusions.

## Study Selection

Two reviewers independently evaluated each study to determine inclusion based on predetermined eligibility criteria developed for each Key Question (Appendix A2). After an initial dual review of citations and abstracts, investigators retrieved full-text articles of potentially relevant material. Two reviewers conducted full-text review of articles; discrepancies were resolved through consensus or with input from a third reviewer. The selection of studies is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists included studies and Appendix A5 lists studies excluded at the full-text level with reasons for exclusion.

The target population was asymptomatic, sexually active adults and adolescents, including those who are pregnant. For screening effectiveness and harms, we included randomized controlled trials (RCT) and controlled observational studies of screening versus no screening in asymptomatic individuals that evaluated health outcomes. Outcomes for KQ1 included reduced complications of chlamydial or gonococcal infections and reduced transmission or acquisition of disease, including gonorrhea, chlamydia, and HIV; and for pregnant individuals, reduced adverse maternal, fetal, or infant outcomes. Studies on risk stratification methods and screening strategies for chlamydia and gonorrhea that reported measures of diagnostic accuracy or discrimination were included for KQ2. For KQ3, we included studies on the diagnostic accuracy (including measures of discrimination) of testing at various anatomic sites or using different collection methods (self- versus clinician- collected). Studies that did not report diagnostic accuracy but provided data to calculate them were also included. For studies of diagnostic accuracy, samples were reported as collected from male or female anatomic sites. This differs from the remainder of the included studies that reported outcomes according to populations of men and women. For KQ4, false alarm rates (the proportion of patients with a positive test who do not have the disease) and false reassurance rates (the proportion of patients with a negative test who actually have the disease) were calculated from the positive predictive value and negative predictive value, respectively, when population prevalence was reported.^59^ False positive and false negative results were also reported. For KQ4, uncontrolled observational studies were also included for the adverse effects of screening.

## Data Abstraction and Quality Rating

We constructed evidence tables summarizing the data from each study. One investigator abstracted details about the study design, patient population, setting, interventions, analysis, followup, and results. A second investigator reviewed data abstraction for accuracy. Two investigators independently applied predefined criteria developed by the USPSTF (Appendix A6) to rate the quality of individual controlled trials, systematic reviews, and observational studies and rate them as “good,” “fair,” or “poor,” depending on the extent of methodological shortcomings.^57^ We modified the cohort criteria for cross-sectional studies. Discrepancies were resolved through consensus. In accordance with USPSTF procedures, we excluded studies rated poor quality due to important methodological shortcomings that severely undermine their reliability.^57^

## Data Synthesis

We assessed the aggregate internal validity (quality) of the body of evidence for each KQ (“good”, “fair”, “poor”) using methods developed by the USPSTF, based on the number, quality and size of studies, consistency of results between studies, and directness of evidence in the Summary of Evidence.^57^ We determined aggregate internal validity using the totality of evidence (new studies identified for the update plus studies carried forward from the prior USPSTF report).^60^ Statistical meta-analysis was not performed because of methodological limitations of the studies and heterogeneity in study designs, interventions, populations, and other factors.

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF website for public comment from February 7, 2019 to March 6, 2019, and was revised in response to public comments prior to finalization. Revisions included clarification of the populations and risk behaviors addressed, the reference standard for diagnostic accuracy, and terminology regarding anatomic site-specific testing.

The draft report was reviewed by content experts (Appendix A7), USPSTF members, Agency for Healthcare Research and Quality (AHRQ) Medical Officers, and collaborative partners. Reviewer comments were presented to the USPSTF during its deliberations and have been incorporated into the final report. Additionally, a draft version of this report was posted for public comment from March 2, 2021 to March 29, 2021. In response, we revised some of the background, references, and discussion. No substantive changes were necessary.