# Chapter 1 Introduction and Background

## Purpose

This systematic review will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2014 recommendation on screening for chlamydia and gonorrhea infections in sexually active adolescents and adults, including pregnant women.^1^

In 2014, the USPSTF made two separate recommendations for screening for chlamydia (B recommendation) and gonorrhea (B recommendation) in sexually active women aged 24 years or younger and in older women who are at increased risk for infection. These recommendations were based on evidence that screening for chlamydia reduces risk of complications in women at increased risk; evidence that screening for gonorrhea identifies asymptomatic infections and treatment reduces complications associated with untreated asymptomatic infections; and evidence that age was a strong predictor of chlamydial and gonococcal infections, with the highest infection rates occurring in women under 24 years. The USPSTF concluded that the evidence was insufficient to assess the balance of benefits and harms of screening for chlamydia and gonorrhea in men (I statement) due to the absence of evidence that screening in men improves clinical outcomes or reduces disease transmission to sexual partners.

Prior to 2014, the USPSTF issued a separate recommendation on chlamydia and gonorrhea screening. The 2007 USPSTF recommendation on chlamydia screening was similar to the 2014 recommendation, except that it was graded an A recommendation.^2^ The USPSTF also recommended against screening for chlamydia in women aged 25 years or older not at increased risk and found insufficient evidence to recommend routine screening for chlamydia in men. In 2005, the USPSTF recommended screening for gonorrhea in all sexually active women at increased risk for infection, including pregnant women (B recommendation).^3^

## Condition Background

### Condition Definition

Chlamydia is a sexually transmitted infection (STI) caused by the bacterium Chlamydia trachomatis. Most Chlamydia trachomatis strains infect the columnar epithelial cells of the genital tract, causing inflammation that may be asymptomatic or present as signs of infection such as erythema, edema, and mucopurulent discharge.^4^ Infections of the rectum can cause proctitis, while infections of the oropharynx are typically asymptomatic. Inflammation can damage the epithelium and lead to scar formation. In women, scarring may ultimately lead to fallopian tube damage, which is irreversible, and can lead to infertility years after active infection. If left untreated, chlamydia can lead to the same long-term health effects as gonorrhea, including pelvic inflammatory disease (PID), which can lead to complications such as ectopic pregnancy, infertility, and chronic pelvic pain.^5,6^ Infants born to infected mothers may contract chlamydial eye disease or pneumonia.^4,7^

Gonorrhea is a STI caused by the bacterium Neisseria gonorrhoeae, a gram-negative intracellular diplococcus that infects the mucosal epithelium of the genital tract.^8,9^ Other sites of infection include the conjunctiva, oropharynx, and rectum. Infection often leads to local inflammation and, in women, N. gonorrhoeae can ascend the urogenital tract and can also cause PID.^9^ Infants born to infected mothers may contract ophthalmia neonatorum in the first four weeks of life.^6,10^

### Prevalence and Burden of Disease/Illness

Chlamydia is the most commonly reported STI in the United States (U.S.). In 2019, there were 1,808,703 cases of chlamydial infection reported to the Centers for Disease Control and Prevention (CDC), corresponding to a rate of 552.8 cases per 100,000 persons.^11^ Due to under-reporting, the true incidence of chlamydial cases is difficult to accurately estimate. Since the 1980s, the rate of reported chlamydial infection has been rising. This increase is likely related to a combination of enhanced screening efforts, the use of more sensitive tests, and more complete reporting, although it may also reflect a true increase in incidence. In 2019, the rate of chlamydial infection among U.S. women (698.9 cases per 100,000 females) was nearly double the rate among men (399.9 cases per 100,000 males) with the majority of reported cases occurring among women aged 15 to 24 years (3,728.1 per 100,000). From 2018-19, increased rates were observed in females 15-19 year of age (0.8% increase) and 20-24 years of age (0.2% increase). The rate among males increased 5.3 percent between 2018-2019, possibly due to either increased transmission or improved case identification among men who have sex with men (MSM).^11^ Increased rates in men also correspond to the increased availability of urine testing and extragenital screening. Males 15 to 44 years of age comprised 93 percent of male chlamydia cases in 2019.^11^ Within these populations, prevalence varies by geography, race/ethnicity, and HIV status.^11^

During 2013 to 2019, rates of reported chlamydia cases increased among all racial and Hispanic/Latino ethnicity groups. Chlamydia incidence varies by race, with rates 5.9 times higher in Black compared with White persons.^11^ In 2019, the rate of chlamydial infection reported among Black persons was more than five times the rate among White persons (1,233.2 and 209.7 cases per 100,000 population, respectively) and the rate among Hispanic/Latino persons (387.3 cases per 100,000) was nearly two times the rate among White persons.^11^ High rates were also reported for American Indians/Alaska Natives (760.0 per 100,000) and Native Hawaiians/Other Pacific Islanders (733.4 per 100,000), while lower rates were reported among those identifying as Asian (128.4 per 100,000) or multirace (231.0 per 100,000). Data from the 2007 to 2012 National Health and Nutrition Examination Survey also demonstrates disparities.^12^

Gonorrhea is the second most commonly reported STI in the U.S., though it is also underreported. In 2019, 616,392 cases were reported to the CDC, corresponding to a rate of 188.4 cases per 100,000 persons, a 5.7 percent increase during 2018-2019.^11^ The rate of increase in gonorrhea cases was 5.9 percent for males during 2018-2019 (211.9 to 224.4 per 100,000) and 5.1 percent increase for females (145.2 to 152.6 cases per 100,000). In 2019, the highest rates of infection were among females aged 20 to 24 years (737.4 cases per 100,000), females 15-19 years (559.5 cases per 100,000), males aged 20 to 24 years (743.5 per 100,000) and males 25-29 years (700.6 per 100,000). Black and Hispanic/Latino persons also had higher rates of gonococcal infection (581.0 and 118.3 per 100,000 population, respectively) than White persons (73.9 per 100,000 population). In 2019, rates of infection in Black persons were 7.9 times the infection rate in Whites.^11^ From 2015 to 2019 the rate of gonorrhea among males increased 62.3 percent (139.7 to 224.4 cases per 100,000), possibly related to increased transmission and/or case ascertainment among MSM.

#### Pregnancy

Untreated chlamydial infection in pregnancy is associated with complications including preterm labor, premature rupture of membranes, and low birth weight.^13^ Infants born to mothers infected with either chlamydial or gonococcal infection are at risk of neonatal conjunctivitis and in the case of chlamydial infection, neonatal pneumonia.^4,7,14^ The risk of vertical transmission of gonorrhea is between 30 and 47 percent in the absence of ocular prophylaxis.^15^ Rates of gonococcal ophthalmia neonatorum in the U.S. was an estimated 0.4 cases per 100,000 live births per year from 2013 to 2017.^6^ Gonococcal ophthalmia neonatorum can cause corneal scarring, ocular perforation, and blindness as early as 24 hours after birth.^16^ The USPSTF addresses ocular prophylaxis for gonococcal ophthalmia neonatorum in a separate recommendation and reaffirmed its recommendation for ocular prophylaxis in 2019 (A recommendation).^17^

### Etiology and Natural History

In women, chlamydial infection is usually asymptomatic, but can result in transmission and can lead to cervicitis and urethritis.^5^ Untreated chlamydial infections may progress to symptomatic PID, which can subsequently result in infertility, chronic pelvic pain, and ectopic pregnancy.^5,6^ However, many women with PID have subtle signs and symptoms, leading to clinically silent spread of infection to the upper genital tract and subsequent subclinical pelvic inflammatory disease.^18,19^ Chlamydial infection can also facilitate infection with HIV and may potentiate the risk for cervical cancer.^20,21^

In men, genital chlamydial infection is also likely to be asymptomatic but if symptoms do appear, the most common presentation is urethritis.^22^ Other symptoms include non-gonococcal urethritis, epididymitis, and in rare instances, reactive arthritis may occur.^22,23,24^ Chlamydial infection in men also facilitates HIV transmission^25,26^ and can be an etiologic agent of asymptomatic infection of the rectum.^27^

As with chlamydial infection, women infected with gonorrhea are often asymptomatic, but infection can result in cervicitis and complications including PID, ectopic pregnancy, infertility, and chronic pelvic pain.^6^ In men, gonorrhea can lead to symptomatic urethritis, epididymitis, and proctitis.^23,28^ The majority of urethral infections among males are symptomatic, leading to timely treatment that prevents serious complications, but not transmission to others.^29^ However, the overwhelming majority of extragenital (e.g., pharyngeal, rectal) infections in men are asymptomatic. Rarely, local gonococcal infection may disseminate and cause acute dermatitis tenosynovitis syndrome, monoarticular arthritis, meningitis, or endocarditis.^8,30^ Gonococcal infection facilitates HIV transmission in both men and women.^20^

### Risk Factors

Age is a strong risk factor for both chlamydia and gonorrhea. In 2019, the highest age-specific rates of chlamydial infection among women and men occurred in the 20 to 24 year age category (4,109.5 cases per 100,000 females; 1,871.5 cases per 100,000 males), followed by women aged 15 to 19 years (3,333.8 cases per 100,000 females).^11^ In 2019, rates of gonococcal infection reported to the CDC were also highest among women and men aged 20 to 24 years (737.4 cases per 100,000 females; 743.5 cases per 100,000 males), followed by women aged 15 to 19 years (559.5 cases per 100,000 population).^11^ During 2018 to 2019, the largest increase in gonococcal infection was among individuals aged 40 to 44 years (11.3 percent increase).

Other risk factors associated with chlamydial and gonococcal infection include having multiple sexual partners, having a new sexual partner or a sexual partner infected with an STI, inconsistently using barrier contraceptives, and having a history of previous or coexisting STIs.^11^ In a 2018 study of STI clinic attendees, MSM had higher reported prevalence rates of chlamydial and gonococcal infections than other clinic attendees, with median prevalence rates of 16.9 and 20.5 percent.^11^ A 2017 survey of MSM attending community clinics in five cities reported that approximately one in eight had an extragenital chlamydial or gonococcal infection.^31^ Rectal gonorrhea prevalence was higher in MSM infected with HIV than in those not infected with HIV. Notably, chlamydia and gonorrhea at extragenital (rectal and pharyngeal) anatomic sites are often asymptomatic, and these anatomic sites may act as a reservoir of infection, thus affecting gonococcal antimicrobial resistance, and increased risk for HIV transmission and acquisition. One study suggests 70 to 85 percent of infections would be missed with urethral screening alone.^32^ A systematic review of prevalence studies conducted in MSM estimated rectal chlamydia and gonorrhea prevalence among MSM as 9.0% and 6.1%, respectively.^33^ Epidemiologic data supports the prevalence of extragenital infection in women, which may also present an opportunity for ongoing transmission.^34–36^

### Rationale for Screening/Screening Strategies

Both chlamydial and gonococcal infections are often asymptomatic in women and can lead to serious complications, including PID and associated sequelae.^11^ Pregnant women with these infections are at risk of transmitting them to their infants. The risk of vertical transmission of gonorrhea during pregnancy is between 30 and 47 percent.^15^ Specific populations of men, particularly young men and MSM, have a higher burden of infection with chlamydia and may be at higher risk for gonococcal infection, many of which are often asymptomatic.^37^ Among MSM, rectal chlamydial and gonococcal infections, especially those that are recurrent, have been associated with increased risk for HIV infection.^38^ Screening asymptomatic MSM for infection could help to identify those men at high risk for HIV acquisition and lead to consideration of PrEP.^39^

Identification of asymptomatic individuals with chlamydia or gonorrhea through screening could identify those who would benefit from earlier evaluation and management. Screening could also lead to interventions to decrease transmission, and identify close contacts who might benefit from testing.

### Intervention/Treatment

The CDC recommends seven days of doxycycline as treatment for chlamydial infections in non-pregnant adolescents and adults as a first line regimen.^29,40^ Alternative regimens include a single dose of azithromycin or levofloxacin for seven days, but treatment failure among men is noted to be higher for azithromycin compared with doxycycline^41^ and questions remain about the effectiveness of azithromycin for treating rectal infections in both men and women.^29^ For patients in whom compliance or loss to followup is a concern, direct observation of a single dose of azithromycin is recommended. In recent years, treatment of gonococcal infection has been complicated by increasing drug resistance to N. gonorrhoeae. Consequently, the CDC now recommends a single 500mg intramuscular dose of ceftriaxone for uncomplicated urogenital, anorectal, and pharyngeal gonorrhea for persons weighing less than 150kg, and 1g ceftriaxone for those weighing over 150kg.^29,42^ Treatment for chlamydial coinfection with oral doxycycline (100mg twice daily for 7 days) should occur when chlamydial infection cannot be excluded.^42^

The CDC recommends that all sex partners of patients with either gonococcal or chlamydial infection exposed in the preceding 60 days undergo evaluation and treatment for infection.^29^ In the case of a sex partner that cannot be linked to care, expedited partner therapy (EPT) given by the patient is suggested.^29^ EPT is the clinical practice of treating sex partners of persons who receive gonorrhea or chlamydia diagnoses by providing medications or prescriptions to the patient, unless prohibited by law, and is recommended for heterosexual partners for both infections. Patients provide partners with these therapies without the examination of the partner by a health-care provider. Rescreening all patients diagnosed with chlamydial or gonococcal infection three months after treatment is recommended due to risk of re-infection, regardless of whether the index patient believes that sex partners were successfully treated.^29^

#### Pregnancy

The CDC recommends using azithromycin as the treatment of choice for pregnant women infected with chlamydia. The CDC also recommends repeat testing to document eradication of chlamydial infection four weeks post-treatment.^29^ Prevention of chlamydial neonatal pneumonia requires treating maternal chlamydial infection during pregnancy via prenatal detection and treatment. Gonorrhea is treated with a single 500mg intramuscular dose of ceftriaxone.^42^ The risk of neonatal ophthalmia due to maternal gonococcal infection can be reduced with routine topical prophylaxis at delivery. Pregnant women diagnosed with either infection should have repeat testing three months after treatment (or at the third trimester or within three months of delivery).^29^

### Current Clinical Practice/Recommendations of Other Groups

Screening for Neisseria gonorrhoeae and Chlamydia trachomatis is usually performed by testing urine or urogenital swab specimens from the endocervix, vagina, or male urethra.^43^ Extragenital testing allows for test samples obtained from other sites, including the oropharynx and rectum, and has been cleared by the FDA.^43,44^ Rectal swabs can be used to detect infection in persons who engage in receptive anal intercourse, and self-collected vaginal swabs are also available. Nucleic acid amplification test (NAAT) is the preferred diagnostic test for chlamydia because of its high sensitivity and specificity and its use on specimens obtained noninvasively (using vaginal or urine specimens).^45^ The CDC and the USPSTF both support the use of NAAT to detect chlamydial and gonococcal infections and NAAT is FDA-approved for this purpose.^29,46^

The CDC recommends the use of NAAT to diagnose genitourinary gonococcal infection because NAAT permits testing on the widest variety of specimens, including endocervical, vaginal, rectal, oral, and male urethral swabs, as well as urine samples. NAATs are also FDA-approved for this purpose.^29^ Neisseria gonorrhoeae can be diagnosed from a culture or Gram stain of the male urethra showing intracellular Gram-negative diplococci. However, a negative Gram stain does not rule out gonococcal infection, due to lower sensitivity than NAAT in asymptomatic males.^47^

The CDC screening recommendations for screening for chlamydia and gonorrhea in young women align with the USPSTF.^29^ The CDC recommends screening for all women age 24 years and younger, and targeted screening in women age 25 and older who are at increased risk of infection. The CDC also recommends screening MSM for both chlamydia and gonorrhea at least annually at sites of sexual contact regardless of condom use.^29^ Furthermore, the CDC recommends screening women up to age 35 years for chlamydia and gonorrhea at intake in juvenile and adult correctional facilities, as well as screening men up to age 30 years for chlamydia and gonorrhea at intake into jails.^29^ Recommendations from other medical organizations (Table 1) are consistent with the CDC or USPSTF recommendations.^29,48–55^ The CDC also makes a recommendation to consider screening young men in high prevalence clinical settings or in populations with a high burden of infection (MSM).^29^

Table 1 Screening Recommendations of Other Groups

Organization, year | Recommendations
Centers for Disease Control and Prevention, 2015^29^ | Recommends annual screening for chlamydial and gonococcal infections in all sexually active women younger than 25 and in older women with specific risk factors (a new sex partner or multiple sex partners), per USPSTF. The CDC also recommends screening MSM at least annually, and recommends more frequent screening of MSM with multiple or anonymous partners. Clinical settings with a high prevalence of chlamydia should consider screening sexually active young men. Furthermore, CDC recommends screening women younger than 35 at intake in juvenile and adult correctional facilities and screening men up to age 30 at intake into jails.
American College of Obstetricians and Gynecologists, 2016^48^ | Recommends annual screening for C. trachomatis in all sexually active females aged 25 or younger and in older women with risk factors. Recommends chlamydial screening in all pregnant women in early pregnancy and repeat testing in the third trimester for women with risk factors. Recommends screening for gonorrhea in women younger than 25 years and for women 25 years and older with risk factors, and in pregnant females 25 years or younger or for those living in an area where gonorrhea is common.
American Medical Association, 2009^49^ | Follow CDC recommendations.
American Academy of Pediatricians, 2011^50^ | Follow CDC recommendations
American Academy of Family Physicians, 2016^51^ | Follow USPSTF recommendations.
American College of Physicians, 2015^52^ | Follows USPSTF screening recommendations for chlamydial infections.
Public Health Agency of Canada^53–55^ | Recommends annual screening for C. trachomatis and N. Gonorrhoeae in all sexually active persons under the age of 25 with retesting after 3 months in infected patients or based on continued risk factors. Risk-based screening is recommended for those 25 years and older. Recommends screening for chlamydia and gonorrhea at the first prenatal visit and again during pregnancy based on risk factors.

Abbreviations: ACOG = American College of Obstetricians and Gynecologists; CDC = Centers for Disease Control and Prevention; MSM= men who have sex with men

The CDC recommends screening all pregnant women up to age 25 years, and older women at increased risk for chlamydial and gonococcal infection at their first prenatal visit.^29^ Third trimester screening for chlamydial and gonococcal infections is recommended for women who are at high risk for re-infection to prevent postnatal complications and infection of the neonate.

Despite current screening recommendations to screen high-risk persons for chlamydial and gonococcal infection, screening rates are suboptimal. In a review of the healthcare claims of patients presenting for general medical or gynecological examinations, rates of documentation for testing were minimal, regardless of high-risk sexual behavior status. Among patients claiming high-risk sexual behaviors, 21 to 60 percent were tested for chlamydial infection and 21 to 56 percent were tested for gonococcal infection.^56^