# Appendix C Additional Tables

## Appendix C Selective Screening Criteria for Chlamydial Infection as Described in Miller, 2000

Source: Miller WC, Hoffman IF, Owen-O’Dowd J, . Selective screening for chlamydial infection: which criteria to use? Am J Prev Med. 2000 Feb;18(2):115–22. PMID:1069824110698241 .

### CDC Recommendations

Indications for screening:

Mucopurulent discharge

Age < 20 years

Age 20–24 years with 1 risk marker

Age > 24 years with 2 risk markers

Risk markers:

No or inconsistent condom use

New sex partner or ≥ 2 sex partners in past 3 months

### Seattle–1

Any 2 risk markers:

Age ≤ 24 years

No condom use

New sex partner in past 3 months

Cervical friability

Mucopurulent discharge

### Wisconsin

Any 1 risk marker:

New sex partner in past 3 months

≥2 sex partners in past 3 months

Partner with STD

Cervical friability

Mucopurulent discharge

PID

Gonorrheal infection

### Ontario

Any 1 risk marker:

New sex partner in past year

Urinary frequency

Bleeding

Cervical friability

Mucopurulent discharge

Genital warts

### California–1

Any 2 risk markers:

Age ≤ 24 years

Unmarried

No condom use

New sex partner in past 3 months

Cervical friability

### California–2

Any 1 risk marker:

Age ≤ 24 years

Unmarried

Cervicitis (mucopurulent discharge, cervical friability, PID)

### Seattle–2

Sum≥4 points:

1 point – Age ≤ 24 years

2 points – Unmarried

1 point – African-American

1 point – Nulliparous

1 point – ≥ 2 sex partners in past year

1 point – Vaginal douche in past year

2 point – Cervical ectopy

### Seattle–3

Sum ≥ 3 points:

1 point – Age ≤ 24 years

2 points – African-American

1 point – Nulliparous

1 point – ≥ 2 sex partners in past year

1 point – Vaginal douche in past year