# Appendix B Evidence Tables and Quality Tables

Appendix B Table 1 Evidence Table: Effectiveness of Screening to Reduce Complications and Transmission—Study Characteristics

Appendix B Table 2 Evidence Table: Effectiveness of Screening to Reduce Complications and Transmission—Study Outcomes

Appendix B Table 3 Quality Assessment of Studies of Effectiveness of Screening to Reduce Complications and Transmission

Appendix B Table 4 Evidence Table: Accuracy of Risk Stratification Methods or Screening Strategies—Study Characteristics

Appendix B Table 5 Evidence Table: Accuracy of Risk Stratification Methods—Study Outcomes

Appendix B Table 6 Quality Assessment of Studies of Risk Stratification Methods or Screening Strategies—Cohort Studies

Appendix B Table 7 Evidence Table: Diagnostic Accuracy of Anatomic Site-Specific Testing—Study Characteristics

Appendix B Table 8 Evidence Table: Diagnostic Accuracy of Anatomic Site-Specific Testing—Study Outcomes Part 1

Appendix B Table 9 Evidence Table: Diagnostic Accuracy Studies of Anatomic Site-Specific Testing—Study Outcomes, Part 2

Appendix B Table 10 Quality Assessment of Diagnostic Accuracy Studies of Anatomic Site-Specific Testing